# Appendix H: Sensitivity and Specificity of Comparison Tests that Used SIC as a Reference Standard

Table H-1: High molecular weight asthmagens

Table H-2: Low molecular weight asthmagens

Table H-3: Mixed/unknown asthmagens

Table H-1 High molecular weight asthmagens

Comparison Test | Number of Studies | Pooled Sensitivity (95% CI) | | Pooled Specificity (95% CI)
NSBP test | 10 | 79.3 | (67.7, 87.6) | 51.3 | (35.2, 67.2)
Specific skin prick test | 16 | 80.6 | (69.8, 88.1) | 59.6 | (41.7, 75.3)
Specific IgE | 9 | 73.3 | (63.9, 81.0) | 79.0 | (50.5, 93.3)
NSBP test combined with
Specific skin prick test | 4 | 60.6 | (21.0, 89.9) | 82.5 | (54.0, 95.0)
Specific IgE | 2 | 35.6 | (1.2, 96.1) | 84.6 | (48.2, 97.0)
Specific skin prick test and specific IgE | 3 | 65.2 | (6.7, 98.0) | 74.3 | (45.0, 91.0)
Specific skin prick test or specific IgE | 3 | 60.4 | (11.8, 94.5) | 81.5 | (47.8, 95.5)
Serial NSBP test | 1 | 100 | (34.2, 100) | 100 | (20.7, 100)
Clinical diagnosis | 2 | 93.7 | (69.3, 99.0) | 32.3 | (7.5, 73.8)

Table H-2. Low molecular weight asthmagens

Comparison Test | Number of Studies | Pooled Sensitivity (95% CI) | | Pooled Specificity (95% CI)
NSBP test | 24 | 66.7 | (58.4, 74.0) | 63.9 | (56.1, 71.0)
Specific skin prick test | 5 | 72.9 | (59.7, 83.0) | 86.2 | (77.4, 91.9)
Specific IgE | 11 | 31.2 | (22.9, 40.8) | 88.9 | (84.7, 92.1)
NSBP test combined with
Specific skin prick test | 1 | 100 | (74.1, 100) | 80.0 | (49.0, 94.3)
Specific IgE | 1 | 0 | (0, 49.0) | 100 | (61.0, 100)
Serial NSBP test | 2 | 67.5 | (42.6, 85.3) | 65.6 | (41.1, 84.0)
Serial PFT (usually PEFR) | 1 | 86.7 | (59.5, 96.6) | 90.0 | (53.3, 98.6)
Clinical diagnosis | 5 | 93.6 | (85.0, 97.5) | 68.9 | (54.7, 80.3)

Table H-3 Mixed/Unknown Asthmagens

Comparison Test | Number of Studies | Pooled Sensitivity (95% CI) | | Pooled Specificity (95% CI)
NSBP test | 5 | 83.7 | (66.8, 92.9) | 48.4 | (25.9, 71.6)
Specific skin prick test | 5 | 63.0 | (41.5, 80.3) | 59.2 | (45.4, 71.7)
Specific IgE | 2 | 85.1 | (40.3, 98.0) | 61.2 | (7.0, 97.1)
Serial NSBP test | 3 | 50.0 | (35.5, 64.5) | 66.8 | (53.3, 78.0)
Serial PFT (usually PEFR) | 5 | 63.6 | (43.4, 79.9) | 77.2 | (66.5, 85.2)
Clinical diagnosis | 2 | 95.1 | (86.8, 98.3) | 47.7 | (26.7, 69.7)
Eosinophil counts | 3 | 54.9 | (23.7, 82.7) | 72.3 | (54.1, 85.3)

Abbreviations: CI = confidence interval

NSBP = non-specific bronchial provocation

PFT = pulmonary function test

++ = peak expiratory flow rate