# Appendix G: Quality Analysis of the Diagnostic Occupational Asthma Studies

## Quality Analysis

For the diagnosis review, the quality of the included studies was low. More formal analyses of the overall quality was attempted to determine the impact study quality on the results. This was evaluated by visual assessment of the distribution of results according to the validated criteria described in the Methods section of the report.

The figures below illustrate the distribution of efficiency (total proportion of correctly identified patients) according the six relevant diagnostic test methodological criteria outlined in the Methods section for single NSBP test compared to SIC for the 39 studies which gave results for both disease positive and disease negative patients. The seventh validated criterion involves the use of a valid reference standard, and our research team considered SIC to be a valid reference standard for these OA studies. Single NSBP test was selected for evaluation from all other options because it was the most frequently reported comparison test.

Our conclusion that the quality of the studies did not impact the results in the review is based on our observation that the distribution of efficiency did not markedly differ depending on any specific quality maker. We also considered sensitivity and specificity alone and reached the same conclusion.

## Figure G-1. Distribution of efficiency of tests comparing NSBPtest to SIC by diagnostic study quality criteria

[image]