# Appendix F: Technical Expert Panel, List of Peer Reviewers, and Translators

## Technical Expert Panel

- Margaret Coopey
- Agency for Healthcare Research and Quality, Washington, United States

- Richard Jones
- University of Alberta, Edmonton, Canada

- Catherine Lemiere
- University of Montreal, Montreal, Canada

- David Muir
- McMaster University, Hamilton, Canada

- Susan Tarlo
- University of Toronto, Toronto, Canada

- Dilini Vethanayagam
- University of Alberta, Edmonton, Canada

## Peer Reviewers

- Ronald Balkissoon
- University of Colorado School of Medicine, United States

- Sherwood Burge
- Birmingham Heartlands Hospital, United Kingdom

- Prasant Adhikari
- Workers' Compensation Board of Manitoba, Canada

- Mark Cullen
- Yale University School of Medicine, United States

- Paul Cullinan
- Royal Brompton Hospital, United Kingdom

- Clive Deutscher
- Workers' Compensation Board of Alberta, Canada

- David Hendrick
- University of Newcastle Upon Tyne, United Kingdom

- Jean Luc Malo
- University of Montreal Medical School, Canada

- Philliipa Poole
- University of Auckland, New Zealand

- Carrie Redlich
- Yale University School of Medicine, United States

- Olivier Vandenplas
- Université Catholique de Louvain, Belgium

## Translators

- Rudy Bella
- Lefarge, Edmonton, Canada

- Maurice Blitz
- Capital Health, Edmonton, Canada

- Anatoly Dobrousin
- Capital Health, Edmonton, Canada

- Bing Gao
- Capital Health, Edmonton, Canada

- Walter Kipp
- University of Alberta, Edmonton, Canada

- Zhi Li
- University of Alberta, Edmonton, Canada

- Arto Ohinmaa
- University of Alberta, Edmonton, Canada

- Maria Ospina
- University of Alberta, Edmonton, Canada

- Rob Polakowski
- University of Alberta, Edmonton, Canada

- Galina Portmoi
- University of Alberta, Edmonton, Canada

- Jacques Rizkallah
- University of Alberta, Edmonton, Canada

- Paul Sperka
- University of Alberta, Edmonton, Canada