# Appendix E: Evidence Tables

Diagnosis of Occupational Asthma

Management of Occupational Asthma: Cohorts

Management of Occupational Asthma: Trials

Management of Occupational Asthma: Methodological Quality

Table E-1 Description of included studies (Diagnosis review)

Author, Year | Location | Language of Publication | SIC used as Reference Standard | Comparison Tests | Suspected Agent (molecular weight) | Description of Included Workers | Patient Source
Alvarez, 2001 | Spain | English | Yes | Eosinophils, single NSBPT, skin prick, serum specific IgE | Flour: oilseed rape (H) | Farmers with respiratory symptoms related to fodder manipulation | Clinic
Alvarez, 1996 | Spain | English | Yes | Single NSBPT, skin prick, serum specific IgE | Cereals (H) | Bakers, millers, and farmers diagnosed with OA over a five yr period | Clinic
Anees, 2004 | United Kingdom | English | No | Serial PFT (PEFR) | Mixed (M) | Consecutive workers of mixed occupation with definite OA | Clinic
Avery, 1969 | United States | English | No | Lymphocyte blast cell transformation, TDI-HSA | Isocyanates (L) | Workers exposed toTDI; some with severe symptoms at low exposure, others with less symptoms at higher exposures | NR
Balland, 1989 | France | French | Yes | Single NSBPT, serum specific IgE, serum total IgE | Mixed (M) | Workers presenting with symptoms of suspected work-related asthma and rhinitis | Workplace
Baur, 1998 | Germany | English | Yes | Clinical diagnosis, single NSBPT | Mixed (M) | Healthcare workers, bakers, isocyanate workers, and hairdressers who consulted clinic because of suspected OA | Clinic
Baur, 1979 | United Kingdom | English | Yes | Skin prick, serum specific IgE | Papain (H) | Meat or pharmaceutical plant workers exposed to airborne papain | Other
Behr, 1990 | Germany | German | Yes | Clinical diagnosis, single NSBPT | Isocyanates (L) | Workers exposed to isocyanates with workplace related respiratory symptoms | Clinic and workplace
Bernstein, 2002 | Canada | English | Yes | Di-isocyanate antigen stimulation of MCP-1, single NSBPT, serum specific IgE | Isocyanates (L) | Di-isocyanate exposed workers with history of OA, referred for SIC testing | Clinic
Biot, 1980 | France | French | Yes | Basophils granules liberation, single NSBPT, serum total IgE | Mixed (M) | Workers complaining of allergic manifestations in practicing their profession | Workplace
Block, 1983 | Canada | English | Yes | Single NSBPT, skin prick, serum specific IgE | Flour: wheat and rye (H) | Bakers with respiratory symptoms identified from workplace survey or referred to study | Clinic
Burge, 1985 | United Kingdom | English | Yes | Single NSBPT | Formaldehyde (L) | Workers of mixed occupation referred for investigation of symptoms suggestive of OA | Clinic
Burge, 1982b | United Kingdom | English | Yes | Single NSBPT | Isocyanates (L) | Workers with respiratory symptoms when exposed to TDI, MDI, or colophony | NR
Burge, 1980 | United Kingdom | English | Yes | Single NSBPT | Colophony (L) | Electronics workers referred for investigation of respiratory symptoms | Clinic
Burge, 1979a | United Kingdom | English | Yes | Clinical diagnosis, serial PFT (PEFR) | Colophony (L) | Electronics factory workers who had had a bronchial provocation test by exposure to solder-flux fumes in the hospital and had kept a record of their PEFR at home and at work for at least two wks | Clinic
Burge, 1979b | United Kingdom | English | Yes | Clinical diagnosis, serial PFT (PEFR) | Isocyanates (L) | Workers from factories printing and laminating flexible packaging who had been admitted for SIC and had kept at least two wks of PEFR records | Clinic
Burge, 1978 | United Kingdom | English | Yes | Eosinophils, single PFT, skin prick | Colophony (L) | Electronics industry workers exposed to colophony who developed asthma or evidence of a peripheral airway reaction | NR
Butcher, 1980 | United States | English | Yes | Serum specific IgE, serum total IgE | Isocyanates (L) | Workers previously shown to give adverse bronchial reactions to SIC with TDI | Other
Carletti, 1997 | Italy | Italian | Yes | Clinical diagnosis, single NSBPT, single PFT, skin prick | Flour (H) | Millers and bakers with suspected OA | Workplace
Cartier, 1989 | Canada | English | Yes | Serial NSBPT, single NSBPT, skin prick, serum specific IgE, serum specific IgG | Isocyanates (L) | Subjects of various occupations who were being investigated for possible OA caused by isocyanates who underwent SIC | Clinic
Cartier, 1987 | Canada | English | Yes | Single NSBPT, skin prick, serum specific IgE | Psyllium (H) | Nurses with history of asthmatic symptoms after exposure to psyllium | Clinic
Cartier, 1986 | Canada | English | Yes | Skin prick, serum specific IgE | Snow crab (H) | Snow crab workers previously diagnosed with OA | Clinic
Choudat, 1999 | France | English | Yes | Single NSBPT, serum specific IgE | Flour: wheat (H) | Bakers and pastry makers referred for assessment of OA caused by flour | Clinic
Cirla, 1975 | Italy | Italian | Yes | Single NSBPT, skin prick | Isocyanates (L) | Furniture manufacturing workers with symptoms of asthma at work | Clinic
Colas, 1985 | France | French | Yes | Carbon dioxide diffusion, eosinophils, single NSBPT, single PFT, skin prick, serum total IgE | Wood dust: exotic (L) | Workers who had been hospitalized for OA due to exotic woods | Clinic
Cortona, 1980 | Italy | Italian | No | Skin prick | Enzymes: bromolin (H) | Workers from a pharmacuetical industry handling bromelin | Workplace
Cote, 1993 | Canada | English | Yes | Serial PFT (PEFR) | Wood dust: cedar (L) | Consecutive sawmill workers referred by family physician for work related increases in dyspnea and cough | Clinic
Coutts, 1984 | United Kingdom | English | Yes | Single NSBPT, skin prick | Chemical: cimetidine (L) | Syptomatic workers manucturing cimetidine tablets | Workplace
Curran, 1996 | United Kingdom | English | No | Serum specific IgE, serum total IgE | Chemical: glutaraldehyde (L) | Health professionals exposed to glutaraldehyde, some had been diagnosed with OA by respiratory physician, some had respiratory symptoms without diagnosis | Clinic
Davison, 1983 | United Kingdom | English | Yes | Skin prick, serum specific IgE | Castor beans (H) | Merchant seamen and laboratory workers who developed allergic symptoms following exposure to castor beans | Workplace
DeZotti, 1996a | Italy | English | Yes | Eosinophils, single NSBPT, single PFT, skin prick | Wood dust: exotic (L) | Furniture manufacturers and wood processors complaining of respiratory symptoms at work | Clinic
DeZotti, 1996b | Italy | Italian | Yes | Eosinophils, single NSBPT, single PFT, skin prick, serum specific IgE | Mixed (M) | Workers with OA due to isocyanate or wheat exposure | Clinic
Dellabianca, 1996 | Italy | English | Yes | Single NSBPT, single NSBPT | Mixed (M) | Consecutive subjects of mixed occupation referred to clinic for probable OA due to low molecular weight chemicals- both SIC reactors and non-reactors | Clinic
Dente, 1986 | Italy | English | Yes | Single NSBPT | Isocyanates (L) | Workers with occupational exposure to TDI | NR
DiFranco, 1998 | Italy | English | Yes | Eosinophils, single NSBPT | Mixed (M) | Workers with OA induced by low or high molecular weight compounds seen in a clinic over a two yr period | Clinic
DiStefano, 1999 | United Kingdom | English | No | Single NSBPT, skin prick | Chemical: glutaraldehyde (L) | Health care workers with symptoms suggestive of OA due to exposure to glutaraldehyde | Other
Duan, 1989 | China | Chinese | Yes | Clinical diagnosis, serial NSBPT, serial PFT, single PFT, skin prick, serum specific IgE | Isocyanates (L) | Symptomatic TDI factory workers compared to non-symptomatic workers and ordinary asthma workers | Mixed
Ferguson, 1996 | Canada | English | Yes | Single NSBPT, single PFT, serum specific IgE | Isocyanates (L) | Auto manufacturers and spray painters with chest symptoms compatible with asthma and prior exposure to isocyanates | Other
Gannon, 1996 | United Kingdom | English | No | Serial PFT (PEFR) | Mixed (M) | Records from workers from different industries attending an occupational lung disease clinic with suspected OA, and from a cross sectional survey of respiratory symptoms in post office sorting workers | Mixed
Girard, 2004 | Canada | English | Yes | Eosinophils, serial NSBPT, serial PFT, skin prick | Mixed (M) | Subjects referred to OA reference centres for possible OA | Clinic
Graneek, 1987 | United Kingdom | English | Yes | Single NSBPT | Mixed (M) | Workers from various industries who were admitted to hospital for investigation of OA | Other
Grosclaude, 1980 | France | French | Yes | Single NSBPT, skin prick, serum total IgE | Mixed (M) | Workers of mixed occupation with OA due to various causes | Workplace
Harries, 1980 | United Kingdom | English | Yes | Eosinophils, skin prick | Mixed (M) | Workers of various occupation with a history of respiratory illness worsening at work | Clinic
Hinojosa, 1986 | Spain | English | Yes | Skin prick, serum specific IgE, serum total IgE | Wood dust: African maple and ramin (L) | Workers exposed to African maple dust who were admitted for study after being away from work for at least two wks | Clinic
Howe, 1983 | United Kingdom | English | Yes | Skin prick, serum specific IgE | Chemical: TCPA (L) | Factory workers with respiratory symptoms referred by factory management | Workplace
Huggins, 2003 | United Kingdom | English | No | Serial PFT (PEFR) | Enzymes: detergent (H) | Factory workers with work-related respiratory symptoms and positive serum specific IgE or skin prick tests to one of the enzymes used in biological detergents | Clinic and workplace
Jager, 1993 | Germany | German | Yes | Single NSBPT, skin prick, serum specific IgE, supervised work challenge, serum total IgE | Latex (H) | Health care workers with an immediate allergic-type reaction to latex gloves | Clinic
Karol, 1994 | United States | English | Yes | Clinical diagnosis, single NSBPT, serum specific IgE, serum specific IgG, serum total IgE | Isocyanates (L) | Workers with a history of sensitization to isocyanates, referred for evaluation of respiratory symptoms | Clinic
Kern, 1991 | United States | English | No | Single NSBPT | Chemical: glacial acetic acid (L) | Hospital laboratory and radiology workers exposed to a one time spill of 100% acetic acid for two and a half hrs | Workplace
Keskinen, 1988 | Finland | English | Yes | Skin prick, serum specific IgE | Isocyanates (L) | Workers of mixed occupation with verified asthma due to di-isocyanates based on symptoms and SIC | Clinic
Kim, 1999 | Korea | English | Yes | Single NSBPT, single PFT, skin prick, serum specific IgE, serum total IgE | Citrus red mite (H) | Citrus fruit farmers with respiratory symptoms | Clinic
Kim, 1997 | Korea | English | No | Single PFT, serum specific IgE, serum specific IgG | Isocyanates (L) | Workers who had been exposed to TDI in workshops manufacturing furniture or musical instruments or repairing motor vehicles | Workplace
Kongerud, 1992 | Norway | English | No | Clinical diagnosis, eosinophils, serial NSBPT, single NSBPT, symptom score, serum total IgE | Potroom (L) | Potroom workers with a history suggestive of OA after standardized interview and methacholine challenge PC_20_ <32 g/L | Clinic
Kopferschmitt-Kubler, 1998 | France | English | Yes | Serial PFT (FEV_1_), single NSBPT | Isocyanates (L) | Workers with clinical history of isocyanate-induced asthma with reversibility and no positive reaction to low doses of TDI | Clinic
Koskela, 2003 | Australia and Finland | English | Yes | Exhaled nitric oxide, single NSBPT, skin prick, serum specific IgE, serum total IgE | Animal/bird: cow dander (H) | Dairy farmers who were referred to the laboratory because of a suspicion of OA due to bovine allergens | Clinic
Krakowiak, 2003 | Poland | English | Yes | Clinical diagnosis, eosinophils, single NSBPT, skin prick, serum specific IgE | Animal/bird: lab animals (H) | Laboratory animal workers referred to an occupational disease clinic for asthma and allergic rhinitis | Clinic
Lam, 1979 | Canada | English | Yes | Single NSBPT, skin prick | Wood dust: cedar (L) | Subjects with OA that were tested while symptomatic or after removed from exposure | Clinic
LaPaglia, 1986 | Italy | Italian | Yes | Clinical diagnosis, skin prick | Mixed (M) | Subjects with a work-associated respiratory disease | Clinic
Larbanois, 2003 | Belgium | English | Yes | Serial PFT (sGaw), single NSBPT | Mixed (M) | Consecutive subjects of various occupations who were investigated for OA and underwent SIC | Clinic
Lemiere, 2001 | Canada | English | Yes | Eosinophils, single NSBPT, skin prick | Mixed (M) | Workers of various occupations referred to clinic for possible OA and subjects who had a diagnosis of asthma (concentration of methacholine inducing a 20% fall in FEV_1_ of less than 8mg/mL and who could produce sputum) | Clinic
Liss, 1991 | Canada | English | Yes | Serial PFT (PEFR), single NSBPT, single PFT, skin prick | Mixed (M) | Consecutive workers with mixed occupations referred for assessment of possible OA | Clinic
Lozewicz, 1985 | United Kingdom | English | Yes | Single NSBPT, skin prick | Chemical: acrylates (L) | Subjects with asthma associated with exposure to cyanoacrylates | NR
Malo, 1993a | Canada | English | Yes | Serial PFT (PEFR) | Mixed (M) | Workers of mixed occupation referred for investigation of possible OA | Clinic
Malo, 1991 | Canada | English | Yes | Questionnaire, serial NSBPT, serial PFT (PEFR), single NSBPT, skin prick | Mixed (M) | Workers of mixed occupation referred because of possible OA | Clinic
Malo, 1990 | Canada | English | Yes | Single NSBPT, skin prick | Mixed (M) | Records of subjects with late asthmatic reactions and isolated immediate reactions to SIC | Clinic
Malo, 1988a | Canada | English | Yes | Eosinophils, questionnaire, serial PFT (PEFR), single NSBPT, skin prick | Spiromycin (L) | All workers in a pharmaceutical company, intermittently exposed to spiromycin, investigated to determine frequency of OA | Workplace
Mapp, 1986 | Italy | English | Yes | Single NSBPT, skin prick | Isocyanates (L) | Subjects with sensitivity to TDI | NR
Mapp, 1979 | Italy | Italian | Yes | Single NSBPT, skin prick | Isocyanates (L) | Employees who worked in paint, varnish and plastics manufacturing with chronic respiratory symptoms at work | Workplace
Merget, 1997 | Germany | English | Yes | Single NSBPT, skin prick, serum specific IgE, serum total IgE | Flour: wheat (H) | Highly selected bakers referred to clinic for assessment of OA | Clinic
Merget, 1996 | Germany | English | Yes | Single NSBPT, skin prick, serum total IgE | Chemical: platinum salts (L) | Platinum refinery and catalyst production workers who were considered to have OA due to platinum salts | Clinic
Merget, 1993 | Germany | English | Yes | Single NSBPT, skin prick, serum specific IgE, serum total IgE | Enzymes (H) | Enzyme manufacturing plant workers referred to the pulmonary department with work related symptoms | Workplace
Mole, 1977 | Italy | Italian | No | Single NSBPT, skin patch test | Mixed (M) | Workers of many occupations with suspected OA | Clinic
Moller, 1986 | United States | English | Yes | Clinical diagnosis, single NSBPT, single PFT | Isocyanates (L) | Workers of various occupations referred for possible TDI asthma based on consistent clinical and occupational history | Clinic
Moller, 1985 | United States | English | No | Eosinophils, questionnaire, serial PFT (FEV_1_), serum specific IgE | Chemical: hexahydrophthalic anhydride (L) | Workers in a plant manufacturing bushings for electrical transformers who reported symptoms of asthma | Workplace
Moscato, 1993 | Italy | English | Yes | Single NSBPTs, single PFT, skin prick | Isocyanates (L) | Workers in furniture and plastics industries, auto body repair workers, and carpenters referred for probable OA due to TDI | Clinic
Munoz, 2004 | Spain | English | Yes | Serial PFT (PEFR), single NSBPT, skin prick, serum total IgE | Chemical: persulfate (L) | Hairdressers and cosmetic industry workers exposed to hair bleaches diagnosed with OA | Clinic
Nielsen, 1988 | Sweden | English | No | Single NSBPT, skin prick, serum specific IgE, serum specific IgG, serum total IgE | Chemical: phthalic anhydride (L) | Workers from factories producing polyester resins reporting asthma symptoms during exposure | Workplace
Nordman, 1985 | Finland | English | Yes | Eosinophils, serial PFT (PEFR), single NSBPT, single PFT, serum total IgE | Formaldehyde (L) | Workers with various occupations investigated because of suspected formaldehyde-induced asthma | Clinic
O'Brien, 1979a | United Kingdom | English | Yes | Single NSBPT | Isocyanates (L) | Subjects referred for investigation of possible work related respiratory symptoms | Clinic
O'Brien, 1979b | United Kingdom | English | Yes | Exercise test, single NSBPT, skin prick | Isocyanates (L) | Workers occupationally exposed to TDI referred for investigation of possible work related asthma symptoms | Clinic
Obata, 1999 | Canada | English | Yes | Eosinophils, exhaled nitric oxide, single NSBPT, skin prick | Wood dust: cedar (L) | Sawmill workers or carpenters referred to respiratory clinic with symptoms of cough, wheeze and chest tightness after working with red cedar for at least six mos | Clinic
Obtulowicz, 1998 | Poland | English | Yes | Eosinophils, skin prick, serum total IgE | Mixed (M) | Steel and tobacco factory workers with bronchial asthma suspected to be of occupational origin | Other
Paggiaro, 1987b | Canada | English | Yes | Single NSBPT, skin prick, serum specific IgE | Wood dust: cedar (L) | Workers with OA due to western red cedar | Clinic
Paggiaro, 1986 | Italy | English | Yes | Single NSBPT, skin prick | Isocyanates (L) | Furniture industry workers with OA induced by TDI | Clinic
Paggiaro, 1984b | Italy | Italian | Yes | Single NSBPT, skin prick, serum specific IgE, serum total IgE | Enzymes: proteolytic (H) | Workers in a factory producing detergents with symptoms of OA | Workplace
Paggiaro, 1984c | Italy | Italian | Yes | Clinical diagnosis, single NSBPT | Isocyanates (L) | Workers from a furniture industry exposed to isocyanates | Workplace
Paggiaro, 1981 | Italy | English | Yes | Single NSBPT, skin prick, serum specific IgE | Wood dust: tanganyika aningre (L) | Woodworkers exposed to tanganyika aningre with symptoms of dyspnea, cough, and wheezing | Other
Palczynski, 2003 | Poland | English | Yes | Eosinophils, single NSBPT, skin prick, serum specific IgE, serum total IgE | Chloramine (L) | Healthcare workers with a history of respiratory symptoms related to chloramine T | Other
Park, 2002b | Korea | English | Yes | Immunoblotting, single NSBPT, skin prick, serum specific IgE | Alpha amylase (H) | Nurses with asthma symptoms when exposed to porcine pancreatic extracts at work | Clinic
Park, 2001 | Korea | English | Yes | Skin prick, serum specific IgE | Reactive dyes (L) | Workers with OA from reactive dyes (SIC positive) who visited clinic in last ten yrs, asymptomatic workers in a reactive dye factory, and unexposed subjects with negative SIC to reactive dyes | Mixed
Park, 1999 | Korea | English | Yes | Single NSBPT, single PFT, skin prick, serum specific IgE | Isocyanates (L) | Workers with TDI induced asthma, as well as SIC negative workers and control subjects with allergic asthma | Other
Park, 1998 | Korea | English | Yes | Eosinophils, immunoblotting, single NSBPT, skin prick, serum specific IgE | Grain dust (H) | Animal feed industry workers exposed to grain dust | Workplace
Park, 1994 | Korea | English | Yes | Serial PFT (PEFR), single NSBPT, skin patch test, skin prick | Chemical: chromium (L) | Metal plating factory, cement manufacturers and construction workers complaining of work related symptoms | Clinic
Park, 1991 | Korea | English | Yes | Single NSBPT, skin prick, serum specific IgE, serum total IgE | Reactive dyes (L) | Symptomatic textile dye industry workers with bronchial hyperreactivity | Workplace
Park, 1989 | Korea | English | Yes | Single NSBPT, single PFT, skin prick, serum specific IgE | Reactive dyes (L) | Dye process workers who complained of asthmatic symptoms following various lengths of exposure to reactive dyes | Workplace
Perrin, 1990 | Canada | English | Yes | Serial NSBPT, serial PFT (PEFR) | Mixed (M) | Subjects referred for OA to various agents | Clinic
Pezzini, 1984 | Italy | English | Yes | Single NSBPT, skin prick, serum specific IgE | Isocyanates (L) | Polyurethane foam shoe factory and furniture plant workers with diagnosis of isocyanate-induced OA based on symptoms and SIC | NR
Prichard, 1984 | Australia | English | No | Single NSBPT, skin prick | Flour: wheat (H) | Bakers and bakery workers of fulfilled the definition of work related asthma | Workplace
Quirce, 2000 | Spain | English | No | Skin prick, serum specific IgE | Wood dust: obeche (L) | Woodworkers with symptoms of asthma after exposure to obeche wood dust | NR
Quirce, 1992 | Spain | English | Yes | Single NSBPT, skin prick, serum specific IgE | Alpha amylase (H) | Bakers evaluated in clinic because of respiratory symptoms due to exposure to flours and enzymes at work | Clinic
Rasanen, 1994 | Finland | English | Yes | Basophil histamine release, skin prick, serum specific IgE, serum total IgE | Mixed (M) | Workers of mixed occupation with challenge-proven occupational rhinitis or asthma and workers with seasonal rhinitis or other respiratory symptoms | NR
Redlich, 1996 | United States | English | Yes | Bronchial alveolar lavage, eosinophils, single NSBPT | Isocyanates (L) | Currently exposed workers with isocyanate asthma | NR
Ricciardi, 2003 | Italy | English | Yes | Eosinophils, serial PFT (PEFR), single NSBPT, skin prick, serum specific IgE, serum total IgE | Wood dust: iroko (L) | Wood workers who reported asthma symptoms | Clinic
Sander, 2001 | Germany | German | Yes | Skin prick | Flour: wheat and rye (H) | Bakers with asthma symptoms | NR
Sastre, 2003 | Spain | English | Yes | Single NSBPT, serum specific IgE | Isocyanates (L) | Workers with a suspected clinical history of di-isocyanate-induced asthma | Other
Schuermans, 2003 | Belgium | English | Yes | Single NSBPT | Latex (H) | Workers of unreported occupation referred to centre for suspected latex OA | Clinic
Schwaiblmair, 1997 | Germany | English | Yes | Single NSBPT, single PFT, skin prick | Bleaching powder (L) | Hairdressers who had regular contact with various hair products and a clinical history of job related rhinitic/asthma symptoms | Clinic
Schwarting, 1979 | Germany | German | Yes | Clinical diagnosis, skin prick, serum specific IgE | Flour (H) | Bakers who were exposed to flour dust for at least eight hrs per day | Workplace
Shirai, 2003 | Japan | English | Yes | Clinical diagnosis, single NSBPT, skin prick | Green tea (L) | Green tea factory workers with clinical history suggestive of asthma referred to Internal Medicine and associated hospitals | Clinic
Shirakawa, 1988 | Japan | English | Yes | Antibodies (CO-HSA), eosinophils, single NSBPT, skin prick, serum specific IgE | Chemical: cobalt (L) | Hard metal plant workers who met clinical criteria for OA | Clinic
Slovak, 1981 | United Kingdom | English | No | Serial PFT (PEFR), skin prick | Chemical: AZO dicarbonamide (L) | Personnel with positive history of wheezing or chest tightness (+/- cough) related to exposure to azodicarbonamide dust on screening at a manufacturing plant | Workplace
Symington, 1981 | United Kingdom | English | Yes | Skin prick | Mushroom dust (H) | Food manufacturing workers presenting with work related symptoms to dried mushroom dust | Workplace
Tabar, 2004 | Spain | English | Yes | Immunoblotting, skin patch test, skin prick, serum specific IgE, serum total IgE | Asparagus (H) | Workers with various occupations diagnosed with asparagus allergy in the past five yrs | Clinic
Taivainen, 1994 | Finland | Finnish | Yes | Clinical diagnosis, skin prick, serum specific IgE | Animal/bird: cow dander (H) | Farmers refered to a clinic for investigation of OA | Clinic
Tee, 1998 | United Kingdom | English | No | Skin prick, serum specific IgE | Isocyanates (L) | All workers exposed to isocyanates who were referred for investigation of OA from whom blood was available for measurement of serum specific IgE and in whom a firm diagnosis was reached | Clinic
Tse, 1982 | Canada | English | Yes | Serum specific IgE | Wood dust: cedar (L) | Workers suspected to have red cedar asthma who were referred to the clinic to undergo antigenic bronchoprovocation test to have the diagnosis confirmed | Clinic
Vandenplas, 2001 | Belgium | English | Yes | Clinical diagnosis, serial NSBPT, single NSBPT, skin prick | Latex (H) | Consecutive workers who were referred for the investigation of possible OA and who were exposed at work to airborne allergens from natural rubber latex gloves | Clinic
Vandenplas, 1995b | Belgium | English | Yes | Single NSBPT, skin prick | Latex (H) | Hospital employees (nurses, lab technologists, cleaning staff) exposed to latex | Workplace
Vanhanen, 2000 | Finland | English | Yes | Single NSBPT, skin prick, serum specific IgE | Cellulase (H) | Workers with suspected OA or rhinitis due to cellulase who were referred to a clinic | Clinic
Virtanen, 1996 | Finland | English | No | Serum specific IgE, serum specific IgG | Animal/bird: cow dander (H) | Randomly selected dairy farmers diagnosed with cow asthma who were workers of the pulmonary clinic | Clinic
Vogelmeier, 1991 | Germany | English | Yes | Single NSBPT, skin prick, serum specific IgE | Isocyanates (L) | Workers who had occupational contact with TDI and/or MDI and a strong clinical history or workplace-related asthma and normal volunteers; subjects with asthma and no isocyanate exposure | NR
Wurzinger, 1997 | Austria | German | Yes | Single NSBPT, skin prick, serum specific IgE, serum total IgE | Flour (H) | Cooks, bakers, farmers, and confectioners with suspected OA | Clinic
Zeiler, 2002 | Finland | English | Yes | Single NSBPT, skin prick, serum specific IgE, serum specific IgG | Animal/bird: cow dander (H) | Consecutive dairy farmers referred to pulmonary clinic for confirmation of the bovine origin of their OA | Clinic
Zeiss, 1977 | United States | English | No | Skin prick, serum specific IgE, serum specific IgG | Chemical: trimellitic anhydride (L) | Chemical plant workers with asthma and/or rhinitis symptoms due to TMA exposure | Clinic

Abbreviations: AC = azodicarbonamide; CO-HSA = conjugated human serum; FEV _ 1 _ = forced expiratory volume in one second; H = high; L = low; M = mixed; MCP-1 = monocyte chemoattractant protein-1; MDI = diphenylmethane di-isocyanate; mos = months; NR = not reported; NSBPT = non-specific bronchial provocation; OA = occupational asthma; PC _ 20 _ = provocative concentration causing a 20% drop in FEV_1_; PEFR = peak expiratory flow rate; PFT = pulmonary function test; sGaw = specific airways conductance; SIC = specific inhalational challenge; TCPA = tetrachlorophthalic anhydride; TDI-HSA = toluene di-isocyanates human serum albumin; TMA = trimellitic anhydride; wks = weeks; yr = year; yrs = years

Table E-2 Demographic characteristics of included patients (Diagnosis review)

Author, Year | Number of Patients | Male | Age | Atopic | Smoking Status | History of Asthma | %predicted FEV_1_ (unless otherwise stated) | Years of Exposure | Years of Symptoms | Current Medication Stopped for Testing
| | (%) | mean (SD) | (%) | (%) | (%) | mean (SD) | mean (SD) | mean (SD)
Alvarez, 2001 | 3 | 66.7 | 40.3 (13.6) | 0 | C: 0 | _-_ | 94.7 (1.5) | _-_ | 1.7 (0.6) | No
| | | | | Ex: 0
| | | | | N: 100
Alvarez, 1996 | 21 | 95.2 | 38.3 (15.7) | 42.9 | C: 14.3 | _-_ | - | _-_ | 5.5 (7.7) | No
Anees, 2004 | 141 | 73.8 | 46 (10.2) | 45.4 | C: 17.7 | _-_ | - | _-_ | _-_ | Yes
| | | | | Ex: 33.3
| | | | | N: 48.9
Avery, 1969 | 18 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Balland, 1989 | 75 | 61.3 | _-_ | 24 | - | 52 | - | _-_ | _-_ | -
Baur, 1998 | 229 | 66.4 | 35.1 (11.4) | _-_ | - | _-_ | - | 8.6 (8.4) | _-_ | No
Baur, 1979 | 7 | _-_ | _-_ | _-_ | - | _-_ | - | 4.8 (2.8) | _-_ | -
Behr, 1990 | 70 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Bernstein, 2002 | 54 | 96.3 | 39.9 | _-_ | - | _-_ | - | 11.2 (11.1) | _-_ | No
Biot, 1980 | 12 | _-_ | 41.6 (11.4) | _-_ | - | _-_ | - | _-_ | _-_ | -
Block, 1983 | 7 | 100 | 50 (13.6) | 85.7 | C: 42.9 | _-_ | 101.7 (28.8) | 28.4 (16) | _-_ | Yes
| | | | | Ex: 42.9
| | | | | N: 14.3
Burge, 1985 | 15 | 93.3 | 45.7 (11.1) | 46.7 | C: 26.7 | 0 | - | _-_ | _-_ | No
| | | | | Ex: 40
| | | | | N: 33.3
Burge, 1982b | 136 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Burge, 1980 | 49 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Burge, 1979a | 29 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | -
Burge, 1979b | 23 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Burge, 1978 | 21 | 14.3 | 45.2 (12.5) | 42.9 | C: 23.8 | 23.8 | 88.3 (16.5) | _-_ | _-_ | No
| | | | | Ex: 14.3
| | | | | N: 66.7
Butcher, 1980 | 26 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Carletti, 1997 | 37 | 100 | 41 (12) | 37.8 | C: 48.6 | _-_ | - | _-_ | _-_ | No
Cartier, 1989 | 62 | 93.5 | _-_ | 40.3 | C: 27.4 | _-_ | 94 (22) | 8.8 (8.5) | _-_ | -
| | | | | Ex: 37.1
| | | | | N: 35.5
Cartier, 1987 | 5 | 20 | 38.8 (9.9) | 100 | - | 20 | 90 (16.3) | 12.6 (4.3) | 0.7 (0.3) | Yes
Cartier, 1986 | 54 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Choudat, 1999 | 21 | 95.2 | 29.6 (5.7) | _-_ | - | _-_ | 97 (12.3) | 11.6 (6.4) | _-_ | No
Cirla, 1975 | 33 | _-_ | _-_ | _-_ | - | _-_ | 77 (7.8) | _-_ | _-_ | No
Colas, 1985 | 10 | 100 | 47 | 30 | - | 10 | - | 21.6 | 3.4 | No
Cortona, 1980 | 76 | _-_ | 35 | _-_ | - | _-_ | - | _-_ | _-_ | No
Cote, 1993 | 25 | 100 | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Coutts, 1984 | 4 | 100 | 38 (13) | _-_ | - | _-_ | - | _-_ | _-_ | No
Curran, 1996 | 20 | 10 | 46.7 (11.4) | _-_ | - | _-_ | - | _-_ | _-_ | -
Davison, 1983 | 3 | 100 | 29 (2.7) | 100 | C: 66.7 | 0 | PEF: 193.3 (135.8) | _-_ | _-_ | No
| | | | | Ex: 0
| | | | | N: 33.3
DeZotti, 1996a | 4 | 75 | 47.3 (12.3) | 50 | N: 100 | _-_ | - | _-_ | _-_ | -
DeZotti, 1996b | 54 | 61.1 | 30.6 (9.6) | 25.9 | C: 24.1 | 44.4 | - | 8.7 (9.6) | _-_ | No
Dellabianca, 1996 | 40 | 47.5 | 35.6 (11.1) | 20 | C: 20 | _-_ | - | _-_ | 2.35 (10.6) | -
| | | | | Ex: 40
| | | | | N: 42.5
Dente, 1986 | 42 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | -
DiFranco, 1998 | 24 | 75 | 45.3 (9.6) | 25 | C: 0 | _-_ | - | _-_ | 7.33 (4.5) | Yes
| | | | | Ex: 54.2
| | | | | N: 45.8
DiStefano, 1999 | 24 | 12.5 | 38.6 (8.8) | 37.5 | C: 29.2 | 12.5 | 75.8 (14.6) | _-_ | _-_ | -
| | | | | Ex: 16.7
| | | | | N: 54.2
Duan, 1989 | 18 | 33.3 | _-_ | _-_ | - | 100 | - | 9.5 (4.8) | _-_ | No
Ferguson, 1996 | 90 | 63.3 | 34.3 (10.2) | _-_ | C: 46.7 | _-_ | - | 5.7 (5.9) | 1.92 (3.3) | Yes
| | | | | Ex: 35.6
| | | | | N: 16.7
Gannon, 1996 | 127 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Girard, 2004 | 52 | 57.7 | 40.4 (11.5) | 69.2 | C: 23.1 | _-_ | - | 7.2 (8.1) | 10.65 (11.4) | -
| | | | | Ex: 44.2
| | | | | N: 26.9
Graneek, 1987 | 9 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | -
Grosclaude, 1980 | 30 | 73.3 | 38.7 | 10 | - | _-_ | - | 10 | 1.9 | No
Harries, 1980 | 37 | 45.9 | 37.5 (9.8) | 59.5 | - | _-_ | - | _-_ | _-_ | No
Hinojosa, 1986 | 4 | 100 | 40 (6.2) | 25 | C: 25 | _-_ | - | 8.8 (3.3) | 4.8 (2.6) | -
| | | | | Ex: 25
| | | | | N: 50
Howe, 1983 | 7 | 0 | 41.1 (5) | 14.3 | C: 100 | 0 | - | _-_ | _-_ | No
| | | | | Ex: 0
| | | | | N: 0
Huggins, 2003 | 52 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Jager, 1993 | 14 | 14.3 | 34.7 (8.1) | 42.9 | - | 71.4 | - | _-_ | _-_ | No
Karol, 1994 | 63 | 73 | 30.6 | _-_ | - | _-_ | - | 10.1 (9) | 3.08 (3.9) | -
Kern, 1991 | 51 | 19.6 | 37.9 (10.3) | 23.5 | C: 41.2 | 5.9 | - | _-_ | _-_ | No
| | | | | Ex: 13.7
| | | | | N: 45.1
Keskinen, 1988 | 35 | 80 | 37 (10.5) | 31.4 | C: 34.3 | _-_ | - | _-_ | _-_ | No
| | | | | Ex: 0
| | | | | N: 65.7
Kim, 1999 | 16 | 56.3 | 48.6 (10.4) | 37.5 | C: 6.3 | _-_ | - | 20 (5) | _-_ | No
Kim, 1997 | 81 | 50.6 | 41.8 (8.1) | _-_ | - | _-_ | - | _-_ | _-_ | No
Kongerud, 1992 | 14 | 92.9 | 38.1 (9.7) | 28.6 | C: 50 | _-_ | 94.9 (9.9) | _-_ | _-_ | No
| | | | | Ex: 14.3
| | | | | N: 35.7
Kopferschmitt-Kubler, 1998 | 11 | 90.9 | 36.1 (7.3) | 54.5 | C: 18.2 | 9.1 | FEV_1_: 3.4 (0.5) | _-_ | _-_ | -
| | | | | Ex: 54.5
| | | | | N: 27.3
Koskela, 2003 | 37 | 35.1 | 42.8 (8.3) | _-_ | C: 13.5 | _-_ | - | _-_ | _-_ | Yes
Krakowiak, 2003 | 25 | _-_ | 41.9 (11.6) | 72 | C: 20 | 16 | FEV_1_: 3.9 (0.4) | 13 (7) | _-_ | No
| | | | | Ex: 12
| | | | | N: 68
Lam, 1979 | 86 | _-_ | 41.4 (10.5) | 23.3 | C: 7 | _-_ | - | _-_ | _-_ | No
| | | | | Ex: 18.6
| | | | | N: 74.4
LaPaglia, 1986 | 309 | _-_ | 55.6 (10.1) | _-_ | - | 5.2 | - | 32.8 (10.5) | _-_ | No
Larbanois, 2003 | 174 | 62.6 | 38.4 (10) | 58 | N: 59.8 | _-_ | - | _-_ | 3.41 (4.5) | Yes
Lemiere, 2001 | 31 | 90.3 | 42.1 (13) | 71 | C: 58.1 | _-_ | - | _-_ | 3.35 (4.9) | No
| | | | | Ex: 0
| | | | | N: 41.9
Liss, 1991 | 50 | 72 | 44 | 56 | - | _-_ | - | 12 | 3.5 | No
Lozewicz, 1985 | 7 | 42.9 | 43 (11) | 42.9 | C: 14.3 | _-_ | - | _-_ | _-_ | No
Malo, 1993a | 74 | 91.9 | _-_ | _-_ | C: 13.5 | _-_ | 91 (18) | 9.4 (8.1) | _-_ | Yes
| | | | | Ex: 41.9
| | | | | N: 44.6
Malo, 1991 | 162 | 77.2 | 39.6 (11.8) | 54.3 | C: 30.2 | _-_ | 92.7 (16.4) | 6.5 (8.8) | 1.9 (2.7) | Yes
| | | | | Ex: 40.7
| | | | | N: 27.2
Malo, 1990 | 164 | 76.2 | 38.8 (12.2) | 57.3 | C: 27.4 | _-_ | - | 8.8 (8.4) | 3.15 (3.4) | No
| | | | | Ex: 34.8
| | | | | N: 37.8
Malo, 1988a | 51 | 49 | 37 (10) | 39.2 | N: 49 | 7.8 | - | 10 (8) | _-_ | No
Mapp, 1986 | 6 | 66.7 | 31.7 (13) | 33.3 | C: 16.7 | _-_ | 104 (20.6) | 11.6 (10) | 2.11 (2.3) | No
| | | | | Ex: 33.3
| | | | | N: 50
Mapp, 1979 | 15 | 86.7 | 36.8 (12.2) | _-_ | C: 6.7 | _-_ | FEV_1_: 3.6 (0.7) | 7 | _-_ | No
| | | | | Ex: 13.3
| | | | | N: 80
Merget, 1997 | 34 | 76.5 | 26 (10.5) | _-_ | - | _-_ | - | 7.7 (8.4) | _-_ | -
Merget, 1996 | 57 | 94.7 | 37 (10) | 49.1 | C: 54.4 | 0 | 98 (14) | _-_ | 5.25 (5.3) | Yes
| | | | | Ex: 17.5
| | | | | N: 10.5
Merget, 1993 | 42 | _-_ | _-_ | 38.1 | C: 35.7 | _-_ | - | 9.5 (8.5) | _-_ | No
| | | | | Ex: 42.9
| | | | | N: 21.4
Mole, 1977 | 40 | 100 | 34.6 (6) | _-_ | C: 37.5 | _-_ | - | _-_ | _-_ | No
Moller, 1986 | 12 | 83.3 | 41.1 (14.6) | 16.7 | C: 25 | 16.7 | - | 2.1 (3) | _-_ | Yes
| | | | | Ex: 25
| | | | | N: 50
Moller, 1985 | 7 | _-_ | _-_ | 28.6 | - | 28.6 | - | _-_ | _-_ | No
Moscato, 1993 | 75 | 85.3 | 40.1 (10.5) | 41.3 | C: 29.3 | _-_ | - | 19.5 (31.8) | 4.2 (5.4) | No
| | | | | Ex: 26.7
| | | | | N: 42.7
Munoz, 2004 | 8 | 0 | 37 (7.3) | 37.5 | C: 37.5 | _-_ | FEV_1_: 2.9 (0.7) | 11 (5.5) | _-_ | No
Nielsen, 1988 | 5 | _-_ | _-_ | _-_ | - | _-_ | - | 13.8 (9.7) | _-_ | No
Nordman, 1985 | 12 | 25 | _-_ | 16.7 | - | _-_ | FEV_1_: 2.8 (0.7) | _-_ | _-_ | No
O'Brien, 1979a | 24 | 100 | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
O'Brien, 1979b | 63 | _-_ | 43 (8.8) | 36.5 | C: 22.2 | _-_ | - | _-_ | _-_ | -
| | | | | Ex: 23.8
| | | | | N: 36.5
Obata, 1999 | 17 | 100 | 35.3 (10.6) | 70.6 | C: 0 | _-_ | - | 6.2 (9.2) | 2.1 (2.7) | Yes
| | | | | Ex: 5.9
| | | | | N: 94.1
Obtulowicz, 1998 | 49 | 59.2 | 48.5 (8.3) | 36.7 | C: 46.9 | _-_ | - | _-_ | _-_ | Yes
Paggiaro, 1987b | 332 | _-_ | 25.5 (12) | 36.1 | N: 67.8 | _-_ | - | _-_ | _-_ | No
Paggiaro, 1986 | 114 | 75.4 | 46.2 (11.8) | 20.2 | C: 19.3 | _-_ | - | _-_ | 3.69 (3.5) | No
| | | | | Ex: 22.8
| | | | | N: 57
Paggiaro, 1984b | 6 | 33.3 | 37.2 (11.7) | 50 | C: 50 | _-_ | 95.5 (20.2) | 11.8 (4.4) | 5.7 (1.3) | No
| | | | | Ex: 0
| | | | | N: 50
Paggiaro, 1984c | _-_ | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Paggiaro, 1981 | 3 | 100 | 49.3 (13.4) | 33.3 | C: 100 | _-_ | 93.3 (14) | 3.3 (3.9) | 3.1 (4.1) | Yes
| | | | | Ex: 0
| | | | | N: 0
Palczynski, 2003 | 6 | 16.7 | 43.7 (7.9) | 16.7 | C: 0 | _-_ | - | _-_ | _-_ | No
Park, 2002b | 4 | _-_ | 24.8 (1.3) | 75 | C: 0 | _-_ | - | _-_ | _-_ | No
| | | | | Ex: 0
| | | | | N: 100
Park, 2001 | 136 | 89 | 40.8 (8.7) | 38.2 | - | _-_ | - | 9.2 (5.2) | _-_ | No
Park, 1999 | 63 | 73 | 38.5 (10.6) | 52.4 | - | _-_ | - | 5.7 (5.6) | _-_ | No
Park, 1998 | 15 | 100 | _-_ | 93.3 | - | _-_ | - | _-_ | _-_ | No
Park, 1994 | 4 | 100 | 42 (13) | 75 | C: 0 | _-_ | - | _-_ | _-_ | No
| | | | | Ex: 100
| | | | | N: 0
Park, 1991 | 13 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Park, 1989 | 9 | 100 | 35.6 (6) | 33.3 | C: 44.4 | _-_ | FEV_1_: 3.5 (0.6) | 1.5 (0.5) | _-_ | No
| | | | | Ex: 55.6
| | | | | N: 0
Perrin, 1990 | 23 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | -
Pezzini, 1984 | 28 | 64.3 | _-_ | 25 | - | _-_ | - | 12.2 (8.5) | _-_ | No
Prichard, 1984 | 20 | 100 | 32 | _-_ | C: 45 | _-_ | FEV_1_: 4 | _-_ | _-_ | No
| | | | | Ex: 15
| | | | | N: 40
Quirce, 2000 | 5 | 80 | 49.2 (9.5) | 60 | C: 0 | _-_ | - | 23.8 (12.8) | 11.7 (5.9) | No
| | | | | Ex: 20
| | | | | N: 80
Quirce, 1992 | 5 | 80 | 40.8 (17.2) | 80 | C: 60 | _-_ | 90 (8.2) | 22.2 (15.8) | 7.4 (5.6) | No
| | | | | Ex: 0
| | | | | N: 40
Rasanen, 1994 | 28 | 39.3 | 37.6 (9) | _-_ | - | _-_ | - | _-_ | _-_ | Yes
Redlich, 1996 | 3 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Ricciardi, 2003 | 9 | 77.8 | 47.3 (10.6) | 11.1 | C: 11.1 | _-_ | FEV_1_: 4.4 (0) | _-_ | _-_ | No
| | | | | Ex: 0
| | | | | N: 88.9
Sander, 2001 | 7 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Sastre, 2003 | 22 | 81.8 | 38.6 (10.6) | 36.4 | C: 4.5 | _-_ | - | 13.7 (9.1) | 3.7 (3.1) | No
| | | | | Ex: 9.1
| | | | | N: 81.8
Schuermans, 2003 | 39 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Schwaiblmair, 1997 | 55 | 0 | 30.8 (14.1) | 14.5 | C: 34.5 | _-_ | FEV_1_: 3 (0.7) | 15.1 (14.8) | 4.8 (5.2) | No
Schwarting, 1979 | _-_ | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | No
Shirai, 2003 | 21 | 42.9 | 44 (14.5) | 52.4 | C: 14.3 | _-_ | - | _-_ | 3.17 (4.3) | No
| | | | | Ex: 33.3
| | | | | N: 52.4
Shirakawa, 1988 | 12 | _-_ | 48.3 (5.4) | 66.7 | C: 41.7 | _-_ | - | _-_ | _-_ | Yes
Slovak, 1981 | 28 | 100 | 41 (8.5) | 46.4 | C: 42.9 | 0 | - | _-_ | _-_ | No
| | | | | Ex: 32.1
| | | | | N: 25
Symington, 1981 | 8 | 37.5 | _-_ | 25 | - | _-_ | - | 8.1 (4) | _-_ | No
Tabar, 2004 | 10 | 20 | 38.3 (10.2) | 60 | - | _-_ | - | _-_ | _-_ | No
Taivainen, 1994 | 100 | 47 | 44 (10.8) | _-_ | C: 4 | 97 | - | _-_ | _-_ | No
| | | | | Ex: 28
| | | | | N: 68
Tee, 1998 | 101 | 93.1 | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | -
Tse, 1982 | 28 | _-_ | _-_ | _-_ | - | _-_ | - | _-_ | _-_ | -
Vandenplas, 2001 | 45 | 4.4 | 33.6 (6.1) | 68.9 | N: 73.3 | 20 | - | _-_ | 3.01 (2.8) | No
Vandenplas, 1995b | 13 | 0 | 33 (4) | 53.8 | C: 15.4 | _-_ | 97.4 (9.7) | _-_ | 4 (3) | Yes
| | | | | Ex: 23.1
| | | | | N: 61.5
Vanhanen, 2000 | 11 | 36.4 | 36.5 (7.2) | 63.6 | C: 27.3 | _-_ | 93.5 (8.2) | _-_ | _-_ | -
Virtanen, 1996 | 11 | 63.6 | 46 (7.3) | _-_ | - | _-_ | - | _-_ | _-_ | No
Vogelmeier, 1991 | 19 | 94.7 | 49.4 (2.5) | _-_ | - | _-_ | - | 6 (5.8) | _-_ | No
Wurzinger, 1997 | 5 | 40 | 39.6 (19.3) | _-_ | - | _-_ | - | _-_ | _-_ | No
Zeiler, 2002 | 9 | 66.7 | 40 (10) | 66.7 | C: 0 | _-_ | - | _-_ | _-_ | No
| | | | | Ex: 44.4
| | | | | N: 55.6
Zeiss, 1977 | 4 | _-_ | 40.3 (13.4) | 25 | - | _-_ | - | 2 (2.7) | _-_ | No

Abbreviations: C = current; Ex = ex; FEV _ 1 _ = forced expiratory volume in one second; N = never; PEF = peak expiratory flow; SD = standard deviation

Table E-3 Description of diagnostic tests (Diagnosis review)

Author, Year | Highest Reference Standard | | | Comparison Tests
| Test | Positive Response | Methodology | Test | Positive Response | Methodology
Alvarez, 2001 | SIC: oilseed rape flour | ≧20% decline in FEV_1_ | Referenced (Chatham et al., 1982) | Eosinophils: sputum | Not reported | Described in text
| | | | Single NSBPT: methacholine | Not reported | Referenced (Chatham et al., 1982)
| | | | Skin prick: atopy and specific | Wheal diameter ≧3 mm | Referenced (Dreborg, 1989)
| | | | Serum specific IgE | >0.35 KU/L | CAP
Alvarez, 1996 | SIC: cereals (wheat, alpha amylase, soyabean, l.destructor) | ≧20% decline in FEV_1_ | Described in text | Single NSBPT: methacholine | PD_20_ FEV_1_ ≦250 cbu | Referenced (Chatham et al., 1982)
| | | | Skin prick: atopy | Wheal diameter ≧3 mm with no reaction to negative control | Referenced (Chatham et al., 1982)
| | | | Serum specific IgE | CAP score ≧class 1 | CAP
Anees, 2004 | Other: clinical diagnosis | SIC and/or serum specific IgE and/or serial NSBPT | Not reported | Serial PFT (PEFR): monitored at least 3 times/day for at least 5 work (4–6 days) and rest (2–3 days) periods | OASYS-2 score >2.5 | Referenced (Burge et al., 1999)
Avery, 1969 | Other: clinical diagnosis | Not reported | Not reported | Other: TDI-HSA | Not reported | Described in text
Balland, 1989 | SIC: suspected agent | ≧100% increase in specific airway resistance | Not reported | Single NSBPT: methacholine | ≧2 fold increase in airway resistance between 0–1500 gamma of methacholine | Not reported
| | | | Serum specific IgE | Not reported | RAST
| | | | Serum total IgE | Not reported | Not reported
Baur, 1998 | SIC: suspected agent | ≧40% decline in sGaw | Referenced (Jaeger et al., 1992; Marek et al., 1994; Schwaiblmair et al.1991) | Clinical diagnosis | Case history: reversible airway narrowing in the sense of SOB and wheezing causally related to exposure in the working environment | Described in text
| | | | Single NSBPT: methacholine | PD_40_ sGaw <0.3 mg | Described in text
Baur, 1979 | SIC: papain | Not reported | Not reported | Skin prick: atopy and specific | Not reported | Referenced (Aas and Belin, 1972)
| | | | Serum specific IgE | Not reported | RAST
Behr, 1990 | SIC: isocyanates | ≧100% increase in sRaw from baseline and absolute values ≧2.0 kPa/s | Described in text | Clinical diagnosis | Not reported | Not reported
| | | | Single NSBPT: methacholine | ≧100% increase in sRaw from baseline and absolute values ≧2.0 kPa/s | Described in text
Bernstein, 2002 | SIC: isocyanates | ≧20% decline in FEV_1_ | Referenced (Ryan et al., 1981; Stark et al., 1993) | Other: di-isocyanate antigen stimulation of MCP-1 | Maximal antigen stimulation of MCP-1 ≧mean + 2SD of control subjects | Described in text
| | | | Single NSBPT: methacholine | PC_20_ FEV_1_ ≦8 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Serum specific IgE | OD at 405 ≧0.1 | ELISA
Biot, 1980 | SIC: suspected agent | Not reported | Described in text | Other: basophils granules liberation | Not reported | Referenced (Benveniste et al., 1976)
| | | | Single NSBPT: acetylcholine | Not reported | Not reported
| | | | Serum total IgE | Not reported | Not reported
Block, 1983 | SIC: wheat and/or rye flour | ≧20% decline in FEV_1_ | Referenced (Lam et al., 1979) | Single NSBPT: methacholine | PC_20_ FEV_1_: no cutoff reported | Referenced (Lam et al., 1979)
| | | | Skin prick: atopy and specific | Wheal diameter ≧2 mm | Referenced (Cockcroft et al., 1979)
| | | | Serum specific IgE | Not reported | RAST
Burge, 1985 | SIC: formaldehyde | Not reported | Described in text | Single NSBPT: histamine | PC_20_ FEV_1_ ≦32 mg/ml | Referenced (deVries et al., 1964)
Burge, 1982b | SIC: suspected agent | Not reported | Described in text | Single NSBPT: histamine | PD_20_ FEV_1_ <32 mg/mL | Referenced (O'Brien et al., 1979)
Burge, 1980 | SIC: colophony, abietic acid, methyl ester, glycerol ester, amine hydrocholride | ≧15% decline in FEV_1_ | Described in text | Single NSBPT: histamine | PC_20_ FEV_1_ ≦16 mg/ml | Referenced (deVries et al., 1964)
Burge, 1979a | SIC: solder-flux fumes | ≧15% decline in FEV_1_ | Referenced (Burge et al., 1978) | Clinical diagnosis | History and effects of subsequent exposure at work | Described in text
| | | | Serial PFT (PEFR): monitored every hour while away for at least 2 wks at work and at least 2 wks away | Comparison of recordings taken at work compared to those taken away from work | Described in text
Burge, 1979b | SIC: isocyanates | ≧15% decline in FEV_1_ | Referenced (O'Brien et al., 1979) | Clinical diagnosis | Final assessment based on subsequent course of asthma on re-exposure at work | Described in text
| | | | Serial PFT (PEFR): monitored every hour or 2 hrs for at least 2 wks at work and 2 wks away | ≧25% of cases demonstrated specific daily pattern with a weekly pattern | Referenced (Burge et al., 1979)
Burge, 1978 | SIC: colophony | >15% decline in FEV_1_ | Not reported | Eosinophils: blood | Not reported | >400/mm^3^
| | | | Single PFT: FEV_1_, FVC | Not reported | Described in text
| | | | Skin prick: atopy | Mean wheal diameter >2 mm with negative control | Not reported
Butcher, 1980 | SIC: TDI | Not reported | Not reported | Serum specific IgE | 2 definitions: ratio >2; test cpm >control mean + 3SD | RAST
| | | | Serum total IgE | Not reported | PRIST
Carletti, 1997 | SIC: wheat flour | >20% decline in FEV_1_ | Described in text | Clinical diagnosis | Symptoms of cough, expectoration,wheezing, dyspnea, difficulties breathing associated with exposure to wheat powder/flour | Described in text
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_ <1 mg | Referenced (Piaggaro et al., 1990)
| | | | Single PFT: FVC, FEV(25–75) | Not reported | Described in text
| | | | Skin prick: atopy and specific | Mean wheal diameter ≧5 mm for atopy and ≧3 mm for specific | Described in text
Cartier, 1989 | SIC: isocyanates | ≧3 consecutive values with ≧20% decline in FEV_1_ and fluctuations not exceeding 10% on the control | Referenced (Pepys and Hutchcroft, 1975) | Serial NSBPT: histamine or methacholine | ≧3.2 fold change in PC_20_ FEV_1_ before and after SIC | Not reported
| | | | Single NSBPT: histamine or methacholine | PC_20_ FEV_1_ ≦16 mg/ml | Not reported
| | | | Skin prick: atopy and specific | Wheal diameter ≧3 mm without dermographism and with wheal diameter ≧3 mm to histamine control | Described in text
| | | | Serum specific IgE | OD reading ≧two times the OD of the mean of the negative controls | ELISA
| | | | Serum specific IgG | OD reading ≧two times the OD of the mean of the negative controls | ELISA
Cartier, 1987 | SIC: psyllium | ≧20% decline in FEV_1_ | Referenced (Pepys and Hutchcroft, 1975) | Single NSBPT: histamine | PC_20_ FEV_1_ <8 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy and specific | Not reported | Described in text
| | | | Serum specific IgE | Not reported | RAST
Cartier, 1986 | SIC: snowcrab extract | Not reported | Not reported | Skin prick: specific^1^ | Wheal diameter >2 mm larger than control | Referenced (Pepys, 1975)
| | | | Serum specific IgE^1^ | 2 cutoff values: >2; >4.5 | RAST
| | | | Eosinophils: blood^2^ | >500 cells/cc | Not reported
| | | | Serial NSBPT: histamine^2^ | ≧3.2 fold change in PC_20_ FEV_1_ upon return to work | Referenced (Cockcroft et al., 1977)
| | | | Single NSBPT: histamine^2^ | PC_20_ FEV_1_ ≦16 mg/ml | Referenced (Cockcroft et al., 1977)
Choudat, 1999 | SIC: wheat flour | ≧20% decline in FEV_1_ | Referenced (Cloutier et al., 1989) | Single NSBPT: methacholine | PD_20_ FEV_1_: no cutoff | Referenced (Sterk et al., 1993)
| | | | Serum specific IgE | Not reported | CAP
Cirla, 1975 | SIC: TDI | Not reported | Described in text | Single NSBPT: acetylcholine | Not reported | Described in text
| | | | Skin prick: atopy and specific | Not reported | Described in text
Colas, 1985 | SIC: wood dust (exotic) | ≧100% increase in specific airway resistance | Described in text | Eosinophils: blood | Not reported | Not reported
| | | | Other: carbon dioxide diffusion | Not reported | Not reported
| | | | Single NSBPT: carbachol | ≧100% increase in airways resistance (threshold dose) | Not reported
| | | | Single PFT: FEV_1_, FVC | Presence of “trouble ventilatoire obstructif” (airway obstruction) | Not reported
| | | | Skin prick: atopy and specific | Not reported | Not reported
| | | | Serum total IgE | Not reported | Not reported
Cortona, 1980 | Other: clinical diagnosis | Included results from ECSC questionnaire and lung function testing | Described in text | Skin prick: atopy and Specific | Not reported | Referenced (Pepys, 1969)
Cote, 1993 | SIC: plicatic acid | ≧15% decline in FEV_1_ | Referenced (Chan-Yeung et al., 1973) | Serial PFT (PEFR): monitored 6 times/day for 3 wks at work and 2 wks away^3^ | 2 of 3 physicians agreed that PEF graphs showed work related change in 2 of 3 work wks | Referenced (Burge et al., 1979)
| | | | Other: questionnaire^3^ | Not reported | Not reported
| | | | Serial NSBPT: methacholine^4^ | >2 fold decrease in PC_20_ FEV_1_ after 3 work wks compared to after 2 holiday wks | Referenced (Lam et al., 1979)
Coutts, 1984 | SIC: cimetidine powder | Not reported | Not reported | Single NSBPT: histamine | Not reported | Not reported
| | | | Skin prick: atopy and specific | Not reported | Not reported
Curran, 1996 | Other: clinical diagnosis | Not reported | Not reported | Serum specific IgE | >0.88 net RAST % binding with serum total IgE equal to or less than 150 kU/L | RAST
| | | | Serum total IgE | <150 kU/L | RIACT
Davison, 1983 | SIC: castor beans | Not reported | Referenced (Davies et al., 1974) | Skin prick: atopy Serum specific IgE | Not reported | Not reported
| | | | | % binding >2 times the control | RAST
DeZotti, 1996a | SIC: wood dust (exotic) | ≧15% decline in FEV_1_ | Described in text | Eosinophils: blood | Not reported | Not reported
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_: no cutoff | Not reported
| | | | Single PFT: FEV_1_, FVC | Not reported | Described in text
| | | | Skin prick: atopy | Wheal diameter >3 mm | Described in text
DeZotti, 1996b | SIC: suspected agent | ≧15% decline in FEV_1_ | Described in text | Eosinophils: blood | Not reported | Described in text
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_: no cutoff | Described in text
| | | | Single PFT: FEV_1_ | Not reported | Described in text
| | | | Skin prick: atopy | Wheal diameter ≧3 mm | Not reported
| | | | Serum specific IgE | Not reported | RAST
Dellabianca, 1996 | SIC: suspected agent | ≧15% decline in FEV_1_ | Not reported | Single NSBPT: methacholine | PD_20_ FEV_1_ ≦1560 μ | Described in text
Dente, 1986 | SIC: TDI | Not reported | Described in text | Single NSBPT: methacholine | PD_15_ FEV_1_ <1.0 mg | Not reported
DiFranco, 1998 | SIC: suspected agent | Not reported | Not reported | Eosinophils: sputum | >1% | Described in text
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_ <1 mg | Described in text
DiStefano, 1999 | Other: clinical diagnosis | Included SIC and/or serial PFT | Described in text | Single NSBPT: histamine | Not reported | No reference (Yan method)
| | | | Skin prick: atopy | Wheal diameter >3 mm | Not reported
Duan, 1989 | SIC: TDI | ≧15% decline in FEV_1_ (lasted 15 minutes) | Described in text | Clinical diagnosis | Asthma symptoms at work, better or no symptoms away from work | Described in text
| | | | Serial NSBPT: methacholine | 2 times (Chinese translation) | Referenced (Cockcroft et al., 1977)
| | | | Serial PFT: PEFR | Not reported | Described in text
| | | | Single PFT: FEV_1_ (including reversibility) | FEV_1_ decrease 15–20% | Described in text
| | | | Skin prick: specific | Not reported | Described in text
| | | | Serum specific IgE | Not reported | ELISA
Ferguson, 1996 | SIC: isocyanates | ≧15% decline in FEV_1_ (persistent) | Described in text | Single NSBPT: histamine | Not reported | Referenced (Cockcroft et al., 1977)
| | | | Single PFT: FEV_1_, FVC (including reversibility) | Reversibility: ≧15% increase in FEV_1_ | Referenced (American Thoracic Society, 1987)
| | | | Serum specific IgE | Not reported | RAST
Gannon, 1996 | Other: clinical diagnosis | Included SIC and/or bronchial hyperreactivity and/or serum specific IgE (RAST) and/or asymptomatic | Not reported | Serial PFT (PEFR): monitored every 2 hrs for 2 wks at work and 2 wks away | OASYS-2 score ≧2.51 | Referenced (Burge et al., 1979)
Girard, 2004 | SIC: suspected agent | Not reported | Referenced (Cartier, 1997) | Eosinophils: sputum | 3 cutoffs used: >1%, 2%, or 6.4% | Referenced (Pizzichini et al., 1996)
| | | | Serial NSBPT: methacholine | ≧3.2 fold change in PC_20_ FEV_1_ between at work and away | Referenced (Juniper et al., 1994)
| | | | Serial PFT: PEFR | 2 definitions: OASYS-2 score ≧2.51; clinical opinion | Referenced (Burge et al., 1979)
| | | | Skin prick: atopy | Not reported | Not reported
Graneek, 1987 | SIC: suspected agent | >15% decline in FEV_1_ | Referenced (Pepys and Hutchcroft, 1975) | Single NSBPT: histamine | PC_20_ FEV_1_ ≦16 mg/ml | Referenced (Cockcroft et al., 1977)
Grosclaude, 1980 | SIC: suspected agent | ≧50% increase in airway resistance | Described in text | Single NSBPT: acetylcholine | Dose provoking augmentation of 50% of airway resistance ≦1000 μ | Not reported
| | | | Skin prick: atopy and specific | Not reported | Not reported
| | | | Serum total IgE | Not reported | Not reported
Harries, 1980 | SIC: suspected agent | ≧15% decline in FEV_1_ | Described in text | Eosinophils: blood Skin prick: atopy | Not reported | Not reported
| | | | | Wheal diameter >3 mm to at least 1 allergen with negative reaction to control | Described in text
Hinojosa, 1986 | SIC: wood dust (African maple and ramin) | ≧20% decline in FEV_1_ | Described in text | Skin prick: atopy and specific | Not reported | Described in text
| | | | Serum specific IgE | Not reported | REIA
| | | | Serum total IgE | Not reported | Not reported
Howe, 1993 | SIC: lactose powder, TCPA powder, epoxy resin powder, blue pigment powder | ≧15% decline in FEV_1_ | Described in text | Skin prick: atopy and specific^5^ | Wheal diameter >2 mm larger than control | Described in text
| | | | Serum specific IgE^5^ | Not reported | RAST
| | | | Single NSBPT: histamine^6^ | Not reported | Not reported
Huggins, 2003 | Other: clinical diagnosis | Included symptoms and/or serum specific IgE and/or SPT | Not reported | Serial PFT (PEFR): monitored every 2 hrs for 4 wks | Various definitions: expert interpretation; OASYS-2 score ≧2.75; rest-work PEF ≧16 L/min; daily variation at work >daily variation away | Referenced (OASYS)
Jager, 1993 | SIC: latex | 100% increase in sRaw to at least 5 cm H2O/L/s | Described in text | Other: supervised work challenge | Not reported | Described in text
| | | | Single NSBPT: methacholine | Not reported | Not reported
| | | | Skin prick: atopy and specific | Not reported | Described in text
| | | | Serum specific IgE | Not reported | Not reported
| | | | Serum total IgE | Not reported | Not reported
Karol, 1994 | SIC: TDI | ≧20% decline in FEV_1_ | Referenced (Mapp et al., 1988) | Clinical diagnosis | Clinical and workplace history | Described in text
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_ <1.4 mg | Referenced (Chai et al., 1975)
| | | | Serum specific IgE | >mean + 2SD of control subjects | RAST
| | | | Serum specific IgG | Not reported | ELISA
| | | | Serum total IgE | >114 IU/ml | IgE RIA
Kern, 1991 | Other: clinical diagnosis | Based on criteria for diagnosis of RADS | Referenced (Harkonen et al., 1983) | Single NSBPT: methacholine | PD_20_ FEV_1_: no cutoff | Referenced (O'conner et al., 1987)
Keskinen, 1988 | SIC: isocyanates | ≧20% decline in PEF or 15–19% if other supporting findings | Referenced (Newman-Taylor and Davies, 1981) | Skin prick: atopy | Reaction >1/2 reaction to histamine to at least 1 allergen with negative reaction to dilutant | Referenced (Belin and Wass, 1981)
| | | | Serum specific IgE | Ratio values ≧2 with absorbance reading ≧1/2 of the D-reference point | RAST
Kim, 1999 | SIC: citrus red mite | Not reported | Described in text | Single NSBPT: methacholine | PC_20_ FEV_1_ <16 mg/ml | Referenced (Chai et al., 1975)
| | | | Single PFT: FEV_1_ | Reversibility: ≧15% increase in FEV_1_ | Not reported
| | | | Skin prick: atopy and specific | Allergen:histamine wheal diameter ratio >1 | Described in text
| | | | Serum specific IgE | Absorbance value >0.24 | ELISA
| | | | Serum total IgE | ≧160 IU/ml | DPC kit
Kim, 1997 | Other: clinical diagnosis | Included symptoms and serial PFT | Described in text | Single PFT: FEV_1_, FVC | Not reported | Described in text
| | | | Serum specific IgE | Counts per minute of reference disk was >2 times control disk | RAST
| | | | Serum specific IgG | OD ratio >mean +/- 3SD for negative control | ELISA
Kongerud, 1992 | Other: serial PFT | >15% variation in diurnal PEF | Referenced (Burge, 1982) | Clinical diagnosis | Criteria proposed by Burge (1982) | Described in text
| | | | Eosinophils: blood | Not reported | Not reported
| | | | Other: symptom score | Not reported | Described in text
| | | | Serial NSBPT: methacholine | >2 fold change in PC_20_ FEV_1_ between work and away periods | Referenced (Cockcroft et al., 1977)
| | | | Single NSBPT: methacholine | PC_20_ FEV_1_ <8 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Serum total IgE | Not reported | Not reported
Kopferschmitt-Kubler, 1998 | SIC: TDI | ≧20% decline in FEV_1_ | Described in text | Serial PFT (FEV_1_): monitored at least 3 times/day on a 1 month diary card | Not reported | Described in text
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_ <3200 μ | Not reported
Koskela, 2003 | SIC: bovine dander | >15% decline in FEV_1_ | Not reported | Exhaled nitric oxide | >46 ppm | Not reported
| | | | Single NSBPT: histamine or mannitol | Histamine: PC_20_ FEV_1_ <8mg/mL / mannitol: >15% decrease in FEV_1_ | Referenced (histamine: Cockcroft et al., 1974; mannitol: Anderson et al., 1997)
| | | | Skin prick: specific | Wheal diameter ≧3 mm | Referenced (Pepys, 1975)
| | | | Serum specific IgE | >5 IU/L | CAP
| | | | Serum total IgE | Not reported | Immulite 2000
Krakowiak, 2003 | SIC: rodent flour/dust | >20% decline in FEV_1_ | Described in text | Clinical diagnosis | Included medical history, physical examination and spirometry | Not reported
| | | | Eosinophils: nasal lavage | Not reported | Described in text
| | | | Single NSBPT: histamine | PC_20_ FEV_1_: no cutoff | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy and specific | Wheal 4mm >control; flare 5mm >control | Described in text
| | | | Serum specific IgE | Not reported | RAST
Lam, 1979 | SIC: red cedar, aerosol inhalation or exposure to work environment | Not reported | Referenced (Chan-Yeung et al., 1973) | Single NSBPT: methacholine | PC_20_ FEV_1_ ≦16 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy | ≧2 positive reactions | Not reported
LaPaglia, 1986 | SIC: wheat, straw, hay, wood, animal allergens | ≧15% decline in FEV_1_ | Described in text | Clinical diagnosis | Significant reduction in FEV_1_, shortness of breath, wheezing episodes | Described in text
| | | | Skin prick: atopy and specific | Not reported | Described in text
Larbanois, 2003 | SIC: suspected agent | ≧20% decline in FEV_1_ | Referenced (Vandenplas and Malo, 1997) | Serial PFT (sGaw): before and after SIC | 2 cutoff values: >35 decrease; >50% decrease | Described in text
| | | | Single NSBPT: histamine | PC_20_ FEV_1_ <16 mg/ml | Referenced (Cockcroft et al., 1977)
Lemiere, 2001 | SIC: suspected agent | ≧20% decline in FEV_1_ | Referenced (Cartier, 1994) | Eosinophils: sputum | ≧0.26x10^6^ cells/ml | Referenced (Pin et al., 1992)
| | | | Single NSBPT: methacholine | PC_20_ FEV_1_ <8 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy and specific | Wheal diameter ≧3 mm to at least 1 allergen with positive reaction to histamine and negative reaction to diluent | Not reported
Liss, 1991 | SIC: suspected agent | Not reported | Referenced (Pepys and Hutchcroft, 1975) | Serial PFT (PEFR): monitored 4 times/day for at least 2 wks at work and 2 wks away^7^ | ≧20% diurnal variation on at least 2 days with lowest value on a work day | Described in text
| | | | Single NSBPT: methacholine^7^ | PC_20_ FEV_1_ ≦8 mg/ml | Referenced (Juniper et al., 1978)
| | | | Single PFT: FEV_1_ (including reversibility)^7^ | Reversibility: ≧15% increase in FEV_1_ | Described in text
| | | | Skin prick: atopy and specific^7^ | Wheal diameter >2 mm larger than control ≧4 fold shift in PC_20_ | Not reported
| | | | Serial NSBPT: methacholine^8^ | FEV_1_ between after a day at work and after 10 to 14 days off work | Referenced (Cockcroft et al., 1977)
Lozewicz, 1985 | SIC: cyanoacrylate based susbstances | Not reported | Not reported | Single NSBPT: histamine | PC_10_ FEV_1_ ≦32 mg | Referenced (DeVries, 1960 and Cockcroft et al., 1977)
| | | | Skin prick: atopy | Not reported | Not reported
Malo, 1993a | SIC: suspected agent | Not reported | Not reported | Serial PFT (PEFR): monitored every 2 hrs for 2 wks at work and 2 wks away | Not reported | Referenced (Burge et al., 1979)
Malo, 1991 | SIC: red cedar, flour, psyllium, guar gum | >20% decline in FEV_1_ | Referenced (Pepys and Hutchcroft, 1975) | Other: Questionnaire | Not reported | Not reported
| | | | Serial NSBPT: histamine or methacholine | ≧3.2 fold change in PC_20_ FEV_1_ between work and away | Referenced (Cockcroft et al., 1977)
| | | | Serial PFT (PEFR): monitored every 2 hrs or at least 4 times/day | Interpreted by experienced physicians | Referenced (Burge et al., 1979)
| | | | Single NSBPT: histamine or methacholine | PC_20_ FEV_1_ ≦16 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy | Wheal diameter ≧3 mm to at least 1 allergen with positive reaction to histamine and negative reaction to diluent | Not reported
Malo, 1990 | SIC: suspected agent | Immediate: ≧15% decline in FEV_1_; late: ≧12% decline in FEV_1_ | Referenced (Pepys and Hutchcroft, 1975) | Single NSBPT: histamine or methacholine | PC_20_ FEV_1_ <16 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy | Immediate reaction within 10–15 minutes | Not reported
Malo, 1988a | SIC: spiromycin | ≧20% decline in FEV_1_ | Referenced (Pepys and Hutchcroft, 1975) | Eosinophils: blood | Not reported | Not reported
| | | | Other: questionnaire | Not reported | Not reported
| | | | Serial PFT (PEFR): monitored 4 times/day and when they had chest symptoms for 2 wks including weekends | >20% variation | Described in text
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_ ≦16 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy | Not reported | Described in text
Mapp, 1986 | SIC: TDI | Not reported | Described in text | Single NSBPT: methacholine | PD_20_ FEV_1_ ≦0.7 mg | Referenced (Chai et al., 1975)
| | | | Skin prick: atopy | Not reported | Not reported
Mapp, 1979 | SIC: isocyanates | >15% decline in FEV_1_, change in Vmax >20% and change in sGaw >25% | Referenced (Fantuzzi et al., 1973) | Single NSBPT: carbachol | >15% decline if FEV_1_: no cutoff, change in Vmax >20% and change in sGaw >25%/ND | Referenced (Orehek et al., 1977)
| | | | Skin prick: atopy | Not reported | Described in text
Merget, 1997 | SIC: wheat flour | ≧50% decline in sGaw after inhalation of 100 mg/ml flour extract, seven cumulative capsules or less | Not reported | Single NSBPT: methacholine | PD_50_ sGaw ≦1 mg | Referenced (Merget et al., 1994)
| | | | Skin prick: atopy and specific | Wheal diameter ≧3 mm larger than saline control | Referenced (Pepys, 1975)
| | | | Serum specific IgE | RAST ≧0.35 Phadebus RAST units/ml | RAST
| | | | Serum total IgE | Not reported | Enzymun-Test
Merget, 1996 | SIC: platinum salts | ≧50% decline in sGaw with platinum salt concentration ≦0.01 mol/L | Referenced (Merget et al., 1991) | Single NSBPT: methacholine | PD_50_ sGaw ≦8 mg/ml | Referenced (Merget et al., 1991)
| | | | Skin prick: atopy and specific | Atopy: wheal diameter ≧4 mm / Specific: wheal diameter ≧2 mm | Referenced (Pepys, 1975)
| | | | Serum total IgE | Not reported | PRIST
Merget, 1993 | SIC: enzymes | ≧50% decline in sGaw with enzyme concentration ≦10mg/ml | Described in text | Single NSBPT: methacholine | PD_50_ sGaw with dose <mg | Described in text
| | | | Skin prick: atopy and specific | Wheal diameter ≧histamine control | Described in text
| | | | Serum specific IgE | ≧0.35 PRU | EAST
| | | | Serum total IgE | Not reported | PRIST
Mole, 1977 | Other: clinical diagnosis | Included pulmonary function tests, ECG, chest x-ray, and skin prick tests | Described in text | Other: skin patch test | Not reported | Not reported
| | | | Single NSBPT: acetylcholine | >10% decrease in FEV_1_ | Referenced (Sadoul and Aubertin, 1956)
Moller, 1986 | SIC: TDI | ≧20% decline in FEV_1_ | Described in text | Clinical diagnosis | Clinical and occupational history | Described in text
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_: no cutoff | Described in text
| | | | Single PFT: FEV_1_, FVC, PEFR | Not reported | Criteria established by the American Thoracic Society
Moller, 1985 | Other: physician diagnosis | Based on shortness of breath, wheezing or coughing exacerbated at work and/or at night, improvement | Described in text | Eosinophils: not reported | Not reported | Not reported
| | | | Other: questionnaire | Not reported | Not reported
| | | | Serial PFT (FEV_1_): pre- and post- shift | >20% decline in FEV_1_ post-shift compared to pre-shift | Described in text
| | | | Serum specific IgE | ≧1 ng/ml | SPBRIA
Moscato, 1993 | SIC: TDI | ≧15% decline in FEV_1_ | Described in text | Single NSBPT: methacholine | PD_15_ FEV_1_ <0.85 mg | Referenced (Moscato et al., 1991)
| | | | Single PFT: FEV_1_, FVC | Not reported | Described in text
| | | | Skin prick: atopy | Wheal diameter >5 mm | Not reported
Munoz, 2004 | SIC: potassium persulfate | >20% decline in FEV_1_ more than placebo challenge | Referenced (Pepys and Hutchcroft, 1975) | Serial PFT (PEFR): monitored every 4 hrs for 2 wks at work and 2 wks away | Qualitative assessment revealed evident changes between periods | Described in text
| | | | Single NSBPT: methacholine | PC_20_ FEV_1_ <8 mg/ml | Referenced (Chai et al., 1975)
| | | | Skin prick: atopy and specific | Average of largest and smallest wheal diameter >3mm and more than reaction to histamine control | Referenced (Pepys, 1975)
| | | | Serum total IgE | >150 IU | UniCAP
Nielsen, 1988 | Other: clinical diagnosis | Included symptoms during employment and unequivocal and plausible relation to irritant exposure | Described in text | Single NSBPT: methacholine | Not reported | Not reported
| | | | Skin prick: atopy and specific | Wheal area >1/2 of histamine reaction | Not reported
| | | | Serum specific IgE | Ratio >2.2 | RAST
| | | | Serum specific IgG | Not reported | ELISA
| | | | Serum total IgE | Not reported | Not reported
Nordman, 1985 | SIC: formaldehyde | Immediate: ≧15% decline in PEF; late: ≧20% decline in PEF | Referenced (Pepys et al., 1972; Newman-Taylor and Davies, 1981) | Eosinophils: not reported | Not reported | Not reported
| | | | Serial PFT (PEFR): monitored every 3 hrs for at least 24 hrs before SIC | Not reported | Not reported
| | | | Single NSBPT: histamine or methacholine | Histamine: ≧15% drop in PEF / methacholine: Not reported | Referenced (histamine: Laitinen, 1974; methacholine: Hargreave et al., 1981)
| | | | Single PFT: FEV_1_, FVC (including reversibility) | Reversibility: ≧15% increase and 150 ml in FEV_1_ | Described in text
| | | | Serum total IgE | Not reported | Not reported
O'Brien, 1979a | SIC: isocyanates | ≧15% decline in FEV_1_ | Described in text | Single NSBPT: histamine | ≧20% decline in FEV_1_ ≦32 mg/ml | Described in text
O'Brien, 1979b | SIC: TDI | ≧15% decline in FEV_1_ | Described in text | Other: exercise test | >9% fall in FEV_1_ or PEFR | Described in text
| | | | Single NSBPT: histamine | PC_20_ FEV_1_ ≦32 mg/ml | Described in text
| | | | Skin prick: atopy | Not reported | Not reported
Obata, 1999 | SIC: plicatic acid | >20% decline in FEV_1_ or PEF | Referenced (Chan-Yueng et al., 1982) | Eosinophils: sputum | Not reported | Described in text
| | | | Exhaled nitric oxide | Not reported | Described in text
| | | | Single NSBPT: methacholine | PC_20_ FEV_1_ ≦8 mg/ml | Referenced (Lam et al., 1979)
| | | | Skin prick: atopy | Wheal diameter ≧3 mm larger than negative control | Described in text
Obtulowicz, 1998 | SIC: suspected agent | >20% decline in FEV_1_ and MEF 25–75% | Described in text | Eosinophils: blood | Not reported | Not reported
| | | | Skin prick: atopy and specific | Not reported | Described in text
| | | | Serum total IgE | Not reported | ELISA
Paggiaro, 1987b | SIC: plicatic acid | >20% decline in FEV_1_ | Referenced (Lam et al., 1983) | Single NSBPT: methacholine | PC_20_ FEV_1_: no cutoff reported | Referenced (Lam et al., 1979)
| | | | Skin prick: atopy and specific | Wheal diameter ≧3 mm | Described in text
| | | | Serum specific IgE | Ratio >2.0 | RAST
Paggiaro, 1986 | SIC: TDI | ≧15% decline in FEV_1_ | Described in text | Single NSBPT: methacholine | PD_20_ FEV_1_ ≦2 mg | Described in text
| | | | Skin prick: atopy | Wheal diameter >5 mm | Not reported
Paggiaro, 1984b | SIC: enzymes | >15% decline in FEV_1_ | Described in text | Single NSBPT: bethanechol | >15% decline in FEV_1_: no cutoff reported | Referenced (Parlanti et al., 1983)
| | | | Skin prick: atopy and specific | Wheal diameter ≧5 mm | Described in text
| | | | Serum specific IgE | Not reported | RAST
| | | | Serum total IgE | Not reported | PRIST
Paggiaro, 1984c | SIC: isocyanates | ≧15% decline in FEV_1_ | Referenced (Zedda et al., 1976) | Clinical diagnosis | Presence of dyspnea, wheezing from exposure to TDI or MDI and a positive response to SIC | Described in text
| | | | Single NSBPT: bethanechol | PD_15_ FEV_1_ ≦8 | Described in text
Paggiaro, 1981 | SIC: wood dust (tanganyika aningre) | Not reported | Referenced (Pickering et al., 1972) | Single NSBPT: acetylcholine or bethanechol | Not reported | Not reported
| | | | Skin prick: atopy and specific | Not reported | Not reported
| | | | Serum specific IgE | Not reported | RAST
Palczynski, 2003 | SIC: chloramine | Not reported | Not reported | Eosinophils: nasal lavage | Not reported | Referenced (Greiff et al., 1990)
| | | | Single NSBPT: histamine | Not reported | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy and specific | Wheal diameter >3 mm larger than negative control | Not reported
| | | | Serum specific IgE | >35 KU/L | RAST
| | | | Serum total IgE | >35 KU/L | RAST
Park, 2002b | SIC: porcine pancreatic extract | ≧20% decline in FEV_1_ | Referenced (Park and Nahm, 1997) | Other: immunoblotting | Not reported | Described in text
| | | | Single NSBPT: methacholine | Not reported | Referenced (Chai et al., 1977)
| | | | Skin prick: specific | Not reported | Not reported
| | | | Serum specific IgE | >mean + 2SD of unexposed controls | ELISA
Park, 2001 | SIC: reactive dyes | ≧20% decline in FEV_1_ | Not reported | Skin prick: atopy and specific | Wheal diameter >2 mm larger than negative control and erythema reaction >21 mm | Described in text
| | | | Serum specific IgE | OD at 410 >0.013 | ELISA
Park, 1999 | SIC: TDI | Not reported | Referenced (Park et al., 1999) | Single NSBPT: methacholine | PC_20_ FEV_1_: no cutoff reported | Referenced (Park et al., 1999)
| | | | Single PFT: not reported | Not reported | Not reported
| | | | Skin prick: atopy | Not reported | Not reported
| | | | Serum specific IgE | >mean + 2SD of control subjects | ELISA
Park, 1998 | SIC: grain dust | ≧20% decline in FEV_1_ | Referenced (Park and Nahm, 1997) | Eosinophils: blood | Not reported | SDS-Page
| | | | Other: Immunoblotting | Not reported | Not reported
| | | | Single NSBPT: methacholine | PD_20_ FEV_1_ ≦25 mg/ml | Referenced (Chai et al., 1975)
| | | | Skin prick: atopy and specific | Allergen:histamine area ratio between 0.1 and 1 and erythema >21 mm | Described in text
| | | | Serum specific IgE | ≧0.064 | ELISA
Park, 1994 | SIC: chromium salts | ≧20% decline in FEV_1_ | Described in text | Other: skin patch test | Not reported | Described in text
| | | | Serial PFT (PEFR): monitored every 2 hrs for 2 days at work | Not reported | Not reported
| | | | Single NSBPT: methacholine | PC_20_ FEV_1_ ≦25 mg/ml | Referenced (Chai et al., 1975)
| | | | Skin prick: atopy and specific | Not reported | Described in text
Park, 1991 | SIC: reactive dyes | ≧20% decline in FEV_1_ | Referenced (Park et al., 1989) | Single NSBPT: methacholine | PC_20_ FEV_1_ ≦5 mg/ml | Referenced (Chai et al., 1975)
| | | | Skin prick: atopy and specific | Allergen: histamine area ratio between 0.1 and 1 and erythema >21 mm | Not reported
| | | | Serum specific IgE | binding ≧2% | RAST
| | | | Serum total IgE | >160 IU/ml | PRIST
Park, 1989 | SIC: reactive dyes | ≧20% decline in FEV_1_ | Referenced (Chai et al., 1975) | Single NSBPT: methacholine | PC_20_ FEV_1_: no cutoff reported | Referenced (Chai et al., 1975)
| | | | Single PFT: FEV_1_ | Not reported | Not reported
| | | | Skin prick: atopy and specific | Not reported | Described in text
| | | | Serum specific IgE | RAST binding >2% | RAST
Perrin, 1990 | SIC: suspected agent | Not reported | Not reported | Serial NSBPT: histamine or methacholine | ≧2 fold increase in PC_20_ FEV_1_ between at work and away | Not reported
| | | | Serial PFT (PEFR): monitored every 2 hrs for 2 wks or less at work and 2 wks away | Various definitions: number of days with ≧20% variation in PEFR ≧20%; lower maximum PEFR values at work; lower minimum PEFR values at work; lower mean PEFR values at work | Referenced (Burge et al., 1979)
Pezzini, 1984 | SIC: isocyanates | ≧20% fall in FEV_1_ or 35% drop in FEF(25–75) | Referenced (Zedda et al., 1976) | Single NSBPT: bethanechol | PD_20_ FEV_1_: no cutoff | Described in text
| | | | Skin prick: atopy | ≧2 positive reactions | Referenced (Vanselow, 1964)
| | | | Serum specific IgE | NBR level >0.9 | RAST
Prichard, 1984 | Other: clinical diagnosis | Included symptoms and physician diagnosed asthma since began working in industry | Described in text | Single NSBPT: methacholine | PD_20_ FEV_1_ <30 μ | Described in text
| | | | Skin prick: atopy and specific | Wheal ≧3 mm more than negative control | Described in text
Quirce, 2000 | Other: clinical diagnosis | Included SIC or serial PFT | SIC: Referenced (Hinojosa et al., 1984) | Skin prick: specific | Not reported | Described in text
| | | | Serum specific IgE | ≧4 times more serum specific IgE than mean titer of control sera | ELISA
Quirce, 1992 | SIC: alpha-amylase from aspergillus oryzae and cellulase from a. niger | ≧20% decline in FEV_1_ | Described in text | Single NSBPT: methacholine | Not reported | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy and specific | Wheal diameter ≧3 mm | Described in text
| | | | Serum specific IgE | Not reported | REIA (alpha-amylase and cellulase) or RAST (wheat and rye)
Rasanen, 1994 | SIC: suspected agent | ≧15% decline in FEV_1_ and PEFR | Not reported | Other: basophil histamine release | ≧8% | Referenced (Rasanen et al., 1992)
| | | | Skin prick: atopy and specific | Wheal diameter ≧1/2 the size of the reaction to histamine standard | Described in text
| | | | Serum specific IgE | ≧0.7 kU/L | RAST
| | | | Serum total IgE | Not reported | IgE RIA
Redlich, 1996 | SIC: isocyanates | Not reported | Not reported | Eosinophils: blood | Not reported | Described in text
| | | | Other: bronchial alveolar lavage | Not reported | Described in text
| | | | Single NSBPT: methacholine | Not reported | Not reported
Ricciardi, 2003 | SIC: wood dust (iroko) | ≧25% decline in FEV_1_ | Referenced (Frolund, 1996) | Eosinophils: blood | Not reported | Described in text
| | | | Serial PFT (PEFR): monitored every two hrs for 1 wk at work and 1 wk away | Not reported | Not reported
| | | | Single NSBPT: methacholine | ≧20% decline in FEV_1_: no cutoff | Not reported
| | | | Skin prick: atopy and specific | Wheal diameter >7 mm | Described in text
| | | | Serum specific IgE | Not reported | RAST
| | | | Serum total IgE | Not reported | RAST
Sander, 2001 | SIC: wheat and rye | Not reported | Not reported | Skin prick: specific | ≧1/2 of histamine wheal | Described in text
Sastre, 2003 | SIC: isocyanates | ≧20% decline in FEV_1_ | Not reported | Single NSBPT: methacholine | PC_20_ FEV_1_ <16 mg/ml | Referenced (Cockcroft et al., 1977)
Schuermans, 2003 | SIC: latex | Not reported | Not reported | Single NSBPT: histamine | PC_20_ FEV_1_ <0.5 mg/ml | Not reported
Schwaiblmair, 1997 | SIC: bleaching powder | ≧100% increase in specific airway resistance and reached at least 2.0 kPa/s | Described in text | Single NSBPT: methacholine | ≧100% increase in specific airway resistance and reached 2.0 kPa | Referenced (Hargreave et al., 1981)
| | | | Single PFT: FVC, MEF_50_, FEV_1_, RV, TLco, Raw Pa0_2_ | Not reported | Described in text
| | | | Skin prick: atopy and specific | Wheal diameter >3 mm larger than negative control | Referenced (Pepys, 1975)
Schwarting, 1979 | SIC: flour | Not reported | Not reported | Clinical diagnosis | Included medical history, skin prick test, bronchial provocation test, nasal provocation, conjuctivities, and serum specific IgE | Described in text
| | | | Skin prick: specific | Not reported | Not reported
| | | | Serum specific IgE | Not reported | RAST
Shirai, 2003 | SIC: epigallocatechin gallate (EGCg) | ≧20% decline in FEV_1_ | Referenced (Shirai et al., 1997) | Clinical diagnosis | Clinical history, postive SIC, positive SPT | Described in text
| | | | Single NSBPT: methacholine | PC_20_ FEV_1_ <10 mg/ml | Referenced (Makino et al., 1984
| | | | Skin prick: specific | Wheal diameter >7 mm | Described in text
Shirakawa, 1988 | SIC: cobalt chloride | Not reported | Referenced (Chai et al., 1975) | Eosinophils: blood | >200/mm^3^ | Not reported
| | | | Other: antibodies (CO-HSA) | Not reported | Referenced (Ouchterlony, 1968)
| | | | Single NSBPT: methacholine | Not reported | Referenced (Hargreave et al., 1981)
| | | | Skin prick: specific | Wheal diameter >9 mm at <0.1% | Not reported
| | | | Serum specific IgE | >673 cpm (upper normal limit) | RAST
Slovak, 1981 | Other: clinical diagnosis | Based history of repeated episodes of wheezing or chest tightness (with or without cough) related to | Described in text | Serial PFT (PEFR): monitored every 2 hrs while awake for 3 mos | Not reported | Not reported
| | | | Skin prick: atopy and specific | Wheal diameter >3 mm | Described in text
Symington, 1981 | SIC: mushroom dust | Not reported | Described in text | Skin prick: atopy and specific | Wheal diameter ≧3 mm | Described in text
Tabar, 2004 | SIC: asparagus | ≧20% decline in FEV_1_ | Described in text | Other: immunoblotting | Not reported | Not reported
| | | | Skin prick: atopy and specific | Wheal area ≧7 mm^2^ | Referenced (Dreborg, 1993)
| | | | Serum specific IgE | Not reported | Not reported
| | | | Serum total IgE | Not reported | Not reported
Taivainen, 1994 | SIC: cow dander | Immediate: ≧15% change in PEFR; late: ≧20% change in PEFR | Described in text | Clinical diagnosis | Described in text | Described in text
| | | | Skin prick: specific | Two cutoff values: wheal diameter ≧3 mm or >than positive control | Described in text
| | | | Serum specific IgE | Two cutoff values: ≧0.35 kU/L or ≧0.70 kU/L | RAST
Tee, 1998 | Other: clinical diagnosis | Included SIC and/or clinical history and/or serial PFT and/or NSBPT | SIC: Referenced (Newman-Taylor and Davies, 1981) | Skin prick: atopy | Wheal diameter >3 mm | Not reported
| | | | Serum specific IgE | Two cutoff values: ratio ≧2; ratio ≧3 | RAST
Tse, 1982 | SIC: plicatic acid | Not reported | Referenced (Chan-Yeung et al., 1973) | Serum specific IgE | >mean + 2SD of control subjects | RAST
Vandenplas, 2001 | SIC: latex | ≧20% decline in FEV_1_ | Referenced (Vandenplas et al., 1995) | Clinical diagnosis | Questionnaire and clinical history with OA considered likely or highly likely on the basis of consensus assessment by 4 observers | Described in text
| | | | Serial NSBPT: histamine | >3 fold change in PC_20_ FEV_1_ before and after SIC | Referenced (Cockcroft et al., 1977)
| | | | Single NSBPT: histamine | PC_20_ FEV_1_ <16 mg/ml | Referenced (Cockcroft et al., 1977)
| | | | Skin prick: atopy and specific | ≧1 positive reaction | Referenced (Vandenplas et al., 1995)
Vandenplas, 1995b | SIC: latex | ≧20% decline in FEV_1_ | Described in text | Single NSBPT: histamine | PC_20_ FEV_1_ <16 mg/ml | Described in text
| | | | Skin prick: atopy and specific | Wheal ≧3mm greater than control | Described in text
Vanhanen, 2000 | SIC: cellulase (econase ECP) | ≧15% decline in FEV_1_ | Not reported | Single NSBPT: histamine | PD_15_ FEV_1_ ≦1.6 mg | Referenced (Sovijarvi et al., 1993)
| | | | Skin prick: atopy and specific | Not reported | Referenced (Vanhanen et al., 1996)
| | | | Serum specific IgE | >35 KU/L | RAST
Virtanen, 1996 | Other: clinical diagnosis | Included SIC and/or SPT and/or serum specific IgE | Serum specific IgE: described in text | Serum specific IgE | Not reported | ELISA
| | | | Serum specific IgG | Not reported | ELISA
Vogelmeier, 1991 | SIC: TDI | ≧50% decline in sGaw from the zero value | Referenced (Dharmarajan and Rando, 1979; O'Brien et al. 1979) | Single NSBPT: methacholine | ≧50% decline in specific airway conductance | Described in text
| | | | Skin prick: specific | Not reported | Not reported
| | | | Serum specific IgE | Not reported | RAST
Wurzinger, 1997 | SIC: flour | Not reported | Described in text | Single NSBPT: histamine | Not reported | Described in text
| | | | Skin prick: atopy and specific | Not reported | Described in text
| | | | Serum specific IgE | Not reported | RAST
| | | | Serum total IgE | Not reported | ELISA
Zeiler, 2002 | SIC: Bos d2 and standard bovine dander allergen | ≧15% decline in FEV_1_ or PEF | Described in text | Single NSBPT: histamine | PD_15_ FEV_1_ <1.6 mg | Referenced (Sovijarvi et al., 1993)
| | | | Skin prick: specific | Wheal diameter ≧3 mm | Described in text
| | | | Serum specific IgE | Not reported | RAST and ELISA
| | | | Serum specific IgG | Not reported | ELISA
Zeiss, 1977 | Other: clinical diagnosis | Included history, physical, and skin tests when indicated | Described in text | Skin prick: atopy and specific | Not reported | Not reported
| | | | Serum specific IgE | Not reported | PTRIA
| | | | Serum specific IgG | Not reported | PTRIA

Abbreviations: CAP = developed by Pharmacia Diagnostics for measuring specific IgE; cbu = cumulative breath unit; CO-HSA = conjugated human serum albumin; cpm = counts per minute; DPC = diagnostics products corp.; EAST = enzyme allergosorbent test; ECG = electrocardiogram; ECP = eosinophilic cationic protein; ECSC = European coal and steel community; ELISA = enzyme-linked immuno sorbent assay; FEF = forced expiratory flow; FEV _ 1 _ = forced expiratory volume in one second; FVC = forced vital capacity; kPa = kilopascal; MCP-1= monocyte chemoattractant protein-1; MEF = maximal expiratory flow; mos = months; NSBPT = non-specific bronchial provocation; OASYS-2 = occupational asthma system; OD = optical density; PC _ 20 _ = provocative concentration causing a 20% drop in FEV_1;_ PaO _ 2 _ = arterial oxygen partial pressure; PD _ 15 _ = provocative dose causing a 15% drop in FEV_1_; PD _ 50 _ = provocative dose causing a 50% drop in FEV_1_; PD _ 20 _ = provocative dose causing a 20% drop in FEV_1_; PEF = peak expiratory flow; PEFR = peak expiratory flow rate; PFT = pulmonary function test; PRIST = paper radioimmunosorbent test; PRU = phadebas RAST units; PTRIA = polystyrene-tube radioimmunoassay; RADS = reactive airways dysfunction syndrome; RAST = radio allegro sorbent test; REIA = reverse enzyme immunoassay; RIA = radioimmunoassay; RIACT = radioimmunoassay kit for measuring IgE; RV = residual volume; SD = standard deviation; SDS = sodium dodecyl sulphate; sGaw = specific airway conductance; SIC = specific inhalational challenge; SOB = shortness of breath; SPBRIA = solid-phase bead radioimmunoassay; sRaw = specific airway resistance; TCPA = tetrachlorophthalic anhydride; TDI = toluene di-isocyanates; TDI-HSA = toluene di-isocyanates human serum albumin; TLco = single breath carbon monoxide; IU = international units; UniCAP = fluoroenzymeimmunoassay kit developed by Pharmacia Diagnostics; Vmax = maximum flow; wk = week; wks = weeks

Table E-4 Methodological quality of included studies (Diagnosis review)

Author, Year | Data Collection | Patient Recruitment | Blinding | Adequate Description of Reference Standard | Avoidance of Differential Bias | Avoidance of Partial Verification Bias | Funding
Alvarez, 2001 | Prospective | Other | Partial | Yes | No | No | Not reported
Alvarez, 1996 | Prospective | Other | Unclear | Yes | Yes | Yes | Other
Anees, 2004 | Retrospective | Consecutive or random selection | Unclear | Yes | No | No | Foundation, other
Avery, 1969 | Prospective | Other | Unclear | No | No | Unclear | Government
Balland, 1989 | Prospective | Not reported | Unclear | No | Unclear | Yes | Not reported
Baur, 1998 | Prospective | Other | Unclear | Yes | No | No | Not reported
Baur, 1979 | Prospective | Not reported | Unclear | No | Yes | Yes | Foundation
Behr, 1990 | Prospective | Not reported | Unclear | Yes | Unclear | Unclear | Not reported
Bernstein, 2002 | Prospective | Other | Partial | Yes | No | No | Government, private
Biot, 1980 | Prospective | Not reported | Unclear | No | No | No | Not reported
Block, 1983 | Prospective | Other | Unclear | Yes | Yes | Yes | Government
Burge, 1985 | Prospective | Not reported | Unclear | No | No | No | Not reported
Burge, 1982 | Prospective | Other | Unclear | No | No | No | Not reported
Burge, 1980 | Prospective | Other | Unclear | Yes | No | No | Not reported
Burge, 1979a | Prospective | Other | Partial | Yes | No | No | Not reported
Burge, 1979b | Retrospective | Other | Partial | Yes | No | No | Not reported
Burge, 1978 | Prospective | Other | Unclear | Yes | Unclear | Unclear | Not reported
Butcher, 1980 | Retrospective | Not reported | Unclear | No | No | No | Government, private, foundation
Carletti, 1997 | Prospective | Not reported | Unclear | Yes | Unclear | Unclear | Not reported
Cartier, 1989 | Prospective | Other | Partial | Yes | Yes | No | Foundation, internal, government
Cartier, 1987 | Retrospective | Not reported | Unclear | Yes | No | No | Not reported
Cartier, 1984 | Prospective | Other | Unclear | Yes | Unclear | Yes | Government, other
Choudat, 1999 | Prospective | Other | Unclear | Yes | No | No | Other
Cirla, 1975 | Prospective | Other | Unclear | Yes | Unclear | Unclear | Not reported
Colas, 1985 | Prospective | Not reported | Unclear | Yes | No | No | Not reported
Cortona, 1980 | Prospective | Not reported | Partial | No | No | Yes | Not reported
Cote, 1990 | Prospective | Consecutive or random selection | Partial | Yes | No | No | Government
Coutts, 1984 | Prospective | Other | Unclear | No | No | Unclear | Not reported
Curran, 1996 | Prospective | Other | Unclear | No | No | No | Not reported
Davison, 1983 | Prospective | Other | Unclear | Yes | Unclear | Yes | Not reported
Dellabianca, 1996 | Prospective | Consecutive or random selection | Unclear | Yes | No | No | Not reported
Dente, 1986 | Prospective | Not reported | Unclear | No | No | No | Not reported
De Zotti, 1996a | Prospective | Other | Unclear | Yes | No | No | Not reported
De Zotti, 1996b | Prospective | Not reported | Unclear | Yes | No | Unclear | Not reported
DiFranco, 1998 | Prospective | Other | Partial | No | Yes | Yes | Government
Duan, 1989 | Prospective | Not reported | Inadequate | Yes | Unclear | Unclear | Not reported
Ferguson, 1996 | Prospective | Other | Unclear | Yes | No | No | Not reported
Gannon, 1996 | Prospective | Other | Unclear | No | Yes | Yes | Government, foundation
Girard, 2004 | Prospective | Other | Partial | Yes | No | No | Government
Graneek, 1988 | Unclear | Other | Partial | Yes | Yes | No | Not reported
Grosclaude, 1980 | Prospective | Not reported | Unclear | Yes | No | No | Not reported
Harries, 1980 | Prospective | Other | Unclear | Yes | No | No | Not reported
Hinojosa, 1986 | Prospective | Not reported | Unclear | Yes | No | No | Not reported
Howe, 1983 | Prospective | Other | Unclear | Yes | Yes | No | Other
Huggins, 2003 | Prospective | Consecutive or random selection | Partial | No | Unclear | Yes | Not reported
Jager, 1993 | Unclear | Other | Unclear | Yes | No | Yes | Not reported
Karol, 1994 | Prospective | Other | Unclear | Yes | No | No | Government, private
Kern, 1991 | Prospective | Other | Unclear | Yes | No | No | Government
Keskinen, 1988 | Retrospective | Consecutive or random selection | Unclear | Yes | No | No | Not reported
Kim, 1999 | Prospective | Other | Unclear | No | No | Yes | Not reported
Kim, 1997 | Prospective | Other | Unclear | Yes | Yes | Yes | Government
Kopferschmitt-Kubler, 1998 | Prospective | Other | Unclear | Yes | No | No | Not reported
Kongerud, 1992 | Prospective | Other | Partial | No | No | Unclear | Not reported
Koskela, 2003 | Prospective | Consecutive or random selection | Unclear | Yes | Yes | No | Internal
Krakowiak, 2003 | Prospective | Other | Partial | Yes | No | No | Not reported
Lam, 1979 | Prospective | Other | Unclear | Yes | Unclear | Unclear | Foundation
La Paglia, 1986 | Unclear | Not reported | Unclear | No | Yes | Unclear | Not reported
Larbanois, 2003 | Unclear | Consecutive or random selection | Unclear | Yes | No | No | Government
Lemiere, 1999 | Prospective | Other | Full | Yes | No | No | Foundation
Liss, 1991 | Retrospective | Other | Full | Yes | Yes | No | Not reported
Lozewicz, 1985 | Prospective | Other | Partial | No | No | Yes | Not reported
Malo, 1993 | Retrospective | Other | Partial | No | No | No | Not reported
Malo, 1991 | Prospective | Consecutive or random selection | Full | Yes | No | Yes | Not reported
Malo, 1990 | Retrospective | Other | Unclear | Yes | Yes | No | Not reported
Malo, 1988 | Prospective | Consecutive or random selection | Unclear | Yes | Yes | Yes | Not reported
Mapp, 1986 | Prospective | Not reported | Unclear | Yes | No | No | Government
Mapp, 1979 | Prospective | Not reported | Unclear | Yes | No | Yes | Not reported
Merget, 1997 | Prospective | Other | Unclear | Yes | No | No | Not reported
Merget, 1996 | Prospective | Other | Unclear | Yes | No | No | Other
Merget, 1993 | Prospective | Consecutive or random selection | Unclear | Yes | No | No | Not reported
Mole, 1977 | Prospective | Not reported | Unclear | Yes | No | Yes | Not reported
Moller, 1986 | Prospective | Other | Unclear | Yes | Yes | No | Not reported
Moller, 1985 | Prospective | Other | Unclear | No | No | No | Government, foundation
Moscato, 1991 | Retrospective | Other | Unclear | Yes | No | No | Not reported
Munoz, 2004 | Prospective | Other | Unclear | Yes | No | No | Not reported
Nielsen, 1988 | Prospective | Not reported | Partial | Yes | No | No | Foundation
Nordman, 1985 | Retrospective | Consecutive or random selection | Unclear | Yes | Unclear | Unclear | Not reported
Obata, 1999 | Prospective | Consecutive or random selection | Partial | Yes | No | No | Foundation
O'Brien, 1979b | Prospective | Not reported | Unclear | Yes | No | Unclear | Private
O'Brien, 1979a | Prospective | Other | Unclear | Yes | Yes | No | Private
Obutulowicz, 1998 | Prospective | Other | Unclear | No | No | No | Not reported
Paggiaro, 1987 | Retrospective | Other | Unclear | Yes | No | Yes | Not reported
Paggiaro, 1986 | Prospective | Other | Unclear | Yes | Unclear | No | Not reported
Paggiaro, 1984c | Prospective | Not reported | Unclear | Yes | Unclear | Unclear | Not reported
Paggiaro, 1984b | Prospective | Not reported | Unclear | Yes | No | Yes | Not reported
Paggiaro, 1981 | Prospective | Not reported | Inadequate | Yes | No | No | Not reported
Palczynski, 2003 | Prospective | Other | Partial | No | No | No | Government
Park, 2002 | Prospective | Other | Unclear | Yes | No | No | Private
Park, 2001 | Prospective | Other | Partial | Yes | Yes | No | Internal
Park, 1999 | Prospective | Other | Unclear | Yes | No | No | Other
Park, 1998 | Prospective | Other | Unclear | Yes | Yes | Yes | Internal
Park, 1994 | Prospective | Not reported | Unclear | Yes | No | No | Not reported
Park, 1991 | Prospective | Other | Unclear | Yes | Yes | Yes | Not reported
Park, 1989 | Prospective | Not reported | Unclear | Yes | No | No | Internal
Perrin, 1990 | Prospective | Not reported | Unclear | No | No | No | Not reported
Pezzini, 1984 | Prospective | Not reported | Unclear | Yes | Unclear | Unclear | Government
Prichard, 1984 | Prospective | Other | Unclear | No | No | No | Other
Quirce, 2000 | Prospective | Other | Unclear | No | Unclear | Unclear | Not reported
Quirce, 1992 | Retrospective | Other | Unclear | Yes | No | No | Foundation
Rasanen, 1994 | Prospective | Not reported | Unclear | Yes | No | Yes | Not reported
Redlich, 1996 | Prospective | Not reported | Unclear | No | No | No | Internal
Ricciardi, 2003 | Prospective | Other | Unclear | Yes | Yes | Yes | Not reported
Sander, 2001 | Prospective | Not reported | Unclear | Inadequate | Unclear | Unclear | Not reported
Sastre, 2003 | Prospective | Not reported | Unclear | Yes | Yes | No | Not reported
Schuermans, 2003 | Prospective | Not reported | Unclear | No | Unclear | Unclear | Not reported
Schwaiblmair, 1997 | Prospective | Other | Unclear | Yes | No | Yes | Not reported
Schwarting, 1979 | Unclear | Other | Unclear | No | No | Yes | Not reported
Shirai, 2003 | Prospective | Other | Unclear | Yes | No | No | Not reported
Shirakawa, 1988 | Prospective | Other | Unclear | No | No | No | Not reported
Slovak, 1981 | Prospective | Other | Unclear | No | No | No | Not reported
Stefano, 1999 | Prospective | Other | Unclear | Yes | Unclear | Yes | Not reported
Symington, 1981 | Prospective | Other | Unclear | No | Yes | No | Not reported
Tabar, 2004 | Retrospective | Other | Unclear | Yes | Yes | No | Not reported
Taivainen, 1994 | Prospective | Consecutive or random selection | Unclear | Yes | No | Yes | Not reported
Tee, 1998 | Retrospective | Other | Partial | Yes | No | No | Not reported
Tse, 1982 | Prospective | Not reported | Unclear | No | Yes | Yes | Government
Vandenplas, 2001 | Prospective | Consecutive or random selection | Partial | Yes | No | No | Private
Vandenplas, 1995 | Prospective | Other | Unclear | Yes | Yes | Yes | Other
Vanhanen, 2000 | Prospective | Not reported | Inadequate | Yes | No | No | Not reported
Virtanen, 1996 | Prospective | Consecutive or random selection | Unclear | Yes | Yes | No | Foundation
Vogelmeier, 1991 | Prospective | Not reported | Unclear | Yes | No | No | Other
Wurzinger, 1997 | Unclear | Not reported | Unclear | Yes | No | Yes | Not reported
Zeiler, 2002 | Prospective | Consecutive or random selection | Unclear | Yes | No | No | Internal, foundation
Zeiss, 1977 | Prospective | Other | Inadequate | Yes | No | No | Government, internal, private

Table E-5 Description of included studies (Management cohorts review)

Author, Year | Location | Language of Publication | Intervention Categories | Suspected Agent (molecular weight) | Subject Source | Description of Included Subjects
Allard, 1989 | Canada | English | Removed | Mixed (M) | Clinic | Workers with OA due to mixed causes, no longer exposed >5 yrs
Ameille, 1997 | France | English | Exposed, protection, reduced, removed | Mixed (M) | Clinic | Workers diagnosed with OA due to mixed causes between 1989-93, follow-up approximately 3 yrs later
Banks, 1990 | United States | English | Reduced | Isocyanates (L) | Workplace | Polyurethane foam workers with OA due to TDI, follow-up 1982-86
Barker, 1998 | United Kingdom | English | Removed | Chemical: TCPA (L) | Clinic | Female electronic factory workers diagnosed with OA due to TCPA, follow-up at 12 yrs
Bernstein, 2003 | United States | English | Exposed, protection, reduced, removed | Latex (H) | Other | Volunteer health care workers with NRL allergy
Burge, 1982a | United Kingdom | English | Reduced, removed | Colophony (L) | Clinic | Electronics workers with OA due to colophony fumes
Gannon, 1993 | United Kingdom | English | Exposed, removed | Mixed (M) | Clinic | Workers with OA due to various causes diagnosed at least 1 yr ago
Gassert, 1998 | United States | English | Removed | Mixed (M) | Clinic | Workers with OA
Gorski, 1999 | Poland | English | Removed | Flour (H) | Clinic | Workers with bakers asthma, no longer exposed, follow-up approximately 2 yrs
Grammer, 2000 | United States | English | Reduced, removed | Chemical: trimellitic anhydride (L) | Workplace | Workers at TMA manufacturing plant with OA, moved to low exposure jobs >1 yr
Grammer, 1996 | United States | English | Removed | Chemical: anhydride (L) | Other | Workers that prepare epoxy resin with HHPA-induced respiratory disease, non-exposed for approximately 1 yr
Harries, 1979 | United Kingdom | English | Reduced, removed | Isocyanates (L) | Workplace | Workers in rubber manufacturing plant with isocyanate-induced asthma, follow-up approximately 3 yrs
Jyo, 1989 | Japan | English | Medications | Sea squid (H) | - | Oyster shuckers with asthma and sea squirt allergy
Laoprasert, 1998 | United States | English | Protection | Latex (H) | Clinic | Female health care workers with OA due to latex
Lemiere, 2000 | Canada | English | Removed | Isocyanates (L) | Clinic | Workers diagnosed with OA caused by HMW agents had normal NSBR, not exposed for approximately 5 yrs
Lemiere, 1996 | Canada | English | Removed | Mixed (M) | Clinic | Workers with OA due to isocyanate/flour/gum no longer exposed
Lin, 1996 | Canada | English | Exposed, removed | Wood dust: cedar (L) | Clinic | Male workers with OA due to western western red cedar diagnosed between 1972-92
Lozewicz, 1987 | United Kingdom | English | Reduced, removed | Isocyanates (L) | Clinic | Various workers diagnosed with isocyanate-induced asthma between 1971-79, no exposure approximately 4 yrs
Maghni, 2004 | Canada | English | Removed | Mixed (M) | Clinic | Workers with OA due to mixed causes, no longer exposed
Malo, 2004 | Canada | English | Removed | Mixed (M) | - | Workers with OA with serial NSBPT measurements at diagnosis and after removal from exposure
Malo, 1994a | Canada | English | Removed | Chemical: chlorine (L) | Clinic | Pipefitters and welders working in a paper mill with bronchial hyperresponsiveness after 3 month exposure to chlorine
Malo, 1993b | Canada | English | Removed | Mixed (M) | Clinic | Workers, mostly exposed to isocyanates, with a confirmed diagnosis of OA and receiving compensation from WBC
Mapp, 1988 | Italy | English | Exposed, removed | Isocyanates (L) | - | Lumber workers with OA due to TDI, follow-up approximately 10 mos
Malo, 1988b | Canada | English | Removed | Snow crab (H) | - | Snowcrab workers with OA, no longer exposed, follow-up between 12–64 mos
Marabini, 2003 | Italy | English | Exposed | Mixed (M) | Clinic | Carpenters/bakers/farmers/coach worker with OA
Merget, 1999 | Germany | English | Exposed, reduced, removed, | Chemical: platinum salts (L) | Workplace | Metal refinery/catalyst production workers with OA due to platinum salts
Meyer, 1977 | Germany | German | Removed | Metal dust (L) | Workplace | Workers with metal dust allergy identified in the workplace
Moscato, 1999 | Italy | English | Exposed, reduced, removed, | Mixed (M) | Clinic | Workers diagnosed with OA due to mixed causes between 1992-95, follow-up at 12 mos
Munoz, 2003 | Spain | English | Protection, removed | Chemical: persulfate (L) | Clinic | Cosmetic factory workers, hairdressers with OA due to persulfate salts
O'Donnell, 1989 | New Zealand | English | Exposed | Potroom (L) | Workplace | Smelter workers diagnosed with potroom asthma
Orriols, 1999 | Spain | Spanish | Protection, removed | Isocyanates (L) | Clinic | Workers with OA caused by isocyanates
Paggiaro, 1993 | Italy | English | Reduced, removed | Isocyanates (L) | Workplace | Furniture manufacturing workers with OA due to TDI
Paggiaro, 1990 | Italy | English | Removed | Isocyanates (L) | - | Workers with TDI asthma no longer exposed
Paggiaro, 1984a | Italy | English | Exposed, removed | Isocyanates (L) | - | Furniture manufacturing workers with OA due to TDI
Park, 2002a | Korea | English | Removed | Isocyanates (L) | Clinic | Workers with TDI asthma, no longer exposed >5 yrs
Park, 1994 | Korea | English | Removed | Chemical: chromium (L) | Clinic | Workers in metalplating/cement/construction work with OA due to chromium exposure
Perfetti, 1998a | Canada | English | Removed | Mixed (M) | Clinic | Volunteer workers randomly selected from clinic charts diagnosed with OA, mixed causes
Piirila, 1996 | Finland | English | Reduced, removed | Chemical: sulfur dioxide (L) | Workplace | Miners accidentally exposed to sulfur dioxide reviewed 13 yrs later
Pisati, 1994 | Italy | English | Exposed, removed | Chemical: cobalt (L) | Clinic | Workers with OA due to cobalt diagnosed between 1982-90
Pisati, 1993 | Italy | English | Reduced, removed | Isocyanates (L) | Clinic | Workers exposed to paint/varnish/foam diagnosed with TDI asthma between 1980-85
Rosenberg, 1987 | France | English | Exposed, protection, reduced, removed | Isocyanates (L) | Clinic | Car spray-painters/foam manufacturers/cabinet makers, etc. with isocyanate-asthma, follow-up 6–54 mos
Ross, 1998 | United Kingdom | English | Removed | Mixed (M) | Other | Charts of workers with OA refered to SWORD project
Saetta, 1995 | Italy | English | Removed | Isocyanates (L) | - | Workers with OA due to TDI, no longer exposed
Sen, 1998 | United Kingdom | English | Removed | Enzymes: fruit (H) | Workplace | Factory workers preparing fruit with OA due to enzymes
Simonsson, 1985 | Sweden | English | Exposed, removed | Metal: aluminum fluoride or sulfate (L) | Clinic | Workers from aluminum factories with OA due to aluminum fluoride/sulphate
Slovak, 1985 | United Kingdom | English | Protection | Animal/bird: lab animals (H) | Workplace | Lab animal workers diagnosed with OA, still exposed
Smith, 1999 | United Kingdom | English | Exposed, reduced | Flour (H) | Other | Workers across flour-using industries with OA
Sulotto, 1989 | Italy | Italian | Removed, medications | Mixed (M) | Clinic | Workers with clinically diagnosed OA from various causes
Taivainen, 1998 | Finland | English | Protection | Animal/bird: cow dander and grain (H) | Clinic | Farmers with OA due to cow dander or grains
Vandenplas, 2002 | Belgium | English | Reduced, removed | Latex (H) | Clinic | Health-care/non-health-care workers with OA due to latex
Venables, 1987 | United Kingdom | English | Removed | Chemical: TCPA (L) | Workplace | Female process workers with OA due to TCPA, no longer exposed, follow-up approximately 4.5 yrs
Venables, 1985 | United Kingdom | English | Reduced | Isocyanates (L) | Workplace | Various workers in a steel coating plant with OA due to coating vapours

Abbreviations: H = high; HHPA = hexahydrophthalic anhydride; L = low; M = mixed; mos = months; NRL = natural rubber latex; NSBPT = non-specific bronchial provocation; NSBR = non-specific bronchial reactivity; OA = occupational asthma; SWORD = surveillance of work-related occupational respiratory disease; TCPA = tetrachlorophthalic anhydride; TDI = toluene di-isocyanates; TMA = trimellitic anhydride; WCB = workers' compensation board; yr = year; yrs = years

Table E-6 Demographic characteristics of included patients (Management cohorts review)

Author, Year | Number of Patients | Male | Age | Atopic | Smoking Status | History of Asthma | % predicted FEV_1_ (unless otherwise stated) | Years of Exposure | Years of Symptoms | SIC Confirmed OA | Current Medication Stopped for Testing
| | (%) | mean (SD) | (%) | (%) | (%) | mean (SD) | mean (SD) | mean (SD)
Allard, 1989 | 28 | 92.9 | 46 (11) | 60.7 | C: 17.9 | - | 87 (21.3) | 0.5 (0.8) | 0.3 (0.2) | Yes | -
Ameille, 1997 | 209 | 75.1 | 38 (12) | - | - | - | 88 (20) | - | 3.7 (5.1) | No | -
Banks, 1990 | 6 | - | - | - | C: 33.3 | 0 | - | - | - | Yes | -
| | | | | N: 66.7
Barker, 1998 | 6 | 0 | 37 (4.2) | - | - | - | FEV_1_: 2.1 (0.2) | - | - | Yes | -
Bernstein, 2003 | 67 | 4.5 | 36.1 (11.5) | 82.1 | - | - | - | - | 4.5 (4.8) | No | No
Burge, 1982a | 45 | 20 | 49 (6.8) | - | N: 48.9 | - | - | - | 2.5 | Yes | Yes
Gannon, 1993 | 224 | 74.1 | - | - | C: 12.1 | - | - | - | - | No | -
| | | | | Ex: 21.9
| | | | | N: 15.6
Gassert, 1998 | 55 | 29.1 | 41.1 (9.8) | - | C: 9.1 | 25.5 | - | 10.7 (6.9) | - | No | -
| | | | | Ex: 32.7
| | | | | N: 58.2
Gorski, 1999 | 56 | - | 38 (9) | - | C: 26.8 | - | - | - | - | No | -
| | | | | Ex: 26.8
| | | | | N: 46.4
Grammer, 2000 | 29 | 89.7 | 36.5 (8.8) | - | C: 44.8 | - | - | 1.1 (5.2) | - | No | -
| | | | | Ex: 13.8
| | | | | N: 41.4
Grammer, 1996 | 7 | 100 | 37 (4.3) | - | C: 14.3 | - | - | - | - | No | -
| | | | | Ex: 28.6
| | | | | N: 57.1
Harries, 1979 | 3 | 100 | 41.3 (3.7) | 66.7 | C: 66.7 | - | FEV_1_: 3 (0.4) | 8 (9.6) | 2.5 (3.1) | Yes | -
| | | | | Ex: 33.3
| | | | | N: 0
Jyo, 1989 | - | - | - | - | - | - | - | - | - | No | -
Laoprasert, 1998 | 11 | 0 | 35.5 (6.2) | 63.6 | C: 0 | - | - | - | - | No | Yes
| | | | | N: 100
Lemiere, 2000 | 16 | 68.8 | 41.3 (9.9) | 75 | C: 31.3 | - | 99 (14.4) | 10.7 (9.5) | - | Yes | Yes
| | | | | Ex: 50
| | | | | N: 18.8
Lemiere, 1996 | 15 | 73.3 | 49.1 (10.4) | 53.3 | C: 0 | - | 96 (12) | 18.1 (13.6) | 6 (5.6) | Yes | -
| | | | | Ex: 40
| | | | | N: 60
Lin, 1996 | 280 | 100 | 40.9 (11.2) | 27.9 | C: 4.6 | - | 86.1 (16.7) | 6.1 (6.4) | - | Yes | Yes
| | | | | Ex: 28.2
| | | | | N: 67.1
Lozewicz, 1987 | 56 | 83.9 | 46.1 (9.8) | 35.7 | C: 21.4 | 3.6 | 82.5 (21.1) | 6.5 (7.4) | 2.7 (2.1) | Yes | -
| | | | | Ex: 41.1
| | | | | N: 26.8
Maghni, 2004 | 133 | 60.9 | 43 (12) | 59.4 | C: 18 | - | 84.1 (20.3) | 12.1 (10.6) | 3.9 (4.7) | No | Yes
| | | | | Ex: 39.8
| | | | | N: 42.1
Malo, 2004 | 80 | 80 | 42.8 (12.4) | 53.8 | C: 20 | - | 90.2 (16.5) | 11.5 (10.7) | 3.3 (4.2) | Yes | Yes
| | | | | Ex: 37.5
| | | | | N: 42.5
Malo, 1994a | 20 | 100 | 48 (10) | 50 | C: 55 | - | 80.4 (19.3) | - | - | No | -
| | | | | Ex: 40
| | | | | N: 5
Malo, 1993b | 134 | 76.1 | 44 (12) | 60.4 | - | - | 91 (20) | - | - | Yes | -
Malo, 1988b | 31 | 9.7 | 37.1 (12.2) | 29 | C: 64.5 | - | - | 1.1 (0.5) | 0.6 (0.4) | Yes | -
| | | | | Ex: 19.4
| | | | | N: 16.1
Mapp, 1988 | 35 | 71.4 | 34.6 (13.7) | 22.9 | C: 8.6 | 0 | - | 13.5 (11.3) | 3.7 | Yes | Yes
| | | | | Ex: 28.6
| | | | | N: 62.9
Marabini, 2003 | 10 | 90 | 49.9 (7) | 30 | C: 10 | - | 75.1 (12.6) | 24.2 (14.3) | - | Yes | -
| | | | | Ex: 60
| | | | | N: 30
Merget, 1999 | 83 | - | 38 (10.4) | 45.8 | C: 51.8 | - | - | - | - | Yes | -
| | | | | Ex: 22.9
| | | | | N: 25.3
Meyer, 1977 | 168 | - | - | - | - | - | - | - | - | No | -
Moscato, 1999 | 25 | 72 | 34 (9.3) | 16 | C: 28 | - | 103 (6.8) | 5 (5) | 1.8 (1.2) | Yes | Yes
| | | | | Ex: 24
| | | | | N: 48
Munoz, 2003 | 8 | 0 | 35 (10.3) | 37.5 | C: 37.5 | 0 | 99.3 (9.9) | 14.6 (8.7) | - | Yes | -
O'Donnell, 1989 | 57 | 100 | 31 (6.3) | 29.8 | C: 50.9 | - | - | - | - | No | -
Orriols, 1999 | 21 | 81 | 36.4 (10.9) | 23.8 | C: 57.1 | - | 80.8 (21) | 6.1 (6.9) | - | Yes | -
| | | | | Ex: 19
| | | | | N: 23.8
Paggiaro, 1993 | 16 | 68.8 | 46.7 (9.4) | - | C: 12.5 | - | 81.7 (12.5) | 20.7 (8.9) | 3.8 (4.1) | Yes | Yes
| | | | | Ex: 37.5
| | | | | N: 50
Paggiaro, 1990 | 10 | 80 | 49.5 (7.4) | - | C: 10 | - | 82.7 (15.6) | - | 4.3 (2.6) | Yes | Yes
| | | | | Ex: 50
| | | | | N: 40
Paggiaro, 1984a | 27 | 59.3 | 50.2 (9.1) | - | C: 29.6 | - | - | 15.5 (10) | - | Yes | -
| | | | | Ex: 0
| | | | | N: 70.4
Park, 2002a | 41 | - | - | - | - | - | - | 22.4 (5.5) | - | Yes | Yes
Park, 1994 | 3 | 100 | 47.3 (9.1) | 100 | C: 0 | - | - | - | - | Yes | -
| | | | | Ex: 100
| | | | | N: 0
Perfetti, 1998a | 99 | 73.7 | 43 (12) | 59.6 | C: 15.2 | - | - | 12.5 (11.3) | 3.2 | Yes | Yes
| | | | | Ex: 39.4
| | | | | N: 45.5
Piirila, 1996 | 7 | 100 | 26.9 (5.1) | - | C: 57.1 | - | - | - | - | No | -
| | | | | Ex: 0
| | | | | N: 28.6
Pisati, 1994 | 9 | - | - | - | C: 11.1 | - | - | - | - | Yes | -
| | | | | Ex: 11.1
| | | | | N: 77.8
Pisati, 1993 | 60 | - | 37.3 (11.6) | 13.3 | C: 15 | 5 | - | 15.3 (9.1) | 4.4 | Yes | Yes
| | | | | Ex: 0
| | | | | N: 85
Rosenberg, 1987 | 31 | 87.1 | 35.9 (16.6) | 29 | C: 19.4 | 3.2 | 97 (35.7) | 3 (6) | 1.4 (2.2) | Yes | -
Ross, 1998 | 1011 | 70.6 | 40.9 (12.3) | - | C: 22.4 | - | - | 4 (8.1) | - | No | -
| | | | | Ex: 27.8
| | | | | N: 40.8
Saetta, 1995 | 10 | 50 | 39.1 (12.8) | 20 | C: 0 | - | 98.6 (15) | 17.5 (14.5) | 3.5 (3.7) | Yes | Yes
| | | | | Ex: 0
| | | | | N: 100
Sen, 1998 | 3 | 66.7 | 31.3 (13.3) | 100 | C: 33.3 | 66.7 | - | - | 0.5 (0.1) | No | -
| | | | | Ex: 0
| | | | | N: 66.7
Simonsson, 1985 | 19 | 100 | 24 (4.5) | 10.5 | C: 57.9 | 10.5 | 93 (6) | 1.2 (1.3) | - | No | Yes
| | | | | Ex: 31.6
| | | | | N: 10.5
Slovak, 1985 | 8 | - | - | 100 | - | - | - | - | - | No | -
Smith, 1999 | - | - | - | - | - | - | - | - | - | No | -
Sulotto, 1989 | 10 | 50 | 39 (7.3) | - | C: 70 | - | 101.6 (9.5) | 9.5 (7) | - | Yes | No
Taivainen, 1998 | 24 | - | - | - | - | - | - | - | - | Yes | -
Vandenplas, 2002 | 36 | 11.1 | 32 (4.4) | 63.9 | C: 5.6 | 30.6 | - | - | 7.2 | Yes | Yes
| | | | | Ex: 5.6
| | | | | N: 88.9
Venables, 1987 | 6 | 0 | 39 (2.8) | 16.7 | C: 100 | 0 | - | - | - | Yes | -
Venables, 1985 | 21 | 100 | 41.2 | 28.6 | C: 47.6 | - | 93 | 7.7 | - | No | -

Abbreviations: C = current; Ex = ex; FEV_1_ = forced expiratory volume in one second; N = never; OA = occupational asthma; SIC = specific inhalational challenge

Table E-7 Description of interventions and outcomes (Management cohorts review)

Author, Year | Intervention(s) | | | Outcome(s)
| Type of Intervention | Description | Number of Patients | Test | Description
Allard, 1989 | Removed | Ceased exposure for at least 6 mos | 28 | NSBPT | Histamine: PC_20_ FEV_1_
| | | | Pulmonary function | FEV_1_
| | | | Questionnaire | Including symptoms, smoking habits, and need for medication
Ameille, 1997 | Exposed | No change | 20 | Questionnaire | Including current working status and financial situation
| Protection | Improved ventilation or used appropriate respirator | 46
| Reduced | Different job in same workplace | 38
| Removed | Left workplace | 85
Banks, 1990 | Reduced | Moved to areas with negligable or no exposure | 6 | NSBPT | Methacholine: PD_20_ FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
| | | | Questionnaire | Including symptoms and smoking habits
Barker, 1998 | Removed | All subjects left the factory in 1980 | 6 | NSBPT | Histamine bronchial responsiveness
| | | | Pulmonary function | Average daily amplitude (maximum PEFR - minimum PEFR/maximum PEFR) over 28 day period
| | | | Questionnaire | Including symptoms, medication use, and smoking
| | | | Skin prick test | 1% TCPA-HSA
| | | | Serum specific IgE | RAST
Bernstein, 2003 | Exposed | No intervention initiated | 1 | Skin prick test | Latex
| Protection | Used NRL gloves | 19
| Reduced | Transferred | 1
| Removed | Left workplace | 4
Burge, 1982a | Reduced | Moved within factory, no description of exposure status | 9 | NSBPT | Histamine reactivity
| Removed | Changed workplace | 22 | Pulmonary function | FEV_1_ and FVC
| | | | Questionnaire | Including symptoms and medication use
Gannon, 1993 | Exposed | Not described | 34 | Questionnaire | Including symptoms, employment state, and current financial situation
| Removed | Removed from exposure | 78
Gassert, 1998 | Removed | Removed from exposure | 55 | Questionnaire | Including symptoms, daily activity, and medication use
Gorski, 1999 | Removed | Changed jobs or stopped working | 56 | NSBPT | Histamine: PC_20_ FEV_1_
| | | | Pulmonary function | FEV_1_
| | | | Questionnaire | Including symptoms and medication use
| | | | Skin prick test | Common allergens and flours
| | | | Serum specific IgE | RAST
Grammer, 2000 | Reduced | Transferred to lower exposure | 22 | Pulmonary function | Spirometry (not specified)
| Removed | Completely removed from exposure | 7 | Questionnaire | Including type and severity of symptoms
| | | | Serum specific IgE | Described in text
| | | | Serum specific IgG | Described in text
Grammer, 1996 | Removed | Removed from exposure for at least 1 yr | 11 | Pulmonary function | Spirometry (not specified)
| | | | Questionnaire | Including type and severity of symptoms
| | | | Serum specific IgE | Described in text
| | | | Serum specific IgG | Described in text
Harries, 1979 | Reduced | Changed tasks | 1 | Interview | Including medication use
| Removed | Moved to a safer location or left industry | 2 | Pulmonary function | FEV_1_ and FVC
Jyo, 1989 | Medications | Immunotherapy | 47 | Improvement after hyposensitization therapy | Improvement after hyposensitization therapy
| | | | Serum specific IgE | RAST
| | | | Serum specific IgG | RAST
Laoprasert, 1998 | Protection | Used NRL gloves and/or helmet filter | 11 | SIC | Latex aeroallergen
| | | | Symptoms | Not described
Lemiere, 2000 | Removed | Removed from exposure | 16 | Questionnaire | Including symptoms, need for medication, and smoking habits
| | | | SIC | Suspected agent
| | | | Skin prick test | Cereals, guar gum, and psyllium
| | | | Serum specific IgE | RAST
Lemiere, 1996 | Removed | No longer exposed after diagnosis | 15 | Questionnaire | Including symptoms and need for medication
| | | | SIC | Suspected agent
| | | | Skin prick test | Common inhalants
| | | | Serum specific IgE | RAST
| | | | Serum specific IgG | Not described
Lin, 1996 | Exposed | Continued exposure | 158 | Pulmonary function ^17^ | FEV_1_
| Removed | Left industry after diagnosis | 122 | Exhaled nitric oxide ^25^ | Not reported
| | | | NSBPT ^25^ | Methacholine: PC_20_ FEV_1_
| | | | Questionnaire ^25^ | Not described
| | | | Sputum cell counts ^25^ | Eosinophils, neutrophils, epithelial, lymphocytes, and macrophages
| | | | Bronchial lavage ^22^ | Total cell count and % macrophages, lymphocytes, neutrophils, eosinophils, epithelial cells, degenerated cells, total protein, and albumin
| | | | Interview ^20^ | Including current work situation
| | | | Skin prick test ^20^ | Common allergens
| | | | Serum specific IgG ^20^ | Radial immunodiffusion
| Reduced ^18^ | Changed jobs resulting in intermittant exposure | 42 | Serum eosinophil count ^19^ | Serum eosinophil count
| | | | Bronchial lavage ^21^ | Including protein, albumin, eosinophils, and neutrophils
Lozewicz, 1987 | Reduced | Relocated to another area within the plant | 28 | NSBPT | Histamine: 10% fall in FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
| | | | Questionnaire | Including symptoms and medication use
| Removed | Left workplace | 21 | SIC | TDI, MDI, HDI, NDI
| | | | Skin prick test | Common allergens
Maghni, 2004 | Removed | No longer exposed | 133 | NSBPT | Methacholine: PC_20_ FEV_1_
| | | | Pulmonary function | FEV_1_
| | | | Questionnaire | Including exposure status, symptoms, and medication needs
| | | | Sputum cell counts | Eosinophils, neutrophils, IL-8, MPO, and eotaxin
Malo, 2004 | Removed | No longer exposed to causal agent | 80 | NSBPT | Methacholine: PC_20_ FEV_1_
Malo, 1994a | Removed | Not exposed to chlorine during the 1 yr follow-up period | 20 | Medications | Beta-2-agonist and or inhaled steroids or none
| | | | NSBPT | Methacholine: PC_20_ FEV_1_
| | | | Pulmonary function | FEV_1_
Malo, 1993b | Removed | Subjects had left work for at least 2 yrs prior to entering the study | 134 | Quality of life questionnaire ^28^ | Asthma quality of life questionnaire
| | | | WCB claim data ^29^ | Administrative WCB claim data
| | | | NSBPT ^28^ | Methacholine: PC_20_ FEV_1_
| | | | Pulmonary function ^29^ | FEV_1_
| | | | Questionnaire ^29^ | Including symptoms and need for medication
Malo, 1988b | Removed | Removed from exposure since the time of diagnosis | 31 | NSBPT | Histamine or methacholine: PC_20_ FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
| | | | Questionnaire | Including sympoms, need for medication, and smoking habits
| | | | Serum specific IgE | RAST
Mapp, 1988 | Exposed | Not described | 5 | NSBPT | Methacholine: PD_20_ FEV_1_
| Removed | No longer exposed | 30 | Pulmonary function | FEV_1_
| | | | SIC | TDI, MDI, HDI, NDI
| | | | Symptoms | Not described
Marabini, 2003 | Exposed | Attempted to reduce exposure (n=7) but none moved to no exposure | 10 | NSBPT | Methacholine: PC_20_ FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
Merget, 1999 | Exposed | Same workplace | 9 | NSBPT ^30^ | Methacholine: PD_50_ sGaw
| Reduced | Transferred to jobs not directly exposed to irritant | 16 | Pulmonary function ^30^ | FEV_1_
| Removed | Transferred outside of workplace | 19 | Questionnaire ^30^ | Including symptoms at and away from work and employment status
| | | | Skin prick test ^30^ | Platinum salts
| | | | SIC ^31^ | Platinum salts
Meyer, 1977 | Removed | Ceased exposure | 168 | NSBPT | Acetycholine: improved responsiveness
Moscato, 1999 | Exposed | Performed the same task in the same workplace | 7 | NSBPT | Methacholine: PD_20_ FEV_1_
| Reduced | Changed task within workplace and reported intermittent or lower exposure | 5 | Pulmonary function | PEF for the duration of the study
| | | | Questionnaire | Including symptoms, working conditions, financial condition, and disease related costs
| Removed | Left workplace | 7
Munoz, 2003 | Protection | Not described | 3 | NSBPT | Methacholine: PC_20_ FEV_1_
| Removed | All subjects advised to avoid exosure | 5 | Pulmonary function | Serial PEF 4 times/day for 2 wks on and off work
| | | | SIC | Potassium persulfate
| | | | Skin prick test | Potassium and ammonium persulfate
O'Donnell, 1989 | Exposed | Moved within factory, no description of exposure | 57 | NSBPT | Methacholine: PC_20_ FEV_1_
Orriols, 1999 | Protection | Not described | 4 | Symptoms | Persistent, worsening, or asymptomatic
| Removed | Avoided casual exposure | 17
Paggiaro, 1993 | Reduced | Moved within factory with occasional exposure | 7 | NSBPT | Methacholine: PD_20_ FEV_1_
| Removed | Left industry | 9 | SIC | TDI
Paggiaro, 1990 | Removed | Ceased exposure after diagnosis | 10 | Bronchial lavage | Total cell count and % macrophages, lymphocytes, neutrophils, and eosinophils
| | | | NSBPT | Methacholine: PD_15_ FEV_1_
Paggiaro, 1984a | Exposed | Continued exposure | 15 | NSBPT | Bethanechol: 15% drop in FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
| Removed | Left workplace | 12 | SIC | Not described
| | | | Skin prick test | Common allergens
Park, 2002a | Removed | Withdrawn from work to avoid further exposure | 41 | Serum specific IgE ^32^ | ELISA
Park, 1994 | Removed | Advised to discontinue exposure | 3 | NSBPT Serum specific IgG ^32^ | Methacholine: PC_20_ FEV_1_ ELISA
| | | | NSBPT ^33^ | Methacholine: PC_20_ FEV_1_
Perfetti, 1998a | Removed ^34^ | Subjects removed from exposure >or equal to 5 yrs, and those removed from exposure for <5 yrs | 99 | NSBPT ^34^ | Methacholine: PC_20_ FEV_1_
| | | | Pulmonary function ^34^ | FEV_1_
| | | | Questionnaire ^34^ | Including current and previous use of inhaled steroids and exposure status
| | | | Skin prick test ^34^ | Ubiquitous agents
| Reduced ^35^ | Occasional or reduced levels of exposure (wearing a mask or respirator) | 8 | Serum specific IgE ^35^ | EAST
Piirila, 1996 | Reduced | Same task after industrial accident (RADS) | 3 | Bronchodilatory response | Change in FEV_1_ 5 minutes after 3 puffs of rimiterol hydrobromide
| Removed | Retired after industrial accident (RADS) | 1 | Exercise test NSBPT | Change in PEF after exercise Histamine: percent change in FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
Pisati, 1994 | Exposed | Not described | 1 | NSBPT | Methacholine: PD_15_ FEV_1_
| | | | Pulmonary function | FEV_1_and FVC
| Removed | Moved to another industry | 8 | Questionnaire | Including exposure status, symptoms, and medication needs
| | | | SIC | Cobalt
| | | | Skin prick test | Common inhalant allergens and patch test to cobalt sulphate
Pisati, 1993 | Reduced | Different task with reduced exposure and used protective respiratory device | 17 | Interview | Including working conditions, symptoms, need for medication, and hospital stays
| | | | NSBPT | Methacholine: PD_15_ FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
| Removed | Ceased exposure within 6 mos of diagnosis | 43 | Skin prick test | Common inhalant allergens
Rosenberg, 1987 | Exposed | Unchanged work conditions | 4 | NSBPT | Acetycholine: percent change in FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
| Protection | Efficient masks, ventilation | 3 | Questionnaire | Including work status, symptoms, requirement for medications, and smoking habits
| Reduced | Changed task within workplace | 4
| Removed | Completely removed from exposure | 20
Ross, 1998 | Removed | Not described | 1033 | Questionnaire | Including symptoms and employment status
Saetta, 1995 | Removed | Ceased exposure | 10 | Bronchoscopy ^36^ | Fibroblast counts
| | | | NSBPT ^36^ | Methacholine: PD_20_ FEV_1_
| | | | SIC ^36^ | TDI
| | | | Bronchoscopy ^37^ | Basement membrane thickness
Sen, 1998 | Removed | Left industry | 3 | Serum specific IgE | RAST
| | | | Serum specific IgG | RAST
Simonsson, 1985 | Exposed | Not described | 6 | NSBPT | Methacholine: TD_15_ FEV_1_
| | | | Pulmonary function | FEV_1_ and FVC
| Removed | Not described | 13 | SIC | Aluminium salts
Slovak, 1985 | Protection | Helmet respirator and outer protective clothing | 10 | Pulmonary function | Serial PEF every 2 waking hrs for 7 wks
| | | | Skin prick test | Lab animal allergy
Smith, 1999 | Exposed | Same workplace | 11 | Interview | Including symptoms and current job situation
| Reduced | Different job in same workplace | 11
Sulotto, 1989 | Removed and medications | Took beclomethasone for 3 to 12 mos after cessation of exposure | 10 | NSBPT | Methacholine: PD_20_ FEV_1_
| | | | Pulmonary function | FEV_1_, FVC, MEF_50_, MEF_25_
Taivainen, 1998 | Protection | Helmet respirator | 26 | Pulmonary function | Serial PEF: morning and evening
| | | | Symptoms | Recorded daily on a 4 point scale
Vandenplas, 2002 | Reduced | <20 pairs of latex gloves used per wk by co-workers | 20 | NSBPT | Histamine: PC_20_ FEV_1_
| Removed | Latex gloves never used | 16 | Pulmonary function | FEV_1_
| | | | Questionnaire | Including occupational status, smoking habits, symptoms, medication needs, and other allergic reactions
| | | | SIC | Latex gloves
Venables, 1987 | Removed | Not described | 6 | NSBPT | Histamine: PC_20_ FEV_1_
| | | | Pulmonary function | FEV_1_
| | | | Questionnaire | Including current respiratory symptoms, medication, and smoking habits.
| | | | Skin prick test | 1% TCPA-HSA
| | | | Serum specific IgE | RAST
Venables, 1985 | Reduced | Industrial intervention to reduce TDI levels | 21 | Pulmonary function Questionnaire | Serial PEF: every 2 waking hrs for 4 wks Including symptoms

Abbreviations: EAST = enzyme allergosorbent test; ELISA = enzyme-linked immuno sorbent assay; FEV_1_ = forced expiratory volume in one second; FVC = forced vital capacity; HDI = hexamethylene di-isocyanate; hrs = hours; IL-8 = interleukin-8; MDI = diphenylmethane di-isocyanate; MEF_25_ = maximal expiratory flow at 25% of vital capacity; MEF_50_ = maximal expiratory flow at 50% of vital capacity; mos = months; MPO = myeloperoxidase; NDI = naphthalene di-isocyanate; NSBPT = non-specific bronchial provocation; NRL = natural rubber latex; PC_20_ = provocative concentration causing a 20% drop in FEV_1_; PD_15_ = provocative dose causing a 15% drop in FEV_1_; PD_50_ = provocative dose causing a 50% drop in FEV_1_; PEF = peak expiratory flow; PEFR = peak expiratory flow rate; RADS = reactive airways dysfunction syndrome; RAST = radio allegro sorbent test; SIC = specific inhalational challenge; TCPA-HSA = tetrachlorophthalic anhydride human serum albumin; TD_15_ = threshold dose causing a 15% drop in FEV_1_; TDI = toluene di-isocyanates; WCB = workers' compensation board; wk = week; wks = weeks; yr = year; yrs = years

Table E-8 Description of included studies (Management trials review)

Author, Year | Location | Language of Publication | Intervention Categories | Suspected Agent (molecular weight) | Subject Source | Description of Included Subjects
Armentia, 1990 | Spain | English | Medications | Flour (H) | - | Bakers and pastry cooks with asthma symptoms due to wheat flour
Crescioli, 1992 | Italy | English | Medications | Isocyanates (L) | - | Workers SIC positive to TDI
DeMarzo, 1988 | Italy | English | Medications | Isocyanates (L) | - | Workers sensitized to TDI
Fabbri, 1985 | Italy | English | Medications | Isocyanates (L) | - | Workers SIC positive to TDI
Maestrelli, 1993 | Italy | English | Removed and medications | Isocyanates (L) | - | Workers with OA due to TDI
Malo, 1996 | Canada | English | Removed and medications | Mixed (M) | - | Workers with OA due to various causes
Malo, 1994b | Canada | French | Medications | Mixed (M) | - | Workers, mostly exposed to isocyanates, referred to a clinic for exploration of OA
Mapp, 1987 | Italy | English | Medications | Isocyanates (L) | Clinic | Workers with OA due to TDI
Moscato, 1985 | Italy | English | Medications | Isocyanates (L) | - | Male workers with OA due to TDI
Mueller, 1998 | Germany | English | Protection | Straw/grain (U) | - | Dairy/bull breeding farmers with suspected OA
Paggiaro, 1987a | Italy | English | Medications | Isocyanates (L) | - | Workers with OA due to TDI
Vandenplas, 1995a | Belgium | English | Reduced | Latex (H) | - | Healthcare workers with latex glove related asthma
Woitowitz, 1972 | Germany | English | Medications | Flour (H) | - | Workers with OA due to flour

Abbreviations: H = high; L = low; OA = occupational asthma; SIC = specific inhalational challenge; TDI = toluene di-isocyanates; U = unknown

Table E-9 Demographic characteristics of included patients (Management trials review)

Author, Year | Number of Patients | Male | Age | Atopic | Smoking Status | History of Asthma | % predicted FEV_1_ (unless otherwise stated) | Years of Exposure | Years of Symptoms | SIC Confirmed OA | Current Medication Stopped for Testing
| | (%) | mean (SD) | (%) | (%) | (%) | mean (SD) | mean (SD) | mean (SD)
Armentia, 1990 | 30 | - | 34.5 (12.2) | - | - | - | - | 12.8 (9.6) | 5 (4) | Yes | -
Crescioli, 1992 | 6 | 100 | 42.8 (6.5) | 0 | C: 0 | - | 104.5 (10.4) | - | - | Yes | Yes
| | | | | Ex: 0
| | | | | N: 100
DeMarzo, 1988 | 9 | 88.9 | 34.7 (10.4) | 0 | - | - | 96.7 (10.4) | - | - | No | Yes
Fabbri, 1985 | 5 | 60 | 39.6 (17.3) | 0 | C: 0 | - | 108 (11.7) | - | - | Yes | Yes
| | | | | Ex: 20
| | | | | N: 80
Maestrelli, 1993 | 15 | 26.7 | 37.4 (10) | 20 | - | - | - | 12.6 (7.2) | 3.4 (-) | Yes | Yes
Malo, 1996 | 32 | 68.8 | 39.3 (12.9) | 59.4 | C: 21.9 | - | - | 9.4 (11) | 2.7 (-) | Yes | -
| | | | | Ex: 9.4
| | | | | N: 68.8
Malo, 1994b | 22 | 63.6 | 46 (10) | 59.1 | C: 22.7 | - | 84 (13) | 13 (12) | 3 (3) | Yes | Yes
| | | | | Ex: 27.3
| | | | | N: 50
Mapp, 1987 | 24 | 66.7 | 35.2 (11.6) | 29.2 | - | - | - | - | - | Yes | Yes
Moscato, 1985 | 5 | 100 | 29.4 (9) | - | - | - | 92.2 (13.8) | - | - | Yes | -
Mueller, 1998 | 26 | 69.2 | 38.6 (11.8) | 23.1 | C: 38.5 | - | FEV_1_: 3.5 (1) | 34 (14.9) | 9.1 (6.8) | Yes | Yes
Paggiaro, 1987a | 10 | 80 | 48 (8.2) | 20 | C: 20 | - | 82.2 (16.2) | - | 5.5 (4) | No | Yes
| | | | | Ex: 30
| | | | | N: 50
Vandenplas, 1995a | 8 | 12.5 | 31 (3.7) | 62.5 | C: 0 | - | 98.6 (10.2) | - | - | Yes | -
| | | | | Ex: 12.5
| | | | | N: 87.5
Woitowitz, 1972 | 18 | 100 | 31.4 (10.2) | - | - | - | - | - | - | Yes | -

Abbreviations: C = current;

Ex= ex;

FEV _ 1 _ = forced expiratory volume in one second

N = never

OA = occupational asthma

SD = standard deviation

SIC = specific inhalational challenge

Table E-10 Description of interventions and outcomes (Management trials review)

Author, Year | Intervention(s) | | | Outcome(s)
| Type of Intervention | Description | Number of Patients | Test | Description
Armentia, 1990 | Medications | Hyposensitization (immunotherapy) and placebo | 26 | Hypersensitivity after 20 mos of immunotherapy or placebo | Immune complexes ^38^ Wheal area ^39^ ; methacholine challenge ^39^ ; serum total IgE ^39^ ; serum specific IgE ^39^
Crescioli, 1992 | Medications | Theophylline and placebo | 6 | 2 SICs separated by 1 wk: 1 with drug / 1 without | Change in FEV_1_ after SIC
DeMarzo, 1988 | Medications | High dose beclomethasone, low dose beclomethasone, placebo | 9 | 3 SICs separated by at least 1 wk: for each treatment phase | Change in FEV_1_ after SIC
Fabbri, 1985 | Medications | Indomethacin and prednisone | 5 | 2 SICs: pre-treatment and 3 days after treatment started | Change in FEV_1_ after SIC
Maestrelli, 1993 | Removed and medications | Beclomethasone and placebo | 15 | Hypersensitivity after 5 mos of drug or placebo | Maximum fall in FEV_1_ after SIC; PD_20_ FEV1 after methacholine challenge; change in cortisol level
Malo, 1996 | Removed and medications | Beclomethasone and placebo | 32 | Spirometry/hyper-reponsiveness after 12 mos with treatment 1 and 6 mos with treatment 2 | Change in pulmonary function; PC_20_ FEV_1_ after methacholine challenge; quality of life; and symptoms
Malo, 1994b | Medications | Salbutamol and placebo | 25 | Change in FEV_1_ after SIC | Change in FEV_1_ after SIC after administration with salbutomol or placebo to diminish late asthmatic reaction
Mapp, 1987 | Medications | Beclomethasone and placebo, thoephylline and placebo, varapamil and placebo, cromolyn and placebo | 6, 6, 6, 6 | 2 SICs separated by at least 1 wk: 1 with drug / 1 without | Change in FEV_1_ after SIC
Moscato, 1985 | Medications | Nifedipine and placebo | 5 | 2 SICs separated by at least 1 wk: 1 with drug / 1 without | Change in FEV_1_ after SIC
Mueller, 1998 | Protection | Respirators with P2 filters | 26 | 2 SIC's separated by 21 wks: 1 without respirator / 1 with | Change in airway resistance and thoracic gas volume before and after SIC
Paggiaro, 1987a | Medications | Atropine and placebo | 18 | 2 SICs separated by at least 1 wk: 1 with drug / 1 without | Change in airway resistance and thoracic gas volume before and after SIC
Vandenplas, 1995a | Reduced | 4 types of gloves: Triflex®, low-powdered Triflex®, non-powdered Nutex®, powdered Sensi-Touch® | 8 | 3 SICs with different gloves (all Triflex® then randomized to two of low-powdered Triflex®, non-powdered Nutex®, or powdered Sensi-Touch®) | Maximum fall in FEV_1_ after SIC
Woitowitz, 1972 | Medications | Fenoterol and placebo | 9 | SIC after treatment with drug or placebo | Airway resistance

Abbreviations: FEV_1_ = forced expiratory volume in one second

PC _ 20 _ = provocative concentration causing a 20% drop in FEV_1_

PD _ 20 _ = provocative dose causing a 20% drop in FEV_1_

SIC = specific inhalational challenge

wk = week

wks = weeks

Table E-11 Methodological quality of included studies (Management cohorts review)

Author, Year | Downs and Black Quality Score | Data Collection | Provided Individual Patient Data | Funding Source
Allard, 1989 | 16 | Prospective | No | Not reported
Ameille, 1997 | 17 | Prospective | No | Not reported
Banks, 1990 | 17 | Prospective | Yes | Government
Barker, 1998 | 21 | Prospective | Yes | Government
Bernstein, 2003 | 15 | Prospective | No | Government
Burge, 1982a | 16 | Prospective | No | Not reported
Gannon, 1993 | 19 | Prospective | No | Not reported
Gassert, 1998 | 21 | Prospective | No | Government
Gorski, 1999 | 12 | Prospective | No | Not reported
Grammer, 2000 | 15 | Prospective | No | Internal and private
Grammer, 1996 | 17 | Prospective | Yes | Internal
Harries, 1979 | 17 | Prospective | Yes | Not reported
Jyo, 1989 | 9 | Prospective | Yes | Government
Laoprasert, 1998 | 19 | Prospective | Yes | Private and internal
Lemiere, 2000 | 20 | Prospective | Yes | Foundation
Lemiere, 1996 | 22 | Prospective | Yes | Private and other
Lin, 1996 | 22 | Prospective | No | Not reported
Lozewicz, 1987 | 19 | Prospective | No | Not reported
Maghni, 2004 | 21 | Prospective | No | Not reported
Malo, 2004 | 17 | Prospective | No | Not reported
Malo, 1994 | 18 | Prospective | Yes | Government and other
Malo, 1993 | 14 | Prospective | No | Not reported
Malo, 1988 | 18 | Prospective | Yes | Not reported
Mapp, 1988 | 18 | Prospective | Yes | Government and other
Marabini, 2003 | 18 | Prospective | No | Other
Merget, 1999 | 20 | Prospective | No | Not reported
Meyer, 1977 | 6 | Prospective | No | Not reported
Moscato, 1999 | 22 | Prospective | No | Government
Munoz, 2003 | 19 | Prospective | Yes | Not reported
O'Donnell, 1989 | 13 | Prospective | No | Not reported
Orriols, 1999 | 12 | Prospective | No | Not reported
Paggiaro, 1993 | 16 | Prospective | Yes | Government
Paggiaro, 1990 | 18 | Prospective | Yes | Government
Paggiaro, 1984 | 15 | Prospective | Yes | Not reported
Park, 2002 | 18 | Prospective | Yes | Private
Park, 1994 | 12 | Prospective | Yes | Not reported
Perfetti, 1998 | 19 | Prospective | Yes | Foundation
Piirila, 1996 | 17 | Prospective | Yes | Not reported
Pisati, 1994 | 14 | Prospective | Yes | Not reported
Pisati, 1993 | 18 | Prospective | No | Not reported
Rosenberg, 1987 | 10 | Prospective | Yes | Not reported
Ross, 1998 | 22 | Retrospective | No | Government
Saetta, 1995 | 17 | Prospective | Yes | Government
Sen, 1998 | 13 | Prospective | Yes | Not reported
Simonsson, 1985 | 13 | Prospective | Yes | Not reported
Slovak, 1985 | 9 | Prospective | Yes | Not reported
Smith, 1998 | 12 | Prospective | No | Not reported
Sulotto, 1989 | 10 | Prospective | No | Not reported
Taivainen, 1998 | 21 | Prospective | Yes | Not reported
Vandenplas, 2002 | 22 | Prospective | No | Other
Venables, 1987 | 20 | Prospective | Yes | Not reported
Venables, 1985 | 10 | Prospective | No | Not reported

Table E-12 Methodological quality of included studies (Management trials review)

Author, Year | Randomization | Randomization Method | Double Blind | Double Blind Method | Explanation of Withdrawal or Follow-up | Allocation Concealment | Funding
Armentia, 1990 | No | Unclear | Yes | Unclear | Adequate | Inadequate | Not reported
Crescioli, 1992 | Yes | Unclear | Yes | Unclear | Adequate | Unclear | Government and other
DeMarzo, 1988 | Yes | Unclear | Yes | Unclear | Adequate | Unclear | Private and government
Fabbri, 1985 | No | Unclear | No | Unclear | Adequate | Inadequate | Private and government
Malo, 1996 | Yes | Unclear | Yes | Unclear | Adequate | Adequate | Private and foundation
Malo, 1994 | No | Unclear | Yes | Unclear | Adequate | Unclear | Not reported
Mapp, 1987 | Yes | Unclear | Yes | Unclear | Adequate | Unclear | Government and foundation
Mastrelli, 1993 | Yes | Unclear | Yes | Unclear | Adequate | Unclear | Government
Moscato, 1983 | Yes | Unclear | No | Unclear | Adequate | Unclear | Not reported
Muller-Wening, 1998 | No | Unclear | No | Unclear | Adequate | Inadequate | Not reported
Paggiaro, 1987 | No | Unclear | No | Unclear | Adequate | Inadequate | Government
Vandenplas, 1995 | Yes | Unclear | No | Unclear | Adequate | Unclear | Not reported
Woitowitz, 1972 | Yes | Unclear | Yes | Unclear | Adequate | Adequate | Not reported

## References for Appendix E

### Diagnosis

1 Alvarez MJ, Estrada JL, Gozalo F, et al. Oilseed rape flour: another allergen causing occupational asthma among farmers. Allergy. 2001;56(2):185-8. [pmid: 11167382].
2 Alvarez MJ, Tabar AI, Quirce S, et al. Diversity of allergens causing occupational asthma among cereal workers as demonstrated by exposure procedures. Clin Exp Allergy. 1996;26(2):147-53. [pmid: 8835121].
3 Anees W, Gannon PF, Huggins V, et al. Effect of Peak Expiratory Flow Data Quantity on Diagnostic Sensitivity and Specificity in Occupational Asthma. Eur Respir J. 2004;23(5):370-4.
4 Avery SB, Stetson DM, Pan PM, et al. Immunological investigation of individuals with toluene diisocyanate asthma. Clin Exp Immunol. 1969;4(5):585-96. [pmid: 4182406]. [pmcid: 1579066].
5 Balland S, Grosclaude M, Jarsaillon E, et al. Realistic challenge and bronchial hyperreactivity in occupational asthma. [French]. J Toxicol Clin Exp. 1989;9(1 BIS):15-23.
6 Baur X, Fruhmann G. Papain-induced asthma: diagnosis by skin test, RAST and bronchial provocation test. Clin Allergy. 1979;9(1):75-81. [pmid: 421337].
7 Baur X, Huber H, Degens PO, et al. Relation between occupational asthma case history, bronchial methacholine challenge, and specific challenge test in patients with suspected occupational asthma. Am J Ind Med. 1998;33(2):114-22. [pmid: 9438044].
8 Behr J, Baur X, Rommelt H, et al. [Diagnosis of irritative-toxic isocyanate asthma with the isocyanate exposure test]. Pneumologie. 1990;44(Suppl 1):229-31. [pmid: 2367373].
9 Bernstein DI, Cartier A, Cote J, et al. Diisocyanate antigen-stimulated monocyte chemoattractant protein-1 synthesis has greater test efficiency than specific antibodies for identification of diisocyanate asthma.[see comment]. Am J Respir Crit Care Med. 2002;166(4):445-50. [pmid: 12186818].
10 Biot N, Grosclaude M, Meyer JL, et al. [Contribution of biological tests in the evaluation of professional asthma (author's transl)]. [French]. Poumon Coeur. 1980;36(4):257-61. [pmid: 6160568].
11 Block G, Tse KS, Kijek K, et al. Baker's asthma. Clinical and immunological studies. Clin Allergy. 1983;13(4):359-70. [pmid: 6349847].
12 Burge PS. Non-specific bronchial hyper-reactivity in workers exposed to toluene di-isocyanate, diphenyl methane di-isocyanate and colophony. Eur J Respir Dis 1982; Suppl 123:91–6.
13 Burge PS, Harries MG, Lam WK, et al. Occupational asthma due to formaldehyde. Thorax. 1985;40:255-60. [pmid: 4023975]. [pmcid: 460042].
14 Burge PS, Harries MG, O'Brien et al. Bronchial provocation studies in workers exposed to the fumes of electronic soldering fluxes. Clin Allergy 1980; 10:137–49.
15 Burge PS, Harries MG, O'Brien IM, et al. Respiratory disease in workers exposed to solder flux fumes containing colophony (pine resin). Clin Allergy. 1978;8(1):1-14. [pmid: 414855].
16 Burge PS, O'Brien IM, Harries MG. Peak flow rate records in the diagnosis of occupational asthma due to colophony. Thorax. 1979;34:308-16. [pmid: 483205]. [pmcid: 471066].
17 Burge PS, O'Brien IM, Harries MG. Peak flow rate records in the diagnosis of occupational asthma due to isocyanates. Thorax. 1979;34(3):317-23. [pmid: 225841]. [pmcid: 471067].
18 Butcher BT, O'Neil CE, Reed MA, et al. Radioallergosorbent testing of toluene diisocyanate reactive individuals using ptolyl isocyanate antigen. J Allergy Clin Immunol. 1980;66(3):213-6. [pmid: 6251126].
19 Carletti AM, Talini D, Carrara M, et al. [Specific bronchial provocation tests with flour in the diagnosis of occupational bronchial asthma]. Med Lav. 1997;88(5):406-15. [pmid: 9489304].
20 Cartier A, Grammer L, Malo J L, et al. Specific serum antibodies against isocyanates: association with occupational asthma. J Allergy Clin Immunol. 1989;84(4 Pt 1):507-14. [pmid: 2794294].
21 Cartier A, Malo J L,, Dolovich J. Occupational asthma in nurses handling psyllium. Clin Allergy. 1987;17(1):1-6. [pmid: 3829366].
22 Cartier A, Malo JL, Ghezzo H, et al. IgE sensitization in snow crab-processing workers. J Allergy Clin Immunol. 1986;78(2):344-8. [pmid: 3734286].
23 Choudat D, Fabries JF, Martin JC, et al. Quantification of the dose of inhaled flour: relation with nonspecific bronchial and immunological reactivities. Eur Respir J. 1999;14(2):328-34. [pmid: 10515409].
24 Cirla AM, Inzoli S, Aresini G, et al. [Evaluation of the diagnostic criteria in occupational asthma caused by isocyanates]. Med Lav. 1975;66(1):5-23. [pmid: 166293].
25 Colas M, Grosclaude M, Balland S, et al. Value of realistic exposure tests in the diagnosis of occupational asthma due to exotic woods [French]. Rev Pneumol Clin. 1985;41(1):39-46. [pmid: 4001745].
26 Cortona G, Beretta F, Traina G, et al. [Preliminary investigation in a pharmaceutical industry: bromelin-induced pathology (author's transl)] Italian. Med Lav. 1980;1:70-5. [pmid: 6450319].
27 Cote J, Kennedy S, Chan-Yeung M. Quantitative versus qualitative analysis of peak expiratory flow in occupational asthma. Thorax. 1993;48(1):48-51. [pmid: 8434353]. [pmcid: 464241].
28 Coutts IL, Lozewicz S, Dally MB, et al. Respiratory symptoms related to work in a factory manufacturing cimetidine tablets. BMJ (Clin Res Ed). 1984;288(6428):1418.
29 Curran AD, Burge PS, Wiley K. Clinical and immunologic evaluation of workers exposed to glutaraldehyde. Allergy. 1996;51(11):826-32. [pmid: 8947341].
30 Davison AG, Britton MG, Forrester JA, et al. Asthma in merchant seamen and laboratory workers caused by allergy to castor beans: analysis of allergens. Clin Allergy. 1983;13:553-61. [pmid: 6640891].
31 De Zotti R, Gubian F. Asthma and rhinitis in wooding workers. Allergy Asthma Proc. 1996;17(4):199-203. [pmid: 8871738].
32 De Zotti R, Gubian F, Negro C. [Changes in blood eosinophils and nonspecific bronchial reactivity after exposure tests to wheat flour and TDI]. Med Lav. 1996;87(2):152-61. [pmid: 8926918].
33 Dellabianca A, Omodeo P, Colli MC, et al. Bronchial responsiveness to ultrasonic “fog” in occupational asthma due to low molecular weight chemicals. Ann Allergy Asthma Immunol. 1996;77(5):378-84. [pmid: 8933776].
34 Dente PL, Rossi O, Talini D, et al. Bronchial hyperresponsiveness and respiratory symptoms in toluene di-isocyanate (TDI) induced asthma. Bull Eur Physiopathol Respir. 1986;22(Suppl 8):A739.
35 Di Franco A, Vagaggini B, Bacci E, et al. Leukocyte counts in hypertonic saline-induced sputum in subjects with occupational asthma. Respir Med. 1998;92(3):550-7. [pmid: 9692121].
36 Di Stefano F, Siriruttanapruk S, McCoach J, et al. Glutaraldehyde: an occupational hazard in the hospital setting. Allergy. 1999;54(10):1105-9. [pmid: 10536890].
37 Duan YY, et al. Occupational toluene diisocyanate (TDI) asthma inhalation challenge test and TDI-HSA skin test and detection os specific IgE. Chinese J Tubercul Respir Dis. 1989;12(3):149-52.
38 Ferguson K, Gallie A, Ahmad D, et al. Asthma in isocyanate workers: How often is it related to occupation?. J Occup Health Safety - Austr New Zeal. 1996;12(1):31-40.
39 Gannon PF, Newton DT, Belcher J, et al. Development of OASYS-2: a system for the analysis of serial measurement of peak expiratory flow in workers with suspected occupational asthma. Thorax. 1996;51(5):484-9. [pmid: 8711675]. [pmcid: 473592].
40 Girard F, Chaboillez S, Cartier A, et al. An Effective Strategy for Diagnosing Occupational Asthma: Use of Induced Sputum. Am J Respir Crit Care Med. 2004;170(8):845-50. [Epub ahead of print]. [pmid: 15271693].
41 Graneek BJ, Durham SR, Newman Taylor AJ. Late asthmatic reactions and changes in histamine responsiveness provoked by occupational agents Bulletin. Eur Physiopathol Respir. 1987;23(6):577-81.
42 Grosclaude M, Kofman J, Perrin-Fayolle M. Respiratory functional tests in professional asthma. Value of realistic tests. Poumon Coeur. 1980;36(4):249-54. [pmid: 7443616].
43 Harries MG, Burge PS, O'Brien IM. Occupational type bronchial provocation tests. Testing with soluble antigens by inhalation. Br J Ind Med. 1980;37(3):248-52. [pmid: 7426475]. [pmcid: 1008703].
44 Hinojosa M, Losada E, Moneo I, et al. Occupational asthma caused by African maple (Obeche) and Ramin: evidence of cross reactivity between these two woods. Clin Allergy. 1986;16(2):145-53. [pmid: 3518985].
45 Howe W, Venables KM, Topping MD, et al. Tetrachlorophthalic anhydride asthma: evidence for specific IgE antibody. J Allergy Clin Immunol. 1983;71(1 Pt 1):5-11. [pmid: 6822691].
46 Huggins V, Hole A, Burge PS et al. Peak expiratory flow responses analyzed with OASYS in workers exposed to detergent enzymes. Eur Respir Soc 2003.
47 Jager D, Engelke T, Rennert S, et al. [Stepwise diagnosis of respiratory latex allergy]. Pneumologie. 1993;47(8):491-6. [pmid: 8378296].
48 Karol MH, Tollerud DJ, Campbell TP, et al. Predictive value of airways hyperresponsiveness and circulating IgE for identifying types of responses to toluene diisocyanate inhalation challenge. Am J Respir Crit Care Med. 1994;149(3 Pt 1):611-5. [pmid: 8118626].
49 Kern DG. Outbreak of the reactive airways dysfunction syndrome after a spill of glacial acetic acid. Am Rev Respir Dis. 1991;144(5):1058-64. [pmid: 1952431].
50 Keskinen H, Tupasela O, Tiikkainen U, et al. Experiences of specific IgE in asthma due to diisocyanates. Clin Allergy. 1988;18(6):597-604. [pmid: 2854010].
51 Kim H, Kim YD, Choi J. Serioimmunological characteristics of Korean workers exposed to toluene diisocyanate. Environ Res. 1997;75(1):1-6. [pmid: 9356188].
52 Kim YK, Son JW, Kim HY, et al. New occupational allergen in citrus farmers: citrus red mite (Panonychus citri). Ann Allergy Asthma Immunol. 1999;82(2):223-8. [pmid: 10071529].
53 Kongerud J, Soyseth V, Burge PS. Serial measurements of peak expiratory flow and responsiveness to methacholine in the diagnosis of aluminum potroom asthma. Thorax. 1992;47:292-7. [pmid: 1585295]. [pmcid: 463699].
54 Kopferschmitt-Kubler MC, Frossard N, Rohde G, et al. Increase in non-specific bronchial hyperresponsiveness without specific response to isocyanate in isocyanate-induced asthma: a pilot study. Respir Med. 1998;92(9):1093-8. [pmid: 9926161].
55 Koskela H, Taivainen A, Tukiainen H, et al. Inhalation challenge with bovine dander allergens: who needs it?. Chest. 2003;124(1):383-91. [pmid: 12853550].
56 Krakowiak A, Ruta U, Gorski P, et al. Nasal lavage fluid examination and rhinomanometry in the diagnostics of occupational airway allergy to laboratory animals. Int J Occup Med Environ Health. 2003;16(2):125-32. [pmid: 12921381].
57 La Paglia G, Ruvolo M, Scancarello D, et al. [Usefulness of specific bronchial provocation tests in the diagnosis of compensable occupational allergic pneumopathies]. G Ital Med Lav. 1986;8(34):139-44. [pmid: 2968292].
58 Lam S, Wong R, Chan-Yeung M. Nonspecific bronchial reactivity in occupational asthma. J Allergy Clin Immunol. 1979;63:28-34. [pmid: 758339].
59 Larbanois A, Delwiche JP, Jamart J, et al. Comparison of FEV1 and specific airway conductance in assessing airway response to occupational agents. Allergy. 2003;58(12):1256-60. [pmid: 14616100].
60 Lemiere C, Chaboillez S, Malo JL, et al. Changes in sputum cell counts after exposure to occupational agents: what do they mean?. J Allergy Clin Immunol. 2001;107(6):1063-8. [pmid: 11398086].
61 Liss GM, Tarlo SM. Peak expiratory flow rates in possible occupational asthma.[see comment]. Chest. 1991;100(1):63-9. [pmid: 2060392].
62 Lozewicz S. Occupational asthma due to methylcrylate and cyanoacrylates. Thorax. 1985;40(11):836-9. [pmid: 4071461]. [pmcid: 1020561].
63 Malo JL, Cartier A. Occupational asthma in workers of a pharmaceutical company processing spiramycin. Thorax. 1988;43:371-7. [pmid: 3194865]. [pmcid: 461250].
64 Malo JL, Cote J, Cartier A, et al. How many times per day should peak expiratory flow rates be assessed when investigating occupational asthma. Thorax. 1993;48:1211-7. [pmid: 8303625]. [pmcid: 464971].
65 Malo JL, Ghezzo H, L'Archeveque J, et al. Late asthmatic reactions to occupational sensitizing agents: frequency of changes in nonspecific bronchial responsiveness and of response to inhaled beta-2 adrenergic agent. J Allergy Clin Immunol. 1990;85:834-42. [pmid: 2332563].
66 Malo JL, Ghezzo H, L'Archeveque J, et al. Is the clinical history a satisfactory means of diagnosing occupational asthma?. Am Rev Respir Dis. 1991;143:528-32. [pmid: 2001062].
67 Mapp CE, Dal Vecchio L, Boschetto P, et al. Toluene diisocyanate-induced asthma without airway hyperresponsiveness. Eur J Respir Dis. 1986;68(2):89-95. [pmid: 3009212].
68 Mapp CE, Moro G, Fabbri L, et al. [Toluene diisocyanate-induced asthma: specific and non-specific bronchial challenge tests (author's transl)]. Med Lav. 1979;70(3):203-14. [pmid: 224295].
69 Merget R, Dierkes A, Ruckmann A, et al. Absence of relationship between degree of nonspecific and specific bronchial responsiveness in occupational asthma due to platinum salts. [German]. Pneumol. 1996;51(4):345-50.
70 Merget R, Heger M, Globisch A, et al. Quantitative bronchial challenge tests with wheat flour dust administered by Spinhaler: Comparison with aqueous wheat flour extract inhalation. J Allergy Clin Immunol. 1997;100(2):199-207. [pmid: 9275141].
71 Merget R, Stollfuss J, Wiewrodt R, et al. Diagnostic tests in enzyme allergy. J Allergy Clin Immunol. 1993;92(2):264-77. [pmid: 8349937].
72 Mole R, Balletta A. [The significance of acetylcholine test in occupational allergic asthma (author's transl)]. Lav Um. 1977;29(6):188-95. [pmid: 611362].
73 Moller DR, Brooks SM, McKay RT, et al. Chronic asthma due to toluene diisocyanate. Chest. 1986;90(4):494-9. [pmid: 3019611].
74 Moller DR, Gallagher JS, Bernstein DI, et al. Detection of immunoglobulin E-mediated respiratory sensitization in workers exposed to hexahydrophthalic anhydride. J Allergy Clin Immunol. 1985;75(6):663-72. [pmid: 4008795].
75 Moscato G, Dellabianca A, Corsico A, et al. Bronchial responsiveness to ultrasonic fog in occupational asthma due to diisocyanate. Chest. 1993;104(4):1127-32. [pmid: 8404179].
76 Munoz X. Validation of specific inhalation challenge for the diagnosis of occupational asthma due to persulphate salts. Occup Environ Med. 2004;61(10):861-6. [pmid: 15377773]. [pmcid: 1740674].
77 Nielsen J, Welinder H, Schütz A, et al. Specific serum antibodies against phthalic anhydride in occupationally exposed subjects. J Allergy Clin Immunol. 1988;82:126-33. [pmid: 3392364].
78 Nordman H, Keskinen H, Tuppurainen M. Formaldehyde asthma. Rare or overlooked. J Allergy Clin Immunol. 1985;75(1 Pt 1):91-9. [pmid: 3968333].
79 O'Brien IM, Harries MG, Burge PS, et al. Toluene di-isocyanate-induced asthma. I. Reactions to TDI, MDI, HDI and histamine. Clin Allergy. 1979;9:1-6. [pmid: 217556].
80 O'Brien IM, Newman-Taylor AJ, Burge PS, et al. Toluene di-isocyanate-induced asthma. II. Inhalation challenge tests and bronchial reactivity studies. Clin Allergy. 1979;9(1):7-15. [pmid: 217557].
81 Obata H, Dittrick M, Chan H, et al. Sputum eosinophils and exhaled nitric oxide during late asthmatic reactions in patients with western red cedar asthma. Eur Respir J. 1999;13(3):489-95. [pmid: 10232414].
82 Obtulowicz K, Laczkowska T, Kolarzyk E, et al. Obstruction of the small airways in the spirometric diagnosis of occupational bronchial asthma. J Investig Allergol Clinl Immunol. 1998;8(5):300-3.
83 Paggiaro PL, Cantalupi R, Filieri M, et al. Bronchial asthma due to inhaled wood dust (Tanganyika aningre). Clin Allergy. 1981;11(6):605-10. [pmid: 7333004].
84 Paggiaro PL, Chan-Yeung M. Pattern of specific airway response in asthma due to western red cedar (Thuja plicata): relationship with length of exposure and lung function measurements. Clin Allergy. 1987;17:333-9. [pmid: 3304709].
85 Paggiaro PL, Innocenti A, Bacci E, et al. Specific bronchial reactivity to toluene diisocyanate: relationship with baseline clinical findings. Thorax. 1986;41:279-82. [pmid: 3016938]. [pmcid: 460310].
86 Paggiaro PL, Loi AM, Campinoti G et al. Ipereccitabilita bronchiale specifica e aspecifica nell'asma bronchiale da isocianati. 1984.
87 Paggiaro PL, Pardi F, Amram D, et al. [Validity of a specific bronchial provocation test with proteolytic enzymes in occupational bronchial asthma caused by enzymatic detergents]. G Ital Med Lav. 1984;6(56):201-4. [pmid: 6545209].
88 Palczynski C, Walusiak J, Krakowiak A, et al. Nasal lavage fluid examination in diagnostics of occupational allergy to chloramine. Int J Occup Med Environ Health. 2003;16(3):231-40. [pmid: 14587536].
89 Park HS, Kim HY, Nahm DH, et al. Specific IgG, but not specific IgE, antibodies to toluene diisocyanate-human serum albumin conjugate are associated with toluene diisocyanate bronchoprovocation test results. J Allergy Clin Immunol. 1999;104(4 Pt 1):847-51. [pmid: 10518831].
90 Park HS, Kim HY, Suh YJ, et al. Alpha amylase is a major allergenic component in occupational asthma patients caused by porcine pancreatic extract. J Asthma. 2002;39(6):511-6. [pmid: 12375710].
91 Park HS, Kim YJ, Lee MK, et al. Occupational asthma and IgE antibodies to reactive dyes. Yonsei Med J. 1989;30(3):298-304. [pmid: 2588667].
92 Park HS, Lee MK, Kim BO, et al. Clinical and immunologic evaluations of reactive dye-exposed workers. J Allergy Clin Immunol. 1991;87(3):639-49. [pmid: 2005316].
93 Park HS, Nahm DH, Suh CH, et al. Occupational asthma and IgE sensitization to grain dust. J Korean Med Sci. 1998;13(3):275-80. [pmid: 9681805].
94 Park HS, Yu HJ, Jung KS. Occupational asthma caused by chromium. Clin Exp Allergy. 1994;24(7):676-81. [pmid: 7953950].
95 Park JW, Kim CW, Kim KS, et al. Role of skin prick test and serological measurement of specific IgE in the diagnosis of occupational asthma resulting from exposure to vinyl sulphoreactive dyes. Occup Environ Med. 2001;58:417. [pmid: 11351059]. [pmcid: 1740141].
96 Perrin B, Malo JL, L'Archeveque J et al. Comparison of peak expiratory flow rates and bronchial responsiveness with specific inhalation challenges in occupational asthma (abstract). Am Rev Respir Dis 1990; 141.
97 Pezzini A, Riviera A, Paggiaro PL, et al. Specific IgE antibodies in twenty-eight workers with diisocyanate-induced bronchial asthma. Clin Allergy. 1984;14(5):453-61. [pmid: 6091945].
98 Prichard MG, Ryan G, Musk AW. Wheat flour sensitisation and airways disease in urban bakers. Br J Ind Med. 1984;41(4):450-4. [pmid: 6498109]. [pmcid: 1009368].
99 Quirce S, Cuevas M, Diez-Gomez ML, et al. Respiratory allergy to Aspergillus-derived enzymes in bakers' asthma. J Allergy Clin Immunol. 1992;90(6 I):970-8. [pmid: 1281180].
100 Quirce S, Hinojosa M, Maranon F, et al. Identification of obeche wood (Triplochiton scleroxylon) allergens associated with occupational asthma. J Allergy Clin Immunol. 2000;106(2):400-1. [pmid: 10932087].
101 Rasanen L, Kuusisto P, Penttila M, et al. Comparison of immunologic tests in the diagnosis of occupational asthma and rhinitis. Allergy. 1994;49(5):342-7. [pmid: 8092431].
102 Redlich CA, Homer RJ, Smith BR, et al. Immunologic responses to isocyanates in sensitized asthmatic subjects. Clin Exp Immunol. 1996;109(3 Suppl):6S-8S.
103 Ricciardi L, Fedele R, Saitta S, et al. Occupational asthma due to exposure to iroko wood dust. Ann Allergy Asthma Immunol. 2003;91(4):393-7. [pmid: 14582819].
104 Sander I, Degens P, Goldscheid N, et al. Divergente Prickhauttestergebnisse mit verschiedenen Weizen- und Roggenmehlextrakten [German]. Atemw-Lungenkrkh. 2001;27:333-4.
105 Sastre J, Fernandez-Nieto M, Novalbos A, et al. Need for monitoring nonspecific bronchial hyperresponsiveness before and after isocyanate inhalation challenge.[see comment]. Chest. 2003;123(4):1276-9. [pmid: 12684321].
106 Schuermans D, Verbanck S, Vincken W. Role of histamine bronchial hyperresponsiveness (BHR) in the diagnosis of occupational asthma (OA) to latex. Eur Respir Soc 2003.
107 Schwaiblmair M, Vogelmeier C, Fruhmann G. Occupational asthma in hairdressers: results of inhalation tests with bleaching powder. Int Arch Occup Environ Health. 1997;70(6):419-23. [pmid: 9439990].
108 Schwarting HH. [Diagnostic significance of the radioallergosorbent test (RAST) in occupational, flour-related asthma. A comparison with previously used methods in allergy diagnosis]. Z Hautkr. 1979;54(7):306-8. [pmid: 442743].
109 Shirai T, Reshad K, Yoshitomi A, et al. Green tea-induced asthma: relationship between immunological reactivity, specific and non-specific bronchial responsiveness. Clin Exp Allergy. 2003;33(9):1252-5. [pmid: 12956747].
110 Shirakawa T, Kusaka Y, Fujimura N, et al. The existence of specific antibodies to cobalt in hard metal asthma. Clin Allergy. 1988;18:451-60. [pmid: 3233723].
111 Slovak AJ. Occupational asthma caused by a plastics blowing agent AZO dicarbonamide. Thorax. 1981;36(12):906-9. [pmid: 7336369]. [pmcid: 471857].
112 Symington IS, Kerr JW, McLean DA. Type I allergy in mushroom soup processors. Clin Allergy. 1981;11:43-7. [pmid: 7194162].
113 Tabar AI, Alvarez-Puebla MJ, Gomez B, et al. Diversity of asparagus allergy: clinical and immunological features. Clin Exp Allergy. 2004;34(1):131-6. [pmid: 14720273].
114 Taivainen A, Iivonen E, Kokkarinen J, et al. [The diagnosis of asthma caused by cow hair epithelium]. Duodecim. 1994;110(21):1999-2003. [pmid: 8654225].
115 Tee RD, Cullinan P, Welch J, et al. Specific IgE to isocyanates: A useful diagnostic role in occupational asthma. J Allergy Clin Immunol. 1998;101(5):709-15. [pmid: 9600510].
116 Tse KS, Chan H, Chan-Yeung M. Specific IgE antibodies in workers with occupational asthma due to western red cedar. Clin Allergy. 1982;3:249-58. [pmid: 6179654].
117 Vandenplas O. Prevalence of occupational asthma due to latex among hospital personnel. Am J Respir Crit Care Med. 1995;151(1):54-60. [pmid: 7812572].
118 Vandenplas O, Van Cangh FB, Brumagne A, et al. Occupational asthma in symptomatic workers exposed to natural rubber latex: evaluation of diagnostic procedures. J Allergy Clin Immunol. 2001;107(3):542-7. [pmid: 11240958].
119 Vanhanen M, Tuomi T, Tupasela O, et al. Cellulase allergy and challenge tests with cellulase using immunologic assessment. Scand J Work Environ Health. 2000;26(3):250-6. [pmid: 10901118].
120 Virtanen T, Zeiler T, Rautiainen J, et al. Immune reactivity of cow-asthmatic dairy farmers to the major allergen of cow (BDA20) and to other cow-derived proteins. The use of purified BDA20 increases the performance of diagnostic tests in respiratory cow allergy. Clin Exp Allergy. 1996;26(2):188-96. [pmid: 8835127].
121 Vogelmeier C, Baur X, Fruhmann G. Isocyanate-induced asthma: results of inhalation tests with TDI, MDI and methacholine. Int Arch Occup Environ Health. 1991;63(1):9-13. [pmid: 1649802].
122 Wurzinger G, Gillich E, Kroneis C. Bakers/millers-asthma - Different behaviour in inhalative provocation [German]. Atemw-Lungenkrkh 23[Suppl 1], S30–7. 1997.
123 Zeiler T, Taivainen A, Mantyjarvi R, et al. Threshold levels of purified natural Bos d 2 for inducing bronchial airway response in asthmatic patients. Clin Exp Allergy. 2002;32(10):1454-60. [pmid: 12372125].
124 Zeiss CR, Patterson R, Pruzansky JJ, et al. Trimellitic anhydride-induced airway syndromes: clinical and immunologic studies. J Allergy Clin Immunol. 1977;60(2):96-103. [pmid: 68964].

### Cohorts

1 Allard C, Cartier A, Ghezzo H, et al. Occupational asthma due to various agents: absence of clinical and functional improvement at an interval of four or more years after cessation of exposure. Chest. 1989;96(5):1046-9. [pmid: 2805834].
2 Ameille J, Pairon JC, Bayeux MC, et al. Consequences of occupational asthma on employment and financial status: a follow-up study. Eur Respir J. 1997;10(1):55-8. [pmid: 9032492].
3 Banks DE, Rando RJ, Barkman HW Jr. Persistence of toluene diisocyanate-induced asthma despite negligible workplace exposures. Chest. 1990;97(1):121-5. [pmid: 2153064].
4 Barker RD, Harris JM, Welch JA, et al. Occupational asthma caused by tetrachlorophthalic anhydride: a 12-year follow-up. J Allergy Clin Immunol. 1998;101(6 Pt 1):717-9. [pmid: 9648696].
5 Bernstein DI, Karnani R, Biagini RE, et al. Clinical and occupational outcomes in health care workers with natural rubber latex allergy. Ann Allergy Asthma Immunol. 2003;90(2):209-13. [pmid: 12602668].
6 Burge PS. Occupational asthma in electronic workers caused by colophony fumes: follow-up of affected workers. Thorax. 1982;37:348-53. [pmid: 7112471]. [pmcid: 459315].
7 Gannon PF, Weir DC, Robertson AS, et al. Health, employment, and financial outcomes in workers with occupational asthma. Br J Ind Med. 1993;50(6):491-6. [pmid: 8329312]. [pmcid: 1035473].
8 Gassert TH, Hu H, Kelsey KT, et al. Long-term health and employment outcomes of occupational asthma and their determinants. J Occup Environ Med. 1998;40(5):481-91. [pmid: 9604186].
9 Gorski P, Kolacinska B, Wittczak T. Analysis of the clinical state of patients with occupational asthma following cessation of exposure to allergens. Occup Med. 1999;49(5):285-9.
10 Grammer L C,, Shaughnessy MA. Study of employees with anhydride-induced respiratory disease after removal from exposure. J Occup Environ Med. 1996;38(8):771-4. [pmid: 8863202].
11 Grammer LC, Shaughnessy MA, Kenamore BD. Clinical and immunologic outcome of 42 individuals with trimellitic anhydride-induced immunologic lung disease after transfer to low exposure. Allergy Asthma Proc. 2000;21(6):355-9. [pmid: 11191101].
12 Harries MG, Burge PS, Samson M, et al. Isocyanate asthma-respiratory symptoms due to 1,5-naphthylene diisocyanate. Thorax. 1979;34(6):762-6. [pmid: 542916]. [pmcid: 471193].
13 Jyo T, Kodomari Y, Kodomari N, et al. Therapeutic effect and titers of the specific IgE and IgG antibodies in patients with sea squirt allergy Hoya asthma under a long-term hyposensitization with three sea squirt antigens. J Allergy Clin Immunol. 1989;83(2 Pt 1):386-93. [pmid: 2918184].
14 Laoprasert N, Swanson MC, Jones RT, et al. Inhalation challenge testing of latex-sensitive health care workers and the effectiveness of laminar flow HEPA-filtered helmets in reducing rhinoconjunctival and asthmatic reactions. J Allergy Clin Immunol. 1998;102(6 Pt 1):998-1004. [pmid: 9847441].
15 Lemiere C, Cartier A, Dolovich J, et al. Outcome of specific bronchial responsiveness to occupational agents after removal from exposure. Am J Respir Crit Care Med. 1996;154(2 Pt 1):329-33. [pmid: 8756802].
16 Lemiere C, Cartier A, Malo JL, et al. Persistent specific bronchial reactivity to occupational agents in workers with normal nonspecific bronchial reactivity. Am J Resp Crit Care Med. 2000;162(3 Pt 1):976-80. [pmid: 10988116].
17 Lin FJ, Dimichward H, Chan-Yeung M. Longitudinal decline in lung function in patients with occupational asthma due to western red cedar. Occup Environ Med. 1996;53(11):753-6. [pmid: 9038799]. [pmcid: 1128593].
18 Lozewicz S, Assoufi BK, Hawkins R, et al. Outcome of asthma induced by isocyanates. Br J Dis Chest. 1987;81(1):14-22. [pmid: 3663485].
19 Maghni K, Lemiere C, Ghezzo H, et al. Airway inflammation after cessation of exposure to agents causing occupational asthma. Am J Respir Crit Care Med. 2004;169(3):367-72. [pmid: 14578217].
20 Malo J L,, Ghezzo H. Recovery of methacholine responsiveness after end of exposure in occupational asthma. Am J Respir Crit Care Med. 2004;169(12):1304-7. [pmid: 15070824].
21 Malo JL, Boulet LP, Dewitte JD, et al. Quality of life of subjects with occupational asthma. J Allergy Clin Immunol. 1993;91(6):1121-7. [pmid: 8509574].
22 Malo JL, Cartier A, Boulet LP, et al. Bronchial hyperresponsiveness can improve while spirometry plateaus two to three years after repeated exposure to chlorine causing respiratory symptoms. Am J Respir Crit Care Med. 1994;150(4):1142-5. [pmid: 7921449].
23 Malo JL, Cartier A, Ghezzo H, et al. Patterns of improvement in spirometry, bronchial hyperresponsiveness, and specific IgE antibody levels after cessation of exposure in occupational asthma caused by snow-crab processing. Am Rev Respir Dis. 1988;138(4):807-12. [pmid: 3202454].
24 Mapp CE, Corona PC, De Marzo N, et al. Persistent asthma due to isocyanates. A follow-up study of subjects with occupational asthma due to toluene diisocyanate (TDI). Am Rev Respir Dis. 1988;137(6):1326-9. [pmid: 2849330].
25 Marabini A, Siracusa A, Stopponi R, et al. Outcome of occupational asthma in patients with continuous exposure - a 3-year longitudinal study during pharmacologic treatment. Chest. 2003;124(6):2372-6. [pmid: 14665523].
26 Merget R, Schulte A, Gebler A, et al. Outcome of occupational asthma due to platinum salts after transferral to low-exposure areas. Int Arch Occup Environ Health. 1999;72(1):33-9. [pmid: 10029228].
27 Meyer WC. [Prognosis of occupational bronchial asthma after change of occupation and elimination of antigen (author's transl)]. MMW Munch Med Wochenschr. 1977;119(11):363-6. [pmid: 403419].
28 Moscato G, Dellabianca A, Perfetti L, et al. Occupational asthma: A longitudinal study on the clinical and socioeconomic outcome after diagnosis. Chest. 1999;115(1):249-56. [pmid: 9925092].
29 Munoz X, Cruz MJ, Orriols R, et al. Occupational asthma due to persulfate salts: diagnosis and follow-up. Chest. 2003;123(6):2124-9. [pmid: 12796198].
30 O'Donnell TV, Welford B, Coleman ED. Potroom asthma: New Zealand experience and follow-up. Am J Ind Med. 1989;15(1):43-9. [pmid: 2929607].
31 Orriols R, Drobnic ME, Munoz X, et al. [Occupational asthma due to isocyanates: a study of 21 patients]. Med Clin (Barc). 1999;113(17):659-62. [pmid: 10618782].
32 Paggiaro PL, Bacci E, Paoletti P, et al. Bronchoalveolar lavage and morphology of the airways after cessation of exposure in asthmatic subjects sensitized to toluene diisocyanate. Chest. 1990;98(3):536-42. [pmid: 2168308].
33 Paggiaro PL, Loi AM, Rossi O, et al. Follow-up study of patients with respiratory disease due to toluene diisocyanate. Clin Allergy. 1984;14(5):463-9. [pmid: 6091946].
34 Paggiaro PL, Vagaggini B, Dente FL, et al. Bronchial hyperresponsiveness and toluene diisocyanate. Long-term change in sensitized asthmatic subjects. Chest. 1993;103(4):1123-8. [pmid: 8131451].
35 Park HS, Lee SK, Kim HY, et al. Specific immunoglobulin E and immunoglobulin G antibodies to toluene diisocyanate-human serum albumin conjugate: Useful markers for predicting long-term prognosis in toluene diisocyanate-induced asthma. Clin Exp Allergy. 2002;32(4):551-5. [pmid: 11972601].
36 Park HS, Yu HJ, Jung KS. Occupational asthma caused by chromium. Clin Exp Allergy. 1994;24(7):676-81. [pmid: 7953950].
37 Perfetti L, Cartier A, Ghezzo H, et al. Follow-up of occupational asthma after removal from or diminution of exposure to the responsible agent: relevance of the length of the interval from cessation of exposure. Chest. 1998;114(2):398-403. [pmid: 9726721].
38 Piirila PL, Nordman H, Korhonen OS, et al. A thirteen-year follow-up of respiratory effects of acute exposure to sulfur dioxide. Scand J Work Environ Health. 1996;22(3):191-6. [pmid: 8837264].
39 Pisati G, Baruffini A, Zedda S. Toluene diisocyanate induced asthma: Outcome according to persistence or cessation of exposure. Br J Ind Med. 1993;50(1):60-4. [pmid: 8381658]. [pmcid: 1061235].
40 Pisati G, Zedda S. Outcome of occupational asthma due to cobalt hypersensitivity. Sci Total Environ. 1994;150(13):167-71. [pmid: 7939592].
41 Rosenberg N, Garnier R, Rousselin X, et al. Clinical and socio-professional fate of isocyanate-induced asthma. Clin Allergy. 1987;17(1):55-61. [pmid: 3829371].
42 Ross DJ, Mcdonald JC. Health and employment after a diagnosis of occupational asthma: a descriptive study. Occup Med (Oxf). 1998;48(4):219-25. [pmid: 9800419].
43 Saetta M, Maestrelli P, Turato G, et al. Airway wall remodeling after cessation of exposure to isocyanates in sensitized asthmatic subjects. Am J Respir Crit Care Med. 1995;151(2 Pt 1):489-94. [pmid: 7842211].
44 Sen D, Wiley K, Williams JG. Occupational asthma in fruit salad processing. Clin Exp Allergy. 1998;28(3):363-7. [pmid: 9543087].
45 Simonsson BG, Sjoberg A, Rolf C, et al. Acute and long-term airway hyperreactivity in aluminum-salt exposed workers with nocturnal asthma. Eur J Respir Dis. 1985;66(2):105-18. [pmid: 3882443].
46 Slovak AJ, Orr RG, Teasdale EL. Efficacy of the helmet respirator in occupational asthma due to laboratory animal allergy. Am Ind Hygiene Assoc J. 1985;46(8):411-5.
47 Smith TA, Patton J. Health surveillance in milling, baking and other food manufacturing operations - five years' experience. Occup Med (Oxf). 1999;49(3):147-53. [pmid: 10451595].
48 Sulotto F, Romano C, Piolatto G, et al. [Effects of long-term use of inhaled steroids (beclomethasone dipropionate) in patients with occupational asthma no longer exposed]. Med Lav. 1989;80(6):498-505. [pmid: 2630896].
49 Taivainen A, Tukiainen O, Terho O, et al. Powered dust respirator helmets in the prevention of occupational asthma among farmers. Scand J Work Environ Health. 1998;24(6):503-7. [pmid: 9988093].
50 Vandenplas O, Jamart J, Delwiche JP, et al. Occupational asthma caused by natural rubber latex: outcome according to cessation or reduction of exposure. J Allergy Clin Immunol. 2002;109(1):125-30. [pmid: 11799378].
51 Venables KM, Dally MB, Burge PS, et al. Occupational asthma in a steel coating plant. Br J Ind Med. 1985;42(8):517-24. [pmid: 2990525]. [pmcid: 1007521].
52 Venables KM, Topping MD, Nunn AJ, et al. Immunologic and functional consequences of chemical (tetrachlorophthalic anhydride)-induced asthma after four years of avoidance of exposure. J Allergy Clin Immunol. 1987;80(2):212-8. [pmid: 3611542].

### Trials

1 Armentia A, Martin-Santos JM, Quintero A, et al. Baker's asthma: prevalence and evaluation of immunotherapy with wheat flour extract. Ann Allergy. 1990;65(4):265-72. [pmid: 2221484].
2 Crescioli S, De Marzo N, Boschetto P, et al. Theophylline inhibits late asthmatic reactions induced by toluene diisocyanate in sensitized subjects. Eur J Pharmacol - Environ Toxicol Pharmacol Sect. 1992;1(1):45-50.
3 De Marzo N, Fabbri LM, Crescioli S, et al. Dose-dependent inhibitory effect of inhaled beclomethasone on late asthmatic reactions and increased responsiveness to methacholine induced by toluene diisocyanate in sensitised subjects. Pulm Pharmacol. 1988;1(1):15-20. [pmid: 2856542].
4 Fabbri LM, Di Giacomo GR, Dal Vecchio L, et al. Prednisone, indomethacin and airway responsiveness in toluene diisocyanate sensitized subjects. Bull Eur Physiopathol Respir. 1985;21:421-6. [pmid: 2998519].
5 Maestrelli P, De Marzo N, Saetta M, et al. Effects of inhaled beclomethasone on airway responsiveness in occupational asthma. Placebo-controlled study of subjects sensitized to toluene diisocyanate. Am Rev Respir Dis. 1993;148(2):407-12. [pmid: 8393638].
6 Malo JL, Cartier A, Cote J, et al. Influence of inhaled steroids on recovery from occupational asthma after cessation of exposure: an 18-month double-blind crossover study. Am J Respir Crit Care Med. 1996;153(3):953-60. [pmid: 8630579].
7 Malo JL, Perrin B, L'Archeveque J, et al. Effect on an inhaled beta-2 adrenergic agent on late asthamtic reactions due to occupational agents. Rev Mal Resp. 1994;11:479-84.
8 Mapp CE, Boschetto P, Dal Vecchio L, et al. Protective effect of antiasthma drugs on late asthmatic reactions and increased airway responsiveness induced by toluene diisocyanate in sensitized subjects. Am Rev Respir Dis. 1987;136(6):1403-7. [pmid: 2825567].
9 Moscato G, Gherson G, Biscaldi G, et al. Protective effect of nifedipine upon specific bronchial responses to isocyanates. G Ital Med Lav. 1985;5(6):247-50. [pmid: 6100488].
10 Mueller-Wening D, Neuhauss M. Protective effect of respiratory devices in farmers with occupational asthma. Eur Respir J. 1998;12(3):569-72. [pmid: 9762781].
11 Paggiaro PL, Bacci E, Talini D, et al. Atropin does not inhibit late asthmatic responses induced by Toluene diisocyanate in sensitized subjects. Am Rev Respir Dis. 1987;136(5):1237-41. [pmid: 2823652].
12 Vandenplas O, Delwiche JP, Depelchin S, et al. Latex gloves with a lower protein content reduce bronchial reactions in subjects with occupational asthma caused by latex. Am J Respir Crit Care Med. 1995;151(3 Pt 1):887-91. [pmid: 7881687].
13 Woitowitz HJ, Woitowitz RH. Clinical experiences with a new sympathicomimetic substance in the provoked attack in occupational asthma. Respir. 1972;29(5):549-55.