# Appendix D: Multiple Publications

Occupational Asthma Cohorts

Table D-1: Diagnosis cohorts

Table D-2: Management cohorts

Table D-3: Trial cohort

During the study screening and data extraction processes, several articles were identified where different outcomes were reported for what appeared to be the same clinical cohort. We did not want to exclude any relevant results, but also did not want to over-represent results when the same outcome had been reported for a cohort in different publications. A main (usually most recent) publication for these cohorts was identified based on a careful review of the paper for references to prior publications, contact with the authors when possible, and cross-referencing descriptions of patient demographics. These references are described below for the diagnosis and management systematic reviews respectively.

Table D-1 Diagnosis cohorts

Linked References (* indicates the primary publication) | Rational
Cartier, 1986* ^1^ ; Cartier, 1984 ^2^ | Cartier et al. (1986) describe results from IgE testing of snow crab processors diagnosed with OA. The authors refer to Cartier et al. (1984) in the description of subjects included in the present analysis.
Cote, 1993* ^3^ ; Cote, 1990 ^4^ | Cote et al. (1992) investigated the utility of serial PEFR in 25 subjects investigated for OA caused by red cedar. In 1990, the same authors report results on 23 subjects; study design, subject, and methods sections are very similar to the later publication. We assumed the 1992 paper extends the results of the 1990 publication.
Howe, 1983* ^5^ ; Venables, 1990 ^6^ | Howe et al. (1983) report results from seven patients investigated for OA caused by TCPA. Venables et al. (2003) refer to Howe et al. (1983) stating that it “presented only the tests with highest TCPA concentrations”; this paper presented results using “data from all the tests”.
Liss, 1991* ^7^ ; Tarlo, 1991 ^8^ | Liss and Tarlo (1991) report on an investigation of serial PEFR measurements in a cohort of 50 subjects referred to a clinic in Toronto, Canada. The authors refer to Tarlo and Broder (1991) in their methods section with respect to how patients were identified and diagnosed.
Malo, 1991* ^9^ ; Perrin, 1992 ^10^ | Malo et al. (1991) describe diagnostic findings from a cohort of 162 patients with OA caused by various agents. Perrin et al. (1992) appear to report on a subset of 61 patients with serial PEFR measurements.
Moscato, 1993* ^11^ ; Moscato, 1991 ^12^ | Moscato et al. (1993) report results from an assessment of two NSBPT substances for diagnosing OA caused by TDI. The authors refer to Moscato et al. (1991) in their description of the methacholine NSBPT. Moscato et al. (1993) appears to report on a subset of patients, originally identified in the 1991 paper, who underwent both tests.
Paggiaro, 1987* ^13^ ; Lam, 1983 ^14^ | Paggiaro and Chan-Yeung (1987) report on a cohort of 332 subjects investigated for OA caused by exposure to red cedar noting that it includes “206 previously reported subjects”. Lam et al. (1983) is the publication for those 206 subjects.

Abbreviations: NSBPT = non-specific bronchial provocation test

OA = occupational asthma

PEFR = peak expiratory flow rate

TCPA = tetrachlorophthalic anhydride

TDI = toluene di-isocyanates

Table D-2 Management cohorts

Linked References (* indicates the primary publication) | Rational
Grammer, 2000* ^15^ ; Grammer, 1993 ^16^ | Grammer et al. (2000) describe a cohort of 29 OA patients; 22 who had been transferred to low exposure and seven who had been completely removed. The authors state that the purpose of the study was to “extend our previous observations”, referring to their 1993 paper.
Lin, 1996* ^17^ ; Chan-Yeung, 1987 ^18^ ; Chan-Yeung, 1982 ^19^ ; Chan-Yeung, 1977 ^20^ ; Lam, 1987 ^21^ ; Chan-Yeung, 1988 ^22^ ; Cote, 1990b ^23^ ; Marabini, 1993 ^24^ ; Chan-Yeung, 1999 ^25^ | Lin et al. (1996) describes the largest cohort of subjects followed at a clinic in Vancouver, Canada after diagnosis with OA caused by exposure to western red cedar. Outcomes are assessed based on each patient's symptoms and exposure status at follow-up. Chan-Yeung et al. (1987), Chan-Yeung et al. (1982) and Chan-Yeung et al. (1977) are previous reports of smaller cohorts of similarly described subjects. Lam et al. (1987) describes a subset of patients who underwent bronchial lavage before and at various intervals after SIC. Chan-Yeung et al. (1988) considered similar outcomes in a group of subjects who had been removed from exposure for at least 1 year. Cote at al. (1990) report clinical outcomes of a subset of patients who continued exposure and categorized them as stable or deteriorated. Socioeconomic and clinical outcomes were reported by Marabini et al. in 1993. Chan-Yeung et al. (1999) describes airway inflammation and exhaled nitric oxide in a subset of patients followed for at least one year; patients were classified according to exposure and medication status.
Malo, 1988* ^26^ ; Hudson, 1985 ^27^ | Malo et al. (1988) describe a cohort of 31 subjects with OA from working in a snow crab processing facility and report results from three follow-up visits at approximately 1, 2.5, and 5 years. Hudson et al. (1985) report on two cohorts, one of which is a group of 31 workers with OA caused by snow crab with 12 months of follow-up. Results from this paper were similar to the first follow-up visit in Malo et al. (1988).
Malo 1993* ^28^ Dewitte 1994 ^29^ | Malo et al. (1993) included 134 Quebec workers diagnosed with OA who are removed from exposure and receiving compensation. Outcomes included quality of life and pulmonary function, bronchial responsiveness, and asthma severity. Dewitte et al. (1994) describes 134 workers with OA that were diagnosed at the same clinic during the same time period; economic consequences of OA are evaluated. Also, the baseline characteristics of the patients in the two studies are similar.
Merget, 1999* ^30^ ; Merget, 1994 ^31^ | Merget et al. (1999) reports results from a cohort of 74 patients with OA due to platinum salts who are grouped by exposure status at follow-up. This publication refers to Merget et al. (1994) and states “the present study was designed to describe a larger cohort of workers”.
Park, 2002a* ^32^ ; Park, 1997 ^33^ | Park et al. (2002) report follow-up results from 41 patients with OA caused by TDI who had been removed from exposure who were categorized as not improved, improved, and in remission. In Park et al. (1997), 35 patients were categorized using the same definitions. Park et al. (2002) refers to Park et al. (1997), but does not state that the results are an extension of previous work.
Perfetti, 1998a* ^34^ ; Perfetti, 1998b ^35^ | Perfetti et al. (1998a) reports results of 99 patients with OA who had been removed from exposure and followed for various lengths of times; outcomes are assessed comparing those followed for less than 5 years and those followed for more than 5 years. Perfetti et al. (1998b) from the same clinical group, describes the same study design; however, outcomes are compared based on molecular weight of the suspected asthmagen.
Saetta, 1995* ^36^ ; Saetta, 1992 ^37^ | Saetta et al. (1995) describe a cohort of 10 subjects with OA caused by isocyanates. The authors state that this publication is an extension of their previous work (Saetta 1992).

Abbreviations: OA = occupational asthma

TDI = toluene di-isocyanates

Table D-3 Trial cohort

Linked References (* indicates the primary publication) | Rational
Armentia, 1990* ^38^ ; Armentia, 1992 ^39^ | Armentia et al. have two publications describing an immunothearpy trial of 30 asthmatic bakers. Armentia et al. (1990) describes skin prick tests, NSBPT, and serum specific IgE results before and after treatment. Armentia et al. (1992) evaluates immune complexes in these patients.

Abbreviations: NSBPT = non-specific bronchial provocation test

## References for Appendix D

1 Cartier A, Malo JL, Ghezzo H, et al. IgE sensitization in snow crab-processing workers. J Allergy Clin Immunol. 1986;78(2):344-48. [pmid: 3734286].
2 Cartier A, Malo JL, Forest F, et al. Occupational Asthma in Snow Crab-Processing Workers. J Allergy Clin Immunol. 1984;74(3):261-69. [pmid: 6470360].
3 Cote J, Kennedy S, Chan-Yeung M. Quantitative versus qualitative analysis of peak expiratory flow in occupational asthma. Thorax. 1993;48(1):48-50. [pmid: 8434353]. [pmcid: 464241].
4 Cote J, Kennedy S, Chan-Yeung M. Sensitivity and specificity of PC20 and peak expiratory flow rate in cedar asthma. J Allergy Clin Immunol. 1990;85(3):592-98. [pmid: 2179365].
5 Howe W, Venables KM, Topping MD, et al. Tetrachlorophthalic anhydride asthma: evidence for specific IgE antibody. J Allergy Clin Immunol. 1983;71(1 Pt 1):5-11. [pmid: 6822691].
6 Venables KM, Newman-Taylor AJ. Exposure-response relationships in asthma caused by tetrachlorophthalic anhydride. J Allergy Clin Immunol. 1990;85(1 Pt 1):55-8. [pmid: 2299106].
7 Liss GM, Tarlo SM. Peak expiratory flow rates in possible occupational asthma. Chest. 1991;100(1):63-9. [pmid: 2060392].
8 Tarlo SM, Broder I. Outcome of assessments for occupational asthma. Chest. 1991;100:329-35. [pmid: 1864102].
9 Malo JL, Ghezzo H, L'Archeveque J, et al. Is the clinical history a satisfactory means of diagnosing occupational asthma?. Am Rev Respir Dis. 1991;143:528-32. [pmid: 2001062].
10 Perrin B, Lagier F, L'Archeveque J, et al. Occupational asthma: validity of monitoring of peak expiratory flow rates and non-allergic bronchial responsiveness as compared to specific inhalation challenge. Eur Respir J. 1992;5:40-8. [pmid: 1577147].
11 Moscato G, Dellabianca A, Corsico A, et al. Bronchial responsiveness to ultrasonic fog in occupational asthma due to diisocyanate. Chest. 1993;104(4):1127-32. [pmid: 8404179].
12 Moscato G, Dellabianca A, Vinci G, et al. Toluene diisocyanate-induced asthma: clinical findings and bronchial responsiveness studies in 113 exposed subjects with work-related respiratory symptoms. J Occup Med. 1991;33(6):720-25. [pmid: 1650820].
13 Paggiaro P, Chan-Yeung M. Pattern of specific airway response in asthma due to western red cedar (Thuja plicata): relationship with length of exposure and lung function measurements. Clin Allergy. 1987;17:333-39. [pmid: 3304709].
14 Lam S, Tan F, Chan H, et al. Relationship between types of asthmatic reaction, nonspecific bronchial reactivity and specific IgE antibodies in patients with red cedar asthma. J Allergy Clin Immunol. 1983;72(2):134-39. [pmid: 6350407].
15 Grammer LC, Shaughnessy MA, Kenamore BD. Clinical and immunologic outcome of 42 individuals with trimellitic anhydride-induced immunologic lung disease after transfer to low exposure. Allergy Asthma Proc. 2000;21(6):355-35. [pmid: 11191101].
16 Grammer LC, Harris KE, Yarnold PR. A clinical and immunologic study of workers with trimellitic-anhydride-induced immunologic lung disease after transfer to low expsoure jobs. Am Rev Respir Dis. 1993;148:54-57. [pmid: 8317814].
17 Lin FJ, Dimichward H, Chan-Yeung M. Longitudinal decline in lung function in patients with occupational asthma due to western red cedar. Occup Environ Med. 1996;53(11):753-6. [pmid: 9038799]. [pmcid: 1128593].
18 Chan-Yeung M, MacLean L, Paggiaro P. Follow-up study of 232 patients with occupational asthma caused by western red cedar (thuja-plicata). J Allergy Clin Immunol. 1987;79(5):792-96. [pmid: 3571771].
19 Chan-Yeung M, Lam S, Koener S. Clinical features and natural history of occupational asthma due to western red cedar (Thuja plicata). Am J Med. 1982;72(3):411-15. [pmid: 7058838].
20 Chan-Yeung M. Fate of occupational asthma.A follow-up study of patients with occupational asthma due to western red cedar (Thuja-Plicata). Am Rev Respir Dis. 1977;116(6):1023-30. [pmid: 931178].
21 Lam S, LeRiche J, Phillips D, et al. Cellular and protein changes in bronchial lavage fluid after late asthmatic reaction in patients with red cedar asthma. J Allergy Clin Immunol. 1987;80(1):44-50. [pmid: 3598029].
22 Chan-Yeung M, LeRiche J, MacLean L, et al. Comparison of cellular and protein changes in bronchial lavage fluid of symptomatic and asymptomatic patients with red cedar asthma on follow-up examination. Clin Allergy. 1988;18(4):359-66. [pmid: 3046776].
23 Cote J, Kennedy S, Chan-Yeung M. Outcome of patients with cedar asthma with continuous exposure. Am Rev Respir Dis. 1990;141:373-76. [pmid: 1689129].
24 Marabini A, Dimich-Ward H, Kwan SY, et al. Clinical and socioeconomic features of subjects with red cedar asthma: a follow-up study. Chest. 1993;104:821-24. [pmid: 8365295].
25 Chan-Yeung M, Obata H, Dittrick M, et al. Airway inflammation, exhaled nitric oxide, and severity of asthma in patients with western red cedar asthma. Am J Respir Crit Care Med. 1999;159(5 Pt 1):1434-38. [pmid: 10228107].
26 Malo JL, Cartier A, Ghezzo H, et al. Patterns of improvement in spirometry, bronchial hyperresponsiveness, and specific IgE antibody levels after cessation of exposure in occupational asthma caused by snow-crab processing. Am Rev Respir Dis. 1988;138(4):807-12. [pmid: 3202454].
27 Hudson P, Cartier A, Pineau L, et al. Follow-up of occupational asthma caused by crab and various agents. J Allergy Clin Immunol. 1985;76(5):682-28. [pmid: 4056252].
28 Malo JL, Boulet LP, Dewitte JD, et al. Quality of life of subjects with occupational asthma. J Allergy Clin Immunol. 1993;91:1121-27. [pmid: 8509574].
29 Dewitte JD, Chan-Yeung M, Malo JL. Medicolegal and compensation aspects of occupational asthma. Eur Respir J. 1994;7:969-80. [pmid: 8050556].
30 Merget R, Schulte A, Gebler A, et al. Outcome of occupational asthma due to platinum salts after transferral to low-exposure areas. Intl Arch Occup Environ Health. 1999;72(1):33-9.
31 Merget R, Reineke M, Rueckmann A, et al. Nonspecific and specific bronchial responsiveness in occupational asthma caused by platinum salts after allergen avoidance. Am J Respir Crit Care Med. 1994;150(4):1146-49. [pmid: 7921450].
32 Park HS, Lee SK, Kim HY, et al. Specific immunoglobulin E and immunoglobulin G antibodies to toluene diisocyanate-human serum albumin conjugate: Useful markers for predicting long-term prognosis in toluene diisocyanate-induced asthma. Clin Exper Allergy. 2002;32(4):551-55. [pmid: 11972601].
33 Park HS, Nahm DH. Prognostic factors for toluene diisocyanate-induced occupational asthma after removal from exposure. Clin Exper Allergy. 1997;27(10):1145-50. [pmid: 9383254].
34 Perfetti L, Cartier A, Ghezzo H, et al. Follow-up of occupational asthma after removal from or diminution of exposure to the responsible agent: relevance of the length of the interval from cessation of exposure. Chest. 1998;114(2):389-403.
35 Perfetti L, Hebert J, Lapalme Y, et al. Changes in IgE-mediated allergy to ubiquitous inhalants after removal from or diminution of exposure to the agent causing occupational asthma. Clin Exp Allergy. 1998;28(1):66-73. [pmid: 9537782].
36 Saetta M, Maestrelli P, Turato G, et al. Airway wall remodeling after cessation of exposure to isocyanates in sensitized asthmatic subjects. Am J Respir Crit Care Med. 1995;151(2 Pt 1):489-94. [pmid: 7842211].
37 Saetta M, Maestrelli P, Di Stefano A, et al. Effect of cessation of exposure to toluene diisocyanate (TDI) on bronchial mucosa of subjects with TDI-induced asthma. Am Rev Respir Dis. 1992;145(1):169-74. [pmid: 1309964].
38 Armentia A, Arranz M, Martin JM, et al. Baker's asthma: prevelance and evaluation of immunotherapy with wheat flour extract. Ann Allergy. 1990;65(4):265-72. [pmid: 2221484].
39 Armentia A, Martin-Santos JM, Quintero A, et al. Evaluation of immune complexes after immunotherapy with wheat flour in bakers' asthma. Ann Allergy. 1992;69(5):441-44. [pmid: 1456487].