# Appendix C: Levels of Evidence

Levels of Evidence: Diagnosis of Occupational Asthma

Table C-1: Levels of evidence: Occupational asthma with latency of allergic or presumed immunological mechanism

Table C-2: Levels of evidence: Occupational asthma without latency

Table C-3: Levels of evidence: Work-aggravated asthma

Table C-1 Levels of evidence: Occupational asthma with latency of allergic or presumed immunological mechanism

Test | Level
Specific inhalation challenge test OR supervised workplace inhalation challenge | Level Ia
Lung function test* and methacholine challenge test^, and immunological testing** | Level Ib
Combination of lung function tests* and methacholine challenge test^ | Level II
Combination of methacholine challenge^ testing and immunological testing** | Level IIIa
Combination of lung function tests* and immunological testing** | Level IIIb
Combination of lung function testing* or serial methacholine challenge testing and cessation of symptoms following removal from the workplace | Level IV
^^Clinical diagnosis of occupational or work-related asthma by a physician specializing in Occupational Medicine or Pulmonary Medicine and exposure to an “asthmagen” | Level V

* Lung function tests include FEV_1_ and PEF and must be done serially at work and away from work

^ Methacholine testing must be done at and away from work

** Immunological testing refers to skin prick tests or specific IgE

^^ We propose that, regardless of the final hierarchy, that ‘physician diagnosis’ be the lowest acceptable reference standard for the purposes of comparisons made in this review. The physician's diagnosis may have been reached using a variety of historical information, examination and tests, and this will differ from study to study. It is recognized that a physician diagnosis in the absence of any objective testing would not usually be considered sufficient acceptable evidence in an individual clinical case of suspected occupational asthma.

Table C-2 Levels of Evidence: Occupational asthma without latency

Test | Level
Combination of: | Level I
No preceding symptoms
*Symptoms after single specific exposure incident
*Exposure to irritant gas/smoke/fume/vapour in high concentrations
*Symptom onset <24hours after exposure
*Symptoms persist >3months after onset
Symptoms similar to asthma with cough wheeze and dyspnoea predominant
*PFTs show airflow obstruction with significant bronchial response (180mL/12%)
*Non-specific airway responsiveness present
Other pulmonary disease excluded
One of above * criteria not documented or not present | Level II
Two of above * criteria not documented or not present | Level III
Three of above * criteria not documented or not present | Level IV
^Clinical diagnosis of occupational or work-related asthma by a physician specializing in Occupational Medicine or Pulmonary Medicine | Level V

^ We propose that, regardless of the final hierarchy, that ‘physician diagnosis’ be the lowest acceptable reference standard for the purposes of comparisons made in this review. The physician's diagnosis may have been reached using a variety of historical information, examination and tests, and this will differ from study to study. It is recognized that a physician diagnosis in the absence of any objective testing would not usually be considered sufficient acceptable evidence in an individual clinical case of suspected occupational asthma.

Table C-3 Levels of Evidence: Work-aggravated asthma

Test | Level
Previous history of asthma. Documented work related changes in lung function* with documented exposure to a relevant precipitating or ‘triggering’ agent, but not a recognised asthmagen, at work | Level Ia
Previous history of asthma. Documented work related changes in lung function* with documented exposure to a relevant precipitating or ‘triggering’ agent at work. Exposure also to an asthmagen(s) at work, but negative specific inhalation challenge to asthmagen(s) | Level Ib
Previous history of asthma. History of worsening symptoms related to periods at work with improvements when away from work, and exposure to a relevant precipitating or ‘triggering’ agent, but not a recognised asthmagen, at work | Level II
No previous or concurrent history of asthma. History of worsening symptoms related to periods at work with improvements when away from work, and exposure to a relevant precipitating or ‘triggering’ agent, but not a recognised asthmagen, at work | Level III
Clinical diagnosis of work aggravated asthma by a physician specializing in Occupational Medicine or Pulmonary Medicine** | Level IV

* Lung function tests include FEV_1_ and PEF

** We propose that, regardless of the final hierarchy, that ‘physician diagnosis’ be the lowest acceptable reference standard for the purposes of comparisons made in this review. The physician's diagnosis may have been reached using a variety of historical information, examination and tests, and this will differ from study to study. It is recognized that a physician diagnosis in the absence of any objective testing would not usually be considered sufficient acceptable evidence in an individual clinical case of suspected occupational asthma.