# Appendix B: Sample Data Forms

Inclusion/Exclusion Criteria

Form B-1: Inclusion form: Diagnosis of occupational asthma

Form B-2: Inclusion form: Management of occupational asthma

Quality Assessment

Form B-3: Assessment of methodology for diagnostic studies: Diagnosis of occupational asthma

Form B-4: Assessment of methodology for non-randomized controlled trials: Management of occupational asthma

Form B-5: Assessment of methodology for randomized controlled trials: Management of occupational asthma

Data Extraction

Form B-6: Data extraction form: Diagnosis of occupational asthma

Form B-7: Data extraction form: Management of occupational asthma

Form B-1. Inclusion form: Diagnosis of occupational asthma

Reviewer: _______________ Date: _______________ Reference Number: _________

TOPIC, include if either:

[ ] Examining the diagnostic utility of one test in workers with a previous diagnosis of work-related or occupational asthma [previous diagnosis of asthma counts as one of the reference standards]

[ ] Comparing the diagnostic utility of two or more tests in workers with suspected occupational asthma

[ ] Examining the role of specific inhalation challenge testing in the diagnosis of occupational asthma

DESIGN, include if any of the following:

[ ] Randomized clinical trial

[ ] Controlled clinical trial

[ ] Prospective cohort

[ ] Retrospective cohort/case-series

[ ] Cross-sectional

PARTICPIANTS, include if:

Workers with either:

[ ] De novo occupationally induced asthma

[ ] A previous diagnosis of asthma that is exacerbated at work (i.e. work related asthma). ‘Exacerbated at work’ refers to underlying asthma that is made worse by a workplace exposure. This includes an episode of bronchoconstriction triggered by cold air or exercise.

REFERENCE STANDARD, include if there is at least one of the following:

[ ] Specific inhalation challenge testing

[ ] Supervised workplace challenge

[ ] Serial peak flow or serial spirometry monitoring (some type of serial lung function)

[ ] Serial measurement of non-specific airway reactivity, such as methacholine, histamine, or other challenges

[ ] Immunological testing

[ ] Clinical diagnosis of occupational asthma by an expert (occupational or pulmonary medicine specialist) and exposure to an “asthmagen”

OTHER COMPARISON TEST, include if there is at least one of the following:

[ ] Specific inhalation challenge testing

[ ] Supervised workplace challenge

[ ] Serial peak flow or serial spirometry monitoring (some type of serial lung function)

[ ] Serial measurement of non-specific airway reactivity, such as methacholine, histamine, or other challenges

[ ] Immunological testing

[ ] Clinical diagnosis of occupational asthma by an expert (occupational or pulmonary medicine specialist) and exposure to an “asthmagen”

[ ] Sputum, metabonomics, etc

[ ] Nitrous oxide

[ ] Other: ________________

OUTCOMES, include if there is at least one of the following:

[ ] Absolute numbers are presented to construct a 2 × 2 (comparing two diagnostic techniques) or 2 × 1 (assessing one diagnostic technique in patients with a previous diagnoses of occupational asthma) table

[ ] Sensitivity, specificity, or likelihood ratios

[ ] Cost of diagnosis

[ ] Time to complete diagnosis

[ ] Adverse effects

FINAL DECISION:

[ ] INCLUDE (meets all of the above inclusion criteria)

[ ] EXCLUDE

[ ] CAN't TELL

[ ] Further information is required

[ ] Not English (state language):

If disagreement between reviewers, final outcome:

[ ] INCLUDED [ ] EXCLUDED

Check box if study provides useful background information □

Form B-2. Inclusion form: Management of occupational asthma

Reviewer: _______________ Date: _______________ Reference Number: _________

TOPIC, include if either:

[ ] Examining the treatment or management in workers with a previous diagnosis of occupational asthma

DESIGN, include if any of the following:

[ ] Randomized clinical trial

[ ] Controlled clinical trial

[ ] Prospective cohort

[ ] Retrospective cohort/case-series

[ ] Cross-sectional

PARTICPIANTS, include if:

Currently employed workers or previously employed workers with either:

[ ] De novo occupationally induced asthma

[ ] A previous diagnosis of asthma that is exacerbated at work. This includes an episode of bronchoconstriction triggered by cold air or exercise.

[ ] Can't tell, but participants have occupational asthma

INTERVENTION, include if there is at least one of the following:

[ ] Removal from the offending workplace

[ ] Relocated to a position with decreased exposure to the “asthmagen” within the same workplace

[ ] Provided personal protective equipment (e.g. masks, respirators)

[ ] Engineering controls

[ ] Pharmacological treatment (e.g. bronchodilators, inhaled corticosteroids)

[ ] Other:

OUTCOMES, include if there is at least one of the following:

[ ] Pulmonary function

[ ] Use of medication

[ ] Healthcare utilization (e.g. admissions, ED visits, visits to primary care providers, referral to specialist)

[ ] Frequency of exacerbations

[ ] Quality of life

[ ] Symptoms

[ ] Economic consequences (to worker, employer, society)

[ ] Adverse events

FINAL DECISION:

[ ] INCLUDE (meets all of the above inclusion criteria)

[ ] EXCLUDE

[ ] CAN't TELL

[ ] Further information is required

[ ] Not English (state language):

If disagreement between reviewers, final outcome:

[ ] INCLUDED [ ] EXCLUDED

Check box if study provides useful background information □

Form B-3. Assessment of methodology for diagnostic studies: Diagnosis of occupational asthma

Reviewer: _______________ Date: _______________ Reference Number: _________

(Empirically validated items marked with an asterisk- Adapted from Lijmer et al.)

1 Design *
  a) Case control
  b) Cohort
  c) Other - specify________________
2 Blinding of measurements (test vs. reference standard) *
  a) Both measurements blinded
  b) One measurement blinded- specify (test vs. reference)_______________
  c) Other - specify________________
  d) Neither measurements blinded
  e) Unclear
3 Appropriate reference standard *
  a) Level of evidence reference standard:________________
  b) Other - specify________________
4 Description of reference standard *
  a) Adequate (e.g. referral to standard SIC methodology, timing of lung function tests, referral to standard challenge dosages and methodology, how an OA specialist made the diagnosis; there is enough information to reproduce the test)
  b) Inadequate
5 Description of test *
  Test I: _____________________
  a) Adequate (i.e. referral to standard methodology; there is enough information to reproduce the test)
  b) Inadequate
  Test II: _____________________
  a) Adequate (i.e. referral to standard methodology; there is enough information to reproduce the test)
  b) Inadequate
  Test III: _____________________
  a) Adequate (i.e. referral to standard methodology; there is enough information to reproduce the test)
  b) Inadequate
  Test IV: _____________________
  a) Adequate (i.e. referral to standard methodology; there is enough information to reproduce the test)
  b) Inadequate
  Test V: _____________________
  a) Adequate (i.e. referral to standard methodology; there is enough information to reproduce the test)
  b) Inadequate
6 Description of population *
  a) Adequate (i.e. patients described in terms of age, sex and presenting signs and symptoms)
  b) Inadequate
7 Differential reference bias * (i.e. those who test negatively or strongly positive are given a less or more thorough reference test for verification of the negative test; those who test negative or strongly positive are given a less thorough reference standard)
  a) Yes
  b) No
  c) Unclear
8 Partial verification bias (i.e. decision to perform the reference test is based upon the results of the test under examination; result of the test predicts patient moving on to the reference standard or vice versa)
  a) No - specify number ___________ (must be ≥90% for the risk of partial verification bias to be minimal)
  b) Yes
  c) Unclear
9 Data collection
  a) Retrospective
  b) Prospective (may be selected retrospectively but data is collected prospectively)
  c) Unclear
10 Patient selection
  a) Consecutive or random selection
  b) Other - specify __________________
  c) Not reported
11 Inter-rater reliability
  a) Reported
  b) Not reported
12 Reporting of results
  a) Allows for re-creation of contingency tables
  b) Does not allow for recreation of contingency tables

Form B-4. Assessment of methodology for non-randomized controlled trials: Management of occupational asthma

Reporting

1. Is the hypothesis/aim/objective of the study clearly described? This question refers to a clear statement of the objective, i.e. to measure the effectiveness of × in population y with respect to z, even if x, y and z are not clearly described (see questions 2, 3 and 4)

Yes | 1
No | 0

2. Are the main outcomes to be measured clearly described in the Introduction or Methods section? If the main outcomes are first mentioned in the Results section, the question should be answered no. In case-control studies the case definition should be considered the outcome.

Yes | 1
No | 0

3. Are the characteristics of the patients included in the study clearly described in the Introduction or Methods section? In cohort studies and trials, inclusion and or exclusion criteria should be given. In case-control studies, a case definition and the source for controls should be given.

Yes | 1
No | 0

4. Are the interventions of interest clearly described in the Introduction or Methods section? Treatments and placebo (where relevant) that are to be compared should be clearly described.

Yes | 1
No | 0

5. Are the distributions of principal confounders in each group of subjects to be compared clearly described? A list of principal confounders is provided.

Yes | 2
Partially | 1
No | 0

6. Are the main findings of the study clearly described? Simple outcome data (including denominators and numerators) should be reported for all major findings so that the reader can check the major analyses and conclusions. This question does not cover statistical tests, which are considered below.

Yes | 1
No | 0

7. Does the study provide estimates of the random variability in the data for the main outcomes? In non-normally distributed data the inter-quartile range of results should be reported. In normally distributed data the standard error, standard deviation or confidence intervals should be reported. If the distribution of the data is not described, it must be assumed that the estimates used were appropriate and the question should be answered yes.

Yes | 1
No | 0

8. Have all important adverse events that may be a consequence of the intervention been reported? This should be answered yes if the study demonstrates that there was a comprehensive attempt to measure adverse events. (A list of possible adverse events is provided).

Yes | 1
No | 0

9. Have the characteristics of patients lost to follow-up been described? This should be answered yes where there were no losses to follow-up or where losses to follow-up were so small that findings would be unaffected by their inclusion. This should be answered no where a study does no report the number of patients lost to follow-up.

Yes | 1
No | 0

10. Have 95% CIs and/or actual probability values been reported (e.g. 0.035 rather than <0.05) for the main outcomes except where the probability value is less than 0.001? (both CI and p value, either CI or p value, neither)

Yes | 1
No | 0

External validity

11. Were the subjects asked to participate in the study representative of the entire population from which they were recruited? The study must identify the source population for patients and describe how the patients were selected. Patients would be representative if they comprised the entire source population, an unselected sample of consecutive patients, or a random sample. Random sampling is only feasible where a list of all members of the relevant population exists. Where a study does not report the proportion of the source population from which the patients are derived, the question should be answered as unable to determine.

Yes | 1
No | 0
Unable to determine | 0

12. Were those subjects who were prepared to participate representative of the entire population from which they were recruited? The proportion of those asked who agreed should be stated. Validation that the sample was representative would include demonstrating that the distribution of the main confounding factors was the same in the study sample and the source population.

Yes | 1
No | 0
Unable to determine | 0

13. Were the staff, places, and facilities where the patients were treated, representative of the treatment the majority of patients receive? For the study to be answered yes the study should demonstrate that the intervention was representative of that in use in the source population. The question should be answered no if, for example, the intervention was undertaken in a specialist centre unrepresentative of the hospitals most of the source population would attend.

Yes | 1
No | 0
Unable to determine | 0

Internal validity - bias

14. Was an attempt made to blind study subjects to the intervention they have received? For studies where the patients would have no way of knowing which intervention they received, this should be answered yes.

Yes | 1
No | 0
Unable to determine | 0

15. Was an attempt made to blind those measuring the main outcomes of the intervention?

Yes | 1
No | 0
Unable to determine | 0

16. If any of the results of the study were based on “data dredging”, was this made clear? Any analyses that had not been planned at the outset of the study should be clearly indicated. If no retrospective unplanned subgroup analyses were reported, then answer yes.

Yes | 1
No | 0
Unable to determine | 0

17. In trials and cohort studies, do the analyses adjust for different lengths of follow-up of patients, or in case-control studies, is the time period between the intervention and outcome the same for cases and controls? Where follow-up was the same for all study patients that answer should be yes. If different lengths of follow-up were adjusted for by, for example, survival analysis the answer should be yes. Studies where differences in follow-up are ignored should be answered no.

Yes | 1
No | 0
Unable to determine | 0

18. Were the statistical tests used to assess the main outcomes appropriate? The statistical techniques used must be appropriate to the data. For example non-parametric methods should be used for small sample sizes. Where little statistical analysis has been undertaken but where there is no evidence of bias, the question should be answered yes. If the distribution of the data (normal or not) is not described it must be assumed that the estimates used were appropriate and the question should be answered yes.

Yes | 1
No | 0
Unable to determine | 0

19. Was compliance with the interventions reliable? Where there was non compliance with the allocated treatment or where there was contamination of one group, the question should be answered no. For studies where the effect of any misclassification was likely to bias any association to the null, the question should be answered yes.

Yes | 1
No | 0
Unable to determine | 0

20. Were the main outcome measures used accurate (valid and reliable)? For studies where the outcome measured are clearly described, the question should be answered yes. For studies which refer to other work or that demonstrates the outcome measures are accurate, the question should be answered as yes.

Yes | 1
No | 0
Unable to determine | 0

Internal validity - confounding (selection bias)

21. Were the patients in different intervention groups (trials and cohort studies) or were the cases and controls (case-control studies) recruited from the same population? For example, patients for all comparison groups should be selected from the same hospital. The question should be answered unable to determine for cohort and case-control studies where there is no information concerning the source of patients included in the study.

Yes | 1
No | 0
Unable to determine | 0

22. Were study subjects in different intervention groups (trials and cohort studies) or were the cases and controls (case-control studies) recruited over the same period of time? For a study which does not specify the time period over which patients were recruited, the question should be answered as unable to determine.

Yes | 1
No | 0
Unable to determine | 0

23. Were the subjects randomized to intervention groups? Studies which state that subjects were randomized should be answered yes except where method of randomization would not ensure random allocation. For example alternate allocation would score no because it is predictable.

Yes | 1
No | 0
Unable to determine | 0

24. Was the randomized intervention assignment concealed from both patients and health care staff until recruitment was complete and irrevocable? All non-randomized studies should be answered no. If assignment was concealed from patients but not from staff, it should be answered no.

Yes | 1
No | 0
Unable to determine | 0

25. Was there adequate adjustment for confounding in the analyses from which the main findings were drawn? This question should be answered no for trials if: the main conclusions of the study were based on analyses of treatment rather than intention to treat; the distribution of known confounders in the different treatment groups was not described; or the distribution of known confounders different between the treatment groups but was not taken into account in the analyses. In non-randomized studies if the effect of the main confounders was not investigated or confounding was demonstrated but no adjustment was made in the final analyses the question should be answered as no.

Yes | 1
No | 0
Unable to determine | 0

26. Were losses to patients to follow-up take into account? (yes, no, unable to determine) If the numbers of patients lost to follow-up are not reported, the question should be answered as unable to determine. If the proportion lost to follow-up was too small to affect the main findings, the question should be answered yes.

Yes | 1
No | 0
Unable to determine | 0

Power

27. Was a power calculation reported for the primary outcome?

Yes | 1
No | 0
Unable to determine | 0

28. Did the study have sufficient power to detect a clinically important effect where the probability value for a difference being due to chance in less than 5%?

Yes | 1
No | 0
Unable to determine | 0

Form B-5. Assessment of methodology for randomized controlled trials: Management of occupational asthma

JADAD SCORE: circle the appropriate response and total for the final Jadad score

Randomization:
1. Was the study described as being randomized? | 1 = Yes | 0 = No
2. Was the method of randomization appropriate? | 1 = Yes | 0 = No
3. Was the method of randomization inadequate? | -1 = Yes | 0 = No
Double Blindedness:
4. Was the study described as double-blind? | 1 = Yes | 0 = No
5. Was the method of double-blinding appropriate? | 1 = Yes | 0 = No
6. Was the method of double-blinding inadequate? | -1 = Yes | 0 = No
Withdrawals:
7. Was there an adequate description of withdrawals? | 1 = Yes | 0 = No
| | Total Score:

CONCEALMENT OF ALLOCATION: was the method used to conceal the randomization list

[ ] adequate

[ ] inadequate

[ ] unclear

Form B-6. Data extraction form: Diagnosis of occupational asthma

Patient Flow

1 Initial number selected/screened/eligible: n=___________________
2 Total agreed to participate: n= _______________________
3 Exclusions: □ Yes n=_____ □ No □ Unclear □ NR Reasons:
4 Withdrawals / dropouts / refusals: □ Yes n=_____ □ No □ Unclear □ NR Reasons:
5 Number who completed the study: n=___________
6 Was there a comparison group or control subgroup within cohort □ Yes n=____ □ No

Methods

Anti-asthma medications stopped pre-testing: □ Yes (attempted) □ No □ NR

Baseline Characteristics

Please indicate the statistic, (%, SD, SEM, range, AND the units) (insert a ' - ' if no data available)

| Group A: __________ N ___ | Group B: _____________ N ___ | ALL ________ N ___
Males/females (%)
Age: Mean; SD
Race: (White % )
Mean duration work related symptoms (yr)
Mean duration workplace exposure (yr)
Latency (yr)
Atopic (%)
Smokers: (%)
Current smokers
Ex-smokers
Never smoked
Hx asthma (%)
Pulmonary function (single measure - specify)
Other -Specify
Other -Specify

Current medications documented □ Yes□ No

Other outcomes reported □ Yes□ No

| Group A: __________ N ___ | Group B: _____________ N ___ | ALL ________ N ___
Costs mean; sd
Time to complete Dx mean; sd
Adverse events
Other - specify
Other - specify

Test Characteristics

1 SIC Method followed ______________________________ □ referenced □ described in text
  a Inclusion criteria _________________________________________________________________
    □ NR
  b Exclusion criteria _________________________________________________________________
    □ NR
  c +ve test or significant change: _________________________________________________________________
    □ NR
2 NSBPT Method followed ___________________________ □ referenced □ described in text
  □ Methacholine □ Histamine □ Both
  □ Single □ Serial (i.e. >1 challenge)
  a Inclusion criteria _________________________________________________________________
    □ NR
  b Exclusion criteria _________________________________________________________________
    □ NR
  c +ve test or significant change: _________________________________________________________________
    Serial measure:
    ____________________________________________________________
    □ NR
3 Single Pulmonary Function Measure (specify)_____________________________________________
  □ Reversibility reported □ Yes □No
  a Inclusion criteria _________________________________________________________________
    □ NR
  b Exclusion criteria _________________________________________________________________
    □ NR
  c +ve test or significant change: _________________________________________________________________
    □ NR
4 Serial Pulmonary Function
  Duration: ______________@ work___________@ away from work; recorded__________ times/day
  Measure taken: □ FEV1 □ PEF
  a Inclusion criteria _________________________________________________________________
    □ NR
  b Exclusion criteria _________________________________________________________________
    □ NR
  c +ve test or significant change: _________________________________________________________________
    □ NR
5 Other: ________________________
  Method ____________________________ □ Referenced □ Described in text
  a Inclusion criteria _________________________________________________________________
  b Exclusion criteria _________________________________________________________________
  c +ve test or significant change: _________________________________________________________________
    □ NR
6 Clinical Diagnosis of OA (as defined in article) ____________________________________________
  □ NR
7 Immunological Testing
  a Skin prick test: Method followed ____________________□ Referenced □ Described in text
    Reason □ Atopy (common allergens) □ Specific □ Both
    +ve test: ___________________________________________________________□ NR
  b Total IgE □ Yes□ No+ve test or significant change:_____________________ □ NR
    Method: □ RAST□ ELISA□ Other, Specify___________________
  c Specific IgE □ yes □ no+ve test or significant change: ____________________ □ NR
    Method: □ RAST□ ELISA □ Other, Specify___________________
  d Other:__________________+ve test or significant change:_____________________ □ NR
    Method: □ RAST□ ELISA □ Other, Specify___________________
  e Other:__________________+ve test or significant change:_____________________ □ NR
    Method: □ RAST □ ELISA □ Other, Specify___________________

Results Reported

[underlined: Test results (put highest level of evidence test at the top, comparison test on the left side)]

1. ___________________ compared to __________________

_______________________ 2 × 2 table □ Reported □ Calculated

| OA | not OA
+ve
-ve

Sensitivity:_____________________ Specificity:_____________________

2. ___________________ compared to __________________

_______________2 × 2 table □ Reported □ Calculated

| OA | not OA
+ve
-ve

Sensitivity:_____________________ Specificity:_____________________

3. ___________________ compared to __________________

_______________2 × 2 table □ Reported □ Calculated

| OA | not OA
+ve
-ve

Sensitivity:_____________________ Specificity:_____________________

4. _______________2 × 2 table □ Reported □ Calculated

| OA | not OA
+ve
-ve

Sensitivity:_____________________ Specificity:_____________________

5. ___________________ compared to __________________

_______________2 × 2 table □ Reported □ Calculated

| OA | not OA
+ve
-ve

Sensitivity:_____________________ Specificity:_____________________

6. ___________________ compared to __________________

_______________2 × 2 table □ Reported □ Calculated

| OA | not OA
+ve
-ve

Sensitivity:_____________________ Specificity:_____________________

Form B-7. Data extraction form: Management of occupational asthma

Patient Flow

1 Initial number eligible (i.e. confirmed Dx of OA): n=___________________ □ Not known
2 Total agreed to participate: n= _______________________
3 Exclusions: □ Yes n=_____ □ No □ Unclear □ NR Reasons:
4 Withdrawals / dropouts / refusals: □ Yes n=_____ □ No □ Unclear □ NR Reasons:
5 Number who completed the study / follow-up: n=___________
6 Was there a comparison group or control subgroup within cohort □ Yes n=____ □ No Describe:

Intervention:□ Removal from offending workplace n=_______

□ Advised to avoid exposure n=_________

□ Remained at same workplace:

□ Moved to reduced exposure n=________

□ Moved to no exposure n= ______

□ Used protective equipment n=________

type: ________________________________________

□ Used medications n=_____

type: ________________________________________

□ Remained fully exposed n=_____

Methods

Data Collection: □ Questionnaire □ Interview □ Clinical review □ Retrospective chart review

Medications (anti-asthma) stopped pre-testing: □ Yes (attempted) □ No □ NR

Baseline Characteristics at Diagnosis:

Please indicate the statistic, e.g. %, mean, SD, range AND the units (which gets filled in will depend on how reported)

Other Baseline Data at Diagnosis: (specify measure plus metric)

| Group A ___________ n= | Group B _________ n= | Group C ___________ n= | Group D ___________ n= | Group E ___________ n=

Follow-Up Results:

| Group A ___________ n= | Group B ___________ n= | Group C ___________ n= | Group D ___________ n= | Group D ___________ n=
Smokers: n (%) CS
ExS
NS

Test Characteristics and Results

Test ________________________________

Method followed ____________________________________________

□ Referenced □ Described in text

+ve test or significant change: _______________________________________________________________□ NR

FU time______________ | Group A ___________ n= | Group B ___________ n= | Group C ___________ n= | Group D ___________ n= | Group D ___________ n=

Notes:

Test ________________________________

Method followed _____________________________________________

□ Referenced □ Described in text

+ve test or significant change: _______________________________________________________________□ NR

FU time______________ | Group A ___________ n= | Group B ___________ n= | Group C ___________ n= | Group D ___________ n= | Group D ___________ n=

Test ________________________________

Method followed ____________________________________________

□ Referenced □ Described in text

+ve test or significant change: _______________________________________________________________□ NR

FU time______________ | Group A ___________ n= | Group B ___________ n= | Group C ___________ n= | Group D ___________ n= | Group D ___________ n=

Test ________________________________

Method followed ____________________________________________

□ Referenced □ Described in text

+ve test or significant change: _______________________________________________________________□ NR

FU time______________ | Group A ___________ n= | Group B ___________ n= | Group C ___________ n= | Group D ___________ n= | Group D ___________ n=