# Appendix A: Exact Search Strings

Diagnosis of Occupational Asthma Searches

Table A-1: Agricola and Biological Abstracts

Table A-2: Cinahl

Table A-3: Embase

Table A-4: Medline

Table A-5: Web of Science

Management of Occupational Asthma Searches

Table A-6: Agricola and Biological Abstracts

Table A-7: Cinahl

Table A-8: Cochrane Airways Group

Table A-9: Embase

Table A-10: Medline

Table A-11: Web of Science

Occupational Asthma Searches

Table A-12: Dissertation Abstracts

Table A-13: Expanded Academia

Table A-14: NASD

Table A-1 Agricola and Biological Abstracts: Diagnosis of occupational asthma (1970 to September 2003)

Set # and Keyword Search
1. | (asthma or wheez* or respiratory sound* or airway obstruction* or airway*
2. | (respiratory or pneumonitis or alveol* or bronchial or airway* or lung*) silo filler* disease or bird fancier* lung or pneumoconiosis or baker* or skin prick* or respiratory function test* or bronchial provocation test* or work caus* or work aggravat* or concurrent or job or employ* or occupation*
3. | 1 or 2
4. | (occupational disease* or agricultural worker* disease* or farmer* lung or
5. | (animal* or fowl or farmer* or pheasant* or bird* or pigeon* or hen or
6. | occupation* asthma*
7. | 4 or 5
8. | 3 and 7
9. | 6 or 8 and (hypersensitiv* or hyperreactiv* or hyper reactiv* or allerg* or breath test* or spirometry or spirometr* or bronchospirometry or physical bronchial responsive* or nsbr or nsbh or bronchospas* or bronchoconstric* or chloride or immunologic test* or immunosorbent technique* or skin test* or dysfunction* or airway obstruct* or reactive airway* or lung disease* or epoxy resin* or latex or red cedar* or occupation* air pollutant* or exam* or medical history taking or questionnaire*) expiratory flow rate* or pef or pefr or forced expiratory volume or fev1 or expiratory flow-volume curve* or maximal midexpiratory flow rate* or peak forced expiratory flow rate* or maximal expiratory flow rate* or maximal grain* or industry or worker* or worksite* or work site* or work relat* or handler*) (hens) and (fancier* or worker* or breeder* or keeper* or raiser* or hyperreactiv* or bronchial spasm* or bronch* spas* or bronchial disease* or hyperresponsiv* or non specific bronchial responsive* or non-specific inhalation expos* or occupational expos* or di-isocynate* or isocynate* or insufficien*) methacholine or pulmonary or inhal* or antigen* or allergen* or hypertonic monitor* or measur* or provocation) non specific bronchial hyperresponsiv* or nonspecific bronchial obstructive lung disease* or respiratory tract disease or bronchial occupational airway*) or environment* or workplace or employment or environmental expos* or isocapnic or hyperosmolar) and (challenge* or test or tests or testing or rhonchi or twitchy airway*)
10. | (induced sputum* or inhalation challeng* or peak flow* or methacholine
11. | (bronchial or carbachol or serial or cold air or histamine* or
12. | 10 or 11
13. | 9 and 12

Table A-2 Cinahl: Diagnosis of occupational asthma (1982 to February Week 1 2004)

Set # and Keyword Search
1. | asthma/ or asthma$.tw.
2. | wheez$.tw.
3. | respiratory sounds/
4. | airway obstruction/
5. | (airway$ adj3 (dysfunction$ or obstruct$)).tw.
6. | reactive airway$.tw.
7. | lung diseases/
8. | lung diseases, obstructive/
9. | respiratory tract diseases/
10. | bronchial hyperreactivity/
11. | bronchial spasm/ or (bronch$ adj5 spas$).tw.
12. | bronchial diseases/
13. | (non specific bronchial hyperresponsiv$ or nonspecific bronchial hyperresponsiv$).tw.
14. | (non specific bronchial responsiv$ or nonspecific bronchial responsiv$).tw.
15. | (nsbr or nsbh).tw.
16. | (bronchospas$ or bronchoconstric$ or rhonchi).tw.
17. | twitchy airway$.tw.
18. | (respiratory or pneumonitis or alveol$ or bronchial or airway$ or lung$) adj3 (hypersensitiv$ or hyperreactiv$ or hyper reactiv$ or allerg$ or insufficien$)).mp.
19. | or/1–18
20. | occupational diseases/
21. | pneumoconiosis/
22. | ((animal$ or fowl or farmer$ or pheasant$ or bird$ or pigeon$ or hen or hens) adj3 (fancier$ or worker$ or breeder$ or keeper$ or raiser$ or handler$)).mp.
23. | (baker$ or grain$).tw.
24. | exp industry/
25. | (worker$ or worksite$ or work site$ or work relat$ or work caus$ or work aggravat$ or concurrent or job or employ$ or occupation$ or environment$).tw.
26. | (workplace or employment).mp.
27. | environmental exposure/
28. | occupational exposure/
29. | (environmental exposur$ or inhalation exposur$ or occupational exposur$).mp.
30. | (di-isocynate$ or isocynate$).tw.
31. | (epoxy resin$ or latex or red cedar$).mp.
32. | air pollutants, occupational/
33. | occupational airway$.mp.
34. | (occupation$ adj5 asthma$).mp.
35. | or/20–33
37. | 19 and 35
38. | 37 or 34
39. | induced sputum$.tw.
40. | inhalation challeng$.tw.
41. | ((bronchial or carbachol or serial or cold air or histamine$ or methacholine or pulmonary or inhal$ or antigen$ or allergen$ or hypertonic or isocapnic or hyperosmolar) adj3 (challenge$ or test or tests or testing or monitor$ or measur$ or provocation)).tw.
42. | peak flow$.tw.
43. | methacholine chloride/du
44. | immunologic tests/ or exp immunosorbent techniques/
45. | exp skin tests/ or skin prick$.mp.
46. | respiratory function tests/
47. | bronchial provocation tests/
48. | forced expiratory flow rates/
49. | maximal expiratory flow rate/
50. | maximal expiratory flow-volume curves/
51. | peak expiratory flow rate/
52. | (pef or pefr).tw.
53. | forced expiratory volume.mp. or fev1.tw.
54. | breath tests/
55. | spirometry/ or spirometr$.tw.
56. | physical examination/
57. | medical history taking/
58. | questionnaires/
59. | diagnostic techniques, respiratory system/
60. | or/39–59
61. | diagnostic accuracy.tw.
62. | exp diagnosis/
63. | diagnos$.tw.
64. | “sensitivity and specificity”/
65. | (sensitivity or specificity).tw.
66. | (predictive adj4 value$).tw.
67. | diagnostic errors/
68. | false negative reactions/
69. | false positive reactions/
70. | (false negativ$ or false positiv$).tw.
71. | observer variation$.mp.
72. | ((roc or receiver operating) adj curve$).tw.
73. | roc curve/
74. | (likelihood adj4 ratio$).tw.
75. | likelihood function/
76. | (di or du or et or ae or ci).fs.
77. | or/61–76
78. | and/38,60,77
79. | limit 78 to (newborn infant <birth to 1 month>or infant <1 to 23 months>or preschool child <2 to 5 years>or child <6 to 12 years>or adolescence <13 to 18 years>)
80. | 78 not 79
81. | limit 80 to (case study or review)
82. | 80 not 81

Table A-3 Embase: Diagnosis of occupational asthma (1988 to January Week 0 2004)

Set # and Keyword Search
1. | asthma/
2. | asthma$.tw.
3. | Wheezing/
4. | wheez$.tw.
5. | abnormal respiratory sound/
6. | breathing disorder/
7. | Airway Obstruction/
8. | respiratory tract disease/ or bronchus disease/ or lung disease/ or respiratory distress/ or respiratory function disorder/ or respiratory tract inflammation/
9. | reactive airway$.tw.
10. | ((airway$ or lung$) adj3 (dysfunction$ or obstruct$)).tw.
11. | Bronchus Hyperreactivity/
12. | Bronchospasm/
13. | (bronch$ adj3 (disease$ or spas$)).tw.
14. | (non-specific bronchial hyperresponsiv$ or nonspecific bronchial hyperresponsiv$).tw.
15. | (non-specific bronchial responsiv$ or nonspecific bronchial responsiv$).tw.
16. | (nsbr or nsbh).tw.
17. | (bronchospas$ or bronchoconstrict$ or rhonchi).tw.
18. | twitchy airway$.tw.
19. | ((respiratory or pneumonitis or alveol$ or bronchial or airway$ or lung$) adj3 (hypersensitiv$ or hyperreactiv$ or hyper reactiv$ or allerg$ or insufficien$)).mp.
20. | Lung Insufficiency/
21. | or/1–20
22. | occupational disease/ or occupational allergy/ or occupational lung disease/
23. | bird breeder lung/
24. | allergic pneumonitis/
25. | Pneumoconiosis/
26. | ((animal$ or fowl or farmer$ or pheasant$ or bird$ or pigeon$ or hen or hens) adj3 (fancier$ or worker$ or breeder$ or keeper$ or raiser$ or handler$)).mp.
27. | farmer$ lung.tw.
28. | ((agricultur$ or silo filler$) adj3 disease$).tw.
29. | (baker$ or grain$).tw.
30. | (worker$ or worksite$ or work site$ or work relate$ or work cause$ or work aggravat$ or concurrent or job or employ$ or occupation$ or environment$).mp.
31. | work/ or work environment/
32. | exp worker/
33. | environmental exposure/
34. | exposure/
35. | occupational exposure/
36. | (environment$ exposur$ or inhalation exposur$ or occupation$ exposur$).tw.
37. | Isocyanate/
38. | (di-isocynate$ or isocyanate$).mp.
39. | (Epoxy Resin or latex or “red cedar”).mp.
40. | air pollutant/
41. | occupational airway$.tw.
42. | (occupation$ adj5 asthma$).mp.
43. | exp Occupational Asthma/
44. | 42 or 43
45. | or/22–41
46. | 21 and 45
47. | 46 or 44
48. | sputum analysis/
49. | induced sputum$.tw.
50. | provocation test/
51. | inhalation challenge$.tw.
52. | ((bronchial or carbachol or serial or cold air or histamine$ or methacholine or pulmonary or inhal$ or antigen$ or allergen$ or hypertonic or isocapnic or hyperosmolar) adj3 (challenge$ or test or tests or testing or monitor$ or measur$ or provocation)).tw.
53. | METHACHOLINE CHLORIDE/
54. | enzyme linked immunosorbent assay/
55. | ((bronchial or carbachol or serial or cold air or histamine$ or methacholine or pulmonary or inhal$ or antigen$ or allergen$ or hypertonic or isocapnic or hyperosmolar or immunologic$) adj3 (challenge$ or test or tests or testing or monitor$ or measur$ or provocation)).tw.
56. | skin test/
57. | prick test/
58. | exp lung function test/
59. | inhalation test/
60. | forced expiratory flow/
61. | forced expiratory volume/
62. | maximal expiratory flow$.tw.
63. | (maximal expiratory flow$ or maximal midexpiratory flow$).tw.
64. | peak expiratory flow/
65. | (pef or pefr).tw.
66. | peak flow.tw.
67. | (forced expiratory volume or fev1).tw.
68. | breath analysis/
69. | breath test$.tw.
70. | spirometr$.tw.
71. | bronchospirography/
72. | bronchospirometry.tw.
73. | physical examination/
74. | anamnesis/
75. | questionnaire/
76. | exp respiratory tract examination/
77. | or/48–76
78. | diagnostic accuracy/
79. | exp diagnosis/
80. | diagnos$.tw.
81. | “sensitivity and specificity”/
82. | (sensitivity or specificity).tw.
83. | (predictive adj4 value$).tw.
84. | diagnostic error/
85. | (false negativ$ or false positiv$).tw.
86. | observer variation$.mp.
87. | roc curve/
88. | receiver operating characteristic/
89. | (likelihood adj4 ratio$).tw.
90. | statistical model/
91. | (di or du or et or ae or ci).fs.
92. | or/78–91
93. | and/47,77,92
94. | limit 93 to (embryo <first trimester>or infant <to one year>or child <unspecified age>or preschool child <1 to 6 years>or school child <7 to 12 years> or adolescent <13 to 17 years>)
95. | 93 not 94
96. | limit 95 to (report or review)
97. | 95 not 96
98. | exp case report/
99. | 97 not 98

Table A-4 Medline: Diagnosis of occupational asthma (1966 to January Week 3 2004)

Set # and Keyword Search
1. | asthma/ or asthma$.tw.
2. | wheez$.tw.
3. | respiratory sounds/
4. | airway obstruction/
5. | (airway$ adj3 (dysfunction$ or obstruct$)).tw.
6. | reactive airway$.tw.
7. | lung diseases/
8. | lung diseases, obstructive/
9. | respiratory tract diseases/
10. | bronchial hyperreactivity/
11. | bronchial spasm/ or (bronch$ adj5 spas$).tw.
12. | bronchial diseases/
13. | (non specific bronchial hyperresponsiv$ or nonspecific bronchial hyperresponsiv$).tw.
14. | (non specific bronchial responsiv$ or nonspecific bronchial responsiv$).tw.
15. | (nsbr or nsbh).tw.
16. | (bronchospas$ or bronchoconstric$ or rhonchi).tw.
17. | twitchy airway$.tw.
18. | ((respiratory or pneumonitis or alveol$ or bronchial or airway$ or lung$) adj3 (hypersensitiv$ or hyperreactiv$ or hyper reactiv$ or allerg$ or insufficien$)).mp.
19. | or/1–18
20. | occupational diseases/
21. | agricultural workers' diseases/
22. | farmer's lung/
23. | silo filler's disease/
24. | bird fancier's lung/
25. | pneumoconiosis/
26. | ((animal$ or fowl or farmer$ or pheasant$ or bird$ or pigeon$ or hen or hens) adj3 (fancier$ or worker$ or breeder$ or keeper$ or raiser$ or handler$)).mp.
27. | (baker$ or grain$).tw.
28. | exp industry/
29. | (worker$ or worksite$ or work site$ or work relat$ or work caus$ or work aggravat$ or concurrent or job or employ$ or occupation$ or environment$).tw.
30. | (workplace or employment).mp.
31. | environmental exposure/
32. | inhalation exposure/
33. | occupational exposure/
34. | (environmental exposur$ or inhalation exposur$ or occupational exposur$).mp.
35. | (di-isocynate$ or isocynate$).tw.
36. | (epoxy resin$ or latex or red cedar$).mp.
37. | air pollutants, occupational/
38. | occupational airway$.mp.
39. | (occupation$ adj5 asthma$).mp.
40. | or/20–39
41. | 19 and 40
42. | 39 or 41
43. | induced sputum$.tw.
44. | inhalation challeng$.tw.
45. | ((bronchial or carbachol or serial or cold air or histamine$ or methacholine or pulmonary or inhal$ or antigen$ or allergen$ or hypertonic or isocapnic or hyperosmolar) adj3 (challenge$ or test or tests or testing or monitor$ or measur$ or provocation)).tw.
46. | peak flow$.tw.
47. | methacholine chloride/du
48. | immunologic tests/ or exp immunosorbent techniques/
49. | exp skin tests/ or skin prick$.mp.
50. | respiratory function tests/
51. | bronchial provocation tests/
52. | forced expiratory flow rates/
53. | maximal expiratory flow rate/
54. | maximal expiratory flow-volume curves/
55. | maximal midexpiratory flow rate/
56. | peak expiratory flow rate/
57. | (pef or pefr).tw.
58. | forced expiratory volume.mp. or fev1.tw.
59. | breath tests/
60. | spirometry/ or spirometr$.tw.
61. | bronchospirometry/
62. | physical examination/
63. | medical history taking/
64. | questionnaires/
65. | diagnostic techniques, respiratory system/
66. | or/43–65
67. | diagnostic accuracy.tw.
68. | exp diagnosis/
69. | diagnos$.tw.
70. | “sensitivity and specificity”/
71. | (sensitivity or specificity).tw.
72. | (predictive adj4 value$).tw.
73. | diagnostic errors/
74. | false negative reactions/
75. | false positive reactions/
76. | (false negativ$ or false positiv$).tw.
77. | observer variation$.mp.
78. | ((roc or receiver operating) adj curve$).tw.
79. | roc curve/
80. | (likelihood adj4 ratio$).tw.
81. | likelihood function/
82. | (di or du or et or ae or ci).fs.
83. | or/67–82
84. | and/42,66,83
85. | limit 84 to (all infant <birth to 23 months> or all child <0 to 18 years> or newborn infant <birth to 1 month> or infant <1 to 23 months> or preschool child <2 to 5 years> or child <6 to 12 years> or adolescent <13 to 18 years>)
86. | 84 not 85
87. | limit 86 to (case reports or review or review, academic or review literature or review, tutorial)
88. | 86 not 87

Table A-5 Web of Science: Diagnosis of occupational asthma (1966 to January Week 3 2004)

Set # and Keyword Search
1. | Burge PS, O'Brien IM, Harries MG. Peak flow rate records in the diagnosis of occupational asthma due to isocyanates. Thorax 1979;34:317–323.
2. | Cote J, Kennedy S, Chan-Yeung M. Sensitivity and specificity of p20 and peak expiratory flow rate in cedar asthma. J Allergy Clin Immunol 1990;85:592–598.
3. | Perrin B, Lagier F, L'Archeveque J, Cartier A, Boulet LP, Cote J, Malo JL. Occupational asthma: validity of monitoring of peak expiratory flow rates and non-allergic bronchial responsiveness as compared to specific inhalation challenge. Eur Respir J. 1992;5:40–8.

Table A-6 Agricola and Biological Abstracts: Management of occupational asthma (1970 to September 2003)

Set # and Keyword Search
1. | (asthma or wheez* or respiratory sound* or airway obstruction* or airway* dysfunction* or airway obstruct* or reactive airway* or lung disease* or obstructive lung disease* or respiratory tract disease or bronchial hyperreactiv* or bronchial spasm* or bronch* spas* or bronchial disease* or non specific bronchial hyperresponsiv* or nonspecific bronchial hyperresponsiv* or non specific bronchial responsive* or non-specific bronchial responsive* or nsbr or nsbh or bronchospas* or bronchoconstric* or rhonchi or twitchy airway*)
2. | (respiratory or pneumonitis or alveol* or bronchial or airway* or lung*) and (hypersensitiv* or hyperreactiv* or hyper reactiv* or allerg* or insufficien*)
3. | 1 or 2
4. | (occupational disease* or agricultural worker* disease* or farmer* lung or silo filler* disease or bird fancier* lung or pneumoconiosis or baker* or grain* or industry or worker* or worksite* or work site* or work relat* or work caus* or work aggravat* or concurrent or job or employ* or occupation* or environment* or workplace or employment or environmental expos* or inhalation expos* or occupational expos* or di-isocynate* or isocynate* or epoxy resin* or latex or red cedar* or occupation* air pollutant* or occupational airway*)
5. | (animal* or fowl or farmer* or pheasant* or bird* or pigeon* or hen or hens) and (fancier* or worker* or breeder* or keeper* or raiser* or handler*)
6. | occupation* asthma*
7. | 4 or 5
8. | 3 and 7
9. | 6 or 8
10. | (work or job or occupation* or profession* or employe*) and (remov* or modif* or adjust* or transfer* or alter* or leave or terminat* or cease or cessation or return*)
11. | change and (employe* or work* or occupation* or work* or process* or procedur*)
12. | (prevent* or reduc* or eliminat* or minimiz* or minimis* or minimal* or control*) and (expos* or agent* or irritant* or sensitizer*) 13 (change or retrain* or alter*) and (employe* or work* or occupation* or work* or process* or procedur*)
14. | 10 or 11 or 12 or 13
15. | 9 and 14

Table A-7 Cinahl: Management of occupational asthma (1982 to February Week 1 2004)

Set # and Keyword Search
1. | asthma/ or asthma$.tw.
2. | wheez$.tw.
3. | respiratory sounds/
4. | airway obstruction/
5. | (airway$ adj3 (dysfunction$ or obstruct$)).tw.
6. | reactive airway$.tw.
7. | lung diseases/
8. | lung diseases, obstructive/
9. | respiratory tract diseases/
10. | bronchial hyperreactivity/
11. | bronchial spasm/ or (bronch$ adj5 spas$).tw.
12. | bronchial diseases/
13. | (non specific bronchial hyperresponsiv$ or nonspecific bronchial hyperresponsiv$).tw.
14. | (non specific bronchial responsiv$ or nonspecific bronchial responsiv$).tw.
15. | (nsbr or nsbh).tw.
16. | (bronchospas$ or bronchoconstric$ or rhonchi).tw.
17. | twitchy airway$.tw.
18. | ((respiratory or pneumonitis or alveol$ or bronchial or airway$ or lung$) adj3 (hypersensitiv$ or hyperreactiv$ or hyper reactiv$ or allerg$ or insufficien$)).mp.
19. | or/1–18
20. | occupational diseases/
21. | pneumoconiosis/
22. | ((animal$ or fowl or farmer$ or pheasant$ or bird$ or pigeon$ or hen or hens) adj3 (fancier$ or worker$ or breeder$ or keeper$ or raiser$ or handler$)).mp.
23. | (baker$ or grain$).tw.
24. | exp industry/
25. | (worker$ or worksite$ or work site$ or work relat$ or work caus$ or work aggravat$ or concurrent or job or employ$ or occupation$ or environment$).tw.
26. | (workplace or employment).mp.
27. | environmental exposure/
28. | occupational exposure/
29. | (environmental exposur$ or inhalation exposur$ or occupational exposur$).mp.
30. | (di-isocynate$ or isocynate$).tw.
31. | (epoxy resin$ or latex or red cedar$).mp.
32. | air pollutants, occupational/
33. | occupational airway$.mp.
34. | (occupation$ adj5 asthma$).mp.
35. | or/20–33
37. | 19 and 35
38. | 37 or 34
39. | ((work or job or occupation$ or profession$ or employe$) adj5 (remov$ or modif$ or adjust$ or transfer$ or alter$ or leave or terminat$ or cease or cessation or return$)).tw.
40. | (change adj5 (employe$ or work$ or occupation$ or work$ or process$ or procedur$)).tw.
41. | ((prevent$ or reduc$ or eliminat$ or minimiz$ or minimis$ or minimal$ or control$) adj5 (expos$ or agent$ or irritant$ or sensitizer$)).tw.
42. | ((change or retrain$ or alter$) adj5 (employe$ or work$ or occupation$ or work$ or process$ or procedur$)).tw.
43. | or/39–42
44. | 38 and 43

Table A-8 Cochrane Airways Group: Management of occupational asthma (March 2004)

Set # and Keyword Search
1. | Searched using the following free text terms: occupation* or work* or baker* or mining or miner* or asbestos* or silicosis or wheat or flour* or farmer* or latex*

Table A-9 Embase: Management of occupational asthma (1988 to February Week 6 2004)

Set # and Keyword Search
1. | asthma/
2. | asthma$.tw.
3. | Wheezing/
4. | wheez$.tw.
5. | abnormal respiratory sound/
6. | breathing disorder/
7. | Airway Obstruction/
8. | respiratory tract disease/ or bronchus disease/ or lung disease/ or respiratory distress/ or respiratory function disorder/ or respiratory tract inflammation/
9. | reactive airway$.tw.
10. | ((airway$ or lung$) adj3 (dysfunction$ or obstruct$)).tw.
11. | Bronchus Hyperreactivity/
12. | Bronchospasm/
13. | (bronch$ adj3 (disease$ or spas$)).tw.
14. | (non-specific bronchial hyperresponsiv$ or nonspecific bronchial hyperresponsiv$).tw.
15. | (non-specific bronchial responsiv$ or nonspecific bronchial responsiv$).tw.
16. | (nsbr or nsbh).tw.
17. | (bronchospas$ or bronchoconstrict$ or rhonchi).tw.
18. | twitchy airway$.tw.
19. | ((respiratory or pneumonitis or alveol$ or bronchial or airway$ or lung$) adj3 (hypersensitiv$ or hyperreactiv$ or hyper reactiv$ or allerg$ or insufficien$)).mp.
20. | Lung Insufficiency/
21. | or/1–20
22. | occupational disease/ or occupational allergy/ or occupational lung disease/
23. | bird breeder lung/
24. | allergic pneumonitis/
25. | Pneumoconiosis/
26. | ((animal$ or fowl or farmer$ or pheasant$ or bird$ or pigeon$ or hen or hens) adj3 (fancier$ or worker$ or breeder$ or keeper$ or raiser$ or handler$)).mp.
27. | farmer$ lung.tw.
28. | ((agricultur$ or silo filler$) adj3 disease$).tw.
29. | (baker$ or grain$).tw.
30. | (worker$ or worksite$ or work site$ or work relate$ or work cause$ or work aggravat$ or concurrent or job or employ$ or occupation$ or environment$).mp.
31. | work/ or work environment/
32. | exp worker/
33. | environmental exposure/
34. | exposure/
35. | occupational exposure/
36. | (environment$ exposur$ or inhalation exposur$ or occupation$ exposur$).tw.
37. | Isocyanate/
38. | (di-isocynate$ or isocyanate$).mp.
39. | (Epoxy Resin or latex or “red cedar”).mp.
40. | air pollutant/
41. | occupational airway$.tw.
42. | (occupation$ adj5 asthma$).mp.
43. | exp Occupational Asthma/
44. | 42 or 43
45. | or/22–41
46. | 21 and 45
47. | 46 or 44
48. | ((work or job or occupation$ or profession$ or employ$) adj5 (remov$ or modif$ or adjust$ or transfer$ or alter$ or leave or terminat$ or cease or cessation or return$)).tw.
49. | (change adj5 (employ$ or work$ or occupation$ or work$ or process$ or procedur$)).tw.
50. | ((prevent$ or reduc$ or eliminat$ or minimiz$ or minimis$ or minimal$ or control$) adj5 (expos$ or agent$ or irritant$ or sensitizer$)).tw.
51. | ((change or retrain$ or alter$) adj5 (employ$ or work$ or occupation$ or process$ or procedur$)).tw.
52. | or/48–51
53. | 47 and 52

Table A-10 Medline: Management of occupational asthma (1966 to January Week 4 2004)

Set # and Keyword Search
1. | ASTHMA/
2. | asthma$.tw.
3. | wheez$.tw.
4. | respiratory sounds/
5. | airway obstruction/
6. | (airway$ adj3 (dysfunction$ or obstruct$)).tw.
7. | reactive airway$.tw.
8. | Lung Diseases/
9. | Lung Diseases, obstructive/
10. | Respiratory Tract Diseases/
11. | bronchial hyperreactivity/
12. | bronchial spasm/ or (bronch$ adj5 spas$).tw.
13. | bronchial diseases/
14. | (non-specific bronchial hyperresponsiv$ or nonspecific bronchial hyperresponsiv$).tw.
15. | (non-specific bronchial responsiv$ or nonspecific bronchial responsiv$).tw.
16. | (nsbr or nsbh).tw.
17. | bronchospas$ or bronchoconstrict$ or rhonchi).tw.
18. | twitchy airway$.tw.
19. | ((respiratory or pneumonitis or alveol$ or bronchial or airway$ or lung$) adj3 (hypersensitiv$ or hyperreactiv$ or hyper reactiv$ or allerg$ or insufficien$)).mp.
20. | or/1–19
21. | occupational diseases/
22. | agricultural workers' diseases/
23. | farmer's lung/
24. | silo filler's disease/
25. | bird fancier's lung/
26. | pneumoconiosis/
27. | ((animal$ or fowl or farmer$ or pheasant$ or bird$ or pigeon$ or hen or hens) adj3 (fancier$ or worker$ or breeder$ or keeper$ or raiser$ or handler$)).mp.
28. | (baker$ or grain$).tw.
29. | (worker$ or worksite$ or work site$ or work relate$ or work cause$ or work aggravat$ or concurrent or job or employ$ or occupation$ or environment$).tw.
30. | (workplace or employment).mp.
31. | environmental exposure/
32. | inhalation exposure/
33. | Occupational Exposure/
34. | (environmental exposur$ or inhalation exposur$ or occupational exposur$).mp.
35. | (di-isocynate$ or isocynate$).tw.
36. | (epoxy resin$ or latex or “red cedar”).mp.
37. | air pollutants, occupational/
38. | occupational airway$.mp.
39. | (occupation$ adj5 asthma$).mp.
40. | or/21–38
41. | 20 and 40
42. | 39 or 41
43. | ((work or job or occupation$ or profession$ or employe$) adj5 (remov$ or modif$ or adjust$ or transfer$ or alter$ or leave or terminat$ or cease or cessation or return$)).tw.
44. | (change adj5 (employe$ or work$ or occupation$ or work$ or process$ or procedur$)).tw.
45. | ((prevent$ or reduc$ or eliminat$ or minimiz$ or minimis$ or minimal$ or control$) adj5 (expos$ or agent$ or irritant$ or sensitizer$)).tw.
46. | ((change or retrain$ or alter$) adj5 (employe$ or work$ or occupation$ or work$ or process$ or procedur$)).tw.
47. | or/43–46
48. | 42 and 47

Table A-11 Web of Science: Management of occupational asthma (1966 to January Week 4 2004)

Set # and Keyword Search
1. | Pisati G, Baruffini A, Zedda S. Toluene diisocyante induced asthma: outcome according to persistence or cessation of exposure. Br J Ind Med 1993;50:60–64.
2. | Cote J, Kennedy S, Chan-Yeung M. Outcome of patients with cedar asthma with continuous exposure. Am Rev Respir Dis 1990;141:373–6.

Table A-12 Dissertation Abstracts: Occupational asthma (searched February 2004)

Set # and Keyword Search
1. | Searched using keyword: “occupational asthma”

Table A-13 Expanded Academic: Occupational asthma (1980 to February 2004)

Set # and Keyword Search
1. | Searched using keyword: “occupational asthma”

Table A-14 NASD: Occupational asthma (searched January 2004)

Set # and Keyword Search
1. | Searched using keywords: “occupational asthma”, work related asthma, work caused asthma, occupation* disease, respiratory disease, specific inhalation challenge, peak flow, methacholine, forced expiratory volume, spirometry