# Appendixes

Appendix A: Exact Search Strings

Appendix B: Sample Data Forms

Appendix C: Levels of Evidence

Appendix D: Multiple Publications

Appendix E: Evidence Tables

Appendix F: Technical Expert Panel, List of Peer Reviewers, and Translators

Appendix G: Quality Analysis of the Diagnostic Occupational Asthma Studies

Appendix H: Sensitivity and Specificity of Comparison Tests that Used SIC as a Reference Standard