# Acronyms and Abbreviations

2-hr PG | 2-hour Plasma Glucose
4S | Scandinavian Simvastatin Survival Study
AAFP | American Academy of Family Physicians
AAP | American Academy of Pediatrics
ACP | American College of Physicians
ADA | American Diabetes Association
AHRQ | Agency for Healthcare Research and Quality
AMED | Allied and Complementary Medicine Database
AR | Attributable Risk
ARIC | Atherosclerosis Risk in Communities Study
AusDiab | Australian Diabetes, Obesity and Lifestyle Study
BID | Two times daily
BIP | Bezafibrate Infarction Prevention trial
BMI | Body Mass Index
BP | Blood Pressure
CABG | Coronary Artery Bypass Graft
CARE | Cholesterol and Recurrent Events Study
CCT | Controlled Clinical Trial
CHD | Coronary Heart Disease
CHS | Cardiovascular Health Study
CI | Confidence Interval
CINAHL^®^ | Cumulative Index to Nursing and Allied Health Literature
CR | Chromium-supplementation
CV | Coefficient Variation
CVD | Cardiovascular Disease
d | Day
DBP | Diastolic Blood Pressure
DECODA | Diabetes Epidemiology: Collaborative Analysis of Diagnostic Criteria in Asia
DECODE | Diabetes Epidemiology: Collaborative Analysis of Diagnostic Criteria in Europe
DM | Diabetes Mellitus
DPP | Diabetes Prevention Program
EDIP | Early Diabetes Intervention Program
EMBASE^®^ | Excerpta Medica Database
EPC | Evidence-based Practice Center
FDPS | Finnish Diabetes Prevention Study
FPG | Fasting Plasma Glucose
HDL | High Density Lipoprotein
HealthSTAR | Health Services Technology, Administration, and Research
Hong Kong CRFP | Hong Kong Cardiovascular Risk Factor Prevalence study
HR | Hazard Ratio
IFG | Impaired Fasting Glucose
IGT | Impaired Glucose Tolerance
I-IGT | Isolated Impaired Glucose Tolerance
I-IFG | Isolated Impaired Fasting Glucose
IRAS | Insulin Resistance Atherosclerosis Study
ITT | Intention To Treat
JACDS | Japanese American Community Diabetes Study
LDL | Low Density Lipoprotein
LIPID | Long-term Intervention with Pravastatin in Ischemic Disease
m | Month
MEDLINE^®^ | Database of the National Library of Medicine
MI | Myocardial Infarction
n | Number of subjects
NDDG | National Diabetes Data Group
NFG | Normal Fasting Glucose
NGT | Normal Glucose Tolerance
NHANES | National Health and Nutrition Examination Survey (I: 1971-1973; II: 1976-1980; III: 1988-1994)
NIDDM | Non-Insulin Dependent Diabetes Mellitus
NNT | Number Needed to Treat
NR | Not Reported
NS | Not Significant
OGTT | Oral Glucose Tolerance Test
OR | Odds Ratio
PC | Prospective Cohort
PEDS | Pediatric
Pima | Pima Indians Study
PPS | Paris Prospective Study
PsycINFO^®^ | Abstract database of the American Psychological Association
pt | Patient
PTCA | Percutaneous Transluminal Coronary Angioplasty
pts | Patients
R | Risk
RCT | Randomized Control Trial
REP | Rochester Epidemiology Project
RIAD | Risk factors in IGT for Atherosclerosis and Diabetes
RR | Relative Risk
RRR | Relative Risk Reduction
SBP | Systolic Blood Pressure
SD | Standard Deviation
SE | Standard Error
SS | Statistically Significant
STOP-NIDDM | Study to Prevent Non-Insulin Dependent Diabetes Mellitus
TC | Total Cholesterol
TEP | Technical Expert Panel
TIA | Transient Ischemic Attack
TID | Three times daily
Tx | Treatment
WHO | World Health Organization
y | Year