# References

Note: See Appendix E for excluded studies and Appendix F for complete bibliography.

1 Wild S, Roglic G, Green A, et al. Global prevalence of diabetes: estimates for the year 2000 and projections for 2030. Diabetes Care. May. 2004;27(5):1047-53. [pmid: 15111519].
2 Harris MI, Flegal KM, Cowie CC, et al. Prevalence of diabetes, impaired fasting glucose, and impaired glucose tolerance in U.S. adults: the Third National Health and Nutrition Examination Survey, 1988-1994. Diabetes Care. Apr. 1998;21(4):518-24. [pmid: 9571335].
3 Hogan P, Dall T, Nikolov P. Economic costs of diabetes in the US in 2002. Diabetes Care. Mar. 2003;26(3):917-32. [pmid: 12610059].
4 Genuth S, Alberti KG, Bennett P, et al. Follow-up report on the diagnosis of diabetes mellitus. Diabetes Care. Nov. 2003;26(11):3160-7. [pmid: 14578255].
5 Unwin N, Shaw J, Zimmet P, et al. Impaired glucose tolerance and impaired fasting glycaemia: the current status on definition and intervention. Diabet Med. 2002;19(9):708-23. [pmid: 12207806].
6 Hassan IA, Wickramasinghe YA, Spencer SA. Effect of a change in global metabolic rate on peripheral oxygen consumption in neonates. Archives of Disease in Childhood: Fetal & Neonatal Edition. Mar. 2003;88(2):F143-F146. [pmid: 12598505].
7 Borch-Johnsen K, Neil A, Balkau B. Is fasting glucose sufficient to define diabetes? Epidemiological data from 20 European studies. Diabetologia. 1999;42(6):647-54. [pmid: 10382583].
8 WHO expert committee on diabetes mellitus. World Health Organization Technical Report Series 1980;1–80.
9 Court de, Pettitt DJ, Knowler WC. Hypertension in Pima Indians: prevalence and predictors. Public Health Rep. 1996;111(Suppl 2):40-3. [pmid: 8898771]. [pmcid: 1381662].
10 Dean HJ, Young TK, Flett B, et al. Screening for type-2 diabetes in aboriginal children in northern Canada. Lancet. Nov 7. 1998;352(9139):1523-4. [pmid: 9820307].
11 Harris SB, Perkins BA, Whalen-Brough E. Non-insulin-dependent diabetes mellitus among First Nations children. New entity among First Nations people of north western Ontario. Can Fam Physician. May. 1996;42:869-76. [pmid: 8688690]. [pmcid: 2146381].
12 Sinha R, Fisch G, Teague B, et al. Prevalence of impaired glucose tolerance among children and adolescents with marked obesity. N Engl J Med. Mar 14. 2002;346(11):802-10. [pmid: 11893791].
13 Statistics Canada. National Center for Health Statistics. 2001.
14 Knowler WC, Pettitt DJ, Saad MF, et al. Diabetes mellitus in the Pima Indians: incidence, risk factors and pathogenesis. Diabetes Metab Rev. Feb. 1990;6(1):1-27. [pmid: 2192853].
15 Dean HJ, Mundy RL, Moffatt M. Non-insulin-dependent diabetes mellitus in Indian children in Manitoba. CMAJ. Jul 1. 1992;147(1):52-7. [pmid: 1393888]. [pmcid: 1336119].
16 Reference Manager [computer program]. ISI Research Soft. 10. Carlsbad, CA, USA: ISI Research Soft; 2001;
17 Microsoft Access [computer program]. Microsoft. 2000. USA: Microsoft Corporation; 1999;
18 Oremus M, Wolfson C, Perrault A, et al. Interrater reliability of the modified Jadad quality scale for systematic reviews of Alzheimer's disease drug trials. Dement Geriatr Cogn Disord. May. 2001;12(3):232-6. [pmid: 11244218].
19 MacKay M, Scanlan A, Olsen L, et al. Looking for the evidence: a systematic review of prevention strategies addressing sport and recreational injury among children and youth. J Sci Med Sport. Mar. 2004;7(1):58-73. [pmid: 15139166].
20 Alberti KGMM, Zimmet PZ. Definition, diagnosis and classification of diabetes mellitus and its complications part 1: Diagnosis and classification of diabetes mellitus - Provisional report of a WHO consultation. Diabet Med. Jul. 1998;15(7):539-53. [pmid: 9686693].
21 Cohen J. A coefficient of agreement for nominal scales. Educational and Psychological Measurement. 1960;20:37-46.
22 Fleiss JL, Cohen J, Everitt BS. Large-sample standard errors of kappa and weighted kappa. Psychological Bulletin. 1969;72:323-7.
23 Kelsey JL, Whittemore AS, Evans AS, et al. Methods in Observational Epidemiology. 2. New York: Oxford University Press; 1996.
24 Jaeschke R, Guyatt G, Shannon H, et al. Basic statistics for clinicians: 3. Assessing the effects of treatment: measures of association. CMAJ. Feb 1. 1995;152(3):351-7. [pmid: 7828099]. [pmcid: 1337533].
25 Sas/STAT User's Guide. [computer program]. SAS Institute. 8. Cary, NC, USA: SAS Institute Inc.; 2001;
26 Cochrane reviewers' Handbook 4.2. Chichester: Wiley; 2004.
27 Sutton AJ, Abrams KR, Jones DR, et al. Meta-analysis in medical research. Rexdale, Ontario, Canada: Wiley; 2000.
28 Matt GE, Cook TD. Threats to the validity of research synthosis. In: Cooper H, Hedges LV, editors. The Handbook of Research Synthesis, New York: Russell Sage Foundation; 1994. p. 503–20.
29 Mooy JM, Grootenhuis PA, de Vries H, et al. Intra-individual variation of glucose, specific insulin and proinsulin concentrations measured by two oral glucose tolerance tests in a general Caucasian population: the Hoorn Study. Diabetologia. Mar. 1996;39(3):298-305. [pmid: 8721775].
30 de Vegt F, Dekker JM, Stehouwer CD, et al. Similar 9-year mortality risks and reproducibility for the World Health Organization and American Diabetes Association glucose tolerance categories: the Hoorn Study. Diabetes Care. Jan. 2000;23(1):40-4. [pmid: 10857966].
31 Farrer M, Fulcher G, Albers CJ, et al. Patients undergoing coronary artery bypass graft surgery are at high risk of impaired glucose tolerance and diabetes mellitus during the first postoperative year. Metabolism. Aug. 1995;44(8):1016-27. [pmid: 7637643].
32 Ko GTC, Chan JCN, Woo J, et al. The reproducibility and usefulness of the oral glucose tolerance test in screening for diabetes and other cardiovascular risk factors. ANN CLIN BIOCHEM. 1998;35(1):62-7. [pmid: 9463740].
33 Ko GT, Chan JC, Woo J, et al. Use of the 1997 American Diabetes Association diagnostic criteria for diabetes in a Hong Kong Chinese population. Diabetes Care. Dec. 1998;21(12):2094-7. [pmid: 9839099].
34 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. Mar. 1977;33(1):159-74. [pmid: 843571].
35 de Vegt F, Dekker JM, Jager A, et al. Relation of impaired fasting and postload glucose with incident type 2 diabetes in a Dutch population: The Hoorn Study. JAMA. Apr 25. 2001;285(16):2109-13. [pmid: 11311100].
36 Gabir MM, Hanson RL, Dabelea D, et al. The 1997 American Diabetes Association and 1999 World Health Organization criteria for hyperglycemia in the diagnosis and prediction of diabetes. Diabetes Care. Aug. 2000;23(8):1108-12. [pmid: 10937506].
37 Qiao Q, Nakagami T, Tuomilehto J, et al. Comparison of the fasting and the 2-h glucose criteria for diabetes in different Asian cohorts. Diabetologia. Dec. 2000;43(12):1470-5. [pmid: 11151755].
38 Kousta E, Lawrence NJ, Penny A, et al. Implications of new diagnostic criteria for abnormal glucose homeostasis in women with previous gestational diabetes. Diabetes Care. Jun. 1999;22(6):933-7. [pmid: 10372245].
39 Tavintharan S, Chew LS, Heng DM. A rational alternative for the diagnosis of diabetes mellitus in high risk individuals. Ann Acad Med Singapore. Mar. 2000;29(2):213-8. [pmid: 10895342].
40 Puavilai G, Chanprasertyotin S, Sriphrapradaeng A. Diagnostic criteria for diabetes mellitus and other categories of glucose intolerance: 1997 criteria by the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus (ADA), 1998 WHO consultation criteria, and 1985 WHO criteria. World Health Organization. Diabetes Res Clin Pract. Apr. 1999;44(1):21-6. [pmid: 10414936].
41 Gatling W, Begley JP. Diagnosing diabetes mellitus in clinical practice: Is fasting plasma glucose a good initial test?. Practical Diabetes International. 2001;18(3):89-93.
42 Croxson SCM, Thomas PH. Glucose tolerance test results reappraised using recent ADA criteria. Practical Diabetes International. Sep. 1998;15(6):178-80.
43 Balkau B, Forhan A, Eschwege E. Two hour plasma glucose is not unequivocally predictive for early death in men with impaired fasting glucose: more results from the Paris Prospective Study. Diabetologia. Sep. 2002;45(9):1224-30. [pmid: 12242454].
44 Li C-L, Tsai S-T, Chou P. Comparison of metabolic risk profiles between subjects with fasting and 2-hour plasma glucose impairment: The Kinmen Study. J Clin Epidemiol. 2002;55(1):19-24. [pmid: 11781118].
45 Amoah AGB. Undiagnosed diabetes and impaired glucose regulation in adult Ghanaians using the ADA and WHO diagnostic criteria. Acta Diabetol. 2002;39(1):7-13. [pmid: 12043940].
46 Dunstan DW, Zimmet PZ, Welborn TA, et al. The rising prevalence of diabetes and impaired glucose tolerance: the Australian Diabetes, Obesity and Lifestyle Study. Diabetes Care. May. 2002;25(5):829-34. [pmid: 11978676].
47 Drzewoski J, Czupryniak L. Concordance between fasting and 2-h post-glucose challenge criteria for the diagnosis of diabetes mellitus and glucose intolerance in high risk individuals. Diabet Med. 2001;18(1):29-31. [pmid: 11168338].
48 Balkau B. The DECODE study. Diabetes epidemiology: collaborative analysis of diagnostic criteria in Europe. Diabetes Metab. Sep. 2000;26(4):282-6. [pmid: 11011220].
49 Norman RJ, Masters L, Milner CR, et al. Relative risk of conversion from normoglycaemia to impaired glucose tolerance or non-insulin dependent diabetes mellitus in polycystic ovarian syndrome. Hum Reprod. Sep. 2001;16(9):1995-8. [pmid: 11527911].
50 Wein P, Beischer N, Harris C, et al. A trial of simple versus intensified dietary modification for prevention of progression to diabetes mellitus in women with impaired glucose tolerance. Aust N Z J Obstet Gynaecol. 1999;39(2):162-6. [pmid: 10755770].
51 Pettitt DJ, Narayan KM, Hanson RL, et al. Incidence of diabetes mellitus in women following impaired glucose tolerance in pregnancy is lower than following impaired glucose tolerance in the non-pregnant state. Diabetologia. Nov. 1996;39(11):1334-7. [pmid: 8933001].
52 Goldberg RB, Mellies MJ, Sacks FM, et al. Cardiovascular events and their reduction with pravastatin in diabetic and glucose-intolerant myocardial infarction survivors with average cholesterol levels: subgroup analyses in the cholesterol and recurrent events (CARE) trial. The Care Investigators. Circulation. 1998;98(23):2513-9. [pmid: 9843456].
53 Larsson H, Lindgarde F, Berglund G, et al. Prediction of diabetes using ADA or WHO criteria in post-menopausal women: a 10-year follow-up study. Diabetologia. Oct. 2000;43(10):1224-8. [pmid: 11079739].
54 Charles MA, Eschwege E, Thibult N, et al. The role of non-esterified fatty acids in the deterioration of glucose tolerance in Caucasian subjects: results of the Paris Prospective Study. Diabetologia. Sep. 1997;40(9):1101-6. [pmid: 9300248].
55 Balkau B, Eschwege E, Ducimetiere P, et al. The high risk of death by alcohol related diseases in subjects diagnosed as diabetic and impaired glucose tolerant: the Paris Prospective Study after 15 years of follow-up. J Clin Epidemiol. 1991;44(6):465-74. [pmid: 2037851].
56 Fontbonne A, Tchobroutsky G, Eschwege E, et al. Coronary heart disease mortality risk: plasma insulin level is a more sensitive marker than hypertension or abnormal glucose tolerance in overweight males. The Paris Prospective Study. Int J Obes. 1988;12(6):557-65. [pmid: 3069769].
57 Fontbonne AM, Eschwege EM. Insulin and cardiovascular disease. Paris Prospective Study. Diabetes Care. Jun. 1991;14(6):461-9. [pmid: 1864219].
58 Fontbonne A, Eschwege E. Insulin-resistance, hypertriglyceridaemia and cardiovascular risk: the Paris Prospective Study. Diabete Metab. May. 1991;17(1 Pt 2):93-5. [pmid: 1936489].
59 Balkau B, Eschwege E, Fontbonne A, et al. Cardiovascular and alcohol-related deaths in abnormal glucose tolerant and diabetic subjects. Diabetologia. Jan. 1992;35(1):39-44. [pmid: 1541380].
60 Balkau B, Eschwege E, Papoz L, et al. Risk factors for early death in non-insulin dependent diabetes and men with known glucose tolerance status. BMJ. Jul 31. 1993;307(6899):295-9. [pmid: 8374376]. [pmcid: 1678578].
61 Charles MA, Fontbonne A, Thibult N, et al. Risk factors for NIDDM in white population. Paris prospective study. Diabetes. Jul. 1991;40(7):796-9. [pmid: 2060716].
62 Inoue I, Takahashi K, Katayama S, et al. A higher proinsulin response to glucose loading predicts deteriorating fasting plasma glucose and worsening to diabetes in subjects with impaired glucose tolerance. Diabet Med. 1996;13(4):330-6. [pmid: 9162608].
63 Ko GT, Chan JC, Tsang LW, et al. Combined use of fasting plasma glucose and HbA1c predicts the progression to diabetes in Chinese subjects. Diabetes Care. Dec. 2000;23(12):1770-3. [pmid: 11128350].
64 Ko GTC, Chan JCN, Cockram CS. Change of glycaemic status in Chinese subjects with impaired fasting glycaemia. Diabet Med. 2001;18(9):745-8. [pmid: 11606173].
65 Vermes E, Ducharme A, Bourassa MG, et al. Enalapril reduces the incidence of diabetes in patients with chronic heart failure: insight from the Studies of Left Ventricular Dysfunction (SOLVD). Circulation. Mar 11. 2003;107(9):1291-6. [pmid: 12628950].
66 Li G, Hu Y, Yang W, et al. Effects of insulin resistance and insulin secretion on the efficacy of interventions to retard development of type 2 diabetes mellitus: the DA Qing IGT and Diabetes Study. Diabetes Res Clin Pract. 2002;58(3):193-200. [pmid: 12413779].
67 Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20(4):537-44. [pmid: 9096977].
68 Chiasson JL, Josse RG, Gomis R, et al. Acarbose for prevention of type 2 diabetes mellitus: the STOP-NIDDM randomised trial. Lancet. 2002;359(9323):2072-7. [pmid: 12086760].
69 Saad MF, Knowler WC, Pettitt DJ, et al. The natural history of impaired glucose tolerance in the Pima Indians. N Engl J Med. Dec 8. 1988;319(23):1500-6. [pmid: 3054559].
70 Nelson RG, Bennett PH, Beck GJ, et al. Development and progression of renal disease in Pima Indians with non-insulin-dependent diabetes mellitus. Diabetic Renal Disease Study Group. N Engl J Med. Nov 28. 1996;335(22):1636-42. [pmid: 8929360].
71 Saad MF, Knowler WC, Pettitt DJ, et al. Transient impaired glucose tolerance in Pima Indians: is it important?. BMJ. Dec 3. 1988;297(6661):1438-41. [pmid: 3147006]. [pmcid: 1835114].
72 Stefan N, Stumvoll M, Bogardus C, et al. Elevated plasma nonesterified fatty acids are associated with deterioration of acute insulin response in IGT but not NGT. Am J Physiol Endocrinol Metab. Jun. 2003;284(6):E1156-E1161. [pmid: 12582008].
73 Ammari F, Batieha A, Jaddou PHH, et al. A natural history of impaired glucose tolerance in North Jordan. Practical Diabetes International. 1998;15(5):139-40.
74 Puavilai G, Tiewtranon V, Pensuwan S, et al. Impaired glucose tolerance in Thai adults: status of glucose tolerance after 2-year follow up. J Med Assoc Thai. Mar. 1987;70(Suppl 2):68-76. [pmid: 3298521].
75 Motala AA, Omar MA, Gouws E. High risk of progression to NIDDM in South-African Indians with impaired glucose tolerance. Diabetes. Apr. 1993;42(4):556-63. [pmid: 8454106].
76 Motala AA, Omar MA. Evaluation of WHO and NDDG criteria for impaired glucose tolerance. Diabetes Res Clin Pract. Mar. 1994;23(2):103-9. [pmid: 8070301].
77 Motala AA, Omar MA, Gouws E. Transient impaired glucose tolerance in South African Indians does not carry a risk for progression to NIDDM. Diabetes Care. Jul. 1997;20(7):1101-7. [pmid: 9203444].
78 Schranz AG. Abnormal glucose tolerance in the Maltese. A population-based longitudinal study of the natural history of NIDDM and IGT in Malta. Diabetes Res Clin Pract. Jun 20. 1989;7(1):7-16. [pmid: 2752891].
79 Ferrannini E, Nannipieri M, Williams K, et al. Mode of Onset of Type 2 Diabetes from Normal or Impaired Glucose Tolerance. Diabetes. 2004;53(1):160-5. [pmid: 14693710].
80 Li CL, Tsai ST, Chou P. Relative role of insulin resistance and beta-cell dysfunction in the progression to type 2 diabetes--The Kinmen Study. Diabetes Res Clin Pract. Mar. 2003;59(3):225-32. [pmid: 12590020].
81 Wat NM, Lam TH, Janus ED, et al. Central obesity predicts the worsening of glycemia in southern Chinese. Int J Obes Relat Metab Disord. Dec. 2001;25(12):1789-93. [pmid: 11781759].
82 Li CL, Pan CY, Lu JM, et al. Effect of metformin on patients with impaired glucose tolerance. Diabet Med. 1999;16(6):477-81. [pmid: 10391395].
83 Keech A, Colquhoun D, Best J, et al. Secondary prevention of cardiovascular events with long-term pravastatin in patients with diabetes of impaired fasting glucose: Results from the LIPID trial. Diabetes Care. 2003;26(10):2713-21. [pmid: 14514569].
84 Rubins HB, Robins SJ, Collins D, et al. Diabetes, plasma insulin, and cardiovascular disease: subgroup analysis from the Department of Veterans Affairs high-density lipoprotein intervention trial (VA-HIT). Arch Intern Med. 2002;162(22):2597-604. [pmid: 12456232].
85 Bonora E, Kiechl S, Oberhollenzer F, et al. Impaired glucose tolerance, Type II diabetes mellitus and carotid atherosclerosis: prospective results from the Bruneck Study. Diabetologia. Feb. 2000;43(2):156-64. [pmid: 10753036].
86 Smith NL, Barzilay JI, Shaffer D, et al. Fasting and 2-hour postchallenge serum glucose measures and risk of incident cardiovascular events in the elderly. Arch Intern Med. 2002;162(2):209-16. [pmid: 11802755].
87 Kuller LH, Velentgas P, Barzilay J, et al. Diabetes mellitus: subclinical cardiovascular disease and risk of incident cardiovascular disease and all-cause mortality. Arterioscler Thromb Vasc Biol. Mar. 2000;20(3):823-9. [pmid: 10712409].
88 Wagenknecht LEZ. Diabetes and progression of carotid atherosclerosis: the insulin resistance atherosclerosis study. Arterioscler Thromb Vasc Biol. Jun 1. 2003;23(6):1035-41. [pmid: 12702517].
89 Tenenbaum A, Motro M, Fisman EZ, et al. Status of glucose metabolism in patients with heart failure secondary to coronary artery disease. Am J Cardiol. 2002;90(5):529-32. [pmid: 12208417].
90 Gokcel A, Baltali M, Tarim E, et al. Detection of insulin resistance in Turkish adults: a hospital-based study. Diabetes Obes Metab. Mar. 2003;5(2):126-30. [pmid: 12630938].
91 Fisman EZ, Motro M, Tenenbaum A, et al. Impaired fasting glucose concentrations in nondiabetic patients with ischemic heart disease: a marker for a worse prognosis. Am Heart J. Mar. 2001;141(3):485-90. [pmid: 11231448].
92 Saydah SH, Loria CM, Eberhardt MS, et al. Subclinical states of glucose intolerance and risk of death in the U.S. Diabetes Care. Mar. 2001;24(3):447-53. [pmid: 11289466].
93 Tominaga M, Eguchi H, Manaka H, et al. Impaired glucose tolerance is a risk factor for cardiovascular disease, but not impaired fasting glucose. The Funagata Diabetes Study. Diabetes Care. Jun. 1999;22(6):920-4. [pmid: 10372242].
94 van Dijk RA, Dekker JM, Nijpels G, et al. Brachial artery pulse pressure and common carotid artery diameter: mutually independent associations with mortality in subjects with a recent history of impaired glucose tolerance. Eur J Clin Invest. Sep. 2001;31(9):756-63. [pmid: 11589717].
95 Saydah SH, Loria CM, Eberhardt MS, et al. Abnormal glucose tolerance and the risk of cancer death in the United States. Am J Epidemiol. Jun 15. 2003;157(12):1092-100. [pmid: 12796045].
96 Pfeffer F, Nauck MA, Drognitz O, et al. Postoperative oral glucose tolerance and stimulated insulin secretion: a predictor of endocrine graft function more than 10 years after pancreas-kidney transplantation. Transplantation. Nov 27. 2003;76(10):1427-31. [pmid: 14657680].
97 Ito C, Maeda R, Ishida S, et al. Importance of OGTT for diagnosing diabetes mellitus based on prevalence and incidence of retinopathy. Diabetes Res Clin Pract. 2000;49(23):181-6. [pmid: 10963830].
98 Haffner SM, Valdez R, Morales PA, et al. Greater effect of glycemia on incidence of hypertension in women than in men. Diabetes Care. Oct. 1992;15(10):1277-84. [pmid: 1425089].
99 Liao D, Asberry PJ, Shofer JB, et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. Sep. 2002;25(9):1504-10. [pmid: 12196418].
100 Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343-50. [pmid: 11333990].
101 Lindi VI, Uusitupa MI, Lindstrom J, et al. Association of the Pro12Ala polymorphism in the PPAR-gamma2 gene with 3-year incidence of type 2 diabetes and body weight change in the Finnish Diabetes Prevention Study. Diabetes. Aug. 2002;51(8):2581-6. [pmid: 12145174].
102 Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527]. [pmcid: 1370926].
103 Lindstrom J, Eriksson JG, Valle TT, et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the finnish diabetes prevention study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14(7 Suppl 2):S108-S113. [pmid: 12819313].
104 Oldroyd JC, Unwin NC, White M, et al. Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001;52(1):29-43. [pmid: 11182214].
105 Weber-Hamann B, Hentschel F, Kniest A, et al. Hypercortisolemic depression is associated with increased intra-abdominal fat. Psychosomatic-Medicine. 2002;64(2):274-7. [pmid: 11914443].
106 Lehtovirta M, Forsen B, Gullstrom M, et al. Metabolic effects of metformin in patients with impaired glucose tolerance. Diabet Med. 2001;18(7):578-83. [pmid: 11553189].
107 Chiasson JL, Josse RG, Gomis R, et al. Acarbose treatment and the risk of cardiovascular disease and hypertension in patients with impaired glucose tolerance: the STOP-NIDDM trial. JAMA. 2003;290(4):486-94. [pmid: 12876091].
108 Eriksson J, Tuominen J, Valle T, et al. Aerobic endurance exercise or circuit-type resistance training for individuals with impaired glucose tolerance?. Horm Metab Res. Jan. 1998;30(1):37-41. [pmid: 9503037].
109 Uusitupa MI, Mykkanen L, Siitonen O, et al. Chromium supplementation in impaired glucose tolerance of elderly: effects on blood glucose, plasma insulin, C-peptide and lipid levels. Br J Nutr. 1992;68(1):209-16. [pmid: 1390605].
110 Nagi DK, Knowler WC, Charles MA, et al. Early and late insulin response as predictors of NIDDM in Pima Indians with impaired glucose tolerance. Diabetologia. Feb. 1995;38(2):187-92. [pmid: 7713313].
111 Rosenbloom AL, Hunt SS. Prognosis of imparied glucose tolerance in children with stress hyperglycemia, symptoms of hypoglycemia, or asymptomatic glucosuria. J Pediatr. Sep. 1982;101(3):340-4. [pmid: 7108655].
112 Solomon MP, Wilson DC, Corey M, et al. Glucose intolerance in children with cystic fibrosis. J Pediatr. Feb. 2003;142(2):128-32. [pmid: 12584532].
113 Cucinotta D, De Luca F, Gigante A, et al. No changes of insulin sensitivity in cystic fibrosis patients with different degrees of glucose tolerance: an epidemiological and longitudinal study. European Journal of Endocrinology. Mar. 1994;130(3):253-8. [pmid: 8156098].
114 Rakotoambinina B, Delaisi B, Laborde K, et al. Insulin responses to intravenous glucose and the hyperglycemic clamp in cystic fibrosis patients with different degrees of glucose tolerance. Pediatr Res. 1994;36(5):667-71. [pmid: 7877889].
115 Austin A, Kalhan SC, Orenstein D, et al. Roles of insulin resistance and beta-cell dysfunction in the pathogenesis of glucose intolerance in cystic fibrosis. J Clin Endocrinol Metab. 1994;79(1):80-5. [pmid: 8027259].
116 Cucinotta D, De Luca F, Arrigo T, et al. First-phase insulin response to intravenous glucose in cystic fibrosis patients with different degrees of glucose tolerance. J Pediatr Endocrinol. 1994;7(1):13-7. [pmid: 8186820].
117 Peraldo M, Fasulo A, Chiappini E, et al. Evaluation of glucose tolerance and insulin secretion in cystic fibrosis patients. Horm Res. 1998;49(2):65-71. [pmid: 9485173].
118 Milla CE, Warwick WJ, Moran A. Trends in pulmonary function in patients with cystic fibrosis correlate with the degree of glucose intolerance at baseline. Am J Respir Crit Care Med. Sep. 2000;162(3 Pt 1):891-5. [pmid: 10988101].
119 Garagorri JM, Rodriguez G, Ros L, et al. Early detection of impaired glucose tolerance in patients with cystic fibrosis and predisposition factors. J Pediatr Endocrinol Metab. 2001;14(1):53-60. [pmid: 11220706].
120 Arrigo T, Cucinotta D, Conti NS, et al. Longitudinal evaluation of glucose tolerance and insulin secretion in non-diabetic children and adolescents with cystic fibrosis: results of a two-year follow-up. Acta Paediatr. Mar. 1993;82(3):249-53. [pmid: 8495078].
121 Trivedi N, Mithal A, Gupta SK, et al. Reversible impairment of glucose tolerance in patients with endemic fluorosis. Diabetologia. 1993;36(9):826-8. [pmid: 8405753].
122 Haeusler G, Frisch H. Growth hormone treatment in Turner's syndrome: Short and long-term effects on metabolic parameters. Clin Endocrinol (Oxf). 1992;36(3):247-54. [pmid: 1563078].
123 Schulz B, Witt S, Hildmann W, et al. Islet cell antibodies in individuals at increased risk for IDDM. Exp Clin Endocrinol. Apr. 1984;83(2):192-8. [pmid: 6373322].
124 Gale EA. European Nicotinamide Diabetes Intervention Trial Group. Intervening before the onset of Type 1 diabetes: baseline data from the European Nicotinamide Diabetes Intervention Trial (ENDIT). Diabetologia. Mar. 2003;46(3):339-46. [pmid: 12687331].
125 Ratzman K-P, Strese J, Rjasanowski I. Prevalence of islet cell antibodies (ICA) and islet cell surface antibodies (ICSA) in children and adolescents with antecedent mumps infection. Exp Clin Endocrinol. 1984;83(2):199-202. [pmid: 6539220].
126 Rakotoambinina B, Timsit J, Deschamps I, et al. Insulin responses to intravenous glucose, intravenous arginine and a hyperglycaemic clamp in ICA-positive subjects with different degrees of glucose tolerance. Diabetes Metab. Feb. 1997;23(1):43-50. [pmid: 9059765].
127 Lorini R, Alibrandi A, Vitali L, et al. Risk of type 1 diabetes development in children with incidental hyperglycemia: A multicenter Italian study. Diabetes Care. Jul. 2001;24(7):1210-6. [pmid: 11423504].
128 Hanley AJ, McKeown-Eyssen G, Harris SB, et al. Cross-sectional and prospective associations between abdominal adiposity and proinsulin concentration. J Clin Endocrinol Metab. Jan. 2002;87(1):77-83. [pmid: 11788626].
129 Harris SB, Zinman B, Hanley A, et al. The impact of diabetes on cardiovascular risk factors and outcomes in a native Canadian population. Diabetes Res Clin Pract. 2002;55(2):165-73. [pmid: 11796183].
130 Zimmet PZ, Collins VR, Dowse GK, et al. Hyperinsulinaemia in youth is a predictor of Type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1992;35(6):534-41. [pmid: 1612226].
131 Braun B, Zimmermann MB, Kretchmer N, et al. Risk factors for diabetes and cardiovascular disease in young Asutralian Aborigines. Diabetes Care. May. 1996;19(5):472-9. [pmid: 8732712].
132 King H, Zimmet P, Raper LR, et al. The natural history of impaired glucose tolerance in the Micronesian population of Nauru: a six-year follow-up study. Diabetologia. Jan. 1984;26(1):39-43. [pmid: 6706044].
133 Silverman BL, Metzger BE, Cho NH, et al. Impaired glucose tolerance in adolescent offspring of diabetic mothers: relationship to fetal hyperinsulinism. Diabetes Care. May. 1995;18(5):611-7. [pmid: 8585997].
134 Invitti C, Guzzaloni G, Gilardini L, et al. Prevalence and concomitants of glucose intolerance in European obese children and adolescents. Diabetes Care. Jan. 2003;26(1):118-24. [pmid: 12502667].
135 Goran MI, Bergman RN, Avila Q, et al. Impaired glucose tolerance and reduced beta-cell function in overweight Latino children with a positive family history for type 2 diabetes. J Clin Endocrinol Metab. Jan. 2004;89(1):207-12. [pmid: 14715851].
136 Silverman BL, Rizzo TA, Cho NH, et al. Long-term effects of the intrauterine environment. The Northwestern University Diabetes in Pregnancy Center. Diabetes Care. Aug. 1998;21(Suppl 2):B142-B149. [pmid: 9704242].
137 Fagot-Campagna A, Saaddine JB, Flegal KM, et al. Diabetes, impaired fasting glucose, and elevated HbA1c in U.S. adolescents: the Third National Health and Nutrition Examination Survey. Diabetes Care. May. 2001;24(5):834-7. [pmid: 11347739].
138 Swai ABM, McLarty DG, Kitange HM, et al. Study in Tanzania of impaired glucose tolerance: Methodological myth?. Diabetes. 1991;40(4):516-20. [pmid: 2010053].
139 Arslanian SA, Lewy V, Danadian K, et al. Metformin therapy in obese adolescents with polycystic ovary syndrome and impaired glucose tolerance: amelioration of exaggerated adrenal response to adrenocorticotropin with reduction of insulinemia/insulin resistance. J Clin Endocrinol Metab. Apr. 2002;87(4):1555-9. [pmid: 11932281].
140 Al Lawati JA, Mohammed AJ. Diabetes in Oman: Comparison of 1997 American diabetes association classification of diabetes mellitus with 1985 WHO classification. Annals of Saudi Medicine. 2000;20(1):12-5. [pmid: 17322734].
141 Tai ES, Lim SC, Tan BY, et al. Screening for diabetes mellitus - A two-step approach in individuals with impaired fasting glucose improves detection of those at risk of complications. Diabet Med. 2000;17(11):771-5. [pmid: 11131101].
142 Smith SM, Holohan J, McAuliffe A, et al. Irish diabetes detection programme in general practice. Diabet Med. Sep. 2003;20(9):717-22. [pmid: 12925050].
143 Schmidt MI, Duncan BB, Vigo A, et al. Detection of undiagnosed diabetes and other hyperglycemia states: The atherosclerosis risk in communities study. Diabetes Care. 2003;26(5):1338-43. [pmid: 12716785].
144 Tripathy D, Carlsson M, Almgren P, et al. Insulin secretion and insulin sensitivity in relation to glucose tolerance: Lessons from the Botnia Study. Diabetes. 2000;49(6):975-80. [pmid: 10866050].
145 Barzilay JI, Spiekerman CF, Wahl PW, et al. Cardiovascular disease in older adults with glucose disorders: comparison of American Diabetes Association criteria for diabetes mellitus with WHO criteria... including commentary by Davies M. Lancet. Aug. 1999;354(9179):622-5. [pmid: 10466662].
146 Perry RC, Shankar RR, Fineberg N, et al. HbA1c measurement improves the detection of type 2 diabetes in high-risk individuals with nondiagnositc levels of fasting plasma glucose: the Early Diabetes Intervention Program (EDIP).[comment]. Diabetes Care. 2001;24(3):465-71. [pmid: 11289469].
147 de Vegt F, Dekker JM, Stehouwer CDA, et al. The 1997 American Diabetes Association criteria versus the 1985 World Health Organization criteria for the diagnosis of abnormal glucose tolerance: Poor agreement in the Hoorn Study. Diabetes Care. 1998;21(10):1686-90. [pmid: 9773731].
148 Liao D, Shofer JB, Boyko EJ, et al. Abnormal glucose tolerance and increased risk for cardiovascular disease in Japanese-Americans with normal fasting glucose. Diabetes Care. 2001;24(1):39-44. [pmid: 11194238].
149 Saydah SH, Miret M, Sung J, et al. Postchallenge hyperglycemia and mortality in a national sample of U.S. adults. Diabetes Care. Aug. 2001;24(8):1397-402. [pmid: 11473076].
150 Harris MI, Eastman RC, Cowie CC, et al. Comparison of Diabetes diagnostic categories in the U.S. population according to 1997 American Diabetes Association and 1980-1985 World Health Organization diagnostic criteria. Diabetes Care. 1997;20(12):1859-62. [pmid: 9405907].
151 Gabir MM, Hanson RL, Dabelea D, et al. Plasma glucose and prediction of microvascular disease and mortality: Evaluation of 1997 American Diabetes Association and 1999 World Health Organization criteria for diagnosis of diabetes. Diabetes Care. 2000;23(8):1113-8. [pmid: 10937507].
152 Weyer C, Bogardus C, Pratley RE. Metabolic characteristics of individuals with impaired fasting glucose and/or impaired glucose tolerance. Diabetes. Nov. 1999;48(11):2197-203. [pmid: 10535454].
153 Balkau B, Bertrais S, Ducimetiere P, et al. Is there a glycemic threshold for mortality risk?. Diabetes Care. 1999;22(5):696-9. [pmid: 10332668].
154 Hanefeld M, Temelkova-Kurktschiev T, Schaper F, et al. Impaired fasting glucose is not a risk factor for atherosclerosis. Diabet Med. Mar. 1999;16(3):212-8. [pmid: 10227566].
155 Hanefeld M, Koehler C, Fuecker K, et al. Insulin secretion and insulin sensitivity pattern is different in isolated impaired glucose tolerance and impaired fasting glucose: The risk factor in impaired glucose tolerance for atherosclerosis and diabetes study. Diabetes Care. 2003;26(3):868-74. [pmid: 12610051].
156 Lorenzo C, Okoloise M, Williams K, et al. The Metabolic Syndrome as Predictor of Type 2 Diabetes: The San Antonio Heart Study. Diabetes Care. 2003;26(11):3153-9. [pmid: 14578254].
157 Lim S-C, Tai E-S, Tan B-Y, et al. Cardiovascular risk profile in individuals with borderline glycemia: The effect of the 1997 American Diabetes Association diagnostic criteria and the 1998 World Health Organization Provisional Report. Diabetes Care. 2000;23(3):278-82. [pmid: 10868851].
158 Metcalf PA, Scragg RKR. Comparison of WHO and ADA criteria for diagnosis of glucose status in adults. Diabetes Res Clin Pract. 2000;49(23):169-80. [pmid: 10963829].
159 Anand SS, Razak F, Vuksan V, et al. Diagnostic strategies to detect glucose intolerance in a multiethnic population. Diabetes Care. Feb. 2003;26(2):290-6. [pmid: 12547851].
160 Carnevale Schianca GP, Rossi A, Sainaghi PP, et al. The significance of impaired fasting glucose versus impaired glucose tolerance: Importance of insulin secretion and resistance. Diabetes Care. 2003;26(5):1333-7. [pmid: 12716784].
161 Choi KM, Lee J, Kim DR, et al. Comparison of ADA and WHO criteria for the diagnosis of diabetes in elderly Koreans. Diabet Med. 2002;19(10):853-7. [pmid: 12358874].
162 Pablos-Velasco PL, Martinez-Martin FJ, Rodriguez-Perez F, et al. Prevalence and determinants of diabetes mellitus and glucose intolerance in a Canarian Caucasian population - comparison of the 1997 ADA and the 1985 WHO criteria. The Guia Study. Diabet Med. Mar. 2001;18(3):235-41. [pmid: 11318846].
163 Tuomilehto J, Borch-Johnsen K, Tajima N, et al. Cardiovascular risk profile assessment in glucose-intolerant Asian individuals - An evaluation of the World Health Organization two-step strategy: The DECODA Study (Diabetes Epidemiology: Collaborative Analysis of Diagnostic Criteria in Asia). Diabet Med. 2002;19(7):549-57. [pmid: 12099957].
164 Flores-Saenz JL, Trujillo-Arriaga HM, Rivas-Vilchis JF, et al. Crossover and double blind study with metformin and rosiglitazone in impaired glucose tolerance subjects. Proc West Pharmacol Soc. 2003;46:143-7. [pmid: 14699913].
165 Gokcel A, Ozsahin AK. High prevalence of diabetes in Adana, a southern province of Turkey. Diabetes Care. Nov. 2003;26(11):3031-4. [pmid: 14578235].
166 Gomez-Perez FJ, Aguilar-Salinas CA, Lopez-Alvarenga JC, et al. Lack of agreement between the World Health Organization category of impaired glucose tolerance and the American Diabetes Association category of impaired fasting glucose. Diabetes Care. Nov. 1998;21(11):1886-8. [pmid: 9802737].
167 Guerrero-Romero F, Rodriguez-Moran M. Impaired glucose tolerance is a more advanced stage of alteration in the glucose metabolism than impaired fasting glucose. J Diabetes Complications. 2001;15(1):34-7. [pmid: 11259924].
168 Jaber LA, Brown MB, Hammad A, et al. Epidemiology of diabetes among Arab Americans. Diabetes Care. Feb. 2003;26(2):308-13. [pmid: 12547854].
169 Kim SG, Yang SW, Jang AS, et al. Prevalence of diabetes mellitus in the elderly of Namwon County, South Korea. Korean J Intern Med. Sep. 2002;17(3):180-90. [pmid: 12298429].
170 Li C-L, Tsai S-T, Chou P. Comparison of the results between two diagnostic criteria by ADA and WHO among subjects with FPG 5.6–7.8 mmol/l in Kin-Hu and Kin-Chen, Kinmen, 1991-94. Diabetes Res Clin Pract. 1999;45(1):51-9. [pmid: 10499885].
171 Mannucci E, Bardini G, Ognibene A, et al. Comparison of ADA and WHO screening methods for diabetes mellitus in obese patients. Diabet Med. 1999;16(7):579-85. [pmid: 10445834].
172 Mannucci E, Ognibene A, Sposato I, et al. Fasting plasma glucose and glycated haemoglobin in the screening of diabetes and impaired glucose tolerance. Acta Diabetol. 2003;40(4):181-6. [pmid: 14740278].
173 Richard JL, Sultan A, Daures JP, et al. Diagnosis of diabetes mellitus and intermediate glucose abnormalities in obese patients based on ADA (1997) and WHO (1985) criteria. Diabet Med. Apr. 2002;19(4):292-9. [pmid: 11943000].
174 Shaw JE, Zimmet PZ, Court de, et al. Impaired fasting glucose or impaired glucose tolerance. What best predicts future diabetes in Mauritius?. Diabetes Care. Mar. 1999;22(3):399-402. [pmid: 10097917].
175 Snehalatha C, Ramachandran A, Sivasankari S, et al. Insulin secretion and action show differences in impaired fasting glucose and impaired glucose tolerance in Asian Indians. Diabetes Metab Res Rev. 2003;19(4):329-32. [pmid: 12879411].
176 Molitch ME, Fujimoto W, Hamman RF, et al. The diabetes prevention program and its global implications. J Am Soc Nephrol. Jul. 2003;14(7 Suppl 2):S103-S107. [pmid: 12819312]. [pmcid: 2560181].
177 Eriksson J, Lindstrom J, Valle T, et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42(7):793-801. [pmid: 10440120].
178 Lindstrom J, Louheranta A, Mannelin M, et al. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26(12):3230-6. [pmid: 14633807].
179 Uusitupa M, Louheranta A, Lindstrom J, et al. The Finnish Diabetes Prevention Study. Br J Nutr. 2000;83(Suppl 1):S137-S142. [pmid: 10889804].
180 Tan KCB, Wat NMS, Tam SCF, et al. C-reactive protein predicts the deterioration of glycemia in Chinese subjects with impaired glucose tolerance. Diabetes Care. 2003;26(8):2323-8. [pmid: 12882856].
181 Nijpels G, Popp-Snijders C, Kostense PJ, et al. Fasting proinsulin and 2-h post-load glucose levels predict the conversion to NIDDM in subjects with impaired glucose tolerance: the Hoorn Study. Diabetologia. Jan. 1996;39(1):113-8. [pmid: 8720611].
182 Nijpels G, Popp-Snijders C, Kostense PJ, et al. Cardiovascular risk factors prior to the development of non-insulin-dependent diabetes mellitus in persons with impaired glucose tolerance: the Hoorn Study. J Clin Epidemiol. Sep. 1997;50(9):1003-9. [pmid: 9363034].
183 van Leiden HA, Dekker JM, Moll AC, et al. Risk factors for incident retinopathy in a diabetic and nondiabetic population: The Hoorn study. Arch Ophthalmol. 2003;121(2):245-51. [pmid: 12583792].
184 Kahn SE, Leonetti DL, Prigeon RL, et al. Proinsulin levels predict the development of non-insulin-dependent diabetes mellitus (NIDDM) in Japanese-American men. Diabet Med. Sep. 1996;13(9 Suppl 6):S63-S66. [pmid: 8894485].
185 Chou P, Li CL, Wu GS, et al. Progression to type 2 diabetes among high-risk groups in Kin-Chen, Kinmen. Exploring the natural history of type 2 diabetes. Diabetes Care. Jul. 1998;21(7):1183-7. [pmid: 9653617].
186 Dowse GK, Zimmet PZ, Finch CF, et al. Decline in incidence of epidemic glucose intolerance in Nauruans: implications for the “thrifty genotype”. Am J Epidemiol. Jun 1. 1991;133(11):1093-104. [pmid: 2035513].
187 Dowse GK, Zimmet PZ, Collins VR. Insulin levels and the natural history of glucose intolerance in Nauruans. Diabetes. Oct. 1996;45(10):1367-72. [pmid: 8826973].
188 Little RR, England JD, Wiedmeyer HM, et al. Glycated haemoglobin predicts progression to diabetes mellitus in Pima Indians with impaired glucose tolerance. Diabetologia. Mar. 1994;37(3):252-6. [pmid: 8174838].
189 Narayan KM, Hanson RL, Pettitt DJ, et al. A two-step strategy for identification of high-risk subjects for a clinical trial of prevention of NIDDM. Diabetes Care. Sep. 1996;19(9):972-8. [pmid: 8875091].
190 Weyer C, Bogardus C, Pratley RE. Metabolic factors contributing to increased resting metabolic rate and decreased insulin-induced thermogenesis during the development of type 2 diabetes. Diabetes. Aug. 1999;48(8):1607-14. [pmid: 10426380].
191 Weyer C, Tataranni PA, Bogardus C, et al. Insulin resistance and insulin secretory dysfunction are independent predictors of worsening of glucose tolerance during each stage of type 2 diabetes development. Diabetes Care. Jan. 2001;24(1):89-94. [pmid: 11194248].
192 Haffner SM, Stern MP, Mitchell BD, et al. Incidence of type II diabetes in Mexican Americans predicted by fasting insulin and glucose levels, obesity, and body-fat distribution. Diabetes. Mar. 1990;39(3):283-8. [pmid: 2407581].
193 Haffner SM, Miettinen H, Gaskill SP, et al. Decreased insulin secretion and increased insulin resistance are independently related to the 7-year risk of NIDDM in Mexican-Americans. Diabetes. Dec. 1995;44(12):1386-91. [pmid: 7589843].
194 Haffner SM, Miettinen H, Stern MP. Are risk factors for conversion to NIDDM similar in high and low risk populations?. Diabetologia. Jan. 1997;40(1):62-6. [pmid: 9028719].
195 Stern MP, Morales PA, Valdez RA, et al. Predicting diabetes. Moving beyond impaired glucose tolerance. Diabetes. May. 1993;42(5):706-14. [pmid: 8482427].
196 Marshall JA, Hoag S, Shetterly S, et al. Dietary fat predicts conversion from impaired glucose tolerance to NIDDM: The San Luis Valley Diabetes Study. Diabetes Care. 1994;17(1):50-5. [pmid: 8112189].
197 Hanley AJ, McKeown-Eyssen G, Harris SB, et al. Cross-sectional and prospective associations between proinsulin and cardiovascular disease risk factors in a population experiencing rapid cultural transition.[erratum appears in Diabetes Care 2001 Oct;24(10):1851]. Diabetes Care. Jul. 2001;24(7):1240-7. [pmid: 11423509].
198 Campbell KL, Borde-Perry WC, Murtaugh KH, et al. Glucose tolerance and cardiovascular risk in young adult African Americans. Am J Med Sci. May. 2002;323(5):231-7. [pmid: 12018664].
199 Clark CV, Mapstone R. Progression of impaired glucose tolerance to diabetes mellitus in patients with primary glaucoma and ocular hypertension. Diabet Med. 1986;3(3):226-9. [pmid: 2951174].
200 Fujishima M, Kiyohara Y, Kato I, et al. Diabetes and cardiovascular disease in a prospective population survey in Japan: The Hisayama Study. Diabetes. Jul. 1996;45(Suppl3):S14-S16. [pmid: 8674881].
201 Fujita H, Narita T, Ito S. Abnormality in urinary protein excretion in Japanese men with impaired glucose tolerance. Diabetes Care. May. 1999;22(5):823-6. [pmid: 10332689].
202 Long SD, O'Brien K, MacDonald KG Jr., et al. Weight loss in severely obese subjects prevents the progression of impaired glucose tolerance to type II diabetes. A longitudinal interventional study. Diabetes Care. May. 1994;17(5):372-5. [pmid: 8062602].
203 Messina MF, Lombardo F, Meo A, et al. Three-year prospective evaluation of glucose tolerance, beta-cell function and peripheral insulin sensitivity in non-diabetic patients with thalassemia major. J Endocrinol Invest. Jun. 2002;25(6):497-501. [pmid: 12109619].
204 Mykkanen L, Kuusisto J, Pyorala K, et al. Cardiovascular disease risk factors as predictors of type 2 (non-insulin-dependent) diabetes mellitus in elderly subjects. Diabetologia. Jun. 1993;36(6):553-9. [pmid: 8335178].
205 Oohashi H, Mihara T, Hirata Y. Prospective follow-up study of diabetic retinopathy in Japanese subjects showing impaired glucose tolerance. J Med Assoc Thai. Mar. 1987;70(Suppl 2):144-8. [pmid: 3598423].
206 Racette SB, Weiss EP, Obert KA, et al. Modest lifestyle intervention and glucose tolerance in obese African Americans. Obes Res. Jun. 2001;9(6):348-55. [pmid: 11399781].
207 Ramachandran A, Snehalatha C, Naik RA, et al. Significance of impaired glucose tolerance in an Asian Indian population: a follow-up study. Diabetes Res Clin Pract. Jun. 1986;2(3):173-8. [pmid: 3527626].
208 Van Dijk RAJM, Nijpels G, Twisk JWR, et al. Change in common carotid artery diameter, distensibility and compliance in subjects with a recent history of impaired glucose tolerance: A 3-year follow-up study. J Hypertens. 2000;18(3):293-300. [pmid: 10726716].
209 Wong M-S, Gu K, Heng D, et al. The Singapore Impaired Glucose Tolerance Follow-Up Study: Does the ticking clock go backward as well as forward?. Diabetes Care. 2003;26(11):3024-30. [pmid: 14578234].
210 Yamanouchi T, Inoue T, Ogata E, et al. Post-load glucose measurements in oral glucose tolerance tests correlate well with 1,5-anhydroglucitol, an indicator of overall glycaemic state, in subjects with impaired glucose tolerance. Clin Sci (Colch ). Sep. 2001;101(3):227-33. [pmid: 11524039].
211 Wei M, Gibbons LW, Mitchell TL, et al. The association between cardiorespiratory fitness and impaired fasting glucose and type 2 diabetes mellitus in men.[erratum appears in Ann Intern Med 1999 Sep 7;131(5):394]. Annals of Internal Medicine. Jan. 1999;130(2):89-96. [pmid: 10068380].
212 Dinneen SF, Maldonado D, III, Leibson CL, et al. Effects of changing diagnostic criteria on the risk of developing diabetes. Diabetes Care. Sep. 1998;21(9):1408-13. [pmid: 9727885].
213 Shimizu S, Kawata Y, Kawakami N, et al. Effects of changes in obesity and exercise on the development of diabetes and return to normal fasting plasma glucose levels at one-year follow-up in middle-aged subjects with impaired fasting glucose. Environmental Health & Preventive Medicine. 2001;6(2):127-31.
214 Ma S, Cutter J, Tan CE, et al. Associations of diabetes mellitus and ethnicity with mortality in a multiethnic Asian population: data from the 1992 Singapore National Health Survey. Am J Epidemiol. Sep 15. 2003;158(6):543-52. [pmid: 12965880].
215 Shaw JE, Zimmet PZ, Hodge AM, et al. Impaired fasting glucose: How low should it go?. Diabetes Care. 2000;23(1):34-9. [pmid: 10857965].
216 Diabetes Prevention Program Research Group. Effects of withdrawal from metformin on the development of diabetes in the diabetes prevention program. Diabetes Care. 2003;26(4):977-80. [pmid: 12663559]. [pmcid: 1360737].
217 Arslanian SA, Lewy VD, Danadian K. Glucose intolerance in obese adolescents with polycystic ovary syndrome: Roles of insulin resistance and beta-cell dysfunction and risk of cardiovascular disease. J Clin Endocrinol Metab. 2001;86(1):66-71. [pmid: 11231980].
218 Neufeld ND, Raffel LJ, Landon C, et al. Early presentation of type 2 diabetes in Mexican-American youth. Diabetes Care. Jan. 1998;21(1):80-6. [pmid: 9538974].
219 Stahl M, Brandslund I, Jorgensen LGM, et al. Can capillary whole blood glucose and venous plasma glucose measurements be used interchangeably in diagnosis of diabetes mellitus?. Scand J Clin Lab Invest. 2002;62(2):159-66. [pmid: 12004932].
220 Colagiuri S, Sandbaek A, Carstensen B, et al. Comparability of venous and capillary glucose measurements in blood. Diabet Med. Nov. 2003;20(11):953-6. [pmid: 14632723].
221 Fraser GC. Biological variation: from principles to practice. Washington: AACC press; 2001.
222 Stahl M, Jorgensen LG, Hyltoft PP, et al. Optimization of preanalytical conditions and analysis of plasma glucose. 1. Impact of the new WHO and ADA recommendations on diagnosis of diabetes mellitus. Scand J Clin Lab Invest. May. 2001;61(3):169-79. [pmid: 11386604].
223 Shapiro ET, Polonsky KS, Copinschi G, et al. Nocturnal elevation of glucose levels during fasting in noninsulin-dependent diabetes. J Clin Endocrinol Metab. Feb. 1991;72(2):444-54. [pmid: 1991813].
224 Jorgensen LG, Stahl M, Brandslund I, et al. Plasma glucose reference interval in a low-risk population. 2. Impact of the new WHO and ADA recommendations on the diagnosis of diabetes mellitus. Scand J Clin Lab Invest. May. 2001;61(3):181-90. [pmid: 11386605].
225 Westgard JO. Cooking the books: is it happening in lab error budgets? Nothing but the truth about quality. Madison, WI: Westgard QC; 2004.
226 Widjaja A, Morris RJ, Levy JC, et al. Within- and between-subject variation in commonly measured anthropometric and biochemical variables. Clin Chem. 1999;45(4):561-6. [pmid: 10102917].
227 Buse JB, Ahroni JH, Bakris GL. Summary of revisions for the 2004 clinical practice recommendations. Diabetes Care. 2004;27:S3-S10.
228 Lyon AW, Larsen ET, Edwards AL. The impact of new guidelines for glucose tolerance testing on clinical practice and laboratory services. CMAJ. Oct 26. 2004;171(9):1067-9. [pmid: 15505270]. [pmcid: 526333].