# Acknowledgments

We are grateful to the following individuals for their contributions throughout the course of developing this report: Emily Booker, Jessica Cheeseman, Roxanne Cheeseman, Laurie Cocking, Angela Eady, Eileen Estrabillo, Connie Freeborn, Mary Gauld, Susan Hanna, Dorothy Kendry, Helen Massfeller, Rob Stevens, members of the TEP, representatives from the ACP, the AACP and from AHRQ.

We are also thankful to Dr. Stephen D. Walter for his statistical consultation, specifically for the analysis of the prognosis section.