# Discussion

This systematic review evaluates the evidence for three major questions on the diagnosis, prognosis, and treatment of IFG and IGT.

## Diagnosis

An accurate diagnosis of DM is required as the consequences for the individual are considerable and lifelong. The diagnosis of IFG or IGT does not carry with it the same implications as DM, but these categories are being used as risk indicators for future DM and/or CVD.

It is important to review briefly the origin and rationale of the diagnostic criteria used for the various categories of glycemia. Frequency distribution studies for glucose demonstrate skewed or bimodal distributions (Figure 21). The center point between the two subpopulations in the bimodal distribution is the cut point above which DM is defined (7.8 mmol/L and 11.0 mmol/L for FPG and 2-hr PG, respectively). However, the proportion of subjects classified as DM by the 2-hr PG exceeds that of the FPG cut-point. In order to make these proportions equal, an FPG cut point for DM of 7.0 mmol/L was chosen. The risk for retinopathy, the most specific complication of DM, shows a sharp inflection at this point. The upper cut point for normal glucose metabolism is arbitrarily defined as concentrations below which there does not appear to be a risk for microvascular complications (6.1 mmol/L). This leaves a zone between normal glucose metabolism and DM termed impaired glucose metabolism (IFG or IGT).

Figure 21. Schematic diagrams (not to scale) for frequency distributions of a) 2-hr plasma glucose, and b) fasting plasma glucose

For both curves the shaded areas represent the current glucose concentration range for IGT (7.8 - 11.0 mmol/L) and IFG (5.6 - 6.9 mmol/L) diagnosis.

The problem with these arbitrary classifications is that test reproducibility is poor, particularly for IGT and IFG. Knowledge of the poor reproducibility for IGT and IFG encourages repeat testing and adds to the uncertainty and confusion of the diagnosis when results are different. Also, patients classified as IFG or IGT may revert to apparently normal glucose metabolism; and, in fact, a large proportion of patients do. This effect may in part be explained by variability in glucose measurement and the cut-offs chosen on the frequency distribution curve. Subjects classified as IFG or IGT may have values anywhere within the criteria used to define these categories. They may be at the low end or at the high end of the curve but are still grouped together. The frequency distribution of glucose values within this range is greater at the low end of the range and less at the high end of the range. Therefore, subjects with low glucose concentrations will have a higher probability of changing classification from IGT to NGT than subjects with higher glucose concentrations.

### Reproducibility of IFG and IGT

This review examined the problem with reproducibility for IGT and IFG. Four studies published after 1979 fulfilled the inclusion criteria of repeat testing within eight weeks using a venous plasma sample. The rationale for using these inclusion criteria was to reduce the variability in diagnostic criteria among different sample types. ^219,^ ^220^ Glucose measurement using capillary blood is not interchangeable with glucose measurement using plasma. ^219^ There are variable and unpredictable differences that cannot be resolved by conventional formulas and are sufficiently large to lead to misclassifications of glucose status. ^220^ The eight-week repeat time interval was selected, based on expert opinion, to avoid any physiological changes that could affect glucose homeostasis over a longer period of time (e.g., diet and exercise). The observed reproducibility for both IGT and IFG classifications in these studies was roughly 50%. IFG reproducibility (51% and 64%) was only slightly better than IGT reproducibility (33%, 44%, 47%, and 48%), which was somewhat poorer than DM reproducibility (69% and 59% for FPG and 2-hr PG, respectively). ^33^ Kappa coefficients were also calculated to express the agreement between IFG and IGT categorizations using the results of test one compared to the results of test two. The kappa coefficients were 0.04, 0.38, 0.42, and 0.56 for the IGT category and 0.22 and 0.44 for the IFG category. These kappa coefficients are quite low and overall indicate fair agreement. The variation in reproducibility among these studies may be a function of the population characteristics. For example, reproducibility of IFG compared to IGT in the Ko study, ^33^ a random sample of healthy working Hong Kong Chinese participants, was higher (64% and 44%, respectively) than in de Vegt's study, ^30^ an older Caucasian Dutch population that excluded participants with known DM (47% and 51%, respectively).

Although population type may help explain the variation among studies, it does not explain the sources of variation within a study. The uncertainty in glucose measurement can be estimated by considering all possible variables. Three categories of variables characterize the uncertainty and are expressed as coefficients of variation (CV = mean/SD * 100%). They are pre-analytical variation, biological variation, and analytical variation (CV_A_). Biological variation, also called physiological variation, can be further divided into the variation occurring within an individual (CV_I_) and the variation occurring between individuals (CV_G_). These concepts of variation have been thoroughly described in Fraser's book Biological Variation: From Principles to Practice. ^221^

The potential factors contributing to the variation and poor reproducibility were not assessed for this review but are fundamental for explaining the results obtained from this review. As described above, the sources of variation include pre-analytical, biological, and analytical variation. Pre-analytical variation is often considered to be part of biological variation because it is difficult to quantify pre-analytical variation separately from biological variation. Furthermore, the pre-analytical component of variation is considered to be negligible under optimal conditions. The optimal conditions were recently investigated and the following recommendations made. ^222^ Patients should be instructed to fast for a minimum of eight hours, refrain from smoking and heavy exercise within two hours of sample collection, and rest in a sitting position for a minimum of 15 minutes. The blood sample is best taken in a tube containing heparin as the anticoagulant and sodium fluoride as a glycolytic inhibitor between 6:30 am and 9:00 am and placed immediately on ice water for a maximum time of one hour. Plasma should be separated within one hour by centrifugation at a minimum of 1000xg for 10 minutes, after which the sample is stable for 48 hours at ambient temperature (22^o^C). The evidence for the recommendation of these sampling criteria comes from several supporting studies. One study demonstrated diurnal variation with a difference in glucose concentration by as much as 10% (highest in the morning). ^223^ Increased FPG is also associated with increased BMI ≥ 27 kg/m^2^, increasing age, and male sex. ^224^

Studies to determine biological variation are most often done in controlled settings on normal individuals, thereby minimizing pre-analytical variation. In large population-based studies, however, variation in how the pretest instructions were followed is largely unknown and difficult to ascertain. Did participants actually fast for as long as they said, refrain from anything but water, and refrain from any drugs that might alter glucose metabolism? Other variables, such as time of day and stress, are not usually considered, but they have been shown to alter glucose concentration. Glucose concentration also increases with age, but the diagnostic criteria do not take this into consideration. The estimates of biological variation are limited to the studies in which they were obtained. These estimates may vary among different populations (e.g., age, sex, and ethnicity) as well as in the presence of disease. They are at best approximations and may not be appropriate for all situations or individuals. Due to these reasons, biological variation is often overlooked when assessing diagnostic tests.

The quantification of analytical imprecision and bias of the glucose test methods is, however, much easier to do and is a lot less variable. Data from laboratory proficiency surveys and peer-comparison programs show CVs of 3% to 5% for total-group method (similar analytical methodology) and 2%, typically, for individual methods. Excellent laboratories may achieve a CV_A_ of 1%. ^225^ Analytical variation is a small component of the total variation of glucose measurements.

All three components of variation can be taken together to obtain an estimate of measurement uncertainty in an individual test result. The magnitude of the variation will determine the probability that an individual's glycemic classification (normal, impaired, or diabetic) will be the same when measured again. The reference change value (RCV) estimates the probability that a significant change has occurred in serial measurements. The RCV calculation considers the total CV determined by calculating the sum of the squares of analytical variation (CV_A_) and individual biological variation (CV_I_) such that RCV = 2^½^ * Z * (CV_A_ ^2^ + CV_I_ ^2^)^½^. The number 2 accounts for both samples being compared, and Z is a multiplier or standard normal deviates and relates to the probability. Conventional Z-scores are 1.96 and 2.58 corresponding to 95% and 99% probability, respectively. The RCVs for FPG and 2-hr PG can be calculated if CV_A_ and CV_I_ data are available. There was only one study in this systematic review with this data. ^29^ using a Z score of 1.96 the RCV for FPG was 17.9% or RCV = 2^½^ * 1.96 * (1.4^2^ + 6.3^2^) ^½^. For 2-hr PG, the RCV = 2^½^ * 1.96 * (1.4^2^ + 16.6^2^) ^½^ or 46. 2%. Therefore, the difference between two FPGs would need to be greater than 17.9% to be significantly different. A 95% probability can be described as, to prompt, suggest, advise, and propose. Although other probabilities may fulfill or better represent the clinical need. For example, if the probability sought were to hint, indicate or draw attention to, then a Z score of 80 % would be preferable. Another example, considers two repeat FPG concentrations of 6.9 mmol/L and 6.0 mmol/L. The difference between them is 15%. Since this value is less than 17.9%, there is a 95% probability there is no difference between these two glucose results. Another way of expressing this is the 95% CIs which around 6.9 mmol/L (5.7 to 8.1 mmol/L) and 6.0 mmol/L (4.9 to 7.1 mmol/L) overlap. A lower RCV would increase the sensitivity to change, or reduce the variation noise, and could be achieved if the CV_A_ or CV_I_ are lowered. Values for CV_I_ differ somewhat in the literature and depend on the type of participants selected and how closely the pretest protocol was followed. The lowest biological variability for fasting glucose was reported in a study of 12 young, healthy participants where there was strict adherence to a pretest protocol. ^226^ The FPG CV_I_ in this study was 4.8%. If this value is used along with an intra-laboratory imprecision of 1%, the RCV can be reduced to 13.6%. This is the very best or lowest amount of variation possible for an FPG measurement at a 95% probability. The biological variation values used here are for populations and appear to be slightly different among individual diagnostic categories of glycemia. ^29^ There is more biological variation in subjects classified as IFG (5.9%) or DM (7.0%) compared to NFG (4.6%), but the opposite is seen for subjects classified as IGT (14.9%) or DM (12.6%) compared to NGT (16.3%). ^29^

Repeating a test will also reduce variation. The amount the variation will be reduced by a factor of n^½^. For example, in the best case, if two FPG tests are done the RCV will be reduced by a factor of 2^½^ , giving a new RCV of 9.6%. More realistically, the RCV will only be reduced to 12.8% when population CVs are used. ^29^ Repeat testing will reduce the deviation around the homeostatic set-point and have a much greater effect for 2-hr PG than FPG because of the higher individual variation for 2-hr PG. In the above calculation, the 2-hr PG RCV would be reduced to 33%, albeit still about three times higher than for repeat FPG testing.

The new clinical practice recommendations of the American Diabetes Association (ADA) redefined the diagnostic criteria for DM. ^227^ The IFG category has now been widened by 0.5 mmol/L: 5.6 to 6.9 mmol/L from 6.1 to 6.9 mmol/L. This new range will positively impact IFG category reproducibility. There will be a slight increase in reproducibility because of the larger range of glucose values that determine this category.

The changes in criteria were made for fasting glucose only. No changes were made to the 2-hr PG OGTT criteria. Normoglycemia has been lowered to a glucose value of < 5.6 mmol/L from < 6.1 mmol/L. Hence, the IFG category has now been widened by 0.5 mmol/L: 5.6 to 6.9 mmol/L. Diagnosis of DM remains at ≤ 7.0 mmol/L. The new term “prediabetes” was introduced and refers to patients with IFG and/or IGT. This term indicates that patients with this diagnosis have a relatively high risk for the development of DM.

The new recommendations for the diagnosis of IFG will result in an increase in the number of patients diagnosed as IFG. Patients with a fasting glucose value ≥ 5.6 mmol/L, but less than 6.1 mmol/L, will now also be classified as IFG. Previously, these patients would have been categorized as normoglycemia. The impact of this will no doubt be an increase in repeat FPG tests and more OGTTs to confirm the abnormal result. If the ADA guidelines are followed closely, no repeat FPG or OGTT will be done on patients with glucose values < 7.0 mmol/L unless there is a high suspicion for DM. Repeat testing (FPG or OGTT) is only indicated for confirmation of DM and not for confirmation of IFG or IGT. However, the suggestion for patients classified as IFG on the first test is to do an OGTT to determine if they also have IGT. Also, since the diagnostic glucose range for IFG has been changed, there will be slightly better reproducibility in IFG categorization.

The actual increase in the number of OGTTs performed on patients with IFG on the first test will ultimately depend on the physician's suspicion that a patient may be at risk for DM and their comfort level with a single test result. The potential increase in OGTTs was recently estimated using glucose data from a large regional laboratory. ^228^ A frequency plot of all fasting glucose results showed that 14.8% of FPG concentrations were between 5.6 and 6.9 mmol/L. This percentage is similar to the reference distribution for FPG. A conservative estimate of the potential increase in number of OGTTs based on this percentage is 10-fold, and represents a huge increased economical burden on health care resources.

### Comparison of IFG and IGT Diagnosis

This review also compared the proportion of participants classified according to the various criteria and categories for IGT and IFG with one test. No confirmation testing was done. As expected, the changing criteria for IGT (FPG < 7.8 mmol/L to < 7.0 mmol/L) decreased the number of participants classified as IGT, although the proportion varied among the different studies (a function of population type). A change of criteria from 7.8 mmol/L to 7.0 mmol/L had greater impact in a high-risk population (previous gestational DM) than in large population-based studies. A change to the lower cut point of 6.1 mmol/L saw a large negative reduction in IGT for a Caucasian population with no DM compared to the general population of Pima Indians. The population effect was also observed when study data were plotted as a function of IFG or IGT category (Figure 3). In most studies that involved high-risk participants, the proportion of IFG was greater than that of IGT. Overall, there was a wide variation in the proportion of participants classified as IGT (2-hr PG), IGT (FPG and 2-hr PG), I-IGT, IFG, I-IFG, and IGT and IFG (Table 7). Furthermore, comparisons among these various categories were statistically significant except for I-IGT versus IFG and I-IFG versus IGT and IFG. This comparison highlights that the proportion of study subjects differs depending on which criteria are used to classify impaired glucose status. It also exemplifies the importance of clearly distinguishing categories as this can affect the conclusions from prognosis and treatment data. One of the most problematical aspects for this review was in the differentiation of what each study called IFG or IGT. The term IGT was used liberally to refer to the statistically different categories of IGT diagnosed with a) only the 2-hr PG criteria, b) both FPG and the 2h PG criteria and c) I-IGT criteria. A similar but not as profound a problem was seen for IFG and I-IFG nomenclature.

The clinical significance of the difference between IGT diagnosis and IFG diagnosis is not clearly understood, but either condition is a risk factor for DM and its associated outcomes such as CVD. The oral glucose tolerance test and its 2-hr PG value are described as a marker for early insulin resistance, which is a risk for CVD, whereas FPG value is considered a marker of impaired insulin secretion and suppression of hepatic glucose output.

## Prognosis

The results of this systematic review clearly show that IGT, IFG, I-IGT, I-IFG, and combined IGT and IFG are strong risk factors for future DM. All of the dysglycemic classifications are also modest risk factors for various cardiovascular outcomes.

Most of the relevant data came from epidemiological studies that determined the glycemic status of participants at baseline and follow-up on the basis of a single glucose tolerance test. ^20^ As this test has poor reproducibility, many participants may have been misclassified at baseline or at follow-up. The misclassification can occur in either direction. The observation that the results of the placebo arm data from RCTs (some of which did repeat testing) and the epidemiological studies are concordant may suggest that such misclassification was not an important determinant of the findings in this systematic review.

### Progression to DM

The risk for progression to DM for patients within the five dysglycemic categories was consistent across different countries, study populations, study durations, and study designs. There was no evidence of a difference in risk among people with IGT, IFG, I-IGT, or I-IFG. Indeed, the meta-analysis of these groups reveals that the relative risks varied from 4.7 to 7.24 and the CIs for the pooled estimates of risk substantially overlapped. However, the three studies on people with both IFG and IGT yielded a much larger estimate of 12.21 (95% CI 4.32 to 20.10). From a clinical perspective, this is not surprising as individuals within this category likely have a more advanced metabolic disturbance than individuals in any of the other groups.

The estimate of AR was not influenced by study duration, population, or dysglycemic group. The AR varied from 53% to 97%, suggesting that for those with IFG or IGT, up to 97% of their risk for DM could potentially be prevented if the IFG or IGT were successfully treated or eliminated. It also suggests that much of the risk for progressing to DM is associated with the exposure to IFG or IGT rather than to other factors. Thus any public health initiative to prevent DM in society or in a subgroup of individuals necessarily becomes an initiative to treat IFG or IGT. Since DM is associated with progression to several other health outcomes (see analytic framework), such as CVD and retinopathy, both the prevention of DM and the treatment of IFG and IGT may have far reaching health benefits.

### Risk for Reversion to NFG or NGT

This review also showed that up to 53% of dysglycemic individuals may revert to “normoglycemia” within one year. This observation does not mean that they have become metabolically normal. First, the poor reproducibility of glucose testing means that this observation may have occurred by chance alone. Second, there is no real biological difference between an individual whose 2-hour plasma glucose is 7.8 mmol/L on one occasion and 7.7 mmol/L on a repeat occasion, despite the fact that she would have been classified as IGT on the first occasion and normal on the second occasion. Indeed, these two numbers are likely just different estimates of the true value, as they are within the measurement and reproducibility error of each other. Nevertheless, these data do suggest that at least some individuals may revert to normal. This supports recommendations to diagnose DM in a clinical (as opposed to epidemiological) setting on the basis of at least two tests on two separate days, and suggests that such a recommendation should also be applied to diagnosing IGT and IFG.

### Risk for Nonfatal CVD Outcomes

In the six papers evaluating nonfatal outcomes, CVD was subdivided into atherothrombosis, non-stenotic atherosclerosis, clinical MI, PTCA (some with CABG), stroke, unstable angina, heart failure, and combinations of these (major event and any event). As only one of the included studies comprised people with IGT, the hypothesis that IGT is a stronger risk factor for nonfatal CVD than IFG could not be carefully tested. ^6^ Nevertheless, the single IGT study had higher risk estimates across all four metrics than any of the IFG studies. The largest unadjusted RR was 2.46 for the single IGT study and 1.41 for the IFG group. Within the IFG group the pooled estimates were not significant for the outcomes of PTCA/CABG and stroke and significant for the outcome of any nonfatal CVD event (RR 1.28, 95% CI 1.15 to 1.41). Similarly, the highest AR was 53% for the single IGT study and 33% for the IFG group. This metric suggests that treatment of IGT or IFG may reduce nonfatal CVD, but the impact of such an approach would be much lower than the impact on preventing DM.

### Risk for Fatal CVD Outcomes

Nine studies reported fatal CVD outcomes, which were subdivided into ischemic heart disease, cardiocerebrovascular, and CHD in some studies. These studies varied in duration from five to 18 years and included men only, women only, subjects with a previous MI, a population-based study (the NHANES II cohort), and a clinical trial (the BIP cohort). Estimates of annualized risk per 100 persons were relatively low (less than one) with the exception of one study; two studies had significant RR estimates that varied from 1.67 to 3.08. Moreover, the pooled estimates for IGT show an RR of 1.66 (95% CI 1.21 to 2.11) and for IFG are marginally non-significant for ischemic death (RR 1.27, 95% CI 01.06 to1.54) and CHD death (RR 1.25, 95% CI 0.99 to 1.51). Similar to findings in individuals with nonfatal CVD, these data suggest a greater risk associated with IGT than with IFG.

### Risk for Mortality Outcomes

In general, most studies that reported all-cause mortality outcomes had the largest sample sizes and the longest follow-up duration (up to 18 years) of all eligible studies in this systematic review. The pooled analyses supported the hypothesis that both IGT and IFG are risk factors for mortality, with a slightly higher risk for IGT (RR 1.27, 95% CI 1.06 to 1.54) than IFG (RR 1.21, 95% CI 1.05 to1.36). It is important to note that the category of all-cause mortality contains mortality due to DM. Indeed, much of the risk may be due to the embedded CV mortality risk.

## Treatment

Twenty-three reports of 14 RCTs published between 1992 and 2003 evaluated pharmacotherapeutic or behavioral interventions in adults with IFG or IGT. Duration of follow-up ranged from six months to six years. Studies involved a range (14 to 3234) of participants with mean ages from 37.5 to 70 years. The studies included subjects from Europe, North America, Australia, and Asia. The trials evaluated a range of interventions including diet and exercise, oral hypoglycemic agents (metformin, acarbose, and chromium), a statin (pravastatin), and an ACE inhibitor (enalapril).

### Prevention of DM: Lifestyle Interventions

This systematic review clearly demonstrates that DM can be prevented or delayed with lifestyle modification. Six RCTs have now evaluated the effect of lifestyle interventions on the risk for progressing to DM, or reverting to NGT, in individuals with IGT. All but one of the five studies that evaluated a combined diet and exercise program found significant benefits. The only trial to show no effect of a combined diet and exercise intervention was of short duration and followed patients for only six months, whereas other trials had follow-up durations of two to six years.

Dietary intervention alone reduced the risk for progressing to DM in one trial but had no effect in a second study. Exercise alone has been evaluated in only one trial to date, which found a significant benefit in terms of reduced risk for progressing to DM.

For individual patients with IGT, these results indicate that making meaningful changes in dietary intake and activity levels can dramatically reduce one's risk for progressing to DM. The risk for developing DM was reduced by 31% to 55%, compared with participants in the control arms of the trials. The calculated ARDs in the risk per year for progressing to DM ranged from 1.6% to 7.1%, yielding NNT values of 14 to 62.

Two studies undertook subgroup analyses, but the DPP study provided the most detailed evaluation, though this had not been planned. The analysis demonstrated consistent benefits of combined dietary and exercise intervention regardless of age, sex, ethnic group, BMI, or baseline glucose levels.

Given these findings, and the significant complications associated with established DM, efforts to modify dietary intake and activity levels in individuals at increased risk for DM are clearly warranted. How best to implement such a recommendation, however, remains unclear and is beyond the scope of this review. Public health interventions targeting populations known to be at increased risk would seem appropriate, along with more intensive intervention for individuals especially at risk, such as obese or overweight individuals with IGT or IFG. Development and evaluation of less intensive approaches for effecting lifestyle change will also be very important.

### Prevention of DM: Pharmacotherapeutic Interventions

Only four trials to date have evaluated the effect of pharmacotherapeutic intervention on the risk for developing DM in individuals with IGT. Two of the studies, one involving acarbose and one involving metformin, demonstrated reduced rates for progression to DM with an RRR in the order of 25%. Two smaller trials with metformin that had a shorter duration of follow-up and a smaller number of participants found no significant effect of intervention on the risk for DM. The effects of pharmacological intervention on cardiovascular disease outcomes for individuals with IGT is an important topic that as yet has only been evaluated in one trial. Given this relative paucity of information, it would seem premature to recommend pharmacological intervention for the prevention of DM at this time.

## Pediatric Population

Despite the paucity of population-based studies, several cohort studies in high-risk groups suggest that IGT is a significant and potentially growing problem in the pediatric population. Indeed, larger proportions of children may have IFG/IGT than is currently recognized. It is critical to acquire an understanding of the precursors of type 2 DM development in children and youth. However, few conclusions can be made based on the current pediatric literature. The reproducibility of test results and the prognosis of IGT may differ significantly from those characteristics in adult studies. This may be particularly true in the peri-pubertal period when physiological changes in insulin sensitivity are well known. Further investigation of prevalence in children and adolescents is necessary to clarify the magnitude of the problem.

### Diagnosis

The reproducibility of the diagnosis of IGT with OGTT testing and the clinical significance of IFG versus IGT have not been widely examined in the pediatric literature. Fasting plasma glucose is recommended for the identification of Type 2 diabetes in children. In 2 studies that have compared IFG and IGT, IFG is a very insensitive test for the identification of IGT. Young age has been implicated as a predictor of poor reproducibility of OGTT results in adults, ^138^ suggesting that reproducibility of classification may be worse again in adolescents and children. However, this was not the experience in one study in children (n = 10). ^12^

Clearly, further investigation of the reliability of diagnostic criteria for IFG and IGT is warranted. Furthermore, given the importance of the prevention of type 2 DM, it may be advantageous to identify children who have disturbed glucose metabolism (insulin resistance and/or beta cell dysfunction) before they develop IFG or IGT.

### Prognosis

An understanding of how disturbed glucose metabolism progresses to IGT to type 2 DM is key to the primary prevention of DM. Currently, details of this progression are completely lacking in the pediatric population. Although IGT is present in 25% of obese children and adolescents, DM is found almost exclusively in adolescents. Furthermore, although IGT appears to be prevalent in overweight Caucasian, African-American, and Hispanic populations, type 2 DM is seen more commonly in visible minorities. These data suggest that age, pubertal status, and ethnicity may influence the progression from IGT to type 2 DM, but longitudinal studies to examine this are lacking. Family history of DM, exposure to a diabetic environment in utero, fitness and physical activity, fat distribution, and characteristics of nutritional intake may also influence the prognosis of IFG and IGT. Longitudinal studies are required to examine mid- and long-term outcomes of IGT and the determinants of outcome in multiple ethnic groups and across a broad age range. Investigation of other metabolic outcomes in children and adolescents with IFG and IGT would further improve our understanding of disturbance in health in this population.

Understanding the prognosis of IGT in children and adolescents will clarify the need for intervention and the assessment of outcome within future intervention studies.

### Treatment

A single study has described the pharmacological treatment of IGT, and no randomly controlled lifestyle intervention has been done in the pediatric age group. Although promising, the single study of the effect of metformin on IGT in 15 girls with PCOS needs to be replicated with larger sample sizes and other at-risk populations. Given the increasing rates of these disorders, research on the optimal approach to the management of these children should be a research priority. This research should compare lifestyle intervention and pharmacotherapy and use optimal methodologies for young populations. Although glycemic status is likely the key outcome variable, other metabolic disturbance and psychosocial outcomes should also be addressed.

## Limitations

The results and conclusions of this evidence report are based on the information that was available in published English-language reports. Contact with authors (or industry sponsors of drugs) could have resulted in identifying additional unpublished studies that may have reduced the likelihood of publication bias. Contact with the original authors of studies to supplement missing information from the included papers could have compensated for many of the difficulties in abstracting missing data. Our experience at the McMaster EPC suggests that the majority of authors do not respond in a timely fashion to such requests, if at all. The budget and timelines available, however, were a limiting factor to accomplishing these tasks.

Many of the citations eligible for review were longitudinal studies and, as such, had multiple publications on the same cohort with different sampling frames (time interval[s] of data analyzed) and group analyses (subgroup versus whole sample). These related studies were not independent of each other, and a representative publication (based on study quality or sample size) was selected to combine in the quantitative meta-analysis when it was possible to do so. It was also noted that related papers on the same study cohort had diverse methodological quality scores. If a citation directed us to a previous publication for further details, attempts were made to attain the cited publication, and the quality score was applied accordingly. Despite this, variations were found in the quality scores for studies on the same cohort, and this likely reflects reporting biases. It was observed that often multiple publications on the same cohort undertook different analyses with different outcomes and even different classification criteria.

Despite these limitations, this AHRQ report provides valuable insight with regards to the level of the evidence that addresses the issues of diagnosis, prognosis, and treatment of IFG or IGT identified in this systematic review.

## Summary and Conclusions

The reproducibility for both IGT and IFG categorization is poor by both observed and kappa analysis. The uncertainty in glucose measurement is large and therefore the absolute FPG and 2-hr PG measurement may be more informative than categorization into IFG and IGT, respectively. Comparison of IGT and IFG categories shows wide variation among populations. The prevalence of IGT is greater than that of IFG in almost all studies. High-risk populations have an equal or greater proportion of IFG compared to IGT diagnoses. Statistically, the epidemiological criteria (2-hr PG) result in a greater proportion of study participants being classified as IGT than if the diagnostic criteria (2-hr PG and FPG) are used. This will affect the conclusions of prognosis and possibly treatment data in population studies that use epidemiological criteria only.

IFG and IGT are clearly strong risk factors for future DM, and combined IGT and IFG is the strongest risk factor. These observations are not surprising given the fact that the diagnostic threshold for DM is just a farther point along the dysglycemic spectrum than the threshold for either IFG or IGT. Nevertheless, these large risk estimates clearly do suggest that any clinical approach directed at preventing DM should include a policy of detecting IFG and/or IGT. They do not support suggestions that measures of glucose are not necessary to detect individuals at risk for future DM. However, such a policy may be useful to reduce the number of individuals who require a glucose tolerance test.

The reviewed studies provide confirmation that IFG and/or IGT are risk factors for fatal and nonfatal CVD, and are consistent with other studies that were not eligible because plasma was not used to assay glucose levels, such as the DECODE study. ^48^ Moreover, the suggestion that IGT is a stronger risk factor for CVD than IFG is also supported by this review. This is not surprising given the fact that IGT is detected in response to stressing the physiology with a nonphysiological glucose load, thus exposing a degree of metabolic dysregulation that would not be apparent on the basis of fasting glucose levels alone.

This review also provides further evidence of the relevance of the OGTT as a diagnostic test. Despite the many shortcomings of the OGTT (reviewed herein), it detects a very high-risk group for future DM and may either need to be more accessible to clinicians or replaced by a simpler test that provides comparable predictive information. The OGTT also detects a group at risk for CVD, and if IGT is causally related to CVD, the AR estimates suggest that its treatment may reduce CVD risk by 20% to 40%.

Finally, these studies highlight the relevance of fasting and post-challenge gluco-metabolic abnormalities to clinically relevant outcomes. Intervention studies have already shown that DM can be prevented in these individuals with some interventions (as described herein). Other studies are underway to determine if aggressive treatment of IFG or IGT has cardiovascular benefits.

The following general conclusions can be made:

- Diagnosis of IFG or IGT—The reproducibility for both IGT and IFG categorization is poor. Therefore, an absolute FPG and 2-hr PG measurement may be more informative than categorization into IFG and IGT, respectively. The distribution of study participants in the IGT category varies significantly with the diagnostic criteria used. This will affect findings in epidemiological studies evaluating prognosis and treatment.
- Prognosis of IFG or IGT—Many studies consistently show that both IFG and IGT are strong risk factors for the development of DM. Fewer studies also show that they are risk factors for future CVD, all-cause mortality, and lipid disturbances.
- Treatment—There is evidence that combined diet and exercise, and drug therapy (metformin, acarbose), are effective at preventing progression to DM in IGT subjects.
- Pediatric population—Investigation of IGT and IFG in the pediatric population is extremely limited and is largely confined to descriptions of prevalence within varying populations. These studies confirm that IFG and IGT are relatively common in childhood, particularly in children who are overweight. However, no conclusions can be made relating to the reproducibility of testing for IFG or IGT, the progression to type 2 DM, or the optimal interventions for the management of IGT in childhood.

Given the rising rates of obesity in youth and the recognition that disturbed glucose metabolism and other metabolic disturbances are common in these children, further clarification of population-based prevalence and investigation to improve understanding of the diagnosis, clinical significance, and optimal management of IFG and IGT in childhood is urgently required.