# Results

The original search yielded 25,521 citations for all three questions combined. From the title and abstract screening, 1,243 articles proceeded to full-text screening. After the final eligibility screening, a total of 156 studies were abstracted for data for the diagnosis, prognosis and treatment questions and an additional 12 articles (which did not meet the criteria for the previous sections) were analyzed for the pediatric population alone. Figure 2 details the number of eligible studies for each research question. The results of the review are presented in this chapter according to the four main areas of investigation: diagnosis, prognosis, treatment, and pediatrics.

Figure 2. Flow diagram showing the numbers of included and excluded articles

## Diagnosis

### General Characteristics of the Diagnosis Studies

Fifty-six reports describing 53 unique studies provided data on the reproducibility of repeat testing of FPG or OGTT, comparison of IGT diagnosis by different criteria, and the relationship between IGT and IFG diagnosis in the same population. General characteristics of these studies can be found in Table 4.

Table 4 General study characteristics: Diagnosis

Study group | Author, Year, Country | Study type | Duration | N | Diagnostic Risk Group | Diagnostic criteria | Age, y | Population
| | | | | | | mean (range)
1991 National Diabetes Survey | Al-Lawati ^140^ , 2000, Omani | CS | NA | 4682 | - | WHO 85 | (20+) | -
| | | | | | ADA 97
1992 SNHS | Tai ^141^ , 2000, SG | CS | NA | | - | WHO 85 | (18–69) | Chinese, Malay, Indian
| | | | | | ADA 97
ADSS | Smith ^142^ , 2003, IE | CS | 18 m | 3554 | - | WHO 98 | (40–70+) | -
| | | | | | ADA 97
ARIC | Schmidt ^143^ , 2003, US | CS | 2 y | 8286 | - | Not specified | (53–75) | White, Black
AusDiab | Dunstan ^46^ , 2002, AU | CS | NA | | - | WHO 99 | (25+) | Aboriginal
Botnia | Tripathy ^144^ , 2000, FI | CS | NA | 5396 | - | WHO 98 | 55.8 | Type 2 diabetic patients and their families
CHS | Barzilay ^145^ , 1999, US | PC | 8 y | 4515 | IGT; IFG | WHO 85 | 73 | White, Black. Ambulatory subjects with no severe illness
| | | | | | ADA 97 | (65+)
DECODA | Qiao ^37^ , 2000, BD* | CS | NA | 17666 | - | WHO 85, 99 | (30–90) | Indian, Chinese, Taiwanese, Japanese, Malay, Bengali.
| | | | | | ADA 97
EDIP | Perry ^146^ , 2001, US | CS | NA | | - | WHO 85 | 54 | White, Black, Hispanic, Asian
| | | | | | ADA 99
Hoorn | De Vegt ^147^ , 1998, NL | CS | NA | 2378 | - | WHO 85 | 61.5 | White
| | | | | | ADA 97 | (50–75)
Hoorn | De Vegt ^30^ , 2000, NL | PC | 9 y | 2468 | IGT; IFG | WHO 85 | 61.7 | White. Elderly population
| | | | | | ADA 97
Hoorn | De Vegt ^35^ , 2001, NL | PC | 6.4 y | 1342 | IGT; I-IGT; IFG; I-IFG; IGT-IFG | WHO 85, 99 | (50–75) | White (Dutch). Elderly population
| | | | | | ADA 97
Hoorn | Mooy ^29^ , 1996, NL | CS | 2–6w | 9797 | - | WHO 85 | (50–74) | White
JACDS | Liao ^148^ , 2001, US | CS | NA | 596 | - | WHO 85, 98 | (35–75) | Japanese-American
| | | | | | ADA 97
Kinmen | Li ^80^ , 2003, TW | PC | 5 y | 644 | I-IGT; I-IFG; IGT-IFG | WHO 99 | (30+) | -
NHANES II | Saydah ^149^ , 2001, US | PC | 14 y | 3092 | IGT; I-IFG | WHO 98 | (30–74) | White, non-White.
| | | | | | ADA 97
NHANES III | Harris ^150^ , 1997, US | CS | NA | | - | WHO 85 | (40–74) | Subjects from NHANES III
| | | | | | ADA 97
Pima | Gabir ^36^ , 2000a, US | PC | 5,10 y | 5984 | IGT; IFG; IGT-IFG | WHO 85, 99 | (15+) | Pima Indians
| Gabir ^151^ , 2000b, US | | | | | ADA 97
Pima | Weyer ^152^ , 1999, US | CS | NA | 434 | - | WHO 85 | NR | Pima Indians
| | | | | | ADA 97
PPS | Balkau ^43^ , 2002, | PC | 17 y | 7018 | IGT; IFG | Not specified | (44–55) | Paris civil service employees
| Balkau ^153^ , 1999 FR
RIAD | Hanefeld ^154^ , 1999, DE | CCT | NR | 208 | - | WHO 98 | (40–70) | European. No known diabetes or medication use
| | | | | | ADA 97
RIAD | Hanefeld ^155^ , 2003, DE | CS | NA | | - | WHO 99 | (40–70) | No medication use
SAHS | Lorenzo ^156^ , 2003, US | CS | 8 y | 1539 | - | WHO 99 | (25–68) | Mexican American, non-Hispanic White
SNHS | Lim ^157^ , 2000, SG | CS | NA | 591 | - | WHO 98 | (18–69) | Chinese, Malay, Asian, Indian.
| | | | | | ADA 97
Workforce Diabetes Survey | Metcalf ^158^ , 2000, NZ | CS | ~2y | 5816 | - | WHO 85, 98 | 48 | European, Maori Pacific Islands, Asian, Samoan, Rangar, Niuean, Cook Islands
| | | | | | ADA 97 | (22–78)
None | Amoah ^45^ , 2002, GH | CS | NA | 4636 | - | WHO 85, 98 | 44.2 | No prior history of diabetes. From urban and rural communities
| | | | | | ADA 97, 2000 | (25–55+)
None | Anand ^159^ , 2003, CA | PC | 22 m | | - | WHO 98 | NR | South Asian, Chinese, European.
| | | | | | ADA 97
None | Carnevale Schianca ^160^ , 2003, IT | CS | 5y | 398 | - | WHO 98 | (17–66) | -
| | | | | | ADA 97
None | Choi ^161^ , 2002, KR | CS | NA | 1456 | - | WHO 98 | (60–92) | Korean. Urban community
| | | | | | ADA 97
None | Croxson ^42^ , SCM, GB | RC | NA | 599 | - | WHO 85 | (9–89) | -
| | | | | | ADA 97
None | de Pablos-Velasco ^162^ , 2001, ES | CS | NA | 691 | - | WHO 85 | (30+) | White. Guia population
| | | | | | ADA 97
None | DECODE ^163^ , 2002; IN* | CS | NA | 17512 | - | WHO 99 | (30–89) | Asian
None | Drzewoski ^47^ , 2001, PL | PC | 9 y | 1360 | - | WHO 85, 99 | 65 | All white. Subjects at risk for glucose intolerance
| | | | | | ADA 97
None | Farrer ^31^ , 1995, GB | PC | 1 y | 353 | - | WHO 85 | (56–61) | Patients had CABG surgery
None | Flores-Saenz ^164^ , 2003, MX | RCT | 9 m | 40 | I-IGT, IFG | Not specified | (20–65) | Volunteers. All had IGT and no concurrent illnesses
None | Gatling ^41^ , 2001, GB | PC | 2 y | 1864 | - | WHO 85 | 56.1 | Non-pregnant individuals
| | | | | | | (15–95)
None | Gokcel ^165^ , 2003, TR | CS | NA | 1637 | IGT, I-IFG | WHO 99 | (20–79) | Non-pregnant individuals
None | Gomez-Perez ^166^ , 1998, MX | CS | 5 m | | - | WHO 80, 85 | NR | -
| | | | | | ADA 97
None | Guerrero-Romero ^167^ , 2001, MX | CS | NA | 240 | I-IGT, I-IFG | ADA 99 | 42.1 | Men and non-pregnant women
| | | | | | | (30–64)
None | Jaber ^168^ , 2003, US | CS | NA | 542 | - | WHO 98 | 38 | Lebanese, Yemenis, Iraqis, Palestinian, Arab Americans. Non-pregnant adults
| | | | | | ADA 97 | (20–75)
None | Kim ^169^ , 2002, KR | CS | 4 m | 665 | - | WHO 85 | 62 | -
| | | | | | ADA 97 | (40+)
None | Ko ^33^ , 1998, HK | CS | NA | 1,513 | - | WHO 85 | 37.5 | Population based survey in Hong Kong
| | | | | | ADA 97 | (18–66)
None | Ko ^32^ , 1998, CN | CS | 6 w | 212 | - | WHO 85 | (30–65) | Hong Kong Chinese. No diabetes
None | Kousta ^38^ , 1999, GB | CS | 11 m | 165 | - | WHO 85, 98 | 36.6 | Women. European, South Asian, Afro-Carribean. Previous GDM
| | | | | | ADA 97
None | Li ^170^ , 1999, TW | CS | 3 y | 1456 | - | WHO 85 | (30+) | Chinese, All considered at high risk for DM
| Li ^44^ , 2002, TW | | | | | ADA 97
| | | | | | WHO 99
None | Mannucci ^171^ , 1999, IT | PC | 10 m | 528 | - | WHO 98 | 45.2 | Obese
| | | | | | ADA 97
None | Mannucci ^172^ , 2003, IT | CS | NA | 1215 | - | WHO 98 | (30–70)
None | Puvilai ^40^ , 1999, TH | NC | NA | 1051 | IGT; I-IGT; IFG; IGT-IFG | WHO 85, 98 | 50.0
| | | | | | ADA 97
None | Richard ^173^ , 2002, FR | PC | 3.5 | 1149 | - | WHO 85 | 49 | Obese
| | | | | | ADA 97 | (15–84)
None | Shaw ^174^ , 1999, MU | PC | 5y | 3229 | IGT; IFG; IGT-IFG | ADA 97 | (25–74) | Asian Indian, Chinese, Creole
None | Snelhawatha ^175^ , 2003, IN | CS | 11 m | 289 | - | WHO 98 | 42
None | Tavintharan ^39^ , 2000, SG | CS | NA | 111 | - | WHO 80 | 43.2 | Chinese, Maylay, Indian. Some hypertensive
| | | | | | ADA 97 | (37–50)
None | Tominaga ^93^ , 1999, JP | PC | 7 y | 2651 | IGT; IFG | WHO 85 | 64 | Inhabitants of Funagata
| | | | | | ADA 97 | (41+)

Abbreviations: (+)=Modified criteria; ADA=American Diabetes Association; CS=Cross-Sectional study; d=day; DM=Diabetes; GDM=Gestational Diabetes Mellitus; IFG=Impaired Fasting Glucose; IGT=Impaired Glucose Tolerance; I-IFG=Isolated Impaired Fasting Glucose; I-IGT=Isolated Impaired Glucose Tolerance; m=month; NA=Not Applicable; NC=Not Clear; NR=Not Reported; PC=Prospective Cohort study; RC=Retrospective Cohort; RCT=Randomized Controlled Trial; w=week; WHO=World Health Organization; y=Year(s).

Study Group Abbreviations: ADSS=Australia Diabetes Screening Study; ARIC=Atherosclerosis Risk in Communities Study; AusDiab=Australian Diabetes; Obesity and Lifestyle Study; CHS=Cardiovascular Health Study; DECODA=Diabetes Epidemiology: Collaborative Analysis of Diagnostic Criteria in Asia; EDIP=Early Diabetes Intervention Program; JACDS=Japanese American Community Diabetes Study; NHANES=National Health and Examination Survey; Pima=Pima Indians Study; PPS=Paris Prospective Study; RIAD=Risk factors in IGT for Atherosclerosis and Diabetes; SAHS=San Antonio Heart Study; SNHS=Singapore National Health Survey.

Country Abbreviations: (*)=Additional countries; AU=Australia; BD=Bangladesh; CA=Canada; DE=Germany; ES=Spain; FI=Finland; FR=France; GB=Great Britain; GH=Ghana; IE=Ireland; IN=India; IT=Italy; JP=Japan; KR=Korea; MU=Mauritius; MX=Mexico; NL=Netherlands; NZ=New Zealand; PL=Poland; SE=Sweden; SG=Singapore; TR=Turkey; TW=Taiwan; TZ=Tanzania; US=United States.

### Reproducibility of IGT and IFG Tests

Four studies in five reports ^29^ – ^33^ assessed the reproducibility of the OGTT for diagnosis of IGT, and two studies ^30,^ ^31,^ ^33^ assessed the reproducibility of FPG for the diagnosis of IFG in publications after 1978 (Table 5). All repeat tests were done within six weeks of the first test. No triplicate testing was done. The populations studied were mostly Caucasians, ^29^ – ^31^ except for one study on Hong Kong Chinese in two reports. ^32,^ ^33^ The study populations were subgroups of larger studies and as such did not provide detailed characterization for the subgroup. The selection of the subgroups was essentially random, but not in all cases. Mooy and de Vegt used different subgroups of individuals from the Hoorn study. Mooy's group ^29^ included participants randomly selected from those individuals with a 2 hour post glucose challenge plasma glucose level (2-hr PG) of < 7.5 mmol/L, stratified by age and sex, plus all participants with a 2-hr PG < 7.5 mmol/L (22% IGT by the first OGTT). de Vegt, ^30^ however, used a reconstructed sample that represented participants without known DM (10.5% IGT by the first OGTT). Ko ^32,^ ^33^ reported reproducibility for IGT and IFG from the same random sample of the working Hong Kong Chinese study in two separate publications. Farrer ^31^ reported reproducibility of IGT in a high-risk group of mostly male post-CABG surgery patients. No details were given as to how the subgroup sample was selected. All studies used the same classification criteria: FPG ≥ 7.8 mmol/L and 2-hr PG 7.8 to 11.1 mmol/L for IGT, and FPG 6.1 to 6.9 mmol/L for IFG.

Table 5 Reproducibility of IGT and IFG classification upon retesting within 6 weeks

First test | | | IGT (%) | | | | IFG (%)
Second test | | | NGT | IGT | DM | Kappa | | NFG | IFG | DM | Kappa
| | | | | | (95% CI) | | | | | (95% CI)
Author | n | Repeat interval | | | | | n
Farrer,1995 ^31^ | 49 | 10 d | 61 | 33 | 6 | 0.04
| | | | | | (0–0.22)
Ko,1998 ^32^ , ^33^ | 93 | 6 w | 46.2 | 44.1 | 9.7 | 0.56 | 22 | 31.8 | 63.7 | 0.5 | 0.22
| | | | | | (0.39–0.75) | | | | | (0.09–0.35)
Mooy,1996 ^29^ | 98 | 2 – 6 w | 39.3 | 48 | 12.6 | 0.38
| | | | | | (0.30–0.47)
deVegt,2000 ^30^ | 239 | 2 – 6 w | 40.6 | 47 | 12.6 | 0.42 | 173 | 38.7 | 51.4 | 9.8 | 0.44
| | | | | | (0.35–0.48) | | | | | (0.36–0.51)

Note: DM refers to study participant classification and not diagnosis since confirmation testing was not done.

Abbreviations: NGT=normal glucose tolerance; NFG=normal fasting glucose; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; DM=diabetes mellitus; n=number of participants classified as IFG or IGT by the first test; d=days; w=weeks.

The reproducibility of the IGT and IFG tests was assessed by calculating the kappa coefficient, and the percent positive agreement between participants categorized as IFG or IGT on both tests. The kappa coefficients for IGT ranged from 0.04 to 0.56, indicating poor to moderate agreement. ^34^ The proportion of participants classified as IGT by the first OGTT who remained classified as IGT upon repeat testing ranged from 33% to 48%. Most participants were reclassified as NGT (39.3% to 46.2%) with the remainder reclassified as DM (6% to 12.6%). The two Hoorn substudies gave essentially the same reproducibility, even though Mooy used a higher risk group to examine the reproducibility. ^29^ The study that gave the lowest reproducibility (kappa = 0.04) involved mostly men who had undergone CABG and were considered at high risk for IGT and DM. ^31^ This study population had a significantly higher prevalence of abnormal glucose tolerance compared to the expected proportion of a population with the same 2-hr PG mean and SD.

Two studies retested participants based on FPG for IFG. The kappa coefficients for these studies were 0.22 and 0.44, indicating fair to moderate reproducibility. The proportion of participants classified as IFG by the first FPG, who were classified as IFG again upon repeat testing, was 63.7% and 51.4% for the Ko and de Vegt studies, respectively. ^30,^ ^33^ The reclassified subjects had mostly NFG with some newly diagnosed DM. The low IFG prevalence in the Ko study population of 2.5% compared to 16.5% in the de Vegt study population may have accounted for the difference in reproducibility.

Another measure of reproducibility reported in two studies was within individual coefficient of variation (CV_ I _) for IFP and 2-hr PG ^29,^ ^31^ . The coefficient of variation is the ratio of the standard deviation to the mean and is used as a measure of the relative spread or precision. The CV_I_ is a measure of random variation around a homeostatic set point for each individual. This variation is distinct from analytical variation (CV_A_) of a test method. Both studies gave similar CV_I_ for FPG (6% and 6.3%) and the 2-hr PG (18% and 16.6%) concentrations, ^29,^ ^31^ indicating consistency in variation between the different populations studied. Mooy's study also reported no association between test-retest differences with age, sex, obesity (body mass index [BMI] or waist-hip ratio [WHR]), or BP. However, there was a positive association with heart rate on the difference between the 2-hr PG tests (mean difference 2, 95% CI 1.1 to 2.9 beats/min, p = 0.01). ^29^ Furthermore, when the FPG and the 2-hr PG tests were categorized into NGT, IGT, and DM, the FPG CV_I_ was greater for participants classified as DM (7.0%) compared to IGT (5.9%) or NGT (4.6%). The 2-hr PG CV_I_ gave opposite results with a slightly better CV_I_ for participants classified as DM (12.6%) compared to IGT (14.9%) or NGT (16.3%). No p values were provided, so it is not known if these differences were statistically significant.

### Comparison of IGT Diagnosis Using Different Criteria

Four studies ^35^ – ^38^ compared diagnoses using different IGT criteria (i.e., both IFG and the 2-hr PG concentrations). ^35^ – ^38^ Studies that assessed IGT based on the epidemiological criteria (i.e., the 2-hr PG glucose concentration only) were excluded. ^20^ Study population characteristics varied and thus represent a broad spectrum of populations (Asian, Dutch, Pima Indians, and women with previous gestational DM). The IGT criteria included were WHO 85, WHO 98, and WHO 99. All of these criteria use a 2-hr PG range of 7.8 to 11.0 mmol/L, but the WHO 85 uses an FPG cut point of < 7.8 mmol/L whereas both the WHO 98 and WHO 99 criteria use a cut point of < 7.0 mmol/L.

Table 6 summarizes the data from the four studies. More IGT diagnoses were made using an FPG cut point of < 7.8 mmol/L (13.6% to 31.5 %) than of 7.0 mmol/L (8.3% to 29.7%). There were fewer cases of I-IGT (6.0% to 11.9%) compared to IGT by either FPG cut point.

Table 6 Comparison of IGT classifications using a 2-h PG range of 7.8–11.0 mmol/L and FPG values of < 6.1 mmol/L, < 7.0 mmol/L or < 7.8 mmol/L

| n | % IGT (n)
| | FPG < 6.1 mmol/L | Difference (%) < 6.1 vs < 7.0 mmol/L | FPG < 7.0 mmol/L | Difference (%) < 7.0 vs < 7.8 mmol/L | FPG < 7.8 mmol/L | Difference (%) < 6.1 vs < 7.8 mmol/L
de Vegt, 2001 ^35^ | 1342 | 6.0 (80) | 27.9 | 8.3 (111) | - | - | -
Gabir, 2000 ^36^ | 5023 | 10.7 (537) | 19.0 | 13.2 (663) | 3.1 | 13.6 (684) | 21
Qiao, 2000 ^37^ | 16793 | 11.9 (1984) | 19.3 | 14.5 (2460) | 3.4 | 15.2 (2546) | 22
Kousta, 1999 ^38^ | 165 | - | - | 29.7 (49) | 5.8 | 31.5(52) | -

Abbreviations: FPG=fasting plasma glucose; IGT=impaired glucose tolerance; n=number of subjects.

Of the three studies using FPGs of < 7.8 mmol/L and < 7.0 mmol/L to classify IGT, two large population-based studies showed a similar negative change of 3.1% and 3.4%. One study showed a negative change of 5.8%. The latter study had fewer participants than the other two studies and consisted of a cohort of women with a history of gestational DM. The Pima Indian study group provided cumulative data from 1965 to 1999 for individuals aged ≥ 15 years. The DECODA study included Asian participants from five Asian countries (India, China, Indonesia, Japan, and Singapore) and the U.S. (Los Angeles and Hawaii).

The reduction in IGT classification using an FPG of < 6.1 mmol/L compared to < 7.0 mmol/L was greater in the Hoorn follow-up study (27.9%) compared to the Pima Indian study (19.0 %) and the DECODA study (19.3%). The Hoorn follow-up study excluded participants from the prospective-cohort baseline group who had died, moved away, had missing glucose values, or had DM (1142 of 2484 participants). In contrast, the Pima Indian and the DECODA groups were population-based and included all individuals.

### Relationship Between IGT and IFG

Forty-nine studies provided data on the relationship between the diagnostic criteria for IGT and IFG. Most studies were prospective cohort studies (n = 14) and cross-sectional studies (n = 31). The majority of the studies used the WHO 98, WHO 99, ADA 97, or ADA 98 criteria for IGT. These diagnostic criteria are identical to each other (Table 1). The other major set of criteria used for IGT was the WHO 85 criteria that differed only in the FPG value (< 7.8 mmol/L compared to < 7.0 mmol/L). Many of the studies that reported IGT results with the WHO 85 criteria also reported results with the later criteria (WHO 98, WHO 99). ^20^ One study used the WHO 80 criteria for IGT diagnosis. ^39^ The diagnostic criteria for IFG are the same for the ADA and WHO in any year. However, the data were reported differently across studies. For example, studies may have used the term IFG or IGT but actually reported data for the I-IFG or the I-IGT, respectively. Also, studies reporting IGT classifications may have used only the 2-hr PG value rather than FPG and 2-hr PG values. Therefore, to relate studies according to the diagnostic criteria in Table 1, additional calculations were needed in some studies.

The data were extracted to give seven classifications, regardless of which criteria were described in each article. If the data were available to fit into these classifications, they were extracted to provide maximal information for comparison among studies. The seven classifications include IGT (2-hr PG 7.8 to 11.0 mmol/L), IGT (FPG < 7.8 mmol/L and 2-hr PG 7.8 to 11.0 mmol/L), IGT (FPG < 7.0 mmol/L and 2-hr PG 7.8 to 11.0 mmol/L), IGT (FPG 6.1 to 6.9 mmol/L), I-IGT (FPG < 6.1 mmol/L and 2-hr PG 7.8 to 11.0 mmol/L), I-IFG (FPG 6.1 to 6.9 mmol/L, 2-hr PG < 7.8 mmol/L), and the combined group of IFG and IGT (FPG 6.1 to 6.9 mmol/L and 2-hr PG 7.8 to 11.0).

The difference between IFG and I-IFG classifications among the studies shown in Figure 3 is approximately 2.8 fold (p < 0.0001). Comparison of studies that have both IGT and I-IGT data show that classification is approximately 40% greater for IGT compared to I-IGT (p < 0.0001). Also, an IGT classification using the WHO epidemiological criteria, which omits the FPG value, classified 10% more participants as IGT (p = 0.0033).

Figure 3. Distribution of IGT and IFG classifications in 16 studies

Hospital-based populations (----), random populations (——), selected population (– - –).

Table 7 shows a summary of the percent of study subjects with the diagnoses of IGT, I-IGT, IFG, I-IFG, both IGT/IFG, and ratios of IGT to IFG and I-IGT to I-IFG. Studies containing data for all classification categories (n = 16) are expressed graphically in Figure 3. A line connects each classification group within each to show the change in proportion between each classification group and between studies. In general, the proportion of participants decreased with increased stringency of the diagnostic criteria—that is, IGT (2-hr PG) > IGT (FPG and 2-hr PG) > I-IGT > IFG > I-IFG > IFG and IGT. Four studies had a higher proportion of IFG compared to I-IGT, ^40^ – ^43^ and three studies had a similar proportion of IFG and I-IGT. ^44^ – ^46^ The three studies that had a higher proportion of IFG were hospital-based and selected patients who were at higher risk for DM. The other study ^43^ was conducted on a distinct population of 7018 male police officers in Paris. ^43^ Only one other study ^47^ illustrated in Figure 3 was hospital-based, but this study excluded all patients with disorders that would likely affect glucose metabolism. ^47^ Other studies described high-risk populations but from non-hospital settings. The three studies with a similar proportion of IFG and I-IGT were from populations in Taiwan, ^44^ Ghana, ^45^ and Australia. ^46^ None of the other 16 studies included participants from these countries.

Table 7 Summary of published studies that compared IGT with IFG criteria

Author, Year | n | IGT % (n) 2-hr PG 7.8 – 11.0 mmol/ L | IGT % (n) FPG < 7.8 mmol/ L 2h-PG 7.8 – 11.0 mmol/L | IGT % (n) FPG < 7.0 mmol/ L 2-hr PG 7.8 – 11.0 mmol/L | I-IGT % (n) FPG < 6.1 mmol/L 2-hr PG 7.8 – 11.0 mmol/L | IFG % (n) FPG 6.1 – 6.9 mmol/L | I-IFG % (n) FPG 6.1 – 6.9 mmol/L 2-hr PG < 7.8 mmol/L | IFG and IGT % (n) FPG 6.1 – 6.9 mmol/L 2-hr PG 7.8 – 11.0 mmol/L | Ratio IGT / IFG | Ratio IGT / IFG 2-hr PG only | Ratio I-IGT / I-IFG
Tavintharan, 2000 | 111 | 21.6 (24) | 21.6 (24)* | | 18.9 (21) | 7.2 (8) | 0.9 (1) | 0.9 (1) | 2.8 | 3 | 21
Kousta, 1999 | 192 | | 31.5 (52) | | 24.2 (40) | 10.9 (18) | 4.2 (7) | 5.5 (9) | 2.9 | | 5.7
Weyer, 1999 | 434 | | 22.6 (98) | | | 6.7 (29) | 0.23 (11) | 4.1 (18) | 3.4
Puavilai, 1999 | 1051 | 26.2 (274) | 26.1 (274) | 24.9 (262) | 18.3 (192) | 20.4 (214) | 2.8 (29) | 6.7 (70) | 1.2 | 1.3 | 2.7
De Vegt, 2000* | 1109 | | 21.6 (239) | | | 15.6 (173) | | | 1.4
Richard, 2002 | 1149 | | 22.4 (257) | | 19.9 (229) | 6.0 (69) | 1.3 (15) | 2.1 (24) | | 3.7 | 15.3
De Vegt, 2001 | 1342 | | 8.3 (111) | | 6.0 (80) | 10.2 (137) | 7.9 (106) | 2.3 (31) | 0.81 | | 0.75
De Vegt, 1998 | 2378 | | 10.6 (252) | | 6.9 (163) | 12.0 (285) | 8.2 (195) | 2.7 (64) | 0.8 | 0.9 | 0.8
De Vegt, 2000 | 2468 | | 10.2 (252) | | 6.6 (163) | 11.5 (285) | 7.9 (195) | 2.6 (64) | 0.9 | | 0.8
Harris, 1997 | 2844 | | 15.6 (444) | | 11.0 (313) | 10.1 (287) | 4.4 (125) | 3.9 (111) | 1.5 | | 2.5
Barzilay, 1999 | 4515 | | 32.1 (1448) | | 29.0 (1309) | 14.6 (657) | | | 1.7
Al Lawati, 2000 | 4682 | 10.5 (493) | 10.0 (467) | | 8.2 (385) | 5.7 (268) | 2.5 (115) | 1.8 (82) | 1.7 | 1.8 | 3.3
Flores-Saenz, 2003 | 40 | | | 100 (40) | 80 (32) | | | 20 (8)
Guerrero-Romero, 2001 | 100 | | | | 48 | | 52
Hanefeld, 1999 | 104 | | | | | | 41 (63) | 39 (41)
Perry, 2001 | 244 | 34.0 (83) | | 29.9 (73) | 14.3 (35) | 40.2 (98) | | 15.6 (38) | 0.74 | 0.85
Snehalatha, 2003 | 326 | | | | 20.9 (68) | | 19.9 (65) | 8.3 (27) | | | 1.05
Carnevale Schianca, 2003 | 379 | | | | 14.8 (59) | | 5.5 (22) | 3.5 (14) | | | 2.7
Mannucci, 1999 | 528 | | | 22.9 (121) | 15.9 (84) | 19.1 (101) | 5.5 (29) | 7.0 (37) | 1.2 | | 2.9
Jaber, 2003 | 542 | | | 9.6 (52) | | 7.6 (41) | | 2.4 (13) | 1.3
Liao, 2001 | 596 | | | 35.6 (212) | 29.5 (176) | 9.9 (59) | 0 | 6.0 (36) | 5.9
Croxson, 1998 | 599 | 18.2 (109) | | 11.8 (71) | 7.5 (45) | 17.2 (103) | 8.5 (51) | 4.3 (26) | 0.7 | 1.1 | 0.9
Li, 2003 | 644 | | | | 18.3 (118) | | 6.5 (42) | 7.6 (49) | | | 2.8
Hanefeld, 2003 | 664 | | | 31.2 (207) | 15.2 (101) | | 13.6 (90) | 16.0 (106) | | | 1.1
Kim, 2002 | 665 | 17.9 (119) | | | | 7.1 (47) | | | | 2.5
Pablos-Velasco, 2001 | 691 | 17.1 (118) | | 16.4 (113) | 13.2 (91) | 8.8 (61) | 4.1 (28) | 3.2 (22) | 1.9 | 1.9 | 3.3
Anand, 2003 | 936 | | | 15.2 (142) | 13.2 (124) | 5.2 (49) | 1.9 (18) | 1.9 (18) | 2.9 | | 6.9
Mannucci, 2003 | 1215 | 7.9 (96) | | | | 13.3 (161) | | | | 0.6
Drzewoski, 2001 | 1360 | 25.1 (342) | | 316 | 19.6 (266) | 11.3 (154) | 3.2 (44) | 3.7 (50) | | 2.2 | 6.1
Li, 2002 | 1456 | 23 (335) | | 21.2 (308) | 15.3 (223) | 15.7 (228) | 6.9 (101) | 5.8 (85) | 1.4 | 1.5 | 2.2
Choi, 2002 | 1456 | 23.7 (345) | | 23.1 (337) | 20.0 (292) | 8.0 (117) | 2.7 (40) | 3.1 (45) | | 3 | 7.4
Ko, 1998 | 1486 | 7.4 (110) | | 7.3 (109) | 6.3 (93) | 2.6 (38) | 0.9 (14) | 1.1 (16) | 2.9 | 2.9 | 6.6
Gokcel, 2003 | 1637 | | | 2.3 (37) | | | 1.5 (25) | 0.5 (9)
Gomez-Perez, 1998 | 1706 | 23.9 (407) | | 23.4 (399) | 19.3 (329) | 11.0 (187) | 2.5 (43) | 4.1 (70) | 2.1 | 2.2 | 7.7
Lorenzo, 2003 | 1734 | 11.6 (202) | | | | 1.7 (29) | | | | 6.8
Gatling, 2001 | 1864 | 21.4 (398) | | 18.6 (347) | 9.9 (185) | 22.3 (415) | 7.9 (148) | 8.7 (162) | 0.84 | 0.96 | 1.3
Tominaga, 1999 | 2651 | 14.4 (382) | | | | 5.8 (155) | | | | 2.5
Saydah, 2001 | 3092 | 17.9 (555) | | | | 6.2 (193) | 2.5 (76) | | | 2.9
Tai, 2000 | 3407 | 14.3 (487) | | 13.2 | 10.2 (348) | 8.7 (296) | 3.6 (122) | 3.6 (121) | 1.6 | 1.6 | 2.9
Shaw, 1999 | 3528 | 18.1 (639) | | 17.2 (607) | 13.9 (489) | 9.3 (327) | 4.2 (148) | 3.3 (118) | 1.8 | 1.9 | 3.3
Lim, 2000 | 3568 | | | 13.1 (469) | 9.8 (348) | | 3.4 (122) | 3.4 (121) | | | 2.9
Smith, 2003 | 3821 | 2.7(103) | | | | 1.7 (65) | | | | 1.6
Amoah, 2002 | 4636 | 15.8 (732) | | 14.7 (682) | 10.8 (501) | 10.7 (498) | 6.2 (288) | 3.9 (181) | | 1.5 | 1.7
Gabir, 2000 | 5023 | 13.8 (692) | | 13.6 (684) | 10.7 (537) | 5.9 (298) | 1.9 (93) | 2.5 (126) | 2.3 | 2.3 | 5.8
Tripathy, 2000 | 5396 | | | | 9.1 (493) | | 10.0 (537) | 5.6 (303) | | | 0.92
Metcalf, 2000 | 5816 | 2.8 (163) | | 2.2 (126) | 1.2 (72) | 8.3 (485) | 7.3 (427) | 0.9 (54) | 0.26
Balkau, 2002 | 7018 | 9.2 (645) | | 8.3 (579) | 4.6 (326) | 17.1 (1203) | 13.2 (927) | 0.4 (253) | 0.5 | 0.5 | 0.4
Schmidt, 2003 | 8286 | 28.6 (2369) | | | | 12.9 (1069) | | | | 2.2
Dunstan, 2002 | 11247 | 11.1 (1248) | | 10.6 (1192) | 8.0 (900) | 9.1 (1023) | 5.7 (641) | 2.6 (29) | 1.2 | 1.2 | 1.4
Qiao, 2000 | 16379 | 15.4 (2579) | | 14.7 (2460) | 11.9 (1984) | 8.1 (1352) | 3.7 (621) | 2.8 (476) | 1.8 | 1.9 | 3.2
Tuomilehto, 2002 | 17512 | | | 14.4 (2528) | 11.7 (2044) | | 3.6 (630) | 2.7(484) | | | 3.2

This is a subset of the Hoorn study representing the participants who had repeat OGTT. This subset had a higher prevalence of IGT, IFG and DM.

The prevalence of IGT and IFG varied greatly among the studies, ranging from a few percent to over 30% (Table 7). Comparisons between categories of IGT and IFG among the studies in Figure 3 were significant (paired t-test, p < 0.01) for all combinations except for I-IGT versus IFG and I-IFG versus IGT and IFG. Correlations between IGT and I-IGT and IFG and I-IFG classifications are expected to be high because of the similarity in test criteria. The correlation was much higher in these 16 studies for IGT versus I-IGT than for IFG versus I-IFG. The Passing-Bablok regression equations were IGT versus I-IGT, y = 0.879× – 1.29, r = 0.95, p = 0.0084; IFG versus I-IFG, y = 0.521× – 0.78, r = 0.63, p ≤ 0.0001 (see Figures 4 and 5). Two studies were identified as outliers in the comparison of IFG versus I-IFG: the Paris police study ^43^ and the Bangkok study. ^40^ These studies were unique because the policemen study included men only and the Bangkok study included patients who had a history of borderline fasting glucose values.

Figure 4. Passing-Bablok regression equation for IGT versus I-IGT

Figure 5. Passing-Bablok regression equation for IFG versus I-IFG

## Prognosis

This systematic review addressed the question of whether being classified as IFG or IGT affected the future risk for adverse health outcomes such as DM, CVD (fatal and nonfatal), mortality, and microvascular diseases. This section summarizes studies that address these prognostic questions. As noted in Chapter 2, the eligibility criteria for this entire systematic review excluded studies in which participants were classified on the basis of whole or capillary blood testing. Thus, the well-known DECODE series of studies ^48^ was excluded as the testing protocols for glycemic status included whole blood assays. Similarly, studies (or data within eligible studies) that evaluated predictors for developing IFG or IGT in people without IFG or IGT were excluded because the focus of this report was on the prognosis of those already classified with IFG or IGT.

### General Characteristics of the Prognosis Studies

A total of 104 studies met the initial eligibility criteria; a subset of these provided sufficient data (frequency counts) to estimate the annualized risk, the unadjusted annualized RR (with the CI), the risk difference, and the AR (expressed as a percentage for the observed study duration). Table 8 details the study characteristics for the eligible studies for the prognosis question. All studies prospectively followed cohorts; 90 were epidemiological studies and 14 were RCTs from which data were extracted from the placebo arm only.

The duration of follow-up varied from one year to 18 years. Five studies ^49^ – ^53^ evaluated women only, and nine studies evaluated men only. ^43,^ ^54^ – ^61^ The mean age and the ranges varied significantly among studies, but most included middle-aged and older subjects (Table 8). There was a broad representation of populations, including Pima Indians; Canadian First Nations people; Oriental populations from China, Taiwan, and Japan; Nauruans; Black Americans; Hispanic Americans; Caucasian Europeans (Finland, France, Netherlands, Malta, Europe); and South African Indians.

### Evaluation of Short- and Long-term Risk and Progression to Endpoints of Interest

The estimates of short and long-term risk from eligible prospective cohort studies (Tables 9 to 15) and RCTs (placebo arm only) (Tables 16 to 19) presented sufficient data to compute the four selected measures of risk for different outcomes. The following four metrics of risk were selected to evaluate the short- and long-term risk of subjects with IFG or IGT and the progression to the outcomes of interest:

Table 9 Progression to DM in subjects with the risk factor of dysglycemia. (Note: Annualized risk, unadjusted annualized RR, risk difference on annual data and AR for the study duration (%) are presented across the five diagnostic categories—IGT, IFG, I-IGT, I-IFG and combined IGT/IFG.)

Study Group | Author | Study Duration (y) | Baseline (n) IGT and/or IFG | | Baseline (n) NGT and/or NFG | | Annualized Riskper 100 persons inexposed population | Annualized Relative Risk (95% CI) | Annualized Risk Difference per 100 persons | % Attributable Risk in exposed population for study duration
| | | Outcome: Progression to DM | | Outcome: Progression to DM
| | | Yes | No | Yes | No
Risk group: IGT
| Ko, 2000 ^63^ | 1.6 | 19 | 20 | 25 | 144 | 34.12 | 3.58 | 24.60 | 69.6
| | | | | | | | (2.12–6.06)
| Ammari, 1998 ^73^ | 2 | 10 | 58 | 10 | 134 | 7.65 | 2.16 | 4.11 | 52.8
| | | | | | | | (0.92–5.07)
PPS | Charles, 1997 ^54^ | 2 | 32 | 386 | 27 | 3644 | 3.90 | 10.60 | 3.54 | 90.4
| | | | | | | | (6.38–17.60)
| Puavili, 1987 ^74^ | 2 | 8 | 41 | 1 | 21 | 8.53 | 3.71 | 6.23 | 72.2
| | | | | | | | (0.48–28.75)
HKCRFP | Wat, 2001 ^81^ | 2 | 31 | 291 | 4 | 318 | 4.94 | 7.92 | 4.31 | 87.1
| | | | | | | | (2.81–22.31)
| Inoue, 1996 ^62^ | 2.5 | 5 | 32 | 1 | 21 | 5.64 | 3.06 | 3.80 | 66.4
| | | | | | | | (0.37–25.51)
PPS | Charles, 1991 ^61^ | 3 | 25 | 439 | 23 | 4079 | 1.83 | 9.77 | 1.64 | 89.6
| | | | | | | | (5.56–17.16)
| Mykkanen, 1993 ^204^ | 3.5 | 48 | 155 | 21 | 668 | 7.42 | 8.43 | 6.54 | 87.1
| | | | | | | | (5.08–13.97)
Kinmen | Chou, 1998 ^185^ | 4 | 23 | 108 | 16 | 334 | 4.71 | 4.05 | 3.55 | 74.0
| | | | | | | | (2.16–7.61)
SA-Ind | Motala*, 1993 ^75^ | 4 | 16 | 24 | 0 | 40 | 12.08 | 39.44 | 11.77 | 97.0
| | | | | | | | (2.39–651.84)
| Motala*, 1994 ^76^ | 4 | 16 | 24 | 0 | 32 | 12.08 | 31.71 | 11.70 | 96.2
| | | | | | | | (1.92–523.53)
| Motala*, 1997 ^77^ | 4 | 16 | 24 | 0 | 32 | 12.08 | 31.71 | 11.70 | 96.2
| | | | | | | | (1.92–523.53)
| Kahn, 1996 ^184^ | 5 | 12 | 26 | 4 | 45 | 7.31 | 4.33 | 5.62 | 74.1
| | | | | | | | (1.42–13.21)
Pima | Saad, 1988 ^69^ | 3.3 | 118 | 266 | 25 | 727 | 10.53 | 10.33 | 9.51 | 89.2
| | | | | | | | (6.75–15.82)
| Nelson, 1996 ^70^ | 4 | 12 | 16 | 2 | 26 | 13.06 | 7.11 | 11.22 | 83.3
| | | | | | | | (1.63–31.05)
| Saad, 1988 ^71^ | 5.8 | 49 | 105 | 100 | 1145 | 6.39 | 4.46 | 4.96 | 74.8
| | | | | | | | (3.19–6.23)
| Stefan, 2003 ^72^ | 5.8 | 16 | 28 | 8 | 99 | 7.50 | 5.63 | 6.17 | 79.4
| | | | | | | | (2.44–13.00)
| Little, 1994 ^188^ | 6.1 | 26 | 40 | 10 | 92 | 7.88 | 4.70 | 6.20 | 75.1
| | | | | | | | (2.29–9.64)
Malta | Schranz, 1989 ^78^ | 6 | 23 | 52 | 54 | 1198 | 5.92 | 8.09 | 5.19 | 85.9
| | | | | | | | (5.01–13.06)
| Norman, 2001 ^49^ | 6.2 | 7 | 6 | 4 | 50 | 11.72 | 9.50 | 10.49 | 86.2
| | | | | | | | (2.84–31.78)
Naurua | Dowse, 1996 ^187^ | 5.1 | 58 | 129 | 27 | 624 | 7.02 | 8.49 | 6.19 | 86.6
| | | | | | | | (5.41–13.33)
| King, 1984 ^132^ | 6.2 | 13 | 38 | 14 | 201 | 4.63 | 4.29 | 3.55 | 74.5
| | | | | | | | (2.04–9.04)
Hoorn | De Vegt, 2001 ^35^ | 6.4 | 36 | 75 | 46 | 1185 | 5.94 | 10.01 | 5.35 | 88.5
| | | | | | | | (6.52–15.39)
MCDS | Ferrannini, 2004 ^79^ | 7 | 62 | 89 | 101 | 1097 | 7.27 | 5.82 | 6.02 | 79.5
| | | | | | | | (4.27–7.94)
SAHS | Haffner, 1995 ^193^ | 7 | 55 | 70 | 44 | 545 | 7.95 | 7.21 | 6.85 | 83.0
| | | | | | | | (4.88–10.65)
| Haffner, 1997 ^194^ | 8 | 62 | 102 | 53 | 1000 | 5.76 | 8.96 | 5.12 | 86.7
| | | | | | | | (6.23–12.87)
| Stern, 1993 ^195^ | 8 | 45 | 170 | 31 | 1173 | 2.89 | 8.89 | 2.57 | 87.7
| | | | | | | | (5.64–14.00)
| Wong, 2003 ^209^ | 8 | 102 | 189 | 12 | 266 | 5.25 | 9.55 | 4.70 | 87.7
| | | | | | | | (5.26–17.32)
Risk group: IGT (isolated)
Kinmen | Li, 2003 ^80^ | 5 | 33 | 85 | 38 | 397 | 6.35 | 3.51 | 4.54 | 68.8
| | | | | | | | (2.22–5.54)
Pima | Gabir, 2000 ^36^ | 5 | 107 | 430 | 126 | 3373 | 4.35 | 5.95 | 3.62 | 81.9
| | | | | | | | (4.61–7.67)
Hoorn | De Vegt, 2001 ^35^ | 6.4 | 27 | 53 | 51 | 1074 | 6.23 | 8.63 | 5.51 | 86.6
| | | | | | | | (5.46–13.64)
Risk group: IFG
| Ko, 2001 ^64^ | 1.1 | 14 | 41 | 13 | 251 | 23.44 | 5.22 | 18.95 | 80.7
| | | | | | | | (2.59–10.54)
| Vermes, 2003 ^65^ RCT | 2.9 | 12 | 13 | 19 | 91 | 20.19 | 3.19 | 13.86 | 64.0
| | | | | | | | (1.63–6.25)
LIPID | Keech, 2003 ^83^ RCT | 6 | 43 | 423 | 138 | 3363 | 1.60 | 2.40 | 0.93 | 57.3
| | | | | | | | (1.71–3.37)
Hoorn | De Vegt, 2001 ^35^ | 6.4 | 52 | 85 | 60 | 1145 | 7.19 | 9.04 | 6.39 | 86.9
| | | | | | | | (6.28–13.03)
REP | Dinneen, 1998 ^212^ | 9 | 201 | 320 | 592 | 6295 | 5.27 | 5.31 | 4.28 | 77.7
| | | | | | | | (4.53–6.21)
Risk group: IFG (isolated)
Pima | Gabir, 2000 ^36^ | 5 | 29 | 64 | 126 | 3373 | 7.20 | 9.85 | 6.473 | 88.5
| | | | | | | | (6.65–14.60)
Kinmen | Li, 2003 ^80^ | 5 | 16 | 26 | 38 | 397 | 9.15 | 5.05 | 7.33 | 77.1
| | | | | | | | (2.86–8.90)
Hoorn | De Vegt, 2001 ^35^ | 6.4 | 35 | 71 | 51 | 1074 | 6.07 | 8.40 | 5.35 | 86.3
| | | | | | | | (5.50–12.83)
Risk group: Multiple IGT/IFG
Pima | Gabir, 2000 ^36^ | 5 | 52 | 74 | 126 | 3373 | 10.10 | 13.82 | 9.37 | 91.3
| | | | | | | | (10.10–18.90)
Kinmen | Li, 2003 ^80^ | 5 | 20 | 29 | 38 | 397 | 9.96 | 5.50 | 8.15 | 78.6
| | | | | | | | (3.25–9.30)
Hoorn | De Vegt, 2001 ^35^ | 6.4 | 20 | 11 | 51 | 1074 | 14.95 | 20.69 | 14.22 | 93.0
| | | | | | | | (12.51–34.22)

* Correction for zero values in cells: To avoid division by zero 0.5 was added to the value of all cells.

Abbreviations:DM=Diabetes Mellitus; HKCRP=Hong Kong Cardiovascular Risk Factor Prevalence Study; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; I-IFG=Isolated impaired fasting glucose; I-IGT=Isolated impaired glucose tolerance; MCDS=Mexico City Diabetes Survey; Pima=Pima Indians Study; PPS=Paris Prospective Study; REP=Rochester Epidemiology Project; SAHS=San Antonio Heart Study; SA-Ind=Study of South African Indians; y=Year(s).

Table 10 Table 10. Reversion to NGT/NFG in subjects with the risk factor of dysglycemia. (Note: Annualized risk in the exposed group and annualized risk difference are presented across the five diagnostic categories—IGT, IFG, I-IGT, I-IFG and combined IGT/IFG.)

Study Population | Author | Study Duration (y) | Baseline (n) IGT and/or IFG | | Baseline (n) NGT and/or NFG | | Annualized Risk per 100 persons in exposed group | Absolute Annualized Risk Difference per 100 persons
| | | Outcome: Reversion to normal | | Outcome: Remained normal
| | | Yes | No | Yes | No
Risk group: IGT
| Ammari, 1998 ^73^ | 2 | 27 | 141 | 131 | 23 | 8.39 | 52.97
PPS | Charles, 1997 ^54^ | 2 | 273 | 145 | 3494 | 177 | 41.10 | 36.94
HKCRFP | Wat, 2001 ^81^ | 2 | 174 | 148 | 286 | 36 | 32.20 | 34.36
| Inoue, 1996 ^62^ | 2.5 | 11 | 26 | 14 | 8 | 13.16 | 20.12
Kinmen | Chou, 1998 ^185^ | 4 | 56 | 75 | 295 | 55 | 13.01 | 24.02
SA-Ind | Motala, 1993 ^75^ | 4 | 7 | 17 | 21 | 11 | 8.26 | 15.17
| Motala, 1994 ^76^ | 4 | 7 | 33 | 21 | 11 | 4.70 | 18.73
| Motala, 1997 ^77^ | 4 | 7 | 33 | 21 | 11 | 4.70 | 18.73
Pima | Saad, 1988 ^69^ | 3.3 | 166 | 218 | 727 | 25 | 15.77 | 48.59
| Weyer, 2001 ^191^ | 5 | 49 | 96 | 175 | 79 | 7.77 | 12.70
| Little, 1994 ^188^ | 6.1 | 12 | 28 | 78 | 14 | 5.68 | 20.88
| Ko, 2000 ^63^ | 1.6 | 8 | 31 | 82 | 87 | 13.37 | 20.60
| Norman, 2001 ^49^ | 6.2 | 2 | 11 | 45 | 9 | 2.66 | 22.44
Naurua | Dowse, 1996 ^187^ | 5.1 | 77 | 110 | 559 | 92 | 9.88 | 21.98
| King, 1984 ^132^ | 6.2 | 20 | 31 | 167 | 48 | 7.72 | 13.77
MCDS | Ferrannini, 2004 ^79^ | 7 | 73 | 97 | 969 | 210 | 7.70 | 14.14
| Wong, 2003 ^209^ | 8 | 122 | 169 | 227 | 51 | 6.57 | 12.53
Risk group: IGT (Isolated)
Risk group: IFG
| Ko, 2001 ^64^ | 1.1 | 17 | 38 | 223 | 41 | 28.55 | 53.06
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Notation for NGT and NFG Groups: Note that for the outcome of reversion, the IGT group was compared to the NGT/NFG group who did not remain normal; the NGT/NFG subjects who did not retain their normal glycemic status converted to IGT or DM status.

Absolute Annualized Risk Difference: The absolute value for the Annualized Risk Difference was calculated for this table only, as the annualized rates for the NGT group were generally of greater magnitude than the IGT group.

Abbreviations: HKCRP=Hong Kong Cardiovascular Risk Factor Prevalence Study; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; I-IFG=Isolated impaired fasting glucose; I-IGT=Isolated impaired glucose tolerance; MCDS=Mexico City Diabetes Survey; NFG=Normal fasting glucose; NGT=Normal glucose tolerance; Pima=Pima Indians Study; PPS=Paris Prospective Study; SA-Ind=Study of South African Indians; y=Year(s).

Table 11 Non-fatal cardiovascular disease outcomes in subjects with the risk factor of dysglycemia. (Note: Annualized risk, unadjusted annualized RR, risk difference on annual data and AR for the study duration (%) are presented across the five diagnostic categories—IGT, IFG, I-IGT, I-IFG and combined IGT/IFG)

Study Group | Author | Study Duration (y) | CVD outcome | Baseline IGT and/or IFG | | Baseline NGT and/or NFG | | Annualized risk per 100 persons in exposed population | Annualized Relative Risk (95% CI) | Absolute Annualized Risk Difference per 100 persons | % Attributable Risk in exposed population
| | | | Outcome: CVD | | Outcome: CVD
| | | | Yes | No | Yes | No
Risk group: IGT
Bruneck | Bonora, 2000 ^85^ | 5 | Atherothrombosis | 17 | 20 | 54 | 195 | 11.58 | 2.43 | 6.81 | 52.8
| | | | | | | | | (1.44–4.10)
| | | Non-stenotic atherosclerosis | 15 | 16 | 103 | 349 | 12.39 | 2.46 | 7.35 | 52.9
| | | | | | | | | (1.46–4.12)
Risk group: IGT (isolated)
None
Risk group: IFG
CARE | Goldberg, 1998 ^52^ | 5 | Clinical MI | 21 | 140 | 156 | 1393 | 2.76 | 1.31 | 0.66 | 22.8
| RCT | | | | | | | | (0.84–2.06)
| | | PTCA | 17 | 144 | 167 | 1382 | 2.21 | 0.98 | 0.05 | 0
| | | | | | | | | (0.60–1.60)
| | | Stroke | 5 | 156 | 47 | 1502 | 0.63 | 1.02 | 0.01 | 2.3
| | | | | | | | | (0.41–2.57)
| | | Unstable angina | 28 | 133 | 261 | 1288 | 3.75 | 1.03 | 0.13 | 3.1
| | | | | | | | | (0.71–1.52)
Veterans | Rubins, 2002 ^84^ | 5.1 | Major event | 38 | 122 | 149 | 560 | 5.18 | 1.15 | 0.66 | 11.5
| RCT | | | | | | | | (0.81–1.62)
LIPID | Keech, 2003 ^83^ | 6 | CHD mortality and non-fatal MI | 83 | 383 | 507 | 2994 | 3.22 | 1.25 | 0.64 | 18.7
| RCT | | | | | | | | (0.99–1.57)
| | | Any event | 213 | 253 | 1348 | 2153 | 9.68 | 1.24 | 1.90 | 15.8
| | | | | | | | | (1.08–1.43)
| | | CABG or PTCA | 77 | 389 | 534 | 2967 | 2.97 | 1.09 | 0.24 | 7.7
| | | | | | | | | (0.86–1.38)
| | | Stroke | 25 | 441 | 126 | 3375 | 0.91 | 1.50 | 0.31 | 32.9
| | | | | | | | | (0.98–2.30)
CHS | Smith, 2002 ^86^ | 8.5 | Any event | 141 | 451 | 548 | 2589 | 3.15 | 1.41 | 0.92 | 26.7
| | | | | | | | | (1.17–1.69)
BIP | Tenenbaum, 2002 ^89^ | 9 | Heart failure | 89 | 139 | 647 | 1166 | 5.35 | 1.12 | 0.56 | 8.6
| | | | | | | | | (0.90–1.39)
Risk group: IFG (isolated)
None
Risk group: Multiple IGT/IFG
None

Abbreviations: BIP=Bezafibrate Infarction Prevention trial; CABG=Cardiac artery bypass graft; CARE=Cholesterol and Recurrent Events Study; CHD=Coronary heart disease; CHS=Cardiovascular Health Study; CVD=Cardiovascular disease; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; I-IFG=Isolated impaired fasting glucose; I-IGT=Isolated impaired glucose tolerance; LIPID=Long-term Intervention with Pravastatin in Ischemic Disease; MI=Myocardial infarction; PTCA=Percutaneous transluminal coronary angioplasty; y=Year(s)

Table 12 Cardiovascular disease-related mortality outcomes in subjects with the risk factor of dysglycemia. (Note: Annualized risk, unadjusted annualized RR, risk difference on annual data and AR for the study duration (%) are presented across the five diagnostic categories—IGT, IFG, I-IGT, I-IFG and combined IGT/IFG.)

Study Group | Author | Study Duration (y) | Mortality Type | Baseline (n) IGT and/or IFG | | Baseline (n) NGT and/or NFG | | Annualized Risk per 100 persons in exposed population | Annualized Relative Risk (95% CI) | Annualized Risk Difference per 100 persons | % Attributable Risk in exposed population for study duration
| | | | Mortality | | Mortality
| | | | Yes | No | Yes | No
Risk group: IGT
| Tominaga, 1999 ^93^ | 7 | CVD | 11 | 371 | 19 | 1997 | 0.42 | 3.08 | 0.28 | 67.3
| | | | | | | | | (1.47–6.47)
NHANES II | Saydah, 2001 ^92^ | 16 | CVD | 55 | 425 | 159 | 2104 | 0.76 | 1.67 | 0.30 | 38.7
| | | | | | | | | (1.23–2.26)
PPS | Balkau, 1991 ^55^ | 18 | Ischemic heart disease | 7 | 700 | 46 | 6129 | 0.06 | 1.33 | 0.01 | 24.8
| | | | | | | | | (0.60–2.95)
Risk group: IGT (isolated)
PPS | Balkau, 1992 ^59^ | 18 | Cardio-cerebrovas-cular | 40 | 638 | 210 | 5843 | 0.34 | 1.72 | 0.14 | 41.2
| | | | | | | | | (1.23–2.41)
| | | CHD | 28 | 650 | 158 | 5895 | 0.23 | 1.59 | 0.09 | 36.8
| | | | | | | | | (1.07–2.28)
Risk group: IFG
CARE | Goldberg, 1998 ^52^ | 5 | CHD | 12 | 149 | 71 | 1478 | 1.54 | 1.65 | 0.60 | 38.5
| RCT | | | | | | | | (0.90–3.02)
| Tominaga, 1999 ^93^ | 7 | CVD - 7yr | 3 | 152 | 27 | 2280 | 0.28 | 1.66 | 0.11 | 39.5
| | | | | | | | | (0.50–5.46)
BIP | Fisman, 2001 ^91^ | 9 | CVD - Ischemic | 79 | 1179 | 469 | 9305 | 0.72 | 1.32 | 0.17 | 23.6
| | | | | | | | | (1.04–1.67)
BIP | Tenenbaum, 2002 ^89^ | 9 | Cardiac | 17 | 211 | 90 | 1723 | 0.86 | 1.52 | 0.29 | 33.4
| | | | | | | | | (0.91–2.55)
PPS | Balkau, 2002 ^43^ | 17 | Coronary | 53 | 1209 | 193 | 5321 | 0.25 | 1.20 | 0.04 | 16.7
| | | | | | | | | (0.89–1.63)
| | | CVD | 77 | 1126 | 307 | 5275 | 0.39 | 1.17 | 0.06 | 14.1
| | | | | | | | | (0.91–1.50)
| | | Ischemic | 21 | 1214 | 82 | 5385 | 0.10 | 1.13 | 0.01 | 11.8
| | | | | | | | | (0.70–1.83)
Risk group: IFG (isolated)
None
Risk group: Multiple IGT/IFG
None

Abbreviations: BIP=Bezafibrate Infarction Prevention trial; CHD=Cholesterol and Recurrent Events Study; CHD=Coronary heart disease; CVD=Cardiovascular disease; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; I-IFG=Isolated impaired fasting glucose; I-IGT=Isolated impaired glucose tolerance; NHANES=National Health and Nutrition Examination Survey; PPS=Paris Prospective Study; y=Year(s)

Table 13 Mortality outcomes in subjects with the risk factor of dysglycemia. (Note: Annualized risk, unadjusted annualized RR, risk difference on annual data and AR for the study duration (%) are presented across the five diagnostic categories—IGT, IFG, I-IGT, I-IFG and combined IGT/IFG.)

Study Group | Author | Study Duration (y) | Mortality Type | Baseline (n) IGT and/or IFG | | Baseline (n) NGT and/or NFG | | Annualized Risk per 100 persons in exposed population | Annualized Relative Risk (95% CI) | Absolute Annualized Risk Difference per 100 persons | % Attributable Risk in exposed population for study duration
| | | | Outcome: Mortality | | Outcome: Mortality
| | | | Yes | No | Yes | No
Risk group: IGT
IRAS | Wagenknecht, 2003 ^88^ | 5.2 | All-cause | 8 | 265 | 9 | 544 | 0.57 | 1.81 | 0.26 | 44.5
| | | | | | | | | (0.70–4.68)
Malta | Schranz, 1989 ^78^ | 6 | All-cause | 15 | 94 | 49 | 1036 | 2.44 | 3.18 | 1.67 | 67.2
| | | | | | | | | (1.79–5.63)
Hoorn | Van Dijk, 2001 ^94^ | 6.6 | All-cause | 5 | 63 | 3 | 19 | 1.15 | 0.52 | 1.05 | 0
| | | | | | | | | (0.13–2.17)
| Tominaga, 1999 ^93^ | 7 | All-cause | 26 | 356 | 75 | 1941 | 1.00 | 1.85 | 0.46 | 45.3
| | | | | | | | | (1.19–2.89)
NHANES II | Saydah, 2001 ^92^ | 16 | All-cause | 137 | 343 | 408 | 1855 | 2.08 | 1.68 | 0.84 | 36.8
| | | | | | | | | (1.39–2.04)
NHANES II | Saydah, 2003 ^95^ | 16 | All-cause | 128 | 352 | 459 | 1804 | 1.92 | 1.36 | 0.51 | 23.9
| | | | | | | | | (1.12–1.66)
| | | Cancer | 47 | 430 | 122 | 2128 | 0.65 | 1.86 | 0.30 | 45.0
| | | | | | | | | (1.33–2.60)
| | | Cancer 70 y+ | 60 | 420 | 179 | 2084 | 0.83 | 1.62 | 0.32 | 36.7
| | | | | | | | | (1.21–2.17)
PPS | Balkau, 1991 ^55^ | 18 | Cerebrovascular | 11 | 696 | 41 | 6134 | 0.09 | 2.35 | 0.05 | 57.3
| | | | | | | | | (1.21–4.58)
| | | All-cause | 137 | 570 | 762 | 5413 | 1.19 | 1.63 | 0.46 | 36.3
| | | | | | | | | (1.36–1.96)
Risk group: IGT (isolated)
PPS | Balkau, 1993 ^60^ | 15.6 | All-cause | 132 | 565 | 757 | 5404 | 1.34 | 1.60 | 0.50 | 35.1
| | | | | | | | | (1.33–1.92)
PPS | Balkau, 1992 ^59^ | 18 | Alcohol | 14 | 644 | 61 | 5992 | 0.12 | 2.12 | 0.06 | 52.6
| | | | | | | | | (1.19–3.79)
| | | Cirrhosis | 12 | 666 | 15 | 6038 | 0.10 | 7.19 | 0.09 | 86.0
| | | | | | | | | (3.37–15.37)
| | | Cirrhosis and alcohol | 26 | 652 | 76 | 5977 | 0.22 | 3.09 | 0.15 | 67.3
| | | | | | | | | (1.98–4.83)
Risk group: IFG
| Tominaga, 1999 ^93^ | 7 | All-cause | 10 | 145 | 91 | 2216 | 0.95 | 1.65 | 0.37 | 38.9
| | | | | | | | | (0.86–3.17)
BIP | Fisman, 2001 ^91^ | 9 | All-cause | 253 | 1005 | 1398 | 8375 | 1.31 | 1.45 | 0.41 | 28.9
| | | | | | | | | (1.27–1.66)
BIP | Tenenbaum, 2002 ^89^ | 9 | All-cause | 27 | 201 | 153 | 1660 | 1.39 | 1.43 | 0.42 | 28.7
| | | | | | | | | (0.95–2.14)
PPS | Balkau, 2002 ^43^ | 17 | All-cause | 252 | 954 | 1003 | 4569 | 1.37 | 1.18 | 0.21 | 13.9
| | | | | | | | | (1.03–1.35)
| | | Cancer | 110 | 1099 | 437 | 5166 | 0.56 | 1.17 | 0.08 | 14.3
| | | | | | | | | (0.95–1.45)
Risk group: IFG (isolated)
None
Risk group: Multiple IGT/IFG
None

Abbreviations: BIP=Bezafibrate Infarction Prevention trial; CARE=Cholesterol and Recurrent Events Study; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; I-IFG=Isolated impaired fasting glucose; I-IGT=Isolated impaired glucose tolerance; IRAS=Insulin Resistance Atherosclerosis Study; NHANES II=National Health and Nutrition Examination Survey; PPS=Paris Prospective Study; y=Year(s).

Table 14 Lipid and blood pressure disturbance outcomes in subjects with the risk factor of dysglycemia. (Note: Annualized risk, unadjusted annualized RR, risk difference on annual data and AR for the study duration (%) are presented across the five diagnostic categories—IGT, IFG, I-IGT, I-IFG and combined IGT/IFG.)

Study group | Author | Study Duration (y) | Metabolic Parameter | Baseline IGT and/or IFG | | Baseline NGT and/or NFG | | Annualized Risk per 100 persons in exposed population | Annualized Relative Risk (95% CI) | Absolute Annualized Risk Difference per 100 persons | % Attributable Risk in exposed population for study duration
| | | | Outcome: Metabolic | | Outcome: Metabolic
| | | | Yes | No | Yes | No
Risk group: IGT
SAHS | Haffner, 1992 ^98^ | 8 | Hypertension (men) | 6 | 74 | 43 | 418 | 0.97 | 0.80 | 0.25 | 0
| | | | | | | | | (0.34–1.87)
| | | Hypertension (women) | 15 | 94 | 45 | 590 | 1.83 | 2.00 | 0.92 | 48.5
| | | | | | | | | (1.12–3.58)
| Pfeffer, 2003 ^96^ | 10 | Dialysis return | 5 | 8 | 6 | 22 | 4.74 | 1.99 | 2.36 | 44.3
| | | | | | | | | (0.62–6.42)
Risk group: IGT (isolated)
None
Risk group: IFG
None
Risk group: IFG (isolated)
None
Risk group: Multiple IGT/IFG
None

Abbreviations: IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; iIFG=Isolated impaired fasting glucose; iIGT=Isolated impaired glucose tolerance; SAHS=San Antonio Heart Study; y=Year(s).

Table 15 Other outcomes in subjects with the risk factor of dysglycemia. (Note: Annualized risk, unadjusted annualized RR, risk difference on annual data and AR for the study duration (%) are presented across the five diagnostic categories (IGT, IFG, I-IGT, I-IFG and combined IGT/IFG.)

Study group | Author | Study Duration (y) | Outcome Type | Baseline (n) IGT and/or IFG | | Baseline (n) NGT and/or NFG | | Annualized risk per 100 persons in exposed population | Annualized Relative Risk (95% CI) | Annualized Risk Difference per 100 persons | % Attributable Risk in exposed population
| | | | Outcome Present | | Outcome Present
| | | | Yes | No | Yes | No
Risk group: IGT
None
Risk group: IGT (isolated)
None
| Ito, 2000 ^97^ | 5.5 | Retinopathy | 31 | 773 | 73 | 2235 | 0.71 | 1.22 | 0.13 | 18.0
| | | | | | | | | (0.80–1.86)
Risk group: IFG (isolated)
None
Risk group: Multiple IGT/IFG
None

Abbreviations: IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; I-IFG=Isolated impaired fasting glucose; I-IGT=Isolated impaired glucose tolerance; y=Year(s).

Table 16 Placebo arm of RCTs: Progression to DM. (Note: All subjects in these trials had dysglycemia and only the annualized risk was estimated.)

Study Group | Author | Study Duration (years) | Baseline (n) IGT and/or IFG | | Annualized risk per 100 persons in IGT and/or IFG population
| | | Outcome: Progression to DM
| | | Yes | No
Risk group: IGT
STOP-NIDDM | Chiasson, 2002 ^68^ | 3.3 | 165 (by two OGTT) | 521 | 15.02
| | | 178 (by two FPG) | 508 | 8.70
| | | 285 (by one OGTT) | 401 | 8.00
Shougang | Li, 1999 ^82^ | 1.0 | 6 | 31 | 16.22
Da Qing | Li, 2002 ^66^ | 6.0 | 42 | 20 | 17.19
| Pan, 1997 ^67^ | 6.0 | 88 | 45 | 16.84
| Liao, 2002 ^99^ | 2.0 | 2 | 30 | 3.18
FDPS | Main result for this trial^+^: Tuomilehto, 2001 ^100^ | 3.2 | 59 | 188 | 8.18
DPP | Main result for this trial^++^: Molitch, 2003 ^176^ | 3.0 | 314* | 768 | 11.52
| Wein, 1999 ^50^ | 4.3 | 27 | 69 | 7.39
Risk group: IGT (Isolated)
Risk group: IFG
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Abbreviations: DM=Diabetes Mellitus; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance.

+ Other results for this trial: Lindi, 2002 ^101^ ; Lindstrom, 2003a ^103^ ; Lindstrom, 2003b ^178^

++ Other results for this trial : Knowler, 2002 ^102^

Table 17 Placebo arm of RCTs: Reversion to normal glycemia. (Note: All subjects in these trials had dysglycemia and only the annualized risk was estimated.)

Study Group | Author | Study Duration (years) | Baseline (n) IGT and/or IFG | | | Annualized risk per 100 persons in IGT and/or IFG population
| | | Outcome: Reversion to normal
| | | Yes | No
Risk group: IGT
STOP-NIDDM | Chiasson, 2002 ^68^ | 3.3 | 212 | | 474 | 10.60
Shougang | Li, 1999 ^82^ | 1.0 | 19 | | 18 | 51.35
| Wein, 1999 ^50^ | 4.3 | 43 | | 53 | 12.90
Risk group: IGT (Isolated)
Risk group: IFG
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Abbreviations: STOP-NIDDM=Study to Prevent Non-Insulin Dependent Diabetes Mellitus; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance.

Table 18 Placebo arm of RCTs: Mortality. (Note: All subjects in these trials had dysglycemia and only the annualized risk was estimated.)

Study Group | Author / Parameter | Study Duration (years) | Baseline (n) IGT and/or IFG | | Annualized risk per 100 persons in IGT and/or IFG population
| | | Outcome: Mortality
| | | Yes | No
Risk group: IGT
Da Qing | Pan, 1997 ^67^ | 6.0 | 3 | 130 | 0.38
| All cause mortality
Risk group: IGT (Isolated)
Risk group: IFG
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Abbreviations: IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance.

Table 19 Placebo arm of RCTs: Lipid and blood pressure. (Note: All subjects in these trials had dysglycemia.*)

Study Group | Author / Parameter | Study Duration (years) | Baseline (n) IGT and/or IFG
| | | Outcome: Metabolic
| | | n | Mean change in outcome of interest in control subjects
Risk group: IGT
None | Eriksson, 1999 ^177^ | 1 | 100
| - HDL Cholesterol | | | 0.01 ± 0.15^~^
| - Total Cholesterol | | | -0.1 ± 0.7^~^
| - Triglycerides | | | 0.00 ± 0.69^~^
| - BP (systolic) | | | -1.7 ± 12.4^~^
| - BP (diastolic) | | | -1.0 ± 9.6^~^
Main result: FDPS | Tuomilehto, 2001 ^100^ | 1 | 250
| - HDL Cholesterol | | | 1 ± 6^~^
| - Total Cholesterol | | | -4 ± 28^~^
| - Triglycerides | | | -1 ± 60^~^
| - BP (systolic) | | | -1 ± 15^~^
| - BP (diastolic) | | | -3 ± 9^~^
Other results: FDPS | Lindstrom, 2003 ^103^ | 2 | 250
| - HDL Cholesterol | | | 3 ± 7^~^
| - Total Cholesterol | | | 0 ± 7^~^
| - Triglycerides | | | 0 ± .75^~^
| - BP (systolic) | | | 0 ± 15^~^
| - BP (diastolic) | | | -3 ± 9^~^
| Lindstrom, 2003 ^178^ | 3 | 203
| - Serum Total Cholesterol | | | 0.1 ± 0.8^~^
| - Serum Triglycerides | | | -0.0 ± 0.8^~^
| Uusitupa, 2000 ^179^ | 1 | 143
| - HDL Cholesterol | | | +0.01^~^
| - Total Cholesterol | | | -0.13^~^
| - Triglycerides | | | -0.03^~^
| - BP (systolic) | | | -3^~^
| - BP (diastolic) | | | -1^~^
Risk group: IGT (Isolated)
Risk group: IFG
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

* Because most of these studies provided only change scores, we were unable to estimate risk.

~ change scores presented ± SD if given.

Abbreviations: BP=Blood pressure; FDPS=Finnish Diabetes Prevention Study; HDL=High density lipoprotein; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance.

1) The annualized risk for those with the exposure (IFG or IGT) for developing the outcome per 100 persons by one year. This annualized risk represents the incidence of the outcome for those with the exposure. Because the studies evaluated had different durations (1 to 18 years), risk estimates were standardized for one-year periods across all studies.
2) The annualized RR compares the risk in the exposure group (IFG or IGT) relative to the non-exposed group (NFG or NGT). The annualized RRs are based on the annualized risk calculations and are therefore unadjusted estimates. The 95% CI is also presented.
3) The risk difference estimates the difference in risk that is attributable solely to the exposure, in this case having IFG or IGT. This estimate is based on the annualized risk estimates.
4) The AR estimates the risk beyond the background risk for which the exposed and non-exposed groups are subject to. All persons irrespective of their exposure status are subject to progressing to DM. This risk is also termed the background risk due to factors other than their impaired glycemic status. AR, in part, assumes the potential for a causal relationship between the exposure (IFG or IGT) and the outcome of interest. The AR was expressed as a percent and computed for the duration of the study. The study duration varies, which means that the AR estimates cannot be directly compared across studies.

Each table lists the duration of each study, the raw numbers of the subjects with and without the outcome in each of the exposed (IFG or IGT) and unexposed (NFG or NGT) groups, and the estimates of risk. For example, the study by Charles et al. ^54^ in Table 9 lists four measures of the risk for developing DM in an individual with IGT. First, it shows that the annual risk of progressing to DM is 3.90 per 100 persons. Second, the table lists the unadjusted annualized RR, which is a measure of the strength of association between the exposure (IGT) and the outcome of interest (DM). In this example, an individual with IGT is 10.60 times more likely to develop DM within one year than an individual without IGT (95% CI 6.38 to 17.60). The fact that the CI excludes one, shows that this estimate is significant. Third, Table 9 lists the risk difference, which is the difference in annual risk between individuals with IGT and those without IGT (i.e., 3.54 per 100 persons in one year). Fourth, it lists the AR, which expresses the most that the risk could be reduced if the exposure (IGT) was both causally related to DM and completely eliminated. The estimate of 90.4% for the two-year duration of the study suggests that 9.6% of the risk for developing DM is due to other factors (background risk) and that 90.4% of DM cases could potentially be prevented if the IGT were successfully treated or eliminated. The AR may be used to inform decisions for prioritizing future population-based and clinical preventive interventions.

The annualized risk estimates for the outcome of reversion to NFG or NGT may present some challenge to the traditional clinical interpretation of risk. The typical understanding of risk is one associated with a negative consequence. Most therapeutic interventions are directed towards a change to normal glycemic status, and as such do not view reversion to normal levels as a pejorative outcome. For this reason, Table 10 presents only the annualized risk and risk difference (i.e., difference in risk for being normoglycemic at follow-up in dysglycemic versus normoglycemic people). Finally, several studies reported adjusted estimates of risk. These estimates were evaluated by various statistical models, including logistic regression, multivariate analyses, or proportional hazards modeling, and several covariates were evaluated. Some studies evaluated IFG or IGT populations only in their adjusted analyses. Others included the whole population of subjects (NFG or NGT or DM). As the analyses from these latter studies included an IFG or IGT variable, the “adjusted” estimate of risk for the outcome could be compared with the unadjusted estimate calculated in this report. This report describes some of these results.

### Risk for Progression to DM

Tables 9 and 16 detail the studies that evaluated progression to DM. The number of studies that provided data for the five classification groups varied. Studies of people with IGT (n = 36) were the most numerous, whereas five studies included people with IFG and three studies included people with I-IGT, I-IFG, and both IGT and IFG. In general the methodological quality of the epidemiologic studies varied from 9 ^62^ to 17. ^35^ For RCTs, the Jadad scores varied from 3 to 8 (Table 8).

Estimates of annualized risk per 100 persons in the exposed groups for progression to DM. The minimum and maximum annualized risk estimates for each of the five dysglycemic classification groups are as follows (Tables 9 and 16):

IGT group: | 1.83 to 34.12
I-IGT group: | 4.35 to 6.35
IFG group: | 1.60 to 23.44
I-IFG group: | 6.07 to 9.15
IGT and IFG group: | 9.96 to 14.95

Two epidemiological studies and four RCTs had particularly high annualized risk estimates. The epidemiological studies included populations with many risk factors for DM. The IGT study ^63^ with an estimate of 34.12 per 100 persons included subjects with a family history of DM, history of gestational DM, history of IGT, or obesity (with BMI > 27 kg/m2). The IFG study ^64^ with an estimate 23.44 per 100 persons came from the same centre as the above IGT study ^63^ and included subjects with a family history of DM, history of gestational DM, obesity (with BMI > 25kg/m ^2^ ), or hypertension (systolic BP > 140 mm Hg or diastolic BP > 90 mmHg). An RCT of people with IFG ^65^ included people with unstable angina or an MI in the previous month; three other RCTs ^66^ – ^68^ selected for people at high risk for conversion to DM as they were testing strategies to prevent DM.

The variation in the annualized risk per 100 persons observed in Tables 9 and 16 are likely related to the different populations, mean ages, and sample sizes in these studies. For example, in a series of studies evaluating Pima indigenous populations for the IGT classification group, the annualized risk varied from 6.39 to 10.53 per 100 persons. ^69^ – ^72^ In part, this could be due to subgroup analyses of the larger cohort, ^70^ use of different criteria for determining IGT and DM (WHO 85 versus ADA 97), and varying follow-up lengths. The differences in methodological quality may also have contributed to the variation.

Estimates of unadjusted annualized RR for progression to DM. Table 9 also shows the unadjusted annualized RR and CI for 28 studies. Three of the studies ^62,^ ^73,^ ^74^ within the IGT classification group were non-significant (i.e., contained one in the CI), indicating no association between IGT and progression to DM. Most of these studies had relatively small sample sizes. Three related studies ^75^ – ^77^ all evaluating the same cohort of South African Indians had very high unadjusted annualized RRs (39.44 to 31.71). These high estimates are most likely artifacts reflecting both the small sample sizes and the fact that no NGT subjects developed DM. For the remaining studies, the unadjusted annualized RR with 95% CI varied as a function of the diagnostic groups in the following manner (Tables 9 and 16):

IGT group: | 3.58 (2.12 to 6.06) to 10.60 (6.38 to 17.60)
I-IGT group: | 3.51 (2.22 to 5.54) to 8.63 (5.46 to 13.64)
IFG group: | 2.40 (1.71 to 3.37) to 9.04 (6.28 to 13.03)
I-IFG group: | 5.05 (2.86 to 8.90) to 9.85 (6.65 to 14.60)
IGT and IFG group: | 5.50 (3.25 to 9.30) to 20.69 (12.51 to 34.22)

As with the annualized risk per 100 persons, fewer studies were found in diagnostic categories other than IGT, and, as such, interpretation across classification groups may be limited.

Meta-analysis of the unadjusted annualized RR for progression to DM. Meta-analysis of unadjusted annualized RRs of DM were undertaken for each dysglycemic group. A series of studies ^75^ – ^77^ had no NGT subjects progress to the outcome of interest. To compute estimates of risk, a factor of 0.5 was added to all frequency counts in these studies (Table 9). The unadjusted RR estimates varied widely and we judged these to be inappropriate to include in the meta-analysis. It is likely that these estimates reflected the small sample size, and thus these studies were not included in the meta-analyses. As noted in Chapter 2, the pooled estimates were calculated using fixed-effects models unless there was evidence of statistical heterogeneity, in which case a random effects model was used. Evidence of heterogeneity was present for all of the dysglycemic groups except the I-IFG group.

Seventeen of 28 studies of people with IGT were included in the meta-analysis (Figure 6), and between three and five studies of people with the other glycemic classifications were included (Figure 7 to 10). The I-IGT, I-IFG, and IFG and IGT combined groups had approximately half the sample size of the remaining two dysglycemic groups and were based on estimates from the same three studies. The pooled estimates with the 95% CI are as follows (Tables 9 and 16):

Figure 8. Meta-analysis of annualized RR for progression to DM in IFG group

Figure 9. Meta-analysis of annualized RR for progression to DM in the I-IFG group

Figure 6. Meta-analysis of annualized RR for progression to DM in IGT group

Figure 7. Meta-analysis of annualized RR for progression to DM in I-IGT group

Figure 10. Meta-analysis of annualized RR for progression to DM in combined IFG and IGT groups

IGT group: | 6.02 (4.66 to 7.38) (p < 0.0001)
I-IGT group: | 5.55 (3.15 to 7.95) (p = 0.002)
IFG group: | 4.70 (2.71 to 6.70) (p = 0.0003)
I-IFG group: | 7.24 (5.30 to 9.17) (p = 0.0001)
IFG and I IGT group: | 12.21 (4.32 to 20.10) (p = 0.0054

To determine if statistical heterogeneity in the IGT group was due to one particular study, the analysis was repeated by removing one study at a time. This did not eliminate the heterogeneity. To determine if it was due to methodological weaknesses, the analysis was repeated after removing the three studies with the lowest methodological scores. ^62,^ ^78,^ ^79^ This approach similarly did not reduce heterogeneity.

Estimates of annualized risk difference per 100 persons/year for progression to DM. The range of estimate of annualized risk differences are as follows (Table 9):

IGT group: | 1.64 to 24.60
I-IGT group: | 3.62 to 5.51
IFG group: | 0.93 to 18.95
I-IFG group: | 5.35 to 7.33
IFG and IGT group: | 8.15 to 14.22

Two studies ^63,^ ^64^ recruited high-risk subjects, which could account for the higher risk differences (18.95 and 24.60). Similarly, the Vermes et al. ^65^ study recruited subjects with previous MIs, which may be a factor in the higher risk difference of 13.86 in the IFG group (Table 9).

Estimates of the AR (%) in the exposed group for the entire study duration for progression to DM. High estimates of AR were calculated for the outcome of DM in dysglycemic individuals. Estimates for each dysglycemic group are as follows (Table 9):

IGT group: | 52.8% to 97.0%
I-IGT group: | 68.8% to 86.6%
IFG group: | 57.3% to 86.9%
I-IFG group: | 77.1% to 88.5%
IGT and IFG group: | 78.6% to 93.0%

Thus, if there is a causal relationship between IFG or IGT and progression to DM, as many as 97% of cases of DM within the IGT group could be prevented by treating or eliminating dysglycemia.

Comparison of studies with different diagnostic groups for progression to DM. Table 20 lists estimates of risk for the three studies that evaluated more than two dysglycemic diagnostic groups. These studies represent very different populations, including Pima Indians, ^36^ Asians, ^80^ and Scandinavian subjects, ^35^ which could account for the differences in risk magnitude.

Table 20 Measures of risk for studies with more than one dysglycemia diagnostic group for the outcome of progression to DM

Author | IGT | I-IGT | IFG | I-IFG | IGT & IFG
Gabir, 2000 ^36^ | NT | R = 3.91 | NT | R = 6.05 | R = 7.92
Unadjusted annualized estimates | | RR = 5.95 [95% CI 4.61–7.67] | | RR =9. 85 [95% CI 6.65–14.60] | RR = 13.82 [95% CI 10.10–18.90]
| | RD = 3.19 AR% = 81.9^ | | RD = 5.33 AR% = 88.5^ | RD = 7.20 AR% = 91.3^
Li, 2003 ^80^ | NT | R = 5.44 | NT | R = 7.34 | R = 7.84
Unadjusted annualized estimates | | RR = 3.51 [95% CI 2.22–5.54] | | RR = 5.05 [95% CI 2.86–8.90] | RR = 5.50 [95% CI 3.25–9.30]
| | RD = 3.71 AR% = 68.8^ | | RD = 5.60 AR% = 77.1^ | RD = 6.11 AR% = 78.6^
Adjusted estimates from Proportional Hazard Model | | HR = 2.94 [95% CI 1.81–4.76] | | HR = 5.78 [95% CI 3.20–10.43] | HR = 6.17 [95% CI 3.41–11.15]
| | HR = 2.63 [95% CI 1.53–4.52] | | HR = 3.09 [95% CI 1.31–7.25] | HR = 5.16 [95% CI 2.50–10.67]
De Vegt, 2001 ^35^ | R = 4.94 | R = 5.14 | R = 5.76 | R = 5.03 | R = 9.59
Unadjusted annualized estimates | RR = 10.01 [95% CI 6.52–15.39] | RR = 8.63 [95% CI 5.46–13.64] | RR = 9.04 [95% CI 6.28–13.03] | RR = 8.40 [95% CI 5.50–12.83] | RR = 20.69 [95% CI 12.51–34.22]
| RD = 4.36 AR% = 88.5^ | RD = 4.43 AR% 86.6^ | RD = 4.98 AR% = 86.9^ | RD = 4.32 AR% = 86.3^ | RD = 8.88 AR% = 93.0^
Adjusted estimates from Logistic Regression Model | | OR=10.9* [95% CI 6.0–19.9] | | OR =10.0* [95% CI 6.1–16.5] | OR =39.5* [95% CI 17.0–92.1]

Abbreviations: R=annualized risk per 100 persons in the exposed population; RR=unadjusted annualized relative risk and [95% CI]; RD=Risk difference per 100 persons per year; AR%= percent attributable risk in the exposed population; NT=not tested; HR=Hazard ratio; OR=Odds ratio

^ = AR% is based on study duration of 5 years and 6.4 years for the DeVegt study.

* = OR adjusted for age, sex, and follow-up duration.

Although comparison across the dysglycemic classification groups is limited to these few studies, it suggests a gradient of increasing DM risk (as assessed by any metric) from IGT to IFG, and from IFG to both IFG and IGT. Two of these studies ^80,^ ^35^ reported adjusted analyses that also showed evidence of the gradient observed in the unadjusted estimates.

Evaluation of adjusted estimates of risk in studies evaluating progression to DM. Only 32 of the 104 studies reported multivariate regression analyses and estimates of risk associated with other risk factors. The types of statistical approaches, the population used in the statistical modeling (which often was a subgroup of the study population), and the covariates that were evaluated or significant in the model were abstracted. The factors evaluated in models included age, sex, BMI, WHR, family history of DM, smoking, hypertension, FPG, 2-hr PFG, (2-hour) fasting C-peptide, 2-hr fasting plasma insulin, 2-hr fasting plasma proinsulin, 2h-non-esterified fatty, fasting plasma triglyceride, genotype, hemoglobin-alpha, HDL, ratio of fasting insulin to glucose, illiac-to-thigh ratio, and photoparoxysmal response.

### Proportion of Individuals Reverting to NGT/NFG

Tables 10 and 17 list the annualized risk of reversion from IFG or IGT to normoglycemia (i.e., neither IFG nor IGT) and the absolute difference in this risk between these individuals and individuals who were normoglycemic at baseline.

Estimates of annualized risk per 100 persons in the exposed groups for reversion to normal glycemic status. Only two of the five dysglycemic groups (IGT and IFG) had eligible studies. The ranges of annualized risk of reverting to normal within the exposed group (per 100 persons) are as follows (Tables 10 and 17):

IGT group: | 2.66 to 51.35
IFG group: | 28.55

Five studies had relatively high annualized risk of reversion (15.77 to 51.35 per 100 persons) and three of these studies evaluated subjects of Asian descent ^63,^ ^64,^ ^81,^ ^82^ (Tables 10 and 17); one study evaluated male Paris police officers only ^54^ (risk 41.10 per 100 persons). The only study of women with polycystic ovary syndrome (PCOS) ^49^ had the lowest rate of reversion (risk 2.66 per 100 persons).

The absolute value of the annualized risk differences ranged from 12.53 to 53.06 per 100 persons. Thus up to 53% fewer people with IFG or IGT than normoglycemic people were normoglycemic after one year of follow-up.

Meta-analysis of unadjusted RR. Ten studies that reported reversion rates were pooled (Figure 11). The overall pooled estimate was 0.33 (0.23 to 0.43). The overall estimate would suggest that approximately one third of those with IGT will revert to normoglycemic status at follow-up. Test for heterogeneity was significant (p < 0.0001), suggesting the variability was not due to chance, and further exploration of the causes would be required. Most studies evaluated changes in dysglycemic status using a single test and likely this high rate of reversion is related to misclassification.

Figure 11. Meta-analysis of annualized RR for reversion to normal in IGT group

### Risk for Nonfatal CVD Outcomes

Table 11 details the estimates of risk for nonfatal CVD outcomes for IGT (n = 1) and IFG (n = 5). The outcomes characterizing CVD included atherothrombosis, non-stenotic atherosclerosis, clinical MI, PTCA, stroke, unstable angina, heart failure, and combinations of these (major event, any event). Study durations varied from five to nine years. All of the studies were published from 1998 forward. Three ^52,^ ^83,^ ^84^ of the five studies evaluating IFG as the risk factor are RCTs. One of these studies evaluated post-menopausal women with a history of MI from three to 20 months before recruitment. ^52^

Estimates of annualized risk per 100 persons in the exposed groups for nonfatal CVD outcomes. Estimates of annualized risk per 100 persons varied between the types of CVD events. The highest observed annualized risk was for the outcome of non-stenotic atherosclerosis in the IGT study ^85^ ; the lowest observed annualized risk was for stroke in people with IFG. ^52^ The range of annualized risk estimates are listed below (Table 11):

IGT group: | 11.58 to 12.39
IFG group: | 0.63 to 9.68

Estimates of unadjusted annualized RR for nonfatal CVD outcomes. Only two studies had significant unadjusted annualized RR (Table 11). The IGT study ^85^ had similar (2.43 and 2.46) estimates and CIs for both atherosclerosis groups. The risk estimate was 1.41 for the outcome of any CVD event within the IFG group for one study. ^86^ A second study ^83^ had a RR equal to 1.24 for the outcome of any CVD event. All of these studies had a lower boundary CI near one, suggesting near non-significance. The results (95% CI) for studies with significant unadjusted RRs were as follows (Table 11):

IGT group: | 2.43 (1.44 to 4.10) to 2.46 (1.46 to 4.12)
IFG group: | 1.24 (1.08 to 1.43) to 1.41 (1.17 to 1.69)

Meta-analysis of unadjusted annualized RR estimates for nonfatal CVD outcomes Figures 12 to 14 depict the meta-analyzed results for nonfatal outcomes. Nonfatal CVD outcomes were combined for the three subgroupings of 1) PTCA (and CABG), 2) stroke, and 3) any or major cardiovascular event.

Figure 12. Meta-analysis of annualized RR for non-fatal cardiovascular disease for PTCA/CABG in IFG group

Figure 14. Meta-analysis of annualized RR for non-fatal cardiovascular disease (or any major event) in IFG group

Tests for heterogeneity were not significant so a fixed-effects model was used. For the pooled estimates, two of the meta-analyses were not significant for the subgroups of PTCA and stroke (Figures 12 and 13). The pooled estimate for the outcome of any major cardiovascular event (Figure 14,) was significant (1.28 (1.15 to 1.41, p = 0.0001).

Figure 13. Meta-analysis of annualized RR for non-fatal cardiovascular disease for stroke in IFG group

Estimates of annualized risk difference per 100 persons/year for nonfatal CVD outcomes. The highest risk differences were observed in the sole IGT study; note that these values encompass different nonfatal CVD endpoints and they are as follows (Table 11):

IGT group: | 6.81 to 7.35
IFG group: | 0.01 to 1.90

Estimates of the AR (%) in the exposed group for the entire study duration for nonfatal CVD outcomes. The ARs for CVD outcomes were higher in the IGT group than in the IFG group. The estimates are as follows (Table 11):

IGT group: | 52.8% to 52.9%
IFG group: | 0% to 32.9%

Evaluation of adjusted estimates of risk in studies evaluating nonfatal CVD outcomes. Nine studies undertook statistical analyses to evaluate the independent contribution of the various risk factors. Five of these studies ^52,^ ^83,^ ^84,^ ^86,^ ^87^ employed proportional hazard modeling. Of the two studies ^85,^ ^88^ that evaluated IGT, one study ^88^ found IGT to be statistically significant for the outcome of carotid atherosclerosis, but the magnitude was not reported. The other study ^85^ found IGT to be non-significant and was based solely on the IGT population. A single study ^89^ evaluated IFG as an independent risk factor and was also not significant. One study ^86^ evaluated FPG and the 2-hr PG concurrently; however, only the FPG was significant (RR 1.66, 95% CI 1.39 to 1.98) for the outcome of any CVD event.

The multivariable analysis in these nine studies also evaluated age, smoking, cholesterol (HDL, LDL, and triglyceride), fibrinogen, sex, BMI, race, hypertension, prevastatin treatment group, FPG, 2hFG, FPI, gemfibrozil, creatinine, ferritin, apoliprotein B, and alcohol consumption. Models that did not pre-adjust for age showed that it was marginally significant in two studies. ^85,^ ^90^ Most models pre-adjusted for age, sex, and ethnicity; sex or ethnicity were not shown to be significant risk factors, whereas three studies ^85,^ ^87,^ ^88^ showed age to be significant.

### Risk for Fatal CVD Outcomes

Eight studies reported fatal CVD outcomes, which were subdivided into ischemic heart disease, cardiocerebrovascular, and coronary in some studies (Table 12). Although the classification of subgroups varied somewhat among studies, most used the International Classification of Diseases (ICD) coding system. The I-IFG and IFG and IGT combined classifications could not be evaluated as there were no eligible studies. Study duration varied from five to 18 years. Three of the studies ^43,^ ^55,^ ^59^ were based on a male cohort (Paris Police study) for the IGT, I-IGT, and IFG groups. Similarly, one study ^52^ within the IFG group included only post-menopausal women with a history of MI. Two other studies ^89,^ ^91^ in the IFG group recruited subjects with a history of either MI or coronary heart disease.

Estimates of annualized risk per 100 persons in the exposed groups for fatal CVD outcomes. The annualized risks per 100 persons in the exposed group are listed in Table 12 and 18. The ranges for the annualized estimates are as follows (Table 12):

IGT group: | 0.06 to 0.76
I-IGT group: | 0.23 to 0.34
IFG group: | 0.10 to 1.54

The differences in annualized risk are likely a function of the different study populations described previously above and the categorization of the CVD mortality subgroup classification.

Estimates of unadjusted annualized RR for fatal CVD outcomes. Four ^59,^ ^91^ – ^93^ of eight studies listed in Table 12 had unadjusted annualized RRs that were significant. The calculated estimates (95% CI) are as follows (Table 12):

IGT group: | 1.67 (1.23 to 2.26) to 3.08 (1.47 to 6.47)
I-IGT group: | 1.59 (1.07 to 2.28) to 1.72 (1.23 to 2.41)
IFG group: | 1.32 (1.04 to 1.67)

A single study within the IFG group had a marginally significant unadjusted RR. Tominaga et al. ^93^ evaluated CVD outcomes in both the IGT and IFG groups concurrently, and the annualized risks were 0.42 and 0.28 respectively per 100 persons.

Meta-analysis of the unadjusted annualized RR for fatal CVD outcomes. Figures 15 to 17 show the meta-analyses for the IFG and IGT groups. Within the IGT group CVD and ischemic heart disease were combined (Figure15). The pooled overall estimate was 1.66 (95% CI 1.21 to 2.11). Within the IFG group, two studies were based on the same cohort from the Bezafibrate Infarction Prevention trial, and one of these ^93^ was selected for meta-analysis. Two subgroups of fatal cardiovascular outcomes were selected for pooled estimates. Figure 16 shows the coronary heart disease (CHD)/CVD subgroup, and Figure 17 shows the pooled estimate for the subgroup of ischemic-related CVD mortality. The pooled estimates between the IGT and IFG groups do not differ substantively in magnitude; however only the IGT analysis was significant (with ischemic outcomes marginally so). Overall, the pooled estimates do not provide evidence of a significant association with IFG or IGT and fatal CVD outcomes.

Figure 15. Meta-analysis of annualized RR for cardiovascular disease mortality in IGT group

Figure 16. Meta-analysis of annualized RR for cardiovascular disease mortality in IFG group

Figure 17. Meta-analysis of annualized RR for cardiovascular disease related to Ischemic mortality in IFG group

Estimates of risk difference per 100 persons/year for fatal CVD outcomes. The risk differences vary within each dysglycemic classification as follows (Table 12):

IGT group: | 0.01 to 0.30
I-IGT group: | 0.09 to 0.14
IFG group: | 0.01 to 0.60

Tominaga et al. ^93^ evaluated CVD outcomes in both the IGT and IFG groups concurrently and the risk differences were 0.28 to 0.11, respectively.

Estimates of the AR (%) in the exposed group for fatal CVD outcomes. The AR for fatal CVD outcomes varied as follows (Table 12):

IGT group: | 24.8% to 67.3%
I-IGT group: | 36.8% to 41.2%
IFG group: | 11.8% to 39.5%

With the exception of one study, ^93^ the AR did not exceed 41%. Tominaga et al. ^93^ evaluated CVD outcomes in both the IGT and IFG groups concurrently, and the ARs were 67.3% and 39.5%, respectively.

### Risk for Mortality

In general, most studies that reported mortality outcomes had the largest sample sizes and some had the longest follow-up duration (up to 18 years) (Table 13 and 18). There were eligible studies within the IGT, I-IGT, and IFG classifications only; the I-IGT group was based on two studies on the same cohort.

Estimates of annualized risk per 100 persons for mortality in the exposed groups. Table 13 shows the annualized risk per 100 persons for mortality (all-cause, cancer, and cirrhosis categories). The ranges of the annualized risk are as follows (Tables 13 and 18):

IGT group: | 0.09 to 2.44
I-IGT group: | 0.10 to 1.34
IFG group: | 0.56 to 1.39

The annualized risks for mortality from cancer-related and cerebrovascular disease in the IGT group were the lowest values. In contrast, cirrhosis-related mortality was the highest for the I-IGT group.

Estimates of unadjusted annualized RR for mortality. Two studies in the IGT group ^88,^ ^94^ had non-significant results. The RR for all-cause mortality varied from 1.36 to 3.18 for the IGT group, and from 1.60 to 7.19 for the I-IGT group. One study showed a strong association between I-IGT and the outcome of death due to cirrhosis (RR 7.19) ^59^ for male police officers and also showed the highest AR (0.86) for mortality outcomes. Three studies ^43,^ ^89,^ ^93^ within the IFG group had non-significant results for all cause mortality.

Three studies ^55,^ ^91,^ ^93^ evaluated both all-cause mortality and CVD mortality; both the RR and the AR estimates were approximately double in magnitude for the CVD-related mortality relative to all causes with the exception of one study. ^93^ Two studies ^43,^ ^95^ compared all-cause mortality outcomes to cancer-related deaths, and the RR and AR did not differ substantively for these outcomes.

The all-cause mortality estimates (95% CI) are as follows (Table 13):

IGT group: | 36 (1.12 to 1.66) to 3.18 (1.79 to 5.63)
I-IGT group: | 60 (1.33 to 1.92) to 7.19 (3.37 to 15.37)
IFG group: | 1.18 (1.03 to 1.35) to 1.45 (1.27 to 1.66)

Meta-analysis of the unadjusted annualized RR for mortality. Figures 18 and 19 depict the meta-analysis for all-cause mortality in the IGT and IFG groups, respectively. Both these outcomes are marginally significant. As the Q test for heterogeneity was significant for the IGT group, a random effects model was used. The overall pooled estimates were 1.48 (1.09 to 1.86) for the IGT group and 1.21 (1.05 to 1.36) for the IFG group. To determine if statistical heterogeneity in the IGT group was due to one particular study, the analysis was repeated by removing one study at a time. In this analysis, the exclusion of one study ^94^ changed the significance of the test for heterogeneity (Q test 5.78, p = 0.216); the overall pooled estimate increased from 1.48 (95% CI 1.09 to 1.86) to 1.58 (1.29 to 1.86).

Figure 18. Meta-analysis of annualized RR for all-cause mortality in IGT group

Figure 19. Meta-analysis of annualized RR for all-cause mortality in IFG group

Estimates of risk difference per 100 persons/year for mortality. The ranges for the risk difference are as follows for all-cause mortality (Table 13):

IGT group: | 0.05 to 1.67
I-IGT group: | 0.06 to 0.50
IFG group: | 0.08 to 0.42

The difference for one study ^94^ may be related to the small sample size (fewer normal subjects than IGT subjects). This study also contributed significantly to the heterogeneity in the meta-analysis.

Estimates of the AR (%) in the exposed group for the study duration for mortality. The ARs for all-cause mortality are summarized below (Table 13):

IGT group: | 0.00% to 67.2%
I-IGT group: | 35.1% to 86.0%
IFG group: | 13.9% to 38.9%

The single study ^94^ with an AR equal to 0% has been previously noted for its sample size issues. As with the other risk metrics for mortality, the AR was highest (86%) for cirrhosis- related mortality. ^59^

### Risk for Lipid Disturbances, Hypertension, and Other Outcomes

Tables 14, 15, and 19 detail risk estimates for the studies that evaluated metabolic and other outcomes. The three studies that reported sufficient details regarding lipid type disturbances (Table 19) only reported mean change scores and therefore unable to estimate risk for these outcomes. In Table 14 one study ^96^ was specific to pancreas-kidney transplant patients and had limited generalizability to other populations. Another study ^98^ in Table 14 showed that the RR and AR for the outcome of hypertension was not significant for men but was for women. One study ^97^ evaluated the outcome of retinopathy and showed no significant relationship with IFG (Table 15).

## Treatment

### General Characteristics of the Treatment Studies

Twenty-three reports of 14 RCTs published between 1992 and 2003 evaluated lifestyle or pharmacotherapeutic interventions in adults with IFG or IGT. Table 21 shows the general characteristics of all studies. Duration of follow-up ranged from six months to six years. Studies involved 14 to 3234 participants with their mean ages ranging from 37.5 to 70 years. The studies included subjects from Europe, North America, Australia, and Asia. The trials evaluated a range of interventions, including diet and exercise, oral hypoglycemic agents (metformin, acarbose, and chromium), a statin (pravastatin), and an ACE inhibitor (enalapril). Outcomes included progression to DM or regression to NGT, cardiovascular complications, and the effects on BP and lipid levels (Tables 22 to 26). A meta- analysis was performed for the outcome of progression to DM by combining the four studies that used the intervention of diet and exercise (Figure 20).

Table 22 Randomized controlled trials: Progression to DM. Estimates of NNT and absolute risk reduction across diagnostic groups for IGT and/or IFG

Study Group | Author | Time to endpoint (y) | Intervention | Outcome | Number control subjects | Number control subjects with outcome of interest | Annual risk in control subjects (%) | Number treated subjects | Number treated subjects with outcome of interest | Annual risk in treated subjects (%) | P value | NNT per year | Annualized Absolute risk reduction per 100 persons
Risk group: IGT
Lifestyle intervention
| Liao, 2002 ^99^ | 2.0 | Diet and Exercise | DM | 32 | 2 | 3.18 | 32 | 1 | 1.57 | NS | 62.48 | 1.60
FDPS | Main results^+^: Tuomilehto, 2001 ^100^ | 3.2 | Diet and Exercise | DM | 247 | 59 | 8.18 | 253 | 27 | 3.47 | <0.001 | 21.23 | 4.71
Da Qing | Main results^++^: Pan, 1997 ^67^ | 6.0 | Diet | DM | 133 | 89 | 16.84 | 130 | 62 | 10.24 | <0.05 | 15.15 | 6.60
| | 6.0 | Exercise | DM | 133 | 89 | 16.84 | 141 | 58 | 8.45 | <0.05 | 11.93 | 8.38
| | 6.0 | Diet and Exercise | DM | 133 | 88 | 16.84 | 126 | 58 | 9.77 | <0.05 | 14.15 | 7.07
| Wein, 1999 ^50^ | 4.3 med | Diet | DM | 96 | 27 | 7.39 | 97 | 26 | 7.00 | NS | 254.44 | 0.39
DPP | Main results^+++^: Molitch, 2003 ^176^ | 3.0 | Metformin | DM | 1082 | 314* | 11.52 | 1073 | 236* | 8.49 | <0.001 | 32.97 | 3.03
| | 3.0 | Diet and Exercise | DM | 1082 | 314* | 11.52 | 1079 | 151* | 5.24 | <0.001 | 15.92 | 6.28
Pharmacotherapeutic intervention
STOP-NIDDM | Chiasson, 2002 ^68^ | 3.3 | Acarbose^a^ | DM | 686 | 285 | 15.02 | 682 | 221 | 11.19 | <0.0001 | 26.14 | 3.83
| | 3.3 | Acarbose^b^ | DM | 686 | 178 | 8.70 | 682 | 117 | 5.54 | .0010 | 31.67 | 3.16
| | 3.3 | Acarbose^c^ | DM | 686 | 165 | 8.00 | 682 | 105 | 4.94 | .0003 | 32.69 | 3.06
Shougang | Li, 1999 ^82^ | 1.0 | Metformin | DM | 37 | 6 | 16.22 | 33 | 1 | 3.03 | <0.011 | 7.58 | 13.19
Botnia | Lehtovirta, 2001 ^106^ | 0.5 | Metformin | DM | 20 | 1 | 9.75 | 20 | 1 | 9.75 | NS | NA | 0
Risk group: IGT (Isolated)
Risk group: IFG
| Vermes, 2003 ^65^ | 2.9 | Enalapril | DM | 138 | 31 | 8.40 | 153 | 9 | 2.07 | <0.0001 | 15.80 | 6.33
LIPID | Keech, 2003 ^83^ | 6.0 | Pravastatin | DM | 363 | 33 | 1.58 | 380 | 37 | 1.69 | 0.32 | 865.42~ | 0.12~
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Abbreviations: DM=Diabetes Mellitus; DPP=Diabetes Prevention Program; FDPS=Finnish Diabetes Prevention Study; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; NA=Not applicable; NNT=Number needed to treat; NS=Not significant; STOP-NIDDM=Study to Prevent Non-Insulin Dependent Diabetes Mellitus; LIPID=Long-term Intervention with Pravastatin in Ischemic Disease; y=Year(s).

* calculated from a percent;

a diagnosed by two OGTT;

b diagnosed by two FPG;

c diagnosed by one OGTT.

~ risk is higher for control subjects than for treated subjects.

+ Other reports of this trial : Lindi, 2002 ^101^ , Lindstrom, 2003 ^103^ , Lindstrom, 2003 ^178^

+ Other reports of this trial : Li, 2002 ^66^

+ + Other reports of this trial: Knowler, 2002 ^102^ , DPP group, 2003 ^216^

Table 23 Randomized controlled trials: Reversion to normal glycemic levels. Estimates of NNT and absolute risk reduction across diagnostic groups for IGT and/or IFG

Study Group | Author | Time to endpoint (years) | Intervention | Outcome | Number control subjects in analysis | Number control subjects with outcome of interest in analysis | Annual risk in control subjects (%) | Number treated subjects in analysis | Number treated subjects with outcome of interest in analysis | Annual risk in treated subjects (%) | P value | NNT per year | Annualized Absolute risk reduction per 100 persons
Risk group: IGT - Lifestyle intervention
| Liao, 2002 ^99^ | 2.0 | Diet and Exercise | NGT | 38 | 11 | 15.71 | 36 | 24 | 42.26 | 0.01 | 3.77~ | 26.56~
| Oldroyd, 2001 ^104^ | 0.5 | Diet and Exercise | NGT | 32 | 13 | 64.75 | 35 | 13 | 60.49 | NS | 23.49 | 4.26
| Wein, 1999 ^50^ | 4.3 | Diet | NGT | 96 | 43 | 12.90 | 97 | 43 | 12.73 | NS | 592.16~ | 0.17
Risk group: IGT - Pharmacotherapeutic intervention
STOP-NIDDM | Chiasson, 2002 ^68^ | 3.3 | Acarbose | NGT | 686 | 212 | 10.60 | 682 | 241 | 12.38 | <0.0001 | 56.22~ | 1.78~
Shougang | Li, 1999 ^82^ | 1.0 | Metformin | NGT | 37 | 19 | 51.35 | 33 | 28 | 84.85 | 0.011 | 2.99~ | 33.50~
Botnia | Lehtovirta, 2001 ^106^ | 0.5 | Metformin | NGT | 20 | 6 | 51.00 | 20 | 8 | 64.00 | NS | 7.69~ | 13.00~
Risk group: IGT (Isolated)
Risk group: IFG
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG
| Liao, 2002 ^99^ | 2.0 | Diet and Exercise | NGT | 38 | 11 | 15.71 | 36 | 24 | 42.26 | 0.01 | 3.77~ | 26.56~

Abbreviations: IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; NGT=Normal glucose tolerance; NNT=Number needed to treat; NS=Not significant; STOP-NIDDM=Study to Prevent Non-Insulin Dependent Diabetes Mellitus.

~ risk is higher for control subjects than for treated subjects

Table 24 Randomized controlled trials: Non-fatal cardiovascular disease. Estimates of NNT and absolute risk reduction across diagnostic groups for IGT and/or IFG

Study Group | Author | Time to endpoint (years) | Intervention | Outcome | Number control subjects | Number control subjects with outcome of interest | Annual risk in control subjects | Number treated subjects | Number treated subjects with outcome of interest | Annual risk in treated subjects | P value | NNT over year | Annualized Absolute risk reduction per 100 persons
Risk group: IGT
Risk group: IGT (Isolated)
Risk group: IFG
CARE | Goldberg, 1998 ^52^ | 5.0 | Pravastatin | CABG | 161 | 15 | 1.94 | 181 | 13 | 1.48 | NR | 218.65 | 0.46
| | 5.0 | Pravastatin | PTCA | 161 | 17 | 2.21 | 181 | 16 | 1.83 | NR | 268.03 | 0.37
| | 5.0 | Pravastatin | Stroke | 161 | 5 | 0.63 | 181 | 3 | 0.33 | NR | 338.67 | 0.30
| | 5.0 | Pravastatin | Unstable Angina | 161 | 28 | 3.75 | 181 | 29 | 3.43 | NR | 315.49 | 0.32
LIPID | Keech, 2003 ^83^ | 6.0 | Pravastatin | CHD Mortality [underlined: AND] Non-fatal MI | 466 | 83 | 3.22 | 474 | 56 | 2.07 | NR | 87.51 | 1.14
| | 6.0 | Pravastatin | CVD | 466 | 213 | 9.68 | 474 | 176 | 7.44 | NS | 44.74 | 2.24
| | 6.0 | Pravastatin | CABG or PTCA | 466 | 77 | 2.97 | 474 | 64 | 2.39 | NS | 173.39 | 0.58
| | 6.0 | Pravastatin | Stroke | 466 | 25 | 0.91 | 474 | 16 | 0.57 | NS | 290.58 | 0.34
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Abbreviations: CABG=Coronary artery bypass graft; CARE=Cholesterol and Recurrent Events Study; CHD=Coronary heart disease; CVD=Cardiovascular disease; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; LIPID=Long-term Intervention with Pravastatin in Ischemic Disease; MI=Myocardial infarction; NR=Not reported; NS=Not significant; NNT=Number needed to treat; PTCA=Percutaneous transluminal coronary angioplasty.

Table 25 Randomized controlled trials: Mortality. Estimates of NNT and absolute risk reduction across diagnostic groups for IGT and/or IFG

Study Group | Author | Time to endpoint (years) | Intervention | Outcome | Number control subjects in analysis | Number control subjects with outcome of interest in analysis | Annual risk in control subjects (%) | Number treated subjects in analysis | Number treated subjects with outcome of interest in analysis | Annual risk in treated subjects (%) | P value | NNT per year | Annualized Absolute risk reduction per 100 persons
Risk group: IGT
Da Qing | Pan, 1997 ^67^ | 6.0 | Diet | All cause mortality | 133 | 3 | 0.38 | 130 | 3 | 0.39 | NR | 11307.08~ | 0.01~
| | 6.0 | Exercise | All cause mortality | 133 | 3 | 0.38 | 141 | 0 | 0.00 | NR | 263.49 | 0.38
| | 6.0 | Diet and Exercise | All cause mortality | 133 | 3 | 0.38 | 126 | 5 | 0.67 | NR | 341.23~ | 0.29~
Risk group: IGT (Isolated)
Risk group: IFG and previous MI
CARE | Goldberg, 1998 ^52^ | 5.0 | Pravastatin | CHD mortality | 161 | 12 | 1.54 | 171 | 11 | 1.32 | NR | 462.47 | 0.22
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Abbreviations: CARE=Cholesterol and Recurrent Events Study; CHD=Coronary heart disease; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; MI=Myocardial infarction; NNT=Number needed to treat; NR=Not reported.

~ risk is higher for control subjects than for treated subjects.

Table 26 Randomized controlled trials: Lipid and blood pressure. Effects across diagnostic groups for IGT and/or IFG

Study Group | Author | Time to endpoint (years) | Intervention | Outcome | Number control subjects | Mean value for control subjects (± SD) | Number treated subjects | Mean value for treated subjects (± SD) | P value
Risk group IGT
FDPS | Main result^+^ Lindstrom, 2003 ^103^ | 2 | Diet and Exercise | HDL Cholesterol mg/dl | 250 | 3 ± 7^~^ | 256 | 4± 7^~^ | 0.2003
| | 2 | Diet and Exercise | Total Cholesterol mg/dl | 250 | 0 ± 7^~^ | 256 | -4 ± 31^~^ | 0.1834
| | 2 | Diet and Exercise | Triglycerides mg/dl | 250 | 0 ± .75^~^ | 256 | -18 ± 53^~^ | 0.0026
| | 2 | Diet and Exercise | Ratio of TC to HDL | 250 | -0.3 ± 0.8^~^ | 256 | -0.6 ± 0.9^~^ | 0.0009
| | 2 | Diet and Exercise | BP (systolic) mmHg | 250 | 0 ± 15^~^ | 256 | -5 ± 14^~^ | 0.0005
| | 2 | Diet and Exercise | BP (diastolic) mmHg | 250 | -3 ± 9^~^ | 256 | -5 ± 9^~^ | 0.0124
| Oldroyd, 2001 ^104^ | 0.5 | Diet and Exercise | HDL Cholesterol mmol/l | 32 | 0.06 ± 0.21^~^ | 35 | 0.04 ± 0.19^~^ | NS
| | | Diet and Exercise | LDL Cholesterol mmol/l | 32 | -0.21 ± 0.61^~^ | 35 | -0.10 ± 0.54^~^ | NS
| | | Diet and Exercise | Total Cholesterol mmol/l | 32 | -0.18 ± 0.59^~^ | 35 | -0.16 ± 0.55^~^ | NS
| | | Diet and Exercise | Triglycerides mmol/l | 32 | -0.01 ± 0.67^~^ | 35 | -0.22 ± 0.78^~^ | NS
| | | Diet and Exercise | BP (systolic) mmHg | 32 | -0.27 ± 14.3^~^ | 35 | -0.79 ± 16.7^~^ | 0.050
| | | Diet and Exercise | BP (diastolic) mmHg | 32 | 1.9 ± 10.0^~^ | 35 | -2.9 ± 9.9^~^ | 0.052
| Ericksson, 1997 ^108^ | 0.5 | Exercise | Cholesterol mmol/l | 7 | 0^ | 7 | 0.10^ | NS
| | | | HDL cholesterol mmol/l | 7 | -0.04^ | 7 | 0.09^ | NS
| | | | Triglycerides mmol/l | 7 | 0.23^ | 7 | -0.03^ | NS
| | | | Systolic BP mmHg | 7 | 13^ | 7 | 4^ | NS
| | | | Diastolic BP mmHg | 7 | -7^ | 7 | -3^ | NS
Botnia | Lehtovirta, 2001 ^106^ | 0.5 | Metformin | Cholesterol mmol/l | 20 | 0.1^ | 20 | -0.1^ | NS
| | | | HDL cholesterol mmol/l | 20 | 0.08^ | 20 | -0.01^ | NS
| | | | Triglycerides mmol/l | 20 | 0.33^ | 20 | 0.10^ | NS
| | | | Systolic BP mmHg | 20 | -5^ | 20 | -8^ | NS
| | | | Diastolic BP mmHg | 20 | -1^ | 20 | -4^ | NS
| Uusitupa, 1992 ^109^ | 0.5 | Chromium | Cholesterol mmol/l | 11 | 0^ | 13 | -0.1^ | NS
| | | | HDL cholesterol mmol/l | 11 | 0.06^ | 13 | 0.07^ | NS
| | | | LDL cholesterol mmol/l | 11 | -0.1^ | 13 | -0.2^ | NS
| | | | Triglycerides mmol/l | 11 | 0.1^ | 13 | -0.5^ | NS
Risk group: IGT (Isolated)
Risk group: IFG
Risk group: IFG (isolated)
Risk group: Multiple IGT/IFG

Abbreviations: BP=Blood pressure; CHD=Coronary heart disease; FDPS=Finnish Diabetes Prevention Study; HDL=High density lipoprotein; IFG=Impaired fasting glucose; IGT=Impaired glucose tolerance; LDL=Low density lipoprotein; MI=Myocardial infarction; NNT=Number needed to treat; NR=Not reported; NS=Not significant; SD=Standard Deviation; TC=Total cholesterol.

^ change scores were calculated from pre and post values; no SD was estimated.

~ change scores presented with SD.

+ Other results for this trial: Lindstrom, 2003 ^178^ ;Tuomilehto, 2001 ^100^ ;Uusitupa, 2000 ^179^ ;Eriksson, 1999 ^177^

Figure 20. Meta-analysis of progression to DM for four studies that evaluated combined exercise and diet interventions. Pooled overall estimate, presented as a RR, 95% CI

### Progression to DM: Lifestyle Interventions

Six RCTs evaluated the effect of lifestyle interventions on the risk for developing DM or reverting to NGT. The studies all involved adults with IGT. To be eligible, participants were required to have evidence of IGT on two separate OGTTs, ^99,^ ^100^ or to have an IFG level along with evidence of IGT on a single OGTT. ^101,^ ^102^ Two trials ^50,^ ^67^ enrolled individuals on the basis of a single OGTT. Table 22 details these studies.

Five studies ^67,^ ^99,^ ^102^ – ^104^ compared intensive combined diet and exercise programs that involved frequent study visits with lifestyle advice alone ^67,^ ^99,^ ^102^ – ^104^ One study compared an exercise program with advice alone, ^67^ and two studies evaluated the effect of dietary intervention alone. ^50,^ ^67^ One trial, the Diabetes Prevention Program (DPP), also included a metformin arm. ^102^ The studies involved 64 to 3234 participants and the duration of follow-up ranged from six months to six years. Methodological quality scores ranged from 3 to 5 out of 8 for the modified Jadad scale, with a maximum possible score of 6 out of 8, given the fact that these trials were not blinded.

All but one of the trials that evaluated a combined diet and exercise program found a significant reduction in the risk for developing DM, or a higher rate of regression to NGT, with aggressive lifestyle modification. The absolute risk reduction for progressing to DM per year in the studies varied between 1.6% and 7.1%. The relative risk reduction (RRR) for progressing to DM in the intervention arms of the trials compared with the control arms was between 31% and 55%. The NNT for one year to prevent a case of DM was between 14.2 and 62.5.

Dietary intervention alone significantly reduced the risk for progressing to DM in one trial, ^67^ but had no effect in a second study. ^105^ The trial that evaluated an exercise intervention alone ^67^ showed a significantly reduced rate of progression to DM (ARD 8.4%, NNT 11.9, RRR 49.8%).

The meta-analysis of the 4 studies ^67,^ ^99,^ ^100,^ ^102^ that evaluated a combined diet and exercise intervention on progression to DM yielded a RR of 0.54 (95% CI 0.42–0.70).

### Progression to DM: Pharmacotherapeutic Interventions

Four RCTs evaluated the effects of pharmacotherapeutic interventions on the risk for developing DM in people with IGT. ^68,^ ^82,^ ^102,^ ^106^ These studies assessed the effect of acarbose and metformin. The effect of enalapril in people with IFG and left ventricular dysfunction was assessed in a retrospective post-hoc subgroup analysis. ^65^ The effect of pravastatin on the development of DM in people with IFG and a previous MI was assessed in a retrospective post-hoc subgroup analysis. ^83^

Acarbose. The STOP-NIDDM trial ^68^ involved 1429 people with IGT and a fasting blood glucose value of 5.6 to 7.7 mmol/L and randomized participants to placebo or acarbose at a dose of 100 mg three times daily Follow-up was for a mean of 3.3 years. The methodological quality score was 8 out of 8 for the modified Jadad scale. The study demonstrated a reduced risk for progressing to DM (32% versus 42%; RRR 0.25, 95% CI 0.10 to 0.37). This effect did not vary by age, sex, or BMI. The study also demonstrated an increased rate of reversion to NGT with acarbose relative to placebo (35% versus 31%, p < 0.0001).

Metformin. Three RCTs evaluated the effect of metformin in people with IGT. The methodological quality scores for the studies ranged from 6 to 7 out of 8 for the modified Jadad scale.

The largest study was the Diabetes Prevention Program, ^102^ which involved 3234 people with IGT and a fasting blood glucose value of 5.6 to 6.9 mmol/L and followed participants for a mean of 2.8 years. Metformin was taken at a dose of 850 mg twice daily. The study found a significantly reduced risk of progressing to DM when taking metformin relative to placebo (7.8% versus 11.0% per year; RRR 0.31, 95% CI 0.17 to 0.43).

An unplanned subgroup analysis found that metformin was significantly more effective in individuals with a markedly elevated BMI of > 35 kg/m ^2^ than in individuals with lower BMI levels (RRR for individuals with BMI > 35 kg/m ^2^ 53%, 95% CI 36% to 65%; RRR for individuals with BMI 30 to 35 kg/m ^2^ 16%, 95% CI -19% to 41%; RRR for individuals with BMI 22 to 30 kg/m ^2^ 3%, 95% CI -36% to 30%). Metformin was also significantly more effective in individuals with higher fasting glucose levels (RRR for individuals with fasting glucose 6.1 to 6.9mmol/L, 48%, 95% CI 33% to 60%; RRR for individuals with fasting glucose 5.27 to 6.05 mmol/L 15%, 95% CI -12% to 36%).

A smaller study ^106^ involving 40 people with IGT confirmed on two separate glucose tolerance tests followed participants for one year. Patients in the active arm were treated with metformin 500 mg twice daily. Progression to DM was identical in each arm of the study (5%). Regression to NGT was not significantly different between the arms (40% with metformin and 30% with control).

The third trial ^82^ involved a total of 90 individuals with IGT confirmed on two separate glucose tolerance tests. Patients in the active arm of the study received metformin at a dose of 250 mg three times daily. Follow-up was for one year. The risk for progressing to DM was not significantly decreased when taking metformin (6.7% versus 13.3%; ARD 6.7%, 95% CI - 6.9% to 20.2%). The study did note an increased rate of reversion to NGT with metformin (72.7% versus 51.1%; ARD 21.6%, 95% CI 0.6% to 42.6%).

Enalapril. A retrospective subgroup analysis of the SOLVD trial participants from a single site evaluated the effect of enalapril at a dose of five to 20 mg per day in people with IFG and left ventricular dysfunction. ^65^ The subgroup included 55 individuals with IFG diagnosed on the basis of a baseline fasting glucose level of 6.1 to 6.9 mmol/L (110 to 125 mg/dL). The diagnosis of new onset DM during the trial was based on the finding of a fasting glucose level of 7.0 mmol/L or greater on two separate visits. Chart reviewers were blinded to treatment allocation. Duration of follow-up was 2.9 years. The study found a decreased risk for progression to DM in the enalapril arm relative to the placebo arm (3.3% versus 48%, p = 0.0001).

Pravastatin. In the LIPID trial, a subgroup of 940 individuals with IFG and a previous MI were randomly allocated to treatment with either pravastatin 40 mg daily or placebo and followed for six years. ^83^ A retrospective analysis found no effect on the rate of development of DM (fasting blood glucose level of 7 mmol/L or greater) or reported use of oral hypoglycemic medication or insulin. DM developed in 9.7% of people with IFG in the pravastatin group and 9.2% of people with IFG in the placebo group (p > 0.05) as reported in the study.

### Comparing Lifestyle with Pharmacotherapeutic Interventions for the Prevention of DM in Individuals with IGT

The Diabetes Prevention Program (DPP) ^102^ has directly compared the effects of an aggressive lifestyle intervention that addressed both diet and exercise with a pharmacotherapeutic intervention (metformin) for the prevention of DM in individuals with IGT. The DPP followed 3234 people for a mean of 2.8 years. Metformin was taken at a dose of 850 mg twice daily. The methodological quality score for the study was 5 out of 8 for the modified Jadad scale. The study found a significantly lower risk for progressing to DM with aggressive lifestyle intervention compared with taking metformin (4.8% versus 7.8% per year; RRR 0.39, 95% CI 0.24 to 0.51).

The beneficial effects of lifestyle intervention, compared with metformin, were especially marked in individuals 60 years of age or older (age 60 years or older 3.1% versus 9.6% per year, RRR 0.69, 95% CI 0.47 to 0.82; age 45 to 59 years 4.7% versus 7.6% per year, RRR 0.41, 95% CI 0.18 to 0.57; age 25 to 44 years 6.2% versus 6.7% per year, RRR 0.08, 95% CI -0.36 to 0.37) and in people with a body mass index < 35 kg/m ^2^ (BMI 22 to 30 kg/m ^2^ 3.3% versus 8.8% per year; RRR 0.63, 95% CI 0.44 to 0.76; BMI 30 to 35 kg/m ^2^ 3.7% versus 7.6% per year; RRR 0.53, 95% CI 0.28 to 0.72; BMI 35 kg/m ^2^ or over 7.3% versus 7.0% per year, RRR 0.04, 95% CI 0.47 to 0.26).

### Cardiovascular Outcomes: Lifestyle Interventions

No RCTs of lifestyle interventions evaluated cardiovascular outcomes.

### Cardiovascular Outcomes: Pharmacotherapeutic Interventions in People with IGT

Acarbose. One RCT ^107^ evaluated the effect of acarbose on cardiovascular event rates in people with IGT. The STOP-NIDDM trial ^107^ involved 1429 people with IGT and a fasting blood glucose value of 5.6 to 7.7 mmol/L and randomized participants to placebo or acarbose at a dose of 100 mg three times daily Follow-up was for a mean of 3.3 years. The methodological quality score was 8 out of 8 for the modified Jadad scale. The primary outcome was the development of a major cardiovascular event (MI, new angina, cardiac revascularization procedure, cardiovascular death, congestive heart failure, cerebrovascular event, and peripheral vascular disease). The trial found a significant reduction in the risk for developing a major cardiovascular event in the acarbose arm compared with the placebo arm of the study (RRR 0.49, 95% CI 0.05 to 0.72; ARD 2.5%). Participants' mean age was 54.5 years.

### Cardiovascular Outcomes: Pharmacotherapeutic Interventions in People with a Previous MI and IFG

Two post-hoc retrospective subgroup analyses evaluated the effect of pravastatin therapy on cardiovascular event rates in people with a previous MI and IFG. Both trials assessed IFG status using a single fasting glucose test at baseline (fasting glucose 6.1 to 6.9 mmol/L; 110 to 125 mg/dL). Table 24 details the annualized estimates from these trials.

In the LIPID trial, ^83^ a subgroup of 940 individuals with IFG and a previous MI were randomly allocated to either pravastatin 40 mg daily or placebo and followed for six years. ^83^ The rate of cardiovascular death or nonfatal MI was significantly lower in the pravastatin group. The RRR was 36% (absolute event rate 17.8% in the control arm versus 11.8% in the pravastatin arm, p = 0.009) as reported in the study. The RRR of 36% was not significantly different from the RRR of 23% found in individuals with NFG levels at baseline (absolute event rate 14.5% in the control arm versus 11.3% in the pravastatin arm, p < 0.001 as reported in the study).

In the CARE trial, ^52^ a total of 342 individuals with IFG and a previous MI were randomly allocated to either pravastatin 40 mg daily or placebo and followed for an average of five years. ^52^ The study found an RR for the outcome of cardiovascular death or a nonfatal MI of 0.77 (p > 0.05), a result that was not significantly different from the RR of 0.72 for individuals with NFG levels at baseline.

### Mortality Outcomes: Lifestyle and Pharmacotherapeutic Interventions

One trial ^67^ reported the effect of lifestyle intervention on total mortality rates in individuals with IGT. ^67^

In the Da Qing trial, ^67^ individuals with IGT were allocated to one of four groups (control, dietary intervention, exercise intervention, or combined dietary and exercise intervention) and followed for six years. The methodological quality score was 3 out of 8 for the modified Jadad scale. Mortality rates were not significantly different between the groups (2.3%, 2.3%, 0%, and 4.0%, respectively).

### Microvascular Outcomes

No RCTs evaluated the effect of lifestyle interventions or pharmacotherapeutic interventions on microvascular outcomes in individuals with IFG or IGT.

### Blood Pressure and Lipid Levels: Lifestyle Interventions

Three RCTs evaluated the effect of lifestyle interventions on BP and lipid levels in people with IGT. ^103,^ ^104,^ ^108^ Table 26 details some of the findings for these studies.

The Finnish Diabetes Prevention study ^103^ randomized 522 individuals with IGT to an intensive lifestyle intervention program or a control group and followed them for a mean of 3.2 years. The methodological quality score was 6 out of 8 for the modified Jadad scale. BP levels improved significantly more in the intervention group relative to the control group. Systolic BP fell five mm Hg in the intervention arm and 0 mm Hg in the control group when measured after two years (p = 0.0005). Diastolic BP fell five mm Hg in the intervention group and 3 mm Hg in the control group (p = 0.0125). The total cholesterol-to-HDL cholesterol ratio declined significantly more in the intervention group (0.6) compared with the control group (0.3) after three years (p = 0.0009). The total cholesterol and HDL cholesterol level changes did not differ in the trial. Serum triglyceride levels showed a greater decline in the active arm than in the control arm (0.1 mmol/L versus 0.0mmol/L, p = 0.024).

In a smaller trial, ^104^ 67 people with IGT were randomly allocated to a diet and exercise program or control and followed for six months A significant improvement in systolic BP was noted with the lifestyle intervention. Systolic BP fell 7.6 mm Hg more in the intervention arm than in the control arm (p = 0.05). In the same study, the reduction in the diastolic BP level was 4.9 mm Hg more in the intervention arm than in the control arm (p = 0.052). No significant changes were found in lipid levels. The methodological quality score was 5 out of 8 for the modified Jadad scale.

No significant differences in BP or lipid levels were noted between intervention and control arm patients involved in a small trial ^108^ of exercise alone that involved a total of 14 participants followed for six months.

### Blood Pressure and Lipid Levels: Pharmacotherapeutic Interventions

Four RCTs reported the effects of oral hypoglycemic agents on BP and lipid levels in people with IGT. Table 26 details the findings for these studies.

Two trials reported the effects of metformin on BP levels in people with IGT. ^82,^ ^106^ The two trials involved 40 and 90 participants, respectively, and both had a follow-up duration of 12 months. Metformin was dosed at 500 mg twice daily in one trial and 250 mg three times daily in the second trial. The trials demonstrated no significant effect of metformin on BP or lipid levels.

The STOP-NIDDM trial reported the effects of acarbose therapy on BP and lipid levels in people with IGT. ^68,^ ^107^ The study enrolled 1429 individuals and had a mean follow-up duration of three years. Systolic BP was reduced by 0.97 mm Hg in the treatment arm, compared with 0.05 mm Hg in the control arm, p < 0.001. Diastolic BP fell by 2.8 mm Hg in the treatment arm and 1.4 mm Hg in the control arm (p = 0.008). Hypertension was defined as a BP of at least 140/90 on two consecutive visits to the family physician or the addition of antihypertensive medications between visits. The risk for developing hypertension was significantly reduced with the use of acarbose. In the active arm, 11% of participants developed hypertension compared with 17% in the placebo group (RR 0.66, 95% CI 0.49 to 0.89, p = 0.006; ARD 5.3%). The trial noted a significant reduction in triglyceride levels. Triglyceride levels decreased by 0.18 mg/dL over three years in the active arm, compared with 0.04 mg/dl in the control arm.

A trial of chromium ^109^ at a dose of 160 μg per day in 26 individuals with IGT found no significant effects on lipid levels at six months.

## Pediatric Population

### General Characteristics of the Pediatric Studies

It was expected that the number of pediatric studies would be limited. All articles that met the general criteria (English language, full-text publication, published since 1979, and results for IFG or IGT analyzed separately from other study populations) and included children with IFG or IGT were collected (36 articles). Of these, a subset of five articles met the criteria for diagnosis, prognosis, or treatment according to the criteria outlined in the Methodology (see Table 27). These articles are included in the analysis of their respective sections. Four articles (one diagnosis, three prognosis) included participants 15 years of age and older, but these data were not presented separately (i.e., included with adult data) and were therefore excluded. ^51,^ ^75,^ ^110,^ ^111^

Table 27 Pediatric studies included in the main review

Author | Inclusion in pediatric review | Study type | Duration | # male | # female | Age (y) | Ethnic | IGT 75g cut-offs (mmol/L) | Population | Included for Main Review
Zimmet ^132^ , 1984, Naura | Included in main review; included in pediatric portion | prospective cohort | 6–8 y | 118 | 148 | 0–60+ | Micronesian (Nauruans) | WHO 80: (7.8–11.0) | Micronesian (Nauruans). | Prognosis
| | | mean:6.2 y | | | | | NDDG 79: (7.8–11.0)
Rosenbloom ^111^ , 1982, USA | Included in main review; not included in pediatric portion | prospective cohort | 5–12 y | 4 | 13 | 1.4–20.5 | Not Reported | NDDG 79: (7.8–11.0) | 37 children with stress hyperglycemia, asymptomatic glucosuria or possible hypoglycemia. | Prognosis
Pettitt ^51^ , 1996, USA | Included in main review; not included in pediatric portion (15–39 y with no pediatrics distinction) | prospective cohort | 0.5–10y | | 317 | 15–39 | Pima Indians | WHO 85: (7.8–11.0) | Women of at least half Pima and Tohono O’odham heritage All had IGT at 15–39 yr after at least 1 pregnancy | Prognosis
Nagi ^110^ , 1995, USA | Included in main review; not included in pediatric portion (13.2–51.4 y with no pediatrics detail) | prospective cohort | 1–17.24y | | | mean: 32.6 | Pima Indians | WHO 85 (7.8–11.0) | Pima Indians from Gila River Arizona. | Diagnosis
| | | median 5 y | | | | | | | Prognosis
Motala ^75^ , 1993, Africa | Included in main review; not included in pediatric portion (> 15y with no pediatrics detail) | prospective cohort | 4 y | 67 | 61 | 16+ | South African Indians | WHO 85 (7.8–11.0) | South African Indians. Residents of Durban, S. Africa. | Prognosis
| | | | | | | | WHO 80 (8.0–10.9)

Abbreviations: IGT=Impaired glucose tolerance; NDDG= National Diabetes Data Group; WHO=World Health Organization; y=Year(s).

An additional 31 articles that met the general inclusion criteria, but not the criteria for inclusion in the diagnosis, prognosis, or treatment sections, included subjects < 18 years of age. In 12 of these studies, the pediatric information could be extracted separately and was relevant to IGT in individuals < 18 years of age. Most studies addressed the prevalence of IFG or IGT in various at-risk populations and in the population at large. Two studies compared IFG with IGT for diagnosis in children. Four studies examined longitudinal follow-up of a cohort of children and addressed the prognosis of IFG or IGT. One study examined treatment in an open-label trial with metformin (see Table 28).

Table 28 Pediatric studies evaluated but not included in the main review

Author | Study type | Duration | Male n | Female n | Population characteristics | Age range, years | Mean age, years (SD) | Ethnicity (n) | Study group | Issue addressed | IGT and/or IFG prevalence (%)
Arslanian ^217^ 2001 | CS | 1–2 w | NR | 21 | PCOS IGT, NGT or DM | NR | IGT: 14.4 (0.9) | B (9), W (12) | NR | PREV | 42.9
| | | | | | | NGT: 13.1 (0.8)
Arslanian ^139^ 2002 | OS | 3 m | NR | 15 | PCOS Metformin treatment | NR | 14 (0.8) | B (6), W (9) | NR | RX
Braun ^131^ 1996 | PC | 5 y | 32 | 42 | Aboriginal (Australia) | NR | male: 13.1 (2.5) | Ab | NR | PREV/ PROG | Male: 9.39
| | | | | | | female: 13.5 (3.2) | | | | Female: 4.7
de Courten ^9^ 1996 | PC | 12.3 y | C: 1318 | C: 1349 | Aboriginal (Pima) | C: 6–17 | C: NR | Ab | Pima | PREV/ PROG | 4
| | | A: 1830 | A: 2485 | | A: ≥ 18 | A: 39.5
Fagot-Campagna ^137^ 2001 | CS | 6 y | NR | NR | US Pop based | 12–19 | 16 | | NHANES III | PREV/ DIAG | 1.76 IFG (CI 0.02 – 3.5)
Invitti ^134^ 2003 | CS | 2 w | 345 | 365 | obese | 6–18 | 14 | E | NR | PREV/ DIAG | 4.2
Knowler ^14^ 1990 | PC | 20 y | NR | NR | Aboriginal | ≥ 5 | NR | Ab, W | Pima | REVIEW
Silverman ^133^ 1995 | PC | 6 y | 90 | 78 | ODM | ≥ 1.5 | control: 12.8 (1.7) | NR | NR | PREV/ PROG | <5 y: 1.2
| | | | | | | ODM: 12.3 (1.7) | | | | 5–9 y: 5.4
| | | | | | | | | | | 10–16 y: 18.2
Silverman ^136^ 1998 | PC | 6 y | NR | NR | ODM | NR | NR | B, H, W | NR | PREV/ PROG | 14–17 y:
| | | | | | | | | | | 36% had at least one test with IGT
Sinha ^12^ 2002 | CS | NR | C: 17 | C: 38 | obese | 4–18 | C/male: 8 (0.3) | B (38), H (32), W (97) | NR | PREV/DIAG | 4–10 y: 25.4
| | | Ad: 54 | Ad: 58 | | | C/female: 7 (0.3) | | | | 11–18 y: 20.5
| | | | | | | Ad/male: 14 (0.2)
| | | | | | | Ad/female: 14 (0.2)
Zimmet ^130^ 1992 | PC | 12 y | NR | NR | Aboriginal (Nauruan Tuvalu) | 8 –19 | NR | Other | Nauru | PREV | Naura: 5
| | | | | | 10–19 | | | Tuvalu | | Tuvalu: 3.5
Neufeld ^218^ 1997 | CS | 4 y | 4 | 4 | Siblings of children with Type 2 DM | 8 – 16 | 13.25 ± 2.76 | Mexican | NR | PREV | 25
| | | | | | | | American

Abbreviations: A=Adult; Ab=Aboriginal; Ad=Adolescent; B=Black; C=Children; CS=Cross-sectional; DIAG = Diagnosis; DM=Diabetes Mellitus; E=European; H=Hispanic; IGT=Impaired Glucose Tolerance; m=Month; NGT=Normal Glucose Tolerance; NHANES=National Health and Nutrition Examination Survey; NR=Not Reported; ODM=Offspring of women with pre-gestational and gestational Diabetes Mellitus; OS=Observational Study; PC=Prospective Cohort; PCOS=Polycystic Ovary Syndrome; Pima=Pima Indians; PREV = Prevalence. PROG = Prognosis; RX = Treatment; SD=Standard Deviation; w=Week; W=Caucasian; y=;Year.

The 19 studies not included in the further analysis below were excluded for the following reasons: 9 discussed cystic fibrosis, ^112^ – ^120^ one endemic fluorosis, ^121^ one Turner's syndrome, ^122^ six related to type 1 DM risks, ^111,^ ^123^ – ^127^ and no specific pediatric data could be extracted in two articles. ^128,^ ^129^

### Prevalence

DM in childhood was initially recognized in Aboriginal populations. Thus, most prevalence studies have been in Aboriginal populations. Population-based prevalence of IGT in childhood Aboriginal populations varies from 3.5% ^130^ in Tuvalu to 6.25% of Australian Aboriginals aged seven to 18 years. ^131^ In Nauru, the prevalence varied with gender as 2/28 males and 2/44 females < 19 years of age had IGT in a population-based study. ^132^ The population was a subset of the larger follow-up study published in 1992 ^130^ and was reviewed in the prognosis section.

One population-based study examining IFG has been published. In 1988 to 1994, the Third National Health and Nutrition Examination Survey (NHANES III) was conducted in the U.S., and 1083 12 to 19 year olds had a glucose level measured after a minimum eight-hour fast. Of these, 1.8% had a fasting glucose level between 6.1 and 7.0 mmol/L. Of these 20 children, four were non-Hispanic white, nine were non-Hispanic black, and seven were Mexican American. The mean BMI percentile for this group was 86^th^ percentile, but the range extended from the 10^th^ to 99^th^ percentile.

Studies of IGT prevalence in children are largely restricted to specific “at-risk” populations. IGT estimates in non-at-risk children are limited to a single study. In a study examining IGT in ten-to-16-year-old offspring of diabetic mothers, 2.5% of the control group had IGT. ^133^

The relationship of obesity to DM has prompted several investigators to examine the prevalence of IGT in obese children. ^12,^ ^134^ In both studies, IGT was measured in a population of children referred for the management of obesity in the U.S. ^12^ and Italy. ^134^ IGT was found in 25% of children (age four to ten years) and 21% of adolescents (age 11 to 18 years) in the American study and in 4.2% of six to 18 year olds using the same diagnostic criteria in the Italian study. In the U.S. study, 51% of those with IGT were non-Hispanic white, 30% were non-Hispanic black, and 19% were Hispanic (compared to 58%, 23%, and 19%, respectively, in the population studied). “Silent” DM was diagnosed in four participants (two non-Hispanic black and two Hispanic).

Children with a family history of type 2 diabetes in first-degree relatives have also been studied. In a study of 150 Latino children with a family history of DM, 28% were noted to have IGT. ^135^ A small study found that of eight siblings of Hispanic children diagnosed with type 2 DM, two had IGT.

Offspring of mothers with pre-gestational or gestational DM (ODM) also have a higher prevalence of IGT. In a longitudinal study, the prevalence of IGT in ODM is 1.2% in those < 5 years (n = 168), 5.4% in five-to-nine year olds (n = 111), and 19.3% (95% CI 12.1 to 28.6) in ten to 16 year olds (compared to 2.5% (95% CI 0.4 to 8.1) in controls). ^133^ Although the control group was somewhat lighter (BMI 20.3 ± 4.0 versus 22.8 ± 5.4 kg/m ^2^ ) and had 37% non-Caucasian participants compared to 51% in the ODM group, it is unlikely that these differences would account for the difference in IGT prevalence. Within this same cohort, 36% of ODM have had at least one abnormal OGTT result by 14 to 17 years of age. ^136^ Eleven of 21 adolescents with PCOS had abnormal OGTT results (9 IGT, two DM).

The prevalence of IGT is related to increasing age in several studies, although the articles in this review did not measure prevalence in children less than 10 years of age, except in well-defined populations of obese children referred for management of obesity. Two longitudinal studies with repeated OGTT in Aboriginal and ODM children suggest that rates of IGT increase with increasing age, particularly during the peri-pubertal period.

### Diagnosis

A comparison of IGT with IFG is presented in two articles, ^12,^ ^134^ and IFG and hemoglobin A1c (A1c) are compared in the NHANES III study. ^137^ In obese children, 6.6% of children ^134^ and less than 0.08% of children and adolescents ^12^ with IGT had IFG, indicating that this method of screening for IGT is very insensitive. In the NHANES III study, only three of 20 adolescents with IFG had an A1c that exceeded 6%. Of those children with an A1c over 6% who had IFG measured, three of 10 had IFG, suggesting that A1c is not a good screen for IFG in children.

The reproducibility of OGTT testing was examined by Sinha et al., ^12^ albeit in a small study. Repeat OGTT in 10 of 10 children (four with NGT and six with IGT) had the same categorization three months later. One article included in the full review for reproducibility of diagnosis included adolescents. ^138^ Although specific pediatric numbers were not presented, the reliability of test results was lower in younger populations.

### Prognosis

The prognosis of IGT in childhood and adolescence has not been well studied. Three studies had longitudinal data in IGT, but the numbers were small and did not allow a prediction or rate of conversion from IGT to DM. All of these longitudinal studies were in high-risk populations (two in Aboriginal populations in the U.S. and the South Pacific and one in ODM). Further details on determinants of progression from IGT to DM are not presented.

### Treatment

Only one study has examined treatment of IGT, and this was an open-label trial of metformin for three months in 15 adolescents with PCOS and IGT. ^139^ Eight of 15 children had NGT when re-evaluated after three months of metformin therapy. This was an association with a significant decline in BMI, although there was no significant change in fat mass.