# Introduction

## Background

### Magnitude and Importance of the Problem of IFG/IGT

Diabetes mellitus (DM) and its associated disease outcomes are a growing concern worldwide. The current global prevalence of DM for all ages has been estimated at 2.8% and is predicted to reach 4.4% by 2030. ^1^ In the United States (U.S.), the prevalence of diagnosed DM was estimated at 5.1% in 1997 for adults between the ages of 40 and 74 years. ^2^ In 2002, costs for treating DM and the resulting complications were high, with expenditures and lost productivity estimated at $132 billion in the U.S. ^3^ Due to the high prevalence of DM and the economic and health outcome burdens associated with this disease, there is intense interest in identifying and reducing the impact of risk factors in order to prevent the onset of DM and minimize morbidity.

Impaired fasting glucose (IFG) and impaired glucose tolerance (IGT) refer to the intermediate metabolic states between normal and diabetic glucose homeostasis. One or both of these conditions are thought to be the precursors of DM, but how they progress to overt disease is not well understood. The risk for both macrovascular and microvascular complications increases across the distribution of blood glucose concentrations well below the level for overt DM, and is more strongly associated with post-challenge hyperglycemia than fasting glucose levels. However, it is still unclear from the literature whether this ‘glucose effect’ is independent of other classical risk factors such as blood pressure (BP) and lipids. It is also unclear whether this pathology is related to only blood glucose levels or also involves abnormalities of other metabolites such as free fatty acids. There is accumulating evidence that some microvascular complications emerge in these glucose ‘intolerant’ individuals.

The term IFG was introduced in 1997 to define those individuals with fasting plasma glucose (FPG) between the upper limit of normal FPG and the lower limit of diabetic FPG. IGT refers to those individuals with a 2-hour post-load plasma glucose (2-hr PG) between the upper limit of normal and the lower limit of diabetic. ^4^ The International Diabetes Federation IFG/IGT Consensus Workshop concluded, based on these criteria, that IGT and IFG differ in their prevalence, population distribution, phenotype, sex distribution, and risk for total mortality and cardiovascular disease (CVD). ^5^ Similarly, the Third National Health and Nutrition Examination Survey found differences in the percentage of the U.S. population with IFG for men (8.8%) versus women (5.0%) and for non-Hispanic white (6.8%), non-Hispanic black (7.0%), and Mexican-American (8.9%) people. ^2^ Thus, there is also interest in identifying those subgroups with IFG/IGT who are at greater risk for progression to DM and other health outcomes.

### Historical Development of IGT and IFG Classifications

Both IFG and IGT are associated with glycemic disturbances that represent different metabolic processes with different prognostic consequences. Some evidence suggests that IGT is primarily associated with insulin resistance and IFG is associated with impaired insulin secretion and suppression of hepatic glucose output. ^6^ Also, IGT is more consistently associated with increased risk for CVD, but IFG is not. ^7^ Similarly, the magnitude of the risk for developing DM differs for these two metabolic states.

The historical development of IGT and IFG also has relevance to this systematic review. The diagnostic group of IGT was first defined in 1980 by the World Health Organization (WHO) expert committee on DM. ^8^ IGT was not defined as a disease in itself but rather as a metabolic state (or disease process) associated with increased risk for adverse health outcomes. IGT was defined as dysglycemia between normal and DM. Moreover, it was used to identify individuals at high risk for DM and possibly CVD.

The relationship between IFG and IGT has generated controversy about how best to evaluate dysglycemia using either the oral glucose tolerance test (OGTT) or the FPG test. There is particular interest in which of these glycemic disturbance states is a better predictor of progression to DM or CVD. There are also questions regarding the reliability of FPG and OGTT due to the biological variability and the clinical implications for confirming glycemic disturbance and the increased risk for progression to DM and other health outcomes. Moreover, there is a need to evaluate which interventions (pharmacological or lifestyle) are effective in modifying glycemic disturbance in IFG or IGT populations and identify the gaps in the literature to provide direction for future research.

The prevalence of type 2 DM continues to be higher amongst aboriginal peoples of North America (1% of children six to 17 years of age ^9^ and 4% of adolescent girls ^10,^ ^11^ in a Pima population). Previously undiagnosed DM was also noted in four out of 112 obese adolescents (11 to 18 years) referred to a tertiary-care obesity clinic. ^12^ Given the increasing trends in childhood obesity, it is imperative that our understanding of the precursors to type 2 DM in children is advanced. Furthermore, as the prevalence of obesity in children and adolescents has increased in North America, ^13^ so too has obesity-related co-morbidities, previously thought only to occur in adulthood. Type 2 DM in childhood and adolescence, first recognized in aboriginal populations, ^14,^ ^15^ is now also recognized in many other minorities (Black, Hispanic) and in those of European descent.

## Analytic Framework

The analytic framework of the variables influencing the health of individuals with glycemic disturbance states is shown in Figure 1. For example, a direct relationship may exist between the general population and CVD. Alternatively, the health of individuals may be influenced indirectly by several risk factors that culminate in CVD. The distinction between the direct and indirect pathways was not always possible for some of the cohort studies eligible for this review.

Figure 1. Analytic framework for IFG or IGT as a risk factor for progression to outcomes of interest

## Objectives and Scope of This Systematic Review

The goal of this systematic review is to evaluate the state of the evidence in the areas of the diagnosis, prognosis, and treatment of IFG or IGT. This topic was nominated by the American College of Physicians (ACP). The American Academy of Family Physicians (AAFP) and the American Academy of Pediatrics (AAP) joined the project as partners, and the McMaster University Evidence-based Practice Center (EPC) was contracted through the Agency for Healthcare Research and Quality (AHRQ) to develop the report. The ACP, AAFP, and AAP will use these findings to inform clinical decision-making, develop clinical practice guidelines, and make recommendations. Additionally, research gaps will be identified and recommendations for future research directions will be discussed.

Preliminary questions posed by the AHRQ were subsequently modified and refined in consultation with the partner medical agencies, the AHRQ, and McMaster University EPC. The revised key questions to be addressed in this systematic review are as follows:

### Diagnosis Question

What is the reliability of the diagnosis of IFG or IGT (e.g., does individual variability or measurement error require multiple measurements to ensure reliability of diagnosis)? What is the relationship between IFG and IGT?

### Prognosis Question

For those identified with IFG or IGT, what are the short and long-term risks for developing the following endpoints:

a) Progression to DM or reversion towards normal glucose tolerance (NGT) or fasting glucose level,
b) Cardiovascular events and stroke,
c) Microvascular disease, specifically retinopathy and nephropathy as measured by proteinuria, microalbuminaria, elevated creatinine, albumin to creatinine ratio in the urine, dialysis, and/or renal transplant.

Does this risk vary by subpopulation, such as sex, race, obesity, age, or other risk factors (e.g., BP, elevated lipid levels)?

### Treatment Question

What is the effectiveness of pharmaceutical and behavioral interventions for reducing the risks associated with IFG or IGT on the following endpoints:

a) Delay in onset of DM or reversion towards NGT or fasting glucose level,
b) Reducing risk of cardiovascular events and stroke,
c) Reducing risk of microvascular disease, including early markers such as retinopathy/proteinurea,
d) Improving other metabolic parameters associated with increased risk, such as BP and lipid levels.

Are some treatments more effective than others for any of the above endpoints, and does the effectiveness of interventions vary by subpopulation (e.g., age, sex, obesity)?

### Pediatric Question

What is known about the development of IFG or IGT in the pediatric population?