# Appendix G. Calculations

Section A: Calculation of kappa coefficient and confidence intervals (CI)

The simple kappa coefficient is calculated as:

where

and

The Variance and CI are calculated as follows:

where

and

Section B: Calculation of annualized relative risk, annualized risk for the exposed (IFG or IGT) and the normal glucose groups

Calculation of relative risk (RR_ t_) at time t would be as follows:

where

[image] = Calculated Risk in Exposed Group at time t (or i.e. in Male) and calculated as:

[image] = Calculated Risk in Control Group at time t (or i.e. in Female)

[image] and [image] can be calculated as:

[image] is Observed Risk after T period in Exposed Group

[image] is Observed Risk after T period in Control Group

thus

[image]

where

[image]

T= Observed duration of study (0.5 to 18 years).

t= Up to one year study duration.

Section C: Calculation of 95% confidence intervals (CI) for the unadjusted annualized RR [image]

Where:

[image]

[image]

Section D: Calculation and test of heterogeneity (Q) and the pooled estimate of RR{36574}: [image]

Where k is the number of studies being combined, RR_ i_ is the relative risk estimate in i^th^Study,[image]

is the weighted estimator of relative risk, and W_ i_ is the weight attached to that study (the reciprocal of the variance of the i^th^ study, varRR_ i_).

Q is approximately distributed as a X ^2^ distribution with k- 1 degrees of freedom under H_ 0_

Fixed effects model

Random effect model

and

[image]

Further, define

The estimated component of variance due to inter-study variation in effect size,[image], is calculated as:

[image]

and [image]

Adjusted weights [image] for each of the studies is calculated as

The mean relative risk estimate of all studies [image] can then be computed by:

The variance of this estimate is calculated as:

U.S. Department of Health and Human Services

Mike Leavitt, Secretary

Office of Public Health and Science

Richard H. Carmona, M.D., M.P.H., F.A.C.S., Surgeon General of the United States

Agency for Healthcare Research and Quality

Carolyn M. Clancy, M.D., Director