# Appendix E. Excluded Studies

## References

Anonymous. From the NIH: New standards for classification and diagnosis of diabetes. JAMA 1980; 243:2296–2297. Status: Not included because article is not a fulltext publication
Anonymous. Is fasting glucose sufficient to define diabetes? Epidemiological data from 20 European studies. The DECODE-study group. European Diabetes Epidemiology Group. Diabetes Epidemiology: Collaborative analysis of Diagnostic Criteria in Europe.[see comment]. Diabetologia 1999; 42:647–654. Status: Not included because article does not describe a study or survey
Anonymous. Consequences of the new diagnostic criteria for diabetes in older men and women: the DECODE Study (Diabetes Epidemiology: Collaborative Analysis of Diagnostic Criteria in Europe). Diabetes Care 1999;22:1667–1671. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Anonymous. Diet, exercise delay type 2 diabetes. FDA Consum 2001; 35:10–11. Status: Not included because article is not a fulltext publication
Abbott W.G.H, Thuillez P, Howard B.V. Body composition, adipocyte size, free fatty acid concentration, and glucose tolerance in children of diabetic pregnancies. Diabetes. 1986;35:1077-1080. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3530841].
Abel E.D, Ledingham J.G. Impaired glucose tolerance in hypertension is associated with impaired insulin release independently of changes in insulin sensitivity. J Hypertens. 1994;12:1265-1273. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7868874].
Acosta, Patin, Jimenez-Balderas E, Juarez-Oropeza M.A, Diaz-Zagoya J.C. Hypoglycemic action of Cucurbita ficifolia on Type 2 diabetic patients with moderately high blood glucose levels. J Ethnopharmacol. 2001;77:99-101. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11483384].
Adachi H, Hashimoto R, Tsuruta M, Jacobs D.R Jr, Crow R.S, Imaizumi T. Hyperinsulinemia and the development ST-T electrocardiographic abnormalities: An 11-year follow-up study. Diabetes Care. 1997;20:1688-1692. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9353609].
Adachi H, Hirai Y, Tsuruta M, Fujiura Y, Imaizuml T. Is insulin resistance or diabetes mellitus associated with stroke? An 18-year follow-up study. Diabetes Res Clin Pract. 2001;51:215-223. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11269894].
Adegbenro S.A, Dada O.A, Olanrewaju D.M, Fafunso M.A. Glycosylated haemoglobin levels in children with protein-energy malnutrition. Ann Trop Paediatr. 1991;11:337-341. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1721790].
Adler A.I, Boyko E.J, Schraer C.D, Murphy N.J. Lower prevalence of impaired glucose tolerance and diabetes associated with daily seal oil or salmon consumption among Alaska Natives. Diabetes Care. 1994;17:1498-1501. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7882827].
Adler A.I, Boyko E.J, Schraer C.D, Murphy N.J. The negative association between traditional physical activities and the prevalence of glucose intolerance in Alaska Natives. Diabet Med. 1996;13:555-560. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8799660].
Agardh C.D, Aberg A, Norden N.E. Glucose levels and insulin secretion during a 75 g glucose challenge test in normal pregnancy. J Intern Med. 1996;240:303-309. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8946813].
Agewall S, Persson B, Samuelsson O, Ljungman S, Herlitz H, Fagerberg B. Microalbuminuria in treated hypertensive men at high risk of coronary disease. J Hypertens. 1993;11:461-469. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8390516].
Agner E, Thorsteinsson B, Eriksen M. Impaired glucose tolerance and diabetes mellitus in elderly subjects. Diabetes Care. 1982;5:600-604. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6927730].
Ai M, Tanaka A, Ogita K, Sekine M, Numano F, Numano F, Reaven G.M. Relationship between hyperinsulinemia and remnant lipoprotein concentrations in patients with impaired glucose tolerance. J Clin Endocrinol Metab. 2000;85:3557-3560. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 11061501].
Al Lawati J.A, Al Riyami A.M, Mohammed A.J, Jousilahti P. Increasing prevalence of diabetes mellitus in Oman. Diabet Med. 2002;19:954-957. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12421434].
Al Shoumer K.A. S, Beshyah S.A, Niththyananthan R, Johnston D.G. Effect of glucocorticoid replacement therapy on glucose tolerance and intermediary metabolites in hypopituitary adults. Clin Endocrinol (Oxf). 1995;42:85-90. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7889636].
Alderman B.W, Marshall J.A, Boyko E.J, Markham K.A, Baxter J, Hamman R.F. Reproductive history, glucose tolerance, and NIDDM in Hispanic and non-Hispanic white women. The San Luis Valley Diabetes Study. Diabetes Care. 1993;16:1557-1564. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8299451].
Alemzadeh R, Langley G, Upchurch L, Smith P, Slonim A.E. Beneficial effect of diazoxide in obese hyperinsulinemic adults. J Clin Endocrinol Metab. 1998;83:1911-1915. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9626118].
Alexander C.M, Landsman P.B, Teutsch S.M. Diabetes mellitus, impaired fasting glucose, atherosclerotic risk factors, and prevalence of coronary heart disease. Am J Cardiol. 2000;86:897-902. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11053695].
Algvere P, Efendic S, Luft R, Wajngot A. Retinal microangiopathy and pigment epithelial lesions in subjects with normal, borderline, and decreased oral glucose tolerance. Br J Ophthalmol. 1985;69:416-419. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4005209]. [pmcid: 1040618].
Allegra V, Amendolagine F, Mengozzi G, Jesu L, Vasile A. Metabolic and hormonal assessment of patients on maintenance hemodialysis for 10 years or more and their importance in long-term survival. Nephron. 1988;49:107-113. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3288886].
Allegra V, Mengozzi G, Martimbianco L, Vasile A. Glucose-induced insulin secretion in uremia: effects of aminophylline infusion and glucose loads. Kidney Int. 1990;38:1146-1150. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1963648].
Ambrose P.G, Bhavnani S.M, Cirincione B.B, Piedmonte M, Grasela T.H. Gatifloxacin and the elderly: Pharmacokinetic-pharmacodynamic rationale for a potential age-related dose reduction. J Antimicrob Chemother. 2003;52:435-440. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12917247].
Amin P, Shah S, Walker D, Page S.R. Adverse metabolic and cardiovascular risk following treatment of acute lymphoblastic leukaemia in childhood; two case reports and a literature review. Diabet Med. 2001;18:849-853. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11678978].
Amin R, Ross K, Acerini C.I, Edge J.A, Warner J, Dunger D.B. Hypoglycemia prevalence in prepubertal children with type 1 diabetes on standard insulin regimen: Use of continuous glucose monitoring system. Diabetes Care. 2003;26:662-667. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12610018].
Amoah A.G, Schuster D.P, Gaillard T, Osei K. Insulin resistance, beta cell function and cardiovascular risk factors in Ghanaians with varying degrees of glucose tolerance. Ethn Dis. 2002;12:S3-S7. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design.
Anand S.S, Yusuf S. Risk factors for cardiovascular disease in Canadians of South Asian and European origin: a pilot study of the Study of Heart Assessment and Risk in Ethnic Groups (SHARE). Clin Invest Med. 1997;20:204-210. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9258575].
Anderson R.A, Polansky M.M, Bryden N.A, Canary J.J. Supplemental-chromium effects on glucose, insulin, glucagon, and urinary chromium losses in subjects consuming controlled low-chromium diets. Am J Clin Nutr. 1991;54:909-916. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1951165].
Andronico G, Piazza G, Mangano M.T, Mule G, Carone M.B, Cerasola G. Nifedipine vs. enalapril in treatment of hypertensive patients with glucose intolerance. J Cardiovasc Pharmacol. 1991;18(Suppl 10):S52-S54. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1725004].
Andronico G, Mangano M, Ferrara L, Lamanna D, Mule G, Cerasola G. In vivo relationship between insulin and endothelin role of insulin-resistance. J Hum Hypertens. 1997;11:63-66. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9111160].
Angelopoulos T.J, Schultz R.M, Denton J.C, Jamurtas A.Z. Significant enhancements in glucose tolerance and insulin action in centrally obese subjects following ten days of training. Clinical Journal of Sport Medicine. 2002;12:113-118. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11953558].
Annuzzi G, Rivellese A, Vaccaro O. The relationship between blood glucose concentration and beat-to-beat variation in asymptomatic subjects. Acta Diabetol Lat. 1983;20:57-62. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6858543].
Antonucci T, Whitcomb R, McLain R, Lockwood D. Impaired glucose tolerance is normalized by treatment with the thiazolidinedione troglitazone. Diabetes Care. 1997;20:188-193. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 9118772].
Arashiro R, Katsuren K, Fukuyama S, Ohta T. Effect of Trp64Arg mutation of the beta3-adrenergic receptor gene and C161T substitution of the peroxisome proliferator activated receptor gamma gene on obesity in Japanese children. Pediatrics International. 2003;45:135-141. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12709137].
Arciero P.J, Vukovich M.D, Holloszy J.O, Racette S.B, Kohrt W.M. Comparison of short-term diet and exercise on insulin action in individuals with abnormal glucose tolerance. J Appl Physiol. 1999;86:1930-1935. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10368358].
Arden G.B, Wonke B, Kennedy C, Huehns E.R. Ocular changes in patients undergoing long-term desferrioxamine treatment. Br J Ophthalmol. 1984;68:873-877. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6509007]. [pmcid: 1040501].
Armstrong V.W, Buschmann U, Ebert R. Biochemical investigations of CAPD: Plasma levels of trace elements and amino acids and impaired glucose tolerance during the course of treatment. Int J Artif Organs. 1980;3:237-241. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7409923].
Arrigo T, Cucinotta D, Conti, Nibali S, Di Cesare E, Di Benedetto A, Magazzu G, De Luca F. Longitudinal evaluation of glucose tolerance and insulin secretion in non-diabetic children and adolescents with cystic fibrosis: results of a two-year follow-up. Acta Paediatr. 1993;82:249-253. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 8495078].
Arroliga A.C. Intensive care update: Seven studies that should change your practice. Cleve Clin J Med. 2002;69:505-506. Status: Not included because article does not describe a study or survey. [pmid: 12061466].
Arslanian S.A, Lewy V.D, Danadian K. Glucose intolerance in obese adolescents with polycystic ovary syndrome: Roles of insulin resistance and beta-cell dysfunction and risk of cardiovascular disease. J Clin Endocrinol Metab. 2001;86:66-71. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11231980].
Arslanian S.A, Lewy V, Danadian K, Saad R. Metformin therapy in obese adolescents with polycystic ovary syndrome and impaired glucose tolerance: amelioration of exaggerated adrenal response to adrenocorticotropin with reduction of insulinemia/insulin resistance. J Clin Endocrinol Metab. 2002;87:1555-1559. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 11932281].
Austin A, Kalhan S.C, Orenstein D, Nixon P, Arslanian S. Roles of insulin resistance and beta-cell dysfunction in the pathogenesis of glucose intolerance in cystic fibrosis. J Clin Endocrinol Metab. 1994;79:80-85. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. Bakker S.J. L, Hoogeveen E.K, Nijpels G, Kostense P.J, Dekker J.M, Gans R.O. B, Heine R.J. The association of dietary fibres with glucose tolerance is partly explained by concomitant intake of thiamine: The Hoorn Study. Diabetologia. 1998. 41. 1168. 1175. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8027259].
Baldelli R, Battista C, Leonetti F, Ghiggi M.R, Ribaudo M.C, Paoloni A, D'Amico E, Ferretti E, Baratta R, Liuzzi A, Trischitta V, Tamburrano G. Glucose homeostasis in acromegaly: effects of long-acting somatostatin analogues treatment. Clin Endocrinol (Oxf). 2003;59:492-499. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 14510913].
Balfour, J. A., Faulds, D., Wolffenbuttel, B. H. R., and Mooradian, A. D. Repaglinide. Drugs & Aging 1998;13:173–181. Status: Not included because article does not describe a study or survey
Balkau B. Consequences of the new diagnostic criteria for diabetes in older men and women: The DECODE Study (Diabetes Epidemiology: Collaborative Analysis of Diagnostic Criteria in Europe). Diabetes Care. 1999;22:1667-1671. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10526732].
Balkau B. The DECODE study. Diabetes epidemiology: collaborative analysis of diagnostic criteria in Europe. Diabetes Metab. 2000;26:282-286. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11011220].
Ballantyne C.M, Stein E.A, Paoletti R, Southworth H, Blasetto J.W. Efficacy of Rosuvastatin 10 mg in patients with the Metabolic Syndrome. Am J Cardiol. 2003;91:25C-28C. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Bancroft K, Tuffnell D, Mason G, Rogerson L, Mansfield M. A randomized controlled study of the management of impaired glucose intolerance in pregnancy. British Journal of Obstetrics and Gynaecology. 1998;105 Suppl 17:53-54. Status: Not included because article is not a fulltext publication. [pmid: 9442162].
Bancroft K, Tuffnell D.J, Mason G.C, Rogerson L.J, Mansfield M. A randomised controlled pilot study of the management of gestational impaired glucose tolerance.[comment]. BJOG. 2000;107:959-963. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10955425].
Baral N, Koner B.C, Karki P, Ramaprasad C, Lamsal M, Koirala S. Evaluation of new WHO diagnostic criteria for diabetes on the prevalence of abnormal glucose tolerance in a heterogeneous Nepali population--the implications of measuring glycated hemoglobin. Singapore Med J. 2000;41:264-267. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11109341].
Barrett-Connor E, Frette C. NIDDM, impaired glucose tolerance, and pulmonary function in older adults: The Rancho Bernardo Study. Diabetes Care. 1996;19:1441-1444. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 8941481].
Barzilay J.I, Spiekerman C.F, Kuller L.H, Burke G.L, Bittner V, Gottdiener J.S, Brancati F.L, Orchard T.J, O'Leary D.H, Savage P.J. Cardiovascular, Health Study. Prevalence of clinical and isolated subclinical cardiovascular disease in older adults with glucose disorders: the Cardiovascular Health Study. Diabetes Care. 2001;24:1233-1239. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11423508].
Batty G.D, Shipley M.J, Marmot M, Smith G.D. Physical activity and cause-specific mortality in men with Type 2 diabetes/impaired glucose tolerance: evidence from the Whitehall study. Diabet Med. 2002;19:580-588. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12099962].
Bavirti S, Tayek J.A. Low-dose oral glyburide reduces glucose production rates in patients with impaired fasting glucose. Metabolism. 2003;52:407-412. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 12701050].
Bazaes R.A, Petry C.J, Ong K.K, Avila A, Dunger D.B, Mericq M.V. Insulin gene VNTR genotype is associated with insulin sensitivity and secretion in infancy. Clin Endocrinol (Oxf). 2003;59:599-603. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14616883].
Beasley C.M, Berg P.H, Dananberg J, Kwong K.C, Taylor C.C. M, Breier A. Treatment-emergent potential impaired glucose tolerance and potential diabetes with olanzapine compared to other antipsychotic agents and placebo. Biol Psychiatry. 2001;49:121S. Status: Not included because article is not a fulltext publication.
Beer S.F, Heaton D.A, Alberti K.G, Pyke D.A, Leslie R.D. Impaired glucose tolerance precedes but does not predict insulin-dependent diabetes mellitus: a study of identical twins. Diabetologia. 1990;33:497-502. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2210123].
Beeson M, Sajan M.P, Dizon M, Grebenev D, Gomez-Daspet J, Miura A, Kanoh Y, Powe J, Bandyopadhyay G, Standaert M.L, Farese R.V. Activation of protein kinase C-zeta by insulin and phosphatidylinositol-3,4,5-(PO4)3 is defective in muscle in type 2 diabetes and impaired glucose tolerance: amelioration by rosiglitazone and exercise. Diabetes. 2003;52:1926-1934. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 12882907].
Beks P.H, Mackaay A.J, de Vries H, De Neeling J.N, Bouter L.M, Heine R.J. Carotid artery stenosis is related to blood glucose level in an elderly Caucasian population: the Hoorn Study. Diabetologia. 1997;40:290-298. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9084966].
Beks P.J, Mackaay A.J, De Neeling J.N, de Vries H, Bouter L.M, Heine R.J. Peripheral arterial disease in relation to glycaemic level in an elderly Caucasian population: the Hoorn study. Diabetologia. 1995;38:86-96. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7744233].
Berenson G.S, Radhakrishnamurthy B, Srinivasan S. Plasma glucose and insulin levels in relation to cardiovascular risk factors in children from a biracial population - the Bogalusa heart study. J Chronic Dis. 1981;34:379-391. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7021577].
Bergstrom R.W, Leonetti D.L, Newell-Morris L.L, Shuman W.P, Wahl P.W, Fujimoto W.Y. Association of plasma triglyceride and C-peptide with coronary heart disease in Japanese-American men with a high prevalence of glucose intolerance. Diabetologia. 1990;33:489-496. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 2210122].
Berkowitz K, Peters R, Kjos S.L, Goico J, Marroquin A, Dunn M.E, Xiang A, Azen S, Buchanan T.A. Effect of troglitazone on insulin sensitivity and pancreatic b-cell function in women at high risk of NIDDM. Diabetes. 1996;45:1572-1579. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 8866563].
Berntorp K, Lindgarde F, Mattiasson I. Platelet sodium kinetics, blood pressure and serum urate: aberrations in non-obese men at risk for type 2 diabetes mellitus. Clin Sci (Colch ). 1987;73:109-116. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3608370].
Bertin E, Rich N, Schneider N, Larbre H, Marcus C, Durlach V, Leutenegger M. Insulin and body fat distribution have no direct effect on plasma leptin levels in obese Caucasian women with and without type 2 diabetes mellitus. Diabetes Metab. 1998;24:229-234. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9690055].
Bertolini S, Cordera R, Marcenaro A, Versari G, Cuzzolaro S, Carniel M, Castoldi L, Pessino A, Elicio N, Balestreri R. Metabolic effects of gemfibrozil in patients with primary hypertriglyceridaemia. Diabetes Nutr Metab. 1990;3:23-33. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Bevier W.C, Fischer R, Jovanovic L. Treatment of women with an abnormal glucose challenge test (but a normal oral glucose tolerance test) decreases the prevalence of macrosomia. Am J Perinatol. 1999;16:269-275. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10586979].
Bitzen P.-O, Melander A, Schersten B, Wahlin-Boll E. The influence of glipizide on early insulin release and glucose disposal before and after dietary regulation in diabetic patients with different degrees of hyperglycaemia. Eur J Clin Pharmacol. 1988;35:31-37. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3065086].
Bitzen P.-O, Melander A, Schersten B, Svensson M. Efficacy of dietary regulation in primary health care patients with hyperglycaemia detected by screening. Diabet Med. 1988;5:640-647. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2975547].
Bitzen P.O, Schersten B. Assessment of laboratory methods for detection of unsuspected diabetes in primary health care. Scand J Prim Health Care. 1986;4:85-95. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3726333].
Bjorklund K, Lind L, Andren B, Lithell H. The majority of nondipping men do not have increased cardiovascular risk: a population-based study.[see comment]. J Hypertens. 2002;20:1501-1506. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12172310].
Bjornholt J.V, Erikssen G, Kjeldsen S.E, Bodegard J, Thaulow E, Erikssen J. Fasting blood glucose is independently associated with resting and exercise blood pressures and development of elevated blood pressure. J Hypertens. 2003;21:1383-1389. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12817188].
Blaak E.E, Kemerink G.J, Pakbiers M.T. W, Wolffenbuttel B.H. R, Heidendal G.A, Saris W.H. Microdialysis assessment of local adipose tissue lipolysis during beta-adrenergic stimulation in upper-body-obese subjects with type II diabetes. Clin Sci (Colch ). 1999;97:421-428. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10491342].
Bloomgarden Z.T. Pharmacologic treatment of type 2 diabetes. Diabetes Care. 2003;26:526-533. Status: Not included because article does not describe a study or survey. [pmid: 12547894].
Bluher M, Unger R, Rassoul F, Richter V, Paschke R. Relation between glycaemic control, hyperinsulinaemia and plasma concentrations of soluble adhesion molecules in patients with impaired glucose tolerance or Type II diabetes. Diabetologia. 2002;45:210-216. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11935152].
Boes U, Wallner S, Wascher T.C. Acute effects of nicorandil on glucose tolerance in subjects with borderline fasting blood glucose levels. Wien Klin Wochenschr. 2001;113:127-129. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11253738].
Bogardus C, Lillioja S, Howard B.V. Relationships between insulin secretion, insulin action, and fasting plasma glucose concentration in nondiabetic and noninsulin-dependent diabetic subjects. J Clin Invest. 1984;74:1238-1246. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6384267]. [pmcid: 425290].
Bolk J, van der, Ploeg T, Cornel J.H, Arnold A.E, Sepers J, Umans V.A. Impaired glucose metabolism predicts mortality after a myocardial infarction. Int J Cardiol. 2001;79:207-214. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11461743].
Bolli G, Compagnucci P, Cartechini M.G. HbA1 in subjects with abnormal glucose tolerance but normal fasting plasma glucose. Diabetes. 1980;29:272-277. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7358227].
Bonen A, Ball-Burnett M, Russel C. Glucose tolerance is improved after low- and high-intensity exercise in middle-age men and women. Can J Appl Physiol. 1998;23:583-593. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9822794].
Boonsiri B, Virutamasen P, Tangkeo P, Wongsrichanalai C. Effects of daily 30 MCG norgestrel on glucose, insulin, cholesterol and triglycerides during 1 year' time of use. Asia Oceania J Obstet Gynaecol. 1983;9:180-184. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6351820].
Bortheiry A.L, Malerbi D.A, Franco L.J. The ROC curve in the evaluation of fasting capillary blood glucose as a screening test for diabetes and IGT. Diabetes Care. 1994;17:1269-1272. Status: Not included because article does not describe a study or survey. [pmid: 7821166].
Bos G, Dekker J.M, Nijpels G, de Vegt F, Diamant M, Stehouwer C.D. A, Bouter L.M, Heine R.J. A combination of high concentrations of serum triglyceride and non-high-density-lipoprotein-cholesterol is a risk factor for cardiovascular disease in subjects with abnormal glucose metabolism - The Hoorn Study. Diabetologia. 2003;46:910-916. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12819906].
Bosi E.P, Garancini M.P, Poggiali F, Bonifacio E, Gallus G. Low prevalence of islet autoimmunity in adult diabetes and low predictive value of islet autoantibodies in the general adult population of northern Italy. Diabetologia. 1999;42:840-844. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10440126].
Boucher B.J, Mannan N, Noonan K, Hales C.N, Evans S.J. W. Glucose intolerance and impairment of insulin secretion in relation to vitamin D deficiency in East London Asians. Diabetologia. 1995;38:1239-1245. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8690178].
Bougneres P.-F, Artavia-Loria E, Ferre P. Effects of hypopituitarism and growth hormone replacement therapy on the production and utilization of glucose in childhood. J Clin Endocrinol Metab. 1985;61:1152-1157. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3902870].
Bourn D, Mann J. Screening for noninsulin dependent diabetes mellitus and impaired glucose tolerance in a Dunedin general practice--is it worth it. N Z Med J. 1992;105:208-210. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1598139].
Bourn D.M, Mann J.I. The 3-yr follow-up of subjects with impaired glucose tolerance or non-insulin dependent diabetes mellitus in a diet and exercise intervention programme. Diabetes Nutr Metab. 1996;9:240-246. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Boyko E.J, de Court, Zimmet P.Z, Chitson P, Tuomilehto J, Alberti K.G. Features of the metabolic syndrome predict higher risk of diabetes and impaired glucose tolerance: a prospective study in Mauritius. Diabetes Care. 2000;23:1242-1248. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10977013].
Braun B, Zimmermann M.B, Kretchmer N, Spargo R.M, Smith R.M, Gracey M. Risk factors for diabetes and cardiovascular disease in young Asutralian Aborigines. Diabetes Care. 1996;19:472-479. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8732712].
Breum L, Bjerre U, Bak J.F, Jacobsen S, Astrup A. Long-term effects of fluoxetine on glycemic control in obese patients with non-insulin-dependent diabetes mellitus or glucose intolerance: Influence on muscle glycogen synthase and insulin receptor kinase activity. Metabolism. 1995;44:1570-1576. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8786726].
Brown D.C, Byrne C.D, Clark P.M, Cox B.D, Day N.E, Hales C.N, Shackleton J.R, Wang T.W, Williams D.R. Height and glucose tolerance in adult subjects [see comments]. Diabetologia. 1991;34:531-533. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1916060].
Brown D.W, Giles W.H, Greenlund K.J, Valdez R, Croft J.B. Impaired fasting glucose, diabetes mellitus, and cardiovascular disease risk factors are associated with prolonged QTc duration. Results from the Third National Health and Nutrition Examination Survey. J Cardiovasc Risk. 2001;8:227-233. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11551001].
Bruno A, Pagano G, Benzi L, Di Ciani G, Spallone V, Calabrese G, Passeri A. Change in glucose metabolism after long-term treatment with deflazacort and betamethasone. Eur J Clin Pharmacol. 1992;43:47-50. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1505608].
Bruno A, Fornengo P, Gruden G, Cavallo-Perin P, Cassader M, Milani S, Poggi G, Pagano G. Serum glucose, insulin, C-peptide and plasma glucagon response to oral glucose after intravenous injection of different glucocorticoids at increasing doses in man. Diabetes, Nutrition and Metabolism - Clinical and Experimental. 1997;10:18-23. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Brustman L, Langer O, Engel S, Anyaegbunam A, Mazze R. Verified self-monitored blood glucose data versus glycosylated hemoglobin and glycosylated serum protein as a means of predicting short- and long-term metabolic control in gestational diabetes. Am J Obstet Gynecol. 1987;157:699-703. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3631170].
Buchanan T.A, Xiang A.H, Kjos S.L, Trigo E, Lee W.P, Peters R.K. Antepartum predictors of the development of type 2 diabetes in Latino women 11–26 months after pregnancies complicated by gestational diabetes. Diabetes. 1999;48:2430-2436. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10580433].
Buchanan T.A, Xiang A.H, Peters R.K, Kjos S.L, Berkowitz K, Marroquin A, Goico J, Ochoa C, Azen S.P. Response of pancreatic beta-cells to improved insulin sensitivity in women at high risk for type 2 diabetes. Diabetes. 2000;49:782-788. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10905487].
Buchanan T.A, Xiang A.H, Peters R.K, Kjos S.L, Marroquin A, Goico J, Ochoa C, Tan S, Berkowitz K, Hodis H.N, Azen S.P. Preservation of pancreatic beta-cell function and prevention of type 2 diabetes by pharmacological treatment of insulin resistance in high-risk hispanic women. Diabetes. 2002;51:2796-2803. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12196473].
Bulow B, Erfurth E.M. A low individualized GH dose in young patients with childhood onset GH deficiency normalized serum IGF-I without significant deterioration in glucose tolerance. Clin Endocrinol (Oxf). 1999;50:45-55. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10341855].
Burchfiel C.M, Hamman R.F, Marshall J.A, Baxter J, Kahn L.B, Amirani J.J. Cardiovascular risk factors and impaired glucose tolerance: the San Luis Valley Diabetes Study. Am J Epidemiol. 1990;131:57-70. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 2293753].
Burchfiel C.M, Shetterly S.M, Baxter J, Hamman R.F. The roles of insulin, obesity, and fat distribution in the elevation of cardiovascular risk factors in impaired glucose tolerance: The San Luis Valley Diabetes Study. Am J Epidemiol. 1992;136:1101-1109. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1462970].
Burchfiel C.M, Curb J.D, Rodriguez B.L, Abbott R.D, Chiu D, Yano K. Glucose intolerance and 22-year stroke incidence: The Honolulu Heart Program. Stroke. 1994;25:951-957. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8165689].
Butler W.J, Ostrander L.D Jr, Carman W.J, Lamphiear D.E. Mortality from coronary heart disease in the Tecumseh study. Long-term effect of diabetes mellitus, glucose tolerance and other risk factors. Am J Epidemiol. 1985;121:541-547. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4014143].
Buysschaert M, Vandenbroucke C, Barsoum S. A type 2 diabetes screening program by general practioners in a Belgian at risk population. Diabetes Metab. 2001;27:109-114. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11353875].
Byrne C.D, Wareham N.J, Brown D.C, Clark P.M, Cox L.J, Day N.E, Palmer C.R, Wang T.W, Williams D.R, Hales C.N. Hypertriglyceridaemia in subjects with normal and abnormal glucose tolerance: relative contributions of insulin secretion, insulin resistance and suppression of plasma non-esterified fatty acids. Diabetologia. 1994;37:889-896. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7806018].
Byrne J.J, Leon, Bradlow H. DHEA-PC Slows the progression of type 2 diabetes (Non-Insulin-Dependent Diabetes Mellitus) in the ZDF/Gmi-fa/fa rat. Diabetes Technology& Therapeutics. 2001;3:211-219. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11478327].
Cacciari E, Coccheri S, Bergamaschi R, Fortunato G, Balsamo A, Poggi M, Cicognani A, Pirazzoli P, Zappulla F. Hemostatic balance alterations in obese children. Acta Paediatr Scand. 1982;71:479-484. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6814176].
Calle-Pascual A.L, Rodriguez C, Martin-Alvarez P.J, Camacho F, Calle J.R, Yuste E, Hildago I, Diaz R.J, Martin-Vaquero P, Santiago M. Effect of weight loss on insulin sensitivity and cardiovascular risk factors in glucose tolerant and intolerant obese subjects. Diabete Metab. 1991;17:404-409. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1915998].
Calle-Pascual A.L, Saavedra A, Benedi A, Martin-Alvarez P.J, Garcia-Honduvilla J, Calle J.R, Maranes J.P. Changes in nutritional pattern, insulin sensitivity and glucose tolerance during weight loss in obese patients from a Mediterranean area. Horm Metab Res. 1995;27:499-502. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8770626].
Carel J.C, Boitard C, Eisenbarth G, Bach J.F, Bougneres P.F. Cyclosporine delays but does not prevent clinical onset in glucose intolerant pre-type 1 diabetic children. J Autoimmun. 1996;9:739-745. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9115576].
Carlstrom S, Sartor G. Plasma glycerol and free fatty acids at oral glucose tests in subjects with impaired glucose tolerance. Journal of the Kuwait Medical Association. 1985;19:119-126. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Carneiro D.M, Levi J.U, Irvin G.L III. Rapid insulin assay for intraoperative confirmation of complete resection of insulinomas. Surgery. 2002;132:937-943. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12490839].
Casiglia E, Pauletto P, Mazza A, Ginocchio G, di Menza G, Pavan L, Tramontin P, Capuani M, Pessina A.C. Impaired glucose tolerance and its co-variates among 2079 non-diabetic elderly subjects. Ten year mortality and morbidity in the CASTEL study. Acta Diabetol. 1996;33:284-290. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9033969].
Catalano P.M, Thomas A, Huston-Presley L, Amini S.B. Increased fetal adiposity: a very sensitive marker of abnormal in utero development. Am J Obstet Gynecol. 2003;189:1698-1704. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14710101].
Cavaghan M.K, Ehrmann D.A, Byrne M.M, Polonsky K.S. Treatment with the oral antidiabetic agent troglitazone improves beta cell responses to glucose in subjects with impaired glucose tolerance. J Clin Invest. 1997;100:530-537. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 9239399]. [pmcid: 508219].
Cavallo-Perin P, Bruno A, Scaglione L, Gruden G, Cassader M, Pagano G. Feedback inhibition of insulin and glucagon secretion by insulin is altered in abdominal obesity with normal or impaired glucose tolerance. Acta Diabetol. 1993;30:154-158. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8111076].
Caviezel F, Cattaneo A.G, Pozza G. Long-term administration of acetylsalicylic acid in impaired glucose tolerance in addition to the diet: effects and limits. Acta Diabetol Lat. 1981;18:225-233. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7029988].
Cederholm J. Short-term treatment of glucose intolerance in middle-aged subjects by diet, exercise and sulfonylurea. Upsala Journal of Medical Sciences. 1985;90:229-242. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4095819].
Cederholm J, Wibell L. What causes impaired glucose tolerance to deteriorate or normalize. Scand J Clin Lab Invest. 1992;52:491-496. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1411261].
Chae B.-J, Kang B.-J. The effect of clozapine on blood glucose metabolism. HUM. 2001;16:265-271. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review.
Chae, Beang Jin, Kang, Byung Jo. The effect of clozapine on blood glucose metabolism. Human-Psychopharmacology-Clinical-and-Experimental. 2001;16:265-271. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12404579].
Chaisiri K, Pongpaew P, Tungtrongchitr R, Phonrat B, Kulleap S, Kuhathong C, Sutthiwong P, Intarakhao C, Mahaweerawat U, Khongdee W, Sanchaisuriya P, Saowakontha S, Merkle A, Schelp F.P. Prevalence of abnormal glucose tolerance in Khon Kaen Province and validity of urine stick and fasting blood sugar as screening tools. J Med Assoc Thai. 1997;80:363-371. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9240010].
Charlton K.E, Levitt N.S, Lombard C.J. The prevalence of diabetes mellitus and associated risk factors in elderly coloured South Africans. S Afr Med J. 1997;87:364-367. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9137356].
Chaturvedi N, McKeigue P.M, Marmot M.G. Relationship of glucose intolerance to coronary risk in Afro-Caribbeans compared with Europeans. Diabetologia. 1994;37:765-772. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7988778].
Chen K.T, Chen C.J, Gregg E.W, Imperatore G, Narayan K.M. Impaired fasting glucose and risk of diabetes in Taiwan: follow-up over 3 years. Diabetes Res Clin Pract. 2003;60:177-182. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12757990].
Chi C.-S, Mak S.-C, Shian W.-J, Chen C.-H. Oral glucose lactate stimulation test in mitochondrial diseases. Pediatr Neurol. 1992;8:445-449. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1476574].
Chiaretti A, De Benedictis R, Langer A, Di Rocco C, Bizzarri C, Iannelli A, Polidori G, Akalan N, Erbengi A. Prognostic implications of hyperglycaemia in paediatric head injury. Childs Nervous System. 1998;14:455-459. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Chiasson J, Josse R.G, Leiter L.A, Mihic M, Nathan D.M, Palmason C, Cohen R.M, Wolever T.M. S. The effect of acarbose on insulin sensitivity in subjects with impaired glucose tolerance. Diabetes Care. 1996;19:1190-1193. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8908378].
Chiasson J.-L. The potential use of acarbose in the prevention of type 2 diabetes and cardiovascular disease. European Heart Journal Supplements. 2000;2:35. Status: Not included because article does not describe a study or survey.
Chiasson J.L, Josse R.G, Leiter L.A, Mihic M, Nathan D.M, Palmason C, Cohen R.M, Wolever T.M. The effect of acarbose on insulin sensitivity in subjects with impaired glucose tolerance. Diabetes Care. 1996;19:1190-1193. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8908378].
Chiasson J.L. The effect of acarbose on insulin sensitivity in subjects with impaired glucose tolerance. Diabet Med. 1996;13:S23-S24. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8689858].
Chiasson J.L, Gomis R, Hanefeld M, Josse R.G, Karasik A, Laakso M. The STOP-NIDDM Trial: an international study on the efficacy of an alpha-glucosidase inhibitor to prevent type 2 diabetes in a population with impaired glucose tolerance: rationale, design, and preliminary screening data. Study to Prevent Non-Insulin-Dependent Diabetes Mellitus. Diabetes Care. 1998;21:1720-1725. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 9773737].
Chiasson J.L, Naditch L. Miglitol Canadian University Investigator Group. The synergistic effect of miglitol plus metformin combination therapy in the treatment of type 2 diabetes.[comment]. Diabetes Care. 2001;24:989-994. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11375358].
Chong S.A, Mythily, Lum A, Huak C.Y, Kane J. Tardive dyskinesia and impaired glucose tolerance. HUM. 2002;17:305-307. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control).
Chong, Siow Ann, Mythily, Lum Alvin, Huak, Chan Yiong, Kane John. Tardive dyskinesia and impaired glucose tolerance. Human-Psychopharmacology-Clinical-and-Experimental. 2002;17:305-307. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12404676].
Chu N.-F, Lee M.M. S, Wang D.-J, Chen L.-M, Ding Y.-A, Shieh S.-M. The interrelationship between impaired glucose tolerance and other risk factors for cardiovascular disease: Is it a predictor for cardiovascular disease. J Clin Epidemiol. 1994;47:485-493. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7730874].
Clark C.V. Diabetes mellitus in primary glaucomas. Ann Acad Med Singapore. 1989;18:190-194. Status: Not included because article does not describe a study or survey. [pmid: 2751236].
Clausen J.O, Ibsen H, Ibsen K.K, Borch-Johnsen K. Association of body mass index, blood pressure and serum levels of triglycerides and high-density lipoprotein cholesterol in childhood with the insulin sensitivity index in young adulthood: a 13-year follow-up. J Cardiovasc Risk. 1996;3:427-433. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9048257].
Colagiuri S, Colagiuri R, Na'ati S, Muimuiheata S, Hussain Z, Palu T. The prevalence of diabetes in the kingdom of Tonga. Diabetes Care. 2002;25:1378-1383. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12145238].
Colao A, Baldelli R, Marzullo P, Ferretti E, Ferone D, Gargiulo P, Petretta M, Tamburrano G, Lombardi G, Liuzzi A. Systemic hypertension and impaired glucose tolerance are independently correlated to the severity of the acromegalic cardiomyopathy. J Clin Endocrinol Metab. 2000;85:193-199. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10634386].
Collins V, Taylor R, Zimmet P. Impaired glucose tolerances in Kiribati. N Z Med J. 1984;97:809-812. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6334253].
Colman E, Katzel L.I, Rogus E, Coon P, Muller D, Goldberg A.P. Weight loss reduces abdominal fat and improves insulin action in middle-aged and older men with impaired glucose tolerance. Metabolism. 1995;44:1502-1508. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7476341].
Colman P.G, Thomas D.W, Zimmet P.Z, Welborn T.A, Garcia-Webb P, Moore M.P. New classification and criteria for diagnosis of diabetes mellitus. The Australasian Working Party on Diagnostic Criteria for Diabetes Mellitus.[see comment]. N Z Med J. 1999;112:139-141. Status: Not included because article does not describe a study or survey. [pmid: 10340693].
Cononie, C. C., Goldberg, A. P., Rogus, E., and Hagberg, J. M. Seven consecutive days of exercise lowers plasma insulinresponses to an oral glucose challenge in sedentary elderly. Journal of the American Geriatrics Society 42(4):394–8, 1994Apr (40 ref) 1994; 394–398. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Cook J.T, Page R.C, Levy J.C, Hammersley M.S, Walravens E.K, Turner R.C. Hyperglycaemic progression in subjects with impaired glucose tolerance: association with decline in beta cell function. Diabet Med. 1993;10:321-326. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8508613].
Cooper D.E, Goff D.C Jr, Bell R.A, Zaccaro D, Mayer-Davis E.J, Karter A.J. Is insulin sensitivity a causal intermediate in the relationship between alcohol consumption and carotid atherosclerosis?: the insulin resistance and atherosclerosis study. Diabetes Care. 2002;25:1425-1431. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12145245].
Cornu C, Mercier C, Ffrench P, Bully C, Pugeat M, Cousin P, Riou J.P, Bajart L, Orgiazzi J, Pommet-Nicot C, Darsy P, Boissel J.P, Berthezene F. Postmenopause hormone treatment in women with NIDDM or impaired glucose tolerance: the MEDIA randomized clinical trial. Maturitas. 2000;37:95-104. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11137328].
Costa A, Conget I, Gomis R. Impaired glucose tolerance: Is there a case for pharmacologic intervention. Treatments in Endocrinology. 2002;1:205-210. Status: Not included because article does not describe a study or survey. [pmid: 15799213].
Costa A, Iguala I, Bedini J, Quinto L, Conget I. Uric acid concentration in subjects at risk of type 2 diabetes mellitus: Relationship to components of the metabolic syndrome. Metabolism. 2002;51:372-375. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11887176].
Costa A, Casamitjana R, Casals E, Alvarez L, Morales J, Masramon X, Hernandez G, Gomis R, Conget I. Effects of atorvastatin on glucose homeostasis, postprandial triglyceride response and C-reactive protein in subjects with impaired fasting glucose. Diabet Med. 2003;20:743-745. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12925055].
Costa A, Fernandez-Real J.M, Vendrell J, Broch M, Casamitjana R, Ricart W, Conget I. Lower rate of tumor necrosis factor-alpha -863A allele and higher concentration of tumor necrosis factor-alpha receptor 2 in first-degree relatives of subjects with type 2 diabetes. Metabolism. 2003;52:1068-1071. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12898475].
Coulston A, Greenfield M.S, Kraemer F.B. Effect of differences in source of dietary carbohydrate on plasma glucose and insulin responses to meals in patients with impaired carbohydrate tolerance. Am J Clin Nutr. 1981;34:2716-2720. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7032274].
Coutinho M, Gerstein H.C, Wang Y, Yusuf S. The relationship between glucose and incident cardiovascular events: A metaregression analysis of published data from 20 studies of 95,783 individuals followed for 12.4 years. Diabetes Care. 1999;22:233-240. Status: Not included because article does not describe a study or survey. [pmid: 10333939].
Crapo P.A, Kolterman O.G, Waldeck N, Reaven G.M, Olefsky J.M. Postprandial hormonal responses to different types of complex carbohydrate in individuals with impaired glucose tolerance. AM J CLIN NUTR. 1980;33:1723-1728. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6996472].
Crapo P.A, Scarlett J.A, Kolterman O.G. Comparison of the metabolic responses to fructose and sucrose sweetened foods. Am J Clin Nutr. 1982;36:256-261. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7048890].
Crawford, J. F. Proportional versus projected glucose tolerance values: a quality control program. ClinicalLaboratory Science 13(3):151–9, 2000 Summer (8 ref) 2000; 13:151–159. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Crivaro M, Celentano A, Palmieri V, Oliviero M, Tammaro P, Pietropaolo I, Esposito N.D. P, Bianco A, De Divitiis O. Mild arterial hypertension and impaired glucose tolerance: Short-term effects of manidipine hydrochloride. Advances in Therapy. 1996;13:365-372. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Crook M, Cartwright K, Lumb P, Worsley A. Serum sialic acid in young type-1 diabetic patients. Diabetes Res Clin Pract. 2000;47:119-122. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10670911].
Crowther N.J, Cameron N, Trusler J, Gray I.P. Association between poor glucose tolerance and rapid post natal weight gain in seven-year-old children. Diabetologia. 1998;41:1163-1167. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9794102].
Cruickshank K, Riste L, Anderson S.G, Wright J.S, Dunn G, Gosling R.G. Aortic pulse-wave velocity and its relationship to mortality in diabetes and glucose intolerance: an integrated index of vascular function. Circulation. 2002;106:2085-2090. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12379578].
Csabi G, Torok K, Jeges S, Molnar D. Presence of metabolic cardiovascular syndrome in obese children. Eur J Pediatr. 2000;159:91-94. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10653338].
Cucinotta D, De Luca F, Arrigo T, Di Benedetto A, Sferlazzas C, Gigante A, Rigoli L, Magazzu G. First-phase insulin response to intravenous glucose in cystic fibrosis patients with different degrees of glucose tolerance. J Pediatr Endocrinol. 1994;7:13-17. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8186820].
Cucinotta D, De Luca F, Gigante A, Arrigo T, Di Benedetto A, Tedeschi A, Lombardo F, Romano G, Sferlazzas C. No changes of insulin sensitivity in cystic fibrosis patients with different degrees of glucose tolerance: an epidemiological and longitudinal study. European Journal of Endocrinology. 1994;130:253-258. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8156098].
Curb J.D, Rodriguez B.L, Burchfiel C.M, Abbott R.D, Chiu D, Yano K. Sudden death, impaired glucose tolerance, and diabetes in Japanese American men. Circulation. 1995;91:2591-2595. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7743621].
Curb J.D, Rodriguez B.L, Abbott R.D, Petrovitch H, Ross G.W, Masaki K.H, Foley D, Blanchette P.L, Harris T, Chen R, White L.R. Longitudinal association of vascular and Alzheimer' dementias, diabetes, and glucose tolerance. Neurology. 1999;52:971-975. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10102414].
D'Agostino, R. B., Jr., Burke, G., O'Leary, D., Rewers, M., Selby, J., Savage, P. J., Saad, M. F., Bergman, R. N.,Howard, G., Wagenknecht, L., and Haffner, S. M. Ethnic differences in carotid wall thickness: the Insulin ResistanceAtherosclerosis Study. Stroke 27(10):1744–9, 1996 Oct (54 ref) 1996; 1744–1749. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Daniel M, O'Dea K, Rowley K.G, McDermott R, Kelly S. Glycated hemoglobin as an indicator of social environmental stress among indigenous versus westernized populations.[see comment]. Prev Med. 1999;29:405-413. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10564632].
Davidson M.B. Diagnosing diabetes: Cutoffs vs. tradeoffs. Endocrinologist. 2000;10:90-96. Status: Not included because article does not describe a study or survey.
Davies M, Rayman G, Day J. Increased incidence of coronary disease in people with impaired glucose tolerance: Link with increased lipoprotein(a) concentrations. British Medical Journal. 1992;304:1610-1611. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1385748]. [pmcid: 1881985].
Davies M.J, Rayman G, Gray I.P, Day J.L, Hales C.N. Insulin deficiency and increased plasma concentration of intact and 32/33 split proinsulin in subjects with impaired glucose tolerance. Diabet Med. 1993;10:313-320. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8508612].
Davies M.J, Rayman G, Grenfell A, Gray I.P, Day J.L, Hales C.N. Loss of the first phase insulin response to intravenous glucose in subjects with persistent impaired glucose tolerance. Diabet Med. 1994;11:432-436. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 8088119].
Davies M.J, Raymond N.T, Day J.L, Hales C.N, Burden A.C. Impaired glucose tolerance and fasting hyperglycaemia have different characteristics. Diabet Med. 2000;17:433-440. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10975211].
de Court, Pettitt D.J, Knowler W.C. Hypertension in Pima Indians: prevalence and predictors. Public Health Rep. 1996;111 Suppl 2:40-43. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8898771].
De Luca F, Arrigo T, Conti, Nibali S, Sferlazzas C, Gigante A, Di Cesare E, Cucinotta D. Insulin secretion, glycosylated haemoglobin and islet cell antibodies in cystic fibrosis children and adolescents with different degrees of glucose tolerance. Horm Metab Res. 1991;23:495-498. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1761281].
De Michele M, Panico S, Celentano E, Covetti G, Intrieri M, Zarrilli F, Sacchetti L, Tang R, Bond M.G, Rubba P. Association of impaired glucose homeostasis with preclinical carotid atherosclerosis in women: Impact of the new American Diabetes Association criteria. Metabolism. 2002;51:52-56. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11782872].
De Neeling J.N, Beks P.J, Bertelsmann F.W, Heine R.J, Bouter L.M. Peripheral somatic nerve function in relation to glucose tolerance in an elderly Caucasian population: the Hoorn study. Diabet Med. 1996;13:960-966. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8946154].
de Simone G, Verdecchia P, Pede S, Gorini M, Maggioni A.P. Prognosis of inappropriate left ventricular mass in hypertension: The MAVI study. Hypertension. 2002;40:470-476. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12364349].
de Simone G, Devereux R.B, Palmieri V, Roman M.J, Celentano A, Welty T.K, Fabsitz R.R, Contaldo F, Howard B.V. Relation of insulin resistance to markers of preclinical cardiovascular disease: the Strong Heart Study. Nutr Metab Cardiovasc Dis. 2003;13:140-147. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12955795].
DECODE Study Group on behalf of the European Diabetes Epidemiology Study Group. Will new diagnostic criteria for diabetes mellitus change phenotype of patients with diabetes? Reanalysis of European epidemiological data. [see comment]. BMJ. 1998;317:371-375. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9694750]. [pmcid: 28629].
DECODE Study Group, the European Diabetes Epidemiology Group. Glucose tolerance and cardiovascular mortality: comparison of fasting and 2-hour diagnostic criteria. Arch Intern Med. 2001;161:397-405. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11176766].
Decsi T, Molnar D. Insulin resistance syndrome in children: Pathophysiology and potential management strategies. Paediatric Drugs. 2003;5:291-299. Status: Not included because article does not describe a study or survey. [pmid: 12716216].
Delahanty L.M. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. Diabetes Spectrum. 1995;8:102-103. Status: Not included because article does not describe a study or survey.
Demchuk A.M, Tanne D, Hill M.D, Kasner S.E, Hanson S, Grond M, Levine S.R. Predictors of good outcome after intravenous tPA for acute ischemic stroke. Neurology. 2001;57:474-480. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11502916].
Dessi-Fulgheri P, Pacifico A, Bandiera F, Rubattu S, Madeddu P, Glorioso N, Maioli M, Delitala G, Tomasi P, Rappelli A. Effect of nifedipine and verapamil on carbohydrate metabolism in hypertensive patients with impaired glucose tolerance. J Cardiovasc Pharmacol. 1987;10(Suppl 10):S195-S198. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2455132].
Dessi-Fulgheri P, Zanna C, Di N.G, Baldinelli A, Paci M.V, Espinosa E, Rappelli A. Antihypertensive and metabolic effects of ketanserin in patients with hypertension and impaired glucose tolerance: A double-blind, randomized, placebo-controlled, crossover study. CURR THER RES CLIN EXP. 1991;49:249-255. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months.
Di Giulio R, Gaddi A, Ciarrocchi A, Barozzi G, Fraticelli G, Sangiorgi Z, La Regina G, Descovich G.C. Effects of coenzyme A in massive hypertriglyceridaemia (phenotype IV) and in patients with hypertriglyceridaemia associated with impaired glucose tolerance or diabetes mellitus. Acta Therapeutica. 1993;19:23-34. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Di Simone N, Ronsisvalle E, Fulghesu A.M, Lanzone A, Caruso A. Insulin plasma levels in pregnant patients with impaired glucose tolerance: relationship with pregnancy outcome. Gynecol Obstet Invest. 1996;42:16-20. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8840171].
Diabetes Prevention Program Research Group. The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22:623-634. Status: Not included because article does not describe a study or survey. [pmid: 10189543]. [pmcid: 1351026].
Diabetes Prevention Program Research Group. Hypertension, insulin, and proinsulin in participants with impaired glucose tolerance. Hypertension. 2002;40:679-686. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 12411462]. [pmcid: 2516377].
Diabetes Prevention Program Research Group. Effects of withdrawal from metformin on the development of diabetes in the diabetes prevention program. Diabetes Care. 2003;26:977-980. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12663559]. [pmcid: 1360737].
Dielemans I, de Jong P.T, Stolk R, Vingerling J.R, Grobbee D.E, Hofman A. Primary open-angle glaucoma, intraocular pressure, and diabetes mellitus in the general elderly population. The Rotterdam Study. Ophthalmology. 1996;103:1271-1275. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8764798].
DiPietro, L., Seeman, T. E., Stachenfeld, N. S., Katz, L. D., and Nadel, E. R. Moderate-intensity aerobic trainingimproves glucose tolerance in aging independent of abdominal adiposity. Journal of the American GeriatricsSociety 46(7):875–9, 1998 Jul (36 ref) 1998; 875–879. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review.
Doggrell S.A. Metformin& lifestyle intervention prevent Type 2 diabetes: lifestyle intervention has the greater effect. Expert Opin Pharmacother. 2002;3:1011-1013. Status: Not included because article does not describe a study or survey. [pmid: 12084000].
Dolecek R, Kubis M, Sajnar J, Zavada M. Bromocriptine and glucose tolerance in acromegalics. Pharmatherapeutica. 1982;3:100-106. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7048336].
Dowse G.K, Zimmet P.Z, King H. Relationship between prevalence of impaired glucose tolerance and NIDDM in a population. Diabetes Care. 1991;14:968-974. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1797510].
Dowse G.K, Zimmet P.Z, Gareeboo H, George K, Alberti M.M, Tuomilehto J, Finch C.F, Chitson P, Tulsidas H. Abdominal obesity and physical inactivity as risk factors for NIDDM and impaired glucose tolerance in Indian, Creole, and Chinese Mauritians. Diabetes Care. 1991;14:271-282. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 2060430].
Dowse G.K, Collins V.R, Alberti K.G, Zimmet P.Z, Tuomilehto J, Chitson P, Gareeboo H. Insulin and blood pressure levels are not independently related in Mauritians of Asian Indian, Creole or Chinese origin. The Mauritius Non-communicable Disease Study Group. J Hypertens. 1993;11:297-307. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8387088].
Dowse G.K. Incidence of NIDDM and the natural history of IGT in Pacific and Indian Ocean populations. Diabetes Res Clin Pract. 1996;34 Suppl:S45-S50. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9015669].
Dowse G.K, Humphrey A.R, Collins V.R, Plehwe W, Gareeboo H, Fareed D, Hemraj F, Taylor H.R, Tuomilehto J, Alberti K.G, Zimmet P.Z. Prevalence and risk factors for diabetic retinopathy in the multiethnic population of Mauritius. Am J Epidemiol. 1998;147:448-457. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9525531].
Duffy T.J, Ray R. Oral contraceptive use: prospective follow-up of women with suspected glucose intolerance. Contraception. 1984;30:197-208. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6509976].
Dunn P.J, Cole R.A, Soeldner J.S, Gleason R.E. Reproducibility of hemoglobin A(Ic) and sensitivity to various degrees of glucose intolerance. Annals of Internal Medicine. 1979;91:390-396. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 475166].
Ebert R, Frerichs H, Creutzfeldt W. Impaired feedback control of fat induced gastric inhibitory polypeptide (GIP) secretion by insulin in obesity and glucose intolerance. Eur J Clin Invest. 1979;9:129-135. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 111943].
Efendic S, Wajngot A, Cerasi E, Luft R. Insulin release, insulin sensitivity, and glucose intolerance. Proc Natl Acad Sci U S A. 1980;77:7425-7429. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7012840]. [pmcid: 350516].
El Hazmi M.A. F, Al Swailem A, Al Fawaz I, Warsey A.S, Al Swailem A. Diabetes mellitus in children suffering from beta-thalassaemia. J Trop Pediatr. 1994;40:261-266. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7807619].
Elbein S.C, Wegner K, Miles C, Yu L, Eisenbarth G. The role of late-onset autoimmune diabetes in white familial NIDDM pedigrees. Diabetes Care. 1997;20:1248-1251. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9250448].
Elliott R.B, Chase H.P. Prevention or delay of Type 1 (insulin-dependent) diabetes mellitus in children using nicotinamide. Diabetologia. 1991;34:362-365. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1830860].
Engfeldt P, Tyden G, Gunnarsson R. Impaired glucose tolerance with cyclosporine. Transplant Proc. 1986;18:65-66. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Erenus M, Gurler A.D, Elter K. Should we consider performing oral glucose tolerance tests more frequently in postmenopausal women for optimal screening of impaired glucose tolerance. Menopause. 2002;9:296-301. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12082367].
Ergun Y, Oksuz M, Isiksal F.Y, Kocak F, Abayli B. Frequency of impaired glucose tolerance test and diabetes mellitus in patients with cirrhosis due to hepatitis B virus infection. Annals of Medical Sciences. 2003;12:15-18. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Eriksson J, Saloranta C, Widen E, Ekstrand A, Franssila-Kallunki A, Schalin C, Groop L. Non-esterified fatty acids do not contribute to insulin resistance in persons at increased risk of developing Type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1991;34:192-197. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1884892].
Eriksson J, Valle T, Lindstrom J, Haffner S, Louheranta A, Uusitupa M, Tuomilehto J. Leptin concentrations and their relation to body fat distribution and weight loss--a prospective study in individuals with impaired glucose tolerance. DPS-study group. Horm Metab Res. 1999;31:616-619. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 10598830].
Eriksson J.G, Forsen T, Tuomilehto J, Jaddoe V.W. V, Osmond C, Barker D.J. P. Effects of size at birth and childhood growth on the insulin resistance syndrome in elderly individuals. Diabetologia. 2002;45:342-348. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11914739].
Eriksson K.-F, Lindgarde F. Prevention of Type 2 (non-insulin-dependent) diabetes mellitus by diet and physical exercise. The 6-year Malmo feasibility study. Diabetologia. 1991;34:891-898. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1778354].
Eriksson K.-F, Saltin B, Lindgarde F. Increased skeletal muscle capillary density precedes diabetes development in men with impaired glucose tolerance: A 15-year follow-up. Diabetes. 1994;43:805-808. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8194667].
Eriksson K.-F, Lindgarde F. No excess 12-year mortality in men with impaired glucose tolerance who participated in the Malmo Preventive Trial with diet and exercise. Diabetologia. 1998;41:1010-1016. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9754818].
Eriksson K.F, Lindgarde F. Impaired glucose tolerance in a middle-aged male urban population: a new approach for identifying high-risk cases [see comments]. Diabetologia. 1990;33:526-531. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2253828].
Eriksson K.F, Lindgarde F. Prevention of type 2 (non-insulin-dependent) diabetes mellitus by diet and physical exercise. The 6-year Malmo feasibility study. Diabetologia. 1991;34:891-898. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1778354].
Eriksson K.F, Saltin B, Lindgarde F. Increased skeletal muscle capillary density precedes diabetes development in men with impaired glucose tolerance. A 15-year follow-up. Diabetes. 1994;43:805-808. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8194667].
Eriksson K.F, Nilsson H, Lindgarde F, Osterlin S, Dahlin L.B, Lilja B, Rosen I, Sundkvist G. Diabetes mellitus but not impaired glucose tolerance is associated with dysfunction in peripheral nerves. Diabet Med. 1994;11:279-285. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8033527].
Eriksson K.F, Lindgarde F. No excess 12-year mortality in men with impaired glucose tolerance who participated in the Malmo Preventive Trial with diet and exercise. Diabetologia. 1998;41:1010-1016. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9754818].
Evans J.L, Goldfine I.D, Maddux B.A, Grodsky G.M. Are oxidative stress - Activated signaling pathways mediators of insulin resistance and beta-cell dysfunction. Diabetes. 2003;52:1-8. Status: Not included because article does not describe a study or survey. [pmid: 12502486].
Evans M.F. Can we prevent high-risk patients from getting type 2 diabetes. Canadian Family Physician. 2002;48:279-281. Status: Not included because article is not a fulltext publication. [pmid: 11889887]. [pmcid: 2213974].
Fagerberg B, Berglund A, Holme E, Wilhelmsen L, Elmfeldt D. Metabolic effects of controlled-release metoprolol in hypertensive men with impaired or diabetic glucose tolerance: A comparison with atenolol. J Intern Med. 1990;227:37-43. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2405089].
Fagot-Campagna A, Saaddine J.B, Flegal K.M, Beckles G.L. Diabetes, impaired fasting glucose, and elevated HbA1c in U.S. adolescents: the Third National Health and Nutrition Examination Survey. Diabetes Care. 2001;24:834-837. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11347739].
Fagundes, Neto U, Affonso, Scaletsky I. Escherichia coli infections and malnutrition. Lancet. 2000;356:s27. Status: Not included because article does not describe a study or survey. [pmid: 11191483].
Falch D.K, Schreiner A. The effect of spironolactone on lipid, glucose and uric acid levels in blood during long-term administration to hypertensives. Acta Medica Scandinavica. 1983;213:27-30. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6338681].
Falko J.M, Parr J.H, Simpson R.N, Wynn V. Lipoprotein analysis in varying degrees of glucose tolerance. Comparison between non-insulin-dependent diabetic, impaired glucose tolerant, and control populations. American Journal of Medicine. 1987;83:641-647. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3674053].
Farrer M, Game F.L, Albers C.J, Neil H.A, Winocour P.H, Laker M.F, Adams P.C, Alberti K.G. Association between impaired glucose tolerance and circulating concentration of Lp(a) lipoprotein in relation to coronary heart disease [see comments]. BMJ. 1993;307:832-836. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8401124]. [pmcid: 1678874].
Farrer M, Albers C.J, Neil H.A, Adams P.C, Laker M.F, Alberti K.G. Assessing the impact of blood sample type on the estimated prevalence of impaired glucose tolerance and diabetes mellitus in epidemiological surveys. Diabet Med. 1995;12:325-329. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 7600748].
Fasching P, Ratheiser K, Waldhausl W, Rohac M, Osterrode W, Nowotny P, Vierhapper H. Metabolic effects of fish-oil supplementation in patients with impaired glucose tolerance. Diabetes. 1991;40:583-589. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 2022303].
Felber J.-P, Ferrannini E, Golay A, Meyer H.U, Theibaud D, Curchod B, Maeder E, Jequier E, DeFronzo R.A. Role of lipid oxidation in pathogenesis of insulin resistance of obesity and type II diabetes. Diabetes. 1987;36:1341-1350. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3311856].
Felber J.P, Ferrannini E, Golay A, Meyer H.U, Theibaud D, Curchod B, Maeder E, Jequier E, DeFronzo R.A. Role of lipid oxidation in pathogenesis of insulin resistance of obesity and type II diabetes. Diabetes. 1987;36:1341-1350. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3311856].
Felber J.P, Golay A, Jequier E, Curchod B, Temler E, DeFronzo R.A, Ferrannini E. The metabolic consequences of long-term human obesity. Int J Obes. 1988;12:377-389. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3069764].
Feriozzi S, Meschini L, Costantini S, Gomes V, Ranalli T, Perez M, Ancarani E. Fatal intestinal tuberculosis in a uremic patient with a renal transplant. Jn Journal of Nephrology. 2002;15:593-596. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Fernandez H.H, Trieschmann M.E, Friedman J.H. Treatment of psychosis in Parkinson' disease: Safety considerations. DRUG SAF. 2003;26:643-659. Status: Not included because article does not describe a study or survey. [pmid: 12814332].
Fernando M.R, Wickramasinghe S.M. D. N, Thabrew M.I, Ariyananda P.L, Karunanayake E.H. Effect of Artocarpus heterophyllus and Asteracanthus longifolia on glucose tolerance in normal human subjects and in maturity-onset diabetic patients. J Ethnopharmacol. 1991;31:277-282. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2056756].
Ferrannini E, Mari A. How to measure insulin sensitivity. J Hypertens. 1998;16:895-906. Status: Not included because article does not describe a study or survey. [pmid: 9794728].
Ferrannini E, Gastaldelli A, Miyazaki Y, Matsuda M, Pettiti M, Natali A, Mari A, DeFronzo R.A. Predominant role of reduced beta-cell sensitivity to glucose over insulin resistance in impaired glucose tolerance. Diabetologia. 2003;46:1211-1219. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12879253].
Ferro A, Hall J.A, Dickerson J.E. C, Brown M.J. A prospective study of the effects of prolonged timolol therapy on alpha- and beta-adrenoceptor and angiotensin II receptor mediated responses in normal subjects. Br J Clin Pharmacol. 1997;43:301-308. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 9088585]. [pmcid: 2042735].
Feskens E.J, Bowles C.H, Kromhout D. Inverse association between fish intake and risk of glucose intolerance in normoglycemic elderly men and women. Diabetes Care. 1991;14:935-941. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1797505].
Feskens E.J, Bowles C.H, Kromhout D. Intra- and interindividual variability of glucose tolerance in an elderly population. J Clin Epidemiol. 1991;44:947-953. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1890437].
Feskens E.J, Kromhout D. Glucose tolerance and the risk of cardiovascular disease: the Zutphen Study. J Clin Epidemiol. 1992;45:1327-1334. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1432012].
Feskens E.J, Bowles C.H, Kromhout D. Association between fish intake and coronary heart disease mortality. Differences in normoglycemic and glucose intolerant elderly subjects. Diabetes Care. 1993;16:1029-1034. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8359097].
Feskens E.J, Tuomilehto J, Stengard J.H, Pekkanen J, Nissinen A, Kromhout D. Hypertension and overweight associated with hyperinsulinaemia and glucose tolerance: a longitudinal study of the Finnish and Dutch cohorts of the Seven Countries Study. Diabetologia. 1995;38:839-847. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7556987].
Feskens E.J, Virtanen S.M, Rasanen L, Tuomilehto J, Stengard J, Pekkanen J, Nissinen A, Kromhout D. Dietary factors determining diabetes and impaired glucose tolerance. A 20-year follow-up of the Finnish and Dutch cohorts of the Seven Countries Study. Diabetes Care. 1995;18:1104-1112. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 7587845].
Feskens E.J. M, Kromhout D. Glucose tolerance and the risk of cardiovascular diseases: The Zutphen Study. J Clin Epidemiol. 1992;45:1327-1334. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1432012].
Feskens E.J. M, Bowles C.H, Kromhout D. Glucose tolerance and mortality from ischemic heart disease in an elderly population: Impact of repeated glucose measurements. Ann Epidemiol. 1993;3:336-342. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8275208].
Festa A, D'Agostino R Jr, Mykkanen L, Tracy R.P, Hales C.N, Howard B.V, Haffner S.M. LDL particle size in relation to insulin, proinsulin, and insulin sensitivity. The Insulin Resistance Atherosclerosis Study. Diabetes Care. 1999;22:1688-1693. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10526736].
Flanagan D.E, Moore V.M, Godsland I.F, Cockington R.A, Robinson J.S, Phillips D.I. Fetal growth and the physiological control of glucose tolerance in adults: a minimal model analysis. Am J Physiol Endocrinol Metab. 2000;278:E700-E706. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10751205].
Fliser D, Rett K, Hubinger A, Ritz E. Influence of ACE inhibition on glucose tolerance in patients with stable chronic renal failure. Nephrol Dial Transplant. 1995;10:643-647. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7566576].
Flock E.V, Bennett P.H, Savage P.J. Bimodality of glycosylated hemoglobin distribution in Pima indians: Relationship to fasting hyperglycemia. Diabetes. 1979;28:984-989. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 488548].
Fluckey J.D, Hickey M.S, Brambrink J.K, Hart K.K, Alexander K, Craig B.W. Effects of resistance exercise on glucose tolerance in normal and glucose-intolerant subjects. J Appl Physiol. 1994;77:1087-1092. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7836108].
Folsom A.R, Jacobs D.R Jr, Wagenknecht L.E, Winkhart S.P, Yunis C, Hilner J.E, Savage P.J, Smith D.E, Flack J.M. Increase in fasting insulin and glucose over seven years with increasing weight and inactivity of young adults: the CARDIA Study. Am J Epidemiol. 1996;144:235-246. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8686692].
Fontbonne A, Eschwege E, Cambien F, Richard J.L, Ducimetiere P, Thibult N, Warnet J.M, Claude J.R, Rosselin G.E. Hypertriglyceridaemia as a risk factor of coronary heart disease mortality in subjects with impaired glucose tolerance or diabetes. Results from the 11-year follow-up of the Paris Prospective Study. Diabetologia. 1989;32:300-304. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2666216].
Fontbonne A, Thibult N, Eschwege E, Ducimetiere P. Body fat distribution and coronary heart disease mortality in subjects with impaired glucose tolerance or diabetes mellitus: the Paris Prospective Study, 15-year follow-up. Diabetologia. 1992;35:464-468. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1521729].
Fontbonne A, Charles A, Balkau B, Eschwege E. The insulin resistance syndrome and the Paris Prospective Study. Cardiovascular Risk Factors. 1993;3:36-43. Status: Not included because article does not describe a study or survey.
Fontbonne A, Charles M.A, Juhan-Vague I, Bard J, Andre P, Isnard F, Cohen J, Grandmottet P, Vague P, Safar M.E, Eschwege E. The effect of metformin on the metabolic abnormalities associated with upper-body fat distribution. Diabetes Care. 1996;19:920-926. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8875083].
Ford E.S, Will J.C, Bowman B.A, Narayan K.M. Diabetes mellitus and serum carotenoids: findings from the Third National Health and Nutrition Examination Survey. Am J Epidemiol. 1999;149:168-176. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9921962].
Forrest R.D, Jackson C.A, Yudkin J.S. The abbreviated glucose tolerance test in screening for diabetes: The Islington Diabetes Survey. Diabet Med. 1988;5:557-561. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2974779].
Foucan L, Bangou-Bredent J, Ekouevi D.K, Deloumeaux J, Roset J.E, Kangambega P. Hypertension and combinations of cardiovascular risk factors. An epidemiologic case-control study in an adult population in Guadeloupe (FWI). Eur J Epidemiol. 2002;17:1089-1095. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Fowkes F.G, Housley E, Riemersma R.A, Macintyre C.C, Cawood E.H, Prescott R.J, Ruckley C.V. Smoking, lipids, glucose intolerance, and blood pressure as risk factors for peripheral atherosclerosis compared with ischemic heart disease in the Edinburgh Artery Study. Am J Epidemiol. 1992;135:331-340. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1550087].
Foyle W.J, Carstensen E, Fernandez M.C, Yudkin J.S. Longitudinal study of associations of microalbuminuria with the insulin resistance syndrome and sodium-lithium countertransport in nondiabetic subjects. Arterioscler Thromb Vasc Biol. 1995;15:1330-1337. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7670946].
Frape D.L, Williams N.R, Rajput-Williams J, Maitland B.W, Scriven A.J, Palmer C.R, Fletcher R.J. Effect of breakfast fat content on glucose tolerance and risk factors of atherosclerosis and thrombosis. Br J Nutr. 1998;80:323-331. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9924274].
Frati Munari A.C, Fernandez Harp J.A, De La, Riva H. Effects of nopal (Opuntia sp.) on serum lipids, glycemia and body weight. Arch Invest Med (Mex ). 1983;14:117-125. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6314922].
Frayn K.N, Whyte P.L, Benson H.A, Earl D.J, Smith H.A. Changes in forearm blood flow at elevated ambient temperature and their role in the apparent impairment of glucose tolerance. Clin Sci (Colch ). 1989;76:323-328. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2494016].
Freedman D.S, Serdula M.K, Percy C.A, Ballew C, White L. Obesity, levels of lipids and glucose, and smoking among Navajo adolescents. J Nutr. 1997;127:2120S-2127S. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9339179].
Freemark M. Clinical perspective: Pharmacologic approaches to the prevention of type 2 diabetes in high risk pediatric patients. J Clin Endocrinol Metab. 2003;88:3-13. Status: Not included because article does not describe a study or survey. [pmid: 12519819].
French L.R, Boen J.R, Martinez A.M, Bushhouse S.A, Sprafka J.M, Goetz F.C. Population-based study of impaired glucose tolerance and type II diabetes in Wadena, Minnesota. Diabetes. 1990;39:1131-1137. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 2384192].
Freyschuss U, Gentz J, Noack G, Persson B. Circulatory adaptation in newborn infants of strictly controlled diabetic mothers. Acta Paediatr Scand. 1982;71:209-215. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7136629].
Fujimoto W.Y, Leonetti D.L, Kinyoun J.L, Newell-Morris L, Shuman W.P, Stolov W.C, Wahl P.W. Prevalence of diabetes mellitus and impaired glucose tolerance among second-generation Japanese-American men. Diabetes. 1987;36:721-729. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 3569671].
Fujimoto W.Y, Leonetti D.L, Kinyoun J.L. Prevalence of complications among second-generation Japanese-American men with diabetes, impaired glucose tolerance, and normal glucose tolerance. Diabetes. 1987;36:730-739. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 3569672].
Fujimoto W.Y, Bergstrom R.W, Leonetti D.L, Newell-Morris L.L, Shuman W.P, Wahl P.W. Metabolic and adipose risk factors for NIDDM and coronary disease in third-generation Japanese-American men and women with impaired glucose tolerance. Diabetologia. 1994;37:524-532. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8056192].
Fujiwara R, Kutsumi Y, Hayashi T, Nishio H, Koshino Y, Shimada Y, Nakai T, Miyabo S. Relation of angiographically defined coronary artery disease and plasma concentrations of insulin, lipid, and apolipoprotein in normolipidemic subjects with varying degrees of glucose tolerance. Am J Cardiol. 1995;75:122-126. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 7810485].
Fukuda H, Muto T, Kawamori R. Evaluation of a diabetes patient education program consisting of a three-day hospitalization and a six-month follow-up by telephone counseling for mild type 2 diabetes and IGT. Environmental Health& Preventive Medicine. 1999;4:122-129. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Fukuda I, Hizuka N, Murakami Y, Itoh E, Yasumoto K, Sata A, Takano K. Clinical features and therapeutic outcomes of 65 patients with acromegaly at Tokyo Women' Medical University. Intern Med. 2001;40:987-992. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11688841].
Fulghesu A.M, Cucinelli F, Pavone V, Murgia F, Guido M, Caruso A, Mancuso S, Lanzone A. Changes in luteinizing hormone and insulin secretion in polycystic ovarian syndrome. Hum Reprod. 1999;14:611-617. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10221684].
Fuller J.H, Shipley M.J. Hyperglycaemia as a cardiovascular risk factor. Postgrad Med J. 1989;65:S30-S32. Status: Not included because article does not describe a study or survey. [pmid: 2622811].
Fuller JohnH, Shipley MartinJ, Rose Geoffrey, Jarrett R.John, Keen Harry. Coronary-heart-disease and impaired glucose tolerance. The Whitehall Study. The Lancet. 1980;315:1373-1376. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Gabbay R.A. New developments in home glucose monitoring: Minimizing the pain. Canadian Journal of Diabetes. 2003;27:271-276. Status: Not included because article does not describe a study or survey.
Gale E.A. European Nicotinamide Diabetes Intervention Trial Group. Intervening before the onset of Type 1 diabetes: baseline data from the European Nicotinamide Diabetes Intervention Trial (ENDIT). Diabetologia. 2003;46:339-346. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 12687331].
Gale E.A. M. Intervening before the onset of Type 1 diabetes: baseline data from the European Nicotinamide Diabetes Intervention Trial (ENDIT). Diabetologia. 2003;46:339-346. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12687331].
Galli-Tsinopoulou A, Karamouzis M, Nousia-Arvanitakis S. Insulin resistance and hyperinsulinemia in prepubertal obese children. J Pediatr Endocrinol Metab. 2003;16:555-560. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12793608].
Ganda O.P, Day J.L, Soeldner J.S, Connon J.J, Gleason R.E. Reproducibility and comparative analysis of repeated intravenous and oral glucose tolerance tests. Diabetes. 1978;27:715-725. Status: Not included because article was published before 1979. [pmid: 658617].
Gans D.A, Harper A.E, Bachorowski J.-A, Newman J.P, Shrago E.S, Taylor S.L. Sucrose and delinquency: Oral sucrose tolerance test and nutritional assessment. Pediatrics. 1990;86:254-262. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2196523].
Gapstur S.M, Gann P.H, Lowe W, Liu K, Colangelo L, Dyer A. Abnormal glucose metabolism and pancreatic cancer mortality.[see comment]. JAMA. 2000;283:2552-2558. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10815119].
Garagorri J.M, Rodriguez G, Ros L, Sanchez A. Early detection of impaired glucose tolerance in patients with cystic fibrosis and predisposition factors. J Pediatr Endocrinol Metab. 2001;14:53-60. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11220706].
Gartaganis S.P, Psyrojannis A.J, Koliopoulos J.X, Mela E.K. Contrast sensitivity function in patients with impaired oral glucose tolerance. Optometry& Vision Science. 2001;78:157-161. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11327677].
Gautam V.K, Vasavada J.P, Khanijo S.K. A study of oral glucose tolerance test in patients of hypertension receiving propranolol. Indian Heart J. 1989;41:261-264. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2807363].
Gavella M, Lipovac V, Car A, Vucic M. Baseline diene conjugation in LDL lipids from newly diagnosed type 2 diabetic patients. Diabetes Metab. 2002;28:391-396. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12461476].
Gelmini G, Butturini L, Cucinotta D, Delsignore R, Coiro V. Whole blood filterability in elderly obese women. Acta Diabetol Lat. 1987;24:199-203. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3687312].
Geloneze B, Tambascia M.A, Pareja J.C, Repetto E.M, Magna L.A, Pereira S.G. Serum leptin levels after bariatric surgery across a range of glucose tolerance from normal to diabetes. Obes Surg. 2001;11:693-698. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11775566].
Gerard J, Luyckx A.S, Lefebvre P.J. Acarbose in reactive hypoglycemia: a double-blind study. Int J Clin Pharmacol Ther Toxicol. 1984;22:25-31. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6698657].
Gerritsen J, Dekker J.M, TenVoorde B.J, Bertelsmann F.W, Kostense P.J, Stehouwer C.D, Heine R.J, Nijpels G, Heethaar R.M, Bouter L.M. Glucose tolerance and other determinants of cardiovascular autonomic function: the Hoorn Study. Diabetologia. 2000;43:561-570. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10855530].
Gerstein H.C, Pais P, Pogue J, Yusuf S. Relationship of glucose and insulin levels to the risk of myocardial infarction: a case-control study. J Am Coll Cardiol. 1999;33:612-619. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 10080459].
Giacca A, Groenewoud Y, Tsui E, McClean P, Zinman B. Glucose production, utilization, and cycling in response to moderate exercise in obese subjects with type 2 diabetes and mild hyperglycemia. Diabetes. 1998;47:1763-1770. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9792546].
Giannarelli, R. Aragona. Reducing insulin resistance with metformin: the evidence today. Diabetes Metab 2003; 29:28-35. Status: Not included because article does not describe a study or survey
Ginsberg-Fellner F, Witt M.E, Franklin B.H, Yagihashi S, Toguchi Y, Dobersen M.J, Rubinstein P, Notkins A.L. Triad of markers for identifying children at high risk of developing insulin-dependent diabetes mellitus. JAMA. 1985;254:1469-1472. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3897593].
Ginsberg H.N. Treatment for Pateints with the Metabolic Syndrome. Am J Cardiol. 2003;91:Suppl:29E-39E. Status: Not included because article does not describe a study or survey.
Giugliano D, Torella R, Cacciapuoti F, Gentile S, Verza M, Varricchio M. Impairment of insulin secretion in man by nifedipine. Eur J Clin Pharmacol. 1980;18:395-398. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7002569].
Giugliano D, Quatraro A, Minei A, De Rosa N, Coppola L, D'Onofrio F. Hyperinsulinemia in hypertension: increased secretion, reduced clearance or both. J Endocrinol Invest. 1993;16:315-321. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 8320421].
Giugliano D, Quatraro A, Acampora R, De Rosa N, Ceriello A, D'Onofrio F. Hyperinsulinemia in glucose intolerance: is it true. J Endocrinol Invest. 1994;17:391-396. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7930385].
Glorioso N, Bandiera F, Fulgheri P.D. Once-a-day fenquizone in the treatment of hypertensive patients with impaired glucose tolerance. Current Therapeutic Research, Clinical & Experimental. 1984;35:483-490. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Godsland I.F, Shennan N.M, Wynn V. Insulin action and dynamics modelled in patients taking the anabolic steroid methandienone (Dianabol). Clin Sci (Colch ). 1986;71:665-673. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3539458].
Goedecke J.H, Elmer-English R, Dennis S.C, Schloss I, Noakes T.D, Lambert E.V. Effects of medium-chain triacylglycerol ingested with carbohydrate on metabolism and exercise performance. Int J Sport Nutr. 1999;9:35-47. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10036340].
Goetz F.C, French L.R, Thomas W, Gingerich R.L, Clements J.P. Are specific serum insulin levels low in impaired glucose tolerance and type II diabetes?: measurement with a radioimmunoassay blind to proinsulin, in the population of Wadena, Minnesota. Metabolism. 1995;44:1371-1376. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7476300].
Goetz F.C, Jacobs D.R Jr, Chavers B, Roel J, Yelle M, Sprafka J.M. Risk factors for kidney damage in the adult population of Wadena, Minnesota. A prospective study. Am J Epidemiol. 1997;145:91-102. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9006305].
Golay A, Felber J.P, Meyer H.U, Curchod B, Maeder E, Jequier E. Study on lipid metabolism in obesity diabetes. Metabolism. 1984;33:111-116. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6694554].
Golay A, Felber J.P. Evolution from obesity to diabetes. Diabete Metab. 1994;20:3-14. Status: Not included because article does not describe a study or survey. [pmid: 8056132].
Golay A, Munger R, Assimacopoulos-Jeannet F, Bobbioni-Harsch E, Habicht F, Felber J.-P. Progressive defect of insulin action on glycogen synthase in obesity and diabetes. Metabolism. 2002;51:549-553. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11979384].
Gonzalez, Villalpando C, Stern M.P, Haffner S, Arredondo, Perez B, Martinez, Diaz S, Islas, Andrade S. The insulin resistance syndrome in Mexico. Prevalence and clinical characteristics: a population based study. Arch Med Res. 1995;26 Spec No:S9-15. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8845665].
Goodstein M.H, Herman J.H, Smith J.F, Rubenstein S.D. Metabolic consequences in very low birth weight infants transfused with older AS-1-preserved erythrocytes. Pediatric Pathology& Molecular Medicine. 1998;18:173-185. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Gorogawa S.-I, Kajimoto Y, Umayahara Y, Kaneto H, Watada H, Kuroda A, Kawamori D, Yasuda T, Matsuhisa M, Yamasaki Y, Hori M. Probucol preserves pancreatic beta-cell function through reduction of oxidative stress in type 2 diabetes. Diabetes Res Clin Pract. 2002;57:1-10. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12007724].
Grant K.E, Chandler R.M, Castle A.L, Ivy J.L. Chromium and exercise training: effect on obese women. Medicine& Science in Sports& Exercise. 1997;29:992-998. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9268955].
Grant P. Insulin resistance and cardiovascular disease: Redefining type 2 diabetes. British Journal of Cardiology. 2001;8:S1-S3. Status: Not included because article does not describe a study or survey.
Grant P.T, Oats J.N, Beischer N.A. The long-term follow-up of women with gestational diabetes. Aust N Z J Obstet Gynaecol. 1986;26:17-22. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3460570].
Grassi G, Seravalle G, Dell'Oro R, Trevano F.Q, Bombelli M, Scopelliti F, Facchini A, Mancia G. Comparative effects of candesartan and hydrochlorothiazide on blood pressure, insulin sensitivity, and sympathetic drive in obese hypertensive individuals: Results of the CROSS study. J Hypertens. 2003;21:1761-1769. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12923410].
Greenbaum C.J, Kahn S.E, Palmer J.P. Nicotinamide' effects on glucose metabolism in subjects at risk for IDDM. Diabetes. 1996;45:1631-1634. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8866571].
Griffiths J, Springuel P. Reports on Individual Drugs. WHO Drug Information. 2001;15:152-154. Status: Not included because article does not describe a study or survey.
Grimberg A, Ferry R.J Jr, Kelly A, Koo-Mccoy S, Polonsky K, Glaser B, Permutt M.A, Aguilar-Bryan L, Stafford D, Thornton P.S, Baker L, Stanley C.A. Dysregulation of insulin secretion in children with congenital hyperinsulinism due to sulfonylurea receptor mutations. Diabetes. 2001;50:322-328. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11272143].
Grinker J.A, Tucker K.L, Vokonas P.S, Rush D. Changes in patterns of fatness in adult men in relation to serum indices of cardiovascular risk: The Normative Aging Study. Int J Obes. 2000;24:1369-1378. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Grobin W. A longitudinal study of impaired glucose tolerance and diabetes mellitus in the aged. J Am Geriatr Soc. 1989;37:1127-1134. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2592720].
Guazzarotti L, Fumelli P, Testa I, Pecora R, Panicri F, Bellanne-Chantelot C, Bartolotta E. Diagnosis of MODY in the offspring of parents with insulin-dependent and non-insulin-dependent diabetes mellitus. J Pediatr Endocrinol Metab. 2001;14:611-617. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11393552].
Guerrero-Romero F, Rodriguez-Moran M. Proteinuria is an independent risk factor for ischemic stroke in non- insulin-dependent diabetes mellitus. Stroke. 1999;30:1787-1791. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10471424].
Guerrero-Romero F, Rodriguez-Moran M. Hypomagnesemia is linked to low serum HDL-cholesterol irrespective of serum glucose values. J Diabetes Complications. 2000;14:272-276. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11113690].
Guerrero-Romero F, Rodriguez-Moran M. Glucose intolerance is predicted by the high Fasting Insulin-to-Glucose ratio. Diabetes Metab. 2001;27:117-121. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11353876].
Guerrero-Romero F, Rodriguez-Moran M. Relation of C-reactive protein to features of the metabolic syndrome in normal glucose tolerant, impaired glucose tolerant, and newly diagnosed type 2 diabetic subjects. Diabetes Metab. 2003;29:65-71. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12629450].
Guerrero-Romero F, Rodriguez-Moran M. Pioglitazone increases serum magnesium levels in glucose-intolerant subjects. A randomized, controlled trial. Experimental& Clinical Endocrinology& Diabetes. 2003;111:91-96. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 12746760].
Guichard-Rode S, Charrie A, Penet D, Teboul F, Thivolet C. Massive weight loss does not restore normal insulin secretory pulses in obese patients with type 2 (non-insulin-dependent) diabetes mellitus. Diabetes Metab. 1997;23:506-510. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9496556].
Guillaume M, Lapidus L, Beckers F, Lambert A, Bjorntorp P. Cardiovascular risk factors in children from the Belgian province of Luxembourg. The Belgian Luxembourg Child Study. Am J Epidemiol. 1996;144:867-880. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8890665].
Gulbas Z, Erdogan Y, Balci S. Impaired glucose tolerance in pulmonary tuberculosis. Eur J Respir Dis. 1987;71:345-347. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because of case-control design. Not included for treatment because intervention was not relevant to review. [pmid: 3443157].
Guthrie J.R, Ball M, Dudley E.C, Garamszegi C.V, Wahlqvist M.L, Dennerstein L, Burger H.G. Impaired fasting glycaemia in middle-aged women: a prospective study. Int J Obes Relat Metab Disord. 2001;25:646-651. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11360146].
Haeusler G, Frisch H. Growth hormone treatment in Turner' syndrome: Short and long-term effects on metabolic parameters. Clin Endocrinol (Oxf). 1992;36:247-254. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1563078].
Haffner S.M, Fong D, Hazuda H.P, Pugh J.A, Patterson J.K. Hyperinsulinemia, upper body adiposity, and cardiovascular risk factors in non-diabetics. Metabolism. 1988;37:338-345. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3282148].
Haffner S.M, Stern M.P, Hazuda H.P, Mitchell B.D, Patterson J.K. Cardiovascular risk factors in confirmed prediabetic individuals. Does the clock for coronary heart disease start ticking before the onset of clinical diabetes? [see comments]. JAMA. 1990;263:2893-2898. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2338751].
Haffner S.M, Gonzales C, Valdez R.A, Mykkanen L, Hazuda H.P, Mitchell B.D, Monterrosa A, Stern M.P. Is microalbuminuria part of the prediabetic state? The Mexico City Diabetes Study. Diabetologia. 1993;36:1002-1006. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8243847].
Haffner S.M, Bowsher R.R, Mykkanen L, Hazuda H.P, Mitchell B.D, Valdez R.A, Gingerich R, Monterossa A, Stern M.P. Proinsulin and specific insulin concentration in high-and low-risk populations for NIDDM. Diabetes. 1994;43:1490-1493. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7958504].
Haffner S.M, Agil A, Mykkanen L, Stern M.P, Jialal I. Plasma oxidizability in subjects with normal glucose tolerance, impaired glucose tolerance, and NIDDM. Diabetes Care. 1995;18:646-653. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8586002].
Haffner S.M, Miettinen H, Gaskill S.P, Stern M.P. Decreased insulin action and insulin secretion predict the development of impaired glucose tolerance. Diabetologia. 1996;39:1201-1207. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8897008].
Haffner S.M, Miettinen H, Stern M.P. The homeostasis model in the San Antonio Heart Study. Diabetes Care. 1997;20:1087-1092. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9203442].
Haffner S.M, D'Agostino R Jr, Mykkanen L, Tracy R, Howard B, Rewers M, Selby J, Savage P.J, Saad M.F. Insulin sensitivity in subjects with type 2 diabetes: Relationship to cardiovascular risk factors: The Insulin Resistance Atherosclerosis Study. Diabetes Care. 1999;22:562-568. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10189532].
Haffner S.M, Alexander C.M, Cook T.J, Boccuzzi S.J, Musliner T.A, Pedersen T.R, Kjekshus J, Pyorala K. Reduced coronary events in simvastatin-treated patients with coronary heart disease and diabetes or impaired fasting glucose levels: subgroup analyses in the Scandinavian Simvastatin Survival Study.[comment]. Arch Intern Med. 1999;159:2661-2667. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10597756].
Haffner S.M, Mykkanen L, Festa A, Burke J.P, Stern M.P. Insulin-resistant prediabetic subjects have more atherogenic risk factors than insulin-sensitive prediabetic subjects: implications for preventing coronary heart disease during the prediabetic state. Circulation. 2000;101:975-980. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10704163].
Hallgren R, Berne C. Glucose intolerance in patients with chronic inflammatory diseases is normalized by glucocorticoids. Acta Medica Scandinavica. 1983;213:351-355. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6880857].
Hamada N, Ito K, Mimura T. Factors predicting the course of diabetes mellitus in hyperthyroid patients. Horm Metab Res. 1986;18:260-263. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3519414].
Hamman R.F, Marshall J.A, Baxter J, Kahn L.B, Mayer E.J, Orleans M, Murphy J.R, Lezotte D.C. Methods and prevalence of non-insulin-dependent diabetes mellitus in a biethnic Colorado population. The San Luis Valley Diabetes Study. Am J Epidemiol. 1989;129:295-311. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 2912042].
Hanai H, Ikuma M, Sato Y, Iida T, Hosoda Y, Matsushita I, Nogaki A, Yamada M, Kaneko E. Long-term effects of water-soluble corn bran hemicellulose on glucose tolerance in obese and non-obese patients: improved insulin sensitivity and glucose metabolism in obese subjects. Biosci Biotechnol Biochem. 1997;61:1358-1361. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9301120].
Hanas R, Adolfsson P, Elfvin-Akesson K, Hammaren L, Ilvered R, Jansson I, Johansson C, Kroon M, Lindgren J, Lindh A, Ludvigsson J, Sigstrom L, Wilk A, Aman J. Indwelling catheters used from the onset of diabetes decrease injection pain and pre-injection anxiety. J Pediatr. 2002;140:315-320. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11953729].
Hanefeld M, Temelkova-Kurktschiev T. The postprandial state and the risk of atherosclerosis. Diabet Med. 1997;14:S6-S11. Status: Not included because article does not describe a study or survey. [pmid: 9272607].
Hanefeld M, Koehler C, Henkel E, Fuecker K, Schaper F, Temelkova-Kurktschiev T. Post-challenge hyperglycaemia relates more strongly than fasting hyperglycaemia with carotid intima-media thickness: The RIAD study. Diabet Med. 2000;17:835-840. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11168325].
Hanley A.J, McKeown-Eyssen G, Harris S.B, Hegele R.A, Wolever T.M, Kwan J, Zinman B. Cross-sectional and prospective associations between abdominal adiposity and proinsulin concentration. J Clin Endocrinol Metab. 2002;87:77-83. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11788626].
Hara-Nakamura N, Kohara K, Sumimoto T, Lin M, Hiwada K. Glucose intolerance exaggerates left ventricular hypertrophy and dysfunction in essential hypertension. Am J Hypertens. 1994;7:1110-1114. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7702807].
Harris M.I. Impaired glucose tolerance in the U.S. population. Diabetes Care. 1989;12:464-474. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 2758951].
Harris M.I, Klein R, Cowie C.C, Rowland M, Byrd-Holt D.D. Is the risk of diabetic retinopathy greater in non-Hispanic blacks and Mexican Americans than in non-Hispanic whites with type 2 diabetes? A U.S. population study. Diabetes Care. 1998;21:1230-1235. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9702425].
Harris S.B, Zinman B, Hanley A, Gittelsohn J, Hegele R, Connelly P.W, Shah B, Hux J.E. The impact of diabetes on cardiovascular risk factors and outcomes in a native Canadian population. Diabetes Res Clin Pract. 2002;55:165-173. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11796183].
Hartling S.G, Lindgren F, Dahlqvist G, Persson B, Binder C. Elevated proinsulin in healthy siblings of IDDM patients independent of HLA identity. Diabetes. 1989;38:1271-1274. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2792577].
Hayashi K, Kurushima H, Kuga Y, Shingu T, Tanaka K, Yasunobu Y, Nomura K, Ohtani H, Hiraga T, Toyota Y, Katano T, Sakai-Ohta K, Kajiyama G. Comparison of the effect of bezafibrate on improvement of atherogenic lipoproteins in Japanese familial combined hyperlipidemic patients with or without impaired glucose tolerance. Cardiovascular Drugs& Therapy. 1998;12:3-12. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9607127].
Hays NP.Starling RD.Liu. Effects of an ad libitum low-fat, high-carbohydrate diet on body weight, body composition, and fat distribution in older men and women: a randomized controlled trial. Arch Intern Med 2004; 164:210-217. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review.
He J, Klag M.J, Caballero B, Appel L.J, Charleston J, Whelton P.K. Plasma insulin levels and incidence of hypertension in African Americans and whites. Arch Intern Med. 1999;159:498-503. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10074959].
Heald A.H, Cruickshank J.K, Riste L.K, Cade J.E, Anderson S, Greenhalgh A, Sampayo J, Taylor W, Fraser W, White A, Gibson J.M. Close relation of fasting insulin-like growth factor binding protein-1 (IGFBP-1) with glucose tolerance and cardiovascular risk in two populations. Diabetologia. 2001;44:333-339. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11317665].
Heine R.J, Nijpels G, Mooy J.M. New data on the rate of progression of impaired glucose tolerance to NIDDM and predicting factors. Diabet Med. 1996;13:S12-S14. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Helkala E.L, Lakka T, Vanhanen M, Tuomainen T.P, Ehnholm C, Kaplan G.A, Salonen J.T. Associations between apolipoprotein E phenotype, glucose metabolism and cognitive function in men. An explorative study in a population sample. Diabet Med. 2001;18:991-997. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11903399].
Henkel E, Temelkova-Kurktschiev T, Koehler C, Pietzsch J, Leonhardt W, Hanefeld M. Impaired glucose tolerance is not associated with lipid intolerance. Diabetes Nutr Metab. 2002;15:84-90. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12059096].
Henry R.M. A, Kostense P.J, Spijkerman A.M. W, Dekker J.M, Nijpels G, Heine R.J, Kamp O, Westerhof N, Bouter L.M, Stehouwer C.D. A. Arterial stiffness increases with deteriorating glucose tolerance Status: the Hoorn Study. Circulation. 2003;107:2089-2095. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12695300].
Hermann, J., Chung, H., Arquitt, A., Goad, C., Burns, M., and Chan, B. Effects of chromium or copper supplementation on plasma lipids, plasma glucose and serum insulin in adults over age fifty. Journal of Nutrition for the Elderly 18(1):27–45, 1998 (48 ref) 1998; 27–45. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Herranz L, Megia A, Grande C, Gonzalez-Gancedo P, Pallardo F. Dehydroepiandrosterone sulphate, body fat distribution and insulin in obese men. Int J Obes. 1995;19:57-60. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Herskowitz-Dumont R, Wolfsdorf J.I, Jackson R.A, Eisenbarth G.S. Distinction between transient hyperglycemia and early insulin-dependent diabetes mellitus in childhood: a prospective study of incidence and prognostic factors. J Pediatr. 1993;123:347-354. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8355109].
Hetzler R.K, Warhaftig-Glynn N, Thompson D.L, Dowling E, Weltman A. Effects of acute caffeine withdrawal on habituated male runners. J Appl Physiol. 1994;76:1043-1048. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8005843].
Heymsfield S.B, Segal K.R, Hauptman J, Lucas C.P, Boldrin M.N, Rissanen A, Wilding J.P. H, Sjostrom L. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000;160:1321-1326. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10809036].
Higashi K, Shige H, Ito T, Nakajima K, Ishikawa T, Nakamura H, Ohsuzu F. Impaired glucose tolerance without hypertriglyceridemia does not enhance postprandial lipemia. Horm Metab Res. 2001;33:101-105. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 11294490].
Hilton C.W, Mizuma H, Svec F, Prasad C. Relationship between plasma cyclo (His-Pro), a neuropeptide common to processed protein-rich food, and C-peptide/insulin molar ratio in obese women. Nutritional Neuroscience. 2001;4:469-474. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11843266].
Hiltunen L, Keinanen-Kiukaanniemi S, Laara E, Kivela S.L. Functional ability of elderly persons with diabetes or impaired glucose tolerance. Scand J Prim Health Care. 1996;14:229-237. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8956451].
Hiltunen L, Laara E, Keinanen-Kiukaanniemi S. Changes in glucose tolerance during three years' follow-up in an elderly population. Public Health. 1999;113:181-184. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10483080].
Hiltunen L.A, Keinanen-Kiukaanniemi S.M, Laara E.M. Glucose tolerance and cognitive impairment in an elderly population. Public Health. 2001;115:197-200. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11429715].
Hiltunen L.A. Does glucose tolerance affect elderly persons' balance, gait or muscle strength. Central European Journal of Public Health. 2001;9:22-25. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11243584].
Himmelmann A, Jendle J, Mellen A, Petersen A.H, Dahl U.L, Wollmer P. The impact of smoking on inhaled insulin. Diabetes Care. 2003;26:677-682. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12610021].
Hinds A, Sheehan A.G, Parsons H.G. Tolbutamide causes a modest increase in insulin secretion in cystic fibrosis patients with impaired glucose tolerance. Metabolism. 1995;44:13-18. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7854158].
Hirai N, Kawano H, Hirashima O, Motoyama T, Moriyama Y, Sakamoto T, Kugiyama K, Ogawa H, Nakao K, Yasue H. Insulin resistance and endothelial dysfunction in smokers: effects of vitamin C. Am J Physiol Heart Circ Physiol. 2000;279:H1172-H1178. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 10993781].
Hirano T, Yoshino G, Kashiwazaki K, Adachi M. Doxazosin reduces prevalence of small dense low density lipoprotein and remnant-like particle cholesterol levels in nondiabetic and diabetic hypertensive patients. Am J Hypertens. 2001;14:908-913. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11587157].
Hirose T, Mizuno R, Yoshimoto T. The effects of nateglinide following oral glucose load in impaired glucose tolerance subjects: rapid insulin stimulation by nateglinide in IGT subjects. Endocr J. 2002;49:649-652. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 12625415].
Hjalmarsen A, Aasebo U, Birkeland K, Sager G, Jorde R. Impaired glucose tolerance in patients with chronic hypoxic pulmonary disease. Diabetes Metab. 1996;22:37-42. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8697294].
Hjelmesaeth J, Hartmann A, Midtvedt K, Aakhus S, Stenstrom J, Morkrid L, Egeland T, Tordarson H, Fauchald P. Metabolic cardiovascular syndrome after renal transplantation. Nephrol Dial Transplant. 2001;16:1047-1052. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11328915].
Ho K.K, Jenkins A.B, Furler S.M, Borkman M, Chisholm D.J. Impact of octreotide, a long-acting somatostatin analogue, on glucose tolerance and insulin sensitivity in acromegaly. Clin Endocrinol (Oxf). 1992;36:271-279. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1563080].
Hodge A.M, Dowse G.K, Zimmet P.Z, Gareeboo H, Westerman R.A, Tuomilehto J, Alberti K.G. Factors associated with impaired vibration perception in Mauritians with normal and abnormal glucose tolerance. Mauritius NCD Study Group. J Diabetes Complications. 1995;9:149-157. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7548978].
Hoehner C.M, Greenlund K.J, Rith-Najarian S, Casper M.L, McClellan W.M. Association of the insulin resistance syndrome and microalbuminuria among nondiabetic native Americans. The Inter-Tribal Heart Project. J Am Soc Nephrol. 2002;13:1626-1634. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12039992].
Holl R.W, Kunze D, Etzrodt H, Teller W, Heinze E. Turner syndrome: Final height, glucose tolerance, bone density and psychosocial status in 25 adult patients. Eur J Pediatr. 1994;153:11-16. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8313917].
Holl R.W, Heinze E, Wolf A, Rank M, Teller W.M. Reduced pancreatic insulin release and reduced peripheral insulin sensitivity contribute to hyperglycaemia in cystic fibrosis. Eur J Pediatr. 1995;154:356-361. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7641765].
Holloszy J.O, Schultz J, Kusnierkiewicz J. Effects of exercise on glucose tolerance and insulin resistance. Brief review and some preliminary results. Acta Medica Scandinavica. 1986;220:55-65. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Holstein A, Hinze S, Thiessen E, Plaschke A, Egberts E.H. Clinical implications of hepatogenous diabetes in liver cirrhosis. Journal of Gastroenterology& Hepatology. 2002;17:677-681. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12100613].
Hoogeveen E.K, Kostense P.J, Beks P.J, Mackaay A.J, Jakobs C, Bouter L.M, Heine R.J, Stehouwer C.D. Hyperhomocysteinemia is associated with an increased risk of cardiovascular disease, especially in non-insulin-dependent diabetes mellitus: a population-based study. Arterioscler Thromb Vasc Biol. 1998;18:133-138. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9445267].
Hoogeveen E.K, Kostense P.J, Jager A, Heine R.J, Jakobs C, Bouter L.M, Donker A.J, Stehouwer C.D. Serum homocysteine level and protein intake are related to risk of microalbuminuria: the Hoorn Study.[see comment]. Kidney Int. 1998;54:203-209. Status: Not included because article is not a fulltext publication. [pmid: 9648080].
Hoshino A. Studies on carbohydrate metabolism in infants with congenital heart disease. Part I. Alteration of glucose and lactate metabolism in congenital heart disease. Acta Paediatr Jpn. 1981;23:162-171. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Hramiak I.M, Finegood D.T, Adams P.C. Factors affecting glucose tolerance in hereditary hemochromatosis. Clin Invest Med. 1997;20:110-118. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9088667].
Huang T.T, Johnson M.S, Gower B.A, Goran M.I. Effect of changes in fat distribution on the rates of change of insulin response in children. Obes Res. 2002;10:978-984. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12376577].
Hughes L.O, Raval U, Raftery E.B. First myocardial infarctions in Asian and white men. Br Med J (Clin Res Ed). 1989;298:1345-1350. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Hughes V.A, Fiatarone M.A, Fielding R.A, Ferrara C.M, Elahi D, Evans W.J. Long-term effects of a high-carbohydrate diet and exercise on insulin action in older subjects with impaired glucose tolerance. Am J Clin Nutr. 1995;62:426-433. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7625352].
Husband D.J, Alberti K.G. M. M, Julian D.G. 'Stress' hyperglycaemia during acute myocardial infarction: An indicator of pre-existing diabetes. Lancet. 1983;2:179-181. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6135025].
Hwu C.-M, Kwok C.-F, Kuo B.I, Lin Y.-T, Lee Y.-S, Hsiao L.-C, Lee S.-H, Ho L.-T. Undiagnosed glucose intolerance encountered in clinical practice: Reappraisal of the use of the oral glucose tolerance test. Chinese Medical Journal (Taipei). 2001;64:435-442. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11720141].
Hyltoft, Petersen P, Brandslund I, Jorgensen L, Stahl M, de Fine, Olivarius N, Borch-Johnsen K. Evaluation of systematic and random factors in measurements of fasting plasma glucose as the basis for analytical quality specifications in the diagnosis of diabetes. 3. Impact of the new WHO and ADA recommendations on diagnosis of diabetes mellitus. Scand J Clin Lab Invest. 2001;61:191-204. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11386606].
Hyun, Ko S, Song K.-H, Ahn Y.-B, Yoo S.-J, Son H.-S, Yoon K.-H, Cha B.-Y, Lee K.-W, Son H.-Y, Kang S.-K. The effect of rosiglitazone on serum lipoprotein(a) levels in Korean patients with type 2 diabetes mellitus. Metabolism. 2003;52:731-734. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12800099].
Ilercil A, Devereux R.B, Roman M.J, Paranicas M, O'grady M.J, Welty T.K, Robbins D.C, Fabsitz R.R, Howard B.V, Lee E.T. Relationship of impaired glucose tolerance to left ventricular structure and function: The Strong Heart Study. Am Heart J. 2001;141:992-998. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11376315].
Inoue I, Takahashi K, Katayama S, Akabane S, Negishi K, Suzuki M, Ishii J, Kawazu S. Improvement of glucose tolerance by bezafibrate in non-obese patients with hyperlipidemia and impaired glucose tolerance. Diabetes Res Clin Pract. 1994;25:199-205. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7851275].
Invitti C, Guzzaloni G, Gilardini L, Morabito F, Viberti G. Prevalence and concomitants of glucose intolerance in European obese children and adolescents. Diabetes Care. 2003;26:118-124. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12502667].
Ioka T, Tasaki H, Yashiro A, Yamashita K, Ozumi K, Tsutsui M, Kouzuma R, Okazaki M, Nakashima Y. Association between plasma lipoprotein(a) and endothelial dysfunction in normocholesterolemic and non-diabetic patients with angiographically normal coronary arteries. Circ J. 2002;66:267-271. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11922276].
Islam A.H, Yamashita S, Kotani K, Nakamura T, Tokunaga K, Arai T, Nishida M, Kameda-Takemura K, Matsuzawa Y. Fasting plasma insulin level is an important risk factor for the development of complications in Japanese obese children--results from a cross-sectional and a longitudinal study. Metabolism. 1995;44:478-485. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7723670].
Istfan N.W, Plaisted C.S, Bistrian B.R, Blackburn G.L. Insulin resistance versus insulin secretion in the hypertension of obesity. Hypertension. 1992;19:385-392. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1555870].
Ito C, Maeda R, Nakamura K, Sasaki H. Prediction of diabetes mellitus (NIDDM). Diabetes Res Clin Pract. 1996;34 Suppl:S7-11. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9015664].
Iwaoka T, Umeda T, Inoue J, Naomi S, Sasaki M, Fujimoto Y, Gui C, Ideguchi Y, Sato T. Dietary NaCl restriction deteriorates oral glucose tolerance in hypertensive patients with impairment of glucose tolerance. Am J Hypertens. 1994;7:460-463. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8060581].
Iyer S.R, Iyer R.R, Upasani S.V, Baitule M.N. Diabetes mellitus in Dombivli--an urban population study. J Assoc Physicians India. 2001;49:713-716. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11573556].
Jaap A.J, Shore A.C, Stockman A.J, Tooke J.E. Skin capillary density in subjects with impaired glucose tolerance and patients with type 2 diabetes. Diabet Med. 1996;13:160-164. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8641122].
Jaap A.J, Shore A.C, Tooke J.E. Relationship of insulin resistance to microvascular dysfunction in subjects with fasting hyperglycaemia. Diabetologia. 1997;40:238-243. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9049487].
Jackson K.G, Taylor G.R. J, Clohessy A.M, Williams C.M. The effect of the daily intake of inulin on fasting lipid, insulin and glucose concentrations in middle-aged men and women. Br J Nutr. 1999;82:23-30. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10655953].
Jaffrain-Rea M.L, Moroni C, Baldelli R, Battista C, Maffei P, Terzolo M, Correra M, Ghiggi M.R, Ferretti E, Angeli A, Sicolo N, Trischitta V, Liuzzi A, Cassone R, Tamburrano G. Relationship between blood pressure and glucose tolerance in acromegaly. Clin Endocrinol (Oxf). 2001;54:189-195. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11207633].
Jallut D, Golay A, Munger R, Frascarolo P, Schutz Y, Jequier E, Felber J.P. Impaired glucose tolerance and diabetes in obesity: a 6-year follow-up study of glucose metabolism. Metabolism. 1990;39:1068-1075. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2215253].
Jarrett R.J, McCartney P, Keen H. The Bedford survey: Ten year mortality rates in newly diagnosed diabetics, borderline diabetics and normoglycaemic controls and risk indices for coronary heart disease in borderline diabetics. Diabetologia. 1982;22:79-84. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7060853].
Jarrett R.J, Keen H, McCartney P. The Whitehall study: Ten year follow-up report on men with impaired glucose tolerance with reference to worsening to diabetes and predictors of death. DIABETIC MED. 1984;1:279-283. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6242817].
Jarrett R.J, Keen H, Murrells T. Changes in blood pressure and body weight over ten years in men selected for glucose intolerance. [erratum appears in J Epidemiol Community Health 1987 Sep;41(3):242.]. Journal of Epidemiology& Community Health. 1987;41:145-151. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 3655634]. [pmcid: 1052600].
Jawad F, Shera A.S, Memon R, Ansari G. Glucose intolerance in pulmonary tuberculosis. JPMA J Pak Med Assoc. 1995;45:237-238. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8683828].
Jenkins D.J, Wolever T.M, Taylor R.H, Griffiths C, Krzeminska K, Lawrie J.A, Bennett C.M, Goff D.V, Sarson D.L, Bloom S.R. Slow release dietary carbohydrate improves second meal tolerance. Am J Clin Nutr. 1982;35:1339-1346. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6282105].
Jensen P, Johansen H.K, Carmi P, Hoiby N, Cohen I.R. Autoantibodies to pancreatic hsp60 precede the development of glucose intolerance in patients with cystic fibrosis. J Autoimmun. 2001;17:165-172. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11591125].
Jeon J.Y, Weiss C.B, Steadward R.D, Ryan E, Burnham R.S, Bell G, Chilibeck P, Wheeler G.D. Improved glucose tolerance and insulin sensitivity after electrical stimulation-assisted cycling in people with spinal cord injury. Spinal Cord. 2002;40:110-117. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11859437].
Jiao S, Kameda K, Matsuzawa Y, Kubo M, Nonaka K, Tarui S. Influence of endogenous hyperinsulinism on high density lipoprotein2 level in type 2 (non-insulin-dependent) diabetes mellitus and impaired glucose tolerance. Atherosclerosis. 1986;60:279-286. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 3730047].
Johnson K.C, Graney M.J, Applegate W.B, Kitabchi A.E, Runyan J.W, Rutan G.H. Does syndrome X exist in hypertensive elderly persons with impaired glycemic control. Journals of Gerontology Series A-Biological Sciences& Medical Sciences. 1999;54A:M571-M576. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design.
Kadowaki T, Miyake Y, Hagura R, Kajinuma H, Kuzuya N, Akanuma Y, Kosaka K. On the pathogenesis of type II diabetes with special reference to diminished insulin response and obesity: a 5–12 year follow-up study of subjects with borderline glucose tolerance. Tohoku J Exp Med. 1983;141 Suppl:141-146. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6393431].
Kadowaki T, Miyake Y, Hagura R. Risk factors for worsening to diabetes in subjects with impaired glucose tolerance. Diabetologia. 1984;26:44-49. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6368299].
Kadowaki T, Yoshinaga H. Risk factors for the development of non-insulin-dependent diabetes mellitus (NIDDM) in Japan. Diabetes Res Clin Pract. 1994;24 Suppl:S123-S127. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7859593].
Kalmijn S, Feskens E.J, Launer L.J, Stijnen T, Kromhout D. Glucose intolerance, hyperinsulinaemia and cognitive function in a general population of elderly men. Diabetologia. 1995;38:1096-1102. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8591825].
Kaltiala K.S, Haavisto M.V, Heikinheimo R.J. Blood glucose and diabetes mellitus predicting mortality in persons aged 85 years or above. Age& Ageing. 1987;16:165-170. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3604798].
Kan H, Fujimoto S, Matsuda I. Erythrocyte insulin receptor and glucose tolerance test in children treated with prednisolone. Endocrinol Jpn. 1985;32:347-353. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3899618].
Kanatsuka A, Makino H, Sakurada M, Hashimoto N, Iwaoka H, Yamaguchi T, Taira M, Yoshida S, Yoshida A. First-phase insulin response to glucose in nonobese or obese subjects with glucose intolerance: Analysis by C-peptide secretion rate. Metabolism. 1988;37:878-884. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3047522].
Kaneshige H, Endoh M, Tomino Y. Abnormal glucose tolerance in patients with chronic glomerulonephritis without renal failure. Diabetes Care. 1983;6:381-386. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6352211].
Kanigur-Sultuybek G, Hatemi H, Guven M, Ulutin T, Tezcan V, Ulutin O.N. The effect of metformin and gliclazide on platelets and red blood cell glucose transport mechanisms in impaired glucose tolerance and type II diabetic patients with vasculopathy. Thrombotic& Haemorrhagic Disorders. 1993;7:17-21. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Kankova K, Jansen E.H, Marova I, Stejskalova A, Pacal L, Muzik J, Vacha J. Relations among serum ferritin, C282Y and H63D mutations in the HFE gene and type 2 diabetes mellitus in the Czech population. Experimental& Clinical Endocrinology& Diabetes. 2002;110:223-229. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12148086].
Kannel W.B, McGee D.L. Update on some epidemiologic features of intermittent claudication: The Framingham study. J Am Geriatr Soc. 1985;33:13-18. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3965550].
Kannel W.B. Metabolic risk factors for coronary heart disease in women: perspective from the Framingham Study. Am Heart J. 1987;114:413-419. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3604900].
Kaplan L.A, Cline D, Gartside P, Burstein S, Sperling M, Stein E.A. Hemoglobin A1 in hemolysates from healthy and insulin-dependent diabetic children, as determined with a temperature-controlled minicolumn assay. Clin Chem. 1982;28:13-18. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7034998].
Karadeniz S, KirYilmaz M.T, Ongor E, Dinccag N, Basar D, Akarcay K, Satman I, Devrim A.S. Alteration of visual function in impaired glucose tolerance. Eur J Ophthalmol. 1996;6:59-62. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8744852].
Karvestedt L, Andersson G, Efendic S, Grill V. A rapid increase in beta-cell function by multiple insulin injections in type 2 diabetic patients is not further enhanced by prolonging treatment. J Intern Med. 2002;251:307-316. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11952881].
Kasayama S, Otsuki M, Takagi M, Saito H, Sumitani S, Kouhara H, Koga M, Saitoh Y, Ohnishi T, Arita N. Impaired beta-cell function in the presence of reduced insulin sensitivity determines glucose tolerance status in acromegalic patients. Clin Endocrinol (Oxf). 2000;52:549-555. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10792333].
Kashiwabara H, Inaba M, Maruno Y, Morita T, Awata T, Negishi K, Iitaka M, Katayama S. Insulin levels during fasting and the glucose tolerance test and Homa' index predict subsequent development of hypertension. J Hypertens. 2000;18:83-88. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10678547].
Kasperska-Czyzykowa T, Jaskolska K, Galecki A, Trzaski M, Woy-Wojciechowski J. Effect of biguanide derivatives (phenformin) on carbohydrate tolerance in “borderline” and asymptomatic ("chemical") diabetes. Results of a 5-year prospective study. Acta Med Pol. 1986;27:141-152. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3445789].
Katsumori K, Wasada T, Kuroki H, Arii H, Saeki A, Aoki K, Saito S, Omori Y. Prevalence of macro- and microvascular diseases in non-insulin-dependent diabetic and borderline glucose-intolerant subjects with insulin resistance syndrome. Diabetes Res Clin Pract. 1995;29:195-201. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8591713].
Katzman P.L, Hulthen U.L, Hokfelt B. Glucoregulatory hormone response to insulin-induced hypoglycaemia following long-term calcium antagonism with felodipine in patients with essential hypertension. Acta Endocrinol (Copenh). 1987;116:473-478. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3321819].
Kauffman R.P, Baker V.M, DiMarino P, Gimpel T, Castracane V.D. Polycystic ovarian syndrome and insulin resistance in white and Mexican American women: A comparison of two distinct populations. Am J Obstet Gynecol. 2002;187:1362-1369. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12439532].
Kechrid Z, Kenouz R. Determination of Alkaline Phosphatase Activity in Patients with Different Zinc Metabolic Disorders. Turkish Journal of Medical Sciences. 2003;33:387-391. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Keen H, Jarrett R.J, McCartney P. The ten-year follow-up of the Bedford survey (1962-1972): glucose tolerance and diabetes. Diabetologia. 1982;22:73-78. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7060852].
Kekalainen P, Sarlund H, Pyorala K, Laakso M. Hyperinsulinemia cluster predicts the development of type 2 diabetes independently of family history of diabetes. Diabetes Care. 1999;22:86-92. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10333908].
Kenkre P.V, Lindeman R.D, Lillian, Yau C, Baumgartner R.N, Garry P.J. Serum insulin concentrations in daily drinkers compared with abstainers in the New Mexico elder health survey. Journals of Gerontology Series A-Biological Sciences& Medical Sciences. 2003;58:M960-M963. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design.
Kentala E, Repo U.K. Glucose tolerance and sudden death after myocardial infarction. Ann Clin Res. 1982;14:57-60. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7137878].
Kentrup H, Bongers H, Spengler M, Kusenbach G, Skopnik H. Efficacy and safety of acarbose in patients with cystic fibrosis and impaired glucose tolerance. Eur J Pediatr. 1999;158:455-459. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10378391].
Kida T, Harino S, Sugiyama T, Kitanishi K, Iwahashi Y, Ikeda T. Change in retinal arterial blood flow in the contralateral eye of retinal vein occlusion during glucose tolerance test. Graefes Archive for Clinical& Experimental Ophthalmology. 2002;240:342-347. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Kim D.-J, Lee M.-S, Kim K.-W, Lee M.-K. Insulin secretory dysfunction and insulin resistance in the pathogenesis of Korean type 2 diabetes mellitus. Metabolism. 2001;50:590-593. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11319722].
Kindmark H, Kohler M, Arkhammar P, Efendic S, Larsson O, Linder S, Nilsson T, Berggren P.-O. Oscillations in cytoplasmic free calcium concentration in human pancreatic islets from subjects with normal and impaired glucose tolerance. Diabetologia. 1994;37:1121-1131. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7867884].
Klein-Weigel P, Krall K, Falkensammer J, Heinz-Erian P, Ulmer H, Fraedrich G. Lack of seasonal variation in flow-mediated dilatation of the brachial artery in women with primary Raynaud' phenomenon and healthy controls. Vasa. 2003;32:69-73. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12945098].
Knobler H, Schattner A, Zhornicki T, Malnick S.D, Keter D, Sokolovskaya N, Lurie Y, Bass D.D. Fatty liver--an additional and treatable feature of the insulin resistance syndrome. QJM. 1999;92:73-79. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10209658].
Knowler W.C, Pettitt D.J, Saad M.F, Bennett P.H. Diabetes mellitus in the Pima Indians: incidence, risk factors and pathogenesis. Diabetes Metab Rev. 1990;6:1-27. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 2192853].
Knowler W.C, Saad M.F, Pettitt D.J, Nelson R.G, Bennett P.H. Determinants of diabetes mellitus in the Pima Indians. Diabetes Care. 1993;16:216-227. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8422779].
Knowler W.C, Narayan K.M. V, Hanson R.L, Nelson R.G, Bennett P.H, Tuomilehto J, Schersten B, Pettitt D.J. Preventing non-insulin-dependent diabetes. Diabetes. 1995;44:483-488. Status: Not included because article does not describe a study or survey. [pmid: 7729603].
Knowler W.C, Sartor G, Melander A, Schersten B. Glucose tolerance and mortality, including a substudy of tolbutamide treatment. Diabetologia. 1997;40:680-686. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9222648].
Knuuti J, Takala T.O, Nagren K, Sipila H, Turpeinen A.K, Uusitupa M.I, Nuutila P. Myocardial fatty acid oxidation in patients with impaired glucose tolerance. Diabetologia. 2001;44:184-187. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11270674].
Ko G.T, Chan J.C, Cockram C.S. Use of a paired value of fasting plasma glucose and glycated hemoglobin in predicting the likelihood of diabetes in a community. Diabetes Care. 1999;22:1908-1909. Status: Not included because article is not a fulltext publication. [pmid: 10546031].
Ko G.T, Chan J.C, Yeung V.T, Chow C.C, Tsang L.W, Cockram C.S. A low socio-economic status is an additional risk factor for glucose intolerance in high risk Hong Kong Chinese. Eur J Epidemiol. 2001;17:289-295. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11680550].
Ko G.T. C, Chan J.C. N, Lau E, Woo J, Cockram C.S. Fasting plasma glucose as a screening test for diabetes and its relationship with cardiovascular risk factors in Hong Kong Chinese. Diabetes Care. 1997;20:170-172. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9118766].
Ko G.T. C, Chan W.-B, Chan J.C. N, Tsang L.W. W, Cockram C.S. Gastrointestinal symptoms in Chinese patients with type 2 diabetes mellitus. Diabet Med. 1999;16:670-674. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10477212].
Ko G.T. C, Chan J.C. N, Tsang L.W. W, Yeung V.T. F, Chow C.C, Cockram C.S. Outcomes of screening for diabetes in high-risk Hong Kong Chinese subjects. Diabetes Care. 2000;23:1290-1294. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10977020].
Koebberling J, Berninger D. Natural history of glucose tolerance in relatives of diabetic patients: Low prognostic value of the oral glucose tolerance test. Diabetes Care. 1980;3:21-26. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7408614].
Koh E.T, Ard N.F, Mendoza F. Effects of fructose feeding on blood parameters and blood pressure in impaired glucose-tolerant subjects. Journal of the American Dietetic Association. 1988;88:932-938. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3294273].
Kohner E.M, Dollery C.T, Lowy C, Schumer B. Effect of diuretic therapy on glucose tolerance in hypertensive patients. Lancet. 1971;1:986-990. Status: Not included because article was published before 1979. [pmid: 4102452].
Konukoglu D, Celik C, Akcay T, Ozmen M. The effects of lithium treatment on blood glucose, glycosylated haemoglobin and serum citrate levels. Medical Science Research. 1996;24:525-526. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Koop B.L, Harris A.G, Ezzat S. Effect of octreotide on glucose tolerance in acromegaly. European Journal of Endocrinology. 1994;130:581-586. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 8205258].
Kopp C.W, Kopp H.P, Steiner S, Kriwanek S, Krzyzanowska K, Bartok A, Roka R, Minar E, Schernthaner G. Weight loss reduces tissue factor in morbidly obese patients. Obes Res. 2003;11:950-956. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 12917499].
Kopp H.P, Kopp C.W, Festa A, Krzyzanowska K, Kriwanek S, Minar E, Roka R, Schernthaner G. Impact of weight loss on inflammatory proteins and their association with the insulin resistance syndrome in morbidly obese patients. Arteriosclerosis Thrombosis& Vascular Biology. 2003;23:1042-1047. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review.
Koppel K, Bratt G, Schulman S, Bylund H, Sandstrom E. Hypofibrinolytic state in HIV-1-infected patients treated with protease inhibitor-containing highly active antiretroviral therapy. J Acquir Immune Defic Syndr. 2002;29:441-449. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11981359].
Kosaka K, Kuzuya T, Hagura R, Yoshinaga H. Insulin response to oral glucose load is consistently decreased in established non-insulin-dependent diabetes mellitus: the usefulness of decreased early insulin response as a predictor of non-insulin-dependent diabetes mellitus. Diabet Med. 1996;13:S109-S119. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8894494].
Kosaka K, Kuzuya T, Yoshinaga H, Hagura R. A prospective study of health check examinees for the development of non-insulin-dependent diabetes mellitus: relationship of the incidence of diabetes with the initial insulinogenic index and degree of obesity. Diabet Med. 1996;13:S120-S126. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8894495].
Kothari K, Mathur A, Yadav S. Estimation of fasting and post oral glucose serum insulin levels in hypertensive and obese subjects. J Assoc Physicians India. 1998;46:514-517. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11273248].
Kovacs E.M. R, Westerterp-Plantenga M.S, Saris W.H. M, Melanson K.J, Goossens I, Geurten P, Brouns F. Associations between spontaneous meal initiations and blood glucose dynamics in overweight men in negative energy balance. Br J Nutr. 2002;87:39-45. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11898769].
Kowalska I, Straczkowski M, Szelachowska M, Kinalska I, Prokop J, Bachorzewska-Gajewska H, Stepien A. Circulating E-selectin, vascular cell adhesion molecule-1, and intercellular adhesion molecule-1 in men with coronary artery disease assessed by angiography and disturbances of carbohydrate metabolism. Metabolism. 2002;51:733-736. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12037726].
Krakoff J, Hanson R.L, Kobes S, Knowler W.C. Comparison of the effect of plasma glucose concentrations on microvascular disease between Pima Indian youths and adults. Diabetes Care. 2001;24:1023-1028. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11375364].
Kral J.G, Sjostrom L, Gustafson A. Effects of jejuno-ileal bypass on serum lipoproteins and glucose tolerance in severely obese patients. Eur J Clin Invest. 1980;10:363-367. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6777169].
Krempf M, Louvet J.-P, Allanic H, Miloradovich T, Joubert J.-M, Attali J.-R. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes. 2003;27:591-597. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Krentz A.J, Williams A.C, Nattrass M. Abnormal regulation of carbohydrate metabolism in motor neurone disease. Diabetes Research. 1991;16:93-99. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1817811].
Kristiansson K, Sigfusson N, Sigvaldason H, Thorgeirsson G. Glucose tolerance and blood pressure in a population-based cohort study of males and females: the Reykjavik Study. J Hypertens. 1995;13:581-586. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7594413].
Kristof R.A, Neuloh G, Redel L, Klingmuller D, Schramm J. Reliability of the oral glucose tolerance test in the early postoperative assessment of acromegaly remission. J Neurosurg. 2002;97:1282-1286. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12507124].
Kroke A, Liese A.D, Keil U, Boeing H. Arterial hypertension and glycemia in non-diabetic subjects: is there an association independent of obesity. Diabetes Metab Res Rev. 1999;15:99-105. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10362457].
Kubaszek A, Pihlajamaki J, Komarovski V, Lindi V, Lindstrom J, Eriksson J, Valle T.T, Hamalainen H, Ilanne-Parikka P, Keinanen-Kiukaanniemi S, Tuomilehto J, Uusitupa M, Laakso M. Finnish Diabetes, Prevention Study. Promoter polymorphisms of the TNF-alpha (G-308A) and IL-6 (C-174G) genes predict the conversion from impaired glucose tolerance to type 2 diabetes: the Finnish Diabetes Prevention Study. Diabetes. 2003;52:1872-1876. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12829659].
Kuhl C, Vandsted M, Olsen P.G. Minor physiological relevance of oral glucose tolerance test. Diabete Metab. 1982;8:203-207. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6754492].
Kulkarni M, Jones K.D, Newbold S. Screening for gestational diabetes: A retrospective audit. Journal of Obstetrics& Gynaecology. 2003;23:160-162. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12745560].
Kumar S, Olukoga A.O, Gordoni C, Mawer E.B, France M, Hosker J.P, Davies M, Boulton A.J. M. Impaired glucose tolerance and insulin insensitivity in primary hyperparathyroidism. Clin Endocrinol (Oxf). 1994;40:47-53. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8306480].
Kutnowski M, Daubresse J.C, Friedman H, Kolanowski J, Krzentowski G, Scheen A, Van Gaal L. Fluoxetine therapy in obese diabetic and glucose intolerant patients. Int J Obes Relat Metab Disord. 1992;16 Suppl 4:S63-S66. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1338388].
Kuusisto J, Koivisto K, Mykkanen L, Helkala E.-L, Vanhanen M, Hanninen T, Kervinen K, Kesaniemi Y.A, Riekkinen P.J, Laakso M. Association between features of the insulin resistance syndrome and Alzheimer' disease independently of apolipoprotein E4 phenotype: Cross sectional population based study. British Medical Journal. 1997;315:1045-1049. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9366728]. [pmcid: 2127678].
Laakso M, Sarlund H, Mykkanen L. Insulin resistance is associated with lipid and lipoprotein abnormalities in subjects with varying degrees of glucose tolerance. Arteriosclerosis. 1990;10:223-231. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2180396].
Laakso M, Malkki M, Kekalainen P, Kuusisto J, Mykkanen L, Deeb S.S. Glucokinase gene variants in subjects with late-onset NIDDM and impaired glucose tolerance. Diabetes Care. 1995;18:398-400. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7555485].
Laaksonen D.E, Lakka T.A, Lakka H.M, Nyyssonen K, Rissanen T, Niskanen L.K, Salonen J.T. Serum fatty acid composition predicts development of impaired fasting glycaemia and diabetes in middle-aged men. Diabet Med. 2002;19:456-464. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12060056].
Lakusic N, Mahovic D, Cerovec D, Majsec M. Do patients with coronary heart disease older than seventy benefit from cardiac rehabilitation. Acta Clinica Croatica. 2002;41:69-72. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Landin K, Lindgarde F, Saltin B. Skeletal muscle potassium increases after diet weight reduction in obese subjects with normal and impaired glucose tolerance. Acta Endocrinol (Copenh). 1989;121:21-26. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2741639].
Langer O. Prevention of macrosomia. Baillieres Clinical Obstetrics& Gynaecology. 1991;5:333-347. Status: Not included because article does not describe a study or survey.
Lanng S, Hansen A, Thorsteinsson B, Nerup J, Koch C. Glucose tolerance in patients with cystic fibrosis: five year prospective study. BMJ. 1995;311:655-659. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7549632]. [pmcid: 2551427].
Lao T, Lai, Fong Ho, Bancroft K, Gartside M.W, Hopkins R.E, Chia K.V, Tasker M, Tomlinson A.J. A randomised controlled pilot study of the management of gestational impaired glucose tolerance [1] (multiple letters). Br J Obstet Gynaecol. 2001;108:769. Status: Not included because article is not a fulltext publication.
Lao T.T, Lee C.P, Wong W.M. Placental weight to birthweight ratio is increased in mild gestational glucose intolerance. Placenta. 1997;18:227-230. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9089786].
Lao T.T, Ho L.F. Impaired glucose tolerance and pregnancy outcome in Chinese women with high body mass index. Hum Reprod. 2000;15:1826-1829. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10920111].
Lao T.T, Ho L.F. Perinatal morbidity and placental size in gestational impaired glucose tolerance. J Soc Gynecol Investig. 2001;8:347-350. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Lapidus L, Bengtsson C, Blohme G, Lindquist O, Nystrom E. Blood glucose, glucose tolerance and manifest diabetes in relation to cardiovascular disease and death in women. A 12-year follow-up of participants in the population study of women in Gothenburg, Sweden. Acta Medica Scandinavica. 1985;218:455-462. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4091045].
Larsen M.L. The utility of glycated hemoglobin in identification of impaired glucose tolerance. Diabetes Research. 1989;12:67-70. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2634508].
Larsson H, Ahren B, Lindgarde F, Berglund G. Fasting blood glucose in determining the prevalence of diabetes in a large, homogeneous population of Caucasian middle-aged women. J Intern Med. 1995;237:537-541. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7782724].
Larsson H, Berglund G, Ahren B. Glucose modulation of insulin and glucagon secretion is altered in impaired glucose tolerance. J Clin Endocrinol Metab. 1995;80:1778-1782. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7775622].
Larsson H, Ahren B. Failure to adequately adapt reduced insulin sensitivity with increased insulin secretion in women with impaired glucose tolerance. Diabetologia. 1996;39:1099-1107. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8877295].
Larsson H, Ahren B. Relative hyperproinsulinemia as a sign of islet dysfunction in women with impaired glucose tolerance. J Clin Endocrinol Metab. 1999;84:2068-2074. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10372712].
Larsson H, Elmstahl S, Berglund G, Ahren B. Habitual dietary intake versus glucose tolerance, insulin sensitivity and insulin secretion in postmenopausal women. J Intern Med. 1999;245:581-591. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10395187].
Larsson H, Daugaard J.R, Kiens B, Richter E.A, Ahren B. Muscle fiber characteristics in postmenopausal women with normal or impaired glucose tolerance. Diabetes Care. 1999;22:1330-1338. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10480779].
Larsson H, Ahren B. Glucose intolerance is predicted by low insulin secretion and high glucagon secretion: outcome of a prospective study in postmenopausal Caucasian women. Diabetologia. 2000;43:194-202. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10753041].
Laskarzewski P, Kelly K.A, Mellies M.J, Morrison J.A, Khoury P, Tillett S, Glueck C.J. Interrelationships of lipids, lipoproteins, and clinical chemistry measurements in 1605 schoolchildren, ages 6–17: the Princeton Schoolchildren Study. Metabolism. 1980;29:916-923. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7421581].
Laube H, Linn T, Heyen P. The effect of acarbose on insulin sensitivity and proinsulin in overweight subjects with impaired glucose tolerance. Experimental& Clinical Endocrinology& Diabetes. 1998;106:231-233. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 9710365].
Law C.M, Gordon G.S, Shiell A.W, Barker D.J, Hales C.N. Thinness at birth and glucose tolerance in seven-year-old children. Diabet Med. 1995;12:24-29. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7712699].
Laws A, Marcus E.B, Grove J.S, Curb J.D. Lipids and lipoproteins as risk factors for coronary heart disease in men with abnormal glucose tolerance: the Honolulu Heart Program. J Intern Med. 1993;234:471-478. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8228791].
Lecomte P, Vol S, Caces E, Lasfargues G, Combe H, Laurent S, Tichet J. Impaired fasting glycaemia and undiagnosed diabetes: prevalence, cardiovascular and behavioural risk factors. Diabetes Metab. 2002;28:311-320. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12442069].
Lecomte P, Vol S, Caces E, Lasfargues G, Combe H, Laurent S, Tichet J. Impaired fasting glycaemia and undiagnosed diabetes: Prevalence, cardiovascular and behavioural risk factors. Evidence supporting an early preventive strategy. Diabetes Metab. 2002;28:311-320. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12442069].
Leden I, Schersten B, Svensson B. Glucose metabolism in patients with rheumatoid arthritis. Scandinavian Journal of Rheumatology. 1984;13:129-132. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6740267].
Lee A.J, MacGregor A.S, Hau C.M, Price J.F, Rumley A, Lowe G.D, Fowkes F.G. The role of haematological factors in diabetic peripheral arterial disease: the Edinburgh artery study. Br J Haematol. 1999;105:648-654. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10354125].
Legido A, Sarria A, Bueno M. Relationships of body fat distribution to metabolic complications in obese prepubertal girls. Clin Pediatr (Phila). 1987;26:310-315. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3555941].
Legro R.S, Kunselman A.R, Dodson W.C, Dunaif A. Prevalence and predictors of risk for type 2 diabetes mellitus and impaired glucose tolerance in polycystic ovary syndrome: a prospective, controlled study in 254 affected women.[see comment]. J Clin Endocrinol Metab. 1999;84:165-169. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9920077].
Lehrer J.F, Poole D.C, Seaman M. Identification and treatment of metabolic abnormalities in patients with vertigo. Arch Intern Med. 1986;146:1497-1500. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3524492].
Lemne C, Efendic S, Hamsten A, de Faire U. Impaired glucose and insulin metabolism in borderline hypertension. Blood Pressure. 1994;3:287-294. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 7866592].
Leonard D, McDermott R, O'Dea K, Rowley K.G, Pensio P, Sambo E, Twist A, Toolis R, Lowson S, Best J.D. Obesity, diabetes and associated cardiovascular risk factors among Torres Strait Islander people. Australian & New Zealand Journal of Public Health. 2002;26:144-149. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12054333].
Leonetti F, Silecchia G, Iacobellis G, Ribaudo M.C, Zappaterreno A, Tiberti C, Iannucci C.V, Perrotta N, Bacci V, Basso M.S, Basso N, Di Mario U. Different plasma ghrelin levels after laparoscopic gastric bypass and adjustable gastric banding in morbid obese subjects. J Clin Endocrinol Metab. 2003;88:4227-4231. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12970291].
Leslie R.D. G, Volkmann H.P, Poncher M. Metabolic abnormalities in children of non-insulin dependent diabetics. British Medical Journal. 1986;293:840-842. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3094681]. [pmcid: 1341633].
Leung T.W, Lao T.T. Placental size and large-for-gestational-age infants in women with abnormal glucose tolerance in pregnancy. Diabet Med. 2000;17:48-52. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10691159].
Lev-Ran A. Glycohemoglobin. Its use in the follow-up of diabetes and diagnosis of glucose intolerance. Arch Intern Med. 1981;141:747-749. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7235783].
Levine W, Dyer A.R, Shekelle R.B, Schoenberger J.A, Stamler J. Post-load plasma glucose and cancer mortality in middle-aged men and women. 12-year follow-up findings of the Chicago Heart Association Detection Project in Industry. Am J Epidemiol. 1990;131:254-262. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2296978].
Levitt N.S, Lambert E.V, Woods D, Hales C.N, Andrew R, Seckl J.R. Impaired glucose tolerance and elevated blood pressure in low birth weight, nonobese, young south african adults: early programming of cortisol axis. J Clin Endocrinol Metab. 2000;85:4611-4618. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11134116].
Leyva F, Godsland I.F, Worthington M, Walton C, Stevenson J.C. Factors of the metabolic syndrome: Baseline interrelationships in the first follow-up cohort of the HDDRISC study (HDDRISC-1). Arteriosclerosis Thrombosis& Vascular Biology. 1998;18:208-214. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Leyva F, Rauchhaus M, Anker S.D, Proudler A.J, Godsland I.F, Stiefel P, Coats A.J. S, Poole-Wilson P.A, Stevenson J.C. Non-invasive assessment of vascular function. Paradoxical vascular response to intravenous glucose in coronary heart disease. Eur Heart J. 2000;21:39-44. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10610742].
Li Y, Higashiura K, Ura N, Tor T II, Agata J, Wang L, Togashi N, Shimamoto K. Effects of the Chinese medicine TSJN on insulin resistance and hypertension in fructose-fed rats. Hypertension Research. 2000;23:101-107. Status: Excluded because no subjects diagnosed by included crtieria were analyzed. [pmid: 10770256].
Liang P, Hughes V, Fukagawa N.K. Increased prevalence of mitochondrial DNA deletions in skeletal muscle of older individuals with impaired glucose tolerance: possible marker of glycemic stress.[erratum appears in Diabetes 1997 Sep;46(9):1532]. Diabetes. 1997;46:920-923. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9133566].
Liguori A, Abete P, Hayden J.M, Cacciatore F, Rengo F, Ambrosio G, Bonaduce D, Condorelli M, Reaven P.D, Napoli C. Effect of glycaemic control and age on low-density lipoprotein susceptibility to oxidation in diabetes mellitus type 1. Eur Heart J. 2001;22:2075-2084. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11686665].
Lillioja S, Mott D.M, Howard B.V, Bennett P.H, Yki-Jarvinen H, Freymond D, Nyomba B.L, Zurlo F, Swinburn B, Bogardus C. Impaired glucose tolerance as a disorder of insulin action. Longitudinal and cross-sectional studies in Pima Indians. N Engl J Med. 1988;318:1217-1225. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3283552].
Lind L, Lithell H, Skarfors E, Wide L, Ljunghall S. Reduction of blood pressure by treatment with alphacalcidol. A double-blind, placebo-controlled study in subjects with impaired glucose tolerance. Acta Medica Scandinavica. 1988;223:211-217. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3281411].
Lind L, Lithell H, Wengle B, Wrege U, Ljunghall S. A pilot study of metabolic effects of intravenously given alpha-calcidol in patients with chronic renal failure. Scandinavian Journal of Urology& Nephrology. 1988;22:219-222. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3187441].
Lind L, Pollare T, Hvarfner A, Lithell H, Sorensen O.H, Ljunghall S. Long-term treatment with active vitamin D (alphacalcidol) in middle-aged men with impaired glucose tolerance. Effects on insulin secretion and sensitivity, glucose tolerance and blood pressure. Diabetes Research. 1989;11:141-147. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 2697485].
Lind L, Lithell H, Pollare P, Ljunghall S. On the diversity of insulin secretion and sensitivity in subjects with impaired glucose tolerance. Exp Clin Endocrinol. 1993;101:311-314. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8299708].
Lind L, Lithell H. Impaired glucose and lipid metabolism seen in intensive care patients is related to severity of illness and survival. Clin Intensive Care. 1994;5:100-105. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10150538].
Lind L, Sarabi M, Millgard J, Kahan T. Endothelium-dependent vasodilation is impaired in apparently healthy subjects with a family history of myocardial infarction. J Cardiovasc Risk. 2002;9:53-57. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11984218].
Lindahl B, Nilsson T.K, Jansson J.H, Asplund K, Hallmans G. Improved fibrinolysis by intense lifestyle intervention. A randomized trial in subjects with impaired glucose tolerance. J Intern Med. 1999;246:105-112. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10447232].
Linday L.A. Trivalent chromium and the diabetes prevention program. [Review] [20 refs]. Med Hypotheses. 1997;49:47-49. Status: Not included because article does not describe a study or survey. [pmid: 9247907].
Lindblad U, Lindwall K, Sjostrand A, Ranstam J, Melander A. The NEPI Antidiabetes Sstudy (NANSY). The NEPI antidiabetes study (NANSY). 1: short-term dose-effect relations of glimepiride in subjects with impaired fasting glucose. Diabetes Obes Metab. 2001;3:443-451. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11903417].
Lindeman R.D, Romero L.J, LaRue A, Yau C.L, Schade D.S, Koehler K.M, Baumgartner R.N, Garry P.J. New Mexico Elder Health Survey. A biethnic community survey of cognition in participants with type 2 diabetes, impaired glucose tolerance, and normal glucose tolerance: the New Mexico Elder Health Survey. Diabetes Care. 2001;24:1567-1572. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11522700].
Lindeman R.D, Yau C.L, Baumgartner R.N, Morley J.E, Garry P.J. New Mexico Aging Process Study. Longitudinal study of fasting serum glucose concentrations in healthy elderly. The New Mexico Aging Process Study. J Nutr Health Aging. 2003;7:172-177. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12766795].
Lindquist C.H, Gower B.A, Goran M.I. Role of dietary factors in ethnic differences in early risk of cardiovascular disease and type 2 diabetes... including commentary by Kasim-Karakas SE. Am J Clin Nutr. 2000;71:725-732. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10702165].
Lindsay R.S, Walker J.D, Halsall I, Hales C.N, Calder A.A, Hamilton B.A, Johnstone F.D. Insulin and insulin propeptides at birth in offspring of diabetic mothers. J Clin Endocrinol Metab. 2003;88:1664-1671. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12679454].
Ljunghall S, Lind L, Lithell H, Skarfors E, Selinus I, Sorensen O.H, Wide L. Treatment with one-alpha-hydroxycholecalciferol in middle-aged men with impaired glucose tolerance--a prospective randomized double-blind study. Acta Medica Scandinavica. 1987;222:361-367. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 3321925].
Lo G.S, Goldberg A.P, Lim A. Soy fiber improves lipid and carbohydrate metabolism in primary hyperlipidemic subjects. Atherosclerosis. 1986;62:239-248. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3026411].
Lorentzen B, Birkeland K.I, Endresen M.J, Henriksen T. Glucose intolerance in women with preeclampsia. Acta Obstet Gynecol Scand. 1998;77:22-27. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9492712].
Lorini R, Alibrandi A, Vitali L, Klersy C, Martinetti M, Betterle C, d'Annunzio G, Bonifacio E. Pediatric Italian Study Group of Prediabetes. Risk of type 1 diabetes development in children with incidental hyperglycemia: A multicenter Italian study. Diabetes Care. 2001;24:1210-1216. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11423504].
Louheranta A.M, Sarkkinen E.S, Vidgren H.M, Schwab U.S, Uusitupa M.I.J. Association of the fatty acid profile of serum lipids with glucose and insulin metabolism during 2 fat-modified diets in subjects with impaired glucose tolerance. Am J Clin Nutr. 2002;76:331-337. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 12145003].
Louheranta J. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26:3230-3236. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14633807].
Lourido J, Ederoth P, Sundvall N, Ungerstedt U, Nordstrom C.-H. Correlation between blood glucose concentration and glucose concentration in subcutaneous adipose tissue evaluated with microdialysis during intensive care. Scand J Clin Lab Invest. 2002;62:285-292. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12476927].
Loveman E, Cave C, Green C, Royle P, Dunn N, Waugh N. The clinical and cost-effectiveness of patient education models for diabetes: A systematic review and economic evaluation. Health Technology Assessment (Winchester, England). 2003;7:190. Status: Not included because article does not describe a study or survey.
Lu W, Resnick H.E, Jain A.K, Adams-Campbell L.L, Jablonski K.A, Gottlieb A.M, Robbins D.C, Howard B.V. Effects of isolated post-challenge hyperglycemia on mortality in American Indians: the Strong Heart Study. Ann Epidemiol. 2003;13:182-188. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12604162].
Lucas D, Farez C, Bardou L.G, Vaisse J, Attali J.R, Valensi P. Cytochrome P450 2E1 activity in diabetic and obese patients as assessed by chlorzoxazone hydroxylation. Fundam Clin Pharmacol. 1998;12:553-558. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9794154].
Lundell K.H, Sabel K.G, Eriksson B.O, Mellgren G. Glucose metabolism and insulin secretion in children with cyanotic congenital heart disease. Acta Paediatr. 1997;86:1082-1084. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9350889].
Lunetta M, Di Mauro M, Nicoletti F, Mughini L. Diabetogenic effect of naloxone in subjects with impaired glucose tolerance. Medical Science Research. 1991;19:737-738. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review.
MacGregor A.S, Price J.F, Hau C.M, Lee A.J, Carson M.N, Fowkes F.G. Role of systolic blood pressure and plasma triglycerides in diabetic peripheral arterial disease. The Edinburgh Artery Study. Diabetes Care. 1999;22:453-458. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10097928].
Mackey R.H, Sutton-Tyrrell K, Vaitkevicius P.V, Sakkinen P.A, Lyles M.F, Spurgeon H.A, Lakatta E.G, Kuller L.H. Correlates of aortic stiffness in elderly individuals: A subgroup of the cardiovascular health study. Am J Hypertens. 2002;15:16-23. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11824854].
Maggi S, Zucchetto M, Grigoletto F, Baldereschi M, Candelise L, Scarpini E, Scarlato G, Amaducci L. The Italian Longitudinal Study on Aging (ILSA): design and methods. Aging (Milano). 1994;6:464-473. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7748921].
Mak, R. H. K., Turner, C., Haycock, G. B., and Chantler, C. Secondary hyperparathyroidism and glucose intolerance in children with uremia. Kidney Int 1983; 24 Status: Excluded because no subjects diagnosed by included criteria were analyzed
Mak, R. H. K., Turner, C., Thompson, T., Haycock, G., and Chantler, C. Glucose metabolism in children with uremia: Effect of dietary phosphate and protein. Kidney Int 1987; 32 Status: Excluded because no subjects diagnosed by included criteria were analyzed
Mancini M, Strazzullo P, Trevisan M, Contaldo F, Vaccaro O, Cappuccio F.P. Pathophysiological interrelations of obesity, impaired glucose tolerance, and arterial hypertension. Prev Med. 1985;14:428-435. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 3906627].
Manderson J.G, Patterson C.C, Hadden D.R, Traub A.I, Leslie H, McCance D.R. Leptin concentrations in maternal serum and cord blood in diabetic and nondiabetic pregnancy. Am J Obstet Gynecol. 2003;188:1326-1332. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12748507].
Mangiagli A, Italia S, De Sanctis V, Campisi S. Impaired glucose homeostasis in young adult thalassemic patients: A pilot study with acarbose. J Pediatr Endocrinol Metab. 2002;15:205-210. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11874186].
Mannucci E, Ognibene A, Cremasco F, Bardini G, Mencucci A, Pierazzuoli E, Ciani S, Messeri G, Rotella C.M. Effect of metformin on glucagon-like peptide 1 (GLP-1) and leptin levels in obese nondiabetic subjects. Diabetes Care. 2001;24:489-494. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11289473].
Marceau P, Biron S, Hould F.S, Marceau S, Simard S, Thung S.N, Kral J.G. Liver pathology and the metabolic syndrome X in severe obesity.[see comment]. J Clin Endocrinol Metab. 1999;84:1513-1517. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10323371].
Marchand E, Grigorescu F, Buysschaert M. The hypoglycemic effect of a sulfonylurea (gliclazide) in moderate type II diabetes and glucose intolerance is not accompanied by changes in insulin action and insulin binding to erythrocytes. Molecular Physiology. 1983;4:83-93. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Marchesi E, Baiardini R, Centeleghe P, Covini D, Frattoni A, Muggia C, Ravetta V, Resasco T. Structural changes in the heart and carotid arteries in hypertensive patients associated with cardiovascular risk factors. J Cardiovasc Risk. 1997;4:283-289. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9477207].
Marchesini G, Ronchi M, Forlani G, Bugianesi E, Bianchi G, Fabbri A, Zoli M, Melchionda N. Cardiovascular disease in cirrhosis--a point-prevalence study in relation to glucose tolerance. Am J Gastroenterol. 1999;94:655-662. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10086647].
Mari A. Assessment of insulin sensitivity and secretion with the labelled intravenous glucose tolerance test: Improved modelling analysis. Diabetologia. 1998;41:1029-1039. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9754821].
Mari A, Pacini G, Murphy E, Ludvik B, Nolan J.J. A model-based method for assessing insulin sensitivity from the oral glucose tolerance test. Diabetes Care. 2001;24:539-548. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11289482].
Marugame T, Lee K, Eguchi H, Oda T, Shinchi K, Kono S. Relation of impaired glucose tolerance and diabetes mellitus to colorectal adenomas in Japan. Cancer Causes Control. 2002;13:917-921. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12588087].
Marugame T, Hayasaki H, Lee K, Eguchi H, Matsumoto S. Alveolar bone loss associated with glucose tolerance in Japanese men. Diabet Med. 2003;20:746-751. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12925056].
Mathur H.C, Gupta S.D. Evaluation of correlation of C.S.F. and blood sugar in neurological disorders of childhood. Indian Medical Gazette. 1984;118:331-332. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Matsuda M, DeFronzo R.A. Insulin sensitivity indices obtained from oral glucose tolerance testing: Comparison with the euglycemic insulin clamp. Diabetes Care. 1999;22:1462-1470. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10480510].
Matthews D.R, Edge J.A, Dunger D.B. Un unbiased glucose clamp method using a variable insulin infusion: Its application in diabetic adolescents. Diabet Med. 1990;7:246-251. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2139397].
Mayer-Davis E.J, Costacou T, King I, Zaccaro D.J, Bell R.A. The Insulin Resistance and Atherosclerosis Study (IRAS). Plasma and dietary vitamin E in relation to incidence of type 2 diabetes: The Insulin Resistance and Atherosclerosis Study (IRAS). Diabetes Care. 2002;25:2172-2177. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12453956].
Mazza A, Pessina A.C, Pavei A, Scarpa R, Tikhonoff V, Casiglia E. Predictors of stroke mortality in elderly people from the general population. The CArdiovascular STudy in the ELderly. Eur J Epidemiol. 2001;17:1097-1104. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12530768].
Mbanya J.-C, Cruickshank J.K, Forrester T, Balkau B, Ngogang J.Y, Riste L, Forhan A, Anderson N.M, Bennett F, Wilks R. Standardized comparison of glucose intolerance in West African-origin populations of rural and urban Cameroon, Jamaica, and Caribbean migrants to Britain. Diabetes Care. 1999;22:434-440. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10097925].
McCartney P, Keen H, Jarrett R.J. The Bedford Survey: observations on retina and lens of subjects with impaired glucose tolerance and in controls with normal glucose tolerance. Diabete Metab. 1983;9:303-305. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6667765].
McClain M.R, Srinivasan S.R, Chen W, Steinmann W.C, Berenson G.S. Risk of type 2 diabetes mellitus in young adults from a biracial community: the Bogalusa Heart Study. Prev Med. 2000;31:1-7. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10896837].
McCowen K.C, Friel C, Sternberg J, Chan S, Forse R.A, Burke P.A, Bistrian B.R. Hypocaloric total parenteral nutrition: effectiveness in prevention of hyperglycemia and infectious complications -- a randomized clinical trial. Crit Care Med. 2000;28:3606-3611. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11098961].
McGill H.C Jr, McMahan C.A, Zieske A.W, Malcom G.T, Tracy R.E, Strong J.P. Effects of nonlipid risk factors on atherosclerosis in youth with a favorable lipoprotein profile. Circulation. 2001;103:1546-1550. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11257083].
McIntyre H.D, Begg L.M, Parry A.F, Oats J. Audit of maternal and fetal outcomes in women treated for glucose intolerance during pregnancy. Aust N Z J Obstet Gynaecol. 2002;42:23-28. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11926637].
McKeigue P.M, Shah B, Marmot M.G. Relation of central obesity and insulin resistance with high diabetes prevalence and cardiovascular risk in South Asians [see comments]. Lancet. 1991;337:382-386. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1671422].
McLellan J.A.S, Barrow B.A, Levy J.C, Hammersley M.S, Hattersley A.T, Gillmer M.D.G, Turner R.C. Prevalence of diabetes mellitus and impaired glucose tolerance in parents of women with gestational diabetes. Diabetologia. 1995;38:693-698. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7672491].
McPhillips J.B, Barrett-Connor E, Wingard D.L. Cardiovascular disease risk factors prior to the diagnosis of impaired glucose tolerance and non-insulin-dependent diabetes mellitus in a community of older adults. Am J Epidemiol. 1990;131:443-453. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 2301354].
Meigs J.B, Nathan D.M, Wilson P.W.F, Cupples L.A, Singer D.E. Metabolic risk factors worsen continuously across the spectrum of nondiabetic glucose tolerance: the Framingham Offspring Study. Annals of Internal Medicine. 1998;128:524-533. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9518396].
Meigs J.B, Mittleman M.A, Nathan D.M, Tofler G.H, Singer D.E, Murphy-Sheehy P.M, Lipinska I, D'Agostino R.B, Wilson P.W. Hyperinsulinemia, hyperglycemia, and impaired hemostasis: the Framingham Offspring Study. JAMA. 2000;283:221-228. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10634338].
Meigs J.B, D'Agostino R.B Sr, Nathan D.M, Rifai N, Wilson P.W. Framingham Offspring Study. Longitudinal association of glycemia and microalbuminuria: the Framingham Offspring Study. Diabetes Care. 2002;25:977-983. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12032102].
Meigs J.B, Nathan D.M, D'Agostino R.B Sr, Wilson P.W. Framingham Offspring Study. Fasting and postchallenge glycemia and cardiovascular disease risk: the Framingham Offspring Study. Diabetes Care. 2002;25:1845-1850. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12351489].
Meigs J.B, Muller D.C, Nathan D.M, Blake D.R, Andres R. Baltimore Longitudinal Study of Aging. The natural history of progression from normal glucose tolerance to type 2 diabetes in the Baltimore Longitudinal Study of Aging. Diabetes. 2003;52:1475-1484. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12765960].
Mennen L.I, de Courcy Potier, Guilland J.-C, Ducros V, Bertrais S, Nicolas J.-P, Maurel M, Zarebska M, Favier A, Franchisseur C, Hercberg S, Galan P. Homocysteine, cardiovascular disease risk factors, and habitual diet in the French Supplementation with Antioxidant Vitamins and Minerals Study. Am J Clin Nutr. 2002;76:1279-1289. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12450894].
Menotti A. Cardiovascular risk factors in patients discharged from departments of internal medicine-the Italian FADOI-2 study. European Journal of Internal Medicine. 2002;13:44-51. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11836082].
Mensink M, Blaak E.E, Vidal H, De Bruin T.W.A, Glatz J.F.C, Saris W.H.M. Lifestyle changes and lipid metabolism gene expression and protein content in skeletal muscle of subjects with impaired glucose tolerance. Diabetologia. 2003;46:1082-1089. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12856127].
Mensink M, Corpeleijn E. Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61:49-58. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12849923].
Mensink M, Feskens E.-J.M, Saris W.-H.M, de Bruin T.-W.A, Blaak E.E. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): Preliminary results after one year. International-Journal-of-Obesity-and-Related-Metabolic-Disorders. 2003;27:377-384. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 12629566].
Mertz W. Chromium in human nutrition: A review. J Nutr. 1993;123:626-633. Status: Not included because article does not describe a study or survey. [pmid: 8463863].
Merz C.N.B, Buse J.B, Tuncer D, Twillman G.B. Physician attitudes and practices and patient awareness of the cardiovascular complications of diabetes. J Am Coll Cardiol. 2002;40:1877-1881. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12446074].
Mescheryakov A.V, Kozlov I.A, Dementyeva I.I, Lakhter M.A, Ermolyn A.J, Galyibin A.A. Glucose metabolism and insulin activity during cardiac surgery. J Cardiothorac Anesth. 1989;3:536-543. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2520930].
Mestman J.H. Outcome of diabetes screening in pregnancy and perinatal morbidity in infants of mothers with mild impairment in glucose tolerance. Diabetes Care. 1980;3:447-452. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7389561].
Metzger B.E, Bybee D.E, Freinkel N. Gestational diabetes mellitus. Correlations between the phenotypic and genotypic characteristics of the mother and abnormal glucose tolerance during the first year postpartum. Diabetes. 1985;34:111-115. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3888736].
Micic D, Kendereski A, Sumarac-Dumanovic M, Cvijovic G, Popovic V, Dieguez C, Casanueva F. Growth hormone response to GHRH + GHRP-6 in type 2 diabetes during euglycemic and hyperglycemic clamp. Diabetes Res Clin Pract. 2004;63:37-45. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14693411].
Mihara T, Oohashi H, Hirata Y. Mortality of Japanese diabetics in a seven-year follow-up study. Diabetes Res Clin Pract. 1986;2:139-144. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3743361].
Milla C.E, Warwick W.J, Moran A. Trends in pulmonary function in patients with cystic fibrosis correlate with the degree of glucose intolerance at baseline. Am J Respir Crit Care Med. 2000;162:891-895. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10988101].
Mingrone G, De Gaetano A, Greco A.V, Capristo E, Benedetti G, Castagneto M, Gasbarrini G. Dodecanedioic acid infusion induces a sparing effect on whole-body glucose uptake, mainly in non-insulin-dependent diabetes mellitus. Br J Nutr. 1997;78:723-735. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9389896].
Misra A, Cherukupalli R, Reddy K.S, Mohan A, Bajaj J.S. Hyperinsulinemia and dyslipidemia in non-obese, normotensive offspring of hypertensive parents in northern India. Blood Pressure. 1998;7:286-290. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10321441].
Misra A, Reddy R.B, Reddy K.S, Mohan A, Bajaj J.S. Clustering of impaired glucose tolerance, hyperinsulinemia and dyslipidemia in young north Indian patients with coronary heart disease: a preliminary case-control study. Indian Heart J. 1999;51:275-280. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10624065].
Mitrakou A, Kelley D, Mokan M, Veneman T, Pangburn T, Reilly J, Gerich J. Role of reduced suppression of glucose production and diminished early insulin release in impaired glucose tolerance. N Engl J Med. 1992;326:22-29. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1727062].
Miwa S, Inouye M, Ohmura C, Mitsuhashi N, Onuma T, Kawamori R. Relationship between carotid atherosclerosis and erythrocyte membrane cholesterol oxidation products in type 2 diabetic patients. Diabetes Res Clin Pract. 2003;61:81-88. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12951275].
Miyazaki S. Abnormal glucose tolerance and prognosis after PTCA. Cardiology Review. 2001;18:18-22. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Modan M, Halkin H, Karasik A, Lusky A. Effectiveness of glycosylated hemoglobin, fasting plasma glucose, and a single post load plasma glucose level in population screening for glucose intolerance. The Israel Study of Glucose Intolerance, Obesity and Hypertension. Am J Epidemiol. 1984;119:431-444. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6702817].
Modan M, Or J, Karasik A, Drory Y, Fuchs Z, Lusky A, Chetrit A, Halkin H. Hyperinsulinemia, sex, and risk of atherosclerotic cardiovascular disease [see comments]. Circulation. 1991;84:1165-1175. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1884447].
Molitch M.E, Hou S.H, Gottesman S. Effects of antihypertensive medications on carbohydrate metabolism. Current Therapeutic Research, Clinical & Experimental. 1986;39:398-407. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Montori V.M. A lifestyle intervention or metformin prevented or delayed the onset of type 2 diabetes in persons at risk. ACP Journal Club. 2002;137:5. Status: Not included because article does not describe a study or survey. [pmid: 12093204].
Morel, Y., Lehmann, T., Vadas, L., and, Golay, and A. Effect of Metformine on insulin-resistance in obese patients with glucose-intolerance TO:=Effet de la Metformine sur la résistance á l'insuline chez des patients obèses avec intolérance au glucose. Schweiz Med Wochenschr 1996; 126:12 Status: Not included because article was not published in English
Morel Y, Golay A, Perneger T, Lehmann T, Vadas L, Pasik C, Reaven G.M. Metformin treatment leads to an increase in basal, but not insulin-stimulated, glucose disposal in obese patients with impaired glucose tolerance. Diabet Med. 1999;16:650-655. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10477209].
Morici M.L, Di Marco A, Sestito D, Candore R, Cangemi C, Accardo F, Donatelli M, Cataldo M.G, Lombardo A. The impact of coexistent diabetes on the prevalence of coronary heart disease. J Diabetes Complications. 1997;11:268-273. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9334908].
Motala A.A, Omar M.A. The value of glycosylated haemoglobin as a substitute for the oral glucose tolerance test in the detection of impaired glucose tolerance (IGT). Diabetes Res Clin Pract. 1992;17:199-207. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1425159].
Motala A.A, Omar M.A. Evidence for impaired pancreatic beta cell function in South African Indians with impaired glucose tolerance. Diabet Med. 1994;11:437-444. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8088120].
Muller S, Martin S, Koenig W, Hanifi-Moghaddam P, Rathmann W, Haastert B, Giani G, Illig T, Thorand B, Kolb H. Impaired glucose tolerance is associated with increased serum concentrations of interleukin 6 and co-regulated acute-phase proteins but not TNF-alpha or its receptors. Diabetologia. 2002;45:805-812. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12107724].
Mutch W.J, Stowers J.M. Reversible mild diabetes in children after treatment with chlorpropamide. Lancet. 1980;1:1158-1161. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6103984].
Mykkanen L, Laakso M, Penttila I, Pyorala K. Asymptomatic hyperglycemia and cardiovascular risk factors in the elderly. Atherosclerosis. 1991;88:153-161. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1892482].
Mykkanen L, Haffner S.M, Ronnemaa T, Bergman R.N, Laakso M. Low insulin sensitivity is associated with clustering of cardiovascular disease risk factors. Am J Epidemiol. 1997;146:315-321. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9270410].
Nagai T, Tomizawa T, Minamide S, Nakajima K, Mori M. Serum lipid and lipoprotein metabolism after glucose ingestion in NIDDM and IGT patients: Apolipoprotein-containing particles. Diabetes Care. 1996;19:365-368. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8729161].
Nagi D.K, Ali V.M, Walji S, Jain S.K, Yudkin J.S. Hyperinsulinemia in nondiabetic Asian subjects using specific assays for insulin, intact proinsulin, and des-31, 32-proinsulin. Diabetes Care. 1996;19:39-42. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8720531].
Nagi D.K, Pettitt D.J, Bennett P.H, Klein R, Knowler W.C. Diabetic retinopathy assessed by fundus photography in Pima Indians with impaired glucose tolerance and NIDDM. Diabet Med. 1997;14:449-456. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9212309].
Naito H, Ohneda A, Kojima R, Sato T, Sasaki K, Funayama Y, Fukushima K, Shibata C, Matsuno S, Sasaki I. Plasma glicentin in diabetic and gastrectomized patients. Regul Pept. 1999;79:55-61. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9930583].
Nakai I, Mizuta N, Nakamura K, Okamoto M, Nakajiama H, Yoshimura N, Yasumura T, Omori Y, Oka T. Effects and limits of renal transplantation in patients with impaired glucose tolerance. Transplant Proc. 1998;30:114-115. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9474974].
Nakanishi N, Nakamura K, Matsuo Y, Suzuki K, Tatara K. Cigarette smoking and risk for impaired fasting glucose and Type 2 Diabetes in middle-aged Japanese men. Annals of Internal Medicine. 2000;133:183-191. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10906832].
Nakanishi N, Nishina K, Yoshida H, Matsuo Y, Nagano K, Nakamura K, Suzuki K, Tatara K. Hours of work and the risk of developing impaired fasting glucose or type 2 diabetes mellitus in Japanese male office workers. Occupational & Environmental Medicine. 2001;58:569-574. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11511743]. [pmcid: 1740182].
Nakanishi N, Okamoto M, Yoshida H, Matsuo Y, Suzuki K, Tatara K. Serum uric acid and risk for development of hypertension and impaired fasting glucose or Type II diabetes in Japanese male office workers. Eur J Epidemiol. 2003;18:523-530. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12908717].
Nakanishi N, Nishina K, Li W, Sato M, Suzuki K, Tatara K. Serum gamma-glutamyltransferase and development of impaired fasting glucose or type 2 diabetes in middle-aged Japanese men. J Intern Med. 2003;254:287-295. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12930239].
Nam J.H, Mun J.I, Kim S.I, Kang S.W, Choi K.H, Park K, Ahn C.W, Cha B.S, Song Y.D, Lim S.K, Kim K.R, Lee H.C, Huh K.B. beta-cell dysfunction rather than insulin resistance is the main contributing factor for the development of postrenal transplantation diabetes mellitus. Transplantation. 2001;71:1417-1423. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11391229].
Nannipieri M, Posadas R, Williams K, Politi E, Gonzales-Villalpando C, Stern M.P, Ferrannini E. Association between polymorphisms of the atrial natriuretic peptide gene and proteinuria: a population-based study. Diabetologia. 2003;46:429-432. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12687344].
Nasrat A.A, Augensen K, Abushal M, Shalhoub J.T. The outcome of pregnancy following untreated impaired glucose tolerance. Int J Gynaecol Obstet. 1994;47:1-6. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7813745].
Nathan D.M. Addressing the 21st Century Diabetes Epidemic. Advanced Studies in Medicine. 2002;2:961-965. Status: Not included because article does not describe a study or survey.
Nauck M.A, Weber I, Bach I, Richter S, Orskov C, Holst J.J, Schmiegel W. Normalization of fasting glycaemia by intravenous GLP-1 ([7–36 amide] or [7–37]) in type 2 diabetic patients. Diabet Med. 1998;15:937-945. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9827848].
Nauck M.A, Meier J.J, Wolfersdorff A.V, Tillil H, Creutzfeldt W, Kobberling J. A 25-year follow-up study of glucose tolerance in first-degree relatives of type 2 diabetic patients: Association of impaired or diabetic glucose tolerance with other components of the metabolic syndrome. Acta Diabetol. 2003;40:163-172. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14740275].
Nelson R.G, Tan M, Beck G.J, Bennett P.H, Knowler W.C, Mitch W.E, Blouch K, Myers B.D. Changing glomerular filtration with progression from impaired glucose tolerance to Type II diabetes mellitus. Diabetologia. 1999;42:90-93. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10027584].
Neufeld N.D, Raffel L.J, Landon C, Chen Y.D, Vadheim C.M. Early presentation of type 2 diabetes in Mexican-American youth. Diabetes Care. 1998;21:80-86. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9538974].
Nicholson G, Paton A. Glucose tolerance in alcoholics. J Stud Alcohol. 1979;40:997-1002. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Niemi M, Kervinen K, Rantala A, Kauma H, Paivansalo M, Savolainen M.J, Lilja M, Kesaniemi Y.A. The role of apolipoprotein E and glucose intolerance in gallstone disease in middle aged subjects. Gut. 1999;44:557-562. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 10075965]. [pmcid: 1727442].
Niskanen L, Sarlund H, Laakso M. Metabolic defects in persistent impaired glucose tolerance are related to the family history of non-insulin-dependent diabetes mellitus. Metabolism. 1995;44:1099-1104. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7637652].
Niskanen L.K, Salonen J.T, Nyyssonen K, Uusitupa M.I. Plasma lipid peroxidation and hyperglycaemia: a connection through hyperinsulinaemia?. Diabet Med. 1995;12:802-808. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8542741].
Nissinen A, Tervahauta M, Pekkanen J, Kivinen P, Stengard J, Kaarsalo E, Kivela S.-L, Vaisanen S, Salonen J.T, Tuomilehto J. Prevalence and change of cardiovascular risk factors among men born 1900-19: The Finnish cohorts of the Seven Countries Study. Age & Ageing. 1993;22:365-376. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8237628].
Nord E, Hanson U, Persson B. Blood glucose limits in the diagnosis of impaired glucose tolerance during pregnancy. Acta Obstet Gynecol Scand. 1995;74:589-593. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7660761].
Norhammar A, Tenerz A, Nilsson G, Hamsten A, Efendic S, Ryden L, Malmberg K. Glucose metabolism in patients with acute myocardial infarction and no previous diagnosis of diabetes mellitus: a prospective study.[see comment]. Lancet. 2002;359:2140-2144. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12090978].
Nozaka K, Hamazoe R, Nishimura O. Results of surgical treatment of chronic pancreatitis. Yonago Acta Medica. 1987;30:105-114. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Offenbacher E.G, Pi-Sunyer F.X. Beneficial effect of chromium-rich yeast on glucose tolerance and blood lipids in elderly subjects. Diabetes. 1980;29:919-925. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7000589].
Ogawa O, Onuma T, Uchino H, Takayanagi Y, Tanaka Y, Yamasaki Y, Atsumi Y, Matsuoka K, Kawamori R. Insulin resistance and atherosclerosis in branch retinal vein occlusion. Jpn J Ophthalmol. 2003;47:351-355. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12842202].
Ohlson L.-O, Larsson B, Eriksson H. Diabetes mellitus in Swedish middle-aged men. The study of men born in 1913 and 1923. Diabetologia. 1987;30:386-393. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3678659].
Ohlson L.-O, Larsson B, Bjorntorp P, Eriksson H, Svardsudd K, Welin L, Tibblin G, Wilhelmsen L. Risk factors for Type 2 (non-insulin-dependent) diabetes mellitus. Thirteen and one-half years of follow-up of the participants in a study of Swedish men born in 1913. Diabetologia. 1988;31:798-805. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3234634].
Ohlson L.O, Svardsudd K, Welin L, Eriksson H, Wilhelmsen L, Tibblin G, Larsson B. Fasting blood glucose and risk of coronary heart disease, stroke, and all-cause mortality: a 17-year follow-up study of men born in 1913. Diabet Med. 1986;3:33-37. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2951132].
Ohlson L.O, Bjuro T, Larsson B, Eriksson H, Svardsudd K, Welin L, Wilhelmsen L. A cross-sectional analysis of glucose tolerance and cardiovascular disease in 67-year-old men. Diabet Med. 1989;6:112-120. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2522851].
Ohneda A, Kobayashi T, Nihei J. Evaluation of new criteria for diagnosis of diabetes mellitus based on follow-up study of borderline diabetes. Tohoku J Exp Med. 1982;137:437-444. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6750844].
Ohnishi H, Saitoh S, Takagi S, Ohata J, Isobe T, Kikuchi Y, Takeuchi H, Shimamoto K. Pulse wave velocity as an indicator of atherosclerosis in impaired fasting glucose: the Tanno and Sobetsu study. Diabetes Care. 2003;26:437-440. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12547876].
Oida E, Kannagi T, Moritani T, Yamori Y. Diabetic alteration of cardiac vago-sympathetic modulation assessed with tone-entropy analysis. Acta Physiol Scand. 1999;165:129-134. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10090323].
Oimomi M, Ishikawa K, Kawasaki T. Carbamylation of hemoglobin in renal failure and clinical aspects. Metabolism. 1984;33:999-1002. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6493050].
Okamoto F, Sone H, Nonoyama T, Hommura S. Refractive changes in diabetic patients during intensive glycaemic control. Br J Ophthalmol. 2000;84:1097-1102. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11004091]. [pmcid: 1723257].
Okamura F, Tashiro A, Utumi A, Imai T, Suchi T, Tamura D, Sato Y, Suzuki S, Hongo M. Insulin resistance in patients with depression and its changes during the clinical course of depression: minimal model analysis. Metabolism. 2000;49:1255-1260. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11079812].
Okubo M, Watanabe H, Fujikawa R, Kawamura T, Egusa G, Yamakido M. Reduced prevalence of diabetes according to 1997 American Diabetes Association criteria. Diabetologia. 1999;42:1168-1170. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10525655].
Olatunbosun S.T. Diagnosis and follow-up of subjects with impaired glucose tolerance: how reliable is OGTT? Report from a Nigerian survey. Diabetes Res Clin Pract. 1998;41:147-148. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9789721].
Olsson G, Rehnqvist N. Effects of chronic metoprolol treatment on glucose tolerance after myocardial infarction. Eur J Clin Pharmacol. 1987;33:311-313. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3691619].
Oluboyo P.O, Erasmus R.T. The significance of glucose intolerance in pulmonary tuberculosis. Tubercle. 1990;71:135-138. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because of case-control design. Not included for treatment because intervention was not relevant to review. [pmid: 2219464].
Osei K, Schuster D.P. Decreased insulin-mediated but not non-insulin-dependent glucose disposal rates in glucose intolerance and type II diabetes in African (Ghanaian) immigrants. Am J Med Sci. 1996;311:113-121. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8615385].
Otsuka Y, Miyazaki S, Okumura H, Yasuda S, Daikoku S, Morii I, Sutani Y, Goto Y, Nonogi H. Abnormal glucose tolerance, not small vessel diameter, is a determinant of long-term prognosis in patients treated with balloon coronary angioplasty.[see comment]. Eur Heart J. 2000;21:1790-1796. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11052844].
Oyibo S.O, Prasad Y.D.M, Jackson N.J, Jude E.B, Boulton A.J.M. The relationship between blood glucose excursions and painful diabetic peripheral neuropathy: A pilot study. Diabet Med. 2002;19:870-873. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12358878].
Pagani G, Gianola D, Pagani M.D, Tengattini F, Dominoni P, Ghilardi G, Cortesi L, Pedroncelli A, Tonnarelli G.P. Medical management of acromegaly: Effects of SMS 201-995 in 30 patients. Endocrinol Exp. 1990;24:175-185. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2361459].
Page R.C, Harnden K.E, Cook J.T, Turner R.C. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-566. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1643806].
Page R.C, Walravens E.K, Levy J.C, Stratton I.M, Turner R.C. Prevalence and pathophysiology of impaired glucose tolerance in three different high-risk white groups. Metabolism. 1993;42:932-938. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8345815].
Page R.C, Harnden K.E, Walravens N.K, Onslow C, Sutton P, Levy J.C, Hockaday D.T, Turner R.C. ‘Healthy living’ and sulphonylurea therapy have different effects on glucose tolerance and risk factors for vascular disease in subjects with impaired glucose tolerance. Q J Med. 1993;86:145-154. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8483989].
Page R.C.L, Harnden K.E, Cook J.T.E, Turner R.C. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-566. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1643806].
Page R.C.L, Harnden K.E, Walravens N.K.N, Onslow C, Sutton P, Levy J.C, Hockaday D.T.R, Turner R.C. ‘Healthy living’ and sulphonylurea therapy have different effects on glucose tolerance and risk factors for vascular disease in subjects with impaired glucose tolerance. Q J Med. 1993;86:145-154. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8483989].
Pagnan A, Ambrosio G.B, Vincenzi M, Mormino P, Maiolino P, Gerin L, Barbieri E, Cappelletti F, Dal Palu C. Precursors of atherosclerosis in children: the Cittadella study. Follow-up and tracking of total serum cholesterol, triglycerides, and blood glucose. Prev Med. 1982;11:381-390. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7122430].
Paivansalo M.J, Merikanto J, Savolainen M.J, Lilja M, Rantala A.O, Kauma H, Reunanen A, Kesaniemi Y.A, Suramo I. Effect of hypertension, diabetes and other cardiovascular risk factors on kidney size in middle-aged adults. Clin Nephrol. 1998;50:161-168. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9776419].
Paleologos M, Stone E, Braude S. Persistent, progressive hypophosphataemia after voluntary hyperventilation. Clin Sci (Colch ). 2000;98:619-625. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10781395].
Pallardo F, Herranz L, Garcia-Ingelmo T, Grande C, Martin-Vaquero P, Janez M, Gonzalez A. Early postpartum metabolic assessment in women with prior gestational diabetes. Diabetes Care. 1999;22:1053-1058. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10388966].
Palmer G.S, Clancy M.C, Hawley J.A, Rodger I.M, Burke L.M, Noakes T.D. Carbohyrate ingestion immediately before exercise does not improve 20 km time trial performance in well trained cyclists. Int J Sports Med. 1998;19:415-418. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9774209].
Palumbo G, Barantani E, Pozzi F, Azzolini V, Gronda D, Ronchi E. Long-term nifedipine treatment and glucose homeostasis in hypertensive patients. Current Therapeutic Research, Clinical & Experimental. 1988;43:171-179. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Pan C-Y, Gao Y, Chen J.-W, Luo B.-Y, Fu Z.-Z, Lu J.-M, Guo X.-H, Cheng H. Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003;61:183-190. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12965108].
Pan C.Y.G. Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003;61:183-190. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12965108].
Pan X-R, Hu Y-H, Li G-W, Liu P-A, Bennett P.H, Howard B.V. Impaired glucose tolerance and its relationship to ECG-indicated coronary heart disease and risk factors among Chinese: Da Qing IGT and diabetes study. Diabetes Care. 1993;16:150-156. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8422770].
Panarotto D, Ardilouze J.L, Tessier D, Maheux P. The degree of hyperinsulinemia and impaired glucose tolerance predicts plasma leptin concentrations in women only: a new exploratory paradigm. Metabolism. 2000;49:1055-1062. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10954026].
Paolisso G, Tataranni P.A, Foley J.E, Bogardus C, Howard B.V, Ravussin E. A high concentration of fasting plasma non-esterified fatty acids is a risk factor for the development of NIDDM. Diabetologia. 1995;38:1213-1217. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8690174].
Pappas S, Donohue S.M, Denver A.E, Mohamed-Ali V, Goubet S, Yudkin J.S. Glucose intolerance in thalassemia major is related to insulin resistance and hepatic dysfunction. Metabolism. 1996;45:652-657. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8622611].
Park K.S, Kim C.H, Lee M.K, Shin C.S, Park D.J, Kim S.Y, Cho B.Y, Lee H.K. Metabolic effect of decreasing nonesterified fatty acid levels with acipimox in hyperthyroid patients. Metabolism. 1999;48:1318-1321. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10535397].
Parulkar A.A, Fonseca V.A. Recent advances in pharmacological treatment of type 2 diabetes mellitus. Comprehensive Therapy. 1999;25:418-426. Status: Not included because article does not describe a study or survey. [pmid: 10520444].
Passariello N, Giugliano D, Sgambato S, Torella R, D'Onofrio F. Calcitonin, a diabetogenic hormone?. J Clin Endocrinol Metab. 1981;53:318-323. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7019230].
Passariello N, Giugliano D, Ceriello A. Impaired insulin response to glucose but not to arginine in heroin addicts. J Endocrinol Invest. 1986;9:353-357. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3540079].
Pastore G, Saracco P, del Prever Brach. Glucose metabolism in children with acute lymphoblastic leukemia treated according to two different L-asparaginase schedules. Acta Haematologica. 1984;72:384-387. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6442522].
Payne K, Ireland P. Plasma glucose levels in the peri-operative period in children. Anaesthesia. 1984;39:868-872. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6545086].
Peart W.S, Barnes G.R, Broughton P. Adverse reactions to bendrofluazide and propranolol for the treatment of mild hypertension. Report of medical research council working party on mild to moderate hypertension. Lancet. 1981;2:539-543. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6115999].
Pennebaker, James W, et al. Physical symptoms related to blood glucose in insulin-dependent diabetics. Psychosomatic-Medicine. 1981;43:489-500. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7323257].
Peraldo M, Fasulo A, Chiappini E, Milio C, Marianelli L. Evaluation of glucose tolerance and insulin secretion in cystic fibrosis patients. Horm Res. 1998;49:65-71. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9485173].
Percheron C, Colette C, Avignon A, Monnier L. Metabolic responses to high carbohydrate breakfasts in obese patients with impaired glucose tolerance. Comparison of meals containing dairy products and fruits versus bread. Nutrition Research. 1997;17:797-806. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months.
Pereira, M. A., Jacobs, D. R., Jr., Van Horn, L., Slattery, M. L., Kartashov, A. I., and Ludwig, D. S. Dairy consumption, obesity, and the insulin resistance syndrome in young adults: the CARDIA Study. JAMA 287(16):2081–9, 2153–4, 2002 Apr 24 (56 ref) 2002; 2081–2089. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Perlman J.A, Russell-briefel R, Ezzati T, Lieberknecht G. Oral glucose tolerance and the potency of contraceptive progestins. J Chronic Dis. 1985;38:857-864. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4044771].
Permert J, Ihse I, Jorfeldt L, Von Schenck H, Arnqvist H.J, Larsson J. Pancreatic cancer is associated with impaired glucose metabolism. Eur J Surg. 1993;159:101-107. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 8098623].
Persson B, Hanson U. Insulin dependent diabetes in pregnancy: Impact of maternal blood glucose control on the offspring. Journal of Paediatrics & Child Health. 1993;29:20-23. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8461173].
Persson L-G, Lindstrom K, Bengtsson C. Oral glucose tolerance and its relationship to overweight and other cardiovascular risk factors in men aged 33–42. A study in the Community of Habo, Sweden. Scand J Prim Health Care. 1994;12:261-268. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7863144].
Peters A.L, Davidson M.B, Schriger D.L, Hasselblad V. A clinical approach for the diagnosis of diabetes mellitus: An analysis using glycosylated hemoglobin levels. Journal of the American Medical Association. 1996;276:1246-1252. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8849753].
Pettitt D.J, Bennett P.H, Saad M.F, Charles M.A, Nelson R.G, Knowler W.C. Abnormal glucose tolerance during pregnancy in Pima Indian women. Long-term effects on offspring. Diabetes. 1991;40(Suppl 2):126-130. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1748241].
Peyrot M, Rubin R.R. Structure and correlates of diabetes-specific locus of control. Diabetes Care. 1994;17:994-1001. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7988321].
Phillips D.I, Barker D.J, Hales C.N, Hirst S, Osmond C. Thinness at birth and insulin resistance in adult life. Diabetologia. 1994;37:150-154. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8163048].
Piatti P, Di Mario C, Monti L.D, Fragasso G, Sgura F, Caumo A, Setola E, Lucotti P, Galluccio E, Ronchi C, Origgi A, Zavaroni I, Margonato A, Colombo A. Association of insulin resistance, hyperleptinemia, and impaired nitric oxide release with in-stent restenosis in patients undergoing coronary stenting. Circulation. 2003;108:2074-2081. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14530196].
Piatti P.M, Monti L.D, Galli L, Fragasso G, Valsecchi G, Conti M, Gernone F, Pontiroli A.E. Relationship between endothelin-1 concentration and metabolic alterations typical of the insulin resistance syndrome. Metabolism. 2000;49:748-752. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10877200].
Piatti P.M, Monti L.D, Zavaroni I, Valsecchi G, Van Phan C, Costa S, Conti M, Sandoli E.P, Solerte B, Pozza G, Pontiroli A.E, Reaven G. Alterations in nitric oxide/cyclic-GMP pathway in nondiabetic siblings of patients with type 2 diabetes. J Clin Endocrinol Metab. 2000;85:2416-2420. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10902787].
Pietropaolo M, Barinas-Mitchell E, Pietropaolo S.L, Kuller L.H, Trucco M. Evidence of islet cell autoimmunity in elderly patients with type 2 diabetes. Diabetes. 2000;49:32-38. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10615947].
Piette J.D, Weinberger M, Kraemer F.B, McPhee S.J. Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a Department of Veterans Affairs health care system: A randomized controlled trial. Diabetes Care. 2001;24:202-208. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11213866].
Pietzsch, J., Julius, U., and Hanefeld, M. Metabolic basis of low high density lipoprotein in subjects with impaired glucose tolerance. Ann N Y Acad Sci 1999; 892-326. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design
Piva I, Erle G, Thiella M, Lora L, Strazzabosco M, Sicolo N, Federspil G. A study on the hyperinsulinism of late pregnancy. J Endocrinol Invest. 1991;14:807-814. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1802920].
Poinoosawmy D, Gloster J, Nagasubramanian S, Hitchings R.A. Association between optic disc haemorrhages in glaucoma and abnormal glucose tolerance. Br J Ophthalmol. 1986;70:599-602. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3741826]. [pmcid: 1040780].
Poirier L, Cleroux J, Nadeau A, Lacourciere Y. Effects of nebivolol and atenolol on insulin sensitivity and haemodynamics in hypertensive patients. J Hypertens. 2001;19:1429-1435. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 11518851].
Pokela M.L. Effect of opioid-induced analgesia on beta-endorphin, cortisol and glucose responses in neonates with cardiorespiratory problems. Biol Neonate. 1993;64:360-367. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8286562].
Polyzogopoulou E.V, Kalfarentzos F, Vagenakis A.G, Alexandrides T.K. Restoration of euglycemia and normal acute insulin response to glucose in obese subjects with type 2 diabetes following bariatric surgery. Diabetes. 2003;52:1098-1103. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 12716738].
Pontiroli A.E, Perfetti M.G, Pozza G. Acute effect of glipizide on glucose tolerance in obesity and diabetes mellitus (NIDDM). Eur J Clin Pharmacol. 1991;40:23-26. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 2060541].
Pontiroli A.E, Perfetti M.G, Pozza G. Improvement of glucose tolerance by minimal doses of glipizide in obese subjects with different degrees of glucose intolerance. Horm Metab Res Suppl. 1992;26:32-34. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 1490690].
Pontiroli A.E, Galli L. Duration of obesity is a risk factor far non-insulin dependent diabetes mellitus, not for arterial hypertension or for hyperlipidaemia. Acta Diabetol. 1998;35:130-136. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9840448].
Pontiroli A.E, Pizzocri P, Librenti M.C, Vedani P, Marchi M, Cucchi E, Orena C, Paganelli M, Giacomelli M, Ferla G, Folli F. Laparoscopic adjustable gastric banding for the treatment of morbid (grade 3) obesity and its metabolic complications: a three-year study. J Clin Endocrinol Metab. 2002;87:3555-3561. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12161474].
Pontrelli L, Parris W, Adeli K, Cheung R.C. Atorvastatin treatment beneficially alters the lipoprotein profile and increases low-density lipoprotein particle diameter in patients with combined dyslipidemia and impaired fasting glucose/type 2 diabetes. Metabolism. 2002;51:334-342. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11887170].
Pories W.J, MacDonald K.G Jr, Morgan E.J, Sinha M.K, Dohm G.L, Swanson M.S, Barakat H.A, Khazanie P.G, Leggett-Frazier N, Long S.D. Surgical treatment of obesity and its effect on diabetes: 10-y follow-up. Am J Clin Nutr. 1992;55:582S-585S. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1733132].
Poulton J, Brown M.S, Cooper A, Marchington D.R, Phillips D.I. A common mitochondrial DNA variant is associated with insulin resistance in adult life. Diabetologia. 1998;41:54-58. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9498630].
Power M.J, Fullerton K.J, Stout R.W. Blood glucose and prognosis of acute stroke. Age & Ageing. 1988;17:164-170. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3389245].
Poykko S, Ukkola O, Kauma H, Savolainen M.J, Kesaniemi Y.A. Ghrelin Arg51Gln mutation is a risk factor for Type 2 diabetes and hypertension in a random sample of middle-aged subjects. Diabetologia. 2003;46:455-458. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 12739020].
Premalatha G, Shanthirani S, Deepa R, Markovitz J, Mohan V. Prevalence and risk factors of peripheral vascular disease in a selected South Indian population: the Chennai Urban Population Study. Diabetes Care. 2000;23:1295-1300. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10977021].
Prince M.J, Deeg M.A. Do n-3 fatty acids improve glucose tolerance and lipemia in diabetics?. Current Opinion in Lipidology. 1997;8:7-11. Status: Not included because article does not describe a study or survey. [pmid: 9127704].
Proctor C.A. Abnormal insulin levels and vertigo. Laryngoscope. 1981;91:1657-1662. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7026944].
Pyorala M, Miettinen H, Laakso M, Pyorala K. Hyperinsulinemia predicts coronary heart disease risk in healthy middle- aged men: The 22-year follow-up results of the Helsinki Policemen Study. Circulation. 1998;98:398-404. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9714089].
Qi S, Xu D, Peng J, Vu M.D, Wu J, Bekersky I, Fitzsimmons W.E, Peets J, Sehgal S, Daloze P, Chen H. Effect of tacrolimus (FK506) and sirolimus (rapamycin) mono- and combination therapy in prolongation of renal allograft survival in the monkey. Transplantation. 2000;69:1275-1283. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10798741].
Qiao Q, Keinanen Kukaanniemi S, Kivela S.L. Haemoglobin A(1c) measurement for diabetes among subjects with a previous history of impaired glucose tolerance. Diabetes Res Clin Pract. 1995;30:189-194. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8861458].
Qiao Q, Keinanen-Kiukaanniemi S, Rajala U, Uusimaki A, Kivela S.-L. Risk for diabetes and persistent impaired glucose tolerance among middle-aged Finns. Diabetes Res Clin Pract. 1996;33:191-198. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8922541].
Qiao Q, Rajala U, Keinanen-Kiukaanniemi S. Hypertension, hyperinsulinaemia and obesity in middle-aged Finns with impaired glucose tolerance. J Hum Hypertens. 1998;12:265-269. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9607697].
Qiao Q, Larsen S, Borch-Johnsen K, Nissinen A, Pekkanen J, Tuomilehto J, Jousilahti P, Lindstrom J, Pyorala M, Pyorala K, Balkau B, Eschwege E, Gallus G, Garancini M.P, Bouter L.M, Dekker J.M, Heine R.J, Nijpels G, Stehouwer C.D.A, Feskens E.J.M, Kromhout D, Peltonen M, Pajak A, Eriksson J. Glucose tolerance and cardiovascular mortality. Comparison of fasting and 2-hour diagnostic criteria. Arch Intern Med. 2001;161:397-405. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11176766].
Qiao Q, Tuomilehto J. Diagnostic criteria of glucose intolerance and mortality. Minerva Medica. 2001;92:113-119. Status: Not included because article does not describe a study or survey. [pmid: 11323573].
Qiao Q, Pyorala K, Pyorala M, Nissinen A, Lindstrom J, Tilvis R, Tuomilehto J. Two-hour glucose is a better risk predictor for incident coronary heart disease and cardiovascular mortality than fasting glucose.[see comment]. Eur Heart J. 2002;23:1267-1275. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12175663].
Qiao Q, Lindstrom J, Valle T.T, Tuomilehto J. Progression to clinically diagnosed and treated diabetes from impaired glucose tolerance and impaired fasting glycaemia. Diabet Med. 2003;20:1027-1033. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14632705].
Qiao Q, Jousilahti P, Eriksson J, Tuomilehto J. Predictive properties of impaired glucose tolerance for cardiovascular risk are not explained by the development of overt diabetes during follow-up. Diabetes Care. 2003;26:2910-2914. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514600].
Quatraro A, Giugliano D, De Rosa N, Minei A, Ettorre M, Donzella C, Saccomanno F, Ceriello A. Is a family history of diabetes associated with an increased level of cardiovascular risk factors? Studies in healthy people and in subjects with different degree of glucose intolerance. Diabete Metab. 1993;19:230-238. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8339854].
Quinn L. Glucose monitoring in the acutely III patient with diabetes mellitus. Critical Care Nursing Quarterly. 1998;21:85-96. Status: Not included because article does not describe a study or survey. [pmid: 10646424].
Racette S.B, Kohrt W.M, Landt M, Holloszy J.O. Response to serum leptin concentrations to 7 d of energy restriction in centrally obese African Americans with impaired or diabetic glucose tolerance. Am J Clin Nutr. 1997;66:33-37. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9209166].
Rado J.P, Banos C, Gercsak G, Molnar Z, Pato E, Csabuda M. Glucose-induced hyperkalemia developing in the upright position in captopril-treated hypertensives. Research Communications in Chemical Pathology & Pharmacology. 1982;38:161-164. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6755590].
Rahman Al-Nuaim A. High prevalence of metabolic risk factors for cardiovascular diseases among Saudi population, aged 30–64 years. Int J Cardiol. 1997;62:227-235. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9476683].
Raikkonen K, Matthews K.A, Kuller L.H. The relationship between psychological risk attributes and the metabolic syndrome in healthy women: Antecedent or consequence?. Metabolism. 2002;51:1573-1577. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12489070].
Rajala U, Laakso M, Qiao Q, Keinanen-Kiukaanniemi S. Prevalence of retinopathy in people with diabetes, impaired glucose tolerance, and normal glucose tolerance. Diabetes Care. 1998;21:1664-1669. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9773727].
Rajala U, Qiao Q, Laakso M, Keinanen-Kiukaanniemi S. Antihypertensive drugs as predictors of type 2 diabetes among subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2000;50:231-239. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11106838].
Rakotoambinina B, Delaisi B, Laborde K, Silly C, De Blic J, Lenoir G, Robert J.-J. Insulin responses to intravenous glucose and the hyperglycemic clamp in cystic fibrosis patients with different degrees of glucose tolerance. Pediatr Res. 1994;36:667-671. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 7877889].
Rakotoambinina B, Timsit J, Deschamps I, Laborde K, Gautier D, Jos J, Boitard C, Robert J.J. Insulin responses to intravenous glucose, intravenous arginine and a hyperglycaemic clamp in ICA-positive subjects with different degrees of glucose tolerance. Diabetes Metab. 1997;23:43-50. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 9059765].
Ramachandran A, Mohan V, Snehalatha M.C, Chinnikrishnudu M, Viswanathan M. Use of metformin in selected cases of NIDDM. A clinical trial. Journal of the Diabetic Association of India. 1988;28:137-139. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Ramachandran A, Snehalatha C, Shyamala P, Vijay V, Viswanathan M. High prevalence of NIDDM and IGT in an elderly south Indian population with low rates of obesity. Diabetes Care. 1994;17:1190-1192. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7821141].
Ramachandran A, Snehalatha C, Satyavani K, Vijay V. Effects of genetic predisposition on proinsulin responses in Asian Indians. Diabetes Res Clin Pract. 1998;41:71-77. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9768375].
Ramachandran A, Snehalatha C, Shobana R, Vidyavathi P, Vijay V. Influence of life style factors in development of diabetes in Indians--scope for primary prevention.[see comment]. J Assoc Physicians India. 1999;47:764-766. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10778617].
Ramaiya K.L, Swai A.B, McLarty D.G, Alberti K.G. Improvement in glucose tolerance after one year of follow-up in a Hindu community in Africa. Diabetes Res Clin Pract. 1990;10:245-255. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2073872].
Ramaiya K.L, Swai A.B, McLarty D.G, Bhopal R.S, Alberti K.G. Prevalences of diabetes and cardiovascular disease risk factors in Hindu Indian subcommunities in Tanzania. BMJ. 1991;303:271-276. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1888926]. [pmcid: 1670456].
Rao C.A, Snehalatha C. Hyper insulinism and decreased insulin sensitivity in nonobese healthy offspring of conjugal diabetic parents and individuals with IGT and NIDDM. Indian J Physiol Pharmacol. 1996;40:139-144. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9062808].
Rathmann W, Haastert B, Icks A, Lowel H, Meisinger C, Holle R, Giani G. High prevalence of undiagnosed diabetes mellitus in Southern Germany: target populations for efficient screening. The KORA survey 2000. Diabetologia. 2003;46:182-189. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12627316].
Ratzman K-P, Strese J, Rjasanowski I. Prevalence of islet cell antibodies (ICA) and islet cell surface antibodies (ICSA) in children and adolescents with antecedent mumps infection. Exp Clin Endocrinol. 1984;83:199-202. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 6539220].
Ratzmann K.P, Witt S, Ziegler M, Schulz B. Changes in carbohydrate tolerance and early insulin response to glucose in potential diabetics: a follow-up study of 2--4 years. Endokrinologie. 1980;75:89-97. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6989593].
Ratzmann K.P, Besch W, Witt S, Schulz B. Evaluation of insulin resistance during inhibition of endogenous insulin and glucagon secretion by somatostatin in non-obese subjects with impaired glucose tolerance. Diabetologia. 1981;21:192-197. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6117492].
Ratzmann K.P, Besch W, Witt S, Schulz B. Discrepant effect of the prostaglandin synthesis inhibitor acetylsalicylic acid on insulin and C-peptide response to glucose in man. Horm Metab Res. 1982;14:508-512. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6757082].
Ratzmann K.P, Witt S, Schulz B. The effect of long-term glibenclamide treatment on glucose tolerance, insulin secretion and serum lipids in subjects with impaired glucose tolerance. Diabete Metab. 1983;9:87-93. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6413265].
Ratzmann M.L, Rjasanowski I, Bruns W, Ratzmann K.P. Effects of clofibrate therapy on glucose tolerance, insulin secretion and serum lipids in subjects with hyperlipoproteinemia and impaired glucose tolerance. A follow-up study over a five-year period. Exp Clin Endocrinol. 1983;82:216-221. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6354731].
Rau H, Althoff P-H, Schmidt K, Badenhoop K, Usadel K.H. Bromocriptine treatment over 12 years in acromegaly: Effect on glucose tolerance and insulin secretion. Clin Investig. 1993;71:372-378. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Ravelli A.C.J, van der Meulen J.H.P, Michels R.P.J, Osmond C, Barker D.J.P, Hales C.N, Bleker O.P. Glucose tolerance in adults after prenatal exposure to famine. Lancet. 1998;351:173-177. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9449872].
Reaven G.M, Hollenbeck C.B, Chen Y.-D. Relationship between glucose tolerance, insulin secretion, and insulin action in non-obese individuals with varying degrees of glucose tolerance. Diabetologia. 1989;32:52-55. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 2651188].
Regensteiner J.G, Shetterly S.M, Mayer E.J, Eckel R.H, Haskell W.L, Baxter J, Hamman R.F. Relationship between habitual physical activity and insulin area among individuals with impaired glucose tolerance. Diabetes Care. 1995;18:490-497. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 7497858].
Reiser S, Bohn E, Hallfrisch J, Michaelis O.E, Keeney M, Prather E.S. Serum insulin and glucose in hyperinsulinemic subjects fed three different levels of sucrose. Am J Clin Nutr. 1981;34:2348-2358. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7030048].
Resnick H.E, Shorr R.I, Kuller L, Franse L, Harris T.B. Prevalence and clinical implications of American Diabetes Association-defined diabetes and other categories of glucose dysregulation in older adults: the health, aging and body composition study. J Clin Epidemiol. 2001;54:869-876. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11520645].
Reynolds R.M, Walker B.R, Syddall H.E, Whorwood C.B, Wood P.J, Phillips D.I. Elevated plasma cortisol in glucose-intolerant men: differences in responses to glucose and habituation to venepuncture. J Clin Endocrinol Metab. 2001;86:1149-1153. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11238500].
Riales R, Albrink M.J. Effect of chromium chloride supplementation on glucose tolerance and serum lipids including high-density lipoprotein of adult men. Am J Clin Nutr. 1981;34:2670-2678. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7032273].
Ribstein J, Du Cailar G, Mimran A. Glucose tolerance and age-associated decline in renal function of hypertensive patients. J Hypertens. 2001;19:2257-2264. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11725171].
Riccardi G, Vaccaro O, Rivellese A, Pignalosa S, Tutino L, Mancini M. Reproducibility of the new diagnostic criteria for impaired glucose tolerance. Am J Epidemiol. 1985;121:422-429. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4014132].
Riggio O, Merli M, Cangiano C. Glucose intolerance in liver cirrhosis. Metabolism. 1982;31:627-634. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7043186].
Riley W.J, Maclaren N.K, Spillar R.S. Reversal of deteriorating glucose tolerance with azathioprine in prediabetics. Transplant Proc. 1986;18:819-822. Status: Not included because article does not describe a study or survey.
Ritenbaugh C, Teufel-Shone N.I, Aickin M.G, Joe J.R, Poirier S, Dillingham D.C, Johnson D, Henning S, Cole S.M, Cockerham D. A lifestyle intervention improves plasma insulin levels among Native American high school youth. Prev Med. 2003;36:309-319. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12634022].
Rjasanowski I, Michaelis D, Besch W, Keilacker H, Ziegler B, Hildmann W. Glucose tolerance behaviour before the onset of type I (insulin-dependent) diabetes in young people as a predictor of the further course of the disease: a retrospective analysis of 33 cases. Diabetes Res Clin Pract. 1991;11:107-115. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2022175].
Roberts R.N, Henriksen J.E, Hadden D.R. Insulin sensitivity in pre-eclampsia. Br J Obstet Gynaecol. 1998;105:1095-1100. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9800933].
Roberts W.L, De B.K, Brown D, Hanbury C.M, Hoyer J.D, John W.G, Lambert T.L, Lundell R.B, Rohlfing C, Little R.R. Effects of hemoglobin C and S traits on eight glycohemoglobin methods. Clin Chem. 2002;48:383-385. Status: Not included because article does not describe a study or survey. [pmid: 11805029].
Rodriguez-Villar C, Conget I, Casamitjana R, Ercilla G, Gomis R. Effects of insulin administration in a group of high-risk, non-diabetic, first-degree relatives of Type 1 diabetic patients: an open pilot trial. Diabet Med. 1999;16:160-163. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10229311].
Rodriguez B.L, Lau N, Burchfiel C.M, Abbott R.D, Sharp D.S, Yano K, Curb J.D. Glucose intolerance and 23-year risk of coronary heart disease and total mortality: the Honolulu Heart Program. Diabetes Care. 1999;22:1262-1265. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10480768].
Rogers M.A, Yamamoto C, King D.S, Hagberg J.M, Ehsani A.A, Holloszy J.O. Improvement in glucose tolerance after 1 wk of exercise in patients with mild NIDDM. Diabetes Care. 1988;11:613-618. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3065001].
Rolandsson O, Hagg E, Nilsson M, Hallmans G, Mincheva-Nilsson L, Lernmark A. Prediction of diabetes with body mass index, oral glucose tolerance test and islet cell autoantibodies in a regional population. J Intern Med. 2001;249:279-288. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11298847].
Rolny P, Jagenburg R. Exocrine pancreatic function, fecal fat, and blood glucose in patients with pancreatitis. Scand J Gastroenterol. 1980;15:727-732. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7209383].
Ronchi C, Epaminonda P, Cappiello V, Beck-Peccoz P, Arosio M. Effects of two different somatostatin analogs on glucose tolerance in acromegaly. J Endocrinol Invest. 2002;25:502-507. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12109620].
Rosenbaum M, Hirsch J, Murphy E, Leibel R.L. Effects of changes in body weight on carbohydrate metabolism, catecholamine excretion, and thyroid function. Am J Clin Nutr. 2000;71:1421-1432. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10837281].
Rosenbloom A.L, Hunt S.S, Rosenbloom E.K, Maclaren N.K. Ten-year prognosis of impaired glucose tolerance in siblings of patients with insulin-dependent diabetes. Diabetes. 1982;31:385-387. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6759254].
Rosenfalck A.M, Hendel H, Rasmussen M.H, Almdal T, Anderson T, Hilsted J, Madsbad S. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4:19-28. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11890163].
Rowe B.R, Barnett A.H. Pre-conception counselling in Asian women with non insulin dependent diabetes and impaired glucose tolerance. Diabetes Research. 1988;8:35-38. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3224493].
Rubin R.R, Fujimoto W.Y, Marrero D.G, Brenneman T, Charleston J.B, Edelstein S.L, Fisher E.B, Jordan R, Knowler W.C, Lichterman L.C, Prince M, Rowe P.M. The Diabetes Prevention Program: recruitment methods and results. Control Clin Trials. 2002;23:157-171. Status: Not included because article does not describe a study or survey. [pmid: 11943442].
Ruderman N, Chisholm D, Pi-Sunyer X, Schneider S. The metabolically obese, normal-weight individual revisited. Diabetes. 1998;47:699-713. Status: Not included because article does not describe a study or survey. [pmid: 9588440].
Ruige J.B, Batstra M.R, Aanstoot H.J, Bouter L.M, Bruining G.J, De Neeling J.N, Heine R.J. Low prevalence of antibodies to GAD65 in a 50- to 74-year-old general Dutch population. The Hoorn Study. Diabetes Care. 1997;20:1108-1110. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9203445].
Ruige J.B, De Neeling J.N.D, Kostense P.J, Bouter L.M, Heine R.J. Performance of an NIDDM screening questionnaire based on symptoms and risk factors. Diabetes Care. 1997;20:491-496. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9096967].
Russell-briefel R, Ezzati T.M, Perlman J.A, Murphy R.S. Impaired glucose tolerance in women using oral contraceptives: United States, 1976-1980. J Chronic Dis. 1987;40:3-11. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3805231].
Rutter M.K, Parise H, Benjamin E.J, Levy D, Larson M.G, Meigs J.B, Nesto R.W, Wilson P.W.F, Vasan R.S. Impact of Glucose Intolerance and Insulin Resistance on Cardiac Structure and Function. Circulation. 2003;107:448-454. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12551870].
Ruzsa C, Fiegler M, Nagy L. Effect of indomethacin on glucose absorption and insulin release in patients with impaired glucose tolerance. Int J Clin Pharmacol Res. 1986;6:87-91. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 3522445].
Ryle A.J, Davie S, Gould B.J, Yudkin J.S. A study of the effect of diet on glycosylated haemoglobin and albumin levels and glucose tolerance in normal subjects. Diabet Med. 1990;7:865-870. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1963125].
Sacks D.B. Implications of the revised criteria for diagnosis and classification of diabetes mellitus. Clin Chem. 1997;43:2230-2232. Status: Not included because article does not describe a study or survey. [pmid: 9439437].
Sacks F.M. Dyslipidemia, prediabetes, and type 2 diabetes: clinical implications of the VA-HIT subanalysis. Advanced Studies in Medicine. 2003;3:S228-S233. Status: Not included because article does not describe a study or survey.
Saikawa T, Arita M, Yamaguchi K, Ito M. Hypoglycemic effect of cibenzoline in patients with abnormal glucose tolerance and frequent ventricular arrhythmias. Cardiovascular Drugs & Therapy. 2000;14:665-669. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11300368].
Salemans T.H, Dieijen-Visser M.P, Brombacher P.J. The value of HbA1 and fructosamine in predicting impaired glucose tolerance--an alternative to OGTT to detect diabetes mellitus or gestational diabetes. ANN CLIN BIOCHEM. 1987;24:447-452. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3662394].
Salobir B, Prezelj J, Kocijancic A, Meden-Vrtovec H. Basal glucose level as an independent predictor of fertilization rate in patients without polycystic ovary syndrome included in an in-vitro fertilization program. Wien Klin Wochenschr. 2002;114:454-457. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12422580].
Salomaa V.V, Strandberg T.E, Vanhanen H, Naukkarinen V, Sarna S, Miettinen T.A. Glucose tolerance and blood pressure: long term follow up in middle aged men [published erratum appears in BMJ 1991 Apr 20;302(6782):939]. BMJ. 1991;302:493-496. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2012844]. [pmcid: 1669625].
Salomaa V.V, Tuomilehto J, Jauhiainen M, Korhonen H.J, Stengard J, Uusitupa M, Pitkanen M, Penttila I. Hypertriglyceridemia in different degrees of glucose intolerance in a Finnish population-based study. Diabetes Care. 1992;15:657-665. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1516486].
Saloranta C, Guitard C, Pecher E, Pablos-Velasco P, Lahti K, Brunel P, Groop L. Nateglinide improves early insulin secretion and controls postprandial glucose excursions in a prediabetic population. Diabetes Care. 2002;25:2141-2146. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12453951].
Sandhu M.S, Heald A.H, Gibson J.M, Cruickshank J.K, Dunger D.B, Wareham N.J. Circulating concentrations of insulin-like growth factor-I and development of glucose intolerance: a prospective observational study. Lancet. 2002;359:1740-1745. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12049864].
Sane T, Taskinen M.R. Does familial hypertriglyceridemia predispose to NIDDM?. Diabetes Care. 1993;16:1494-1501. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8299439].
Sann L, Morel Y, Lasne Y. Effect of hydrocortisone on intravenous glucose tolerance in small-for-gestational-age infants. Helv Paediatr Acta. 1983;38:475-482. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6365846].
Santer R, Hillebrand G, Steinmann B, Schaub J. Intestinal glucose transport: Evidence for a membrane traffic-based pathway in humans. Gastroenterology. 2003;124:34-39. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12512027].
Santomauro A.T, Boden G, Silva M.E, Rocha D.M, Santos R.F, Ursich M.J, Strassmann P.G, Wajchenberg B.L. Overnight lowering of free fatty acids with Acipimox improves insulin resistance and glucose tolerance in obese diabetic and nondiabetic subjects. Diabetes. 1999;48:1836-1841. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10480616].
Sarioglu B, Ozerkan E, Can S, Yaprak I, Topcuoglu R. Insulin secretion and insulin resistance determined by euglycemic clamp. J Pediatr Endocrinol Metab. 1998;11:27-33. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9642626].
Sarkkinen E, Schwab U, Niskanen L, Hannuksela M, Savolainen M, Kervinen K, Kesaniemi A, Uusitupa M.I. The effects of monounsaturated-fat enriched diet and polyunsaturated-fat enriched diet on lipid and glucose metabolism in subjects with impaired glucose tolerance. Eur J Clin Nutr. 1996;50:592-598. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 8880038].
Sartor G, Schersten B, Carlstrom S, Melander A, Norden A, Persson G. Ten-year follow-up of subjects with impaired glucose tolerance: prevention of diabetes by tolbutamide and diet regulation. Diabetes. 1980;29:41-49. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7380107].
Sas T, Muinck Keizer-Schrama S, Aanstoot H.J, Stijnen T, Drop S. Carbohydrate metabolism during growth hormone treatment and after discontinuation of growth hormone treatment in girls with Turner syndrome treated with once or twice daily growth hormone injections. Clin Endocrinol (Oxf). 2000;52:741-747. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10848879].
Sas T, Mulder P, Aanstoot H.J, Houdijk M, Jansen M, Reeser M, Hokken-Koelega A. Carbohydrate metabolism during long-term growth hormone treatment in children with short stature born small for gestational age. Clin Endocrinol (Oxf). 2001;54:243-251. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11207640].
Sas T.C, de Muinck Keizer-Schrama S.M, Stijnen T, Aanstoot H.J, Drop S.L. Carbohydrate metabolism during long-term growth hormone (GH) treatment and after discontinuation of GH treatment in girls with Turner syndrome participating in a randomized dose-response study. Dutch Advisory Group on Growth Hormone. J Clin Endocrinol Metab. 2000;85:769-775. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10690889].
Sasaki A, Suzuki T, Horiuchi N. Development of diabetes in Japanese subjects with impaired glucose tolerance: a seven year follow-up study. Diabetologia. 1982;22:154-157. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7075915].
Sasaki S, Kuwahara N, Kunitomo K, Harada S, Yamada T, Azuma A, Takeda K, Nakagawa M. Effects of atorvastatin on oxidized low-density lipoprotein, low-density lipoprotein subfraction distribution, and remnant lipoprotein in patients with mixed hyperlipoproteinemia. Am J Cardiol. 2002;89:386-389. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11835916].
Sasaki T.M, Gray R.S, Ratner R.E, Currier C, Aquino A, Barhyte D.Y, Light J.A. Successful long-term kidney-pancreas transplants in diabetic patients with high C-peptide levels. Transplantation. 1998;65:1510-1512. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9645815].
Saukkonen T, Vaisanen S, Akerblom H.K, Savilahti E, Tuomilehto J, Lounamaa R, Toivanen L, Kaprio E.A, Virtala E, Pitkaniemi J, Fagerlund A, Flittner M, Gustafsson B, Haggqvist C, Hakulinen A, Herva L, Hiltunen P, Huhtamaki T, Huttunen N-P, Huupponen T, Hyttinen M, Joki T, Jokisalo R, Kaar M-L, Kallio S, Kaprio E.A, Kaski U, Knip M, Laine L, Lappalainen J, Maenpaa J, Makela A-L, Niemi K, Niiranen A, Ojajarvi P, Otonkoski T, Pihlajamaki K, Pontynen S, Rajantie J, Sankala J, Schumacher J, Sillanpaa M, Stahlberg M-R, Strahlmann C-H, Uotila T, Vare M, Varimo P, Aro A, Hiltunen M, Hurme H, Hyoty H, Ilonen J, Karjalainen J, Knip M, Leinikki P, Miettinen A, Petays T, Reijonen H, Rasanen L, Reunanen A, Saukkonen T, Savilahti E, Tuomilehto-Wolf E, Vahasalo P, Virtanen S.M. Coeliac disease in children and adolescents with type 1 diabetes: A study of growth, glycaemic control, and experiences of families. Acta Paediatr. 2002;91:297-302. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12022302].
Sayeed M.A, Banu A, Malek M.A, Khan A.K. Blood pressure and coronary heart disease in NIDDM subjects at diagnosis: prevalence and risks in a Bangladeshi population. Diabetes Res Clin Pract. 1998;39:147-155. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9597385].
Schaefer-Graf U.M, Kjos S.L, Kilavuz O, Plagemann A, Brauer M, Dudenhausen J.W, Vetter K. Determinants of fetal growth at different periods of pregnancies complicated by gestational diabetes mellitus or impaired glucose tolerance.[erratum appears in Diabetes Care. 2003 Apr;26(4):1329]. Diabetes Care. 2003;26:193-198. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12502680].
Schafer-Graf U.M, Dupak J, Vogel M, Dudenhausen J.W, Kjos S.L, Buchanan T.A, Vetter K. Hyperinsulinism, neonatal obesity and placental immaturity in infants born to women with one abnormal glucose tolerance test value. J Perinat Med. 1998;26:27-36. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9595364].
Scheen A.J, Letiexhe M.R, Lefebvre P.J. Short administration of metformin improves insulin sensitivity in android obese subjects with impaired glucose tolerance. Diabet Med. 1995;12:985-989. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 8582131].
Scheen A.J, Ernest P. New antiobesity agents in type 2 diabetes: overview of clinical trials with sibutramine and orlistat. [Review] [91 refs]. Diabetes Metab. 2002;28:437-445. Status: Not included because article does not describe a study or survey. [pmid: 12522323].
Scheidt-Nave C, Barrett-Connor E, Wingard D.L, Cohn B.A, Edelstein S.L. Sex differences in fasting glycemia as a risk factor for ischemic heart disease death. Am J Epidemiol. 1991;133:565-576. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2006643].
Schmader K.E. Epidemiology and impact on quality of life of postherpetic neuralgia and painful diabetic neuropathy. Clinical Journal of Pain. 2002;18:350-354. Status: Not included because article does not describe a study or survey. [pmid: 12441828].
Schmid S, Molteni A, Fuchtenbusch M, Naserke H.E, Ziegler A.-G, Bonifacio E. Reduced IL-4 associated antibody responses to vaccine in early pre-diabetes. Diabetologia. 2002;45:677-685. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12107748].
Schoen R.E, Tangen C.M, Kuller L.H, Burke G.L, Cushman M, Tracy R.P, Dobs A, Savage P.J. Increased blood glucose and insulin, body size, and incident colorectal cancer. J Natl Cancer Inst. 1999;19:1147-1154. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Schranz A, Tuomilehto J, Marti B, Jarrett R.J, Grabauskas V, Vassallo A. Low physical activity and worsening of glucose tolerance: results from a 2-year follow-up of a population sample in Malta. Diabetes Res Clin Pract. 1991;11:127-136. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2022178].
Schranz A.G, Savona-Ventura C. Long-term significance of gestational carbohydrate intolerance: a longitudinal study. Experimental & Clinical Endocrinology & Diabetes. 2002;110:219-222. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12148085].
Schultz-Larsen K, Avlund K, Kreiner S. Functional ability of community dwelling elderly. Criterion-related validity of a new measure of functional ability. J Clin Epidemiol. 1992;45:1315-1326. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1432011].
Schultz Susan K, Arndt Stephan, Ho Beng Choon, Oliver Susan E, Andreasen Nancy C. Impaired glucose tolerance and abnormal movements in patients with schizophrenia. American-Journal-of-Psychiatry. 1999;156:640-642. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10200749].
Schulz B, Ratzmann K.P, Heinke P, Besch W. A stimulatory effect of tolbutamide on the insulin-mediated glucose uptake in subjects with impaired glucose tolerance (IGT). Exp Clin Endocrinol. 1983;82:222-231. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6354732].
Schulz B, Witt S, Hildmann W, Ratzmann K.P, Strese J, Keilacker H. Islet cell antibodies in individuals at increased risk for IDDM. Exp Clin Endocrinol. 1984;83:192-198. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 6373322].
Schulz L.O, Weidensee R.C. Glucose tolerance and physical activity in a Mexican indigenous population. Diabetes Care. 1995;18:1274-1276. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8612443].
Schutz Y, Golay A, Felber J.P, Jequier E. Decreased glucose-induced thermogenesis after weight loss in obese subjects: a predisposing factor for relapse of obesity?. Am J Clin Nutr. 1984;39:380-387. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6695838].
Schwab I.R, Dawson C.R, Hoshiwara I, Szuter C.F, Knowler W.C. Incidence of cataract extraction in Pima Indians. Diabetes as a risk factor. Arch Ophthalmol. 1985;103:208-212. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 3883967].
Schwab U.S, Sarkkinen E.S, Lichtenstein A.H, Li Z, Ordovas J.M, Schaefer E.J, Uusitupa M.I. The effect of quality and amount of dietary fat on the susceptibility of low density lipoprotein to oxidation in subjects with impaired glucose tolerance. Eur J Clin Nutr. 1998;52:452-458. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 9683400].
Schwartz G.G, Il'yasova D, Ivanova A. Urinary cadmium, impaired fasting glucose, and diabetes in the NHANES III. Diabetes Care. 2003;26:468-470. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12547882].
Schwarz J-M, Mulligan K, Lee J, Lo J.C, Wen M, Noor M.A, Grunfeld C, Schambelan M. Effects of recombinant human growth hormone on hepatic lipid and carbohydrate metabolism in HIV-infected patients with fat accumulation. J Clin Endocrinol Metab. 2002;87:942-945. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11836345].
Scott, R. D., Kritz-Silverstein, D., Barrett-Connor, E., and Wiederholt, W. C. The association of non-insulin-dependent diabetes mellitus and cognitive function in an older cohort. Journal of the American Geriatrics Society 46(10):1217–22, 1998 Oct (39 ref) 1998; 1217–1222. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design
Seccia T.M, Vulpis V, Ricci S, Pirrelli A. The effects of nitrendipine on glucose tolerance and immunoreactive insulin levels in hypertensive patients. Current Therapeutic Research, Clinical & Experimental. 1994;55:1323-1334. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design.
Seibaek M, Sloth C, Vallebo L, Hansen T, Urhammer S.A, Burchardt H, Torp-Pedersen C, Pedersen O, Hildebrandt P. Glucose tolerance status and severity of coronary artery disease in men referred to coronary arteriography. Am Heart J. 1997;133:622-629. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9200389].
Sermer M, Naylor C.D, Gare D.J, Kenshole A.B, Ritchie J.W, Farine D, Cohen H.R, McArthur K, Holzapfel S, Biringer A. Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. Am J Obstet Gynecol. 1995;173:146-156. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7631672].
Shaten B.J, Smith G.D, Kuller L.H, Neaton J.D. Risk factors for the development of type II diabetes among men enrolled in the usual care group of the Multiple Risk Factor Intervention Trial. Diabetes Care. 1993;16:1331-1339. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8269790].
Shaw J.E, Hodge A.M, de Court Chitson P, Zimmet P.Z. Isolated post-challenge hyperglycaemia confirmed as a risk factor for mortality. Diabetologia. 1999;42:1050-1054. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10447514].
Shelgikar K.M, Naik S.S, Khopkar M, Bhat D.S, Raut K.N, Joglekar C.V, Gerard M.E, Yajnik C.S. Circulating lipids and cardiovascular risk in newly diagnosed non-insulin-dependent diabetic subjects in India. Diabet Med. 1997;14:757-761. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9300225].
Shetty A, Wilson S, Kuo P, Laurin J.L, Howell C.D, Johnson L, Allen E.M. Liver transplantation improves cirrhosis-associated impaired oral glucose tolerance. Transplantation. 2000;69:2451-2454. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10868659].
Shimizu H, Shouzu A, Nishikawa U, Omoto S, Hayakawa T, Miyake Y, Yonemoto T, Inada M. Serum concentration and renal handling of 1,5-anhydro-D-glucitol in patients with chronic renal failure. ANN CLIN BIOCHEM. 1999;36:749-754. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10586312].
Shimokata H, Muller D.C, Fleg J.L, Sorkin J, Ziemba A.W, Andres R. Age as independent determinant of glucose tolerance. Diabetes. 1991;40:44-51. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2015973].
Shinohara R, Ohta Y, Yamauchi M, Ishiguro I. Improved fluorometric enzymatic sorbitol assay in human blood. Clin Chim Acta. 1998;273:171-184. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9657347].
Shinozaki K, Suzuki M, Ikebuchi M, Takaki H, Hara Y, Tsushima M, Harano Y. Insulin resistance associated with compensatory hyperinsulinemia as an independent risk factor for vasospastic angina. Circulation. 1995;92:1749-1757. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 7671357].
Shinozaki K, Suzuki M, Ikebuchi M, Hirose J, Hara Y, Harano Y. Improvement of insulin sensitivity and dyslipidemia with a new a-glucosidase inhibitor, Voglibose, in nondiabetic hyperinsulinemic subjects. Metabolism. 1996;45:731-737. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 8637448].
Shinozaki K, Naritomi H, Shimizu T, Suzuki M, Ikebuchi M, Sawada T, Harano Y. Role of insulin resistance associated with compensatory hyperinsulinemia in ischemic stroke. Stroke. 1996;27:37-43. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8553400].
Shionoiri H, Miyakawa T, Takasaki I. Glucose tolerance during chronic captopril therapy in patients with essential hypertension. J Cardiovasc Pharmacol. 1987;9:160-164. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2435993].
Shionoiri H, Sugimoto K-I, Minamisawa K, Ueda S-I, Ebina T, Matsukawa T, Gotoh E, Ishii M. Glucose and lipid metabolism during long-term treatment with cilazapril in hypertensive patients with or without impaired glucose metabolism. J Cardiovasc Pharmacol. 1990;15:933-938. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1694916].
Shionoiri H, Gotoh E, Ito T, Hata T, Iwatsubo H, Takegawa K, Ogihara T, Mikami H, Ikegami H, Otsuka A. Long-term therapy with terazosin may improve glucose and lipid metabolism in hypertensives: a multicenter prospective study. Am J Med Sci. 1994;307(Suppl 1):S91-S95. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7908168].
Shionoiri H, Takasaki I, Naruse M, Nagamoti I, Himeno H, Ito T, Ohtomi S, Hata T, Shindo K, Mikami H. Effect of cilazapril therapy on glucose and lipid metabolism in patients with hypertension. Clin Ther. 1995;17:1126-1135. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8750404].
Shionoiri H, Ashino K, Yamanaka K, Shindo K, Hiroto S, Arita T. Effect of doxazosin therapy on glucose tolerance and lipid metabolism in hypertensive patients with impaired glucose tolerance. Clin Ther. 1997;19:527-536. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9220217].
Sicree R.A, Zimmet P.Z, King H, Coventry J.S. Weight change amongst Nauruans over 6.5 years: extent, and association with glucose intolerance. Diabetes Res Clin Pract. 1987;3:327-336. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3665732].
Sicree R.A, Zimmet P.Z, King H.O.M, Coventry J.S. Plasma insulin response among nauruans. Diabetes. 1987;36:179-185. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3542644].
Sievenpiper J.L, Jenkins D.J.A, Josse R.G, Leiter L.A, Vuksan V. Simple skinfold-thickness measurements complement conventional anthropometric assessments in predicting glucose tolerance. Am J Clin Nutr. 2001;73:567-573. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11237933].
Sigurdsson G, Gottskalksson G, Thorsteinsson T, Davidsson D, Olafsson O, Samuelsson S, Sigfusson N. Community screening for glucose intolerance in middle-aged Icelandic men. Deterioration to diabetes over a period of 71/2 years. Acta Medica Scandinavica. 1981;210:21-26. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7293824].
Silfverstolpe G, Gustafson A, Samsioe G, Svanborg A. Lipid metabolic studies in oophorectomised women: Effects on serum lipids and lipoproteins of three synthetic progestogens. Maturitas. 1982;4:103-111. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6811837].
Silverman B.L, Metzger B.E, Cho N.H, Loeb C.A. Impaired glucose tolerance in adolescent offspring of diabetic mothers: relationship to fetal hyperinsulinism. Diabetes Care. 1995;18:611-617. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8585997].
Silverman B.L, Rizzo T.A, Cho N.H, Metzger B.E. Long-term effects of the intrauterine environment. The Northwestern University Diabetes in Pregnancy Center. Diabetes Care. 1998;21(Suppl 2):B142-B149. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9704242].
Singh M.M, Biswas S.K, Shah A. Impaired glucose tolerance in active pulmonary tuberculosis. Indian Journal of Tuberculosis. 1984;31:118-121. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Singh R.B, Niaz M.A, Ghosh S. Effect on central obesity and associated distrubances of low-energy, fruit- and vegetable-enriched prudent diet in North Indians. Postgrad Med J. 1994;70:895-900. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7870637]. [pmcid: 2398005].
Singleton J.R, Smith A.G, Bromberg M.B. Painful sensory polyneuropathy associated with impaired glucose tolerance. Muscle & Nerve. 2001;24:1225-1228. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11494277].
Sinha R, Fisch G, Teague B, Tamborlane W.V, Banyas B, Allen K, Savoye M, Rieger V, Taksali S, Barbetta G, Sherwin R.S, Caprio S. Prevalence of impaired glucose tolerance among children and adolescents with marked obesity. N Engl J Med. 2002;346:802-810. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11893791].
Sirtori C.R, Paoletti R, Mancini M, Crepaldi G, Manzato E, Rivellese A, Pamparana F, Stragliotto E. n-3 Fatty acids do not lead to an increased diabetic risk in patients with hyperlipidemia and abnormal glucose tolerance. Am J Clin Nutr. 1997;65:1874-1881. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 9174486].
Sirtori C.R, Crepaldi G, Manzato E, Mancini M, Rivellese A, Paoletti R, Pazzucconi F, Pamparana F, Stragliotto E. One-year treatment with ethyl esters of n-3 fatty acids in patients with hypertriglyceridemia and glucose intolerance: reduced triglyceridemia, total cholesterol and increased HDL-C without glycemic alterations. Atherosclerosis. 1998;137:419-427. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9622285].
Skouby S.O, Molsted-Pedersen L, Kuhl C. Low dosage oral contraception in women with previous gestational diabetes. Obstet Gynecol. 1982;59:325-328. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6804901].
Slabber M, Barnard H.C, Kuyl J.M, Dannhauser A, Schall R. Effects of a low-insulin-response, energy-restricted diet on weight loss and plasma insulin concentrations in hyperinsulinemic obese females. Am J Clin Nutr. 1994;60:48-53. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8017337].
Slama G. The potential of metformin for diabetes prevention. Diabetes Metab. 2003;29:6S104-6S111. Status: Not included because article does not describe a study or survey. [pmid: 14502107].
Slama G. The potential of metformin for diabetes prevention. Diabetes Metab. 2003;29:104-111. Status: Not included because article does not describe a study or survey.
Smith A.G, Ramachandran P, Tripp S, Singleton J.R. Epidermal nerve innervation in impaired glucose tolerance and diabetes-associated neuropathy. Neurology. 2001;57:1701-1704. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11706115].
Smith G.D, Egger M, Shipley M.J, Marmot M.G. Post-challenge glucose concentration, impaired glucose tolerance, diabetes, and cancer mortality in men. Am J Epidemiol. 1992;136:1110-1114. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1462971].
Smith N.L, Savage P.J, Heckbert S.R, Barzilay J.I, Bittner V.A, Kuller L.H, Psaty B.M. Glucose, blood pressure, and lipid control in older people with and without diabetes mellitus: the Cardiovascular Health Study. J Am Geriatr Soc. 2002;50:416-423. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11943034].
Smith S.M, Davis-Street J.E, Fontenot T.B, Lane H.W. Assessment of a portable clinical blood analyzer during space flight. Clin Chem. 1997;43:1056-1065. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9191561].
Smutok M.A, Reece C, Kokkinos P.F, Farmer C.M, Dawson P.K, DeVane J, Patterson J, Goldberg A.P, Hurley B.F. Effects of exercise training modality on glucose tolerance in men with abnormal glucose regulation. Int J Sports Med. 1994;15:283-289. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7822064].
Snehalatha C, Ramachandran A, Satyavani K, Vijay V, Haffner S.M. Specific insulin and proinsulin concentrations in nondiabetic South Indians. Metabolism. 1998;47:230-233. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9472976].
Snehalatha C, Ramachandran A, Saltyamurthy I, Satyavani K, Sivasankari S, Misra J, Viswanathan V. Association of proinsulin and insulin resistance with coronary artery disease in non-diabetic south Indian men. Diabet Med. 2001;18:706-708. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11606167].
Snehalatha C, Vijay V, Suresh Mohan R, Satyavani K, Sivasankari S, Megha T, Radhika S, Ramachandran A. Lack of association of insulin resistance and carotid intimal medial thickness in non-diabetic Asian Indian subjects. Diabetes Metab Res Rev. 2001;17:444-447. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11757080].
Solano M.P, Perry A.C, Wang X, Ross R, Goldberg R.B. Insulin resistance but not visceral adipose tissue is associated with plasminogen activator inhibitor type 1 levels in overweight and obese premenopausal African-American women. Int J Obes. 2003;27:82-87. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Soliman A.T, Al Suwaid A.R, Gamil H, Asfour M. Prevalence and significance of acanthosis nigricans in children and adolescents. Annals of Saudi Medicine. 1996;16:424-428. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 17372496].
Solnica B, Naskalski J.W. Evaluation of analytical performance of Super G1, Super G2+ and Biosen 5030 glucose amperometric analyzers. Clinical Laboratory. 2003;49:233-238. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 15285179].
Solomon C.G, Graves S.W, Greene M.F, Seely E.W. Glucose intolerance as a predictor of hypertension in pregnancy. Hypertension. 1994;23:717-721. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8206568].
Solomon M.P, Wilson D.C, Corey M, Kalnins D, Zielenski J, Tsui L, Pencharz P, Durie P, Sweezey N.B. Glucose intolerance in children with cystic fibrosis. J Pediatr. 2003;142:128-132. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12584532].
Solymoss B.C, Bourassa M.G, Campeau L, Lesperance J, Marcil M, Varga S. Incidence, coronary risk profile and angiographic characteristics of prediabetic and diabetic patients in a population with ischemic heart disease. Canadian Journal of Cardiology. 2003;19:1155-1160. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 14532941].
Sosenko J.M, Kato M, Soto R, Goldberg R.B. Sensory function at diagnosis and in early stages of NIDDM in patients detected through screening [see comments]. Diabetes Care. 1992;15:847-852. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1516503].
Spiller H.A, Weber J.A, Winter M.L, Klein-Schwartz W, Hofman M, Gorman S.E, Stork C.M, Krenzelok E.P. Multicenter case series of pediatric metformin ingestion. Ann Pharmacother. 2000;34:1385-1388. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11144693].
Sprafka J.M, Xue S, Bushhouse S.A, French L.R, Martinez A.M, Goetz F.C. Cardiovascular disease risk factors and glucose tolerance: The Wadena City Health Study. Ann Epidemiol. 1992;2:647-656. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1342316].
Srinivasan S.R, Myers L, Berenson G.S. Predictability of childhood adiposity and insulin for developing insulin resistance syndrome (syndrome X) in young adulthood: The Bogalusa Heart Study. Diabetes. 2002;51:204-209. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11756342].
Steffen L.M, Jacobs D.R Jr, Murtaugh M.A, Moran A, Steinberger J, Hong C.P, Sinaiko A.R. Whole grain intake is associated with lower body mass and greater insulin sensitivity among adolescents. Am J Epidemiol. 2003;158:243-250. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12882946].
Steinmueller T, Konrad T, Jonas S, Tullius S, Bechstein W.O, Mueller A, Platz K.P, Neumann U, Vicini P, Toffolo G, Cobelli C, Usadel K.H, Neuhaus P. The effect of cyclosporine vs FK 506 on glucose metabolism. Transplant Proc. 1999;31:1129-1130. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10083504].
Stengard J.H, Tuomilehto J, Pekkanen J, Kivinen P, Kaarsalo E, Nissinen A, Karvonen M.J. Diabetes mellitus, impaired glucose tolerance and mortality among elderly men: the Finnish cohorts of the Seven Countries Study. Diabetologia. 1992;35:760-765. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1511803].
Stengard J.H, Pekkanen J, Tuomilehto J, Kivinen P, Kaarsalo E, Tamminen M, Nissinen A, Karvonen M.J. Changes in glucose tolerance among elderly Finnish men during a five-year follow-up: the Finnish cohorts of the Seven Countries Study. Diabete Metab. 1993;19:121-129. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8314414].
Stern M.P, Williams K, Haffner S.M. Identification of persons at high risk for type 2 diabetes mellitus: do we need the oral glucose tolerance test?. Annals of Internal Medicine. 2002;136:575-581. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11955025].
Stoddart M.L, Blevins K.S, Lee E.T, Wang W, Blackett P.R. Cherokee Diabetes Study. Association of acanthosis nigricans with hyperinsulinemia compared with other selected risk factors for type 2 diabetes in Cherokee Indians: the Cherokee Diabetes Study. Diabetes Care. 2002;25:1009-1014. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12032107].
Stone L.M, Kahn S.E, Deeb S.S, Fujimoto W.Y, Porte D Jr. Glucokinase gene variations in Japanese-Americans with a family history of NIDDM. Diabetes Care. 1994;17:1480-1483. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7882822].
Storgaard H, Jensen C.B, Vaag A.A, Volund A, Madsbad S. Insulin secretion after short- and long-term low-grade free fatty acid infusion in men with increased risk of developing type 2 diabetes. Metabolism. 2003;52:885-894. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 12870166].
Stowers J.M, Sutherland H.W, Kerridge D.F. Long-range implications for the mother. The Aberdeen experience. Diabetes. 1985;34:106-110. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3888735].
Strand C.L, Garcia H, Costales F. Hyponatremia in spontaneous hyperglycemia: Correlation studies in 100 patients. Clin Chem. 1987;33:1941-1942. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3665062].
Suematsu C, Hayashi T, Fujii S, Endo G, Tsumura K, Okada K, Morii H. Impaired fasting glucose and the risk of hypertension in Japanese men between the 1980s and the 1990s. The Osaka Health Survey. Diabetes Care. 1999;22:228-232. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10333938].
Sum C-F, Webster J.M, Johnson A.B, Catalano C, Cooper B.G, Taylor R. The effect of intravenous metformin on glucose metabolism during hyperglycaemia in Type 2 diabetes. Diabet Med. 1992;9:61-65. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1551312].
Sun B, Wang X, Song Q, Wang Y, Xue L, Wang C, Quan Z, Zhang Y, Niu P. Prospective studies on the relationship between the 50 g glucose challenge test and pregnant outcome. Chin Med J (Engl). 1995;108:910-913. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8728943].
Suvd J, Gerel B, Otgooloi H, Purevsuren D, Zolzaya H, Roglic G, King H. Glucose intolerance and associated factors in Mongolia: results of a national survey. Diabet Med. 2002;19:502-508. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12060063].
Suzuki H, Jae Ho Rhim. Effect of samgyetang feeding on plasma lipids, glucose, glycosylated hemoglobin, and stress-induced gastric ulcers in mice. Nutrition Research. 2000;20:575-584. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Suzuki M, Nishizaki M, Arita M, Kakuta T, Numano F. Impaired glucose tolerance with late hypersecretion of insulin during oral glucose tolerance test in patients with vasospastic angina. J Am Coll Cardiol. 1996;27:1458-1463. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8626958].
Suzuki S, Kawasaki H, Satoh Y, Ohtomo M, Hirai M, Hirai A, Hirai S, Onoda M, Matsumoto M, Hinokio Y, Akai H, Craig J, Larner J, Toyota T. Urinary chiro-inositol excretion is an index marker of insulin sensitivity in Japanese type II diabetes. Diabetes Care. 1994;17:1465-1468. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7882818].
Swinburn B.A, Woollard G.A, Chang E.C, Wilson M.R. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. Journal of the American Dietetic Association. 1999;99:1400-1405. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10570677].
Swinburn B.A, Metcalf P.A, Ley S.J. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24:619-624. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11315819].
Swinn R.A, Wareham N.J, Gregory R, Curling V, Clark P.M, Dalton K.J, Edwards O.M, O'Rahilly S. Excessive secretion of insulin precursors characterizes and predicts gestational diabetes. Diabetes. 1995;44:911-915. : Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7621996].
Szabo C, Zanchi A, Komjati K, Pacher P, Krolewski A.S, Quist W.C, LoGerfo F.W, Horton E.S, Veves A. Poly(ADP-Ribose) polymerase is activated in subjects at risk of developing type 2 diabetes and is associated with impaired vascular reactivity. Circulation. 2002;106:2680-2686. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12438293].
Tahvanainen E, Molin M, Vainio S, Tiret L, Nicaud V, Farinaro E, Masana L, Ehnholm C. Intestinal fatty acid binding protein polymorphism at codon 54 is not associated with postprandial responses to fat and glucose tolerance tests in healthy young Europeans. Results from EARS II participants. Atherosclerosis. 2000;152:317-325. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10998459].
Tajra L.C, Dubernard J.M, Dawhara M, Lefrancois N, Badet L, Martin X. Long-term metabolic control and pancreatic graft survival according to surgical technique. Transplant Proc. 1999;31:3192-3193. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10616436].
Takasaki I, Shionoiri H, Hiroto S, Yasuda G, Gotoh E, Umemura S, Kaneko Y. Long-term captopril therapy with no effect on glucose metabolism in patients with essential hypertension. Am J Hypertens. 1988;1:217S-220S. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 3046627].
Takata Y, Ou O, Nishida H, Sakagami K. Impact of self-monitoring of blood glucose on the lifestyles of subjects with fasting hyperglycemia: A randomized controlled trial. Journal of Occupational Health. 2002;44:28-33. Status: Not included because article was not published in English.
Takebayashi K, Sugita R, Tayama K, Aso Y, Takemura Y, Inukai T. The connection between QT dispersion and autonomic neuropathy in patients with type 2 diabetes. Experimental & Clinical Endocrinology & Diabetes. 2003;111:351-357. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14520602].
Takemura Y, Kikuchi S, Inaba Y, Yasuda H, Nakagawa K. The protective effect of good physical fitness when young on the risk of impaired glucose tolerance when old. Prev Med. 1999;28:14-19. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9973583].
Takeuchi M, Kanazawa A, Suzuki M, Hasegawa M, Kimura Y, Kodama K, Ryomoto K, Hattori Y, Harano Y. Evaluation of factors during OGTT to correlate insulin resistance in non-diabetic subjects. Endocr J. 2000;47:535-542. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11200932].
Takino H, Okuno S, Uotani S, Yano M, Matsumoto K, Kawasaki E, Takao Y, Yamasaki H, Yamaguchi Y, Akazawa S, Nagataki S. Increased insulin responsiveness after CS-045 treatment in diabetes associated with Werner's syndrome. Diabetes Res Clin Pract. 1994;24:167-172. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7988348].
Tan ECTH, De Keijzer M.H, Goris R.J.A. Capillary blood gas analysis in complex regional pain syndrome: A pilot study. ANN CLIN BIOCHEM. 2003;40:569-571. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14503998].
Tan Y.Y, Yeo G.S. Impaired glucose tolerance in pregnancy--is it of consequence?. Aust N Z J Obstet Gynaecol. 1996;36:248-255. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8883744].
Taniguchi A, Nakai Y, Doi K, Fukushima M, Nagata I, Kawamura H, Imura H, Suzuki M, Tokuyama K. Glucose effectiveness in two subtypes within impaired glucose tolerance. Diabetes. 1994;43:1211-1217. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 7926290].
Taniguchi A, Nakai Y, Fukushima M, Imura H, Kawamura H, Nagata I, Florant G.L, Tokuyama K. Insulin sensitivity, insulin secretion, and glucose effectiveness in subjects with impaired glucose tolerance: A minimal model analysis. Metabolism. 1994;43:714-718. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8201959].
Tankova T, Dakovska L, Kirilov G, Koev D. Insulin secretion and anti-GAD65 antibodies in subjects with impaired glucose tolerance. Experimental & Clinical Endocrinology & Diabetes. 2001;109:355-360. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11573145].
Tapp R.J, Shaw J.E, Harper C.A, de Court Balkau B, McCarty D.J, Taylor H.R, Welborn T.A, Zimmet P.Z. AusDiab Study Group. The prevalence of and factors associated with diabetic retinopathy in the Australian population. Diabetes Care. 2003;26:1731-1737. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12766102].
Teixeira C.C, Fuchs F.D, Blotta R.M, Knijnik J, Delgado I.C, Netto M.S, Ferreira E, Costa A.P, Mussnich D.G, Ranquetat G.G. Effect of tea prepared from leaves of Syzygium jambos on glucose tolerance in nondiabetic subjects. Diabetes Care. 1990;13:907-908. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2209336].
Temelkova-Kurktschiev T, Koehler C, Henkel E, Hanefeld M. Leukocyte count and fibrinogen are associated with carotid and femoral intima-media thickness in a risk population for diabetes. Cardiovasc Res. 2002;56:277-283. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12393098].
Ten Boekel E, De Kieviet W, Bartels P.C.M. Subjects with a shortened activated partial thromboplastin time show increased in-hospital mortality associated with elevated D-dimer, C-reactive protein and glucose levels. Scand J Clin Lab Invest. 2003;63:441-448. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14594325].
Tenenbaum A, Motro M, Fisman E.Z, Boyko V, Mandelzweig L, Reicher-Reiss H, Graff E, Brunner D, Behar S. Clinical impact of borderline and undiagnosed diabetes mellitus in patients with coronary artery disease. Am J Cardiol. 2000;86:1363-1366. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11113414].
Tenerz A, Norhammar A, Silveira A, Hamsten A, Nilsson G, Ryden L, Malmberg K. Diabetes, insulin resistance, and the metabolic syndrome in patients with acute myocardial infarction without previously known diabetes. Diabetes Care. 2003;26:2770-2776. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514578].
Tesfaye S. Diabetic neuropathy: Current treatment and potential therapeutic approaches. Diabetes Nutr Metab. 1994;7:375-379. Status: Not included because article does not describe a study or survey.
Testori G.P, Ferrari C, Lepore R, Boghen M. Effect of gemfibrozil treatment on glucose tolerance in hypertriglyceridemic patients with normal or impaired glucose tolerance. Current Therapeutic Research, Clinical & Experimental. 1990;47:390-395. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Teuscher A, Schnell H, Wilson P.W.F. Incidence of diabetic retinopathy and relationship to baseline plasma glucose and blood pressure. Diabetes Care. 1988;11:246-251. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3416678].
The ALLHAT Officers and Coordinators for the ALLHAT Collaborative Research Group. Major Outcomes in High-Risk Hypertensive Patients Randomized to Angiotensin-Converting Enzyme Inhibitor or Calcium Channel Blocker vs Diuretic: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). JAMA. 2002;288:2981-2997. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12479763].
The Diabetes Prevention Program Research Group. The Diabetes Prevention Program: baseline characteristics of the randomized cohort. Diabetes Care. 2000;23:1619-1629. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11092283]. [pmcid: 1360735].
Thong F.S, Graham T.E. Caffeine-induced impairment of glucose tolerance is abolished by beta-adrenergic receptor blockade in humans. J Appl Physiol. 2002;92:2347-2352. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12015346].
Thong F.S.L, Graham T.E. Caffeine-induced impairment of glucose tolerance is abolished by beta-adrenergic receptor blockade in humans. J Appl Physiol. 2002;92:2347-2352. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12015346].
Thorburn A.W, Crapo P.A, Griver K, Wallace P, Henry R.R. Long-term effects of dietary fructose on carbohydrate metabolism in non-insulin-dependent diabetes mellitus. Metabolism. 1990;39:58-63. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2403621].
Thrainsdottir S, Malik R.A, Dahlin L.B, Wiksell P, Eriksson K.F, Rosen I, Petersson J, Greene D.A, Sundkvist G. Endoneurial capillary abnormalities presage deterioration of glucose tolerance and accompany peripheral neuropathy in man. Diabetes. 2003;52:2615-2622. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514647].
Todoroki I, Shinchi K, Kono S, Imanishi K. Lifestyle and glucose tolerance: A cross-sectional study of Japanese men. Ann Epidemiol. 1994;4:363-368. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7981843].
Toeller M, Gries F.A, Dannehl K. Natural history of glucose intolerance in obesity. A ten year observation. Int J Obes. 1982;6(Suppl 1):145-149. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6749720].
Tomiyama H, Kimura Y, Okazaki R, Kushiro T, Abe M, Kuwabara Y, Yoshida H, Kuwata S, Kinouchi T, Doba N. Close relationship of abnormal glucose tolerance with endothelial dysfunction in hypertension. Hypertension. 2000;36:245-249. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 10948085].
Tong P.C.Y, Lee Z.S.K, Sea M, Chow C, Ko G.T.C, Chan W, So W, Ma R.C.W, Ozaki R, Woo J, Cockram C.S, Chan J.C.N. The effect of Orlistat-induced weight loss, without concomitant hypocaloric diet, on cardiovascualr risk factors and insulin sensitivity in young obese Chinese subjects with or without Type 2 Diabetes. Arch Intern Med. 2002;162:2428-2435. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12437401].
Top C, Cingozbay B.Y, Terekeci H, Kucukardali Y, Onde M.E, Danaci M. The effects of valsartan on insulin sensitivity in patients with primary hypertension. J Int Med Res. 2002;30:15-20. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11921494].
Topic E, Pavlicek I, Brinar V, Korsic M. Glycosylated haemoglobin in clarification of the origin of hyperglycaemia in acute cerebrovascular accident. Diabet Med. 1989;6:12-15. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2522367].
Torella R, Salvatore T, Spiezia R. Is the common presence of glucose intolerance in old age a reliable index for the subsequent occurrence of fasting hyperglycemia. Acta Diabetol Lat. 1986;23:57-61. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3716750].
Torgerson J.S.H. XENical in the prevention of diabetes in obese subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. 2004;27:155-161. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14693982].
Toyota T, Oikawa S, Abe R, Sano R, Suzuki N, Hisamichi S, Fukao A. Effect of cilostazol on lipid, uric acid and glucose metabolism in patients with impaired glucose tolerance or type 2 diabetes mellitus a double-blind, placebo-controlled study. Clinical Drug Investigation. 2001;21:325-335. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Trinick T.R, Duly E. Experience of a quality assessment scheme for non-laboratory glucose meters. J Clin Pathol. 1992;45:77-78. Status: Not included because article does not describe a study or survey. [pmid: 1740522]. [pmcid: 495825].
Trivedi N, Mithal A, Gupta S.K, Godbole M.M. Reversible impairment of glucose tolerance in patients with endemic fluorosis. Diabetologia. 1993;36:826-828. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8405753].
Tsai S.-T, Li C.-L, Chen C.-H, Chou P. Community-based epidemiological study of glucose tolerance in Kin-Chen, Kinmen: Support for a new intermediate classification. J Clin Epidemiol. 2000;53:505-510. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10812323].
Tschritter O, Fritsche A, Shirkavand F, Machicao F, Haring H, Stumvoll M. Assessing the shape of the glucose curve during an oral glucose tolerance test. Diabetes Care. 2003;26:1026-1033. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12663568].
Tsutsu N, Nunoi K, Kodama T, Nomiyama R, Iwase M, Fujishima M. Lack of association between blood pressure and insulin in patients with insulinoma. J Hypertens. 1990;8:479-482. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2163424].
Tunbridge F.K.E, Newens A, Home P.D, Davis S.N, Murphy M, Burrin J.M, Alberti K.G.M.M, Jensen I. Double-blind crossover trial of isophane (NPH)- and lente-based insulin regimens. Diabetes Care. 1989;12:115-119. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2649324].
Tunbridge F.K.E, Home P.D, Murphy M, Alberti K.G.M.M. Does flexibility at mealtimes disturb blood glucose control on a multiple insulin injection regimen?. Diabet Med. 1991;8:833-838. Status: Not included because article does not describe a study or survey. [pmid: 1837510].
Tuomilehto-Wolf E, Tuomilehto J, Hitman G.A, Nissinen A, Stengard J, Pekkanen J, Kivinen P, Kaarsalo E, Karvonen M.J. Genetic susceptibility to non-insulin dependent diabetes mellitus and glucose intolerance are located in HLA region [see comments]. BMJ. 1993;307:155-159. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8343743]. [pmcid: 1678370].
Tuomilehto J, Zimmet P, Kankaanpaa J, Wolf E, Hunt D, King H, Ram P. Prevalence of ischaemic ECG abnormalities according to the diabetes status in the population of Fiji and their associations with other risk factors. Diabetes Res Clin Pract. 1988;5:205-217. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 3219991].
Tuomilehto J, Schranz A, Aldana D, Pitkaniemi J. The effect of diabetes and impaired glucose tolerance on mortality in Malta. Diabet Med. 1994;11:170-176. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8200202].
Tuomilehto J, Qiao Q, Borch-Johnsen K, Balkau B. Glucose tolerance and mortality: Comparison of WHO and American Diabetes Association diagnostic criteria. Lancet. 1999;354:617-621. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10466661].
Tuomilehto J, Lindstrom J, Eriksson J.G. Changes in diet and physical activity prevented type 2 diabetes mellitus in people with impaired glucose tolerance. Evidence Based Medicine. 2001;6:17. Status: Not included because article does not describe a study or survey.
Tuomilehto J, Qiao Q, Balkau B, Borch-Johnson K. Glucose tolerance and all-cause mortality. Cardiology Review. 2001;18:28-32. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Tuomilehto J, Lindstrom J, Eriksson J.G, Valle T.T, Hamalainen H, Ilanne-Parikka P, Myers K.A. Lifestyle changes can prevent the development of diabetes mellitus. CMAJ: Canadian Medical Association Journal. 2001;164:188. Status: Not included because article is not a fulltext publication.
Turpeinen A.K, Haffner S.M, Louheranta A.M, Niskanen L.K, Miettinen H, Uusitupa M.I. Serum leptin in subjects with impaired glucose tolerance in relation to insulin sensitivity and first-phase insulin response. Int J Obes Relat Metab Disord. 1997;21:284-287. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9130025].
Turpeinen A.K, Kuikka J.T, Vanninen E, Uusitupa M.I.J. Abnormal myocardial kinetics of 123I-heptadecanoic acid in subjects with impaired glucose tolerance. Diabetologia. 1997;40:541-549. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9165222].
Turpeinen A.K, Takala T.O, Nuutila P, Axelin T, Luotolahti M, Haaparanta M, Bergman J, Hamalainen H, Iida H, Maki M, Uusitupa M.I, Knuuti J. Impaired free fatty acid uptake in skeletal muscle but not in myocardium in patients with impaired glucose tolerance: studies with PET and 14(R,S)-[18F]fluoro-6-thia-heptadecanoic acid. Diabetes. 1999;48:1245-1250. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10342811].
Uchida K, Jikko A, Yamato T. Relationship of glucose intolerance and indocyanine green clearance to respiratory enzyme levels in human cirrhotic liver. Am J Med Sci. 1985;290:19-27. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2994474].
Uusitupa M, Lindi V, Louheranta A, Salopuro T, Lindstrom J, Tuomilehto J. Finnish Diabetes Prevention Study Group. Long-term improvement in insulin sensitivity by changing lifestyles of people with impaired glucose tolerance: 4-year results from the Finnish Diabetes Prevention Study. Diabetes. 2003;52:2532-2538. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514637].
Uusitupa M.I. Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Ann Med. 1996;28:445-449. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8949977].
Vaccaro O, Rivellese A, Riccardi G, Capaldo B, Tutino L, Annuzzi G, Mancini M. Impaired glucose tolerance and risk factors for atherosclerosis. Arteriosclerosis. 1984;4:592-597. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 6391444].
Vaccaro O, Pauciullo P, Rubba P. Peripheral arterial circulation in individuals with impaired glucose tolerance. Diabetes Care. 1985;8:594-597. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 4075946].
Vaccaro O, Ruth K.J, Stamler J. Relationship of postload plasma glucose to mortality with 19-yr follow-up. Comparison of one versus two plasma glucose measurements in the Chicago Peoples Gas Company Study. Diabetes Care. 1992;15:1328-1334. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1425098].
Vaccaro O, Imperatore G, Iovino V, Iovine C, Rivellese A.A, Riccardi G. Does impaired glucose tolerance predict hypertension? A prospective analysis. Diabetologia. 1996;39:70-76. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8720605].
Vaccaro O, Ruffa G, Imperatore G, Iovino V, Rivellese A.A, Riccardi G. Risk of diabetes in the new diagnostic category of impaired fasting glucose: a prospective analysis.[see comment]. Diabetes Care. 1999;22:1490-1493. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10480514].
Vajo Z, Szekacs B, Dachman W. Evidence for genetic variability in venous responsiveness. Acta Physiol Hung. 1996;84:353-360. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9328607].
Valerio G, Franzese A, Carlin E, Pecile P, Perini R, Tenore A. High prevalence of stress hyperglycaemia in children with febrile seizures and traumatic injuries. Acta Paediatr. 2001;90:618-622. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11440092].
van Dam, R. M., Schuit, A. J., Feskens, E. J. M., Seidell, J. C., and Kromhout, D. Physical activity and glucose tolerance in elderly men: the Zutphen elderly study. Medicine & Science in Sports & Exercise 34(7):1132–6, 2002 Jul (22 ref) 2002; 1132–1136. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Van der Merwe M.T, Crowther N.J, Schlaphoff G.P, Gray I.P, Joffe B.I, Lonnroth P.N. Evidence for insulin resistance in black women from South Africa. Int J Obes. 2000;24:1340-1346. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Van der Merwe M.T, Schlaphoff G.P, Crowther N.J, Boyd I.H, Gray I.P, Joffe B.I, Lonnroth P.N. Lactate and glycerol release from adipose tissue in lean, obese, and diabetic women from South Africa. J Clin Endocrinol Metab. 2001;86:3296-3303. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11443204].
Van Kempen A.A.M.W, Romijn J.A, Ruiter A.F.C, Ackermans M.T, Endert E, Hoekstra J.H, Kok J.H, Sauerwein H.P. Adaptation of glucose production and gluconeogenesis to diminishing glucose infusion in preterm infants at varying gestational ages. Pediatr Res. 2003;53:628-634. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12612212].
Van Mieghem W. Evaluation of glucose tolerance during treatment with celiprolol in patients with Mild Arterial Hypertension without diabetes mellitus. Acta Clin Belg. 1997;52:360-366. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9489131].
Van Pareren Y.K, de Muinck Keizer-Schrama S.M, Stijnen T, Sas T.C, Drop S.L. Effect of discontinuation of long-term growth hormone treatment on carbohydrate metabolism and risk factors for cardiovascular disease in girls with Turner syndrome. J Clin Endocrinol Metab. 2002;87:5442-5448. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12466334].
Vanderpump M.P, Tunbridge W.M, French J.M, Appleton D, Bates D, Rodgers H, Evans J.G, Clark F, Tunbridge F, Young E.T. The incidence of diabetes mellitus in an English community: a 20-year follow-up of the Whickham Survey. Diabet Med. 1996;13:741-747. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8862950].
Vangen S, Stoltenberg C, Holan S, Moe N, Magnus P, Harris J.R, Stray-Pedersen B. Outcome of pregnancy among immigrant women with diabetes. Diabetes Care. 2003;26:327-332. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12547857].
Vanhala M.J, Kumpusalo E.A, Pitkajarvi T.K, Notkola I.L, Takala J.K. Hyperinsulinemia and clustering of cardiovascular risk factors in middle-aged hypertensive Finnish men and women. J Hypertens. 1997;15:475-481. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9169999].
Vanhala M.J, Pitkajarvi T.K, Keinanen-Kiukaanniemi S.M, Kumpusalo E.A, Takala J.K. Hyperinsulinaemia in hypertensive subjects: validity of a test for the detection of insulin resistance in clinical practice. J Hum Hypertens. 1998;12:463-467. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9702932].
Vanhanen M, Koivisto K, Kuusisto J, Mykkanen L, Helkala E, Hanninen T, Riekkinen P Sr, Soininen H, Laakso M. Cognitive function in an elderly population with persistent impaired glucose tolerance. Diabetes Care. 1998;21:398-402. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9540022].
Vardi P, Crisa L, Jackson R.A. Predictive value of intravenous glucose tolerance test insulin secretion less than or greater than the first percentile in islet cell antibody positive relatives of type 1 (insulin-dependent) diabetic patients. Diabetologia. 1991;34:93-102. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2065854].
Vasankari T, Hamalainen H, Aunola S, Rastas M, Marniemi J, Ahotupa M. Reduced oxidized LDL after two years dietary and exercise intervention in IGT subjects. European Journal of Endocrinology. 1999;140(Suppl. 1):2. Status: Not included because article is not a fulltext publication.
Velho G, Blanche H, Vaxillaire M, Bellanne-Chantelot C, Pardini V.C, Timsit J, Passa Ph, Deschamps I, Robert J.-J, Weber I.T, Marotta D, Pilkis S.J, Lipkind G.M, Bell G.I, Froguel Ph. Identification of 14 new glucokinase mutations and description of the clinical profile of 42 MODY-2 families. Diabetologia. 1997;40:217-224. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9049484].
Vella A, Reed A.S, Charkoudian N, Shah P, Basu R, Basu A, Joyner M.J, Rizza R.A. Glucose-induced suppression of endogenous glucose production: Dynamic response to differing glucose profiles. Am J Physiol Endocrinol Metab. 2003;285:E25-E30. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12637258].
Verrillo A, de Teresa A, Pinto M, Rucco E. Diurnal variation in the effect of exogenous insulin on blood sugar, growth hormone and free fatty acids in subjects with various degrees of glucose intolerance. IRCS Medical Science. 1983;11:913-914. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design.
Verschoor L, Lamberts S.W.J, Uitterlinden P, Del Pozo E. Glucose tolerance during long term treatment with a somatostatin analogue. British Medical Journal. 1986;293:1327-1328. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2878704]. [pmcid: 1342048].
Vijayakumar T, Vasudevan D.M. Effect of ascorbic acid administration on glucose tolerance and serum cholesterol in normal and in diabetic subjects. Indian Medical Gazette. 1980;114:96-100. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Vijayalingam S, Parthiban A, Shanmugasundaram K.R, Mohan V. Abnormal antioxidant status in impaired glucose tolerance and non-insulin-dependent diabetes mellitus. Diabet Med. 1996;13:715-719. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8862945].
Vinceti M, Rovesti S, Pacchioni C, Ropa G, Roncaia R, Benedetti P, Bergomi M, Vivoli G. Diet as a risk factor for abnormal glucose tolerance in subjects with and without family history of diabetes mellitus. Diabetes Nutr Metab. 1994;7:21-28. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Viswanathan M, Mohan V, Snehalatha C, Ramachandran A. High prevalence of Type 2 (non-insulin-dependent) diabetes among the offspring of conjugal Type 2 diabetic parents in India. Diabetologia. 1985;28:907-910. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4092859].
von Eckardstein A, Schulte H, Assmann G. Risk for diabetes mellitus in middle-aged Caucasian male participants of the PROCAM study: implications for the definition of impaired fasting glucose by the American Diabetes Association. Prospective Cardiovascular Munster. J Clin Endocrinol Metab. 2000;85:3101-3108. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10999793].
Von Mach M-A, Brinkmann C, Hansen T, Weilemann L.S, Beyer J. Differences in pharmacokinetics and pharmacodynamics of insulin lispro and aspart in healthy volunteers. Experimental & Clinical Endocrinology & Diabetes. 2002;110:416-419. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12518253].
Voors A.W, Radhakrishnamurthy B, Srinivasan S.R, Webber L.S, Berenson G.S. Plasma glucose level related to blood pressure in 272 children, ages 7–15 years, sampled from a total biracial population. Am J Epidemiol. 1981;113:347-356. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7211820].
Vuksan V, Sievenpiper J.L, Koo V.Y.Y, Francis T, Beljan-Zdravkovic U. American Ginseng (Panax quinqefolius L) Reduces Postprandial Glycemia in Nondiabetic Subjects and Subjects with Type 2 Diabetes Mellitus. Arch Intern Med. 2000;160:1009-1013. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10761967].
Vuksan V, Sievenpiper J.L, Owen R, Swilley J.A, Spadafora P, Jenkins D.J, Vidgen E, Brighenti F, Josse R.G, Leiter L.A, Xu Z, Novokmet R. Beneficial effects of viscous dietary fiber from Konjac-mannan in subjects with the insulin resistance syndrome: results of a controlled metabolic trial. Diabetes Care. 2000;23:9-14. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10857960].
Wagenaar L.J, Kuck E.M, Hoekstra J.B.L. Troglitazone. Is it all over?. Neth J Med. 1999;55:4-12. Status: Not included because article does not describe a study or survey. [pmid: 10431549].
Wagenknecht L.E, Mayer E.J, Rewers M, Haffner S, Selby J, Borok G.M, Henkin L, Howard G, Savage P.J, Saad M.F, Bergman R.N, Hamman R. The insulin resistance atherosclerosis study (iris): Objectives, design, and recruitment results. Ann Epidemiol. 1995;5:464-472. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8680609].
Wagner Z, Wittmann I, Mazak I, Schinzel R, Heidland A, Kientsch-Engel R, Nagy J. Nepsilon-(Carboxymethyl)lysine levels in patients with type 2 diabetes: Role of renal function. Am J Kidney Dis. 2001;38:785-791. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11576882].
Wahab N.N, Cowden E.A, Pearce N.J, Gardner M.J, Merry H, Cox J.L. Is blood glucose an independent predictor of mortality in acute myocardial infarction in the thrombolytic era?. J Am Coll Cardiol. 2002;40:1748-1754. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12446057].
Walker E.A, Paduano D.J, Shamoon H. Quality assurance for blood glucose monitoring in health-care facilities. Diabetes Care. 1991;14:1043-1049. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1797485].
Wall U, Bergbrant A, Jern S. Impaired glucose tolerance at five-year follow-up of young men with borderline hypertension. Blood Pressure. 1996;5:139-147. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8790924].
Wareham N.J, Byrne C.D, Carr C, Day N.E, Boucher B.J, Hales C.N. Glucose intolerance is associated with altered calcium homeostasis: a possible link between increased serum calcium concentration and cardiovascular disease mortality. Metabolism. 1997;46:1171-1177. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9322802].
Warram J.H, Sigal R.J, Martin B.C, Krolewski A.S, Soeldner J.S. Natural history of impaired glucose tolerance: follow-up at Joslin Clinic. Diabet Med. 1996;13:S40-S45. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8894480].
Wasada T, Kuroki H, Arii H, Maruyama A, Saito S, Watanabe Y, Omori Y. Physiological increase in plasma insulin concentration suppresses proinsulin secretion in normal controls but not in subjects with glucose intolerance. Endocr J. 1994;41:183-188. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7951567].
Watanabe K, Sekiya M, Tsuruoka T, Funada J, Kameoka H. Effect of insulin resistance on left ventricular hypertrophy and dysfunction in essential hypertension. J Hypertens. 1999;17:1153-1160. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10466471].
Watanabe N, Taniguchi T, Taketoh H, Kitagawa Y, Namura H, Yoneda N, Kurimoto Y, Yamada S, Ishikawa Y. Elevated remnant-like lipoprotein particles in impaired glucose tolerance and type 2 diabetic patients. Diabetes Care. 1999;22:152-156. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10333918].
Wei M, Gibbons L.W, Mitchell T.L, Kampert J.B, Stern M.P, Blair S.N. Low fasting plasma glucose level as a predictor of cardiovascular disease and all-cause mortality. Circulation. 2000;101:2047-2052. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10790345].
Weinberger M.H, Fineberg N.S, Fineberg S.E. The influence of blood pressure and carbohydrate tolerance on vascular compliance in humans. Am J Hypertens. 2002;15:678-682. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 12160189].
Weiss H.G, Klocker J, Labeck B, Nehoda H, Aigner F, Klingler A, Ebenbichler C, Foger B, Lechleitner M, Patsch J.R, Schwelberger H.G. Plasma amine oxidase: a postulated cardiovascular risk factor in nondiabetic obese patients. Metabolism. 2003;52:688-692. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12800092].
Weiss P.A.M, Scholz H.S, Haas J, Tamussino K.F, Seissler J, Borkenstein M.H. Long-term follow-up of infants of mothers with type 1 diabetes: Evidence for hereditary and nonhereditary transmission of diabetes and precursors. Diabetes Care. 2000;23:905-911. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10895839].
Weiss R, Dufour S, Taksali S.E, Tamborlane W.V, Petersen K.F, Bonadonna R.C, Boselli L, Barbetta G, Allen K, Rife F, Savoye M, Dziura J, Sherwin R, Shulman G.I, Caprio S. Prediabetes in obese youth: A syndrome of impaired glucose tolerance, severe insulin resistance, and altered myocellular and abdominal fat partitioning. Lancet. 2003;362:951-957. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14511928].
Welborn T.A, Reid C.M, Marriott G. Australian Diabetes Screening Study: impaired glucose tolerance and non-insulin-dependent diabetes mellitus. Metabolism. 1997;46:35-39. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9439557].
Welin L, Eriksson H, Larsson B, Ohlson L.O, Svardsudd K, Tibblin G. Hyperinsulinaemia is not a major coronary risk factor in elderly men. The study of men born in 1913. Diabetologia. 1992;35:766-770. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1511804].
Welin L, Eriksson H, Larsson B, Svardsudd K, Tibblin G, Wilhelmsen L. Triglycerides and blood glucose are the major coronary risk factors in elderly Swedish men. The study of men born in 1913. Ann Epidemiol. 1992;2:113-119. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1342252].
Wells T.G, Ulstrom R.A, Nevins T. Hypoglycemia in pediatric renal allograft recipients. J Pediatr. 1988;113:1002-1007. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3057155].
Widimsky J Jr, Strauch B, Sindelka G, Skrha J. Can primary hyperaldosteronism be considered as a specific form of diabetes mellitus?. Physiol Res. 2001;50:603-607. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11829322].
Wiedeman P.E, Trevillyan J.M. Dipeptidyl peptidase IV inhibitors for the treatment of impaired glucose tolerance and type 2 diabetes. Current Opinion in Investigational Drugs. 2003;4:412-420. Status: Not included because article does not describe a study or survey. [pmid: 12808880].
Wiener K. Fasting plasma glucose as a diagnostic indicator of diabetes mellitus [see comments]. Clin Chim Acta. 1995;238:199-208. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7586579].
Wijeyaratne C.N, Sheriff R, Seneviratne H.R, Sheriffdeen A.H. Pregnancy following renal transplantation in Sri Lanka. Ceylon Med J. 2000;45:168-170. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11293964].
Willi S.M, Kennedy A, Brant B.P, Wallace P, Rogers N.L, Garvey W.T. Effective use of thiazolidinediones for the treatment of glucocorticoid-induced diabetes. Diabetes Res Clin Pract. 2002;58:87-96. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12213349].
Williams D.E.M, Prevost A.T, Whichelow M.J, Cox B.D, Day N.E, Wareham N.J. A cross-sectional study of dietary patterns with glucose intolerance and other features of the metabolic syndrome. Br J Nutr. 2000;83:257-266. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10884714].
Williams D.R, Wareham N.J, Brown D.C, Byrne C.D, Clark P.M, Cox B.D, Cox L.J, Day N.E, Hales C.N, Palmer C.R. Undiagnosed glucose intolerance in the community: the Isle of Ely Diabetes Project. Diabet Med. 1995;12:30-35. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7712700].
Williams D.R.R, Wareham N.J, Brown D.C, Byrne C.D, Clark P.M.S, Cox B.D, Cox L.J, Day N.E, Hales C.N, Palmer C.R, Shackleton J.R, Wang T.W.M. Undiagnosed glucose intolerance in the community: The Isle of Ely Diabetes Project. Diabet Med. 1995;12:30-35. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7712700].
Wing R.R, Venditti E, Jakicic J.M, Polley B.A, Lang W. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21:350-359. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9540015].
Wingard D.L, Barrett-Connor E. Family history of diabetes and cardiovascular disease risk factors and mortality among euglycemic, borderline hyperglycemic, and diabetic adults. Am J Epidemiol. 1987;125:948-958. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3578253].
Wingard D.L, Barrett-Connor E.L, Scheidt-Nave C, McPhillips J.B. Prevalence of cardiovascular and renal complications in older adults with normal or impaired glucose tolerance or NIDDM: A population-based study. Diabetes Care. 1993;16:1022-1025. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8359095].
Wolever T.M, Fernandes J, Rao V.A, Chiasson J.L, Josse R.G, Leiter L.A. Positive methane-producing status associated with increased serum cholesterol in subjects with impaired glucose tolerance. Diabetes Care. 1995;18:1010-1012. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7555532].
Wolever T.M, Chiasson J.L, Csima A, Hunt J.A, Palmason C, Ross S.A, Ryan E.A. Variation of postprandial plasma glucose, palatability, and symptoms associated with a standardized mixed test meal versus 75 g oral glucose. Diabetes Care. 1998;21:336-340. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9540012].
Wolever T.M, Chiasson J.L. Acarbose raises serum butyrate in human subjects with impaired glucose tolerance. Br J Nutr. 2000;84:57-61. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10961161].
Wolever T.M, Mehling C. High-carbohydrate-low-glycaemic index dietary advice improves glucose disposition index in subjects with impaired glucose tolerance. Br J Nutr. 2002;87:477-487. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12010586].
Wolever T.M, Mehling C. Long-term effect of varying the source or amount of dietary carbohydrate on postprandial plasma glucose, insulin, triacylglycerol, and free fatty acid concentrations in subjects with impaired glucose tolerance. Am J Clin Nutr. 2003;77:612-621. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12600851].
Wolever T.M.S, Nguyen P-M, Chiasson J-L, Hunt J.A, Josse R.G, Palmason C, Rodger N.W, Ross S.A, Ryan E.A, Tan M.H. Determinants of diet glycemic index calculated retrospectively from diet records of 342 individuals with non-insulin-dependent diabetes mellitus. Am J Clin Nutr. 1994;59:1265-1269. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8198048].
Wolever T.M.S, Fernandes J, Rao V.A, Chiasson J-L, Josse R.G, Leiter L.A. Positive methane-producing status associated with increased serum cholesterol in subjects with impaired glucose tolerance. Diabetes Care. 1995;18:1010-1012. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7555532].
Wolever T.M.S, Bentum-Williams A, Jenkins D.J.A. Physiological modulation of plasma free fatty acid concentrations by diet: Metabolic implications in nondiabetic subjects. Diabetes Care. 1995;18:962-970. Status: Not included because article does not describe a study or survey. [pmid: 7555557].
Wolever T.M.S, Chiasson J.-L. Acarbose raises serum butyrate in human subjects with impaired glucose tolerance. Br J Nutr. 2000;84:57-61. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10961161].
Wolever T.M.S, Mehling C. Long-term effect of varying the source or amount of dietary carbohydrate on postprandial plasma glucose, insulin, triacylglycerol, and free fatty acid concentrations in subjects with impaired glucose tolerance. Am J Clin Nutr. 2003;77:612-621. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 12600851].
Won Soon Park, Yun Sil Chang, Lee M. Effects of hyperglycemia or hypoglycemia on brain cell membrane function and energy metabolism during the immediate reoxygenation-reperfusion period after acute transient global hypoxia-ischemia in the newborn piglet. Brain Research. 2001;901:102-108. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11368956].
Woo J, Ho S.C, Sham A, Sea M.M, Lam K.S, Lam T.H, Janus E.D. Diet and glucose tolerance in a Chinese population. Eur J Clin Nutr. 2003;57:523-530. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12700613].
Worrall G. Screening healthy people for diabetes: is it worthwhile?. J Fam Pract. 1991;33:155-160. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1890396].
Yajnik C.S, Naik S.S, Bhat D.S, Joshi V.M, Shelgikar K.M, Alberti K.G.M.M, Hockaday T.D.R. The relationship between obesity, plasma immunoreactive insulin concentration and blood pressure in newly diagnosed Indian Type 2 diabetic patients. Diabet Med. 1993;10:146-151. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8458191].
Yajnik C.S, Fall C.H, Vaidya U, Pandit A.N, Bavdekar A, Bhat D.S, Osmond C, Hales C.N, Barker D.J. Fetal growth and glucose and insulin metabolism in four-year-old Indian children. Diabet Med. 1995;12:330-336. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7600749].
Yamada N, Yoshinaga H, Sakurai N, Shimano H, Gotoda T, Ohashi Y, Yazaki Y, Kosaka K. Increased risk factors for coronary artery disease in Japanese subjects with hyperinsulinemia or glucose intolerance. Diabetes Care. 1994;17:107-114. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8137680].
Yamada T, Aizawa T, Nagasawa Y, Ishihara M, Komatsu M, Komiya I, Shinoda T, Takasu N. Ten-year follow-up of Japanese overweight subjects with impaired glucose tolerance: identification of a diabetes-prone subpopulation. Intern Med. 1992;31:877-884. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1450495].
Yamazaki Y, Takahashi K, Yagisawa T, Oba S, Teraoka S, Toma H, Agishi T, Ota K. Alterations in glucose tolerance and insulin release in renal transplant recipients receiving cyclosporine and corticosteroid. Transplant Proc. 1988;20:158-159. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 2968012].
Yanagi K, Yamashita S, Kihara S, Nakamura T, Nozaki S, Nagai Y, Funahashi T, Kameda-Takemura K, Ueyama Y, Jiao S, Kubo M, Tokunaga K, Matsuzawa Y. Characteristics of coronary artery disease and lipoprotein abnormalities in patients with heterozygous familial hypercholesterolemia associated with diabetes mellitus or impaired glucose tolerance. Atherosclerosis. 1997;132:43-51. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9247358].
Yarnell J.W, Pickering J.E, Elwood P.C, Baker I.A, Bainton D, Dawkins C, Phillips D.I. Does non-diabetic hyperglycemia predict future IHD? Evidence from the Caerphilly and Speedwell studies. J Clin Epidemiol. 1994;47:383-388. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7730863].
Yeh G.Y, Eisenberg D.M, Kaptchuk T.J, Phillips R.S. Systematic review of herbs and dietary supplements for glycemic control in diabetes. Diabetes Care. 2003;26:1277-1294. Status: Not included because article does not describe a study or survey. [pmid: 12663610].
Yoshinaga H, Kosaka K. High glycosylated hemoglobin levels increase the risk of progression to diabetes mellitus in subjects with glucose intolerance. Diabetes Res Clin Pract. 1996;31:71-79. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8792104].
Yu W.K, Li W.Q, Li N, Li J.S. Influence of acute hyperglycemia in human sepsis on inflammatory cytokine and counterregulatory hormone concentrations. World J Gastroenterol. 2003;9:1824-1827. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12918129].
Yudkin J.S, Forrest R.D, Jackson C.A. Microalbuminuria as predictor of vascular disease in non-diabetic subjects. Islington Diabetes Survey. Lancet. 1988;2:530-533. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2900920].
Zannolli R, Rebeggiani A, Chiarelli F, Morgese G. Hyperinsulinism as a marker in obese children. Am J Dis Child. 1993;147:837-841. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8352218].
Zargar A.H, Shah N.A, Masoodi S.R, Laway B.A, Dar F.A, Khan A.R, Sofi F.A, Wani A.I. Copper, zinc, and magnesium levels in non-insulin dependent diabetes mellitus. Postgrad Med J. 1998;74:665-668. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10197198]. [pmcid: 2431594].
Zargar A.H, Masoodi S.R, Khan A.K, Bashir M.I, Laway B.A, Wani A.I, Dar F.A. Impaired fasting glucose and impaired glucose tolerance - Lack of agreement between the two categories in a North Indian population. Diabetes Res Clin Pract. 2001;51:145-149. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11165694].
Zavaroni I, Bonini L, Gasparini R, Barilli A.L, Zuccarelli A, Dall'Aglio E, Delsignore R, Reaven G.M. Hyperinsulinemia in a normal population as a predictor of non-insulin- dependent diabetes mellitus, hypertension, and coronary heart disease: The Barilla Factory revisited. Metabolism. 1999;48:989-994. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10459563].
Zawada E.T Jr, Williams L, McClung D.E. Renal-metabolic consequences of antihypertensive therapy with diltiazem versus hypochlorothiazide. Miner Electrolyte Metab. 1987;13:72-77. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3320720].
Zhang J.L, Qin Y.W, Zheng X, Qiu J.L, Zou D.J. Serum resistin level in essential hypertension patients with different glucose tolerance. Diabet Med. 2003;20:828-831. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 14510864].
Zimmet P, King H, Taylor R. The high prevalence of diabetes mellitus, impaired glucose tolerance and diabetic retinopathy in nauru - The 1982 survey. Diabetes Research. 1984;1:13-18. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6529880].
Zimmet P.Z, Collins V.R, Dowse G.K, Knight L.T. Hyperinsulinaemia in youth is a predictor of Type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1992;35:534-541. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1612226].
Zofkova I, Zamrazil V. Does exogenous hypermagnesaemia inhibit insulin secretion in patients with impaired glucose tolerance or non-insulin-dependent diabetes mellitus?. Horm Metab Res. 1994;26:157-159. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8005565].
Loveman E, Cave C, Green C, Royle P, Dunn N, Waugh N. The clinical and cost-effectiveness of patient education models for diabetes: A systematic review and economic evaluation. Health Technology Assessment (Winchester, England). 2003;7:190. Status: Not included because article does not describe a study or survey.
Lu W, Resnick H.E, Jain A.K, Adams-Campbell L.L, Jablonski K.A, Gottlieb A.M, Robbins D.C, Howard B.V. Effects of isolated post-challenge hyperglycemia on mortality in American Indians: the Strong Heart Study. Ann Epidemiol. 2003;13:182-188. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12604162].
Lucas D, Farez C, Bardou L.G, Vaisse J, Attali J.R, Valensi P. Cytochrome P450 2E1 activity in diabetic and obese patients as assessed by chlorzoxazone hydroxylation. Fundam Clin Pharmacol. 1998;12:553-558. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9794154].
Lundell K.H, Sabel K.G, Eriksson B.O, Mellgren G. Glucose metabolism and insulin secretion in children with cyanotic congenital heart disease. Acta Paediatr. 1997;86:1082-1084. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9350889].
Lunetta M, Di Mauro M, Nicoletti F, Mughini L. Diabetogenic effect of naloxone in subjects with impaired glucose tolerance. Medical Science Research. 1991;19:737-738. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review.
MacGregor A.S, Price J.F, Hau C.M, Lee A.J, Carson M.N, Fowkes F.G. Role of systolic blood pressure and plasma triglycerides in diabetic peripheral arterial disease. The Edinburgh Artery Study. Diabetes Care. 1999;22:453-458. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10097928].
Mackey R.H, Sutton-Tyrrell K, Vaitkevicius P.V, Sakkinen P.A, Lyles M.F, Spurgeon H.A, Lakatta E.G, Kuller L.H. Correlates of aortic stiffness in elderly individuals: A subgroup of the cardiovascular health study. Am J Hypertens. 2002;15:16-23. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11824854].
Maggi S, Zucchetto M, Grigoletto F, Baldereschi M, Candelise L, Scarpini E, Scarlato G, Amaducci L. The Italian Longitudinal Study on Aging (ILSA): design and methods. Aging (Milano). 1994;6:464-473. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7748921].
Mak, R. H. K., Turner, C., Haycock, G. B., and Chantler, C. Secondary hyperparathyroidism and glucose intolerance in children with uremia. Kidney Int 1983; 24 Status: Excluded because no subjects diagnosed by included criteria were analyzed
Mak, R. H. K., Turner, C., Thompson, T., Haycock, G., and Chantler, C. Glucose metabolism in children with uremia: Effect of dietary phosphate and protein. Kidney Int 1987; 32 Status: Excluded because no subjects diagnosed by included criteria were analyzed
Mancini M, Strazzullo P, Trevisan M, Contaldo F, Vaccaro O, Cappuccio F.P. Pathophysiological interrelations of obesity, impaired glucose tolerance, and arterial hypertension. Prev Med. 1985;14:428-435. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 3906627].
Manderson J.G, Patterson C.C, Hadden D.R, Traub A.I, Leslie H, McCance D.R. Leptin concentrations in maternal serum and cord blood in diabetic and nondiabetic pregnancy. Am J Obstet Gynecol. 2003;188:1326-1332. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12748507].
Mangiagli A, Italia S, De Sanctis V, Campisi S. Impaired glucose homeostasis in young adult thalassemic patients: A pilot study with acarbose. J Pediatr Endocrinol Metab. 2002;15:205-210. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11874186].
Mannucci E, Ognibene A, Cremasco F, Bardini G, Mencucci A, Pierazzuoli E, Ciani S, Messeri G, Rotella C.M. Effect of metformin on glucagon-like peptide 1 (GLP-1) and leptin levels in obese nondiabetic subjects. Diabetes Care. 2001;24:489-494. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11289473].
Marceau P, Biron S, Hould F.S, Marceau S, Simard S, Thung S.N, Kral J.G. Liver pathology and the metabolic syndrome X in severe obesity.[see comment]. J Clin Endocrinol Metab. 1999;84:1513-1517. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10323371].
Marchand E, Grigorescu F, Buysschaert M. The hypoglycemic effect of a sulfonylurea (gliclazide) in moderate type II diabetes and glucose intolerance is not accompanied by changes in insulin action and insulin binding to erythrocytes. Molecular Physiology. 1983;4:83-93. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Marchesi E, Baiardini R, Centeleghe P, Covini D, Frattoni A, Muggia C, Ravetta V, Resasco T. Structural changes in the heart and carotid arteries in hypertensive patients associated with cardiovascular risk factors. J Cardiovasc Risk. 1997;4:283-289. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9477207].
Marchesini G, Ronchi M, Forlani G, Bugianesi E, Bianchi G, Fabbri A, Zoli M, Melchionda N. Cardiovascular disease in cirrhosis--a point-prevalence study in relation to glucose tolerance. Am J Gastroenterol. 1999;94:655-662. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10086647].
Mari A. Assessment of insulin sensitivity and secretion with the labelled intravenous glucose tolerance test: Improved modelling analysis. Diabetologia. 1998;41:1029-1039. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9754821].
Mari A, Pacini G, Murphy E, Ludvik B, Nolan J.J. A model-based method for assessing insulin sensitivity from the oral glucose tolerance test. Diabetes Care. 2001;24:539-548. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11289482].
Marugame T, Lee K, Eguchi H, Oda T, Shinchi K, Kono S. Relation of impaired glucose tolerance and diabetes mellitus to colorectal adenomas in Japan. Cancer Causes Control. 2002;13:917-921. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12588087].
Marugame T, Hayasaki H, Lee K, Eguchi H, Matsumoto S. Alveolar bone loss associated with glucose tolerance in Japanese men. Diabet Med. 2003;20:746-751. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12925056].
Mathur H.C, Gupta S.D. Evaluation of correlation of C.S.F. and blood sugar in neurological disorders of childhood. Indian Medical Gazette. 1984;118:331-332. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Matsuda M, DeFronzo R.A. Insulin sensitivity indices obtained from oral glucose tolerance testing: Comparison with the euglycemic insulin clamp. Diabetes Care. 1999;22:1462-1470. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10480510].
Matthews D.R, Edge J.A, Dunger D.B. Un unbiased glucose clamp method using a variable insulin infusion: Its application in diabetic adolescents. Diabet Med. 1990;7:246-251. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2139397].
Mayer-Davis E.J, Costacou T, King I, Zaccaro D.J, Bell R.A. The Insulin Resistance and Atherosclerosis Study (IRAS). Plasma and dietary vitamin E in relation to incidence of type 2 diabetes: The Insulin Resistance and Atherosclerosis Study (IRAS). Diabetes Care. 2002;25:2172-2177. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12453956].
Mazza A, Pessina A.C, Pavei A, Scarpa R, Tikhonoff V, Casiglia E. Predictors of stroke mortality in elderly people from the general population. The CArdiovascular STudy in the ELderly. Eur J Epidemiol. 2001;17:1097-1104. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12530768].
Mbanya J-C, Cruickshank J.K, Forrester T, Balkau B, Ngogang J.Y, Riste L, Forhan A, Anderson N.M, Bennett F, Wilks R. Standardized comparison of glucose intolerance in West African-origin populations of rural and urban Cameroon, Jamaica, and Caribbean migrants to Britain. Diabetes Care. 1999;22:434-440. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10097925].
McCartney P, Keen H, Jarrett R.J. The Bedford Survey: observations on retina and lens of subjects with impaired glucose tolerance and in controls with normal glucose tolerance. Diabete Metab. 1983;9:303-305. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6667765].
McClain M.R, Srinivasan S.R, Chen W, Steinmann W.C, Berenson G.S. Risk of type 2 diabetes mellitus in young adults from a biracial community: the Bogalusa Heart Study. Prev Med. 2000;31:1-7. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10896837].
McCowen K.C, Friel C, Sternberg J, Chan S, Forse R.A, Burke P.A, Bistrian B.R. Hypocaloric total parenteral nutrition: effectiveness in prevention of hyperglycemia and infectious complications -- a randomized clinical trial. Crit Care Med. 2000;28:3606-3611. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11098961].
McGill H.C Jr, McMahan C.A, Zieske A.W, Malcom G.T, Tracy R.E, Strong J.P. Effects of nonlipid risk factors on atherosclerosis in youth with a favorable lipoprotein profile. Circulation. 2001;103:1546-1550. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11257083].
McIntyre H.D, Begg L.M, Parry A.F, Oats J. Audit of maternal and fetal outcomes in women treated for glucose intolerance during pregnancy. Aust N Z J Obstet Gynaecol. 2002;42:23-28. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11926637].
McKeigue P.M, Shah B, Marmot M.G. Relation of central obesity and insulin resistance with high diabetes prevalence and cardiovascular risk in South Asians [see comments]. Lancet. 1991;337:382-386. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1671422].
McLellan J.A.S, Barrow B.A, Levy J.C, Hammersley M.S, Hattersley A.T, Gillmer M.D.G, Turner R.C. Prevalence of diabetes mellitus and impaired glucose tolerance in parents of women with gestational diabetes. Diabetologia. 1995;38:693-698. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7672491].
McPhillips J.B, Barrett-Connor E, Wingard D.L. Cardiovascular disease risk factors prior to the diagnosis of impaired glucose tolerance and non-insulin-dependent diabetes mellitus in a community of older adults. Am J Epidemiol. 1990;131:443-453. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 2301354].
Meigs J.B, Nathan D.M, Wilson P.W.F, Cupples L.A, Singer D.E. Metabolic risk factors worsen continuously across the spectrum of nondiabetic glucose tolerance: the Framingham Offspring Study. Annals of Internal Medicine. 1998;128:524-533. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9518396].
Meigs J.B, Mittleman M.A, Nathan D.M, Tofler G.H, Singer D.E, Murphy-Sheehy P.M, Lipinska I, D'Agostino R.B, Wilson P.W. Hyperinsulinemia, hyperglycemia, and impaired hemostasis: the Framingham Offspring Study. JAMA. 2000;283:221-228. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10634338].
Meigs J.B, D'Agostino R.B Sr, Nathan D.M, Rifai N, Wilson P.W. Framingham Offspring Study. Longitudinal association of glycemia and microalbuminuria: the Framingham Offspring Study. Diabetes Care. 2002;25:977-983. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12032102].
Meigs J.B, Nathan D.M, D'Agostino R.B Sr, Wilson P.W. Framingham Offspring Study. Fasting and postchallenge glycemia and cardiovascular disease risk: the Framingham Offspring Study. Diabetes Care. 2002;25:1845-1850. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12351489].
Meigs J.B, Muller D.C, Nathan D.M, Blake D.R, Andres R. Baltimore Longitudinal Study of Aging. The natural history of progression from normal glucose tolerance to type 2 diabetes in the Baltimore Longitudinal Study of Aging. Diabetes. 2003;52:1475-1484. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12765960].
Mennen L.I, de Courcy Potier, Guilland J-C, Ducros V, Bertrais S, Nicolas J-P, Maurel M, Zarebska M, Favier A, Franchisseur C, Hercberg S, Galan P. Homocysteine, cardiovascular disease risk factors, and habitual diet in the French Supplementation with Antioxidant Vitamins and Minerals Study. Am J Clin Nutr. 2002;76:1279-1289. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12450894].
Menotti A. Cardiovascular risk factors in patients discharged from departments of internal medicine-the Italian FADOI-2 study. European Journal of Internal Medicine. 2002;13:44-51. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11836082].
Mensink M, Blaak E.E, Vidal H, De Bruin T.W.A, Glatz J.F.C, Saris W.H.M. Lifestyle changes and lipid metabolism gene expression and protein content in skeletal muscle of subjects with impaired glucose tolerance. Diabetologia. 2003;46:1082-1089. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12856127].
Mensink M, Corpeleijn E. Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61:49-58. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12849923].
Mensink M, Feskens E.-J.M, Saris W.-H.M, de Bruin T.-W.A, Blaak E.E. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): Preliminary results after one year. International-Journal-of-Obesity-and-Related-Metabolic-Disorders. 2003;27:377-384. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 12629566].
Mertz W. Chromium in human nutrition: A review. J Nutr. 1993;123:626-633. Status: Not included because article does not describe a study or survey. [pmid: 8463863].
Merz C.N.B, Buse J.B, Tuncer D, Twillman G.B. Physician attitudes and practices and patient awareness of the cardiovascular complications of diabetes. J Am Coll Cardiol. 2002;40:1877-1881. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12446074].
Mescheryakov A.V, Kozlov I.A, Dementyeva I.I, Lakhter M.A, Ermolyn A.J, Galyibin A.A. Glucose metabolism and insulin activity during cardiac surgery. J Cardiothorac Anesth. 1989;3:536-543. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2520930].
Mestman J.H. Outcome of diabetes screening in pregnancy and perinatal morbidity in infants of mothers with mild impairment in glucose tolerance. Diabetes Care. 1980;3:447-452. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7389561].
Metzger B.E, Bybee D.E, Freinkel N. Gestational diabetes mellitus. Correlations between the phenotypic and genotypic characteristics of the mother and abnormal glucose tolerance during the first year postpartum. Diabetes. 1985;34:111-115. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3888736].
Micic D, Kendereski A, Sumarac-Dumanovic M, Cvijovic G, Popovic V, Dieguez C, Casanueva F. Growth hormone response to GHRH + GHRP-6 in type 2 diabetes during euglycemic and hyperglycemic clamp. Diabetes Res Clin Pract. 2004;63:37-45. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14693411].
Mihara T, Oohashi H, Hirata Y. Mortality of Japanese diabetics in a seven-year follow-up study. Diabetes Res Clin Pract. 1986;2:139-144. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3743361].
Milla C.E, Warwick W.J, Moran A. Trends in pulmonary function in patients with cystic fibrosis correlate with the degree of glucose intolerance at baseline. Am J Respir Crit Care Med. 2000;162:891-895. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10988101].
Mingrone G, De Gaetano A, Greco A.V, Capristo E, Benedetti G, Castagneto M, Gasbarrini G. Dodecanedioic acid infusion induces a sparing effect on whole-body glucose uptake, mainly in non-insulin-dependent diabetes mellitus. Br J Nutr. 1997;78:723-735. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9389896].
Misra A, Cherukupalli R, Reddy K.S, Mohan A, Bajaj J.S. Hyperinsulinemia and dyslipidemia in non-obese, normotensive offspring of hypertensive parents in northern India. Blood Pressure. 1998;7:286-290. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10321441].
Misra A, Reddy R.B, Reddy K.S, Mohan A, Bajaj J.S. Clustering of impaired glucose tolerance, hyperinsulinemia and dyslipidemia in young north Indian patients with coronary heart disease: a preliminary case-control study. Indian Heart J. 1999;51:275-280. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10624065].
Mitrakou A, Kelley D, Mokan M, Veneman T, Pangburn T, Reilly J, Gerich J. Role of reduced suppression of glucose production and diminished early insulin release in impaired glucose tolerance. N Engl J Med. 1992;326:22-29. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1727062].
Miwa S, Inouye M, Ohmura C, Mitsuhashi N, Onuma T, Kawamori R. Relationship between carotid atherosclerosis and erythrocyte membrane cholesterol oxidation products in type 2 diabetic patients. Diabetes Res Clin Pract. 2003;61:81-88. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12951275].
Miyazaki S. Abnormal glucose tolerance and prognosis after PTCA. Cardiology Review. 2001;18:18-22. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Modan M, Halkin H, Karasik A, Lusky A. Effectiveness of glycosylated hemoglobin, fasting plasma glucose, and a single post load plasma glucose level in population screening for glucose intolerance. The Israel Study of Glucose Intolerance, Obesity and Hypertension. Am J Epidemiol. 1984;119:431-444. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6702817].
Modan M, Or J, Karasik A, Drory Y, Fuchs Z, Lusky A, Chetrit A, Halkin H. Hyperinsulinemia, sex, and risk of atherosclerotic cardiovascular disease [see comments]. Circulation. 1991;84:1165-1175. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1884447].
Molitch M.E, Hou S.H, Gottesman S. Effects of antihypertensive medications on carbohydrate metabolism. Current Therapeutic Research, Clinical & Experimental. 1986;39:398-407. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Montori V.M. A lifestyle intervention or metformin prevented or delayed the onset of type 2 diabetes in persons at risk. ACP Journal Club. 2002;137:5. Status: Not included because article does not describe a study or survey. [pmid: 12093204].
Morel, Y., Lehmann, T., Vadas, L., and, Golay, and A. Effect of Metformine on insulin-resistance in obese patients with glucose-intolerance TO:=Effet de la Metformine sur la résistance á l'insuline chez des patients obèses avec intolérance au glucose. Schweiz Med Wochenschr 1996; 126:12 Status: Not included because article was not published in English
Morel Y, Golay A, Perneger T, Lehmann T, Vadas L, Pasik C, Reaven G.M. Metformin treatment leads to an increase in basal, but not insulin-stimulated, glucose disposal in obese patients with impaired glucose tolerance. Diabet Med. 1999;16:650-655. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10477209].
Morici M.L, Di Marco A, Sestito D, Candore R, Cangemi C, Accardo F, Donatelli M, Cataldo M.G, Lombardo A. The impact of coexistent diabetes on the prevalence of coronary heart disease. J Diabetes Complications. 1997;11:268-273. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9334908].
Motala A.A, Omar M.A. The value of glycosylated haemoglobin as a substitute for the oral glucose tolerance test in the detection of impaired glucose tolerance (IGT). Diabetes Res Clin Pract. 1992;17:199-207. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1425159].
Motala A.A, Omar M.A. Evidence for impaired pancreatic beta cell function in South African Indians with impaired glucose tolerance. Diabet Med. 1994;11:437-444. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8088120].
Muller S, Martin S, Koenig W, Hanifi-Moghaddam P, Rathmann W, Haastert B, Giani G, Illig T, Thorand B, Kolb H. Impaired glucose tolerance is associated with increased serum concentrations of interleukin 6 and co-regulated acute-phase proteins but not TNF-alpha or its receptors. Diabetologia. 2002;45:805-812. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12107724].
Mutch W.J, Stowers J.M. Reversible mild diabetes in children after treatment with chlorpropamide. Lancet. 1980;1:1158-1161. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6103984].
Mykkanen L, Laakso M, Penttila I, Pyorala K. Asymptomatic hyperglycemia and cardiovascular risk factors in the elderly. Atherosclerosis. 1991;88:153-161. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1892482].
Mykkanen L, Haffner S.M, Ronnemaa T, Bergman R.N, Laakso M. Low insulin sensitivity is associated with clustering of cardiovascular disease risk factors. Am J Epidemiol. 1997;146:315-321. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9270410].
Nagai T, Tomizawa T, Minamide S, Nakajima K, Mori M. Serum lipid and lipoprotein metabolism after glucose ingestion in NIDDM and IGT patients: Apolipoprotein-containing particles. Diabetes Care. 1996;19:365-368. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8729161].
Nagi D.K, Ali V.M, Walji S, Jain S.K, Yudkin J.S. Hyperinsulinemia in nondiabetic Asian subjects using specific assays for insulin, intact proinsulin, and des-31, 32-proinsulin. Diabetes Care. 1996;19:39-42. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8720531].
Nagi D.K, Pettitt D.J, Bennett P.H, Klein R, Knowler W.C. Diabetic retinopathy assessed by fundus photography in Pima Indians with impaired glucose tolerance and NIDDM. Diabet Med. 1997;14:449-456. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9212309].
Naito H, Ohneda A, Kojima R, Sato T, Sasaki K, Funayama Y, Fukushima K, Shibata C, Matsuno S, Sasaki I. Plasma glicentin in diabetic and gastrectomized patients. Regul Pept. 1999;79:55-61. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9930583].
Nakai I, Mizuta N, Nakamura K, Okamoto M, Nakajiama H, Yoshimura N, Yasumura T, Omori Y, Oka T. Effects and limits of renal transplantation in patients with impaired glucose tolerance. Transplant Proc. 1998;30:114-115. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9474974].
Nakanishi N, Nakamura K, Matsuo Y, Suzuki K, Tatara K. Cigarette smoking and risk for impaired fasting glucose and Type 2 Diabetes in middle-aged Japanese men. Annals of Internal Medicine. 2000;133:183-191. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10906832].
Nakanishi N, Nishina K, Yoshida H, Matsuo Y, Nagano K, Nakamura K, Suzuki K, Tatara K. Hours of work and the risk of developing impaired fasting glucose or type 2 diabetes mellitus in Japanese male office workers. Occupational & Environmental Medicine. 2001;58:569-574. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11511743]. [pmcid: 1740182].
Nakanishi N, Okamoto M, Yoshida H, Matsuo Y, Suzuki K, Tatara K. Serum uric acid and risk for development of hypertension and impaired fasting glucose or Type II diabetes in Japanese male office workers. Eur J Epidemiol. 2003;18:523-530. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12908717].
Nakanishi N, Nishina K, Li W, Sato M, Suzuki K, Tatara K. Serum gamma-glutamyltransferase and development of impaired fasting glucose or type 2 diabetes in middle-aged Japanese men. J Intern Med. 2003;254:287-295. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12930239].
Nam J.H, Mun J.I, Kim S.I, Kang S.W, Choi K.H, Park K, Ahn C.W, Cha B.S, Song Y.D, Lim S.K, Kim K.R, Lee H.C, Huh K.B. beta-cell dysfunction rather than insulin resistance is the main contributing factor for the development of postrenal transplantation diabetes mellitus. Transplantation. 2001;71:1417-1423. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11391229].
Nannipieri M, Posadas R, Williams K, Politi E, Gonzales-Villalpando C, Stern M.P, Ferrannini E. Association between polymorphisms of the atrial natriuretic peptide gene and proteinuria: a population-based study. Diabetologia. 2003;46:429-432. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12687344].
Nasrat A.A, Augensen K, Abushal M, Shalhoub J.T. The outcome of pregnancy following untreated impaired glucose tolerance. Int J Gynaecol Obstet. 1994;47:1-6. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7813745].
Nathan D.M. Addressing the 21st Century Diabetes Epidemic. Advanced Studies in Medicine. 2002;2:961-965. Status: Not included because article does not describe a study or survey.
Nauck M.A, Weber I, Bach I, Richter S, Orskov C, Holst J.J, Schmiegel W. Normalization of fasting glycaemia by intravenous GLP-1 ([7–36 amide] or [7–37]) in type 2 diabetic patients. Diabet Med. 1998;15:937-945. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9827848].
Nauck M.A, Meier J.J, Wolfersdorff A.V, Tillil H, Creutzfeldt W, Kobberling J. A 25-year follow-up study of glucose tolerance in first-degree relatives of type 2 diabetic patients: Association of impaired or diabetic glucose tolerance with other components of the metabolic syndrome. Acta Diabetol. 2003;40:163-172. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14740275].
Nelson R.G, Tan M, Beck G.J, Bennett P.H, Knowler W.C, Mitch W.E, Blouch K, Myers B.D. Changing glomerular filtration with progression from impaired glucose tolerance to Type II diabetes mellitus. Diabetologia. 1999;42:90-93. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10027584].
Neufeld N.D, Raffel L.J, Landon C, Chen Y.D, Vadheim C.M. Early presentation of type 2 diabetes in Mexican-American youth. Diabetes Care. 1998;21:80-86. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9538974].
Nicholson G, Paton A. Glucose tolerance in alcoholics. J Stud Alcohol. 1979;40:997-1002. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Niemi M, Kervinen K, Rantala A, Kauma H, Paivansalo M, Savolainen M.J, Lilja M, Kesaniemi Y.A. The role of apolipoprotein E and glucose intolerance in gallstone disease in middle aged subjects. Gut. 1999;44:557-562. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 10075965]. [pmcid: 1727442].
Niskanen L, Sarlund H, Laakso M. Metabolic defects in persistent impaired glucose tolerance are related to the family history of non-insulin-dependent diabetes mellitus. Metabolism. 1995;44:1099-1104. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7637652].
Niskanen L.K, Salonen J.T, Nyyssonen K, Uusitupa M.I. Plasma lipid peroxidation and hyperglycaemia: a connection through hyperinsulinaemia?. Diabet Med. 1995;12:802-808. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8542741].
Nissinen A, Tervahauta M, Pekkanen J, Kivinen P, Stengard J, Kaarsalo E, Kivela S-L, Vaisanen S, Salonen J.T, Tuomilehto J. Prevalence and change of cardiovascular risk factors among men born 1900-19: The Finnish cohorts of the Seven Countries Study. Age & Ageing. 1993;22:365-376. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8237628].
Nord E, Hanson U, Persson B. Blood glucose limits in the diagnosis of impaired glucose tolerance during pregnancy. Acta Obstet Gynecol Scand. 1995;74:589-593. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7660761].
Norhammar A, Tenerz A, Nilsson G, Hamsten A, Efendic S, Ryden L, Malmberg K. Glucose metabolism in patients with acute myocardial infarction and no previous diagnosis of diabetes mellitus: a prospective study.[see comment]. Lancet. 2002;359:2140-2144. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12090978].
Nozaka K, Hamazoe R, Nishimura O. Results of surgical treatment of chronic pancreatitis. Yonago Acta Medica. 1987;30:105-114. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Offenbacher E.G, Pi-Sunyer F.X. Beneficial effect of chromium-rich yeast on glucose tolerance and blood lipids in elderly subjects. Diabetes. 1980;29:919-925. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7000589].
Ogawa O, Onuma T, Uchino H, Takayanagi Y, Tanaka Y, Yamasaki Y, Atsumi Y, Matsuoka K, Kawamori R. Insulin resistance and atherosclerosis in branch retinal vein occlusion. Jpn J Ophthalmol. 2003;47:351-355. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12842202].
Ohlson L-O, Larsson B, Eriksson H. Diabetes mellitus in Swedish middle-aged men. The study of men born in 1913 and 1923. Diabetologia. 1987;30:386-393. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3678659].
Ohlson L-O, Larsson B, Bjorntorp P, Eriksson H, Svardsudd K, Welin L, Tibblin G, Wilhelmsen L. Risk factors for Type 2 (non-insulin-dependent) diabetes mellitus. Thirteen and one-half years of follow-up of the participants in a study of Swedish men born in 1913. Diabetologia. 1988;31:798-805. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3234634].
Ohlson L.O, Svardsudd K, Welin L, Eriksson H, Wilhelmsen L, Tibblin G, Larsson B. Fasting blood glucose and risk of coronary heart disease, stroke, and all-cause mortality: a 17-year follow-up study of men born in 1913. Diabet Med. 1986;3:33-37. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2951132].
Ohlson L.O, Bjuro T, Larsson B, Eriksson H, Svardsudd K, Welin L, Wilhelmsen L. A cross-sectional analysis of glucose tolerance and cardiovascular disease in 67-year-old men. Diabet Med. 1989;6:112-120. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2522851].
Ohneda A, Kobayashi T, Nihei J. Evaluation of new criteria for diagnosis of diabetes mellitus based on follow-up study of borderline diabetes. Tohoku J Exp Med. 1982;137:437-444. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6750844].
Ohnishi H, Saitoh S, Takagi S, Ohata J, Isobe T, Kikuchi Y, Takeuchi H, Shimamoto K. Pulse wave velocity as an indicator of atherosclerosis in impaired fasting glucose: the Tanno and Sobetsu study. Diabetes Care. 2003;26:437-440. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12547876].
Oida E, Kannagi T, Moritani T, Yamori Y. Diabetic alteration of cardiac vago-sympathetic modulation assessed with tone-entropy analysis. Acta Physiol Scand. 1999;165:129-134. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10090323].
Oimomi M, Ishikawa K, Kawasaki T. Carbamylation of hemoglobin in renal failure and clinical aspects. Metabolism. 1984;33:999-1002. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6493050].
Okamoto F, Sone H, Nonoyama T, Hommura S. Refractive changes in diabetic patients during intensive glycaemic control. Br J Ophthalmol. 2000;84:1097-1102. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11004091]. [pmcid: 1723257].
Okamura F, Tashiro A, Utumi A, Imai T, Suchi T, Tamura D, Sato Y, Suzuki S, Hongo M. Insulin resistance in patients with depression and its changes during the clinical course of depression: minimal model analysis. Metabolism. 2000;49:1255-1260. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11079812].
Okubo M, Watanabe H, Fujikawa R, Kawamura T, Egusa G, Yamakido M. Reduced prevalence of diabetes according to 1997 American Diabetes Association criteria. Diabetologia. 1999;42:1168-1170. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10525655].
Olatunbosun S.T. Diagnosis and follow-up of subjects with impaired glucose tolerance: how reliable is OGTT? Report from a Nigerian survey. Diabetes Res Clin Pract. 1998;41:147-148. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9789721].
Olsson G, Rehnqvist N. Effects of chronic metoprolol treatment on glucose tolerance after myocardial infarction. Eur J Clin Pharmacol. 1987;33:311-313. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3691619].
Oluboyo P.O, Erasmus R.T. The significance of glucose intolerance in pulmonary tuberculosis. Tubercle. 1990;71:135-138. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because of case-control design. Not included for treatment because intervention was not relevant to review. [pmid: 2219464].
Osei K, Schuster D.P. Decreased insulin-mediated but not non-insulin-dependent glucose disposal rates in glucose intolerance and type II diabetes in African (Ghanaian) immigrants. Am J Med Sci. 1996;311:113-121. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8615385].
Otsuka Y, Miyazaki S, Okumura H, Yasuda S, Daikoku S, Morii I, Sutani Y, Goto Y, Nonogi H. Abnormal glucose tolerance, not small vessel diameter, is a determinant of long-term prognosis in patients treated with balloon coronary angioplasty.[see comment]. Eur Heart J. 2000;21:1790-1796. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11052844].
Oyibo S.O, Prasad Y.D.M, Jackson N.J, Jude E.B, Boulton A.J.M. The relationship between blood glucose excursions and painful diabetic peripheral neuropathy: A pilot study. Diabet Med. 2002;19:870-873. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12358878].
Pagani G, Gianola D, Pagani M.D, Tengattini F, Dominoni P, Ghilardi G, Cortesi L, Pedroncelli A, Tonnarelli G.P. Medical management of acromegaly: Effects of SMS 201-995 in 30 patients. Endocrinol Exp. 1990;24:175-185. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2361459].
Page R.C, Harnden K.E, Cook J.T, Turner R.C. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-566. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1643806].
Page R.C, Walravens E.K, Levy J.C, Stratton I.M, Turner R.C. Prevalence and pathophysiology of impaired glucose tolerance in three different high-risk white groups. Metabolism. 1993;42:932-938. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8345815].
Page R.C, Harnden K.E, Walravens N.K, Onslow C, Sutton P, Levy J.C, Hockaday D.T, Turner R.C. ‘Healthy living’ and sulphonylurea therapy have different effects on glucose tolerance and risk factors for vascular disease in subjects with impaired glucose tolerance. Q J Med. 1993;86:145-154. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8483989].
Page R.C.L, Harnden K.E, Cook J.T.E, Turner R.C. Can life-styles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-566. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1643806].
Page R.C.L, Harnden K.E, Walravens N.K.N, Onslow C, Sutton P, Levy J.C, Hockaday D.T.R, Turner R.C. ‘Healthy living’ and sulphonylurea therapy have different effects on glucose tolerance and risk factors for vascular disease in subjects with impaired glucose tolerance. Q J Med. 1993;86:145-154. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8483989].
Pagnan A, Ambrosio G.B, Vincenzi M, Mormino P, Maiolino P, Gerin L, Barbieri E, Cappelletti F, Dal Palu C. Precursors of atherosclerosis in children: the Cittadella study. Follow-up and tracking of total serum cholesterol, triglycerides, and blood glucose. Prev Med. 1982;11:381-390. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7122430].
Paivansalo M.J, Merikanto J, Savolainen M.J, Lilja M, Rantala A.O, Kauma H, Reunanen A, Kesaniemi Y.A, Suramo I. Effect of hypertension, diabetes and other cardiovascular risk factors on kidney size in middle-aged adults. Clin Nephrol. 1998;50:161-168. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9776419].
Paleologos M, Stone E, Braude S. Persistent, progressive hypophosphataemia after voluntary hyperventilation. Clin Sci (Colch ). 2000;98:619-625. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10781395].
Pallardo F, Herranz L, Garcia-Ingelmo T, Grande C, Martin-Vaquero P, Janez M, Gonzalez A. Early postpartum metabolic assessment in women with prior gestational diabetes. Diabetes Care. 1999;22:1053-1058. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10388966].
Palmer G.S, Clancy M.C, Hawley J.A, Rodger I.M, Burke L.M, Noakes T.D. Carbohyrate ingestion immediately before exercise does not improve 20 km time trial performance in well trained cyclists. Int J Sports Med. 1998;19:415-418. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9774209].
Palumbo G, Barantani E, Pozzi F, Azzolini V, Gronda D, Ronchi E. Long-term nifedipine treatment and glucose homeostasis in hypertensive patients. Current Therapeutic Research, Clinical & Experimental. 1988;43:171-179. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Pan C.-Y, Gao Y, Chen J.-W, Luo B.-Y, Fu Z.-Z, Lu J.-M, Guo X.-H, Cheng H. Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003;61:183-190. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12965108].
Pan C.Y.G. Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003;61:183-190. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12965108].
Pan X-R, Hu Y-H, Li G-W, Liu P-A, Bennett P.H, Howard B.V. Impaired glucose tolerance and its relationship to ECG-indicated coronary heart disease and risk factors among Chinese: Da Qing IGT and diabetes study. Diabetes Care. 1993;16:150-156. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8422770].
Panarotto D, Ardilouze J.L, Tessier D, Maheux P. The degree of hyperinsulinemia and impaired glucose tolerance predicts plasma leptin concentrations in women only: a new exploratory paradigm. Metabolism. 2000;49:1055-1062. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10954026].
Paolisso G, Tataranni P.A, Foley J.E, Bogardus C, Howard B.V, Ravussin E. A high concentration of fasting plasma non-esterified fatty acids is a risk factor for the development of NIDDM. Diabetologia. 1995;38:1213-1217. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8690174].
Pappas S, Donohue S.M, Denver A.E, Mohamed-Ali V, Goubet S, Yudkin J.S. Glucose intolerance in thalassemia major is related to insulin resistance and hepatic dysfunction. Metabolism. 1996;45:652-657. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8622611].
Park K.S, Kim C.H, Lee M.K, Shin C.S, Park D.J, Kim S.Y, Cho B.Y, Lee H.K. Metabolic effect of decreasing nonesterified fatty acid levels with acipimox in hyperthyroid patients. Metabolism. 1999;48:1318-1321. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10535397].
Parulkar A.A, Fonseca V.A. Recent advances in pharmacological treatment of type 2 diabetes mellitus. Comprehensive Therapy. 1999;25:418-426. Status: Not included because article does not describe a study or survey. [pmid: 10520444].
Passariello N, Giugliano D, Sgambato S, Torella R, D'Onofrio F. Calcitonin, a diabetogenic hormone?. J Clin Endocrinol Metab. 1981;53:318-323. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7019230].
Passariello N, Giugliano D, Ceriello A. Impaired insulin response to glucose but not to arginine in heroin addicts. J Endocrinol Invest. 1986;9:353-357. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3540079].
Pastore G, Saracco P, del Prever Brach. Glucose metabolism in children with acute lymphoblastic leukemia treated according to two different L-asparaginase schedules. Acta Haematologica. 1984;72:384-387. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6442522].
Payne K, Ireland P. Plasma glucose levels in the peri-operative period in children. Anaesthesia. 1984;39:868-872. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6545086].
Peart W.S, Barnes G.R, Broughton P. Adverse reactions to bendrofluazide and propranolol for the treatment of mild hypertension. Report of medical research council working party on mild to moderate hypertension. Lancet. 1981;2:539-543. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6115999].
Pennebaker James W, et al. Physical symptoms related to blood glucose in insulin-dependent diabetics. Psychosomatic-Medicine. 1981;43:489-500. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7323257].
Peraldo M, Fasulo A, Chiappini E, Milio C, Marianelli L. Evaluation of glucose tolerance and insulin secretion in cystic fibrosis patients. Horm Res. 1998;49:65-71. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9485173].
Percheron C, Colette C, Avignon A, Monnier L. Metabolic responses to high carbohydrate breakfasts in obese patients with impaired glucose tolerance. Comparison of meals containing dairy products and fruits versus bread. Nutrition Research. 1997;17:797-806. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months.
Pereira, M. A., Jacobs, D. R., Jr., Van Horn, L., Slattery, M. L., Kartashov, A. I., and Ludwig, D. S. Dairy consumption, obesity, and the insulin resistance syndrome in young adults: the CARDIA Study. JAMA 287(16):2081–9, 2153–4, 2002 Apr 24 (56 ref) 2002; 2081–2089. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Perlman J.A, Russell-briefel R, Ezzati T, Lieberknecht G. Oral glucose tolerance and the potency of contraceptive progestins. J Chronic Dis. 1985;38:857-864. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4044771].
Permert J, Ihse I, Jorfeldt L, Von Schenck H, Arnqvist H.J, Larsson J. Pancreatic cancer is associated with impaired glucose metabolism. Eur J Surg. 1993;159:101-107. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 8098623].
Persson B, Hanson U. Insulin dependent diabetes in pregnancy: Impact of maternal blood glucose control on the offspring. Journal of Paediatrics & Child Health. 1993;29:20-23. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8461173].
Persson L-G, Lindstrom K, Bengtsson C. Oral glucose tolerance and its relationship to overweight and other cardiovascular risk factors in men aged 33–42. A study in the Community of Habo, Sweden. Scand J Prim Health Care. 1994;12:261-268. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7863144].
Peters A.L, Davidson M.B, Schriger D.L, Hasselblad V. A clinical approach for the diagnosis of diabetes mellitus: An analysis using glycosylated hemoglobin levels. Journal of the American Medical Association. 1996;276:1246-1252. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8849753].
Pettitt D.J, Bennett P.H, Saad M.F, Charles M.A, Nelson R.G, Knowler W.C. Abnormal glucose tolerance during pregnancy in Pima Indian women. Long-term effects on offspring. Diabetes. 1991;40(Suppl 2):126-130. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1748241].
Peyrot M, Rubin R.R. Structure and correlates of diabetes-specific locus of control. Diabetes Care. 1994;17:994-1001. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7988321].
Phillips D.I, Barker D.J, Hales C.N, Hirst S, Osmond C. Thinness at birth and insulin resistance in adult life. Diabetologia. 1994;37:150-154. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8163048].
Piatti P, Di Mario C, Monti L.D, Fragasso G, Sgura F, Caumo A, Setola E, Lucotti P, Galluccio E, Ronchi C, Origgi A, Zavaroni I, Margonato A, Colombo A. Association of insulin resistance, hyperleptinemia, and impaired nitric oxide release with in-stent restenosis in patients undergoing coronary stenting. Circulation. 2003;108:2074-2081. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14530196].
Piatti P.M, Monti L.D, Galli L, Fragasso G, Valsecchi G, Conti M, Gernone F, Pontiroli A.E. Relationship between endothelin-1 concentration and metabolic alterations typical of the insulin resistance syndrome. Metabolism. 2000;49:748-752. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10877200].
Piatti P.M, Monti L.D, Zavaroni I, Valsecchi G, Van Phan C, Costa S, Conti M, Sandoli E.P, Solerte B, Pozza G, Pontiroli A.E, Reaven G. Alterations in nitric oxide/cyclic-GMP pathway in nondiabetic siblings of patients with type 2 diabetes. J Clin Endocrinol Metab. 2000;85:2416-2420. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10902787].
Pietropaolo M, Barinas-Mitchell E, Pietropaolo S.L, Kuller L.H, Trucco M. Evidence of islet cell autoimmunity in elderly patients with type 2 diabetes. Diabetes. 2000;49:32-38. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10615947].
Piette J.D, Weinberger M, Kraemer F.B, McPhee S.J. Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a Department of Veterans Affairs health care system: A randomized controlled trial. Diabetes Care. 2001;24:202-208. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11213866].
Pietzsch, J., Julius, U., and Hanefeld, M. Metabolic basis of low high density lipoprotein in subjects with impaired glucose tolerance. Ann N Y Acad Sci 1999; 892-326. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design
Piva I, Erle G, Thiella M, Lora L, Strazzabosco M, Sicolo N, Federspil G. A study on the hyperinsulinism of late pregnancy. J Endocrinol Invest. 1991;14:807-814. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1802920].
Poinoosawmy D, Gloster J, Nagasubramanian S, Hitchings R.A. Association between optic disc haemorrhages in glaucoma and abnormal glucose tolerance. Br J Ophthalmol. 1986;70:599-602. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3741826]. [pmcid: 1040780].
Poirier L, Cleroux J, Nadeau A, Lacourciere Y. Effects of nebivolol and atenolol on insulin sensitivity and haemodynamics in hypertensive patients. J Hypertens. 2001;19:1429-1435. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 11518851].
Pokela M.L. Effect of opioid-induced analgesia on beta-endorphin, cortisol and glucose responses in neonates with cardiorespiratory problems. Biol Neonate. 1993;64:360-367. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8286562].
Polyzogopoulou E.V, Kalfarentzos F, Vagenakis A.G, Alexandrides T.K. Restoration of euglycemia and normal acute insulin response to glucose in obese subjects with type 2 diabetes following bariatric surgery. Diabetes. 2003;52:1098-1103. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 12716738].
Pontiroli A.E, Perfetti M.G, Pozza G. Acute effect of glipizide on glucose tolerance in obesity and diabetes mellitus (NIDDM). Eur J Clin Pharmacol. 1991;40:23-26. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 2060541].
Pontiroli A.E, Perfetti M.G, Pozza G. Improvement of glucose tolerance by minimal doses of glipizide in obese subjects with different degrees of glucose intolerance. Horm Metab Res Suppl. 1992;26:32-34. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 1490690].
Pontiroli A.E, Galli L. Duration of obesity is a risk factor far non-insulin dependent diabetes mellitus, not for arterial hypertension or for hyperlipidaemia. Acta Diabetol. 1998;35:130-136. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9840448].
Pontiroli A.E, Pizzocri P, Librenti M.C, Vedani P, Marchi M, Cucchi E, Orena C, Paganelli M, Giacomelli M, Ferla G, Folli F. Laparoscopic adjustable gastric banding for the treatment of morbid (grade 3) obesity and its metabolic complications: a three-year study. J Clin Endocrinol Metab. 2002;87:3555-3561. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12161474].
Pontrelli L, Parris W, Adeli K, Cheung R.C. Atorvastatin treatment beneficially alters the lipoprotein profile and increases low-density lipoprotein particle diameter in patients with combined dyslipidemia and impaired fasting glucose/type 2 diabetes. Metabolism. 2002;51:334-342. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11887170].
Pories W.J, MacDonald K.G Jr, Morgan E.J, Sinha M.K, Dohm G.L, Swanson M.S, Barakat H.A, Khazanie P.G, Leggett-Frazier N, Long S.D. Surgical treatment of obesity and its effect on diabetes: 10-y follow-up. Am J Clin Nutr. 1992;55:582S-585S. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1733132].
Poulton J, Brown M.S, Cooper A, Marchington D.R, Phillips D.I. A common mitochondrial DNA variant is associated with insulin resistance in adult life. Diabetologia. 1998;41:54-58. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9498630].
Power M.J, Fullerton K.J, Stout R.W. Blood glucose and prognosis of acute stroke. Age & Ageing. 1988;17:164-170. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3389245].
Poykko S, Ukkola O, Kauma H, Savolainen M.J, Kesaniemi Y.A. Ghrelin Arg51Gln mutation is a risk factor for Type 2 diabetes and hypertension in a random sample of middle-aged subjects. Diabetologia. 2003;46:455-458. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 12739020].
Premalatha G, Shanthirani S, Deepa R, Markovitz J, Mohan V. Prevalence and risk factors of peripheral vascular disease in a selected South Indian population: the Chennai Urban Population Study. Diabetes Care. 2000;23:1295-1300. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10977021].
Prince M.J, Deeg M.A. Do n-3 fatty acids improve glucose tolerance and lipemia in diabetics?. Current Opinion in Lipidology. 1997;8:7-11. Status: Not included because article does not describe a study or survey. [pmid: 9127704].
Proctor C.A. Abnormal insulin levels and vertigo. Laryngoscope. 1981;91:1657-1662. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7026944].
Pyorala M, Miettinen H, Laakso M, Pyorala K. Hyperinsulinemia predicts coronary heart disease risk in healthy middle- aged men: The 22-year follow-up results of the Helsinki Policemen Study. Circulation. 1998;98:398-404. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9714089].
Qi S, Xu D, Peng J, Vu M.D, Wu J, Bekersky I, Fitzsimmons W.E, Peets J, Sehgal S, Daloze P, Chen H. Effect of tacrolimus (FK506) and sirolimus (rapamycin) mono- and combination therapy in prolongation of renal allograft survival in the monkey. Transplantation. 2000;69:1275-1283. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10798741].
Qiao Q, Keinanen Kukaanniemi S, Kivela S.L. Haemoglobin A(1c) measurement for diabetes among subjects with a previous history of impaired glucose tolerance. Diabetes Res Clin Pract. 1995;30:189-194. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8861458].
Qiao Q, Keinanen-Kiukaanniemi S, Rajala U, Uusimaki A, Kivela S.-L. Risk for diabetes and persistent impaired glucose tolerance among middle-aged Finns. Diabetes Res Clin Pract. 1996;33:191-198. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8922541].
Qiao Q, Rajala U, Keinanen-Kiukaanniemi S. Hypertension, hyperinsulinaemia and obesity in middle-aged Finns with impaired glucose tolerance. J Hum Hypertens. 1998;12:265-269. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9607697].
Qiao Q, Larsen S, Borch-Johnsen K, Nissinen A, Pekkanen J, Tuomilehto J, Jousilahti P, Lindstrom J, Pyorala M, Pyorala K, Balkau B, Eschwege E, Gallus G, Garancini M.P, Bouter L.M, Dekker J.M, Heine R.J, Nijpels G, Stehouwer C.D.A, Feskens E.J.M, Kromhout D, Peltonen M, Pajak A, Eriksson J. Glucose tolerance and cardiovascular mortality. Comparison of fasting and 2-hour diagnostic criteria. Arch Intern Med. 2001;161:397-405. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11176766].
Qiao Q, Tuomilehto J. Diagnostic criteria of glucose intolerance and mortality. Minerva Medica. 2001;92:113-119. Status: Not included because article does not describe a study or survey. [pmid: 11323573].
Qiao Q, Pyorala K, Pyorala M, Nissinen A, Lindstrom J, Tilvis R, Tuomilehto J. Two-hour glucose is a better risk predictor for incident coronary heart disease and cardiovascular mortality than fasting glucose.[see comment]. Eur Heart J. 2002;23:1267-1275. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12175663].
Qiao Q, Lindstrom J, Valle T.T, Tuomilehto J. Progression to clinically diagnosed and treated diabetes from impaired glucose tolerance and impaired fasting glycaemia. Diabet Med. 2003;20:1027-1033. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14632705].
Qiao Q, Jousilahti P, Eriksson J, Tuomilehto J. Predictive properties of impaired glucose tolerance for cardiovascular risk are not explained by the development of overt diabetes during follow-up. Diabetes Care. 2003;26:2910-2914. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514600].
Quatraro A, Giugliano D, De Rosa N, Minei A, Ettorre M, Donzella C, Saccomanno F, Ceriello A. Is a family history of diabetes associated with an increased level of cardiovascular risk factors? Studies in healthy people and in subjects with different degree of glucose intolerance. Diabete Metab. 1993;19:230-238. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8339854].
Quinn L. Glucose monitoring in the acutely III patient with diabetes mellitus. Critical Care Nursing Quarterly. 1998;21:85-96. Status: Not included because article does not describe a study or survey. [pmid: 10646424].
Racette S.B, Kohrt W.M, Landt M, Holloszy J.O. Response to serum leptin concentrations to 7 d of energy restriction in centrally obese African Americans with impaired or diabetic glucose tolerance. Am J Clin Nutr. 1997;66:33-37. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9209166].
Rado J.P, Banos C, Gercsak G, Molnar Z, Pato E, Csabuda M. Glucose-induced hyperkalemia developing in the upright position in captopril-treated hypertensives. Research Communications in Chemical Pathology & Pharmacology. 1982;38:161-164. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6755590].
Rahman Al-Nuaim A. High prevalence of metabolic risk factors for cardiovascular diseases among Saudi population, aged 30–64 years. Int J Cardiol. 1997;62:227-235. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9476683].
Raikkonen K, Matthews K.A, Kuller L.H. The relationship between psychological risk attributes and the metabolic syndrome in healthy women: Antecedent or consequence?. Metabolism. 2002;51:1573-1577. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12489070].
Rajala U, Laakso M, Qiao Q, Keinanen-Kiukaanniemi S. Prevalence of retinopathy in people with diabetes, impaired glucose tolerance, and normal glucose tolerance. Diabetes Care. 1998;21:1664-1669. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9773727].
Rajala U, Qiao Q, Laakso M, Keinanen-Kiukaanniemi S. Antihypertensive drugs as predictors of type 2 diabetes among subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2000;50:231-239. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11106838].
Rakotoambinina B, Delaisi B, Laborde K, Silly C, De Blic J, Lenoir G, Robert J.-J. Insulin responses to intravenous glucose and the hyperglycemic clamp in cystic fibrosis patients with different degrees of glucose tolerance. Pediatr Res. 1994;36:667-671. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 7877889].
Rakotoambinina B, Timsit J, Deschamps I, Laborde K, Gautier D, Jos J, Boitard C, Robert J.J. Insulin responses to intravenous glucose, intravenous arginine and a hyperglycaemic clamp in ICA-positive subjects with different degrees of glucose tolerance. Diabetes Metab. 1997;23:43-50. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 9059765].
Ramachandran A, Mohan V, Snehalatha M.C, Chinnikrishnudu M, Viswanathan M. Use of metformin in selected cases of NIDDM. A clinical trial. Journal of the Diabetic Association of India. 1988;28:137-139. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Ramachandran A, Snehalatha C, Shyamala P, Vijay V, Viswanathan M. High prevalence of NIDDM and IGT in an elderly south Indian population with low rates of obesity. Diabetes Care. 1994;17:1190-1192. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7821141].
Ramachandran A, Snehalatha C, Satyavani K, Vijay V. Effects of genetic predisposition on proinsulin responses in Asian Indians. Diabetes Res Clin Pract. 1998;41:71-77. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9768375].
Ramachandran A, Snehalatha C, Shobana R, Vidyavathi P, Vijay V. Influence of life style factors in development of diabetes in Indians--scope for primary prevention.[see comment]. J Assoc Physicians India. 1999;47:764-766. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10778617].
Ramaiya K.L, Swai A.B, McLarty D.G, Alberti K.G. Improvement in glucose tolerance after one year of follow-up in a Hindu community in Africa. Diabetes Res Clin Pract. 1990;10:245-255. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2073872].
Ramaiya K.L, Swai A.B, McLarty D.G, Bhopal R.S, Alberti K.G. Prevalences of diabetes and cardiovascular disease risk factors in Hindu Indian subcommunities in Tanzania. BMJ. 1991;303:271-276. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1888926]. [pmcid: 1670456].
Rao C.A, Snehalatha C. Hyper insulinism and decreased insulin sensitivity in nonobese healthy offspring of conjugal diabetic parents and individuals with IGT and NIDDM. Indian J Physiol Pharmacol. 1996;40:139-144. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9062808].
Rathmann W, Haastert B, Icks A, Lowel H, Meisinger C, Holle R, Giani G. High prevalence of undiagnosed diabetes mellitus in Southern Germany: target populations for efficient screening. The KORA survey 2000. Diabetologia. 2003;46:182-189. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12627316].
Ratzman K-P, Strese J, Rjasanowski I. Prevalence of islet cell antibodies (ICA) and islet cell surface antibodies (ICSA) in children and adolescents with antecedent mumps infection. Exp Clin Endocrinol. 1984;83:199-202. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 6539220].
Ratzmann K.P, Witt S, Ziegler M, Schulz B. Changes in carbohydrate tolerance and early insulin response to glucose in potential diabetics: a follow-up study of 2--4 years. Endokrinologie. 1980;75:89-97. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6989593].
Ratzmann K.P, Besch W, Witt S, Schulz B. Evaluation of insulin resistance during inhibition of endogenous insulin and glucagon secretion by somatostatin in non-obese subjects with impaired glucose tolerance. Diabetologia. 1981;21:192-197. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6117492].
Ratzmann K.P, Besch W, Witt S, Schulz B. Discrepant effect of the prostaglandin synthesis inhibitor acetylsalicylic acid on insulin and C-peptide response to glucose in man. Horm Metab Res. 1982;14:508-512. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6757082].
Ratzmann K.P, Witt S, Schulz B. The effect of long-term glibenclamide treatment on glucose tolerance, insulin secretion and serum lipids in subjects with impaired glucose tolerance. Diabete Metab. 1983;9:87-93. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6413265].
Ratzmann M.L, Rjasanowski I, Bruns W, Ratzmann K.P. Effects of clofibrate therapy on glucose tolerance, insulin secretion and serum lipids in subjects with hyperlipoproteinemia and impaired glucose tolerance. A follow-up study over a five-year period. Exp Clin Endocrinol. 1983;82:216-221. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6354731].
Rau H, Althoff P-H, Schmidt K, Badenhoop K, Usadel K.H. Bromocriptine treatment over 12 years in acromegaly: Effect on glucose tolerance and insulin secretion. Clin Investig. 1993;71:372-378. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Ravelli A.C.J, van der Meulen J.H.P, Michels R.P.J, Osmond C, Barker D.J.P, Hales C.N, Bleker O.P. Glucose tolerance in adults after prenatal exposure to famine. Lancet. 1998;351:173-177. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9449872].
Reaven G.M, Hollenbeck C.B, Chen Y.-D. Relationship between glucose tolerance, insulin secretion, and insulin action in non-obese individuals with varying degrees of glucose tolerance. Diabetologia. 1989;32:52-55. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 2651188].
Regensteiner J.G, Shetterly S.M, Mayer E.J, Eckel R.H, Haskell W.L, Baxter J, Hamman R.F. Relationship between habitual physical activity and insulin area among individuals with impaired glucose tolerance. Diabetes Care. 1995;18:490-497. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 7497858].
Reiser S, Bohn E, Hallfrisch J, Michaelis O.E, Keeney M, Prather E.S. Serum insulin and glucose in hyperinsulinemic subjects fed three different levels of sucrose. Am J Clin Nutr. 1981;34:2348-2358. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7030048].
Resnick H.E, Shorr R.I, Kuller L, Franse L, Harris T.B. Prevalence and clinical implications of American Diabetes Association-defined diabetes and other categories of glucose dysregulation in older adults: the health, aging and body composition study. J Clin Epidemiol. 2001;54:869-876. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11520645].
Reynolds R.M, Walker B.R, Syddall H.E, Whorwood C.B, Wood P.J, Phillips D.I. Elevated plasma cortisol in glucose-intolerant men: differences in responses to glucose and habituation to venepuncture. J Clin Endocrinol Metab. 2001;86:1149-1153. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11238500].
Riales R, Albrink M.J. Effect of chromium chloride supplementation on glucose tolerance and serum lipids including high-density lipoprotein of adult men. Am J Clin Nutr. 1981;34:2670-2678. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7032273].
Ribstein J, Du Cailar G, Mimran A. Glucose tolerance and age-associated decline in renal function of hypertensive patients. J Hypertens. 2001;19:2257-2264. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11725171].
Riccardi G, Vaccaro O, Rivellese A, Pignalosa S, Tutino L, Mancini M. Reproducibility of the new diagnostic criteria for impaired glucose tolerance. Am J Epidemiol. 1985;121:422-429. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4014132].
Riggio O, Merli M, Cangiano C. Glucose intolerance in liver cirrhosis. Metabolism. 1982;31:627-634. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7043186].
Riley W.J, Maclaren N.K, Spillar R.S. Reversal of deteriorating glucose tolerance with azathioprine in prediabetics. Transplant Proc. 1986;18:819-822. Status: Not included because article does not describe a study or survey.
Ritenbaugh C, Teufel-Shone N.I, Aickin M.G, Joe J.R, Poirier S, Dillingham D.C, Johnson D, Henning S, Cole S.M, Cockerham D. A lifestyle intervention improves plasma insulin levels among Native American high school youth. Prev Med. 2003;36:309-319. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12634022].
Rjasanowski I, Michaelis D, Besch W, Keilacker H, Ziegler B, Hildmann W. Glucose tolerance behaviour before the onset of type I (insulin-dependent) diabetes in young people as a predictor of the further course of the disease: a retrospective analysis of 33 cases. Diabetes Res Clin Pract. 1991;11:107-115. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2022175].
Roberts R.N, Henriksen J.E, Hadden D.R. Insulin sensitivity in pre-eclampsia. Br J Obstet Gynaecol. 1998;105:1095-1100. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9800933].
Roberts W.L, De B.K, Brown D, Hanbury C.M, Hoyer J.D, John W.G, Lambert T.L, Lundell R.B, Rohlfing C, Little R.R. Effects of hemoglobin C and S traits on eight glycohemoglobin methods. Clin Chem. 2002;48:383-385. Status: Not included because article does not describe a study or survey. [pmid: 11805029].
Rodriguez-Villar C, Conget I, Casamitjana R, Ercilla G, Gomis R. Effects of insulin administration in a group of high-risk, non-diabetic, first-degree relatives of Type 1 diabetic patients: an open pilot trial. Diabet Med. 1999;16:160-163. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10229311].
Rodriguez B.L, Lau N, Burchfiel C.M, Abbott R.D, Sharp D.S, Yano K, Curb J.D. Glucose intolerance and 23-year risk of coronary heart disease and total mortality: the Honolulu Heart Program. Diabetes Care. 1999;22:1262-1265. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10480768].
Rogers M.A, Yamamoto C, King D.S, Hagberg J.M, Ehsani A.A, Holloszy J.O. Improvement in glucose tolerance after 1 wk of exercise in patients with mild NIDDM. Diabetes Care. 1988;11:613-618. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3065001].
Rolandsson O, Hagg E, Nilsson M, Hallmans G, Mincheva-Nilsson L, Lernmark A. Prediction of diabetes with body mass index, oral glucose tolerance test and islet cell autoantibodies in a regional population. J Intern Med. 2001;249:279-288. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11298847].
Rolny P, Jagenburg R. Exocrine pancreatic function, fecal fat, and blood glucose in patients with pancreatitis. Scand J Gastroenterol. 1980;15:727-732. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7209383].
Ronchi C, Epaminonda P, Cappiello V, Beck-Peccoz P, Arosio M. Effects of two different somatostatin analogs on glucose tolerance in acromegaly. J Endocrinol Invest. 2002;25:502-507. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12109620].
Rosenbaum M, Hirsch J, Murphy E, Leibel R.L. Effects of changes in body weight on carbohydrate metabolism, catecholamine excretion, and thyroid function. Am J Clin Nutr. 2000;71:1421-1432. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10837281].
Rosenbloom A.L, Hunt S.S, Rosenbloom E.K, Maclaren N.K. Ten-year prognosis of impaired glucose tolerance in siblings of patients with insulin-dependent diabetes. Diabetes. 1982;31:385-387. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6759254].
Rosenfalck A.M, Hendel H, Rasmussen M.H, Almdal T, Anderson T, Hilsted J, Madsbad S. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4:19-28. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11890163].
Rowe B.R, Barnett A.H. Pre-conception counselling in Asian women with non insulin dependent diabetes and impaired glucose tolerance. Diabetes Research. 1988;8:35-38. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3224493].
Rubin R.R, Fujimoto W.Y, Marrero D.G, Brenneman T, Charleston J.B, Edelstein S.L, Fisher E.B, Jordan R, Knowler W.C, Lichterman L.C, Prince M, Rowe P.M. The Diabetes Prevention Program: recruitment methods and results. Control Clin Trials. 2002;23:157-171. Status: Not included because article does not describe a study or survey. [pmid: 11943442].
Ruderman N, Chisholm D, Pi-Sunyer X, Schneider S. The metabolically obese, normal-weight individual revisited. Diabetes. 1998;47:699-713. Status: Not included because article does not describe a study or survey. [pmid: 9588440].
Ruige J.B, Batstra M.R, Aanstoot H.J, Bouter L.M, Bruining G.J, De Neeling J.N, Heine R.J. Low prevalence of antibodies to GAD65 in a 50- to 74-year-old general Dutch population. The Hoorn Study. Diabetes Care. 1997;20:1108-1110. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9203445].
Ruige J.B, De Neeling J.N.D, Kostense P.J, Bouter L.M, Heine R.J. Performance of an NIDDM screening questionnaire based on symptoms and risk factors. Diabetes Care. 1997;20:491-496. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9096967].
Russell-briefel R, Ezzati T.M, Perlman J.A, Murphy R.S. Impaired glucose tolerance in women using oral contraceptives: United States, 1976-1980. J Chronic Dis. 1987;40:3-11. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3805231].
Rutter M.K, Parise H, Benjamin E.J, Levy D, Larson M.G, Meigs J.B, Nesto R.W, Wilson P.W.F, Vasan R.S. Impact of Glucose Intolerance and Insulin Resistance on Cardiac Structure and Function. Circulation. 2003;107:448-454. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12551870].
Ruzsa C, Fiegler M, Nagy L. Effect of indomethacin on glucose absorption and insulin release in patients with impaired glucose tolerance. Int J Clin Pharmacol Res. 1986;6:87-91. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 3522445].
Ryle A.J, Davie S, Gould B.J, Yudkin J.S. A study of the effect of diet on glycosylated haemoglobin and albumin levels and glucose tolerance in normal subjects. Diabet Med. 1990;7:865-870. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1963125].
Sacks D.B. Implications of the revised criteria for diagnosis and classification of diabetes mellitus. Clin Chem. 1997;43:2230-2232. Status: Not included because article does not describe a study or survey. [pmid: 9439437].
Sacks F.M. Dyslipidemia, prediabetes, and type 2 diabetes: clinical implications of the VA-HIT subanalysis. Advanced Studies in Medicine. 2003;3:S228-S233. Status: Not included because article does not describe a study or survey.
Saikawa T, Arita M, Yamaguchi K, Ito M. Hypoglycemic effect of cibenzoline in patients with abnormal glucose tolerance and frequent ventricular arrhythmias. Cardiovascular Drugs & Therapy. 2000;14:665-669. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11300368].
Salemans T.H, Dieijen-Visser M.P, Brombacher P.J. The value of HbA1 and fructosamine in predicting impaired glucose tolerance--an alternative to OGTT to detect diabetes mellitus or gestational diabetes. ANN CLIN BIOCHEM. 1987;24:447-452. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3662394].
Salobir B, Prezelj J, Kocijancic A, Meden-Vrtovec H. Basal glucose level as an independent predictor of fertilization rate in patients without polycystic ovary syndrome included in an in-vitro fertilization program. Wien Klin Wochenschr. 2002;114:454-457. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12422580].
Salomaa V.V, Strandberg T.E, Vanhanen H, Naukkarinen V, Sarna S, Miettinen T.A. Glucose tolerance and blood pressure: long term follow up in middle aged men [published erratum appears in BMJ 1991 Apr 20;302(6782):939]. BMJ. 1991;302:493-496. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2012844]. [pmcid: 1669625].
Salomaa V.V, Tuomilehto J, Jauhiainen M, Korhonen H.J, Stengard J, Uusitupa M, Pitkanen M, Penttila I. Hypertriglyceridemia in different degrees of glucose intolerance in a Finnish population-based study. Diabetes Care. 1992;15:657-665. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1516486].
Saloranta C, Guitard C, Pecher E, Pablos-Velasco P, Lahti K, Brunel P, Groop L. Nateglinide improves early insulin secretion and controls postprandial glucose excursions in a prediabetic population. Diabetes Care. 2002;25:2141-2146. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12453951].
Sandhu M.S, Heald A.H, Gibson J.M, Cruickshank J.K, Dunger D.B, Wareham N.J. Circulating concentrations of insulin-like growth factor-I and development of glucose intolerance: a prospective observational study. Lancet. 2002;359:1740-1745. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12049864].
Sane T, Taskinen M.R. Does familial hypertriglyceridemia predispose to NIDDM?. Diabetes Care. 1993;16:1494-1501. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8299439].
Sann L, Morel Y, Lasne Y. Effect of hydrocortisone on intravenous glucose tolerance in small-for-gestational-age infants. Helv Paediatr Acta. 1983;38:475-482. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6365846].
Santer R, Hillebrand G, Steinmann B, Schaub J. Intestinal glucose transport: Evidence for a membrane traffic-based pathway in humans. Gastroenterology. 2003;124:34-39. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12512027].
Santomauro A.T, Boden G, Silva M.E, Rocha D.M, Santos R.F, Ursich M.J, Strassmann P.G, Wajchenberg B.L. Overnight lowering of free fatty acids with Acipimox improves insulin resistance and glucose tolerance in obese diabetic and nondiabetic subjects. Diabetes. 1999;48:1836-1841. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10480616].
Sarioglu B, Ozerkan E, Can S, Yaprak I, Topcuoglu R. Insulin secretion and insulin resistance determined by euglycemic clamp. J Pediatr Endocrinol Metab. 1998;11:27-33. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9642626].
Sarkkinen E, Schwab U, Niskanen L, Hannuksela M, Savolainen M, Kervinen K, Kesaniemi A, Uusitupa M.I. The effects of monounsaturated-fat enriched diet and polyunsaturated-fat enriched diet on lipid and glucose metabolism in subjects with impaired glucose tolerance. Eur J Clin Nutr. 1996;50:592-598. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 8880038].
Sartor G, Schersten B, Carlstrom S, Melander A, Norden A, Persson G. Ten-year follow-up of subjects with impaired glucose tolerance: prevention of diabetes by tolbutamide and diet regulation. Diabetes. 1980;29:41-49. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7380107].
Sas T, Muinck Keizer-Schrama S, Aanstoot H.J, Stijnen T, Drop S. Carbohydrate metabolism during growth hormone treatment and after discontinuation of growth hormone treatment in girls with Turner syndrome treated with once or twice daily growth hormone injections. Clin Endocrinol (Oxf). 2000;52:741-747. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10848879].
Sas T, Mulder P, Aanstoot H.J, Houdijk M, Jansen M, Reeser M, Hokken-Koelega A. Carbohydrate metabolism during long-term growth hormone treatment in children with short stature born small for gestational age. Clin Endocrinol (Oxf). 2001;54:243-251. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11207640].
Sas T.C, de Muinck Keizer-Schrama S.M, Stijnen T, Aanstoot H.J, Drop S.L. Carbohydrate metabolism during long-term growth hormone (GH) treatment and after discontinuation of GH treatment in girls with Turner syndrome participating in a randomized dose-response study. Dutch Advisory Group on Growth Hormone. J Clin Endocrinol Metab. 2000;85:769-775. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10690889].
Sasaki A, Suzuki T, Horiuchi N. Development of diabetes in Japanese subjects with impaired glucose tolerance: a seven year follow-up study. Diabetologia. 1982;22:154-157. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7075915].
Sasaki S, Kuwahara N, Kunitomo K, Harada S, Yamada T, Azuma A, Takeda K, Nakagawa M. Effects of atorvastatin on oxidized low-density lipoprotein, low-density lipoprotein subfraction distribution, and remnant lipoprotein in patients with mixed hyperlipoproteinemia. Am J Cardiol. 2002;89:386-389. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11835916].
Sasaki T.M, Gray R.S, Ratner R.E, Currier C, Aquino A, Barhyte D.Y, Light J.A. Successful long-term kidney-pancreas transplants in diabetic patients with high C-peptide levels. Transplantation. 1998;65:1510-1512. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9645815].
Saukkonen T, Vaisanen S, Akerblom H.K, Savilahti E, Tuomilehto J, Lounamaa R, Toivanen L, Kaprio E.A, Virtala E, Pitkaniemi J, Fagerlund A, Flittner M, Gustafsson B, Haggqvist C, Hakulinen A, Herva L, Hiltunen P, Huhtamaki T, Huttunen N-P, Huupponen T, Hyttinen M, Joki T, Jokisalo R, Kaar M-L, Kallio S, Kaprio E.A, Kaski U, Knip M, Laine L, Lappalainen J, Maenpaa J, Makela A-L, Niemi K, Niiranen A, Ojajarvi P, Otonkoski T, Pihlajamaki K, Pontynen S, Rajantie J, Sankala J, Schumacher J, Sillanpaa M, Stahlberg M-R, Strahlmann C-H, Uotila T, Vare M, Varimo P, Aro A, Hiltunen M, Hurme H, Hyoty H, Ilonen J, Karjalainen J, Knip M, Leinikki P, Miettinen A, Petays T, Reijonen H, Rasanen L, Reunanen A, Saukkonen T, Savilahti E, Tuomilehto-Wolf E, Vahasalo P, Virtanen S.M. Coeliac disease in children and adolescents with type 1 diabetes: A study of growth, glycaemic control, and experiences of families. Acta Paediatr. 2002;91:297-302. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12022302].
Sayeed M.A, Banu A, Malek M.A, Khan A.K. Blood pressure and coronary heart disease in NIDDM subjects at diagnosis: prevalence and risks in a Bangladeshi population. Diabetes Res Clin Pract. 1998;39:147-155. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9597385].
Schaefer-Graf U.M, Kjos S.L, Kilavuz O, Plagemann A, Brauer M, Dudenhausen J.W, Vetter K. Determinants of fetal growth at different periods of pregnancies complicated by gestational diabetes mellitus or impaired glucose tolerance.[erratum appears in Diabetes Care. 2003 Apr;26(4):1329]. Diabetes Care. 2003;26:193-198. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12502680].
Schafer-Graf U.M, Dupak J, Vogel M, Dudenhausen J.W, Kjos S.L, Buchanan T.A, Vetter K. Hyperinsulinism, neonatal obesity and placental immaturity in infants born to women with one abnormal glucose tolerance test value. J Perinat Med. 1998;26:27-36. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9595364].
Scheen A.J, Letiexhe M.R, Lefebvre P.J. Short administration of metformin improves insulin sensitivity in android obese subjects with impaired glucose tolerance. Diabet Med. 1995;12:985-989. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because no extractable data was relevant to review. [pmid: 8582131].
Scheen A.J, Ernest P. New antiobesity agents in type 2 diabetes: overview of clinical trials with sibutramine and orlistat. [Review] [91 refs]. Diabetes Metab. 2002;28:437-445. Status: Not included because article does not describe a study or survey. [pmid: 12522323].
Scheidt-Nave C, Barrett-Connor E, Wingard D.L, Cohn B.A, Edelstein S.L. Sex differences in fasting glycemia as a risk factor for ischemic heart disease death. Am J Epidemiol. 1991;133:565-576. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2006643].
Schmader K.E. Epidemiology and impact on quality of life of postherpetic neuralgia and painful diabetic neuropathy. Clinical Journal of Pain. 2002;18:350-354. Status: Not included because article does not describe a study or survey. [pmid: 12441828].
Schmid S, Molteni A, Fuchtenbusch M, Naserke H.E, Ziegler A.-G, Bonifacio E. Reduced IL-4 associated antibody responses to vaccine in early pre-diabetes. Diabetologia. 2002;45:677-685. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12107748].
Schoen R.E, Tangen C.M, Kuller L.H, Burke G.L, Cushman M, Tracy R.P, Dobs A, Savage P.J. Increased blood glucose and insulin, body size, and incident colorectal cancer. J Natl Cancer Inst. 1999;19:1147-1154. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Schranz A, Tuomilehto J, Marti B, Jarrett R.J, Grabauskas V, Vassallo A. Low physical activity and worsening of glucose tolerance: results from a 2-year follow-up of a population sample in Malta. Diabetes Res Clin Pract. 1991;11:127-136. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2022178].
Schranz A.G, Savona-Ventura C. Long-term significance of gestational carbohydrate intolerance: a longitudinal study. Experimental & Clinical Endocrinology & Diabetes. 2002;110:219-222. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12148085].
Schultz-Larsen K, Avlund K, Kreiner S. Functional ability of community dwelling elderly. Criterion-related validity of a new measure of functional ability. J Clin Epidemiol. 1992;45:1315-1326. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1432011].
Schultz Susan K, Arndt Stephan, Ho Beng Choon, Oliver Susan E, Andreasen Nancy C. Impaired glucose tolerance and abnormal movements in patients with schizophrenia. American-Journal-of-Psychiatry. 1999;156:640-642. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10200749].
Schulz B, Ratzmann K.P, Heinke P, Besch W. A stimulatory effect of tolbutamide on the insulin-mediated glucose uptake in subjects with impaired glucose tolerance (IGT). Exp Clin Endocrinol. 1983;82:222-231. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6354732].
Schulz B, Witt S, Hildmann W, Ratzmann K.P, Strese J, Keilacker H. Islet cell antibodies in individuals at increased risk for IDDM. Exp Clin Endocrinol. 1984;83:192-198. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 6373322].
Schulz L.O, Weidensee R.C. Glucose tolerance and physical activity in a Mexican indigenous population. Diabetes Care. 1995;18:1274-1276. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8612443].
Schutz Y, Golay A, Felber J.P, Jequier E. Decreased glucose-induced thermogenesis after weight loss in obese subjects: a predisposing factor for relapse of obesity?. Am J Clin Nutr. 1984;39:380-387. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6695838].
Schwab I.R, Dawson C.R, Hoshiwara I, Szuter C.F, Knowler W.C. Incidence of cataract extraction in Pima Indians. Diabetes as a risk factor. Arch Ophthalmol. 1985;103:208-212. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 3883967].
Schwab U.S, Sarkkinen E.S, Lichtenstein A.H, Li Z, Ordovas J.M, Schaefer E.J, Uusitupa M.I. The effect of quality and amount of dietary fat on the susceptibility of low density lipoprotein to oxidation in subjects with impaired glucose tolerance. Eur J Clin Nutr. 1998;52:452-458. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 9683400].
Schwartz G.G, Il'yasova D, Ivanova A. Urinary cadmium, impaired fasting glucose, and diabetes in the NHANES III. Diabetes Care. 2003;26:468-470. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12547882].
Schwarz J-M, Mulligan K, Lee J, Lo J.C, Wen M, Noor M.A, Grunfeld C, Schambelan M. Effects of recombinant human growth hormone on hepatic lipid and carbohydrate metabolism in HIV-infected patients with fat accumulation. J Clin Endocrinol Metab. 2002;87:942-945. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11836345].
Scott, R. D., Kritz-Silverstein, D., Barrett-Connor, E., and Wiederholt, W. C. The association of non-insulin-dependent diabetes mellitus and cognitive function in an older cohort. Journal of the American Geriatrics Society 46(10):1217–22, 1998 Oct (39 ref) 1998; 1217–1222. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design
Seccia T.M, Vulpis V, Ricci S, Pirrelli A. The effects of nitrendipine on glucose tolerance and immunoreactive insulin levels in hypertensive patients. Current Therapeutic Research, Clinical & Experimental. 1994;55:1323-1334. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design.
Seibaek M, Sloth C, Vallebo L, Hansen T, Urhammer S.A, Burchardt H, Torp-Pedersen C, Pedersen O, Hildebrandt P. Glucose tolerance status and severity of coronary artery disease in men referred to coronary arteriography. Am Heart J. 1997;133:622-629. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9200389].
Sermer M, Naylor C.D, Gare D.J, Kenshole A.B, Ritchie J.W, Farine D, Cohen H.R, McArthur K, Holzapfel S, Biringer A. Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. Am J Obstet Gynecol. 1995;173:146-156. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7631672].
Shaten B.J, Smith G.D, Kuller L.H, Neaton J.D. Risk factors for the development of type II diabetes among men enrolled in the usual care group of the Multiple Risk Factor Intervention Trial. Diabetes Care. 1993;16:1331-1339. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8269790].
Shaw J.E, Hodge A.M, de Court Chitson P, Zimmet P.Z. Isolated post-challenge hyperglycaemia confirmed as a risk factor for mortality. Diabetologia. 1999;42:1050-1054. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10447514].
Shelgikar K.M, Naik S.S, Khopkar M, Bhat D.S, Raut K.N, Joglekar C.V, Gerard M.E, Yajnik C.S. Circulating lipids and cardiovascular risk in newly diagnosed non-insulin-dependent diabetic subjects in India. Diabet Med. 1997;14:757-761. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9300225].
Shetty A, Wilson S, Kuo P, Laurin J.L, Howell C.D, Johnson L, Allen E.M. Liver transplantation improves cirrhosis-associated impaired oral glucose tolerance. Transplantation. 2000;69:2451-2454. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10868659].
Shimizu H, Shouzu A, Nishikawa U, Omoto S, Hayakawa T, Miyake Y, Yonemoto T, Inada M. Serum concentration and renal handling of 1,5-anhydro-D-glucitol in patients with chronic renal failure. ANN CLIN BIOCHEM. 1999;36:749-754. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10586312].
Shimokata H, Muller D.C, Fleg J.L, Sorkin J, Ziemba A.W, Andres R. Age as independent determinant of glucose tolerance. Diabetes. 1991;40:44-51. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2015973].
Shinohara R, Ohta Y, Yamauchi M, Ishiguro I. Improved fluorometric enzymatic sorbitol assay in human blood. Clin Chim Acta. 1998;273:171-184. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9657347].
Shinozaki K, Suzuki M, Ikebuchi M, Takaki H, Hara Y, Tsushima M, Harano Y. Insulin resistance associated with compensatory hyperinsulinemia as an independent risk factor for vasospastic angina. Circulation. 1995;92:1749-1757. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 7671357].
Shinozaki K, Suzuki M, Ikebuchi M, Hirose J, Hara Y, Harano Y. Improvement of insulin sensitivity and dyslipidemia with a new a-glucosidase inhibitor, Voglibose, in nondiabetic hyperinsulinemic subjects. Metabolism. 1996;45:731-737. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 8637448].
Shinozaki K, Naritomi H, Shimizu T, Suzuki M, Ikebuchi M, Sawada T, Harano Y. Role of insulin resistance associated with compensatory hyperinsulinemia in ischemic stroke. Stroke. 1996;27:37-43. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8553400].
Shionoiri H, Miyakawa T, Takasaki I. Glucose tolerance during chronic captopril therapy in patients with essential hypertension. J Cardiovasc Pharmacol. 1987;9:160-164. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2435993].
Shionoiri H, Sugimoto K-I, Minamisawa K, Ueda S-I, Ebina T, Matsukawa T, Gotoh E, Ishii M. Glucose and lipid metabolism during long-term treatment with cilazapril in hypertensive patients with or without impaired glucose metabolism. J Cardiovasc Pharmacol. 1990;15:933-938. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1694916].
Shionoiri H, Gotoh E, Ito T, Hata T, Iwatsubo H, Takegawa K, Ogihara T, Mikami H, Ikegami H, Otsuka A. Long-term therapy with terazosin may improve glucose and lipid metabolism in hypertensives: a multicenter prospective study. Am J Med Sci. 1994;307(Suppl 1):S91-S95. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7908168].
Shionoiri H, Takasaki I, Naruse M, Nagamoti I, Himeno H, Ito T, Ohtomi S, Hata T, Shindo K, Mikami H. Effect of cilazapril therapy on glucose and lipid metabolism in patients with hypertension. Clin Ther. 1995;17:1126-1135. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8750404].
Shionoiri H, Ashino K, Yamanaka K, Shindo K, Hiroto S, Arita T. Effect of doxazosin therapy on glucose tolerance and lipid metabolism in hypertensive patients with impaired glucose tolerance. Clin Ther. 1997;19:527-536. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9220217].
Sicree R.A, Zimmet P.Z, King H, Coventry J.S. Weight change amongst Nauruans over 6.5 years: extent, and association with glucose intolerance. Diabetes Res Clin Pract. 1987;3:327-336. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3665732].
Sicree R.A, Zimmet P.Z, King H.O.M, Coventry J.S. Plasma insulin response among nauruans. Diabetes. 1987;36:179-185. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3542644].
Sievenpiper J.L, Jenkins D.J.A, Josse R.G, Leiter L.A, Vuksan V. Simple skinfold-thickness measurements complement conventional anthropometric assessments in predicting glucose tolerance. Am J Clin Nutr. 2001;73:567-573. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11237933].
Sigurdsson G, Gottskalksson G, Thorsteinsson T, Davidsson D, Olafsson O, Samuelsson S, Sigfusson N. Community screening for glucose intolerance in middle-aged Icelandic men. Deterioration to diabetes over a period of 71/2 years. Acta Medica Scandinavica. 1981;210:21-26. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7293824].
Silfverstolpe G, Gustafson A, Samsioe G, Svanborg A. Lipid metabolic studies in oophorectomised women: Effects on serum lipids and lipoproteins of three synthetic progestogens. Maturitas. 1982;4:103-111. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6811837].
Silverman B.L, Metzger B.E, Cho N.H, Loeb C.A. Impaired glucose tolerance in adolescent offspring of diabetic mothers: relationship to fetal hyperinsulinism. Diabetes Care. 1995;18:611-617. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8585997].
Silverman B.L, Rizzo T.A, Cho N.H, Metzger B.E. Long-term effects of the intrauterine environment. The Northwestern University Diabetes in Pregnancy Center. Diabetes Care. 1998;21(Suppl 2):B142-B149. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 9704242].
Singh M.M, Biswas S.K, Shah A. Impaired glucose tolerance in active pulmonary tuberculosis. Indian Journal of Tuberculosis. 1984;31:118-121. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Singh R.B, Niaz M.A, Ghosh S. Effect on central obesity and associated distrubances of low-energy, fruit- and vegetable-enriched prudent diet in North Indians. Postgrad Med J. 1994;70:895-900. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7870637]. [pmcid: 2398005].
Singleton J.R, Smith A.G, Bromberg M.B. Painful sensory polyneuropathy associated with impaired glucose tolerance. Muscle & Nerve. 2001;24:1225-1228. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11494277].
Sinha R, Fisch G, Teague B, Tamborlane W.V, Banyas B, Allen K, Savoye M, Rieger V, Taksali S, Barbetta G, Sherwin R.S, Caprio S. Prevalence of impaired glucose tolerance among children and adolescents with marked obesity. N Engl J Med. 2002;346:802-810. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11893791].
Sirtori C.R, Paoletti R, Mancini M, Crepaldi G, Manzato E, Rivellese A, Pamparana F, Stragliotto E. n-3 Fatty acids do not lead to an increased diabetic risk in patients with hyperlipidemia and abnormal glucose tolerance. Am J Clin Nutr. 1997;65:1874-1881. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 9174486].
Sirtori C.R, Crepaldi G, Manzato E, Mancini M, Rivellese A, Paoletti R, Pazzucconi F, Pamparana F, Stragliotto E. One-year treatment with ethyl esters of n-3 fatty acids in patients with hypertriglyceridemia and glucose intolerance: reduced triglyceridemia, total cholesterol and increased HDL-C without glycemic alterations. Atherosclerosis. 1998;137:419-427. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9622285].
Skouby S.O, Molsted-Pedersen L, Kuhl C. Low dosage oral contraception in women with previous gestational diabetes. Obstet Gynecol. 1982;59:325-328. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6804901].
Slabber M, Barnard H.C, Kuyl J.M, Dannhauser A, Schall R. Effects of a low-insulin-response, energy-restricted diet on weight loss and plasma insulin concentrations in hyperinsulinemic obese females. Am J Clin Nutr. 1994;60:48-53. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8017337].
Slama G. The potential of metformin for diabetes prevention. Diabetes Metab. 2003;29:6S104-6S111. Status: Not included because article does not describe a study or survey. [pmid: 14502107].
Slama G. The potential of metformin for diabetes prevention. Diabetes Metab. 2003;29:104-111. Status: Not included because article does not describe a study or survey.
Smith A.G, Ramachandran P, Tripp S, Singleton J.R. Epidermal nerve innervation in impaired glucose tolerance and diabetes-associated neuropathy. Neurology. 2001;57:1701-1704. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11706115].
Smith G.D, Egger M, Shipley M.J, Marmot M.G. Post-challenge glucose concentration, impaired glucose tolerance, diabetes, and cancer mortality in men. Am J Epidemiol. 1992;136:1110-1114. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1462971].
Smith N.L, Savage P.J, Heckbert S.R, Barzilay J.I, Bittner V.A, Kuller L.H, Psaty B.M. Glucose, blood pressure, and lipid control in older people with and without diabetes mellitus: the Cardiovascular Health Study. J Am Geriatr Soc. 2002;50:416-423. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11943034].
Smith S.M, Davis-Street J.E, Fontenot T.B, Lane H.W. Assessment of a portable clinical blood analyzer during space flight. Clin Chem. 1997;43:1056-1065. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9191561].
Smutok M.A, Reece C, Kokkinos P.F, Farmer C.M, Dawson P.K, DeVane J, Patterson J, Goldberg A.P, Hurley B.F. Effects of exercise training modality on glucose tolerance in men with abnormal glucose regulation. Int J Sports Med. 1994;15:283-289. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7822064].
Snehalatha C, Ramachandran A, Satyavani K, Vijay V, Haffner S.M. Specific insulin and proinsulin concentrations in nondiabetic South Indians. Metabolism. 1998;47:230-233. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9472976].
Snehalatha C, Ramachandran A, Saltyamurthy I, Satyavani K, Sivasankari S, Misra J, Viswanathan V. Association of proinsulin and insulin resistance with coronary artery disease in non-diabetic south Indian men. Diabet Med. 2001;18:706-708. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11606167].
Snehalatha C, Vijay V, Suresh Mohan R, Satyavani K, Sivasankari S, Megha T, Radhika S, Ramachandran A. Lack of association of insulin resistance and carotid intimal medial thickness in non-diabetic Asian Indian subjects. Diabetes Metab Res Rev. 2001;17:444-447. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 11757080].
Solano M.P, Perry A.C, Wang X, Ross R, Goldberg R.B. Insulin resistance but not visceral adipose tissue is associated with plasminogen activator inhibitor type 1 levels in overweight and obese premenopausal African-American women. Int J Obes. 2003;27:82-87. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Soliman A.T, Al Suwaid A.R, Gamil H, Asfour M. Prevalence and significance of acanthosis nigricans in children and adolescents. Annals of Saudi Medicine. 1996;16:424-428. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 17372496].
Solnica B, Naskalski J.W. Evaluation of analytical performance of Super G1, Super G2+ and Biosen 5030 glucose amperometric analyzers. Clinical Laboratory. 2003;49:233-238. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 15285179].
Solomon C.G, Graves S.W, Greene M.F, Seely E.W. Glucose intolerance as a predictor of hypertension in pregnancy. Hypertension. 1994;23:717-721. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8206568].
Solomon M.P, Wilson D.C, Corey M, Kalnins D, Zielenski J, Tsui L, Pencharz P, Durie P, Sweezey N.B. Glucose intolerance in children with cystic fibrosis. J Pediatr. 2003;142:128-132. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12584532].
Solymoss B.C, Bourassa M.G, Campeau L, Lesperance J, Marcil M, Varga S. Incidence, coronary risk profile and angiographic characteristics of prediabetic and diabetic patients in a population with ischemic heart disease. Canadian Journal of Cardiology. 2003;19:1155-1160. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 14532941].
Sosenko J.M, Kato M, Soto R, Goldberg R.B. Sensory function at diagnosis and in early stages of NIDDM in patients detected through screening [see comments]. Diabetes Care. 1992;15:847-852. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1516503].
Spiller H.A, Weber J.A, Winter M.L, Klein-Schwartz W, Hofman M, Gorman S.E, Stork C.M, Krenzelok E.P. Multicenter case series of pediatric metformin ingestion. Ann Pharmacother. 2000;34:1385-1388. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11144693].
Sprafka J.M, Xue S, Bushhouse S.A, French L.R, Martinez A.M, Goetz F.C. Cardiovascular disease risk factors and glucose tolerance: The Wadena City Health Study. Ann Epidemiol. 1992;2:647-656. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 1342316].
Srinivasan S.R, Myers L, Berenson G.S. Predictability of childhood adiposity and insulin for developing insulin resistance syndrome (syndrome X) in young adulthood: The Bogalusa Heart Study. Diabetes. 2002;51:204-209. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11756342].
Steffen L.M, Jacobs D.R Jr, Murtaugh M.A, Moran A, Steinberger J, Hong C.P, Sinaiko A.R. Whole grain intake is associated with lower body mass and greater insulin sensitivity among adolescents. Am J Epidemiol. 2003;158:243-250. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12882946].
Steinmueller T, Konrad T, Jonas S, Tullius S, Bechstein W.O, Mueller A, Platz K.P, Neumann U, Vicini P, Toffolo G, Cobelli C, Usadel K.H, Neuhaus P. The effect of cyclosporine vs FK 506 on glucose metabolism. Transplant Proc. 1999;31:1129-1130. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10083504].
Stengard J.H, Tuomilehto J, Pekkanen J, Kivinen P, Kaarsalo E, Nissinen A, Karvonen M.J. Diabetes mellitus, impaired glucose tolerance and mortality among elderly men: the Finnish cohorts of the Seven Countries Study. Diabetologia. 1992;35:760-765. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1511803].
Stengard J.H, Pekkanen J, Tuomilehto J, Kivinen P, Kaarsalo E, Tamminen M, Nissinen A, Karvonen M.J. Changes in glucose tolerance among elderly Finnish men during a five-year follow-up: the Finnish cohorts of the Seven Countries Study. Diabete Metab. 1993;19:121-129. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8314414].
Stern M.P, Williams K, Haffner S.M. Identification of persons at high risk for type 2 diabetes mellitus: do we need the oral glucose tolerance test?. Annals of Internal Medicine. 2002;136:575-581. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11955025].
Stoddart M.L, Blevins K.S, Lee E.T, Wang W, Blackett P.R. Cherokee Diabetes Study. Association of acanthosis nigricans with hyperinsulinemia compared with other selected risk factors for type 2 diabetes in Cherokee Indians: the Cherokee Diabetes Study. Diabetes Care. 2002;25:1009-1014. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12032107].
Stone L.M, Kahn S.E, Deeb S.S, Fujimoto W.Y, Porte D Jr. Glucokinase gene variations in Japanese-Americans with a family history of NIDDM. Diabetes Care. 1994;17:1480-1483. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7882822].
Storgaard H, Jensen C.B, Vaag A.A, Volund A, Madsbad S. Insulin secretion after short- and long-term low-grade free fatty acid infusion in men with increased risk of developing type 2 diabetes. Metabolism. 2003;52:885-894. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 12870166].
Stowers J.M, Sutherland H.W, Kerridge D.F. Long-range implications for the mother. The Aberdeen experience. Diabetes. 1985;34:106-110. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3888735].
Strand C.L, Garcia H, Costales F. Hyponatremia in spontaneous hyperglycemia: Correlation studies in 100 patients. Clin Chem. 1987;33:1941-1942. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3665062].
Suematsu C, Hayashi T, Fujii S, Endo G, Tsumura K, Okada K, Morii H. Impaired fasting glucose and the risk of hypertension in Japanese men between the 1980s and the 1990s. The Osaka Health Survey. Diabetes Care. 1999;22:228-232. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10333938].
Sum C-F, Webster J.M, Johnson A.B, Catalano C, Cooper B.G, Taylor R. The effect of intravenous metformin on glucose metabolism during hyperglycaemia in Type 2 diabetes. Diabet Med. 1992;9:61-65. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1551312].
Sun B, Wang X, Song Q, Wang Y, Xue L, Wang C, Quan Z, Zhang Y, Niu P. Prospective studies on the relationship between the 50 g glucose challenge test and pregnant outcome. Chin Med J (Engl). 1995;108:910-913. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8728943].
Suvd J, Gerel B, Otgooloi H, Purevsuren D, Zolzaya H, Roglic G, King H. Glucose intolerance and associated factors in Mongolia: results of a national survey. Diabet Med. 2002;19:502-508. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12060063].
Suzuki H, Jae Ho Rhim. Effect of samgyetang feeding on plasma lipids, glucose, glycosylated hemoglobin, and stress-induced gastric ulcers in mice. Nutrition Research. 2000;20:575-584. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Suzuki M, Nishizaki M, Arita M, Kakuta T, Numano F. Impaired glucose tolerance with late hypersecretion of insulin during oral glucose tolerance test in patients with vasospastic angina. J Am Coll Cardiol. 1996;27:1458-1463. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8626958].
Suzuki S, Kawasaki H, Satoh Y, Ohtomo M, Hirai M, Hirai A, Hirai S, Onoda M, Matsumoto M, Hinokio Y, Akai H, Craig J, Larner J, Toyota T. Urinary chiro-inositol excretion is an index marker of insulin sensitivity in Japanese type II diabetes. Diabetes Care. 1994;17:1465-1468. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7882818].
Swinburn B.A, Woollard G.A, Chang E.C, Wilson M.R. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. Journal of the American Dietetic Association. 1999;99:1400-1405. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10570677].
Swinburn B.A, Metcalf P.A, Ley S.J. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24:619-624. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11315819].
Swinn R.A, Wareham N.J, Gregory R, Curling V, Clark P.M, Dalton K.J, Edwards O.M, O'Rahilly S. Excessive secretion of insulin precursors characterizes and predicts gestational diabetes. Diabetes. 1995;44:911-915. : Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7621996].
Szabo C, Zanchi A, Komjati K, Pacher P, Krolewski A.S, Quist W.C, LoGerfo F.W, Horton E.S, Veves A. Poly(ADP-Ribose) polymerase is activated in subjects at risk of developing type 2 diabetes and is associated with impaired vascular reactivity. Circulation. 2002;106:2680-2686. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12438293].
Tahvanainen E, Molin M, Vainio S, Tiret L, Nicaud V, Farinaro E, Masana L, Ehnholm C. Intestinal fatty acid binding protein polymorphism at codon 54 is not associated with postprandial responses to fat and glucose tolerance tests in healthy young Europeans. Results from EARS II participants. Atherosclerosis. 2000;152:317-325. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10998459].
Tajra L.C, Dubernard J.M, Dawhara M, Lefrancois N, Badet L, Martin X. Long-term metabolic control and pancreatic graft survival according to surgical technique. Transplant Proc. 1999;31:3192-3193. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10616436].
Takasaki I, Shionoiri H, Hiroto S, Yasuda G, Gotoh E, Umemura S, Kaneko Y. Long-term captopril therapy with no effect on glucose metabolism in patients with essential hypertension. Am J Hypertens. 1988;1:217S-220S. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 3046627].
Takata Y, Ou O, Nishida H, Sakagami K. Impact of self-monitoring of blood glucose on the lifestyles of subjects with fasting hyperglycemia: A randomized controlled trial. Journal of Occupational Health. 2002;44:28-33. Status: Not included because article was not published in English.
Takebayashi K, Sugita R, Tayama K, Aso Y, Takemura Y, Inukai T. The connection between QT dispersion and autonomic neuropathy in patients with type 2 diabetes. Experimental & Clinical Endocrinology & Diabetes. 2003;111:351-357. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14520602].
Takemura Y, Kikuchi S, Inaba Y, Yasuda H, Nakagawa K. The protective effect of good physical fitness when young on the risk of impaired glucose tolerance when old. Prev Med. 1999;28:14-19. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9973583].
Takeuchi M, Kanazawa A, Suzuki M, Hasegawa M, Kimura Y, Kodama K, Ryomoto K, Hattori Y, Harano Y. Evaluation of factors during OGTT to correlate insulin resistance in non-diabetic subjects. Endocr J. 2000;47:535-542. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 11200932].
Takino H, Okuno S, Uotani S, Yano M, Matsumoto K, Kawasaki E, Takao Y, Yamasaki H, Yamaguchi Y, Akazawa S, Nagataki S. Increased insulin responsiveness after CS-045 treatment in diabetes associated with Werner's syndrome. Diabetes Res Clin Pract. 1994;24:167-172. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7988348].
Tan E.C.T.H, De Keijzer M.H, Goris R.J.A. Capillary blood gas analysis in complex regional pain syndrome: A pilot study. ANN CLIN BIOCHEM. 2003;40:569-571. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14503998].
Tan Y.Y, Yeo G.S. Impaired glucose tolerance in pregnancy--is it of consequence?. Aust N Z J Obstet Gynaecol. 1996;36:248-255. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8883744].
Taniguchi A, Nakai Y, Doi K, Fukushima M, Nagata I, Kawamura H, Imura H, Suzuki M, Tokuyama K. Glucose effectiveness in two subtypes within impaired glucose tolerance. Diabetes. 1994;43:1211-1217. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 7926290].
Taniguchi A, Nakai Y, Fukushima M, Imura H, Kawamura H, Nagata I, Florant G.L, Tokuyama K. Insulin sensitivity, insulin secretion, and glucose effectiveness in subjects with impaired glucose tolerance: A minimal model analysis. Metabolism. 1994;43:714-718. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8201959].
Tankova T, Dakovska L, Kirilov G, Koev D. Insulin secretion and anti-GAD65 antibodies in subjects with impaired glucose tolerance. Experimental & Clinical Endocrinology & Diabetes. 2001;109:355-360. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11573145].
Tapp R.J, Shaw J.E, Harper C.A, de Court Balkau B, McCarty D.J, Taylor H.R, Welborn T.A, Zimmet P.Z. AusDiab Study Group. The prevalence of and factors associated with diabetic retinopathy in the Australian population. Diabetes Care. 2003;26:1731-1737. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12766102].
Teixeira C.C, Fuchs F.D, Blotta R.M, Knijnik J, Delgado I.C, Netto M.S, Ferreira E, Costa A.P, Mussnich D.G, Ranquetat G.G. Effect of tea prepared from leaves of Syzygium jambos on glucose tolerance in nondiabetic subjects. Diabetes Care. 1990;13:907-908. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2209336].
Temelkova-Kurktschiev T, Koehler C, Henkel E, Hanefeld M. Leukocyte count and fibrinogen are associated with carotid and femoral intima-media thickness in a risk population for diabetes. Cardiovasc Res. 2002;56:277-283. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 12393098].
Ten Boekel E, De Kieviet W, Bartels P.C.M. Subjects with a shortened activated partial thromboplastin time show increased in-hospital mortality associated with elevated D-dimer, C-reactive protein and glucose levels. Scand J Clin Lab Invest. 2003;63:441-448. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14594325].
Tenenbaum A, Motro M, Fisman E.Z, Boyko V, Mandelzweig L, Reicher-Reiss H, Graff E, Brunner D, Behar S. Clinical impact of borderline and undiagnosed diabetes mellitus in patients with coronary artery disease. Am J Cardiol. 2000;86:1363-1366. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11113414].
Tenerz A, Norhammar A, Silveira A, Hamsten A, Nilsson G, Ryden L, Malmberg K. Diabetes, insulin resistance, and the metabolic syndrome in patients with acute myocardial infarction without previously known diabetes. Diabetes Care. 2003;26:2770-2776. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514578].
Tesfaye S. Diabetic neuropathy: Current treatment and potential therapeutic approaches. Diabetes Nutr Metab. 1994;7:375-379. Status: Not included because article does not describe a study or survey.
Testori G.P, Ferrari C, Lepore R, Boghen M. Effect of gemfibrozil treatment on glucose tolerance in hypertriglyceridemic patients with normal or impaired glucose tolerance. Current Therapeutic Research, Clinical & Experimental. 1990;47:390-395. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Teuscher A, Schnell H, Wilson P.W.F. Incidence of diabetic retinopathy and relationship to baseline plasma glucose and blood pressure. Diabetes Care. 1988;11:246-251. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3416678].
The ALLHAT Officers and Coordinators for the ALLHAT Collaborative Research Group. Major Outcomes in High-Risk Hypertensive Patients Randomized to Angiotensin-Converting Enzyme Inhibitor or Calcium Channel Blocker vs Diuretic: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). JAMA. 2002;288:2981-2997. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12479763].
The Diabetes Prevention Program Research Group. The Diabetes Prevention Program: baseline characteristics of the randomized cohort. Diabetes Care. 2000;23:1619-1629. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11092283]. [pmcid: 1360735].
Thong F.S, Graham T.E. Caffeine-induced impairment of glucose tolerance is abolished by beta-adrenergic receptor blockade in humans. J Appl Physiol. 2002;92:2347-2352. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12015346].
Thong F.S.L, Graham T.E. Caffeine-induced impairment of glucose tolerance is abolished by beta-adrenergic receptor blockade in humans. J Appl Physiol. 2002;92:2347-2352. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12015346].
Thorburn A.W, Crapo P.A, Griver K, Wallace P, Henry R.R. Long-term effects of dietary fructose on carbohydrate metabolism in non-insulin-dependent diabetes mellitus. Metabolism. 1990;39:58-63. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2403621].
Thrainsdottir S, Malik R.A, Dahlin L.B, Wiksell P, Eriksson K.F, Rosen I, Petersson J, Greene D.A, Sundkvist G. Endoneurial capillary abnormalities presage deterioration of glucose tolerance and accompany peripheral neuropathy in man. Diabetes. 2003;52:2615-2622. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514647].
Todoroki I, Shinchi K, Kono S, Imanishi K. Lifestyle and glucose tolerance: A cross-sectional study of Japanese men. Ann Epidemiol. 1994;4:363-368. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7981843].
Toeller M, Gries F.A, Dannehl K. Natural history of glucose intolerance in obesity. A ten year observation. Int J Obes. 1982;6(Suppl 1):145-149. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6749720].
Tomiyama H, Kimura Y, Okazaki R, Kushiro T, Abe M, Kuwabara Y, Yoshida H, Kuwata S, Kinouchi T, Doba N. Close relationship of abnormal glucose tolerance with endothelial dysfunction in hypertension. Hypertension. 2000;36:245-249. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 10948085].
Tong P.C.Y, Lee Z.S.K, Sea M, Chow C, Ko G.T.C, Chan W, So W, Ma R.C.W, Ozaki R, Woo J, Cockram C.S, Chan J.C.N. The effect of Orlistat-induced weight loss, without concomitant hypocaloric diet, on cardiovascualr risk factors and insulin sensitivity in young obese Chinese subjects with or without Type 2 Diabetes. Arch Intern Med. 2002;162:2428-2435. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12437401].
Top C, Cingozbay B.Y, Terekeci H, Kucukardali Y, Onde M.E, Danaci M. The effects of valsartan on insulin sensitivity in patients with primary hypertension. J Int Med Res. 2002;30:15-20. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11921494].
Topic E, Pavlicek I, Brinar V, Korsic M. Glycosylated haemoglobin in clarification of the origin of hyperglycaemia in acute cerebrovascular accident. Diabet Med. 1989;6:12-15. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2522367].
Torella R, Salvatore T, Spiezia R. Is the common presence of glucose intolerance in old age a reliable index for the subsequent occurrence of fasting hyperglycemia. Acta Diabetol Lat. 1986;23:57-61. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 3716750].
Torgerson J.S.H. XENical in the prevention of diabetes in obese subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. 2004;27:155-161. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14693982].
Toyota T, Oikawa S, Abe R, Sano R, Suzuki N, Hisamichi S, Fukao A. Effect of cilostazol on lipid, uric acid and glucose metabolism in patients with impaired glucose tolerance or type 2 diabetes mellitus a double-blind, placebo-controlled study. Clinical Drug Investigation. 2001;21:325-335. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Trinick T.R, Duly E. Experience of a quality assessment scheme for non-laboratory glucose meters. J Clin Pathol. 1992;45:77-78. Status: Not included because article does not describe a study or survey. [pmid: 1740522]. [pmcid: 495825].
Trivedi N, Mithal A, Gupta S.K, Godbole M.M. Reversible impairment of glucose tolerance in patients with endemic fluorosis. Diabetologia. 1993;36:826-828. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8405753].
Tsai S.-T, Li C.-L, Chen C.-H, Chou P. Community-based epidemiological study of glucose tolerance in Kin-Chen, Kinmen: Support for a new intermediate classification. J Clin Epidemiol. 2000;53:505-510. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10812323].
Tschritter O, Fritsche A, Shirkavand F, Machicao F, Haring H, Stumvoll M. Assessing the shape of the glucose curve during an oral glucose tolerance test. Diabetes Care. 2003;26:1026-1033. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12663568].
Tsutsu N, Nunoi K, Kodama T, Nomiyama R, Iwase M, Fujishima M. Lack of association between blood pressure and insulin in patients with insulinoma. J Hypertens. 1990;8:479-482. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2163424].
Tunbridge F.K.E, Newens A, Home P.D, Davis S.N, Murphy M, Burrin J.M, Alberti K.G.M.M, Jensen I. Double-blind crossover trial of isophane (NPH)- and lente-based insulin regimens. Diabetes Care. 1989;12:115-119. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2649324].
Tunbridge F.K.E, Home P.D, Murphy M, Alberti K.G.M.M. Does flexibility at mealtimes disturb blood glucose control on a multiple insulin injection regimen?. Diabet Med. 1991;8:833-838. Status: Not included because article does not describe a study or survey. [pmid: 1837510].
Tuomilehto-Wolf E, Tuomilehto J, Hitman G.A, Nissinen A, Stengard J, Pekkanen J, Kivinen P, Kaarsalo E, Karvonen M.J. Genetic susceptibility to non-insulin dependent diabetes mellitus and glucose intolerance are located in HLA region [see comments]. BMJ. 1993;307:155-159. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8343743]. [pmcid: 1678370].
Tuomilehto J, Zimmet P, Kankaanpaa J, Wolf E, Hunt D, King H, Ram P. Prevalence of ischaemic ECG abnormalities according to the diabetes status in the population of Fiji and their associations with other risk factors. Diabetes Res Clin Pract. 1988;5:205-217. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 3219991].
Tuomilehto J, Schranz A, Aldana D, Pitkaniemi J. The effect of diabetes and impaired glucose tolerance on mortality in Malta. Diabet Med. 1994;11:170-176. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8200202].
Tuomilehto J, Qiao Q, Borch-Johnsen K, Balkau B. Glucose tolerance and mortality: Comparison of WHO and American Diabetes Association diagnostic criteria. Lancet. 1999;354:617-621. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10466661].
Tuomilehto J, Lindstrom J, Eriksson J.G. Changes in diet and physical activity prevented type 2 diabetes mellitus in people with impaired glucose tolerance. Evidence Based Medicine. 2001;6:17. Status: Not included because article does not describe a study or survey.
Tuomilehto J, Qiao Q, Balkau B, Borch-Johnson K. Glucose tolerance and all-cause mortality. Cardiology Review. 2001;18:28-32. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Tuomilehto J, Lindstrom J, Eriksson J.G, Valle T.T, Hamalainen H, Ilanne-Parikka P, Myers K.A. Lifestyle changes can prevent the development of diabetes mellitus. CMAJ: Canadian Medical Association Journal. 2001;164:188. Status: Not included because article is not a fulltext publication.
Turpeinen A.K, Haffner S.M, Louheranta A.M, Niskanen L.K, Miettinen H, Uusitupa M.I. Serum leptin in subjects with impaired glucose tolerance in relation to insulin sensitivity and first-phase insulin response. Int J Obes Relat Metab Disord. 1997;21:284-287. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9130025].
Turpeinen A.K, Kuikka J.T, Vanninen E, Uusitupa M.I.J. Abnormal myocardial kinetics of 123I-heptadecanoic acid in subjects with impaired glucose tolerance. Diabetologia. 1997;40:541-549. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9165222].
Turpeinen A.K, Takala T.O, Nuutila P, Axelin T, Luotolahti M, Haaparanta M, Bergman J, Hamalainen H, Iida H, Maki M, Uusitupa M.I, Knuuti J. Impaired free fatty acid uptake in skeletal muscle but not in myocardium in patients with impaired glucose tolerance: studies with PET and 14(R,S)-[18F]fluoro-6-thia-heptadecanoic acid. Diabetes. 1999;48:1245-1250. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10342811].
Uchida K, Jikko A, Yamato T. Relationship of glucose intolerance and indocyanine green clearance to respiratory enzyme levels in human cirrhotic liver. Am J Med Sci. 1985;290:19-27. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2994474].
Uusitupa M, Lindi V, Louheranta A, Salopuro T, Lindstrom J, Tuomilehto J. Finnish Diabetes Prevention Study Group. Long-term improvement in insulin sensitivity by changing lifestyles of people with impaired glucose tolerance: 4-year results from the Finnish Diabetes Prevention Study. Diabetes. 2003;52:2532-2538. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14514637].
Uusitupa M.I. Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Ann Med. 1996;28:445-449. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8949977].
Vaccaro O, Rivellese A, Riccardi G, Capaldo B, Tutino L, Annuzzi G, Mancini M. Impaired glucose tolerance and risk factors for atherosclerosis. Arteriosclerosis. 1984;4:592-597. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because follow-up was less than 1 year. Not included for treatment because of study design. [pmid: 6391444].
Vaccaro O, Pauciullo P, Rubba P. Peripheral arterial circulation in individuals with impaired glucose tolerance. Diabetes Care. 1985;8:594-597. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 4075946].
Vaccaro O, Ruth K.J, Stamler J. Relationship of postload plasma glucose to mortality with 19-yr follow-up. Comparison of one versus two plasma glucose measurements in the Chicago Peoples Gas Company Study. Diabetes Care. 1992;15:1328-1334. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1425098].
Vaccaro O, Imperatore G, Iovino V, Iovine C, Rivellese A.A, Riccardi G. Does impaired glucose tolerance predict hypertension? A prospective analysis. Diabetologia. 1996;39:70-76. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8720605].
Vaccaro O, Ruffa G, Imperatore G, Iovino V, Rivellese A.A, Riccardi G. Risk of diabetes in the new diagnostic category of impaired fasting glucose: a prospective analysis.[see comment]. Diabetes Care. 1999;22:1490-1493. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10480514].
Vajo Z, Szekacs B, Dachman W. Evidence for genetic variability in venous responsiveness. Acta Physiol Hung. 1996;84:353-360. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9328607].
Valerio G, Franzese A, Carlin E, Pecile P, Perini R, Tenore A. High prevalence of stress hyperglycaemia in children with febrile seizures and traumatic injuries. Acta Paediatr. 2001;90:618-622. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11440092].
van Dam, R. M., Schuit, A. J., Feskens, E. J. M., Seidell, J. C., and Kromhout, D. Physical activity and glucose tolerance in elderly men: the Zutphen elderly study. Medicine & Science in Sports & Exercise 34(7):1132–6, 2002 Jul (22 ref) 2002; 1132–1136. Status: Excluded because no subjects diagnosed by included criteria were analyzed
Van der Merwe M.T, Crowther N.J, Schlaphoff G.P, Gray I.P, Joffe B.I, Lonnroth P.N. Evidence for insulin resistance in black women from South Africa. Int J Obes. 2000;24:1340-1346. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Van der Merwe M.T, Schlaphoff G.P, Crowther N.J, Boyd I.H, Gray I.P, Joffe B.I, Lonnroth P.N. Lactate and glycerol release from adipose tissue in lean, obese, and diabetic women from South Africa. J Clin Endocrinol Metab. 2001;86:3296-3303. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11443204].
Van Kempen A.A.M.W, Romijn J.A, Ruiter A.F.C, Ackermans M.T, Endert E, Hoekstra J.H, Kok J.H, Sauerwein H.P. Adaptation of glucose production and gluconeogenesis to diminishing glucose infusion in preterm infants at varying gestational ages. Pediatr Res. 2003;53:628-634. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12612212].
Van Mieghem W. Evaluation of glucose tolerance during treatment with celiprolol in patients with Mild Arterial Hypertension without diabetes mellitus. Acta Clin Belg. 1997;52:360-366. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9489131].
Van Pareren Y.K, de Muinck Keizer-Schrama S.M, Stijnen T, Sas T.C, Drop S.L. Effect of discontinuation of long-term growth hormone treatment on carbohydrate metabolism and risk factors for cardiovascular disease in girls with Turner syndrome. J Clin Endocrinol Metab. 2002;87:5442-5448. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12466334].
Vanderpump M.P, Tunbridge W.M, French J.M, Appleton D, Bates D, Rodgers H, Evans J.G, Clark F, Tunbridge F, Young E.T. The incidence of diabetes mellitus in an English community: a 20-year follow-up of the Whickham Survey. Diabet Med. 1996;13:741-747. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8862950].
Vangen S, Stoltenberg C, Holan S, Moe N, Magnus P, Harris J.R, Stray-Pedersen B. Outcome of pregnancy among immigrant women with diabetes. Diabetes Care. 2003;26:327-332. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12547857].
Vanhala M.J, Kumpusalo E.A, Pitkajarvi T.K, Notkola I.L, Takala J.K. Hyperinsulinemia and clustering of cardiovascular risk factors in middle-aged hypertensive Finnish men and women. J Hypertens. 1997;15:475-481. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9169999].
Vanhala M.J, Pitkajarvi T.K, Keinanen-Kiukaanniemi S.M, Kumpusalo E.A, Takala J.K. Hyperinsulinaemia in hypertensive subjects: validity of a test for the detection of insulin resistance in clinical practice. J Hum Hypertens. 1998;12:463-467. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9702932].
Vanhanen M, Koivisto K, Kuusisto J, Mykkanen L, Helkala E, Hanninen T, Riekkinen P Sr, Soininen H, Laakso M. Cognitive function in an elderly population with persistent impaired glucose tolerance. Diabetes Care. 1998;21:398-402. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9540022].
Vardi P, Crisa L, Jackson R.A. Predictive value of intravenous glucose tolerance test insulin secretion less than or greater than the first percentile in islet cell antibody positive relatives of type 1 (insulin-dependent) diabetic patients. Diabetologia. 1991;34:93-102. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2065854].
Vasankari T, Hamalainen H, Aunola S, Rastas M, Marniemi J, Ahotupa M. Reduced oxidized LDL after two years dietary and exercise intervention in IGT subjects. European Journal of Endocrinology. 1999;140(Suppl. 1):2. Status: Not included because article is not a fulltext publication.
Velho G, Blanche H, Vaxillaire M, Bellanne-Chantelot C, Pardini V.C, Timsit J, Passa Ph, Deschamps I, Robert J.-J, Weber I.T, Marotta D, Pilkis S.J, Lipkind G.M, Bell G.I, Froguel Ph. Identification of 14 new glucokinase mutations and description of the clinical profile of 42 MODY-2 families. Diabetologia. 1997;40:217-224. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9049484].
Vella A, Reed A.S, Charkoudian N, Shah P, Basu R, Basu A, Joyner M.J, Rizza R.A. Glucose-induced suppression of endogenous glucose production: Dynamic response to differing glucose profiles. Am J Physiol Endocrinol Metab. 2003;285:E25-E30. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12637258].
Verrillo A, de Teresa A, Pinto M, Rucco E. Diurnal variation in the effect of exogenous insulin on blood sugar, growth hormone and free fatty acids in subjects with various degrees of glucose intolerance. IRCS Medical Science. 1983;11:913-914. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design.
Verschoor L, Lamberts S.W.J, Uitterlinden P, Del Pozo E. Glucose tolerance during long term treatment with a somatostatin analogue. British Medical Journal. 1986;293:1327-1328. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2878704]. [pmcid: 1342048].
Vijayakumar T, Vasudevan D.M. Effect of ascorbic acid administration on glucose tolerance and serum cholesterol in normal and in diabetic subjects. Indian Medical Gazette. 1980;114:96-100. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Vijayalingam S, Parthiban A, Shanmugasundaram K.R, Mohan V. Abnormal antioxidant status in impaired glucose tolerance and non-insulin-dependent diabetes mellitus. Diabet Med. 1996;13:715-719. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8862945].
Vinceti M, Rovesti S, Pacchioni C, Ropa G, Roncaia R, Benedetti P, Bergomi M, Vivoli G. Diet as a risk factor for abnormal glucose tolerance in subjects with and without family history of diabetes mellitus. Diabetes Nutr Metab. 1994;7:21-28. Status: Excluded because no subjects diagnosed by included criteria were analyzed.
Viswanathan M, Mohan V, Snehalatha C, Ramachandran A. High prevalence of Type 2 (non-insulin-dependent) diabetes among the offspring of conjugal Type 2 diabetic parents in India. Diabetologia. 1985;28:907-910. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 4092859].
von Eckardstein A, Schulte H, Assmann G. Risk for diabetes mellitus in middle-aged Caucasian male participants of the PROCAM study: implications for the definition of impaired fasting glucose by the American Diabetes Association. Prospective Cardiovascular Munster. J Clin Endocrinol Metab. 2000;85:3101-3108. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10999793].
Von Mach M-A, Brinkmann C, Hansen T, Weilemann L.S, Beyer J. Differences in pharmacokinetics and pharmacodynamics of insulin lispro and aspart in healthy volunteers. Experimental & Clinical Endocrinology & Diabetes. 2002;110:416-419. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12518253].
Voors A.W, Radhakrishnamurthy B, Srinivasan S.R, Webber L.S, Berenson G.S. Plasma glucose level related to blood pressure in 272 children, ages 7–15 years, sampled from a total biracial population. Am J Epidemiol. 1981;113:347-356. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7211820].
Vuksan V, Sievenpiper J.L, Koo V.Y.Y, Francis T, Beljan-Zdravkovic U. American Ginseng (Panax quinqefolius L) Reduces Postprandial Glycemia in Nondiabetic Subjects and Subjects with Type 2 Diabetes Mellitus. Arch Intern Med. 2000;160:1009-1013. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10761967].
Vuksan V, Sievenpiper J.L, Owen R, Swilley J.A, Spadafora P, Jenkins D.J, Vidgen E, Brighenti F, Josse R.G, Leiter L.A, Xu Z, Novokmet R. Beneficial effects of viscous dietary fiber from Konjac-mannan in subjects with the insulin resistance syndrome: results of a controlled metabolic trial. Diabetes Care. 2000;23:9-14. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10857960].
Wagenaar L.J, Kuck E.M, Hoekstra J.B.L. Troglitazone. Is it all over?. Neth J Med. 1999;55:4-12. Status: Not included because article does not describe a study or survey. [pmid: 10431549].
Wagenknecht L.E, Mayer E.J, Rewers M, Haffner S, Selby J, Borok G.M, Henkin L, Howard G, Savage P.J, Saad M.F, Bergman R.N, Hamman R. The insulin resistance atherosclerosis study (iris): Objectives, design, and recruitment results. Ann Epidemiol. 1995;5:464-472. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8680609].
Wagner Z, Wittmann I, Mazak I, Schinzel R, Heidland A, Kientsch-Engel R, Nagy J. Nepsilon-(Carboxymethyl)lysine levels in patients with type 2 diabetes: Role of renal function. Am J Kidney Dis. 2001;38:785-791. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11576882].
Wahab N.N, Cowden E.A, Pearce N.J, Gardner M.J, Merry H, Cox J.L. Is blood glucose an independent predictor of mortality in acute myocardial infarction in the thrombolytic era?. J Am Coll Cardiol. 2002;40:1748-1754. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12446057].
Walker E.A, Paduano D.J, Shamoon H. Quality assurance for blood glucose monitoring in health-care facilities. Diabetes Care. 1991;14:1043-1049. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1797485].
Wall U, Bergbrant A, Jern S. Impaired glucose tolerance at five-year follow-up of young men with borderline hypertension. Blood Pressure. 1996;5:139-147. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8790924].
Wareham N.J, Byrne C.D, Carr C, Day N.E, Boucher B.J, Hales C.N. Glucose intolerance is associated with altered calcium homeostasis: a possible link between increased serum calcium concentration and cardiovascular disease mortality. Metabolism. 1997;46:1171-1177. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9322802].
Warram J.H, Sigal R.J, Martin B.C, Krolewski A.S, Soeldner J.S. Natural history of impaired glucose tolerance: follow-up at Joslin Clinic. Diabet Med. 1996;13:S40-S45. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8894480].
Wasada T, Kuroki H, Arii H, Maruyama A, Saito S, Watanabe Y, Omori Y. Physiological increase in plasma insulin concentration suppresses proinsulin secretion in normal controls but not in subjects with glucose intolerance. Endocr J. 1994;41:183-188. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7951567].
Watanabe K, Sekiya M, Tsuruoka T, Funada J, Kameoka H. Effect of insulin resistance on left ventricular hypertrophy and dysfunction in essential hypertension. J Hypertens. 1999;17:1153-1160. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 10466471].
Watanabe N, Taniguchi T, Taketoh H, Kitagawa Y, Namura H, Yoneda N, Kurimoto Y, Yamada S, Ishikawa Y. Elevated remnant-like lipoprotein particles in impaired glucose tolerance and type 2 diabetic patients. Diabetes Care. 1999;22:152-156. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 10333918].
Wei M, Gibbons L.W, Mitchell T.L, Kampert J.B, Stern M.P, Blair S.N. Low fasting plasma glucose level as a predictor of cardiovascular disease and all-cause mortality. Circulation. 2000;101:2047-2052. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10790345].
Weinberger M.H, Fineberg N.S, Fineberg S.E. The influence of blood pressure and carbohydrate tolerance on vascular compliance in humans. Am J Hypertens. 2002;15:678-682. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 12160189].
Weiss H.G, Klocker J, Labeck B, Nehoda H, Aigner F, Klingler A, Ebenbichler C, Foger B, Lechleitner M, Patsch J.R, Schwelberger H.G. Plasma amine oxidase: a postulated cardiovascular risk factor in nondiabetic obese patients. Metabolism. 2003;52:688-692. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12800092].
Weiss P.A.M, Scholz H.S, Haas J, Tamussino K.F, Seissler J, Borkenstein M.H. Long-term follow-up of infants of mothers with type 1 diabetes: Evidence for hereditary and nonhereditary transmission of diabetes and precursors. Diabetes Care. 2000;23:905-911. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10895839].
Weiss R, Dufour S, Taksali S.E, Tamborlane W.V, Petersen K.F, Bonadonna R.C, Boselli L, Barbetta G, Allen K, Rife F, Savoye M, Dziura J, Sherwin R, Shulman G.I, Caprio S. Prediabetes in obese youth: A syndrome of impaired glucose tolerance, severe insulin resistance, and altered myocellular and abdominal fat partitioning. Lancet. 2003;362:951-957. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 14511928].
Welborn T.A, Reid C.M, Marriott G. Australian Diabetes Screening Study: impaired glucose tolerance and non-insulin-dependent diabetes mellitus. Metabolism. 1997;46:35-39. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9439557].
Welin L, Eriksson H, Larsson B, Ohlson L.O, Svardsudd K, Tibblin G. Hyperinsulinaemia is not a major coronary risk factor in elderly men. The study of men born in 1913. Diabetologia. 1992;35:766-770. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1511804].
Welin L, Eriksson H, Larsson B, Svardsudd K, Tibblin G, Wilhelmsen L. Triglycerides and blood glucose are the major coronary risk factors in elderly Swedish men. The study of men born in 1913. Ann Epidemiol. 1992;2:113-119. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1342252].
Wells T.G, Ulstrom R.A, Nevins T. Hypoglycemia in pediatric renal allograft recipients. J Pediatr. 1988;113:1002-1007. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3057155].
Widimsky J Jr, Strauch B, Sindelka G, Skrha J. Can primary hyperaldosteronism be considered as a specific form of diabetes mellitus?. Physiol Res. 2001;50:603-607. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11829322].
Wiedeman P.E, Trevillyan J.M. Dipeptidyl peptidase IV inhibitors for the treatment of impaired glucose tolerance and type 2 diabetes. Current Opinion in Investigational Drugs. 2003;4:412-420. Status: Not included because article does not describe a study or survey. [pmid: 12808880].
Wiener K. Fasting plasma glucose as a diagnostic indicator of diabetes mellitus [see comments]. Clin Chim Acta. 1995;238:199-208. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7586579].
Wijeyaratne C.N, Sheriff R, Seneviratne H.R, Sheriffdeen A.H. Pregnancy following renal transplantation in Sri Lanka. Ceylon Med J. 2000;45:168-170. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11293964].
Willi S.M, Kennedy A, Brant B.P, Wallace P, Rogers N.L, Garvey W.T. Effective use of thiazolidinediones for the treatment of glucocorticoid-induced diabetes. Diabetes Res Clin Pract. 2002;58:87-96. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12213349].
Williams D.E.M, Prevost A.T, Whichelow M.J, Cox B.D, Day N.E, Wareham N.J. A cross-sectional study of dietary patterns with glucose intolerance and other features of the metabolic syndrome. Br J Nutr. 2000;83:257-266. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 10884714].
Williams D.R, Wareham N.J, Brown D.C, Byrne C.D, Clark P.M, Cox B.D, Cox L.J, Day N.E, Hales C.N, Palmer C.R. Undiagnosed glucose intolerance in the community: the Isle of Ely Diabetes Project. Diabet Med. 1995;12:30-35. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7712700].
Williams D.R.R, Wareham N.J, Brown D.C, Byrne C.D, Clark P.M.S, Cox B.D, Cox L.J, Day N.E, Hales C.N, Palmer C.R, Shackleton J.R, Wang T.W.M. Undiagnosed glucose intolerance in the community: The Isle of Ely Diabetes Project. Diabet Med. 1995;12:30-35. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7712700].
Wing R.R, Venditti E, Jakicic J.M, Polley B.A, Lang W. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21:350-359. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9540015].
Wingard D.L, Barrett-Connor E. Family history of diabetes and cardiovascular disease risk factors and mortality among euglycemic, borderline hyperglycemic, and diabetic adults. Am J Epidemiol. 1987;125:948-958. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3578253].
Wingard D.L, Barrett-Connor E.L, Scheidt-Nave C, McPhillips J.B. Prevalence of cardiovascular and renal complications in older adults with normal or impaired glucose tolerance or NIDDM: A population-based study. Diabetes Care. 1993;16:1022-1025. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 8359095].
Wolever T.M, Fernandes J, Rao V.A, Chiasson J.L, Josse R.G, Leiter L.A. Positive methane-producing status associated with increased serum cholesterol in subjects with impaired glucose tolerance. Diabetes Care. 1995;18:1010-1012. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7555532].
Wolever T.M, Chiasson J.L, Csima A, Hunt J.A, Palmason C, Ross S.A, Ryan E.A. Variation of postprandial plasma glucose, palatability, and symptoms associated with a standardized mixed test meal versus 75 g oral glucose. Diabetes Care. 1998;21:336-340. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 9540012].
Wolever T.M, Chiasson J.L. Acarbose raises serum butyrate in human subjects with impaired glucose tolerance. Br J Nutr. 2000;84:57-61. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10961161].
Wolever T.M, Mehling C. High-carbohydrate-low-glycaemic index dietary advice improves glucose disposition index in subjects with impaired glucose tolerance. Br J Nutr. 2002;87:477-487. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12010586].
Wolever T.M, Mehling C. Long-term effect of varying the source or amount of dietary carbohydrate on postprandial plasma glucose, insulin, triacylglycerol, and free fatty acid concentrations in subjects with impaired glucose tolerance. Am J Clin Nutr. 2003;77:612-621. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because follow-up was less than 6 months. [pmid: 12600851].
Wolever T.M.S, Nguyen P-M, Chiasson J-L, Hunt J.A, Josse R.G, Palmason C, Rodger N.W, Ross S.A, Ryan E.A, Tan M.H. Determinants of diet glycemic index calculated retrospectively from diet records of 342 individuals with non-insulin-dependent diabetes mellitus. Am J Clin Nutr. 1994;59:1265-1269. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8198048].
Wolever T.M.S, Fernandes J, Rao V.A, Chiasson J-L, Josse R.G, Leiter L.A. Positive methane-producing status associated with increased serum cholesterol in subjects with impaired glucose tolerance. Diabetes Care. 1995;18:1010-1012. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 7555532].
Wolever T.M.S, Bentum-Williams A, Jenkins D.J.A. Physiological modulation of plasma free fatty acid concentrations by diet: Metabolic implications in nondiabetic subjects. Diabetes Care. 1995;18:962-970. Status: Not included because article does not describe a study or survey. [pmid: 7555557].
Wolever T.M.S, Chiasson J.-L. Acarbose raises serum butyrate in human subjects with impaired glucose tolerance. Br J Nutr. 2000;84:57-61. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10961161].
Wolever T.M.S, Mehling C. Long-term effect of varying the source or amount of dietary carbohydrate on postprandial plasma glucose, insulin, triacylglycerol, and free fatty acid concentrations in subjects with impaired glucose tolerance. Am J Clin Nutr. 2003;77:612-621. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because follow-up was less than 6 months. [pmid: 12600851].
Won Soon Park, Yun Sil Chang, Lee M. Effects of hyperglycemia or hypoglycemia on brain cell membrane function and energy metabolism during the immediate reoxygenation-reperfusion period after acute transient global hypoxia-ischemia in the newborn piglet. Brain Research. 2001;901:102-108. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11368956].
Woo J, Ho S.C, Sham A, Sea M.M, Lam K.S, Lam T.H, Janus E.D. Diet and glucose tolerance in a Chinese population. Eur J Clin Nutr. 2003;57:523-530. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design. [pmid: 12700613].
Worrall G. Screening healthy people for diabetes: is it worthwhile?. J Fam Pract. 1991;33:155-160. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1890396].
Yajnik C.S, Naik S.S, Bhat D.S, Joshi V.M, Shelgikar K.M, Alberti K.G.M.M, Hockaday T.D.R. The relationship between obesity, plasma immunoreactive insulin concentration and blood pressure in newly diagnosed Indian Type 2 diabetic patients. Diabet Med. 1993;10:146-151. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 8458191].
Yajnik C.S, Fall C.H, Vaidya U, Pandit A.N, Bavdekar A, Bhat D.S, Osmond C, Hales C.N, Barker D.J. Fetal growth and glucose and insulin metabolism in four-year-old Indian children. Diabet Med. 1995;12:330-336. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7600749].
Yamada N, Yoshinaga H, Sakurai N, Shimano H, Gotoda T, Ohashi Y, Yazaki Y, Kosaka K. Increased risk factors for coronary artery disease in Japanese subjects with hyperinsulinemia or glucose intolerance. Diabetes Care. 1994;17:107-114. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8137680].
Yamada T, Aizawa T, Nagasawa Y, Ishihara M, Komatsu M, Komiya I, Shinoda T, Takasu N. Ten-year follow-up of Japanese overweight subjects with impaired glucose tolerance: identification of a diabetes-prone subpopulation. Intern Med. 1992;31:877-884. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 1450495].
Yamazaki Y, Takahashi K, Yagisawa T, Oba S, Teraoka S, Toma H, Agishi T, Ota K. Alterations in glucose tolerance and insulin release in renal transplant recipients receiving cyclosporine and corticosteroid. Transplant Proc. 1988;20:158-159. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because the intervention was not relevant to review. [pmid: 2968012].
Yanagi K, Yamashita S, Kihara S, Nakamura T, Nozaki S, Nagai Y, Funahashi T, Kameda-Takemura K, Ueyama Y, Jiao S, Kubo M, Tokunaga K, Matsuzawa Y. Characteristics of coronary artery disease and lipoprotein abnormalities in patients with heterozygous familial hypercholesterolemia associated with diabetes mellitus or impaired glucose tolerance. Atherosclerosis. 1997;132:43-51. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 9247358].
Yarnell J.W, Pickering J.E, Elwood P.C, Baker I.A, Bainton D, Dawkins C, Phillips D.I. Does non-diabetic hyperglycemia predict future IHD? Evidence from the Caerphilly and Speedwell studies. J Clin Epidemiol. 1994;47:383-388. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 7730863].
Yeh G.Y, Eisenberg D.M, Kaptchuk T.J, Phillips R.S. Systematic review of herbs and dietary supplements for glycemic control in diabetes. Diabetes Care. 2003;26:1277-1294. Status: Not included because article does not describe a study or survey. [pmid: 12663610].
Yoshinaga H, Kosaka K. High glycosylated hemoglobin levels increase the risk of progression to diabetes mellitus in subjects with glucose intolerance. Diabetes Res Clin Pract. 1996;31:71-79. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8792104].
Yu W.K, Li W.Q, Li N, Li J.S. Influence of acute hyperglycemia in human sepsis on inflammatory cytokine and counterregulatory hormone concentrations. World J Gastroenterol. 2003;9:1824-1827. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 12918129].
Yudkin J.S, Forrest R.D, Jackson C.A. Microalbuminuria as predictor of vascular disease in non-diabetic subjects. Islington Diabetes Survey. Lancet. 1988;2:530-533. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 2900920].
Zannolli R, Rebeggiani A, Chiarelli F, Morgese G. Hyperinsulinism as a marker in obese children. Am J Dis Child. 1993;147:837-841. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8352218].
Zargar A.H, Shah N.A, Masoodi S.R, Laway B.A, Dar F.A, Khan A.R, Sofi F.A, Wani A.I. Copper, zinc, and magnesium levels in non-insulin dependent diabetes mellitus. Postgrad Med J. 1998;74:665-668. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10197198]. [pmcid: 2431594].
Zargar A.H, Masoodi S.R, Khan A.K, Bashir M.I, Laway B.A, Wani A.I, Dar F.A. Impaired fasting glucose and impaired glucose tolerance - Lack of agreement between the two categories in a North Indian population. Diabetes Res Clin Pract. 2001;51:145-149. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 11165694].
Zavaroni I, Bonini L, Gasparini R, Barilli A.L, Zuccarelli A, Dall'Aglio E, Delsignore R, Reaven G.M. Hyperinsulinemia in a normal population as a predictor of non-insulin- dependent diabetes mellitus, hypertension, and coronary heart disease: The Barilla Factory revisited. Metabolism. 1999;48:989-994. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 10459563].
Zawada E.T Jr, Williams L, McClung D.E. Renal-metabolic consequences of antihypertensive therapy with diltiazem versus hypochlorothiazide. Miner Electrolyte Metab. 1987;13:72-77. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 3320720].
Zhang J.L, Qin Y.W, Zheng X, Qiu J.L, Zou D.J. Serum resistin level in essential hypertension patients with different glucose tolerance. Diabet Med. 2003;20:828-831. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis and treatment because of study design (case-control). [pmid: 14510864].
Zimmet P, King H, Taylor R. The high prevalence of diabetes mellitus, impaired glucose tolerance and diabetic retinopathy in nauru - The 1982 survey. Diabetes Research. 1984;1:13-18. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 6529880].
Zimmet P.Z, Collins V.R, Dowse G.K, Knight L.T. Hyperinsulinaemia in youth is a predictor of Type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1992;35:534-541. Status: Not included for diagnosis because article does not compare IGT and IFG criteria. Not included for prognosis because no extractable data was relevant to review. Not included for treatment because of study design. [pmid: 1612226].
Zofkova I, Zamrazil V. Does exogenous hypermagnesaemia inhibit insulin secretion in patients with impaired glucose tolerance or non-insulin-dependent diabetes mellitus?. Horm Metab Res. 1994;26:157-159. Status: Excluded because no subjects diagnosed by included criteria were analyzed. [pmid: 8005565].