# Appendix D. Peer Reviewers

Dr. Nathaniel Clark, American Diabetes Association, Alexandria, VA, USA

Dr. Michael Engelgau, Centers for Disease Control and Prevention, Atlanta, GA, USA

Dr. Rita Goodman, CQI Branch, Health Resources and Services Admin., Bethesda, MD, USA

Dr. Steven Haffner, University of Texas, San Antonio, TX, USA

Dr. Mary Hager, American Dietetic Association, Washington, DC, USA

Dr. Markolf Hanefeld, Centre for Clinical Studies, Technical University, Dresden, Germany

Dr. Rodney Hornbake, (ACP representative), Hadlyme, CT, USA

Dr. Belinda Ireland - AAFP, Leawood, KS, USA

Dr. Francine Ratner Kaufman, Childrens Hospital Los Angeles, Los Angeles, CA, USA

Dr. Matthew McQueen, Hamilton Health Sciences Corporation, Hamilton, ON, Canada

Drs. Kelly Moore, Steve Rith-Najarian and Charlton Wilson, Indian Health Services, Albuquerque, NM, USA

Dr. Robert Ratner, MedStar Research Institute, Hyattsville, MD, USA

AHRQ representatives:

Dr. David Atkins - AHRQ, Gaithersburg, MD, USA

Dr. Steven Fox - AHRQ, Gaithersburg, MD, USA

Criticism editor:

Dr. Patricia Huston, Ottawa, ON