# Appendix B. Forms

## IGT FULLTEXT SCREENING FORM

Author_______________________________ Screener __________________ IGT RefID_________________

AREA | GENERAL | NO | YES/MAYBE
^(a)^ GENERAL | Is article published in English language? | Exclude from review □ | Continue to next line □
| | Done
^(b)^ GENERAL | Is article a fulltext publication? | Exclude from review □ | Continue to next line □
| | Done
^(c)^ GENERAL | Was the article published in or after 1979? | Exclude from review □ | Continue to next line □
| | Done
^(d)^ DESIGN | Does the report describe any type of study or survey? | Exclude from review □ | Continue to next line □
| | Done
^(e)^ POPULATION | Are results for subjects with IGT or IFG analyzed separately from any others in the study population? | Exclude from review □ | Continue to next line □
| | Done
^(f)^ POPULATION | Does the study include children with IGT or IFG? | Go to Diagnosis □ | Include for children □
| | | Go to diagnosis

AREA | DIAGNOSIS | NO | YES/MAYBE
^(a)^ OUTCOME | Does the article examine the variability in repeated measurements (within 8 weeks) of glucose tolerance or fasting glucose in a single subject? | Continue to next line □ | Include for diagnosis □
| | | Go to prognosis
^(b)^ OUTCOME | Does the article compare the result of diagnosis by application of IGT criteria with the result of diagnosis by application of IFG criteria? | Exclude for diagnosis □ | Include for diagnosis □
| | Go to prognosis | Go to prognosis

AREA | PROGNOSIS | NO | YES/MAYBE
^(a)^ DESIGN | Does the study use a prospective cohort or case control design? | Exclude for prognosis □ | Continue to next line □
| | Go to treatment
^(b)^ OUTCOME | Does the article describe the risk of developing diabetes type 2 (by our definition) or reversion towards normal glucose tolerance or fasting glucose? | Continue to next line □ | Include for prognosis □
| | | Go to treatment
^(c)^ OUTCOME | Does the article describe the risk of the development of acute coronary events or coronary mortality as defined for our review? | Continue to next line □ | Include for prognosis □
| | | Go to treatment
^(d)^ OUTCOME | Does the article describe the risk of developing retinal or nephropathy outcomes as defined for our review? | Continue to next line □ | Include for prognosis □
| | | Go to treatment
^(e)^ OUTCOME | Does the article describe the risk of effects on blood pressure, lipid levels, amputation or all cause mortality? | Exclude for prognosis □ | Include for prognosis □
| | Go to treatment | Go to treatment

AREA | TREATMENT | NO | YES/MAYBE
^(a)^ DESIGN | Is the study design an RCT for any treatment or a controlled clinical trial or concurrent cohort trial for behavioral or lifestyle or surgical treatment? | Exclude for treatment □ | Continue to next line □
| | Done
^(b)^ INTERVENTION | Does the study evaluate the effect of a therapeutic agent, lifestyle intervention, behavioral intervention or surgical intervention for IGT or IFG? | Exclude for treatment □ | Continue to next line □
| | Done
^(c)^ OUTCOME | Does the study evaluate the effect of therapy on the development or time to development of diabetes type 2 (by our definition) or reversion towards normal glucose tolerance or fasting glucose? | Continue to next line □ | Include for treatment □
| | | Done
^(d)^ OUTCOME | Does the study evaluate the effect of therapy on the development of acute coronary events or coronary mortality as defined for our review? | Continue to next line □ | Include for treatment □
| | | Done
^(e)^ OUTCOME | Does the study evaluate the effect of therapy on the development of retinal or nephropathy outcomes as defined for our review? | Continue to next line □ | Include for treatment □
| | | Done
^(f)^ OUTCOME | Does the study evaluate the effect of therapy on blood pressure, lipid levels, amputation or all cause mortality? | Exclude for treatment □ | Include for treatment □
| | Done | Done

THIS IS A CONSENSUS FORM □

Appendix B. Forms - Quality Assessment

REFID ____________ 1^st^ AUTHOR _________________ EXTRACTOR ___________

QUALITY SCORE FOR JADAD SCALE AND FOR MODIFIED JADAD SCALE

CRITERIA | RESULT | SCORING | SCORE
Reported as randomized | □ YES □ NO | 1 point for YES
Randomization is appropriate | □ YES □ NO □ NOT DESCRIBED | 1 point for YES
| | -1 point for NO
Double blinding is reported | □ YES □ NO | 1 point for YES
Double blinding is appropriate | □ YES □ NO □ NOT DESCRIBED | 1 point for YES
| | -1 point for NO
Withdrawals are reported by number and reason per arm | □ YES □ NO | 1 point for YES
JADAD SCORE | | | _____ /5
Method used to assess adverse events is described | □ YES □ NO | 1 point for YES
Methods of statistical analysis are described | □ YES □ NO | 1 point for YES
Inclusion criteria reported | □ YES □ NO | 1 point for YES in at least one of two criteria
Exclusion criteria reported | □ YES □ NO
MODIFIED JADAD SCORE | | | _____ /3
TOTAL SCORE (out of 8)
Intended allocation to tx group concealed from investigator | □ YES □ NO □ NOT REPORTED

Source of population (circle): sampled

convenience

clinic

industry

volunteer

Other (specify):

IGT Systematic Review: July 2004

COHORT DESIGN QUALITY ASSESSMENT

Reference ID/RM # _________ Date of Review __________ Reviewer_______

[underlined: REPORTING]

| yes | No
Q1. Is the hypothesis/aim/objective of the study clearly described? | 1 | 0
Q2. Are the main outcomes to be measured clearly described in the Introduction or Methods section? | 1 | 0
If the main outcomes are first mentioned in the Results section, the question should be answered no.
Q3. Are the criteria for inclusion in and exclusion from the study clearly described? | 1 | 0
Q4. Are the exposures of interest (interventions) clearly described? | 1 | 0
Q5. Are the main findings of the study clearly described? | 1 | 0
Simple outcome data (including denominators and numerators) should be reported for all major findings so that the reader can check the major analyses and conclusions.

Reporting Score = ___ / 5

INTERNAL VALIDITY

Confounding/Selection Bias

Q6. Are the exposed and non-exposed cohorts comparable on the basis of the design or analysis? | An analysis has been done to check comparability of exposed and non-exposed cohorts and the most obvious confounders and other factors are controlled for in the design or analysis | Study controls for some factors, but does not control all of the most obvious factors | Study does not control for any factors
Consult the list of confounding and other factors. | SCORE: 1 | SCORE: ½ | SCORE: 0

Q7. Is the selection of the non-exposed cohort appropriate? | Drawn from the same community as the exposed cohort | Drawn from a different source or no description of the derivation of the non- exposed cohort
| SCORE: 1 | SCORE : 0
Q8. Is the follow-up of cohorts adequate? | Complete follow up - all subjects accounted for | There is not an adequate description of those lost to follow-up
| OR | OR
| Subjects lost to follow up unlikely to introduce bias - small number lost (number reported and an adequate discussion of why unlikely to introduce bias) | Unable to determine
| SCORE: 1 | SCORE: 0

Assessment Bias

| Yes | No | Unclear
Q9. Was the outcome of interest demonstrated to be not present at start of the study? | 1 | 0 | 0
Q10. Was the intervention/exposure assessment appropriate and demonstrated to be valid? | 1 | 0 | 0
Answer Yes if the outcome is assessed by either independent assessment or self-report that has been demonstrated to be valid.
Q11. Was the intervention/exposure assessment appropriate and demonstrated to be reliable? | 1 | 0 | 0
Answer Yes if the outcome is assessed by either independent assessment or self-report that has been demonstrated to be reliable.
Q12. Was the outcome assessment appropriate and demonstrated to be valid? | 1 | 0 | 0
Answer Yes if the outcome is assessed by either independent assessment or self-report that has been demonstrated to be valid. A valid assessment would include an accepted diagnostic test (e.g. an X-ray).
Q13. Was the outcome assessment appropriate and demonstrated to be reliable? | 1 | 0 | 0
Answer Yes if the outcome is assessed by either independent assessment or self-report that has been demonstrated to be reliable.
Q14. Was the outcome assessor blinded appropriately to the intervention status? | 1 | 0 | 0
To receive a Yes, the assessor must have been blinded to the intervention and the blinding must be appropriate for the situation. For independent assessment the assessor must be blind to the intervention status. In case of self-report, the interviewer or person administering the questionnaire must be blind to intervention status.
Q15. Was follow up long enough for outcomes to occur? | 1 | 0
This would be of particular concern when looking at overuse injuries or extremely rare injuries. One season would typically be long enough for outcome to occur.

Intervention Integrity

| Yes | No | Unable to Determine
Q16. Was the consistency of the intervention measured? | 1 | 0 | 0
This refers to whether the authors described measuring if the intervention was provided to all participants the same way.
Q17. Has the possibility of participants having received an unintended intervention (contamination or co-intervention) that may influence the results been reported and ruled out? | 1 | 0 | 0
Co-intervention occurs when the study group receives an additional intervention other than that intended. In this case, it is possible that the effect of the intervention may be over-estimated. Contamination refers to situations where the control group accidentally receives the study intervention. This could result in an underestimation of the impact of the intervention. Answer Yes if potential contamination or co-intervention is reported and demonstrated to be unlikely to have had an effect.

Internal Validity Score = ____/ 12

Total Score = ____ / 17

EXTERNAL VALIDITY/ GENERALIZABILITY

Q18. How representative is the exposed cohort?

Randomly selected from target population with high response and low loss to follow-up (gold standard) | 1
Somewhat representative of the target population - misses the gold standard | ½
Convenience sample - e.g. teams at one centre, volunteers | 0
No description of how the cohort was selected | 0

External Validity Score = ___ / 1

Source of population (circle): sampled

convenience

clinic

industry

volunteer

Other (specify):

Appendix B. Forms - Data Extraction

REFID # _____________ 1^ST^ AUTHOR __________________ EXTRACTOR ___________

GENERAL
Question | Answer | Mark
Type of study | □ RCT □ Controlled clinical trial □ Other (specify) ________________________________________________ | One
Publication year | | Date
Location of study reported on | □ USA □ Canada □ Germany □ Italy □ France □ Britain □ Netherlands □ China □ Africa □ Australia □ S. America □ Other ___________________ | All
Funding source | □ Industry □ Government □ Consumer □ Charity □ Professional □ NR □ Other __________________ | All
Association with industry reported | □ YES □ NO | One
| If yes, company mentioned ______________________________
Number of authors | | □
Study duration (day week month year) reported on | ____________________________ □ NR | □
Gender of subjects | □ Male _______________ □ Female _______________ □ NR | All
Age of subjects | □<10 □ 10–18 □19–40 □ 41–60 □ 61–80 □>80 Range _____________________ Mean _____________□ NR | All
Ethnic groups mentioned | □ NO □ YES (specify groups) _____________________________________ | All
Diagnostic criteria used | IGT: | All
| 75g OGTT 2 hr cutoffs __________________________
| FPG cutoffs ___________________________________
| IFG:
| 75g OGTT 2 hr cutoffs __________________________
| FPG cutoffs ___________________________________
| Other (specify) ________________________________
Personal characteristics described | □ Family history □ Socioeconomic □ Education □ Diet history □ Weight □ Gestational diabetes □ Medical history □ Other ____________________ □ NR | All
Other specific population characteristics for all included | | Text
(not necessarily inclusion criteria, but may be a requirement)
(e.g. all subjects had MS or all subjects were Japanese)

REFID # ________ 1^ST^ AUTHOR _____________________ EXTRACTOR ___________

DIAGNOSIS
Question | Answer | Mark
Number of subjects included | ___________ | □
Diagnosis comparisons reported | □ IFG vs IGT □ WHO vs ADA criteria □ Repeat testing □ YEAR vs YEAR criteria | All
Units compared for IFG vs IGT | | Text
Results of IFG vs IGT | | Text
Units compared for ADA vs WHO | | Text
Results of ADA vs WHO | | Text
Units compared for repeat testing within 8 weeks | | Text
Results of repeat testing within 8 weeks | | Text
Units compared for year vs year criteria | | Text
Results of year vs year criteria | | Text
Outcome(1) compared for one diagnosis vs another | | Text
Units used for outcome (1) comparison between diagnoses | | Text
Results of outcome(1) comparison between diagnoses | | Text
Outcome(2) compared for one diagnosis vs another | | Text
Units used for outcome (2) comparison between diagnoses | | Text
Results of outcome(2) comparison between diagnoses | | Text
Outcome(3) compared for one diagnosis vs another | | Text
Units used for outcome (3) comparison between diagnoses | | Text
Results of outcome(3) comparison between diagnoses | | Text
Outcome(4) compared for one diagnosis vs another | | Text
Units used for outcome (4) comparison between diagnoses | | Text
Results of outcome(4) comparison between diagnoses | | Text

REFID # __________ 1ST AUTHOR _____________________ EXTRACTOR ___________

PROGNOSIS
Question | Answer | Mark
Number of untreated IGT subjects included | ___________ | □
Outcome reported on (1) | | Text
Units used for outcome (1) | | Text
Results of outcome (1) | | Text
Outcome reported on (2) | | Text
Units used for outcome (2) | | Text
Results of outcome (2) | | Text
Outcome reported on (3) | | Text
Units used for outcome (3) | | Text
Results of outcome (3) | | Text
Outcome reported on (4) | | Text
Units used for outcome (4) | | Text
Results of outcome (4) | | Text
Outcome reported on (5) | | Text
Units used for outcome (5) | | Text
Results of outcome (5) | | Text

REFID # ________ 1^ST^ AUTHOR ________________________ EXTRACTOR ___________

TREATMENT
Question | Answer | Mark
Total number of subjects included | | □
Number of subjects treated | | □
Number of control subjects included | | □
Number of control subjects reported on | | □
Number of treated subjects reported on | | □
Adverse events reported | □ YES □ NO (specify how) _________________________________________ | One/text
Number of treatment arms | | □
Treatment 1 (control) | | Text
Treatment 2 | | Text
Treatment 3 | | Text
Treatment 4 | | Text
Intervention duration (day week month) | ___________________ □ day □ week □ month □ year □ NR | □
One outcome identified as primary | □ YES □ NO (specify) ________________________________________________________________________________ | One/text
Treatment compliance monitoring reported | □ YES □ NO | One
Double blinding is reported | □ YES □ NO | One
Withdrawals are reported by number and reason per arm | □ YES □ NO | One
Outcome (1) reported on | | Text
Units used for outcome (1) | | Text
Results of outcome (1) favor | | Text
Outcome (2) reported on | | Text
Units used for outcome (2) | | Text
Results of outcome (2) favor | | Text
Outcome (3) reported on | | Text
Units used for outcome (3) | | Text
Results of outcome (3) favor | | Text
Outcome (4) reported on | | Text
Units used for outcome (4) | | Text
Results of outcome (4) favor | | Text
Outcome (5) reported on | | Text
Units used for outcome (5) | | Text
Results of outcome (5) favor | | Text

THIS IS A CONSENSUS FORM □