# Appendix A. Search Strategies

## Medline and HealthStar

1 exp case-control studies/
2 prospective:.tw.
3 case control:.tw.
4 1 or 2 or 3
5 exp “sensitivity and specificity”/
6 sensitiv:.tw.
7 diagnos:.tw,sh.
8 di.fs.
9 biological variation.mp. [mp=title, abstract, keywords, mesh subject heading]
10 reliability.tw.
11 “reproducibility of results”/
12 mass screening/
13 screen:.tw.
14 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15 glucose intolerance/
16 (impaired glucose or impaired fasting glucose).tw.
17 (igt or ifg).tw.
18 blood glucose/
19 limit 18 to yr=1996-2004
20 glucose tolerance test/
21 prediabetic state/
22 prediabet:.tw.
23 pre-diabet:.tw.
24 fasting plasma glucose.tw.
25 15 or 16 or 17 or 19 or 20 or 21 or 22 or 23 or 24
26 exp epidemiologic studies/
27 predict:.mp.
28 ep.xs.
29 exp prognosis/
30 26 or 27 or 28 or 29
31 randomized-controlled-trial.pt.
32 controlled-clinical-trial.pt.
33 randomized-controlled-trials/
34 random-allocation/
35 double-blind-method/
36 single-blind-method/
37 clinical trial.pt.
38 exp clinical trials/
39 (clin: adj trial:).ti,ab.
40 ((singl: or doubl: or tripl: or trebl:) adj (mask: or blind:)).ti,ab.
41 placebos.sh.
42 placebo:.ti,ab.
43 random:.ti,ab.
44 research design/
45 exp cohort studies/
46 ((control: adj3 (group: or condition:)) or (control: adj2 (trial: or study or studies))).tw.]
47 (cohort adj (study or studies or trial or trials)).tw.
48 multivariate analysis/
49 intervention studies/
50 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49
51 animal/ not (animal/ and human/)
52 50 not 51
53 25 and 14 and 4
54 25 and 30 and 4
55 25 and 50
56 53 or 54 or 55
57 56 not 51
58 (addresses or analytic or bibliography or biography or classical article or comment or consensus development conference or consensus development conference nih or current biog obit or dictionary or directory or duplicate publication or editorial or festschrift or historial article or interview or lectures or legal cases or letter or news or newspaper article or review of reported cases or review tutorial or meeting abstracts or meeting report or meeting paper).pt.
59 57 not 58
60 limit 59 to (english language and yr=1979-2004)

## Cochrane

1 ((glucose next blood next level)
2 or (glucose next tolerance next test)
3 or prediabetes
4 or pre-diabetes
5 or prediabetic
6 or pre-diabetic
7 or igt
8 or ifg
9 or (glucose next intolerance)
10 or (impaired next glucose)
11 or (impaired next fasting next glucose)
12 or (fasting next plasma next glucose))

## Embase

1 “sensitivity and specificity”/
2 sensitiv:.tw
3 exp diagnosis/
4 diagnos:.tw.
5 di.fs.
6 biological variation.tw.
7 reliability.tw.
8 reproducibility/
9 screening/ or screening test/ or exp mass screening/
10 screen:.tw.
11 or/1–10
12 case control study/
13 prospective:.tw.
14 case control.tw.
15 or/12–14
16 exp methodology/
17 predict:.mp.
18 prognosis/
19 ep.fs.
20 or/16–19
21 exp Practice Guideline/
22 abstract report/ or editorial/ or letter/ or note/ or exp conference paper/
23 21 or 22
24 double blind procedure/ or experimental design/ or latin square design/ or parallel design/ or single blind procedure/
25 randomization/
26 (clin: adj trial:).ti,ab.
27 ((singl: or doubl: or tripl: or trebl:) adj (mask: or blind:)).ti,ab.
28 Placebo/
29 placebo:.ti,ab.
30 random:.ti,ab.
31 ((control: adj3 (group: or condition:)) or (control: adj2 (trial: or study or studies))).tw.
32 (cohort adj (study or studies or trial or trials)).tw.
33 exp multivariate analysis/
34 clinical study/ or case control study/ or clinical article/ or longitudinal study/ or major clinical study/ or open study/ or prospective study/ or retrospective study/ or clinical trial/ or multicenter study/ or phase 1 clinical trial/ or phase 2 clinical trial/ or phase 3 clinical trial/ or phase 4 clinical trial/ or randomized controlled trial/ or postmarketing surveillance/ or drug surveillance program/ or methodology/ or case finding/ or cohort analysis/ or contingent valuation/ or crossover procedure/ or double blind procedure/ or experimental design/ or intermethod comparison/ or latin square design/ or parallel design/ or pilot study/ or questionnaire/ or sample size/ or single blind procedure/ or evidence based medicine/ or meta analysis/ or outcomes research/ or quality control/ or good laboratory practice/ or medical audit/ or total quality management/ or validation process/
35 or/24–34
36 Glucose Intolerance/
37 (impaired glucose or impaired fasting glucose).tw.
38 (igt or ifg).tw.
39 glucose blood level/
40 exp glucose tolerance test/
41 prediabet:.tw.
42 pre-diabet:.tw.
43 fasting plasma glucose.tw.
44 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43
45 44 and 11 and 15
46 44 and 20 and 15
47 44 and 35
48 45 or 46 or 47
49 48 not 23
50 animal/ not (human/ and animal/)
51 49 not 50
52 limit to (english and yr=1979-2004)

## CINAHL

1 Glucose Intolerance/
2 (impaired glucose or impaired fasting glucose).tw.
3 (igt or ifg).tw.
4 Blood Glucose/
5 glucose/ or metabolism/ or metabolic diseases/
6 limit 5 to yr=1982-1998
7 Glucose Tolerance Test/
8 prediabet:.tw.
9 pre-diabet:.tw.
10 fasting plasma glucose.tw.
11 1 or 2 or 3 or 4 or 6 or 7 or 8 or 9 or 10
12 exp Clinical Trials/
13 Random Assignment/
14 clinical trial.pt.
15 (clin: adj trial:).ti,ab.
16 ((singl: or doubl: or tripl: or trebl:) adj (mask: or blind:)).ti,ab.
17 Placebos/
18 placebo:.ti,ab.
19 random:.ti,ab.
20 meta analysis/ or exp study design/
21 ((control: adj3 (group: or condition:)) or (control: adj2 (trial: or study or studies))).tw.
22 (cohort adj (study or studies or trial or trials)).tw.
23 Multivariate Analysis/
24 or/12–23
25 Case Control Studies/
26 prospective:.tw.
27 case control:.tw.
28 or/25–27
29 “Sensitivity and Specificity”/
30 sensitiv:.tw.
31 diagnos:.tw.
32 exp Diagnosis/
33 di.fs.
34 biological variation.tw.
35 reliability.tw.
36 Reproducibility of Results/
37 screen:.tw.
38 or/29–37
39 book preservation/ or book reviews/ or allied health literature/ or nursing literature/ or pamphlets/ or “policy and procedure manuals”/ or reports/ or incident reports/ or report writing/ or serial publications/ or newsletters/ or newspapers/ or “theses and dissertations”/
40 Epidemiological Research/
41 predict:.mp.
42 prognosis/ or treatment outcomes/
43 or/41–43
44 11 and 38 and 28
45 11 and 44 and 28
46 11 and 24
47 45 or 46 or 47
48 48 not 40
49 animal/ not (animal/ and human/)
50 49 not 50
51 limit 51 to (english and yr=1979-2003)

## AMED

1 exp glucose/ or blood glucose/
2 (impaired glucose or impaired fasting glucose).tw.
3 (igt or ifg).tw.
4 glucose tolerance test.tw.
5 prediabet:.tw.
6 fasting plasma glucose.tw.
7 or/1–6
8 exp clinical trials/ or randomized controlled trials/
9 exp research design/ or clinical trials/ or randomized controlled trials/ or comparative study/ or double blind method/ or random allocation/
10 (clin: adj trial:).ti,ab.
11 ((singl: or doubl: or tripl: or trebl:) adj (mask: or blind:)).ti,ab.
12 placebos/
13 placebo:.ti,ab.
14 random:.ti,ab.
15 ((control: adj3 (group: or condition:)) or (control: adj2 (trial: or study or studies))).tw.
16 (cohort adj (study or studies or trial or trials)).tw.
17 or/8–16
18 predict:.mp.
19 exp prognosis/
20 18 or 19
21 prospective:.tw.
22 case control:.tw.
23 21 or 22
24 sensitiv:.tw.
25 diagnos:.tw.
26 diagnosis/ or diagnosis computer assisted/ or diagnosis differential/ or diagnostic errors/ or “diagnostic techniques and procedures”/ or mass screening/
27 biological variation.tw.
28 reliability.tw.
29 reproducibility of results/
30 screen:.tw.
31 or/24–30
32 7 and 31 and 23
33 7 and 20 and 23
34 7 and 17
35 32 or 33 or 34
36 animal/ not (animal/ and human/)
37 35 not 36
38 limit 37 to (english and yr=1979-2004)

## PsycINFO

1 glucose intolerance
2 impaired glucose
3 impaired fasting glucose
4 igt or ifg
5 prediabetic or prediabetes or pre-diabetic or pre-diabetes
6 fasting plasma glucose
7 glucose blood level/
8 glucose tolerance test/
9 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8
10 #10 #9 and (LA=ENGLISH) and (PO=HUMAN) and (PY=1979-2004)