# Appendixes

Appendix A. Search Strategies

Appendix B. Forms

Appendix C. Lifestyle Studies

Appendix D. Peer Reviewers

Appendix E. Excluded Studies

Appendix F. Bibliography

Appendix G. Calculations