# List of Excluded Studies

Level 3 Exclusions: Citations did not provide sufficient level of evidence for related question.

Author not cited. Quick action in ER improves stroke care for all patients. Clin Resour Manag 2000;1(5):65–72.
Albers GW, Clark WM, for the et al. The ATLANTIS rt-PA (Alteplase) acute stroke trial: final results. Cerebrovasc Dis 1999;9(Suppl 1).
Alberts MJ, Perry A, Dawson DV, et al. Effects of public and professional education on reducing the delay in presentation and referral of stroke patients. Stroke. 1992;23(3):352-6. [pmid: 1542895].
Alexandrov AV. Ultrasound-enhanced thrombolysis for stroke: clinical significance. Eur J Ultrasound. 2002;16(12):131-40. [pmid: 12470858].
Alexandrov AV, Demchuk AM, Burgin WS, et al. Ultrasound-Enhanced Thrombolysis for Acute Ischemic Stroke: Phase I. Findings of the CLOTBUST Trial. J Neuroimaging. 2004;14(2):113-7. [pmid: 15095555].
Alexandrov AV, Wojner AW, Grotta JC, et al. CLOTBUST: design of a randomized trial of ultrasound-enhanced thrombolysis for acute ischemic stroke. J Neuroimaging. 2004;14(2):108-12. [pmid: 15095554].
Arnold M, Schroth G, Nedeltchev K, et al. Intra-arterial thrombolysis in 100 patients with acute stroke due to middle cerebral artery occlusion. Stroke. 2002;33(7):1828-33. [pmid: 12105361].
Baltacioglu F, Afsar N, Ekinci G, et al. Intraarterial thrombolysis with r-tPA for treatment of anterior circulation acute ischemic stroke: Technical and clinical results. Interventional Neuroradiology. 2003;9(3):273-82. [pmid: 20591253].
Barber PA, Demchuk AM, Hudon ME, et al. Hyperdense sylvian fissure MCA “dot” sign: A CT marker of acute ischemia. Stroke. 2001;32(1):84-8. [pmid: 11136919].
Barr JD, Mathis JM, Wildenhain S, L, et al. Acute stroke intervention with intraarterial urokinase infusion. Journal of Vascular & Interventional Radiology. 1994;5(5):705-13. [pmid: 8000119].
Barsan WG, Brott TG, Broderick JP, et al. Urgent therapy for acute stroke. Effects of a stroke trial on untreated patients. Stroke. 1994;25(11):2132-2137. [pmid: 7974533].
Becker K, Fruin M, Gooding T, et al. Community-based education improves stroke knowledge. Cerebrovasc Dis. 2001;11(1):34-43. [pmid: 11173792].
Bourekas EC, Slivka AP, Shah R, et al. Intraarterial thrombolytic therapy within 3 hours of the onset of stroke. Neurosurgery. 2004;54(1):39-44. [pmid: 14683539].
Brott TG, Haley ECJ, Levy DE, et al. Urgent therapy for stroke. Part I. Pilot study of tissue plasminogen activator administered within 90 minutes. Stroke. 1992;23(5):632-40. [pmid: 1579958].
Chalela JA, Kang DW, Luby M, et al. Early magnetic resonance imaging findings in patients receiving tissue plasminogen activator predict outcome: Insights into the pathophysiology of acute stroke in the thrombolysis era. Ann Neurol. 2004;55(1):105-12. [pmid: 14705118].
Cohen ZR, Ram Z, Knoller N, et al. Management and outcome of non-traumatic cerebellar haemorrhage. Cerebrovasc. Dis. 2002;14(34):207-13.
Collins DR, O'Neill D, McCormack PM. Potential for treatment with thrombolysis in an Irish stroke unit. Ir Med J. 1999;92(1):236-8. [pmid: 10360096].
Comerota AJ, Eze AR. Intraoperative high-dose regional urokinase infusion for cerebrovascular occlusion after carotid endarterectomy. Eur J Vasc Surg. 1996;24(6):1008-16.
Da Pian R, Bazzan A, Pasqualin A. Surgical versus medical treatment of spontaneous posterior fossa haematomas: a cooperative study on 205 cases. Neurol Res. 1984;6(3):145-51. [pmid: 6151139].
Deinsberger W, Lang C, Hornig C, et al. Stereotactic aspiration and fibrinolysis of spontaneous supratentorial intracerebral hematomas versus conservative treatment: a matched-pair study. Zentralbl. Neurochir. 2003;64(4):145-50.
Ducrocq X, Anxionnat R, Taillandier L,. Lacour J-C, Bracard S, Bollaert P-E, et al. Intravenous versus intra-arterial urokinase thrombolysis in acute ischemic stroke. Randomised study of 27 patients, Cerebrovascular Diseases, 10(Suppl 2), 2000
Egan R, Clark W, Lutsep H, et al. Efficacy of intraarterial thrombolysis of basilar artery stroke. Journal of Stroke & Cerebrovascular Diseases. 1999;8(1):22-7. [pmid: 17895133].
Emergency Management, Of Stroke, (EMS) Investigators. Combined intra-arterial and intravenous tPA for stroke. Stroke 1997;28(1):273.
Figueira FF. Stroke study group. Preliminary results. Early intensive care improves functional outcome. Arq Neuropsiquiatr. 1994;52(3):330-8. [pmid: 7893206].
Fitt GJ, Farrar J, Baird AE, et al. Intra-arterial streptokinase in acute ischaemic stroke. A pilot study. Med J Aust. 1993;159(5):331-334. [pmid: 8361430].
Gonner F, Remonda L, Mattle H, et al. Local intra-arterial thrombolysis in acute ischemic stroke. Stroke. 1998;29(9):1894-1900. [pmid: 9731615].
Hahnel S, Schellinger PD, Gutschalk A, et al. Local intra-arterial fibrinolysis of thromboemboli occurring during neuroendovascular procedures with recombinant tissue plasminogen activator. Stroke. 2003;34(7):1723-28. [pmid: 12805492].
Harbison J, Massey A, Barnett L, et al. Rapid ambulance protocol for acute stroke. Lancet. 1999;353(9168):1935. [pmid: 10371574].
Hardemark HG, Wesslen N, Persson L. Influence of clinical factors, CT findings and early management on outcome in supratentorial intracerebral hemorrhage. Cerebrovasc. Dis. 1999;9(1):10-21.
Haring HP, Dilitz E, Pallua A, et al. Attenuated corticomedullary contrast: An early cerebral computed tomography sign indicating malignant middle cerebral artery infarction. A case-control study.[see comment]. Stroke. 1999;30(5):1076-82. [pmid: 10229747].
Hill MD, Barber PA, Demchuk AM, et al. Acute intravenous--intra-arterial revascularization therapy for severe ischemic stroke. Stroke. 2002;33(1):279-82. [pmid: 11779923].
Hill MD, Rowley HA, Adler F, et al. Selection of acute ischemic stroke patients for intra-arterial thrombolysis with pro-urokinase by using ASPECTS.[see comment]. Stroke. 2003;34(8):1925-31. [pmid: 12843342].
IMS S. Combined intravenous and intra-arterial recanalization for acute ischemic stroke: the Interventional Management of Stroke Study.[see comment]. Stroke. 2004;35(4):904-11. [pmid: 15017018].
Ito H, Arakawa M, Shibasaki T, et al. Acute antihypertensive effect of nifedipine by sublingual route in cases with clinically severe systolic hypertension. A study up to 4 h after administration. Arzneimittelforschung. 1984;34(5):630-6. [pmid: 6380506].
Iwamoto N, Kusaka M, Tsurutani T, et al. Ultrasound imaging for stereotactic evacuation of hypertension-associated intracerebral hematomas with aqua-stream and aspiration. Stereotact Funct Neurosurg. 1993;60(4):194-204. [pmid: 8327798].
Kase CS, Furlan AJ, Wechsler LR, et al. Symptomatic intracranial hemorrhage after intraarterial thrombolysis with recombinant prourokinase in acute ischemic stroke: the PROACT II Study. Neurology 2000;54(Suppl 3):
Kaya RA, Turkmenoglu O, Ziyal IM, et al. The effects on prognosis of surgical treatment of hypertensive putaminal hematomas through transsylvian transinsular approach. Surg Neurol. 2003;59(3):176-183. [pmid: 12681546].
Kerber CW, Barr JD, Berger RM, et al. Snare retrieval of intracranial thrombus in patients with acute stroke. J Vasc Interv Radiol. 2002;13(12):1269-74. [pmid: 12471193].
Kidwell CS, Saver JL, Carneado J, et al. Predictors of hemorrhagic transformation in patients receiving intra-arterial thrombolysis.[see comment]. Stroke. 2002;33(3):717-24. [pmid: 11872894].
Kidwell CS, Saver JL, Starkman S, et al. Late secondary ischemic injury in patients receiving intraarterial thrombolysis.[see comment]. Ann Neurol. 2002;52(6):698-703. [pmid: 12447922].
Kim MH, Kim EY, Song JH, et al. Surgical options of hypertensive intracerebral hematoma: stereotactic endoscopic removal versus stereotactic catheter drainage. J Korean Med Sci. 1998;13(5):533-40. [pmid: 9811185].
Kim Y-B, Lee K-H, Lee SJ, et al. Safety and efficacy of intravenous thrombolysis with tissue plasminogen activator using triphasic perfusion CT in acute ischemic stroke. Cerebrovasc Dis 2000;10(Suppl 2):
Koenig M, Kraus M, Theek C, et al. Quantitative assessment of the ischemic brain by means of perfusion-related parameters derived from perfusion CT. Stroke. 2001;32(2):431-7. [pmid: 11157178].
Kuroda K, Kuwata N, Sato N, et al. Changes in cerebral blood flow accompanied with reduction of blood pressure treatment in patients with hypertensive intracerebral hemorrhages. Neurol Res. 1997;19(2):169-73. [pmid: 9175147].
Kurtsoy A, Oktem IS, Koc RK, et al. Surgical treatment of thalamic hematomas via the contralateral transcallosal approach. Neurosurg Rev. 2001;24(23):108-13. [pmid: 11485230].
Larrue V, von Kummer R, RR Muller A, et al. Risk factors for severe hemorrhagic transformation in ischemic stroke patients treated with recombinant tissue plasminogen activator: a secondary analysis of the European-Australasian Acute Stroke Study (ECASS II). Stroke. 2001;32(2):438-41. [pmid: 11157179].
Lee DH, Jo KD, Kim HG, et al. Local intraarterial urokinase thrombolysis of acute ischemic stroke with or without intravenous abciximab: a pilot study. J Vasc Interv Radiol. 2002;13(8):769-74. [pmid: 12171979].
Lee K, Lee S, Kim Y, et al. Usefulness of triphasic perfusion CT for intravenous thrombolysis with tissue plasminogen activator in acute ischemic stroke. Stroke. 2000;31(11):2889.
Lee KH, Lee SJ, Cho SJ, et al. Usefulness of triphasic perfusion computed tomography for intravenous thrombolysis with tissue-type plasminogen activator in acute ischemic stroke. Arch Neurol. 2000;57(7):1000-8. [pmid: 10891982].
Lev MH, Segal AZ, Farkas J, et al. Utility of perfusion-weighted CT imaging in acute middle cerebral artery stroke treated with intra-arterial thrombolysis: prediction of final infarct volume and clinical outcome. Stroke. 2001;32(9):2021-8. [pmid: 11546891].
Lin DDM, Gailloud P, Beauchamp NJ, et al. Combined Stent Placement and Thrombolysis in Acute Vertebrobasilar Ischemic Stroke. AJNR Am J Neuroradiol. 2003;24(9):1827-33. [pmid: 14561611].
Mahaffey KW, Granger CB, Sloan MA, et al. Neurosurgical evacuation of intracranial hemorrhage after thrombolytic therapy for acute myocardial infarction: experience from the GUSTO-I trial. Global Utilization of Streptokinase and tissue-plasminogen activator (tPA) for Occluded Coronary Arteries. Am Heart J. 1999;138(3 Pt 1):493-9. [pmid: 10467200].
Marler Tilley, BC Lu M, Brott T, et al. Earlier treatment associated with better outcomes in the ninds tPA stroke study. Stroke 1999;30244.
Mayer TE, Hamann GF, Brueckmann HJ. Treatment of basilar artery embolism with a mechanical extraction device: necessity of flow reversal.[see comment]. Stroke. 2002;33(9):2232-5. [pmid: 12215592].
McCarron MO, Nicoll JA, Love S, et al. Surgical intervention, biopsy and APOE genotype in cerebral amyloid angiopathy-related haemorrhage. Br J Neurosurg. 1999;13(5):462-7. [pmid: 10627776].
Moazami N, Smedira NG, McCarthy PM, et al. Safety and efficacy of intraarterial thrombolysis for perioperative stroke after cardiac operation.[see comment]. Ann Thorac. Surg. 2001;72(6):1933-7.
Morgenstern LB, King M, Staub L, et al. Community and professional intervention to increase FDA-approved acute stroke therapy: final main results of the TLL Temple Foundation stroke project. Neurology. 2001;56(suppl 3):A77.
Morgenstern LB, Staub L, Chan W, et al. Improving delivery of acute stroke therapy: The TLL Temple Foundation Stroke Project. Stroke. 2002;33(1):160-6. [pmid: 11779906].
Moulin T, Sablot D, Vidry E, et al. Impact of emergency room neurologists on patient management and outcome. Eur Neurol. 2003;50(4):207-14. [pmid: 14634264].
Muiz AJ, Abdullah J, Naing NN, et al. Spontaneous intracerebral hemorrhage in northeast Malaysian patients: a four-year study. Neuroepidemiology. 2003;22(3):184-195. [pmid: 12711851].
Nakano S, Iseda T, Yoneyama T, et al. Direct percutaneous transluminal angioplasty for acute middle cerebral artery trunk occlusion: an alternative option to intra-arterial thrombolysis.[see comment]. Stroke. 2002;33(12):2872-6. [pmid: 12468784].
Neumann-Haefelin T, Du Mesnil, Fiebach DR, et al. Effect of Incomplete (Spontaneous and Postthrombolytic) Recanalization after Middle Cerebral Artery Occlusion: A Magnetic Resonance Imaging Study. Stroke. 2004;35(1):109-14. [pmid: 14671246].
O'Rourke F, Akhtar N, Emery D, et al. Use of MRI in the identification and treatment of early ischemic stroke lesions. CMAJ. 2004;170(3):335-6. [pmid: 14757667]. [pmcid: 331381].
Patel RV, Kertland HR, Jahns BE, et al. Labetalol: response and safety in critically ill hemorrhagic stroke patients. Ann Pharmacother. 1993;27(2):180-1. [pmid: 8439694].
Pexman JH, Barber PA, Hill MD, et al. Use of the Alberta Stroke Program Early CT Score (ASPECTS) for assessing CT scans in patients with acute stroke. Ajnr: Am J Neuroradiol. 2001;22(8):1534-42. [pmid: 11559501].
Powers WJ, Zazulia AR, Videen TO, et al. Autoregulation of cerebral blood flow surrounding acute (6 to 22 hours) intracerebral hemorrhage.[see comment]. Neurology. 2001;57(1):18-24. [pmid: 11445622].
Qureshi AI, Ali Z, Suri MF, et al. Intra-arterial third-generation recombinant tissue plasminogen activator (reteplase) for acute ischemic stroke. Neurosurgery. 2001;49(1):41-8. [pmid: 11440458].
Qureshi AI, Siddiqui AM, Suri MF, et al. Aggressive mechanical clot disruption and low-dose intra-arterial third-generation thrombolytic agent for ischemic stroke: a prospective study. Neurosurgery. 2002;51(5):1319-27. [pmid: 12383381].
Qureshi AI, Suri MF, Shatla AA, et al. Intraarterial recombinant tissue plasminogen activator for ischemic stroke: an accelerating dosing regimen.[see comment]. Neurosurgery. 2000;47(2):473-6. [pmid: 10942026].
Restrepo L, Pradilla G, Llinas R, et al. Perfusion- and diffusion-weighted MR imaging-guided therapy of vertebral artery dissection: intraarterial thrombolysis through an occipital vertebral anastomosis. Am J Neuroradiol. 2003;24(9):1823-6. [pmid: 14561610].
Riopelle RJ, Howse DC, Bolton C, et al. Regional access to acute ischemic stroke intervention. Stroke. 2001;32(3):652-5. [pmid: 11239182].
Roux FE, Boetto S, Tremoulet M. Third ventriculocisternostomy in cerebellar haematomas. Acta Neurochir (Wien). 2002;144(4):337-42. [pmid: 12021879].
Sakas DE, Singounas EG, Karvounis PC. Spontaneous intracerebral haematomas: surgical versus conservative treatment based on Glascow Coma Scale score and computer tomography data. J Neurosurg Sci. 1989;33(2):165-72. [pmid: 2795189].
Schaller C, Rohde V, Meyer B, et al. Stereotactic puncture and lysis of spontaneous intracerebral hemorrhage using recombinant tissue-plasminogen activator. Neurosurgery. 1995;36(2):328-33. [pmid: 7731513].
Siddique MS, Fernandes HM, Arene NU, et al. Changes in cerebral blood flow as measured by HMPAO SPECT in patients following spontaneous intracerebral haemorrhage. Acta Neurochir Suppl 2000;76517–20.
Silver B, Demaerschalk B, Merino JG, et al. Improved outcomes in stroke thrombolysis with pre-specified imaging criteria.[see comment]. Can J Neurol Sci. 2001;28(2):113-9. [pmid: 11383934].
Smith WS, Corry MD, Fazackerley J, et al. Improved paramedic sensitivity in identifying stroke victims in the prehospital setting. Prehosp Emerg Care. 1999;3(3):207-10. [pmid: 10424857].
Steiner T, Bluhmki E, Kaste M, et al. The ECASS 3-hour cohort. Secondary analysis of ECASS data by time stratification. ECASS Study Group. European Cooperative Acute Stroke Study. Cerebrovasc Dis. 1998;8(4):198-203. [pmid: 9684058].
Suwanwela NC, Phanthumchinda K, Suwanwela N, et al. Thrombolytic treatment for acute ischemic stroke: a 2 year-experience at King Chulalongkorn Memorial Hospital. J Med Assoc Thai. 2001;84(Suppl 1):S428-36. [pmid: 11529370].
Sylaja PN, Kuruttukulam G, Joseph S, et al. Selective intra arterial thrombolysis in acute carotid territory stroke. Neurol India. 2001;49(2):153-7. [pmid: 11447435].
Tan SH, Ng PY, Yeo TT, et al. Hypertensive basal ganglia hemorrhage: a prospective study comparing surgical and nonsurgical management. Surg Neurol. 2001;56(5):287-92. [pmid: 11749988].
The EMS, Bridging Trial, Investigators. Combined intravenous/intra-arterial thrombolytic therapy: safety, time to treatment, and frequency of clot. Stroke 1996;27(1):165.
Tilley BC, Lyden PD, Brott TG, et al. Total quality improvement method for reduction of delays between emergency department admission and treatment of acute ischemic stroke. The National Institute of Neurological Disorders and Stroke rt-PA Stroke Study Group. Arch Neurol. 1997;54(12):1466-74. [pmid: 9400355].
Tong DC, Adami A, Moseley ME, et al. Prediction of hemorrhagic transformation following acute stroke: role of diffusion- and perfusion-weighted magnetic resonance imaging.[see comment]. Arch Neurol. 2001;58(4):587-93. [pmid: 11295989].
Tong DD. Intra-arterial thrombolytic therapy for acute stroke: the debate continues.[comment]. Stroke. 2002;33(7):1827. [pmid: 12109492].
Tyler D, Mandybur G. Interventional MRI-guided stereotactic aspiration of acute/subacute intracerebral hematomas. Stereotact Funct Neurosurg. 1999;72(24):129-35. [pmid: 10853064].
Ueda T, Hatakeyama T, Kumon Y, et al. Evaluation of risk of hemorrhagic transformation in local intra-arterial thrombolysis in acute ischemic stroke by initial SPECT. Stroke. 1994;25(2):298-303. [pmid: 8303735].
Ueda T, Sakaki S, Nochide I, et al. Angioplasty after intra-arterial thrombolysis for acute occlusion of intracranial arteries. Stroke. 1998;29(12):2568-74. [pmid: 9836769].
von Kummer R, Allen KL, Holle R, et al. Acute stroke: usefulness of early CT findings before thrombolytic therapy.[see comment]. Radiology. 1997;205(2):327-33. [pmid: 9356611].
von Kummer R, Bourquain H, Bastianello S, et al. Early prediction of irreversible brain damage after ischemic stroke at CT. Radiology. 2001;219(1):95-100. [pmid: 11274542].
Wardlaw JM, Lindley RI, Warlow CP, et al. A pilot study of intra-arterial thrombolysis for acute ischaemic stroke. J Neurol Neurosurg Psychiatry 1994;57251.
Wechsler LR, Roberts R, Furlan AJ, et al. Factors influencing outcome and treatment effect in PROACT II. Stroke. 2003;34(5):1224-9. [pmid: 12677011].
Weinhardt J, Parker C. Developing a patient education video as a tool to case manage patients who have had strokes. Nurs Case Manag. 1999;4(4):198-200. [pmid: 10690108].
Wester P, Radberg J, Lundgren B, et al. Factors associated with delayed admission to hospital and in-hospital delays in acute stroke and TIA: a prospective, multicenter study. Seek- Medical-Attention-in-Time Study Group. Stroke. 1999;30(1):40-8. [pmid: 9880386].
Williams JE, Rosamond WD, Morris DL. Stroke symptom attribution and time to emergency department arrival: the delay in accessing stroke healthcare study. Acad Emerg Med. 2000;7(1):93-6. [pmid: 10894250].
Yoneda Y, Mori E, Uehara T, et al. Intracarotid regional infusion of recombinant tissue plasminogen activator for acute hemispheric stroke. Cerebrovasc Dis 1998;8357–9.
Yoneyama T, Nakano S, Kawano H, et al. Combined direct percutaneous transluminal angioplasty and low-dose native tissue plasminogen activator therapy for acute embolic middle cerebral artery trunk occlusion. Ajnr: Am J Neuroradiol. 2002;23(2):277-81. [pmid: 11847054].
Zaidat OO, Suarez JI, Santillan C, et al. Response to intra-arterial and combined intravenous and intra-arterial thrombolytic therapy in patients with distal internal carotid artery occlusion.[see comment]. Stroke. 2002;33(7):1821-6. [pmid: 12105360].
Zeumer H, Freitag HJ, Zanella F, et al. Local intra-arterial fibrinolytic therapy in patients with stroke: urokinase versus recombinant tissue plasminogen activator (r-TPA). Neuroradiology. 1993;35(2):159-62. [pmid: 8433796].
Ziai WC, Port JD, Cowan JA, et al. Decompressive craniectomy for intractable cerebral edema: experience of a single center. J Neurosurg Anesthesiol. 2003;15(1):25-32. [pmid: 12499979].

Level 2 Exclusions

A comparison of reteplase with alteplase for acute myocardial infarction. The Global Use of Strategies to Open Occluded Coronary Arteries (GUSTO III) Investigators.[see comment]. N Engl J Med 1997;337(16):1118–1123. Study did not involve relevant population [defined as adult (>16) with acute stroke].
A systems approach to immediate evaluation and management of hyperacute stroke. Experience at eight centers and implications for community practice and patient care. The National Institute of Neurological Disorders and Stroke (NINDS) rt-PA Stroke Study Group. Stroke 1997;28(8):1530–1540. No intervention of interest studied.
Abe T. Oral urokinase: absorption, mechanisms of fibrinolytic enhancement and clinical effect on cerebral thrombosis. Folia Haematologica - Internationales Magazin fur Klinische und Morphologische Blutforschung. 1986;113(12):122-136. No intervention of interest studied.
Abernethy JD, Baker JL, Bullen MU et al. Report on progress in the Australian National Blood Pressure Study (NBPS). Clinical Science & Molecular Medicine - Supplement 1976;3645s-647s. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Adams HPJ. Management of patients with acute ischaemic stroke. [erratum appears in Drugs. Mar. 2000;59(3):476. ]. [Review][87 refs]. Drugs 1997;54 Suppl 360–69. No original empirical evidence presented.
Adams HPJ. Low molecular weight heparinoid, ORG 10172 (danaparoid), and outcome after acute ischemic stroke: A randomized controlled trial. J Am Med Assoc. 1998;279(16):1265-1272. No intervention of interest studied.
Adams JG, Chisholm CD. SAEM Board, et al. The Society for Academic Emergency Medicine position on optimizing care of the stroke patient.[see comment]. Acad Emerg Med. 2003;10(7):805N. o human participants. [pmid: 12837657].
Adams HP, Adams RJ, Brott T, et al. Guidelines for the early management of patients with ischemic stroke: A scientific statement from the Stroke Council of the American Stroke Association. Stroke. 2003;34(4):1056-1083. No original empirical evidence presented. [pmid: 12677087].
Adamson K. A winning team. Case Manager. 2004;15(3):67-70. Unable to obtain by final date for inclusion. [pmid: 15163963].
Adiseshiah M. Avoidable factors in stroke. Consider carotid endarterectomy.[see comment][comment]. BMJ. 1994;308(6922):201N. o original empirical evidence presented.
Agarwal R. Selection of initial antihypertensive therapy, regimen design, and goal blood pressure. Cardiol Rev. 2003;11(4):197-205. No original empirical evidence presented. [pmid: 12852796].
Ahmed N, Nasman P, Wahlgren NG. Effect of intravenous nimodipine on blood pressure and outcome after acute stroke. Stroke. 2000;31(6):1250-1255. No intervention of interest studied. [pmid: 10835440].
Ahmed N, Wahlgren G. High initial blood pressure after acute stroke is associated with poor functional outcome. J Intern Med. 2001;249(5):467-473. No intervention of interest studied. [pmid: 11350571].
Ahmed N, Wahlgren NG. Effects of blood pressure lowering in the acute phase of total anterior circulation infarcts and other stroke subtypes. Cerebrovasc Dis. 2003;15(4):235-243. No intervention of interest studied. [pmid: 12686786].
Akins CW, Daggett WM, Vlahakes GJ et al. Cardiac operations in patients 80 years old and older. Ann Thorac Surg 1997;64(3):606–614. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Akopov S, Cohen SN. Preventing stroke: A review of current guidelines. J Am Med Dir Assoc 2003;4(5 SUPPL.):S127–S132. No original empirical evidence presented.
Akopov SE, Simonian NA. Comparison of isradipine and enalapril effects on regional carotid circulation in patients with hypertension with unilateral internal carotid artery stenosis. J Cardiovasc Pharmacol 1997;30(5):562–570. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Alabama benchmarking project improves stroke treatment. Data Strateg Benchmarks 2002;6(8):113–118. No original empirical evidence presented.
Albers GW. Advances in intravenous thrombolytic therapy for treatment of acute stroke. [Review] [37 refs]. Neurology. 2001;57(5 Suppl 2):S77-S81. No original empirical evidence presented. [pmid: 11552060].
Albers GW. Expanding the window for thrombolytic therapy in acute stroke. The potential role of acute MRI for patient selection. Stroke. 1999;30(10):2230-2237. No original empirical evidence presented. [pmid: 10512933].
Albers GW. Rationale for early intervention in acute stroke. [Review] [32 refs]. Am J Cardiol. 1997;80(4C):4D-10D. No original empirical evidence presented.
Albers GW. Prevention and management issues in stroke. Consultant. 2003;43(2):243-251. No original empirical evidence presented.
Alberts MJ. Emergency brain resuscitation. [Review] [48 refs]. Compr Ther. 1997;23(6):391-399. No original empirical evidence presented. [pmid: 9239489].
Alberts MJ. TPA in stroke. Neurology 1993;43233No original empirical evidence presented.
Alberts MJ, Bennett CA, Rutledge VR. Hospital charges for stroke patients. Stroke. 1996;27(10):1825-1828. No intervention of interest studied. [pmid: 8841339].
Alberts MJ, Easton JD. Stroke Best Practices: A Team Approach to Evidence-Based Care. J Natl Med Assoc. 2004;96(4 SUPPL.):5S-20S. No original empirical evidence presented.
Alexander KP, Peterson ED. Evidence-based care for all patients. Am J Med. 2003;114(4):333-335. No original empirical evidence presented. [pmid: 12681466].
Alexandrov AV, Burgin WS, Demchuk AM, et al. Speed of intracranial clot lysis with intravenous tissue plasminogen activator therapy: sonographic classification and short-term improvement. Circulation. 2001;103(24):2897-2902. No intervention of interest studied. [pmid: 11413077].
Alexandrov AV, Demchuk AM, Felberg RA, et al. High rate of complete recanalization and dramatic clinical recovery during tPA infusion when continuously monitored with 2-MHz transcranial doppler monitoring.[see comment]. Stroke. 2000;31(3):610-614. No intervention of interest studied. [pmid: 10700493].
Alexandrov AV, Demchuk AM, Felberg RA, et al. Intracranial clot dissolution is associated with embolic signals on transcranial Doppler. J Neuroimaging. 2000;10(1):27-32. No intervention of interest studied. [pmid: 10666979].
Alexandrov AV, Grotta JC. Arterial reocclusion in stroke patients treated with intravenous tissue plasminogen activator. Neurology. 2002;59(6):862-867. No intervention of interest studied. [pmid: 12297567].
Alexandrov AV, Hall CE, Labiche LA, et al. Ischemic Stunning of the Brain: Early Recanalization Without Immediate Clinical Improvement in Acute Ischemic Stroke. Stroke. 2004;35(2):449-452. No intervention of interest studied. [pmid: 14726543].
Alexandrov AV, Masdeu JC, Devous MDS, et al. Brain single-photon emission CT with HMPAO and safety of thrombolytic therapy in acute ischemic stroke. Proceedings of the meeting of the SPECT Safe Thrombolysis Study Collaborators and the members of the Brain Imaging Council of the Society of Nuclear Medicine. [Review] [32 refs]. Stroke. 1997;28(9):1830-1834. No original empirical evidence presented. [pmid: 9303032].
Alexandrov AV, Pullicino PM, Meslin EM, et al. Agreement on disease-specific criteria for do-not-resuscitate orders in acute stroke. Members of the Canadian and Western New York Stroke Consortiums. Stroke. 1996;27(2):232-237. No original empirical evidence presented. [pmid: 8571415].
Algra A. Atenolol (50mg a day) in patients after a TIA or minor stroke. Cerebrovasc Dis 1992;2236Study did not involve relevant population [defined as adult (>16) with acute stroke].
Allen GS. Role of calcium antagonists in cerebral arterial spasm. Am J Cardiol. 1985;55(3):149B-153B. No human participants.
Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. Journal of Stroke & Cerebrovascular Diseases. 2002;11(2):88-98. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 17903862].
Allen KR, Hazelett SE, Palmer RR, et al. Developing a stroke unit using the acute care for elders intervention and model of care. [Review] [30 refs]. J Am Geriatr Soc. 2003;51(11):1660-1667. No original empirical evidence presented. [pmid: 14687400].
Alteplase for thrombolysis in acute ischemic stroke. Medical Letter on Drugs & Therapeutics 1996;38(987):99–100. No original empirical evidence presented.
Alter M, Lai SM, Friday G, et al. Stroke recurrence in diabetics. Does control of blood glucose reduce risk? Stroke. 1997;28(6):1153-1157. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Alvarez-Sabin J, Molina C, Montaner J, et al. [Clinical benefit following the implementation of a specialized urgent stroke care system].[see comment]. [Spanish]. Med Clin (Barc). 4–17. 2004;122(14):528-531. Unable to obtain by final date for inclusion. [pmid: 15117644].
Amery A, Birkenhager W, Brixko P, et al. Mortality and morbidity results from the European Working Party on High Blood Pressure in the Elderly trial. Lancet. 1985;1(8442):1349-1354. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 2861311].
Andrews PJ. Critical care management of acute ischemic stroke. Curr Opin Crit Care. 2004;10(2):110-115. No original empirical evidence presented. [pmid: 15075720].
Anzola GP, Zavarize P, Morandi E, et al. Transcranial Doppler and risk of recurrence in patients with stroke and patent foramen ovale. Eur J Neurol. 2003;10(2):129-135. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12603287].
Arai T, Sekizawa K, Yoshimi N, et al. Cabergoline and silent aspiration in elderly patients with stroke [2]. J Am Geriatr Soc. 2003;51(12):1815-1816. No original empirical evidence presented. [pmid: 14687367].
Arai T, Yasuda Y, Takaya T, et al. Angiotensin II receptor antagonists cannot prevent symptomless dysphagia in hypertensive bedridden older patients with stroke. J Am Geriatr Soc. 2000;48(12):1741-1742. No original empirical evidence presented.
Arai T, Yoshimi N, Fujiwara H, et al. Serum substance P concentrations and silent aspiration in elderly patients with stroke. Neurology. 2003;61(11):1625-1626. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14663061].
Ardern-Holmes SL, Raman R, Anderson NE, et al. Opinion of New Zealand physicians on management of acute ischaemic stroke: results of a national survey. Australian & New Zealand Journal of Medicine. 1999;29(3):324-330. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10868495].
Arjona A, Serrano-Castro. [Malignant middle cerebral artery infarction: medical or surgical treatment?]. Rev Neurol 1-16-2004;38(2):145–150. Non-English publication.
Arterburn D, Noel PH. Extracts from “Clinical Evidence”. Obesity. BMJ. 2001;322(7299):1406-1409. No original empirical evidence presented. [pmid: 11397749]. [pmcid: 1120474].
Aschenbrenner DS. HRT Reconsidered: What should you tell patients about it now? [Review] [13 refs]. AJN, American Journal of Nursing. 2004;104(6):51-53. Unable to obtain by final date for inclusion.
Asia Pacific Consensus Forum on Stroke Management. [Review][0 refs]. Stroke 1998;29(8):1730–1736. No original empirical evidence presented.
Asimos AW, Norton HJ, Price MF, et al. Therapeutic yield and outcomes of a community teaching hospital code stroke protocol. Acad Emerg Med. 2004;11(4):361-370. Unable to obtain by final date for inclusion. [pmid: 15064210].
Aslanyan S, Fazekas F, Weir CJ, et al. Effect of blood pressure during the acute period of ischemic stroke on stroke outcome: a tertiary analysis of the GAIN International Trial. Stroke. 2003;34(10):2420-2425. No intervention of interest studied. [pmid: 14500934].
Aspirin and cardiovascular disease. S Afr Med J 2003;93(12 I):892No original empirical evidence presented.
Asplund K, Hagg E, Helmers C et al. The natural history of stroke in diabetic patients. Acta Med Scand 1980;207(5):417–424. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Avery JK. Loss prevention case of the month. Was there real deviation in this case?. Tenn Med. 2003;96(12):548-549. Unable to obtain by final date for inclusion. [pmid: 15077558].
Awad IA, Fayad P, Abdulrauf SI. Protocols and critical pathways for stroke care. [Review][26 refs]. Clin Neurosurg 1999;4586–100. No original empirical evidence presented.
Ayala C, Croft JB, Keenan NL, et al. Increasing trends in pre-transport stroke deaths--United States, 1990-1998. Ethn Dis. 2003;13(2 Suppl 2):S131-S137. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 13677428].
Aylward P. Can we improve on front-loaded alteplase (r-TPA)?. Australian & New Zealand Journal of Medicine. 1998;28(4):511-513. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9777130].
Aylward PE, Wilcox RG, Horgan JH, et al. Relation of increased arterial blood pressure to mortality and stroke in the context of contemporary thrombolytic therapy for acute myocardial infarction. A randomized trial. GUSTO-I Investigators. Ann Intern Med. 1996;125(11):891-900. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8967669].
Azcona A, Lataste X. Isradipine in patients with acute ischaemic cerebral infarction. An overview of the ASCLEPIOS Programme. Drugs. 1990;40 Suppl:252-57. No intervention of interest studied.
Baardman T, Hermens WT, Lenderink T, et al. Differential effects of tissue plasminogen activator and streptokinase on infarct size and on rate of enzyme release: influence of early infarct related artery patency. The GUSTO Enzyme Substudy.[comment]. Eur Heart J. 1996;17(2):237-246. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8732377].
Background Health Technol Assess 2004; 8(1): No original empirical evidence presented.
Badrinath P. Preventing stroke with ramipril. Results should have been presented in ways that help practising clinicians.[see comment][comment]. BMJ. 2002;325(7361):439N. o original empirical evidence presented.
Baird AE, Donnan GA, Austin MC, et al. Reperfusion after thrombolytic therapy in ischemic stroke measured by single-photon emission computed tomography. Stroke. 1994;25(1):79-85. No original empirical evidence presented. [pmid: 8266387].
Baird TA, Parsons MW, Phanh T, et al. Persistent poststroke hyperglycemia is independently associated with infarct expansion and worse clinical outcome. Stroke. 2003;34(9):2208-2214. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12893952].
Barber AC. Changes in stroke care at Auckl and Hospital between 1996 and 2001. N Z Med J 2004;117(1190):U797No intervention of interest studied.
Barber M, Langhorne P, Stott DJ. Barriers to delivery of thrombolysis for acute stroke. Age & Ageing. 2004;33(2):94-95. No original empirical evidence presented. [pmid: 14960419].
Barber PA, Demchuk AM, Zhang J, et al. Computed tomographic parameters predicting fatal outcome in large middle cerebral artery infarction. Cerebrovasc Dis. 2003;16(3):230-235. No intervention of interest studied. [pmid: 12865610].
Barber PA, Hill MD, Demchuk AM, et al. Doubts, fears and misconceptions. What is the future of thrombolysis in acute stroke? [Review] [33 refs]. Can J Neurol Sci. 2000;27(4):283-287. No original empirical evidence presented. [pmid: 11097516].
Barber A, Charleston A, Anderson N et al. Changes in stroke care at Auckland Hospital between 1996 and 2001.[see comment]. N Z Med J 3-12-2004;117(1190):U797Unable to obtain by final date for inclusion.
Barber PA, Parsons MW, Desmond PM, et al. The use of PWI and DWI measures in the design of “proof-of-concept” stroke trials. J Neuroimaging. 2004;14(2):123-132. Unable to obtain by final date for inclusion. [pmid: 15095557].
Barch C, Spilker J, Bratina P, et al. Nursing management of acute complications following rt-PA in acute ischemic stroke. The NINDS rt-PA Stroke Study Group. [Review] [18 refs]. J Neurosci Nurs. 1997;29(6):367-372. No original empirical evidence presented. [pmid: 9479658].
Barinaga M. Finding new drugs to treat stroke. Science. 1996;272(5262):664-666. No original empirical evidence presented. [pmid: 8614822].
Barnes MP. Community Rehabilitation after Stroke. Critical Reviews in Physical & Rehabilitation Medicine. 2003;15(34):223-234. No original empirical evidence presented.
Barr JD, Connors JJ, Sacks D, et al. Quality improvement guidelines for the performance of cervical carotid angioplasty and stent placement: Developed by a collaborative panel of the American Society of Interventional and Therapeutic Neuroradiology, the American Society of Neuroradiology, and the Society of Interventional Radiology. Journal of Vascular & Interventional Radiology. 2003;14(9 I):1079-1093. No human participants. [pmid: 14514797].
Barrowman NJ. Missing the point (estimate)? Confidence intervals for the number needed to treat.[comment]. CMAJ Canadian Medical Association Journal. 2002;166(13):1676-1677. No human participants.
Barsan WG, Brott TG, Broderick JP, et al. Time of hospital presentation in patients with acute stroke. Arch Intern Med. 1993;153(22):2558-2561. No intervention of interest studied. [pmid: 7598755].
Barsan WG, Brott TG, Olinger CP, et al. Identification and entry of the patient with acute cerebral infarction. [Review] [35 refs]. Ann Emerg Med. 1988;17(11):1192-1195. No original empirical evidence presented. [pmid: 3142316].
Barton J, Levene J, Kladakis B, et al. Stroke: a group learning approach. Nurs Times. 2002;98(7):34-35. No original empirical evidence presented.
Bath P. Alteplase not yet proven for acute ischaemic stroke.[see comment][comment]. Lancet. 1998;352(9136):1238-1239. No original empirical evidence presented. [pmid: 9788448].
Bath P, Bath F, Rashid P, et al. Acute ischaemic stroke. Large trial of effect of reducing blood pressure in acute stroke is being set up.[comment]. BMJ. 2000;321(7256):300. No original empirical evidence presented.
Bauer RB, Tellez H. Dexamethasone as treatment in cerebrovascular disease. 2. A controlled study in acute cerebral infarction. Stroke. 1973;4(4):547-555. No intervention of interest studied. [pmid: 4579369].
Baumgartner RW, Studer A, Arnold M, et al. Recanalisation of cerebral venous thrombosis. Journal of Neurology, Neurosurgery & Psychiatry. 2003;74(4):459-461. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Bazta JJ, Hornillos M, Rodriguez M, et al. More on PROSPER [10] (multiple letters). Lancet. 2003;361(9363):1135-1136. No original empirical evidence presented.
Becker KJ. Thrombolysis for acute ischemic stroke. [Review] [52 refs]. Physical Medicine & Rehabilitation Clinics of North America. 1999;10(4):773-785. No original empirical evidence presented. [pmid: 10573706].
Becker KJ, Baxter AB, Bybee HM, et al. Extravasation of radiographic contrast is an independent predictor of death in primary intracerebral hemorrhage. Stroke. 1999;30(10):2025-2032. No intervention of interest studied. [pmid: 10512902].
Becker KJ, Tirschwell DL. Ensuring patient safety in clinical trials for treatment of acute stroke.[see comment][comment]. JAMA. 2001;286(21):2718-2719. No original empirical evidence presented. [pmid: 11730448].
Bednar MM, Gross CE. Antiplatelet therapy in acute cerebral ischemia.[see comment]. [Review] [96 refs]. Stroke. 1999;30(4):887-893. No original empirical evidence presented. [pmid: 10187896].
Behrens S, Daffertshofer M, Interthal C, et al. Improvement in stroke quality management by an educational programme. Cerebrovasc Dis. 2002;13(4):262-266. No intervention of interest studied. [pmid: 12011551].
Belardi P, Lucertini G, Ermirio D. Stump pressure and transcranial Doppler for predicting shunting in carotid endarterectomy. European Journal of Vascular & Endovascular Surgery. 2003;25(2):164-167. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12552479].
Ben Hur T, Cohen JE. Case 5-2004: a man with slurred speech and left hemiparesis.[comment]. N Engl J Med. 5–20. 2004;350(21):2213-2214. Unable to obtain by final date for inclusion.
Benavente O, Hart RG. Stroke: part II. Management of acute ischemic stroke. [Review] [21 refs]. Am Fam Physician. 1999;59(10):2828-2834. No original empirical evidence presented. [pmid: 10348075].
Bendixen BH, Ocava L. Evaluation and management of acute ischemic stroke. [Review] [54 refs]. Curr Cardiol Rep. 2002;4(2):149-157. No original empirical evidence presented. [pmid: 11827639].
Benesch C. Antithrombotic and thrombolytic therapy for ischemic stroke. Curr Atheroscler Rep. 2003;5(4):267-275. No original empirical evidence presented. [pmid: 12793967].
Bennett J, Glasziou P. Ins and outs of the pharmaceutical benefits scheme. Med Today. 2003;4(3):105-110. Unable to obtain by final date for inclusion.
Bentur N, Resnizky S. Care of acute stroke patients in general hospitals in Israel. Israel Medical Association Journal: Imaj. 2003;5(5):343-345. No intervention of interest studied.
Berger C, Fiorelli M, Steiner T, et al. Hemorrhagic transformation of ischemic brain tissue: asymptomatic or symptomatic?[see comment]. Stroke. 2001;32(6):1330-1335. No intervention of interest studied. [pmid: 11387495].
Berglund G, Sannerstedt R, Andersson O, et al. Coronary heart-disease after treatment of hypertension. Lancet. 1978;1(8054):1-5. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 74494].
Berlis A, Lutsep H, Barnwell S, et al. Mechanical thrombolysis in acute ischemic stroke with endovascular photoacoustic recanalization. Stroke. 2004;35(5):1112-1116. Unable to obtain by final date for inclusion. [pmid: 15017011].
Berrouschot J, Barthel H, Hesse S, et al. Reperfusion and metabolic recovery of brain tissue and clinical outcome after ischemic stroke and thrombolytic therapy. Stroke. 2000;31(7):1545-1551. No intervention of interest studied. [pmid: 10884451].
Bes A, Orgogozo JM, Poncet M, et al. A 24-month, double-blind, placebo-controlled multicentre pilot study of the efficacy and safety of nicergoline 60 mg per day in elderly hypertensive patients with leukoaraiosis. Eur J Neurol. 1999;6(3):313-322. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10210912].
Bhalla A, Wolfe CD, Rudd AG. Management of acute physiological parameters after stroke. [Review] [79 refs]. QJM. 2001;94(3):167-172. No original empirical evidence presented. [pmid: 11259692].
Birkmeyer JD. Invited commentary: Is it a mistake to focus on errors?. Surgery. 2003;133(6):622-623. No human participants. [pmid: 12796728].
Bis JC, Smith NL, Psaty BM, et al. Angiotensinogen Met235Thr polymorphism, angiotensin-converting enzyme inhibitor therapy, and the risk of nonfatal stroke or myocardial infarction in hypertensive patients. Am J Hypertens. 2003;16(12):1011-1017. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14643574].
Bisset AF, Chesson R. Qualitative study on patients with stroke. Leaves questions unanswered.[comment]. BMJ. 1995;311(7010):949-950. No original empirical evidence presented.
Black A. Innocence revisited - 38. Med Today. 2003;4(8):99U. nable to obtain by final date for inclusion.
Blackman DJ, Ferguson JD, Sprigings DC, et al. Revascularisation for acute coronary syndromes in older people. Age & Ageing. 2003;32(2):129-135. No original empirical evidence presented. [pmid: 12715777].
Blake K. Evaluation of stroke family support services. National Research Register 2001;(1):Unable to obtain by final date for inclusion.
Blard JM, Finiels PJ, Combalbert A, et al. [Symptomatic aneurysms of the postero-inferior cerebellar artery. A multicenter retrospective study of 29 cases]. [Review] [53 refs] [French]. Rev Neurol (Paris). 1997;155(1):41-50. Non-English publication. [pmid: 9296155].
Blood pressure, in Acute, Stroke Collaboration et al. Interventions for deliberately altering blood pressure in acute stroke.[update of Cochrane Database Syst Rev. 2000;(2):CD000039; PMID: 10796286]. [Review][50 refs]. Cochrane Database Syst Rev 2001;(3):CD000039No original empirical evidence presented.
Blood pressure, in Acute, Stroke Collaboration et al. Interventions for deliberately altering blood pressure in acute stroke.[update of Cochrane Database Syst Rev. 2000;(2):CD000039; PMID: 10796286]. [Review][50 refs]. Cochrane Database Syst Rev 2001;(3):CD000039No original empirical evidence presented.
Blood pressure lowering for the secondary prevention of stroke: rationale and design for PROGRESS. PROGRESS Management Committee. Perindopril Protection Against Recurrent Stroke Study. [Review][20 refs]. Journal of Hypertension - Supplement 1996;14(2):S41–S45. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Boatright. New urgency for rapid transport of patients with stroke to appropriate hospitals. [Review][2 refs]. J Emerg Nurs 2003;29(4):344–346. No original empirical evidence presented.
Boger RH. [Asymmetrical methylarginine (ADMA) as a cardiovascular risk factor: epidemiological and prospective data]. [Review] [31 refs] [German]. Dtsch Med Wochenschr. 4–8. 2004;129(15):820-824. Unable to obtain by final date for inclusion. [pmid: 15054688].
Bogousslavsky J, Aarli J, Kimura J. Stroke and neurology: A plea from the WFN. Lancet Neurology. 2003;2(4):212-213. No human participants. [pmid: 12849207].
Bogousslavsky J, Aarli J, Kimura J. Stroke: Time for a global campaign?. Cerebrovasc Dis. 2003;16(2):111-113. No human participants. [pmid: 12852391].
Bogousslavsky J, Paciaroni M, Gallai V. Acute stroke treatment: thrombolysis. [Review] [27 refs]. Cerebrovasc Dis. 2000;10 Suppl:414-16. No original empirical evidence presented.
Boissel JP, Gueyffier F, Boutitie F. Risk reduction for stroke and coronary events.[comment]. Lancet. 2002;359(9313):1249-1. No original empirical evidence presented.
Bokemark L, Blomstrand C, Fagerberg B. [Considerable differences in the management of stroke. A study of structured vs. conventional care (see comments)] TO:Stora skillnader i slaganfallsvarden. Studie av strukturerad vard kontra konventionell. Unable to obtain by final date for inclusion.
Bonnono C, Criddle LM. Acute ischemic stroke Emergi-path. J Emerg Nurs. 2000;26(4):340-342. No original empirical evidence presented. [pmid: 10940843].
Bonnono C, Criddle LM, Lutsep H, et al. Emergi-paths and stroke teams: an emergency department approach to acute ischemic stroke. J Neurosci Nurs. 2000;32(6):298-305. No original empirical evidence presented. [pmid: 11155343].
Booth B. The knowledge nurses need to educate patients about stroke. Nurs Times. 1994;90(15):32-34. No original empirical evidence presented.
Borhani NO. Clinical trials on the efficacy of pharmacologic intervention reducing mortality from cardiovascular diseases. Cardiology. 1985;72(56):366-375. No human participants. [pmid: 2866843].
Bousser MG. Cerebral venous thrombosis: nothing, heparin, or local thrombolysis?[see comment][comment]. Stroke. 1999;30(3):481-483. No original empirical evidence presented. [pmid: 10066839].
Bowler JV. Vascular cognitive impairment. Stroke. 2004;35(2):386-388. No original empirical evidence presented. [pmid: 14757888].
Boysen G, Engell HC, Henriksen H. The effect of induced hypertension on internal carotid artery pressure and regional cerebral blood flow during temporary carotid clamping for endarterectomy. Neurology. 1972;22(11):1133-1144. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 4673557].
Bozik M. He who pays the piper calls the tune: The role of the industry sponsor in acute stroke trials. Eur Neurol. 2003;49(2):128-130. No human participants. [pmid: 12584425].
Bozzao A, Floris R, Fasoli F, et al. Cerebrospinal fluid changes after intravenous injection of gadolinium chelate: Assessment by FLAIR MR imaging. Eur Radiol. 2003;13(3):592-597. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12594563].
Bozzao A, Floris R, Villani A, et al. [An evaluation of the carotid bifurcation and of the intracranial circle by angio-spiral computed tomography]. [Italian]. Radiol Med (Torino). 1998;95(6):577-582. Non-English publication. [pmid: 9717538].
Bradley RN. Educating the public about stroke: Role in improving outcomes. Disease Management & Health Outcomes. 2003;11(5):321-325. No original empirical evidence presented.
Brainin M, Olsen TS, Chamorro A, et al. Organization of stroke care: education, referral, emergency management and imaging, stroke units and rehabilitation. European Stroke Initiative. Cerebrovasc Dis. 2004;17 Suppl:21-14. No human participants. [pmid: 14530634].
Braithwaite V, McGown A. Caregivers" emotional well-being and their capacity to learn about stroke. J Adv Nurs. 1993;18(2):195-202. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8436710].
Bratina P, Greenberg L, Pasteur W, et al. Current emergency department management of stroke in Houston, Texas. Stroke. 1995;26(3):409-414. No intervention of interest studied. [pmid: 7886715].
Brauer DJ, Schmidt BJ, Pearson V. A framework for care during the stroke experience. Rehabil Nurs. 2001;26(3):88-93. No original empirical evidence presented. [pmid: 12035694].
Braus DF, Strobel J, Myers A, et al. [Stereotactic evacuation and early rehabilitation in space-occupying cerebral hemorrhage]. [German]. Wien Med Wochenschr. 1991;141(7):136-140. Non-English publication. [pmid: 2058161].
Bravata DM, Kim N, Concato J, et al. yperglycaemia in patients with acute ischaemic stroke: How often do we screen for undiagnosed diabetes?. Qjm: Monthly Journal of the Association of Physicians. 2003;96(7):491-497. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12881591].
Bravata DM, Kim N, Concato J, et al. Thrombolysis for acute stroke in routine clinical practice.[see comment]. Arch Intern Med. 2002;162(17):1994-2001. No intervention of interest studied. [pmid: 12230423].
Brett B, Peak EJ, Nair A, et al. Do not resuscitate decisions. More consumer education and involvement are needed.[comment]. BMJ. 2001;322(7278):103-104. No original empirical evidence presented.
Brice JH, Griswell JK, Delbridge TR, et al. Stroke: from recognition by the public to management by emergency medical services. [Review] [32 refs]. Prehosp Emerg Care. 2002;6(1):99-106. No original empirical evidence presented. [pmid: 11789659].
Brockington CD, Lyden PD. Criteria for selection of older patients for thrombolytic therapy. [Review] [38 refs]. Clin Geriatr Med. 1999;15(4):721-739. No original empirical evidence presented. [pmid: 10499932].
Broderick JP. William M. Feinberg Lecture: stroke therapy in the year 2025: burden, breakthroughs, and barriers to progress. Stroke. 2004;35(1):205-211. No original empirical evidence presented. [pmid: 14671248].
Broderick JP. Recanalization therapies for acute ischemic stroke. [Review] [59 refs]. Semin Neurol. 1998;18(4):471-484. No original empirical evidence presented. [pmid: 9932618].
Broderick JP. Practical considerations in the early treatment of ischemic stroke. [Review] [17 refs]. Am Fam Physician. 1998;57(1):73-80. No original empirical evidence presented. [pmid: 9447215].
Broderick JP, Hacke W. Treatment of acute ischemic stroke: Part II: neuroprotection and medical management. [Review] [45 refs]. Circulation. 2002;106(13):1736-1740. No original empirical evidence presented. [pmid: 12270871].
Broderick JP, Hacke W. Treatment of acute ischemic stroke: Part I: recanalization strategies. [Review] [63 refs]. Circulation. 2002;106(12):1563-1569. No original empirical evidence presented. [pmid: 12234965].
Broderick JP, Lu M, Kothari R, et al. Finding the most powerful measures of the effectiveness of tissue plasminogen activator in the NINDS tPA stroke trial. Stroke. 2000;31(10):2335-2341. No intervention of interest studied. [pmid: 11022060].
Brott T. Thrombolysis for stroke. Arch Neurol. 1996;53(12):1305-1306. No original empirical evidence presented. [pmid: 8970461].
Brott T. Thrombolytic therapy for stroke. [Review] [172 refs]. Cerebrovascular & Brain Metabolism Reviews. 1991;3(2):91-113. No original empirical evidence presented. [pmid: 1854597].
Brott T, Broderick J, Kothari R. Thrombolytic therapy for stroke. [Review] [50 refs]. Curr Opin Neurol. 1994;7(1):25-35. No original empirical evidence presented. [pmid: 8173673].
Brott T, Haley EC, Levy DE, et al. The investigational use of tPA for stroke. Ann Emerg Med. 1988;17(11):1202-1205. No original empirical evidence presented. [pmid: 3142318].
Brott T, Lu M, Kothari R, et al. Hypertension and its treatment in the NINDS rt-PA stroke trial. Stroke. 1998;29(8):1504-1509. No intervention of interest studied. [pmid: 9707184].
Brown DL. Deaths associated with platelet glycoprotein IIb/IIIa inhibitor treatment. Heart. 2003;89(5):535-537. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12695459]. [pmcid: 1767648].
Brown DL, Haley EC. Post-emergency department management of stroke. Emerg Med Clin North Am. 2002;20(3):687-702. No original empirical evidence presented. [pmid: 12379968].
Brown MM. Brain attack: a new approach to stroke. [Review] [20 refs]. Clin Med (Northfield Il). 2002;2(1):60-65. No original empirical evidence presented.
Brown MM, Humphrey PR. Carotid endarterectomy: recommendations for management of transient ischaemic attack and ischaemic stroke. Association of British Neurologists.[see comment]. BMJ. 1992;305(6861):1071-1074. No human participants. [pmid: 1467689]. [pmcid: 1883621].
Brozman M, Gobo T, Raisova M, et al. Intravenous rt-PA thrombolytic therapy in fifty-six ischemic stroke patients - A prospective follow-up study. Acta Clinica Croatica. 2003;42(4):289-297. No intervention of interest studied.
Brucker AB, Vollert-Rogenhofer H, Wagner M, et al. Heparin treatment in acute cerebral sinus venous thrombosis: a retrospective clinical and MR analysis of 42 cases. Cerebrovasc Dis. 1998;8(6):331-337. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9774750].
Bruno A. Tissue-plasminogen activator for acute ischaemic stroke.[comment]. Lancet. 1997;349(9050):503-504. No original empirical evidence presented.
Bruno A, Biller J, Adams HPJ, et al. Acute blood glucose level and outcome from ischemic stroke. Trial of ORG 10172 in Acute Stroke Treatment (TOAST) Investigators. Neurology. 1999;52(2):280-284. No intervention of interest studied. [pmid: 9932944].
Bruno A, Biller J, Adams HP, et al. Acute blood glucose level and outcome from ischemic stroke. Neurology. 1999;52(2):80-284. No intervention of interest studied.
Bruno A, Levine SR, Frankel MR, et al. Admission glucose level and clinical outcomes in the NINDS rt-PA Stroke Trial. Neurology. 2002;59(5):669-674. No intervention of interest studied. [pmid: 12221155].
Bruno A, Saha C, Williams LS, et al. IV insulin during acute cerebral infarction in diabetic patients. Neurology. 4–27. 2004;62(8):1441-1442. Unable to obtain by final date for inclusion. [pmid: 15111697].
Brunyee P. Stroke services. The right register. Health Serv J. 1999;109(5668):31N. o human participants. [pmid: 10662314].
Bryan RN. Diffusion-weighted imaging: to treat or not to treat? That is the question.[comment]. Ajnr: American Journal of Neuroradiology. 1998;19(2):396-397. No human participants. [pmid: 9504505].
Bukachi F, Clague Waldenstrom A, Kazzam E, et al. Clinical outcome of coronary angioplasty in patients with ischaemic cardiomyopathy. Int J Cardiol. 2003;88(23):167-174. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12714195].
Burgin WS, Staub L, Chan W, et al. Acute stroke care in non-urban emergency departments. Neurology. 2001;57(11):2006-2012. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11739817].
Burkart DJ, Borsa JJ, Anthony JP, et al. Thrombolysis of acute peripheral arterial and venous occlusions with tenecteplase and eptifibatide: A pilot study. Journal of Vascular & Interventional Radiology. 2003;14(6):729-733. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12817039].
Butcher K, Parsons M, Baird T, et al. Perfusion thresholds in acute stroke thrombolysis. Stroke. 2003;34(9):2159-2164. No intervention of interest studied. [pmid: 12893953].
Butterworth RJ, Cluckie A, Jackson SH, et al. Pathophysiological assessment of nitric oxide (given as sodium nitroprusside) in acute ischaemic stroke. Cerebrovasc Dis. 1998;8(3):158-165. No intervention of interest studied. [pmid: 9619699].
Cabral NL, Moro C, Silva GR, et al. Study comparing the stroke unit outcome and conventional ward treatment: a randomized study in Joinville, Brazil. Arq Neuropsiquiatr. 2003;61(2A):188-193. No intervention of interest studied. [pmid: 12806495].
Cakmak S, Derex L, Berruyer M, et al. Cerebral venous thrombosis: clinical outcome and systematic screening of prothrombotic factors. Neurology. 2003;60(7):1175-1178. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12682328].
Calcium-channel therapy similar but not equivalent to diuretic and beta-blocker treatment in reducing cardiovascular disease. Hosp Formul 2003;38(6):345Unable to obtain by final date for inclusion.
Candelise L, Roncaglioni C, Aritzu E, et al. Thrombolytic therapy. From myocardial to cerebral infarction. The MAST-I Group. Multicentre Acute Stroke Trial. [Review] [134 refs]. Ital J Neurol Sci. 1996;17(1):5-21. No original empirical evidence presented. [pmid: 8742984].
Cao P, Zannetti S, Giordano G, et al. Cerebral tomographic findings in patients undergoing carotid endarterectomy for asymptomatic carotid stenosis: short-term and long-term implications. Eur J Vasc Surg. 1999;29(6):995-1005. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Caplan LR. Now is an exciting time to care for stroke patients. South Med J. 2003;96(4):329-330. No human participants. [pmid: 12916548].
Carrageta MO, Negrao L, de Padua F. Community-based stroke prevention: a Portuguese challenge.[see comment]. [Review] [21 refs]. Health Rep. 1994;6(1):189-195. No human participants. [pmid: 7919080].
Carroll C, Hobart J, Fox C, et al. Stroke in Devon: knowledge was good, but action was poor. Journal of Neurology, Neurosurgery & Psychiatry. 2004;75(4):567-571. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Carrozzella J, Jauch EC. Emergency stroke management: a new era. [Review] [27 refs]. Crit Care Nurs Clin North Am. 2002;37(1):35-57. No human participants.
Carson JL, Armas-Loughran B. Blood transfusion: Less is more?. Crit Care Med. 2003;31(9):2409-2410. No original empirical evidence presented. [pmid: 14501980].
Carter AB. Hypotensive therapy in stroke survivors. Lancet. 1970;1(7645):485-489. No intervention of interest studied. [pmid: 4190177].
Caso V, Hacke W. The very acute stroke treatment: fibrinolysis and after. [Review] [37 refs]. Clinical & Experimental Hypertension (New York). 2002;24(78):595-602. No original empirical evidence presented.
Castaldo JE, Nelson JJ, Reed JF, et al. The delay in reporting symptoms of carotid artery stenosis in an at-risk population. The Asymptomatic Carotid Atherosclerosis Study experience: a statement of concern regarding watchful waiting. Arch Neurol. 1997;54(10):1267-1271. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9341573].
Castellan L, Causin F, Danieli D, et al. Carotid stenting with filter protection. Correlation of ACT values with angiographic and histopathologic findings. AJNR Am J Neuroradiol. 2003;30(2):103-108. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Catford J. The health of the nation. Coronary heart disease and stroke. Br J Hosp Med. 1993;49(1):11-14. No original empirical evidence presented. [pmid: 8431719].
Cavallini A, Micieli G, Marcheselli S, et al. Role of monitoring in management of acute ischemic stroke patients. Stroke. 2003;34(11):2599-2603. No intervention of interest studied. [pmid: 14563969].
Centers for, Disease Control, Prevention (CDC). Awareness of stroke warning signs--17 states and the U.S. Virgin Islands, 2001. MMWR Morb Mortal Wkly Rep 5-7-2004;Morbidity & Mortality Weekly Report. 53( 17):359–362. Unable to obtain by final date for inclusion.
Chalela JA, Kang DW, Warach S. Multiple cerebral microbleeds: MRI marker of a diffuse hemorrhage-prone state. J Neuroimaging. 2004;14(1):54-57. No human participants. [pmid: 14748209].
Chalmers J. Volhard Lecture. Brain, blood pressure and stroke. [Review] [73 refs]. J Hypertens. 1998;16(12 Pt 2):1849-1858. No original empirical evidence presented. [pmid: 9886869].
Chamorro A, Obach V. Anticoagulant therapy. Cerebrovasc Dis. 2003;15(SUPPL. 2):49-55. No original empirical evidence presented.
Chan LL, Khoo JB, Thng CH, et al. Diffusion weighted MR imaging in acute stroke: the SGH experience. Singapore Med J. 2002;43(3):118-123. No intervention of interest studied. [pmid: 12005336].
Chang GY, Lackey NR, Gates MF. An ischemic stroke during intravenous recombinant tissue plasminogen activator infusion for evolving myocardial infarction. Eur J Neurol. 2001;8(3):267-268. No intervention of interest studied. [pmid: 11328336].
Chappel D, Bailey J, Stacy R, et al. Implementation and evaluation of local-level priority setting for stroke. Public Health. 2001;115(1):21-29. No human participants. [pmid: 11402348].
Chasis H. Appraisal of antihypertensive drug therapy. Circulation. 1974;50(1):4-8. No original empirical evidence presented. [pmid: 4600521].
Chaturvedi S. Should the multicenter carotid endarterectomy trials be repeated?. Arch Neurol. 2003;60(5):774-775. No original empirical evidence presented. [pmid: 12756145].
Cheanvechai V, Harthun NL, Graham LM, et al. Incidence of peripheral vascular disease in women: Is it different from that in men?. Journal of Thoracic & Cardiovascular Surgery. 2004;127(2):314-317. No original empirical evidence presented. [pmid: 14762335].
Check mental status or risk missing problems. Hosp Case Manag 2003;11(5):72–74. No original empirical evidence presented.
Cheung RT. Hong Kong patients" knowledge of stroke does not influence time-to-hospital presentation. J Clin Neurosci. 2001;8(4):311-314. No intervention of interest studied. [pmid: 11437568].
Chilton R. Web alert. Curr Atheroscler Rep. 2001;3(4):271-272. No human participants. [pmid: 11432384].
Ciccone A, Sterzi R, Crespi V, et al. Thrombolysis for acute ischemic stroke: the patient"s point of view. Cerebrovasc Dis. 2001;12(4):335-340. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11721105].
Circulation Respiratory, health. CIHR Institute. Unable to obtain by final date for inclusion.
Claesson L, Gosman-Hedstrom G, Fagerberg B, et al. Hospital re-admissions in relation to acute stroke unit care versus conventional care in elderly patients the first year after stroke: the Goteborg 70+ Stroke study. Age & Ageing. 2003;32(1):109-113. No intervention of interest studied. [pmid: 12540357].
Clark D, Forbes C. Patient empowerment stroke--a strategy for Scotland. Scott Med J. 2001;46(3):71-72. No human participants. [pmid: 11501323].
Clark MS, Rubenach S, Winsor A. A randomized controlled trial of an education and counselling intervention for families after stroke. Clin Rehabil. 2003;17(7):703-712. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14606735].
Coca A. Actual blood pressure control: are we doing things right? [Review] [43 refs]. Journal of Hypertension - Supplement. 1998;16(1):S45-S51. No human participants.
Coe M. Understanding the CVA patient. The damage is much more than physical. Nurs Care. 1974;7(5):16-18. No human participants. [pmid: 4495243].
Cohen DL, Grant FM. The effect of randomisation without CT on treatment in one large international stroke trial centre. Age & Ageing. 1997;26(suppl 1):42N. o intervention of interest studied.
Collaborative systematic review of the randomised trials of organised inpatient (stroke unit) care after stroke. Stroke Unit Trialists" Collaboration.[see comment]. BMJ 1997;314(7088):1151–1159. No original empirical evidence presented.
Collice MD. Surgery for intracerebral hemorrhage. Neurol Sci. 2004;;25 Suppl:1S10-S11. No original empirical evidence presented.
Collins DR, McCormack PM, O"Neill D. General perception of stroke. Poor knowledge of stroke can be improved by simple measures.[comment]. BMJ. 2002;325(7360):392N. o original empirical evidence presented.
Connors JJ. Pharmacologic Agents in Stroke Prevention, Acute Stroke Therapy, and Interventional Procedures. Journal of Vascular & Interventional Radiology. 2004;15(1 II):S87-S101. No original empirical evidence presented. [pmid: 15101518].
Cornu C, Amsallem E, Serradj-Jaillard AA. Thrombolytic therapy for acute ischemic stroke. [Review] [45 refs]. American Journal of Cardiovascular Drugs. 2001;1(4):281-292. No original empirical evidence presented. [pmid: 14728027].
Coull BM, Brockschmidt JK, Howard G, et al. Community hospital-based stroke programs in North Carolina, Oregon, and New York. IV. Stroke diagnosis and its relation to demographics, risk factors, and clinical status after stroke. Stroke. 1990;21(6):867-873. No intervention of interest studied. [pmid: 2349589].
Counsell C. Meta-analysis. Practical Neurology. 2003;3(5):300-305. No human participants.
Coutts S, Frayne R, Sevick R, et al. Microbleeding on MRI as a marker for hemorrhage after stroke thrombolysis.[comment]. Stroke. 2002;33(6):1457-1458. No original empirical evidence presented. [pmid: 12052973].
Coutts SB, Simon JE, Tomanek AI, et al. Reliability of assessing percentage of diffusion-perfusion mismatch.[see comment]. Stroke. 2003;34(7):1681-1683. No intervention of interest studied. [pmid: 12805485].
Crawley F, Clifton A, Buckenham T, et al. Comparison of hemodynamic cerebral ischemia and microembolic signals detected during carotid endarterectomy and carotid angioplasty. Stroke. 1997;28(12):2460-2464. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9412633].
Crisostomo RA, Garcia MM, Tong DC. Detection of diffusion-weighted MRI abnormalities in patients with transient ischemic attack: correlation with clinical characteristics. Stroke. 2003;34(4):932-937. No intervention of interest studied. [pmid: 12637695].
CRITICAL PATH NETWORK. Study says EDs don't meet time targets for stroke: patients not given diagnostic tests in recommended time frames. Hosp Case Manag 2003;11(8):119–122. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Crocco T, Gullett T, Davis SM, et al. Feasibility of neuroprotective agent administration by prehospital personnel in an urban setting. Stroke. 2003;34(8):1918-1922. No intervention of interest studied. [pmid: 12843348].
Crocco TJ, Kothari RU, Sayre MR, et al. A nationwide prehospital stroke survey. Prehosp Emerg Care. 1999;3(3):201-206. No intervention of interest studied. [pmid: 10424856].
Crocco TJ, Moreno R, Jauch EC, et al. Teaching ACLS stroke objectives to prehospital providers: a case-based approach. Prehosp Emerg Care. 2003;7(2):229-234. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12710784].
CVA (cerebrovascular accident) pathway cuts across seven hospital units. Hosp Case Manag 1998;6(2):33–34. No original empirical evidence presented.
D"Afflitti JG, Weitz GW. Rehabilitating the stroke patient through patient-family groups. Int J Group Psychother. 1974;24(3):323-332. No human participants. [pmid: 4415526].
Daffertshofer M, Hennerici M. Ultrasound in the treatment of ischaemic stroke. [Review] [60 refs]. Lancet. 2003;2(5):283-290. No original empirical evidence presented.
Daley S, Braimah J, Sailor S, et al. Education to improve stroke awareness and emergent response. The NINDS rt-PA Stroke Study Group. [Review] [12 refs]. J Neurosci Nurs. 1997;29(6):393-396. No original empirical evidence presented. [pmid: 9479661].
Dancer S. Redesigning care for the nonhemorrhagic stroke patient. J Neurosci Nurs. 1996;28(3):183-189. No original empirical evidence presented. [pmid: 8818984].
Daugherty SA, Berman R, Entwisle G, et al. Cerebrovascular events in the Hypertension Detection and Follow-up Program. Prog Cardiovasc Dis. 1986;29(3 Suppl 1):63-72. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 3538180].
Davalos A. Fibrinolytic therapy for acute stroke: the Spanish experience. ECASS-II Spanish Group. Cerebrovasc Dis. 1999;9(Suppl 3):9-15. No intervention of interest studied. [pmid: 10436320].
Davalos A, Cendra E, Gonzalez B et al. Double blind randomized clinical trial of nicardipine vs placebo in acute ischemic stroke: clinical, radiological and biochemical evaluation of the ischemic area. Preliminary results. Neurol India 1989;37(Suppl):Unable to obtain by final date for inclusion.
Davalos A, Fernandez-Real JM, Ricart W, et al. Iron-related damage in acute ischemic stroke.[erratum appears in Stroke 1994 Nov;25(11):2300]. Stroke. 1994;25(8):1543-1546. No intervention of interest studied. [pmid: 8042204].
Davalos A, Toni D, Iweins F, et al. Neurological deterioration in acute ischemic stroke: potential predictors and associated factors in the European cooperative acute stroke study (ECASS) I. Stroke. 1999;30(12):2631-2636. No intervention of interest studied. [pmid: 10582989].
Davalos A, De CE, Genis D, et al. Double blind clinical trial of nicardipine versus placebo in the treatment of the acute phase of stroke. Neurology. 1992;7(6):157U. nable to obtain by final date for inclusion.
Davenport J, Hanson SK, Altafullah IM, et al. tPA: a rural network experience.[comment]. Stroke. 2000;31(6):1457-1458. No original empirical evidence presented. [pmid: 10835477].
Davenport R, Dennis M. Neurological emergencies: acute stroke.[see comment]. [Review] [99 refs]. Journal of Neurology, Neurosurgery & Psychiatry. 2000;68(3):277-288. No original empirical evidence presented.
Davenport RJ. Treating hypertension after stroke.[comment]. BMJ. 1994;309(6955):669N. o original empirical evidence presented. [pmid: 8087009].
Davis PH, Clarke WR, Bendixen BH, et al. Silent cerebral infarction in patients enrolled in the TOAST Study. Neurology. 1996;46(4):942-948. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8780069].
Davis S, Tress B, Barber PA, et al. Echoplanar magnetic resonance imaging in acute stroke. [Review] [45 refs]. J Clin Neurosci. 2000;7(1):3-8. No original empirical evidence presented. [pmid: 10847641].
Davis SM, Donnan GA. Thrombolysis for stroke: defining the time window.[comment]. Stroke. 2002;33(2):495-496. No original empirical evidence presented. [pmid: 12532952].
Davis SM, Donnan GA. Stroke unit design: high tech versus low tech.[comment]. Stroke. 2004;35(4):1021N. o original empirical evidence presented. [pmid: 15001794].
Davis TME, Colagiuri S. The continuing legacy of the United Kingdom prospective diabetes study. Med J Aust. 2004;180(3):104-105. No original empirical evidence presented. [pmid: 14748669].
Dawson K, Gordon BJ, Guend A. Progress in reducing stroke mortality in Wisconsin, 1984-1998. WMJ. 1998;101(3):32-36. Study did not involve relevant population [defined as adult (>16) with acute stroke].
de Bray JM, Missoum A, Dubas F, et al. Detection of vertebrobasilar intracranial stenoses: transcranial Doppler sonography versus angiography. J Ultrasound Med. 1997;16(3):213-218. No intervention of interest studied. [pmid: 9166821].
De Deyn PP, Reuck JD, Deberdt W, et al. Treatment of acute ischemic stroke with piracetam. Members of the Piracetam in Acute Stroke Study (PASS) Group. Stroke. 1997;28(12):2347-2352. No intervention of interest studied. [pmid: 9412612].
De Keyser J. Thrombolysis and hemorrhagic transformation.[comment]. Stroke. 2002;33(3):724N. o original empirical evidence presented. [pmid: 12532967].
De Keyser J, Sulter G, Langedijk M, et al. Management of acute ischaemic stroke. [Review] [25 refs]. Acta Clin Belg. 1999;54(5):302-305. No original empirical evidence presented. [pmid: 10555390].
De Keyser J, Van dV V, Schellens RL, et al. Safety and pharmacokinetics of the neuroprotective drug lubeluzole in patients with ischemic stroke. Clin Ther. 1997;19(6):1340-1351. No intervention of interest studied. [pmid: 9444444].
Debrun GM, Aletich VA, Kehrli P, et al. Aneurysm geometry: an important criterion in selecting patients for Guglielmi detachable coiling. [Review] [139 refs]. Neurol Med Chir (Tokyo). 1998;38 Supp:l1-20. No original empirical evidence presented.
del Zoppo GJ. Thrombolysis: from the experimental findings to the clinical practice. [Review] [78 refs]. Cerebrovasc Dis. 2004;17 Suppl:1144-152. No original empirical evidence presented.
del Zoppo GJ. Thrombolysis in acute stroke. [Review] [105 refs]. Actas Luso Esp Neurol Psiquiatr Cienc Afines. 1995;10 Suppl:237-47. No original empirical evidence presented.
del Zoppo GJ. An open, multicenter trial of recombinant tissue plasminogen activator in acute stroke. A progress report. The rt-PA Acute Stroke Study Group. Stroke. 1990;21(12 Suppl):IV174-IV175. No intervention of interest studied. [pmid: 2124386].
del Zoppo GJ, Poeck K, Pessin MS, et al. Recombinant tissue plasminogen activator in acute thrombotic and embolic stroke. Ann Neurol. 1992;32(1):78-86. No intervention of interest studied. [pmid: 1642475].
DeLemos CD, Atkinson RP, Croopnick SL, et al. How effective are “community” stroke screening programs at improving stroke knowledge and prevention practices? Results of a 3-month follow-up study. Stroke. 2003;34(12):e247-e249. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14631093].
Demaerschalk BM. Evidence-Based Clinical Practice Education in Cerebrovascular Disease. Stroke. 2004;35(2):392-396. No original empirical evidence presented. [pmid: 14757890].
Demchuk AM, Burgin WS, Christou I, et al. Thrombolysis in brain ischemia (TIBI) transcranial Doppler flow grades predict clinical severity, early recovery, and mortality in patients treated with intravenous tissue plasminogen activator.[see comment]. Stroke. 2001;32(1):89-93. No intervention of interest studied. [pmid: 11136920].
Denby F, Harvey RL. An educational intervention for stroke rehabilitation patients and their families: Healthy living after stroke. Top Stroke Rehabil. 2003;9(4):34-45. No original empirical evidence presented. [pmid: 14523698].
Dennis M. Stroke services: the good, the bad and the. J R Coll Physicians Lond. 2000;34(1):92-96. No human participants. [pmid: 10717888].
Dennis M, Langhorne P. So stroke units save lives: where do we go from here?[see comment]. [Review] [25 refs]. BMJ. 1994;309(6964):1273-1277. No original empirical evidence presented. [pmid: 7888851]. [pmcid: 2541829].
Dennis M, O"Rourke S, Slattery J, et al. Evaluation of a stroke family care worker: results of a randomised controlled trial.[see comment]. BMJ. 1997;314(7087):1071-1076. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9133884]. [pmcid: 2126479].
Dennis MS. Stroke unit versus neurology ward--a short commentary. J Neurol. 2003;250(11):1370-1371. No human participants. [pmid: 14648155].
Derex L, Nighoghossian N, Hermier M, et al. Early detection of cerebral arterial occlusion on magnetic resonance angiography: predictive value of the baseline NIHSS score and impact on neurological outcome. Cerebrovasc Dis. 2002;13(4):225-229. No intervention of interest studied. [pmid: 12011545].
Derex L, Tomsick TA, Brott TG, et al. Outcome of stroke patients without angiographically revealed arterial occlusion within four hours of symptom onset. Ajnr: American Journal of Neuroradiology. 2001;22(4):685-690. No intervention of interest studied. [pmid: 11290479].
Derex LN. Thrombolysis for ischemic stroke in patients with old microbleeds on pretreatment MRI. Cerebrovasc Dis. 2004;17(23):238-241. No intervention of interest studied. [pmid: 14718753].
Dezsi L. Fibrinolytic actions of ACE inhibitors: a significant plus beyond antihypertensive therapeutic effects.[comment]. Cardiovasc Res. 2000;47(4):642-644. No original empirical evidence presented. [pmid: 10974213].
Diuretics prevail as initial therapy in largest hypertension trial ever. Hosp Formul 2003;38(1):17+23No original empirical evidence presented.
Di Carlo A, Lamassa M, Baldereschi M, et al. Sex differences in the clinical presentation, resource use, and 3-month outcome of acute stroke in Europe: data from a multicenter multinational hospital-based registry. Stroke. 2003;34(5):1114-1119. No intervention of interest studied. [pmid: 12690218].
Di Napoli M, Papa F. Angiotensin-converting enzyme inhibitor use is associated with reduced plasma concentration of C-reactive protein in patients with first-ever ischemic stroke. Stroke. 2003;34(12):2922-2929. No intervention of interest studied. [pmid: 14605324].
Diamantopoulos EJ, Andreadis EA, Vassilopoulos CV, et al. Adherence to an intensive antihypertensive follow-up programme. J Hum Hypertens. 2003;17(6):437-439. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12764408].
Diaz FG, Ausman JI, Mehta B, et al. Acute cerebral revascularization. J Neurosurg. 1985;63(2):200-209. No intervention of interest studied. [pmid: 4020443].
Dibler CB. Management of the stroke patient. 1994 Ishmael Essay Award. [Review] [15 refs]. J Okla Dent Assoc. 1994;85(1):22-24. No original empirical evidence presented. [pmid: 9526220].
Dion JE. Management of Ischemic Stroke in the Next Decade: Stroke Centers of Excellence. Journal of Vascular & Interventional Radiology. 2004;15(1 II):S133-S141. No original empirical evidence presented. [pmid: 15101522].
Dippel DW, Du Ry van Beest, et al. The validity and reliability of signs of early infarction on CT in acute ischaemic stroke. Neuroradiology. 2000;42(9):629-633. No intervention of interest studied. [pmid: 11071432].
DM approach to post-stroke care shows early promise. Senior Care Management 2003;6(3):33–37. No original empirical evidence presented.
Doggrell SA. Alteplase: descendancy in myocardial infarction, ascendancy in stroke. [Review] [91 refs]. Expert Opin Investig Drugs. 2001;10(11):2013-2029. No original empirical evidence presented.
Doggrell SA. SCOPE (Study, of Cognition, et al. Candesartan for the prevention and treatment of stroke - results of the SCOPE and ACCESS trials. [Review] [10 refs]. Expert Opin Pharmacother. 2004;5(3):687-690. Unable to obtain by final date for inclusion. [pmid: 15013936].
Dollet JM, Champigneulle B, Evangelista M, et al. Sclerotherapy versus propranolol after first variceal haemorrhage in alcoholic cirrhosis. Lancet. 1985;2(8446):97N. o original empirical evidence presented.
Donnan GA. Stroke: prediction, prevention, and outcome. [Review] [5 refs]. Lancet. 2004;3(1):9N. o original empirical evidence presented.
Donnan GA. Therapy in cerebrovascular disease: current status and future directions. [Review] [144 refs]. Med J Aust. 1991;155(8):563-571. No original empirical evidence presented. [pmid: 1943940].
Donnan GA, Davis SM. Controversy: the essence of medical debate. Stroke. 2003;34(2):372-373. No human participants. [pmid: 12574541].
Donnelly M, Power M, Russell M, et al. Randomized controlled trial of an early discharge rehabilitation service: the Belfast Community Stroke Trial. Stroke. 2004;35(1):127-133. No intervention of interest studied. [pmid: 14671238].
Dorman P, Sandercock P. TPA within 3 hours of acute ischaemic stroke?[see comment]. Lancet. 1996;348(9042):1600-1601. No original empirical evidence presented.
Dorman T, Thompson DA, Breslow MJ, et al. Nicardipine versus nitroprusside for breakthrough hypertension following carotid endarterectomy. J Clin Anesth. 2001;13(1):16-19. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11259889].
Drake WEJ, Dietrich BJ, Hunt G, et al. Community action in stroke management. Am J Public Health. 1972;62(4):522-529. No original empirical evidence presented. [pmid: 5020618]. [pmcid: 1530108].
Drake WE, Hamilton MJ, Carlsson M, et al. Acute stroke management and patient outcome: the value of Neurovascular Care Units (NCU). Stroke. 1973;4(6):933-945. No intervention of interest studied. [pmid: 4203027].
Dressman LA, Hunter J. Stroke awareness and knowledge retention in children: The Brain Child Project. Stroke. 2002;33(2):623-625. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11823680].
Drummond AE. The effects of a stroke unit on activities of daily living. Clin Rehabil. 1996;10(1):12-22. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Ducharme J, Currie T, Ovens H et al. Acute stroke management.[comment]. Can Fam Physician 2001;472458No human participants.
Dulli DA, Dempsey RJ, Levine RL. Attitudes and approaches to acute ischemic stroke in Wisconsin hospitals. WMJ. 2001;100(5):44-49. No intervention of interest studied.
Dumo P, Fagan SC, Carhuapoma J. Thrombolysis in acute ischemic stroke. [Review] [9 refs]. Am J Health Syst Pharm. 1997;54(19):2213-2217. No original empirical evidence presented. [pmid: 9331444].
Dundas R, Morgan M, Redfern J, et al. Ethnic differences in behavioural risk factors for stroke: implications for health promotion. Ethn Health. 2001;6(2):95-103. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11480965].
Dunn SA, Nelson CD, Peterson PM. An education program about stroke. Rehabil Nurs. 1984;9(5):27-29. No original empirical evidence presented.
Dustan HP, Roccella EJ, Garrison HH. Controlling hypertension. A research success story. [Review] [67 refs]. Arch Intern Med. 1996;156(17):1926-1935. No original empirical evidence presented. [pmid: 8823146].
Eames S, McKenna K, Worrall L, et al. The suitability of written education materials for stroke survivors and their carers. Top Stroke Rehabil. 2003;10(3):70-83. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14681821].
Easton KL, Zemen DM, Kwiatkowski S. Developing and implementing a stroke education series for patients and families. Rehabil Nurs. 1994;19(6):348-351. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7855402].
Eaves YD. “What happened to me” rural African American elders" experiences of stroke. J Neurosci Nurs. 2000;32(1):37-48. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10955273].
Ebersole P. The horse & buggy syndrome or was good enough for grandpa good enough for me?. Geriatr Nurs (Minneap). 1999;20(2):62-63. No original empirical evidence presented.
Ebrahim S, Smith GD. Exporting failure? Coronary heart disease and stroke in developing countries. Int J Epidemiol. 2001;30(2):201-205. No human participants. [pmid: 11369713].
Eckert B, Koch C, Thomalla G, et al. Acute basilar artery occlusion treated with combined intravenous Abciximab and intra-arterial tissue plasminogen activator: report of 3 cases. Stroke. 2002;33(5):1424-1427. No intervention of interest studied. [pmid: 11988626].
Eckstein HH, Schumacher H, Dorfler A, et al. Carotid endarterectomy and intracranial thrombolysis: simultaneous and staged procedures in ischemic stroke. J Vasc. urg. 1999;29(3):459-471. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Edmans J A. Comparison of stroke unit and nonstroke unit. Unable to obtain by final date for inclusion.
Edwards G. Good practice for keeping stroke patients and carers informed. Pap Natl Conf Prof Nurses Physicians. 2003;18(9):529-532. No original empirical evidence presented.
Effect of angiotensin-converting enzyme inhibition compared with conventional therapy on cardiovascular morbidity and mortality in hypertension: the Captopril Prevention Project (CAPP) randomized trial. The Captopril Prevention Project (CAPP) Study Group. Curr Hypertens Rep 1999;1(6):466–467. No original empirical evidence presented.
Effect of antihypertensive treatment on stroke recurrence. Hypertension-Stroke Cooperative Study Group. JAMA 1974;229(4):409–418. Study did not involve relevant population [defined as adult (>16) with acute stroke].
El Mitwalli A, Saad M, Christou I, et al. Clinical and sonographic patterns of tandem internal carotid artery/middle cerebral artery occlusion in tissue plasminogen activator-treated patients. Stroke. 2002;33(1):99-102. No intervention of interest studied. [pmid: 11779896].
Eliasziw M, Spence JD, Barnett HJ. Carotid endarterectomy does not affect long-term blood pressure: observations from the NASCET. North American Symptomatic Carotid Endarterectomy Trial. Cerebrovasc Dis. 1998;8(1):20-24. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9645977].
Elkind MS. Stroke in the elderly. [Review] [50 refs]. Mt Sinai J Med. 2003;70(1):27-37. No original empirical evidence presented. [pmid: 12516007].
Elliott BM, Collins GJ J, Youkey Donohue, et al. Intraoperative local anesthetic injection of the carotid sinus nerve. A prospective, randomized study. Am J Surg. 1986;152(6):695-699. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 3789297].
Ellis SJ. Tissue-plasminogen activator for acute ischaemic stroke.[comment]. Lancet. 1997;349(9050):504. No original empirical evidence presented. [pmid: 9040600].
Enevoldsen EM, Norby J, Rohr N, et al. Outcome for patients with carotid stenosis undergoing carotid endarterectomy, the cerebral condition followed by extra/intracranial ultrasound examinations. Acta Neurol Scand. 1999;99(6):340-348. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10577267].
Engelstein E, Margulies J, Jeret JS. Lack of t-PA use for acute ischemic stroke in a community hospital: high incidence of exclusion criteria.[see comment]. Am J Emerg Med. 2000;18(3):257-260. No intervention of interest studied. [pmid: 10830678].
Englert J, Davis KM, Koch KE. Using clinical practice analysis to improve care. Jt Comm J Qual Improv. 2001;27(6):291-301. No original empirical evidence presented. [pmid: 11402776].
Eo E-K, Ryu J-Y, Cheon Y-J, et al. Effects of Training Paramedics on Prehospital Stroke Management. Neurology Psychiatry & Brain Research. 2003;10(4):165-172. Unable to obtain by final date for inclusion.
Eriksson S, Olofsson B-O, Wester P-O. Test study. A Swedish multicentre trial of long term atenolol treatment in stroke patients - an intermediate report. J Neurol 1990;237134Study did not involve relevant population [defined as adult (>16) with acute stroke].
Evans DM. Stroke education: the development of a documentation system and resource guide. Axone. 1998;20(1):19-22. No original empirical evidence presented. [pmid: 9849139].
Evans MF. Do intensive blood pressure lowering and low-dose ASA help our hypertensive patients? Can Fam Physician 1998;442655–2657. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Evans SN, Ahmed U, Fotherby MD. Effect of antihypertensive therapy on blood pressure after stroke. Cerebrovasc Dis 1998;8(Suppl 4):No intervention of interest studied.
Exall K, Johnston H. Caring for carers coping with stroke. Nurs Times. 1999;95(11):50-51. No original empirical evidence presented.
Ezura M, Takahashi A, Shimizu H, et al. Diffusion-weighted MRI and selection of patients for fibrinolytic therapy of acute cerebral ischaemia. Neuroradiology. 2000;42(5):379-383. No intervention of interest studied. [pmid: 10872162].
Fagan SC, Morgenstern LB, Petitta A, et al. Cost-effectiveness of tissue plasminogen activator for acute ischemic stroke. NINDS rt-PA Stroke Study Group.[see comment]. Neurology. 1998;50(4):883-890. No intervention of interest studied. [pmid: 9566367].
Fagan SC, Zarowitz BJ, Robert S. "Brain attack": an indication for thrombolysis? [Review] [70 refs]. Ann Pharmacother. 1992;26(1):73-80. No original empirical evidence presented. [pmid: 1606347].
Falconer JA, Roth EJ, Sutin JA, et al. The critical path method in stroke rehabilitation: lessons from an experiment in cost containment and outcome improvement.[see comment]. QRB Qual Rev Bull. 1993;19(1):8-16. No original empirical evidence presented. [pmid: 8455920].
Farquhar JW, Fortmann SP, Maccoby N, et al. The Stanford Five-City Project: design and methods. Am J Epidemiol. 1985;122(2):323-334. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 4014215].
Fassbender K, Dempfle CE, Mielke O, et al. Changes in coagulation and fibrinolysis markers in acute ischemic stroke treated with recombinant tissue plasminogen activator. Stroke. 1999;30(10):2101-2104. No intervention of interest studied. [pmid: 10512913].
Favrole P, Guichard J-P, Crassard I, et al. Diffusion-Weighted Imaging of Intravascular Clots in Cerebral Venous Thrombosis. Stroke. 2004;35(1):99-103. No intervention of interest studied. [pmid: 14699171].
Feigenson JS, McDowell F. Stroke rehabilitation; Alternatives for health-care delivery. N Y State J Med. 1980;80(5):752-756. No human participants. [pmid: 6930550].
Felberg RA. Case study: Brain attack. Ochsner Journal. 2003;5(1):44-46. No original empirical evidence presented.
Felberg RA. From the editor"s desk. Ochsner Journal 2003;5(1):Unable to obtain by final date for inclusion.
Felberg RA, Naidech A. The five Ps of acute ischemic stroke treatment: Parenchyma, pipes, perfusion, penumbra, and prevention of complications. Ochsner Journal. 2003;5(1):5-11. No original empirical evidence presented.
Ferguson JJ. New treatments for acute ischemic stroke. Circulation. 1996;93(9):1604. No original empirical evidence presented. [pmid: 8653859].
Fessler AJ, Alberts MJ. Stroke treatment with tissue plasminogen activator in the setting of aortic dissection. Neurology. 2000;54(4):1010. No original empirical evidence presented. [pmid: 10691010].
Fiebach JB, Schellinger PD, Jansen O, et al. CT and diffusion-weighted MR imaging in randomized order: diffusion-weighted imaging results in higher accuracy and lower interrater variability in the diagnosis of hyperacute ischemic stroke.[see comment]. Stroke. 2002;33(9):2206-2210. No original empirical evidence presented. [pmid: 12215588].
Fiehler J, von Bezold M, Kucinski T, et al. Cerebral blood flow predicts lesion growth in acute stroke patients. Stroke. 2002;33(10):2421-2425. No intervention of interest studied. [pmid: 12364732].
Fieschi C, Argentino C, Lenzi GL, et al. Clinical and instrumental evaluation of patients with ischemic stroke within the first six hours. J Neurol Sci. 1989;91(3):311-321. No intervention of interest studied. [pmid: 2671268].
Fieschi C, Sette G, Toni D. Assessment of brain tissue viability under clinical circumstances. [Review] [62 refs]. Acta Neurochirurgica. Supplementum. 1999:7373-80. No original empirical evidence presented.
Fink JN, Caplan LR. Cerebrovascular cases. [Review] [67 refs]. Med Clin North Am. 2003;87(4):755-770. No intervention of interest studied. [pmid: 12834147].
Fiorelli M, Bastianello S, von Kummer R, et al. Hemorrhagic transformation within 36 hours of a cerebral infarct: relationships with early clinical deterioration and 3-month outcome in the European Cooperative Acute Stroke Study I (ECASS I) cohort.[see comment]. Stroke. 1999;30(11):2280-2284. No intervention of interest studied. [pmid: 10548658].
Fischer J. TPA for acute ischemic stroke. S D J Med. 1997;50(2):69-70. No original empirical evidence presented. [pmid: 9062450].
Fisher M, Bozik ME. 90-day outcome of patients receiving i.v. tPA in the POST trials. Stroke. 2003;34(1):283. No intervention of interest studied.
Fisher M, Brott TG. Emerging therapies for acute ischemic stroke: new therapies on trial. [Review] [32 refs]. Stroke. 2003;34(2):359-361. No human participants. [pmid: 12574536].
Fisher M, Davalos A. Emerging therapies for cerebrovascular disorders. [Review] [11 refs]. Stroke. 2004;35(2):367-369. No original empirical evidence presented. [pmid: 14757882].
Fisher TR. Education is key to stroke-prevention program. Pa Med. 1997;100(3):43-44. No original empirical evidence presented. [pmid: 9086801].
Fisher WS, Jordan WD. Carotid angioplasty. Surg Neurol. 1998;50(4):295-298. No original empirical evidence presented. [pmid: 9817450].
Fitzmaurice DA, Raftery JP, Bryan S. Policy dilemmas for oral anticoagulation management. Br J Gen Pract. 2000;50(459):779-780. No original empirical evidence presented. [pmid: 11127164]. [pmcid: 1313815].
Fjaertoft H, Ekeberg G, Loge AD, et al. Extended stroke unit care with early supported discharge co-ordinated by a stroke team improves outcome for stroke patients. Eur J Neurol. 1999;6(5):A8-A9. No intervention of interest studied.
Fjaertoft H, Indredavik B, Lydersen S. Stroke unit care combined with early supported discharge: long-term follow-up of a randomized controlled trial.[see comment]. Stroke. 2003;34(11):2687-2691. No intervention of interest studied. [pmid: 14576376].
Fleck LM, Hayes OW. Ethics and consent to treat issues in acute stroke therapy. Emerg Med Clin North Am. 2002;20(3):703-715. No original empirical evidence presented. [pmid: 12379969].
Fleishaker JC, Peters GR. Pharmacokinetics of tirilazad and U-89678 in ischemic stroke patients receiving a loading regimen and maintenance regimen of 10 mg/kg/day of tirilazad. J Clin Pharmacol. 1996;36(9):809-813. No intervention of interest studied. [pmid: 8889901].
Fleming T, Borer J, Armstrong PW, et al. Food and Drug Administration: Cardiovascular and Renal Drugs Advisory Committee, 98th meeting, January 6th-7th, 2003. Circulation. 2003;107(2):e9002-e9003. No original empirical evidence presented. [pmid: 12538443].
Fletcher BJ, King K. Stroke Nursing Committee: addressing a special need of the Council of Cardiovascular Nursing. Stroke. 2001;32(5):1238N. o human participants. [pmid: 11340244].
Flint J. The expert patient: Good thinking or a cross to bear?. British Journal of Cardiology. 2003;10(1):11. +13. No original empirical evidence presented.
Foell RB, Silver B, Merino JG, et al. Effects of thrombolysis for acute stroke in patients with pre-existing disability. CMAJ Canadian Medical Association Journal. 2003;169(3):193-197. No intervention of interest studied.
Foerch C, Du Mesnil DR, Singer O, et al. S100B as a surrogate marker for successful clot lysis hyperacute middle cerebral artery occlusion. Journal of Neurology, Neurosurgery & Psychiatry. 2003;74(3):322-325. No intervention of interest studied.
Fogari R, Pasotti C, Zoppi A, et al. Effect of perindopril and atenolol on plasm PAI-1 in hypertensive patients with acute ischemic stroke. Stroke. 2003;34(1):309. No intervention of interest studied.
Fogelholm R, Murros K, Rissanen A, et al. Factors delaying hospital admission after acute stroke. Stroke. 1996;27(3):398-400. No intervention of interest studied. [pmid: 8610302].
Folden SL. Effect of a supportive-educative nursing intervention on older adults" perceptions of self-care after a stroke. Rehabil Nurs. 1993;18(3):162-167. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8502841].
Ford G, Freemantle N. ECASS-II: Intravenous alteplase in acute ischaemic stroke. Lancet. 1999:35365-68. No original empirical evidence presented.
Forster A, Smith J, Young J et al. Information provision for stroke patients and their caregivers. [Review][54 refs]. Cochrane Database Syst Rev 2001;(3):CD001919No original empirical evidence presented.
Fotherby MD. Stroke, blood pressure and antihypertensive therapy. J Hum Hypertens 1997;11625–627. No original empirical evidence presented.
Fotherby MD, Panayiotou B. Antihypertensive therapy in the prevention of stroke: what, when and for whom? [Review] [72 refs]. Drugs. 1999;58(4):663-674. No original empirical evidence presented. [pmid: 10551436].
Fournier A, Mazouz H, Achard JM. STOPPING at the CAPPP of good HOPE.[comment]. Nephrology Dialysis Transplantation. 2001;16(1):185-187. No original empirical evidence presented.
Fournier A, Oprisiu R, Andrejak M, et al. Reducing the Risk of Stroke [2] (multiple letters). J Am Med Assoc. 2003;289(15):1927-1929. No human participants.
Fragoso YD, Baroncelli C, Gibbons AP, et al. Does effective secondary prevention of ischemic events start at hospitalization?. Medgenmed [Computer File]: Medscape General Medicine. 2000;2(1):E23. No original empirical evidence presented. [pmid: 11104469].
Frankel MR. Update: The Paul Coverdell Georgia stroke registry pilot prototype. Ethn Dis. 2003;13(3 SUPPL. 3). No human participants.
Frankel MR, Morgenstern LB, Kwiatkowski T, et al. Predicting prognosis after stroke: a placebo group analysis from the National Institute of Neurological Disorders and Stroke rt-PA Stroke Trial. Neurology. 2000;55(7):952-959. No intervention of interest studied. [pmid: 11061250].
Frazier JM, Kane KY. ACE inhibitors are better than diuretics for treatment of hypertension in the elderly. J Fam Pract. 2003;52(6):436-438. No original empirical evidence presented. [pmid: 12791220].
Frijling BD, Lobo CM, Keus IM, et al. Perceptions of cardiovascular risk among patients with hypertension or diabetes. Patient Education & Counseling. 2004;52(1):47-53. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14729290].
Fuentes B, Tejedor ED. Re: Randomized controlled study of stroke unit versus stroke team care in different stroke subtypes.[comment]. Stroke. 2002;33(7):1740-1741. No original empirical evidence presented. [pmid: 12105337].
Fujioka K. Clinical trials and anti-obesity agents: Expect the unexpected. Curr Opin Investig Drugs. 2003;4(10):1164-1165. No human participants.
Furlan AJ. Acute stroke therapy: beyond i.v. tPA. [Review] [10 refs]. Cleve Clin J Med. 2002;69(9):730-734. No original empirical evidence presented. [pmid: 12222978].
Furlan AJ, Abou-Chebi A. The role of recombinant pro-urokinase (r-pro-UK) and intra-arterial thrombolysis in acute ischaemic stroke: the PROACT trials. Prolyse in Acute Cerebral Thromboembolism. Current Medical Research & Opinion. 2002;18 Suppl:2s44-s47. No original empirical evidence presented.
Futrell N, Millikan CH. Stroke is an emergency. [Review] [198 refs]. Dis Mon. 1996;42(4):199-264. No original empirical evidence presented. [pmid: 8603565].
Gabis LV, Yangala R, Lenn NJ. Time lag to diagnosis of stroke in children. Pediatrics. 2002;110(5):924-928. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12415031].
Gagliardi R, Benvenuti L, Guizzardi G. Acute operation in cases of middle cerebral artery occlusion. Neurosurgery. 1983;12(6):636-639. No original empirical evidence presented. [pmid: 6877545].
Gagnon RL, Marsh ML, Smith RW, et al. Intracranial hypertension caused by nitroglycerin. Anesthesiology. 1979;51(1):86-87. No original empirical evidence presented. [pmid: 110177].
Gambhir IS, Gupta SS, Singh DS. Sublingual nifedipine in hypertensive emergencies with special reference to cerebrovascular accident. J Indian Med Assoc. 1991;89(8):231-234. No intervention of interest studied. [pmid: 1748801].
Garraway WM, Akhtar AJ, Prescott RJ, et al. Management of acute stroke in the elderly: preliminary results of a controlled trial. BMJ. 1980;280(6220):1040-1043. No intervention of interest studied. [pmid: 6996779]. [pmcid: 1600646].
Gaumann DM, Tassonyi E, Rivest RW, et al. Cardiovascular and endocrine effects of clonidine premedication in neurosurgical patients.[see comment]. Can J Anaesth. 1991;38(7):837-843. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 1742817].
Gavestinel produces no benefit for stroke patients, study finds. Clin Resour.Manag 2001;2(11):173–175. No original empirical evidence presented.
Gebel JM, Sila CA, Sloan MA, et al. Thrombolysis-related intracranial hemorrhage: a radiographic analysis of 244 cases from the GUSTO-1 trial with clinical correlation. Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries. Stroke. 1998;29(3):563-569. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9506593].
Generalized efficacy of t-PA for acute stroke. Subgroup analysis of the NINDS t-PA Stroke Trial. Stroke 1997;28(11):2119–2125. No intervention of interest studied.
Gerber CS. Stroke: historical perspectives. Crit Care Nurs Q. 2003;26(4):268-275. No original empirical evidence presented. [pmid: 14604125].
Geroldi C, Galluzzi S, Testa C, et al. Validation study of a CT-based weighted rating scale for subcortical ischemic vascular disease in patients with mild cognitive deterioration. Eur Neurol. 2003;49(4):193-209. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12736535].
Gerriets T, Postert T, Goertler M, et al. DIAS I: duplex-sonographic assessment of the cerebrovascular status in acute stroke. A useful tool for future stroke trials. Stroke. 2000;31(10):2342-2345. No intervention of interest studied. [pmid: 11022061].
Ghosh S, Aronow WS. Utilization of lipid-lowering drugs in elderly persons with increased serum low-density lipoprotein cholesterol associated with coronary artery disease, symptomatic peripheral arterial disease, prior stroke, or diabetes mellitus before and after an educational program on dyslipidemia treatment. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2003;58(5):432-435. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Gibbon B. Stroke care and rehabilitation. Nurs Stand Spec Suppl. 1995;9(43):31-35. No original empirical evidence presented.
Giese M, Lackland DT, Egan BM. The hypertension initiative of South Carolina. Promoting cardiovascular health through better blood pressure control. Journal - South Carolina Medical Association. 2001;97(2):57-62. No original empirical evidence presented. [pmid: 11235117].
Gifford RWJ. Long-term clinical trials in hypertension. [Review] [23 refs]. Journal of Hypertension - Supplement. 1990;8(2):S17-S22. No original empirical evidence presented.
Gil Nunez AC, Vivancos MJ. Organization of medical care in acute stroke: importance of a good network. [Review] [131 refs]. Cerebrovasc Dis. 2004;17 Suppl:1113-123. No original empirical evidence presented.
Gitlin LN, Luborsky MR, Schemm RL. Emerging concerns of older stroke patients about assistive device use. Clin Gerontol. 1998;38(2):169-180. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Glader EL, Stegmayr B, Norrving B, et al. Sex differences in management and outcome after stroke: a Swedish national perspective. Stroke. 2003;34(8):1970-1975. No intervention of interest studied. [pmid: 12855818].
Gladman J, Barer D, Langhorne P. Specialist rehabilitation after stroke.[comment]. BMJ. 1996;312(7047):1623-1624. No human participants. [pmid: 8664701]. [pmcid: 2351345].
Gladman J, Whynes D, Lincoln N. Cost comparison of domiciliary and hospital-based stroke rehabilitation. DOMINO Study Group. Age & Ageing. 1994;23(3):241-245. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8085511].
Glasziou P, Guyatt GH, Dans AL, et al. Applying the results of trials and systematic reviews to individual patients.[see comment]. ACP J Club. 1998;129(3):A15-A16. No original empirical evidence presented. [pmid: 9825009].
Goh KY, Poon WS. Recombinant tissue plasminogen activator for the treatment of spontaneous adult intraventricular hemorrhage. Surg Neurol. 1998;50(6):526-531. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9870812].
Goldberg RJ, Mooradd M, Gurwitz JH, et al. Impact of time to treatment with tissue plasminogen activator on morbidity and mortality following acute myocardial infarction (The second National Registry of Myocardial Infarction). Am J Cardiol. 1998;82(3):259-264. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9708650].
Goldstein LB. Editorial comment--Advertising strategies to increase the public knowledge of the warning signs of stroke.[comment]. Stroke. 2003;34(8):1968-1969. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12869722].
Goldstein LB. Prevention and health services delivery. [Review] [20 refs]. Stroke. 2003;34(2):367-369. No human participants. [pmid: 12574539].
Goldstein LB. Effects of amphetamines and small related molecules on recovery after stroke in animals and man. [Review] [117 refs]. Neuropharmacology. 2000;39(5):852-859. No original empirical evidence presented. [pmid: 10699450].
Goldstein LB. Common drugs may influence motor recovery after stroke. The Sygen In Acute Stroke Study Investigators.[see comment]. Neurology. 1995;45(5):865-871. No intervention of interest studied. [pmid: 7746398].
Goldstein LB. Blood Pressure Management in Patients with Acute Ischemic Stroke. Hypertension. 2004;43(2 I):137-141. No original empirical evidence presented. [pmid: 14718352].
Goldstein LB, Albers GW. Patient safety in trials of therapy for acute ischemic stroke.[comment]. JAMA. 2002;287(8):987N. o original empirical evidence presented. [pmid: 11866641].
Goldstein LB, Amarenco P. Prevention and health services delivery. Stroke. 2004;35(2):401-403. No original empirical evidence presented. [pmid: 14757892].
Goldstein LB, SASS I. Antihypertensives and stroke recovery. Stroke 1998;29317Study did not involve relevant population [defined as adult (>16) with acute stroke].
Goldstein LB, Edwards MG, Wood DP. Delay between stroke onset and emergency department evaluation. Neuroepidemiology. 2001;20(3):196-200. No intervention of interest studied. [pmid: 11490166].
Goldstein LB, Hey LA, Laney R. North Carolina stroke prevention and treatment facilities survey: rtPA therapy for acute stroke. Stroke. 1998;29(10):2069-2072. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9756583].
Goldstein LB, Hey LA, Laney R. North Carolina stroke prevention and treatment facilities survey. Statewide availability of programs and services. Stroke. 2000;31(1):66-70. No human participants. [pmid: 10625717].
Goldstein LB, Matchar DB, Hoff-Lindquist J, et al. VA Stroke Study: Neurologist care is associated with increased testing but improved outcomes. Neurology. 2003;61(6):792-796. No intervention of interest studied. [pmid: 14504322].
Gompertz P, Pound P, Briffa J, et al. How useful are non-random comparisons of outcomes and quality of care in purchasing hospital stroke services?. Age & Ageing. 1995;24(2):137-141. No intervention of interest studied. [pmid: 7793336].
Gompertz P, Slack A, Vogel M, et al. Education in stroke: strategies to improve stroke patient care. [Review] [14 refs]. Hospital Medicine (London). 2002;63(7):408-411. No original empirical evidence presented.
Gonzaga-Camfield R. Developing an emergency department team for treatment of stroke with recombinant tissue plasminogen activator. Crit Care Nurs Clin North Am. 1999;11(2):261-268. No original empirical evidence presented. [pmid: 10838987].
Gordon DL. The Mississippi Stroke Education Consortium: a state-based template to promote stroke awareness, prevention and emergency treatment. Neuroepidemiology. 2000;19(1):1-12. No human participants. [pmid: 10654283].
Gorelick PB. Stroke prevention: windows of opportunity and failed expectations? A discussion of modifiable cardiovascular risk factors and a prevention proposal. Neuroepidemiology. 1997;16(4):163-173. No original empirical evidence presented. [pmid: 9267832].
Gorman MJ. Acute thrombolytic therapy in stroke: focus on the 3- to 6-hour time window. [Review] [20 refs]. Ethn Dis. 2002;12(1):S1-S7. No original empirical evidence presented.
Gosman-Hedstrom G, Claesson L, Blomstrand C, et al. Use and cost of assistive technology the first year after stroke. A randomized controlled trial. Int J Technol Assess Health Care. 2002;18(3):520-527. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12391945].
Grade C, Redford B, Chrostowski J, et al. Methylphenidate in early poststroke recovery: a double-blind, placebo-controlled study. Archives of Physical Medicine & Rehabilitation. 1998;79(9):1047-1050. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9749682].
Gradison M. Decreasing the morbidity, mortality, and cost of stroke through awareness and prevention.[comment]. Am Fam Physician. 2003;68(12):2335-2340. No original empirical evidence presented. [pmid: 14705753].
Graf J, Skutta B, Kuhn FP, et al. Computed tomographic angiography findings in 103 patients following vascular events in the posterior circulation: potential and clinical relevance. J Neurol. 2000;247(10):760-766. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11127530].
Graham CA. Transient cerebral ischemia demands urgent evaluation. Stroke. 2003;34(10):2451-2452. No original empirical evidence presented. [pmid: 14500925].
Graham GD. Tissue plasminogen activator for acute ischemic stroke in clinical practice: a meta-analysis of safety data. Stroke. 2003;34(12):2847-2850. No original empirical evidence presented. [pmid: 14605319].
Gray CS, Scott JF, French JM, et al. Prevalence and prediction of unrecognised diabetes mellitus and impaired glucose tolerance following acute stroke. Age & Ageing. 2004;33(1):71-77. No original empirical evidence presented. [pmid: 14695867].
Green D. Thrombosis and Stroke: Foreword. Top Stroke Rehabil. 2003;10(3):v-vi. No human participants.
Greenberg RK. Endovascular therapy or conventional vascular surgery? A complex choice. Cleve Clin J Med. 2003;70(12):1038-1054. No original empirical evidence presented. [pmid: 14686683].
Griffith DN, James IM, Newbury PA, et al. The effect of beta-adrenergic receptor blocking drugs on cerebral blood flow. Br J Clin Pharmacol. 1979;7(5):491-494. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 38822]. [pmcid: 1429570].
Grotta J. Lubeluzole treatment of acute ischemic stroke. The US and Canadian Lubeluzole Ischemic Stroke Study Group.[see comment]. Stroke. 1997;28(12):2338-2346. No intervention of interest studied. [pmid: 9412611].
Grotta J, Bratina P. Subjective experiences of 24 patients dramatically recovering from stroke. Stroke. 1995;26(7):1285-1288. No intervention of interest studied. [pmid: 7604427].
Grotta JC. Adding to the effectiveness of intravenous tissue plasminogen activator for treating acute stroke.[comment]. Circulation. 2003;107(22):2769-2770. No original empirical evidence presented. [pmid: 12796412].
Grotta JC, Alexandrov AV. tPA-associated reperfusion after acute stroke demonstrated by SPECT.[comment]. Stroke. 1998;29(2):429-432. No intervention of interest studied. [pmid: 9472885].
Grotta JC, Chiu D, Lu M, et al. Agreement and variability in the interpretation of early CT changes in stroke patients qualifying for intravenous rtPA therapy.[comment]. Stroke. 1999;30(8):1528-1533. No intervention of interest studied. [pmid: 10436095].
Grotta JC, Welch KM, Fagan SC, et al. Clinical deterioration following improvement in the NINDS rt-PA Stroke Trial. Stroke. 2001;32(3):661-668. No intervention of interest studied. [pmid: 11239184].
Gruber A, Ungersbock K, Reinprecht A, et al. Evaluation of cerebral vasospasm after early surgical and endovascular treatment of ruptured intracranial aneurysms.[see comment]. Neurosurgery. 1998;42(2):258-267. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9482176].
Guadagno JV, Calautti C, Baron J-C. Progress in imaging stroke: Emerging clinical applications. Br Med Bull. 2003;65(pp 145157):157. No original empirical evidence presented.
Gueyffier F. Secondary Prevention of Stroke: Beyond Meta-Analyses. Stroke. 2003;34(11):2748-2749. No original empirical evidence presented. [pmid: 14576371].
Gueyffier F, Boissel JP, Boutitie F, et al. Effect of antihypertensive treatment in patients having already suffered from stroke. Gathering the evidence. The INDANA (INdividual Data ANalysis of Antihypertensive intervention trials) Project Collaborators. Stroke. 1997;28(12):2557-2562. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9412649].
Guo Y, Jiang X, Zhou Z, et al. Relationship between levels of serum C-reactive protein, leucocyte count and carotid plaque in patients with ischemic stroke. J Huazhong Univ Sci Technolog Med Sci. 2003;23(3):263-265. No intervention of interest studied. [pmid: 14526428].
Gupta A, Thomas P. General perception of stroke. Knowledge of stroke is lacking.[comment]. BMJ. 2002;325(7360):392N. o original empirical evidence presented.
Gupta R, Schumacher HC, Mangla S, et al. Urgent endovascular revascularization for symptomatic intracranial atherosclerotic stenosis.[see comment]. Neurology. 2003;61(12):1729-1735. No intervention of interest studied. [pmid: 14694038].
Gurwitz JH, Gore JM, Goldberg RJ, et al. Risk for intracranial hemorrhage after tissue plasminogen activator treatment for acute myocardial infarction. Participants in the National Registry of Myocardial Infarction 2.[see comment]. Ann Intern Med. 1998;129(8):597-604. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9786806].
Gusev EI, Martynov MI, Boiko AN, et al. [Antihypertensive treatment with eprosartan mesilate of patients in acute and late periods of ischemic stroke]. [Russian]. Zh Nevrol Psikhiatr Im S S Korsakova. 2003;S. Korsakova. 103(11):15-20. Unable to obtain by final date for inclusion.
Hachinski V. Awareness: the first step to action.[comment]. Stroke. 2002;33(5):1173N. o original empirical evidence presented. [pmid: 11988581].
Hachinski V. Our Readers Speak. Stroke 2004;35(1):No original empirical evidence presented.
Hack W, Kaste M, Bogousslavsky J, et al. European Stroke Initiative Recommendations for Stroke Management-update 2003. Cerebrovasc Dis. 2003;16(4):311-337. No original empirical evidence presented. [pmid: 14584488].
Hacke W, Bluhmki E, Steiner T, et al. Dichotomized efficacy end points and global end-point analysis applied to the ECASS intention-to-treat data set: post hoc analysis of ECASS I. Stroke. 1998;29(10):2073-2075. No intervention of interest studied. [pmid: 9756584].
Hacke W, Brott T, Caplan L, et al. Thrombolysis in acute ischemic stroke: controlled trials and clinical experience. [Review] [12 refs]. Neurology. 1999;53(7 Suppl 4):S3-14. No original empirical evidence presented.
Hacke W, Donnan G, Fieschi C, et al. Association of outcome with early stroke treatment: pooled analysis of ATLANTIS, ECASS, and NINDS rt-PA stroke trials. Lancet. 2004;363(9411):768-774. No original empirical evidence presented. [pmid: 15016487].
Hacke W, Kaste M, Olsen TS, et al. European Stroke Initiative: recommendations for stroke management. Organisation of stroke care. J Neurol. 2000;247(9):732-748. No original empirical evidence presented. [pmid: 11081821].
Hacke W, Marler J. TPA in acute stroke. Eur Heart J 1997;181360. No original empirical evidence presented.
Hacke W, Ringleb P, Stingele R. Update in thrombolytic therapy. [Review] [15 refs]. Rev Neurol (Paris). 1999;155(9):662-665. No original empirical evidence presented. [pmid: 10528345].
Hademenos G. Metro Stroke Task Force: first-year experience. Stroke. 1999;30(11):2512. No original empirical evidence presented. [pmid: 10548694].
Haley ECJ, Levy DE, Brott TG, et al. Urgent therapy for stroke. Part II. Pilot study of tissue plasminogen activator administered 91–180 minutes from onset. Stroke. 1992;23(5):641-645. No intervention of interest studied. [pmid: 1579959].
Haley ECJ, Lewandowski C, Tilley BC. Myths regarding the NINDS rt-PA Stroke Trial: setting the record straight.[see comment]. Ann Emerg Med. 1997;30(5):676-682. No original empirical evidence presented. [pmid: 9360581].
Haley EC, TPA Bridging, Study Group. Pilot randomised trial of tissue plasminogen activator in acute ischemic stroke. Neurology 1992;42(Suppl 3). No intervention of interest studied.
Hammett DC, MacFadyen JC. Don"t keep that ACE (inhibitor) up your sleeve! Is ramipril effective for secondary prevention of cardiovascular disease and stroke?. Can Fam Physician. 2000;46(4):821-823. No original empirical evidence presented. [pmid: 10790814]. [pmcid: 2144832].
Hampton. Mega-trials and equivalence trials: Experience from the INJECT study. Eur Heart J 1996;17(SUPPL. E):28–34. No original empirical evidence presented.
Hanger HC, Fogarty B, Wilkinson TJ, et al. Stroke patients" views on stroke outcomes: death versus disability. Clin Rehabil. 2000;14(4):417-424. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10945426].
Hanger HC, Mulley GP. Questions people ask about stroke. Stroke. 1993;24(4):536-538. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8465358].
Hankey GJ. Clomethiazole: an unsuccessful bachelor, but perhaps a prosperous married man?[comment]. Stroke. 2002;33(1):128-129. No intervention of interest studied. [pmid: 11817345].
Hankey GJ. Stroke: how large a public health problem, and how can the neurologist help? [Review] [36 refs]. Arch Neurol. 1999;56(6):748-754. No original empirical evidence presented. [pmid: 10369318].
Hankey GJ. Thrombolytic therapy in acute ischaemic stroke: the jury needs more evidence. [Review] [27 refs]. Med J Aust. 1997;166(8):419-422. No original empirical evidence presented. [pmid: 9140348].
Hankey GJ, Deleo D, Stewart-Wynne EG. Stroke units: an Australian perspective. Australian & New Zealand Journal of Medicine. 1997;27(4):437-438. No intervention of interest studied. [pmid: 9448885].
Hankey GJ. Heart Outcomes, PE Perindopril, et al. Angiotensin-converting enzyme inhibitors for stroke prevention: is there HOPE for PROGRESS After LIFE? [Review] [19 refs]. Stroke. 2003;34(2):354-356. No original empirical evidence presented. [pmid: 12574534].
Hankey G J, Deleo D, Stewart Wynne E G. Acute hospital care for stroke patients; a randomised controlled trial. Cerebrovasc Dis 1995;5. No intervention of interest studied.
Hanley DF. Review of critical care and emergency approaches to stroke. [Review] [21 refs]. Stroke. 2003;34(2):362-364. No original empirical evidence presented. [pmid: 12574537].
Hanley DF, Hacke W. Critical Care and Emergency Medicine Neurology. Stroke. 2004;35(2):365-366. No original empirical evidence presented. [pmid: 14757881].
Hansson L, Himmelmann A. Carvedilol in the treatment of hypertension--a review of the clinical data base. [Review][178 refs]. Scandinavian Cardiovascular Journal Supplement 1998;4767–80. No original empirical evidence presented.
Hansson L, Lithell H, Skoog I, et al. Study on COgnition and Prognosis in the Elderly (SCOPE). Blood Press. 1999;8(3):177-183. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10595696].
Hantson L, Gheuens J, Tritsmans L, et al. Hospital referral of stroke patients: a survey of attitudes in general practice, and consideration of entry times for clinical trials. Clinical Neurology & Neurosurgery. 1994;96(1):32-37. No intervention of interest studied. [pmid: 8187379].
Harbison J, Hossain O, Jenkinson D, et al. Diagnostic accuracy of stroke referrals from primary care, emergency room physicians, and ambulance staff using the face arm speech test. Stroke. 2003;34(1):71-76. No intervention of interest studied. [pmid: 12511753].
Harmon RL, Woolley SM, Horn LJ. Use of clonidine for spasticity arising from stroke and brain injury: a pilot placebo-controlled trial. Archives of Physical Medicine & Rehabilitation 1996;77934. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Hart E. Evaluating a pilot community stroke service using insights from medical anthropology. J Adv Nurs. 1998;27(6):1177-1183. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9663869].
Hart RG, Benavente O. Stroke: part I. A clinical update on prevention. [Review] [27 refs]. Am Fam Physician. 1999;59(9):2475-2482. No original empirical evidence presented. [pmid: 10323355].
Hashimoto Y, Terasaki T, Yonehara T, et al. Critical pathway and hospital-hospital cooperation in acute stroke: Reduction of the length of hospital stay. Interventional Neuroradiology.6(SUPPL.1):251–5, 2000. 2000;6(1 Suppl):251-255. No intervention of interest studied.
Hedner T, Himmelmann A, Kjeldsen SE. Contrasting messages but not contradicting results from ALLHAT and ANBP2. Blood Press. 2003;12(2):68-69. No original empirical evidence presented. [pmid: 12797626].
Heinsius T, Bogousslavsky J, van Melle G. Large infarcts in the middle cerebral artery territory. Etiology and outcome patterns.[see comment][erratum appears in Neurology 1998 Jun;50(6):1940–3]. Neurology. 1998;50(2):341-350. No intervention of interest studied. [pmid: 9484351].
Heiss WD, Graf R, Grond M, et al. Quantitative neuroimaging for the evaluation of the effect of stroke treatment. [Review] [29 refs]. Cerebrovasc Dis. 1998;8 Suppl:223-29. No original empirical evidence presented.
Heiss WD, Grond M, Thiel A, et al. Ischaemic brain tissue salvaged from infarction with alteplase. Lancet. 1997;349(9065):1599-1600. No intervention of interest studied. [pmid: 9174564].
Heiss WD, Grond M, Thiel A, et al. Tissue at risk of infarction rescued by early reperfusion: a positron emission tomography study in systemic recombinant tissue plasminogen activator thrombolysis of acute stroke. Journal of Cerebral Blood Flow & Metabolism. 1998;18(12):1298-1307. No intervention of interest studied. [pmid: 9850142].
Heiss WD, Kracht L, Grond M, et al. Early [(11)C]Flumazenil/H(2)O positron emission tomography predicts irreversible ischemic cortical damage in stroke patients receiving acute thrombolytic therapy. Stroke. 2000;31(2):366-369. No intervention of interest studied. [pmid: 10657407].
Heiss WD, Kracht LW, Thiel A, et al. Penumbral probability thresholds of cortical flumazenil binding and blood flow predicting tissue outcome in patients with cerebral ischaemia.[see comment]. Brain Dev. 2001;124(Pt 1):20-29. No intervention of interest studied.
Helgeland A. Treatment of mild hypertension: a five year controlled drug trial. The Oslo study. Am J Med. 1980;69(5):725-732. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7001898].
Hemphill JC. New treatments for stroke. [Review] [22 refs]. Prog Cardiovasc Nurs. 1998;13(1):4-15. No human participants. [pmid: 9614684].
Henkel J. New success against stroke. Prevention, improved therapies help fight this devastating condition. FDA Consum. 1998;32(2):12-16. No original empirical evidence presented.
Hennekens CH. Role of aspirin with thrombolytic therapy in acute myocardial infarction. Chest. 1990;97(4 Suppl):151S-155S. No original empirical evidence presented. [pmid: 2108852].
Henriques IL, Bogousslavsky J. Value of stroke data banks for the analysis of clinical syndromes. [Review] [13 refs]. Neuroepidemiology. 1994;13(6):296-300. No intervention of interest studied. [pmid: 7800108].
Herd AM. Current management of acute ischemic stroke. Part 2: Antithrombotics, neuroprotectives, and stroke units.[see comment]. Can Fam Physician 2001;471795–1800. No human participants.
Herd AM. Current management of acute ischemic stroke. Part 1: Thrombolytics and the 3-hour window.[see comment]. Can Fam Physician 2001;471787–1793. No original empirical evidence presented.
Hermier M, Nighoghossian N, Derex L, et al. Hypointense transcerebral veins at T2*-weighted MRI: a marker of hemorrhagic transformation risk in patients treated with intravenous tissue plasminogen activator. Journal of Cerebral Blood Flow & Metabolism. 2003;23(11):1362-1370. No intervention of interest studied. [pmid: 14600444].
Heros RC, Camarata PJ, Latchaw RE. Brain attack. Introduction. [Review] [114 refs]. Neurosurg Clin N Am. 1997;8(2):135-144. No original empirical evidence presented. [pmid: 9113697].
Hess DC, Wheby MS. Ischemic stroke. Medical Crossfire. 2003;5(7):17-19. No human participants.
Heuschmann PU, Berger K, Misselwitz B, et al. Frequency of thrombolytic therapy in patients with acute ischemic stroke and the risk of in-hospital mortality: the German Stroke Registers Study Group.[see comment]. Stroke. 2003;34(5):1106-1113. No intervention of interest studied.
Heyman A, Fields WS, Keating RD. Joint study of extracranial arterial occlusion. VI. Racial differences in hospitalized patients with ischemic stroke. JAMA. 1972;222(3):285-289. No intervention of interest studied. [pmid: 4678681].
Hickenbottom SL, Morgenstern LB. Educating North America: lessons learned. Journal of Stroke & Cerebrovascular Diseases. 2002;11(3/4):174-182. No original empirical evidence presented. [pmid: 17903873].
Higashida RT, Furlan AJ, Roberts H, et al. Trial design and reporting standards for intra-arterial cerebral thrombolysis for acute ischemic stroke.[see comment][erratum appears in Stroke. 2003 Nov;34(11):2774]. Stroke. 2003;34(8):e109-e137. No original empirical evidence presented. [pmid: 12869717].
Hilker R, Poetter C, Findeisen N, et al. Nosocomial pneumonia after acute stroke: implications for neurological intensive care medicine.[see comment]. Stroke. 2003;34(4):975-981. No intervention of interest studied. [pmid: 12637700].
Hill MD, Buchan AM. Methodology for the Canadian Activase for Stroke Effectiveness Study (CASES). CASES Investigators.[erratum appears in Can J Neurol Sci 2002 Feb;29(1):103]. Can J Neurol Sci. 2001;28(3):232-238. No intervention of interest studied. [pmid: 11513342].
Hill MN. Comprehensive hypertension care in young urban black men: an example of a program of nursing research that integrates genetic science, clinical interventions, and patient outcomes. Crit Care Nurs Clin North Am. 2000;35(3):773-793. No original empirical evidence presented.
Hillis AE, Barker PB, Beauchamp NJ, et al. MR perfusion imaging reveals regions of hypoperfusion associated with aphasia and neglect. Neurology. 2000;55(6):782-788. No intervention of interest studied. [pmid: 10993996].
Hillis AE, Ulatowski JA, Barker PB, et al. A pilot randomized trial of induced blood pressure elevation: Effects on function and focal perfusion in acute and subacute stroke. Cerebrovasc Dis. 2003;16(3):236-246. No intervention of interest studied. [pmid: 12865611].
Hinchey JA, Benesch C. Thrombolytic therapy in patients with acute ischemic stroke. [Review] [28 refs]. Arch Neurol. 2000;57(10):1430-1436. No original empirical evidence presented. [pmid: 11030794].
Hinckley JJ, Packard ME. Family education seminars and social functioning of adults with chronic aphasia. J Commun Disord. 2001;34(3):241-254. No original empirical evidence presented. [pmid: 11409606].
Hinton RC, Mohr JP, Ackerman RH, et al. Symptomatic middle cerebral artery stenosis. Ann Neurol. 1979;5(2):152-157. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 426478].
Ho SS, Metreweli C, Yu CH. Color velocity imaging quantification in the detection of intracranial collateral flow. Stroke. 2002;33(7):1795-1798. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12105355].
Hoang KD, Rosen P. The efficacy and safety of tissue plasminogen activator in acute ischemic strokes. [Review] [59 refs]. Am J Emerg Med. 1992;10(3):345-352. No original empirical evidence presented.
Hoballah JJ, Nazzal MM, Jacobovicz C, et al. Entering the ninth decade is not a contraindication for carotid endarterectomy. Angiology. 1998;49(4):275-278. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9555930].
Hock N. Neuroprotective and thrombolytic agents: advances in stroke treatment. [Review] [51 refs]. J Neurosci Nurs. 1998;30(3):175-184. No original empirical evidence presented. [pmid: 9689609].
Holloway RG, Vickrey BG, Benesch C, et al. Development of performance measures for acute ischemic stroke. [Review] [27 refs]. Stroke. 2001;32(9):2058-2074. No intervention of interest studied. [pmid: 11546898].
Horowitz N, Kapeliovich M, Beyar R, et al. Stenting in acute myocardial infarction: In hospital and long-term follow-up. Israel Medical Association Journal: Imaj. 2003;5(2):107-111. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Horstmann S, Kalb P, Koziol J, et al. Profiles of matrix metalloproteinases, their inhibitors, and laminin in stroke patients: influence of different therapies.[see comment]. Stroke. 2003;34(9):2165-2170. No intervention of interest studied. [pmid: 12907822].
Hospital focus. Teach patients to recognize warning signs of stroke. Article adapted from one that appeared in sister company American Health Consultants' newsletter ED Nursing. RN 2002;65(10):Suppl. No original empirical evidence presented.
Hou M-C, Lin H-C, Liu T-T, et al. Antibiotic Prophylaxis after Endoscopic Therapy Prevents Rebleeding in Acute Variceal Hemorrhage: A Randomized Trial. J Gastroenterol Hepatol. 2004;39(3):746-753. Study did not involve relevant population [defined as adult (>16) with acute stroke].
How do stroke units improve patient outcomes? A collaborative systematic review of the randomized trials. Stroke Unit Trialists Collaboration. [Review][30 refs]. Stroke 1997;28(11):2139–2144. No original empirical evidence presented.
Hu KK. Fighting for a peaceful death: a personal essay. J Palliat Med. 2001;4(2):209-213. No original empirical evidence presented. [pmid: 11441629].
Hui E, Lum CM, Woo J, et al. Outcomes of elderly stroke patients. Day hospital versus conventional medical management. Stroke. 1995;26(9):1616-1619. No intervention of interest studied. [pmid: 7660408].
Hund E, Grau A, Hacke W. Neurocritical care for acute ischemic stroke. [Review] [87 refs]. Neurosurg Clin N Am. 1997;8(2):271-282. No human participants. [pmid: 9113709].
Hurst RW, Haskal ZJ, Zager E, et al. Endovascular stent treatment of cervical internal carotid artery aneurysms with parent vessel preservation. Surg Neurol. 1998;50(4):313-317. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9817452].
Hurtubise A. Organized stroke care is emerging in Ontario.[comment]. Can Fam Physician 2002;4831–32. No human participants.
Hussein Z, Fraser IJ, Lees KR, et al. Pharmacokinetics of 619C89, a novel neuronal sodium channel inhibitor, in acute stroke patients after loading and discrete maintenance infusions. Br J Clin Pharmacol. 1996;41(6):505-511. No intervention of interest studied. [pmid: 8799514]. [pmcid: 2042617].
Hux K, Rogers T, Mongar K. Common perceptions about strokes. J Community Health. 2000;25(1):47-65. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10706209].
Hyde SL, Dowell MS. Acute stroke management: the importance of vital signs. Nurse 2 Nurse. 2002;2(12):10. Unable to obtain by final date for inclusion.
Iacopino DG, Conti A, Battaglia C, et al. Transcranial Doppler ultrasound study of the effects of nitrous oxide on cerebral autoregulation during neurosurgical anesthesia: A randomized controlled trial. J Neurosurg. 2003;99(1):58-64. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12854745].
Iadecola C, Gorelick PB. Hypertension, Angiotensin, and Stroke: Beyond Blood Pressure. Stroke. 2004;35(2):348-350. No original empirical evidence presented. [pmid: 14757875].
Iino K, Abe K, Kariya S, et al. A controlled, double-blind study of dl-alpha-tocopheryl nicotinate (Juvela-Nicotinate) for treatment of symptoms in hypertension and cerebral arteriosclerosis. Jpn Heart J. 1977;18(3):277-283. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 881743].
Indredavik B. Stroke units - the Norwegian experience. Cerebrovasc Dis. 2003;15 Suppl:119-20. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Indredavik B, Bakke F, Slordahl SA, et al. Stroke unit treatment. 10–year follow-up. Stroke. 1999;30(8):1524-1527. No intervention of interest studied. [pmid: 10436094].
Indredavik B, Bakke F, Slordahl SA, et al. Treatment in a combined acute and rehabilitation stroke unit: which aspects are most important?. Stroke. 1999;30(5):917-923. No intervention of interest studied. [pmid: 10229720].
Indredavik B, Bakke F, Solberg R, et al. Benefit of a stroke unit: a randomized controlled trial. Stroke. 1991;22(8):1026-1031. No intervention of interest studied. [pmid: 1866749].
Indredavik B, Fjaertoft H, Ekeberg G, et al. The benefit of an extended stroke unit service. A randomised controlled trial. Stroke. 2000;31(11):2832. No intervention of interest studied.
Indredavik B, Fjaertoft H, Ekeberg G, et al. Benefit of an extended stroke unit service with early supported discharge: A randomized, controlled trial.[see comment]. Stroke. 2000;31(12):2989-2994. No intervention of interest studied. [pmid: 11108761].
Indredavik B, Slordahl SA, Bakke F, et al. Stroke unit treatment. Long-term effects.[see comment]. Stroke. 1997;28(10):1861-1866. No intervention of interest studied. [pmid: 9341685].
Indredavik B, et al. Treatment in a combined acute and rehabilitation stroke unit. Stroke. 2000;30(5):917-923. No intervention of interest studied.
Innes K. Stroke Nurse, Collaborative Group. Thrombolysis for acute ischaemic stroke: core nursing requirements. [Review] [30 refs]. Br J Nurs. 2003;12(7):416-424. No original empirical evidence presented. [pmid: 12743488].
Ischemic stroke pathway relies on ED order sheets. Hosp Case Manag 1977;7(4):67–68. No human participants.
Ischemic stroke pathway relies on ED order sheets. RN 1999;62(10):24ac7–24ac8. No human participants.
Iso H, Shimamoto T, Naito Y, et al. Effects of a long-term hypertension control program on stroke incidence and prevalence in a rural community in northeastern Japan. Stroke. 1998;29(8):1510-1518. No original empirical evidence presented. [pmid: 9707185].
Iwase M, Yamamoto M, Yoshinari M, et al. Stroke topography in diabetic and nondiabetic patients by magnetic resonance imaging. Diabetes Research & Clinical Practice. 1998;42(2):109-116. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9886747].
Jaeger M, Schuhmann MU, Samii M, et al. Neurosurgical emergencies and missing neurosurgical intensive care unit capacity: is “operate-and-return” a sound policy?[see comment]. Eur J Emerg Med. 2002;9(4):334-338. No intervention of interest studied. [pmid: 12501033].
Jaffary F, Khan T, Kamali F, et al. The effect of stability of oral anticoagulant therapy upon patient-perceived health status and quality of life. J Am Geriatr Soc. 2003;51(6):885-887. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12757586].
Jaillard A, Cornu C, Durieux A, et al. Hemorrhagic transformation in acute ischemic stroke. The MAST-E study. MAST-E Group. Stroke. 1999;30(7):1326-1332. No intervention of interest studied. [pmid: 10390303].
Jauch E, Yealy DM, Adams JG. Society for Academic Emergency Medicine (SAEM) Neurologic Emergencies Interest Group Response to the SAEM Board Position on Optimizing Care of the Stroke Patient [2] (multiple letters). Acad Emerg Med. 2004;11(1):116-118. No original empirical evidence presented. [pmid: 14709442].
Jauss M, Krieger D, Hornig C, et al. Surgical and medical management of patients with massive cerebellar infarctions: results of the German-Austrian Cerebellar Infarction Study.[erratum appears in J Neurol 1999 Jul;246(7):628]. J Neurol. 1999;246(4):257-264. No intervention of interest studied. [pmid: 10367693].
Jeffery J. Setting up a stroke club. Health Visit. 1990;63(2):56-58. No original empirical evidence presented. [pmid: 2312317].
Jensen K, Bunemann L, Riisager S, et al. Cerebral blood flow during anaesthesia: influence of pretreatment with metoprolol or captopril. Br J Anaesth. 1989;62(3):321-323. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 2649124].
Jensen ME, Kallmes DF. The current status of endovascular stroke therapy. [Review] [14 refs]. Va Med Q. 1998;125(2):133-137. No original empirical evidence presented. [pmid: 9577718].
Jichici D, Frank JI. Thrombolytic therapy in neurointensive care. [Review] [126 refs]. Crit Care Clin. 1997;13(1):201-227. No original empirical evidence presented. [pmid: 9012582].
Jin L, Jin H, Zhang G, et al. Changes in coagulation and tissue plasminogen activator after the treatment of cerebral infarction with lumbrokinase. Clinical Hemorheology & Microcirculation. 2000;23(24):213-218. No intervention of interest studied. [pmid: 11321442].
Johansson L, Jansson JH, Boman K, et al. Tissue plasminogen activator, plasminogen activator inhibitor-1, and tissue plasminogen activator/plasminogen activator inhibitor-1 complex as risk factors for the development of a first stroke. Stroke. 2000;31(1):26-32. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10625711].
Johnson S, Snelling. Comparison of out-of-hospital diagnosis of stroke with emergency department diagnosis of stroke. Acad Emerg Med. 2001;8(5):489. No intervention of interest studied.
Johnston KC, Connors AFJ, Wagner DP, et al. Risk adjustment effect on stroke clinical trials. Stroke. 2004;35(2):e43-e45. No intervention of interest studied. [pmid: 14715975].
Johnston KC, Connors AFJ, Wagner DP, et al. Predicting outcome in ischemic stroke: external validation of predictive risk models. Stroke. 2003;34(1):200-202. No intervention of interest studied. [pmid: 12511774].
Johnston KC, Connors AF, Wagner DP, et al. A predictive risk model for outcomes of ischemic stroke. Stroke. 2000;31(2):448-455. No intervention of interest studied. [pmid: 10657421].
Johnston KC, Wagner DP, Connors AF, et al. Risk adjustment uncovers greater treatment effects of NINDS tPA trial. Stroke. 2003;34(1):256. No intervention of interest studied.
Johnston KC, Wagner DP, Haley EC, et al. Combined clinical and imaging information as an early stroke outcome measure. Stroke. 2002;33(2):466-472. No intervention of interest studied. [pmid: 11823654].
Johnston SC, Easton JD. Are patients with acutely recovered cerebral ischemia more unstable?[see comment]. Stroke. 2003;34(10):2446-2450. No intervention of interest studied. [pmid: 12958326].
Johnston SC, Fung LH, Gillum LA, et al. Utilization of intravenous tissue-type plasminogen activator for ischemic stroke at academic medical centers: the influence of ethnicity.[see comment]. Stroke. 2001;32(5):1061-1068. No intervention of interest studied. [pmid: 11340210].
Johnston SC, Leira EC, Hansen MD, et al. Early recovery after cerebral ischemia risk of subsequent neurological deterioration. Ann Neurol. 2003;54(4):439-444. No intervention of interest studied. [pmid: 14520654].
Jonas S, Tran AQ, Eisenberg E et al. Does effect of a neuroprotective agent on volume of experimental animal cerebral infarct predict effect of the agent on clinical outcome in human stroke? [Review][34 refs]. Ann N Y Acad Sci 1997;825281–287. No original empirical evidence presented.
Jordan WD J, Voellinger DC, Doblar DD, et al. Microemboli detected by transcranial Doppler monitoring in patients during carotid angioplasty versus carotid endarterectomy. Semin Thorac Cardiovasc Surg. 1999;7(1):33-38. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Jordan WD J, Voellinger DC, Fisher WS, et al. A comparison of carotid angioplasty with stenting versus endarterectomy with regional anesthesia.[see comment]. Eur J Vasc Surg. 1998;28(3):397-402. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Jorgensen H, Nakayama H, Raaschou HO, et al. Stroke in patients with diabetes. The Copenhagen Stroke Study. Stroke. 1994;25(10):1977-1984. No intervention of interest studied. [pmid: 8091441].
Jorgensen HS, Kammersgaard LP, Nakayama H, et al. Treatment and rehabilitation on a stroke unit improves 5-year survival. A community-based study. Stroke. 1999;30(5):930-933. No intervention of interest studied. [pmid: 10229722].
Jorgensen HS, Nakayama H, Raaschou HO, et al. Acute stroke: prognosis and a prediction of the effect of medical treatment on outcome and health care utilization. The Copenhagen Stroke Study. Neurology. 1997;49(5):1335-1342. No intervention of interest studied. [pmid: 9371918].
Jorgensen HS, Nakayama H, Reith J, et al. Factors delaying hospital admission in acute stroke: the Copenhagen Stroke Study. Neurology. 1996;47(2):383-387. No intervention of interest studied. [pmid: 8757008].
Jorgensen HS, Reith J, Nakayama H, et al. Potentially reversible factors during the very acute phase of stroke and their impact on the prognosis: is there a large therapeutic potential to be explored?. Cerebrovasc Dis. 2001;11(3):207-211. No intervention of interest studied. [pmid: 11306769].
Kain K, Catto AJ, Carter AM, et al. Decreased fibrinolytic potential in South Asian women with ischaemic cerebrovascular disease. Br J Haematol. 2001;114(1):155-161. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11472361].
Kallmes DF, Kallmes MH. Cost-effectiveness of angiography performed during surgery for ruptured intracranial aneurysms. AJNR Am J Neuroradiol. 1997;18(8):1453-1462. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9296186].
Kalra L. Scoring systems for the differential diagnosis of ischaemic and haemorrhagic stroke. Natl Med J India. 2003;16(1):1-3. No original empirical evidence presented.
Kalra L, Evans A, Perez I et al. A randomised comparison of processes of care between stroke unit and stroke team management. Cerebrovasc Dis 2001;11(Suppl 4):Study did not involve relevant population [defined as adult (>16) with acute stroke].
Kane RL, Chen Q, Finch M, et al. Functional outcomes of posthospital care for stroke and hip fracture patients under medicare. J Am Geriatr Soc. 1998;46(12):1525-1533. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9848813].
Kaposzta Z, Clifton A, Molloy J, et al. S-nitrosoglutathione reduces asymptomatic embolization after carotid angioplasty. Circulation. 2002;106(24):3057-3062. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12473551].
Karanjia PN, Nelson JJ, Lefkowitz DS, et al. Validation of the ACAS TIA/stroke algorithm. Neurology. 1997;48(2):346-351. No intervention of interest studied. [pmid: 9040719].
Kase CS, Pessin MS, Zivin JA, et al. Intracranial hemorrhage after coronary thrombolysis with tissue plasminogen activator. Am J Med. 1992;92(4):384-390. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 1558085].
Kasner SE. Editorial comment--More than one way to lyse a clot.[comment]. Stroke. 2004;35(4):911-912. No original empirical evidence presented. [pmid: 15044811].
Kasner SE, Grotta JC. Emergency identification and treatment of acute ischemic stroke.[see comment]. [Review] [53 refs]. Ann Emerg Med. 1997;30(5):642-653. No original empirical evidence presented. [pmid: 9360577].
Kasner SE, Grotta JC. Ischemic stroke. [Review] [73 refs]. Neurol Clin. 1998;16(2):355-372. No original empirical evidence presented. [pmid: 9537966].
Kaste M. hrombolysis in ischaemic stroke -- present and future: role of combined therapy. [Review] [33 refs]. Cerebrovasc Dis. 2001;11 Suppl:155-59. No original empirical evidence presented.
Kaste M, Overgaard K, del Zoppo G, et al. Who benefits and who suffers from iv recombinant tissue plasminogen activator (rt-PA) in ischemic hemispheric stroke. Subgroup analyses of ECASS. Stroke. 1996;27(1):164. No intervention of interest studied.
Katz SG, Kohl RD. Does the choice of material influence early morbidity in patients undergoing carotid patch angioplasty?. Surgery. 1996;119(3):297-301. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8619185].
Katzan IL, Hammer MD, Furlan AJ, et al. Quality improvement and tissue-type plasminogen activator for acute ischemic stroke: a Cleveland update. Stroke. 2003;34(3):799-800. No intervention of interest studied. [pmid: 12624312].
Katzan IL, Graber TM, Furlan AJ, et al. Cuyahoga County Operation Stroke speed of emergency department evaluation and compliance with National Institutes of Neurological Disorders and Stroke time targets. Stroke. 2003;34(4):994-998. No intervention of interest studied. [pmid: 12624218].
Katzman R, Clasen R, Klatzo I, et al. Report of Joint Committee for Stroke Resources. IV. Brain edema in stroke. [Review] [290 refs]. Stroke. 1977;8(4):512-540. No human participants. [pmid: 197665].
Kawiak W, Fidor A, Grabarz B. The influence of glucose loading on the content of free fatty acids in blood of patients with cerebral infarction and with acute transient circulatory cerebral insufficiency. Annales Universitatis Mariae Curie-Sklodowska - Sectio d - Medicina 1992;47147–151. No intervention of interest studied.
Kawiak W, Pilarczyk M, Chmielewska B et al. The effect of piracetam on the content of glucose in the blood of patients with cerebral infarction at the very early stage of the illness. Annales Universitatis Mariae Curie-Sklodowska - Sectio d - Medicina 1992;47153–156. No intervention of interest studied.
Kelley RE. Thrombolytic therapy for acute ischemic stroke. [Review] [17 refs]. J La State Med Soc. 2000;152(5):253-258. No human participants. [pmid: 10875215].
Kendall MJ. Hypertension in the elderly. Basic Res Cardiol. 1998;93 Suppl:243-46. No original empirical evidence presented.
Kennedy J, Buchan AM. Acute Neurovascular Syndromes: Hurry Up, Please, It"s Time. Stroke. 2004;35(2):360-362. No original empirical evidence presented. [pmid: 14757879].
Kennedy J, Buchan AM, Barnett HJ. Thrombolysis must be considered after stroke.[comment]. BMJ. 2001;323(7318):937. No original empirical evidence presented.
Kennedy J, Ma C, Buchan AM. Organization of regional and local stroke resources: methods to expedite acute management of stroke. [Review] [65 refs]. Current Neurology & Neuroscience Reports. 2004;4(1):13-18. No original empirical evidence presented. [pmid: 14683622].
Kennedy MS, Ferri RS, Sofer D. tPA after stroke: the sooner the better: clinical benefit is gone by six hours. AJN, American Journal of Nursing. 2004;104(6):18. Unable to obtain by final date for inclusion.
Kent DM, Ruthazer R, Selker HP. Are some patients likely to benefit from recombinant tissue-type plasminogen activator for acute ischemic stroke even beyond 3 hours from symptom onset?. Stroke. 2003;34(2):464-467. No original empirical evidence presented. [pmid: 12574561].
Kent DMH. In acute ischemic stroke, are asymptomatic intracranial hemorrhages clinically innocuous?. Stroke. 2004;35(5):1141-1146. No original empirical evidence presented. [pmid: 15087567].
Kent TA, Soukup VM, Fabian RH. Heterogeneity affecting outcome from acute stroke therapy: making reperfusion worse. [Review] [169 refs]. Stroke. 2001;32(10):2318-2327. No original empirical evidence presented. [pmid: 11588320].
Kernan WN. Re: Evaluation of acute candesartan cilexetil therapy in stroke survivors.[comment]. Stroke. 2003;34(12):e237-e238. No original empirical evidence presented.
Kida Y, Kobayashi T, Mori Y. Radiosurgery of angiographically occult vascular malformations. [Review] [25 refs]. Neurosurg Clin N Am. 1999;10(2):291-303. No original empirical evidence presented. [pmid: 10099094].
Kidwell CS, Saver JL, Mattiello J, et al. Thrombolytic reversal of acute human cerebral ischemic injury shown by diffusion/perfusion magnetic resonance imaging. Ann Neurol. 2000;47(4):462-469. No intervention of interest studied. [pmid: 10762157].
Kidwell CS, Saver JL, Mattiello J, et al. Diffusion-perfusion MRI characterization of post-recanalization hyperperfusion in humans. Neurology. 2001;57(11):2015-2021. No intervention of interest studied. [pmid: 11739819].
Kidwell CS, Saver JL, Schubert GB, et al. Design and retrospective analysis of the Los Angeles Prehospital Stroke Screen (LAPSS). Prehosp.Emerg Care. 1998;2(4):267-273. No intervention of interest studied. [pmid: 9799012].
Kidwell CS, Shephard T, Tonn S, et al. Establishment of primary stroke centers: a survey of physician attitudes and hospital resources. Neurology. 2003;60(9):1452-1456. No human participants. [pmid: 12743230].
Kikuchi H, Yamaguchi T, Hiroshi ABE, et al. Thrombolytic Therapy of SM-9527 (Duteplase; rt-PA) in Hyperacute Embolic Stroke. The clinical efficacy and safety of thrombolytic agent in a randomized double-blind study. Rinsho Hyoka (Clinical Evaluation). 1994;22(1):105-139. No intervention of interest studied.
Kilbride C. Stroke treatment for everyone: the team approach. International Journal of Therapy & Rehabilitation. 2003;10(6):246. No original empirical evidence presented.
Kim S. [Scope]. [Review] [4 refs] [Japanese]. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2004;62 Suppl:3644-647. Unable to obtain by final date for inclusion.
King DF, Trouth AJ, Adams AO. Factors preventing African Americans from seeking early intervention in the treatment of ischemic strokes. J Natl Med Assoc. 2001;93(2):43-46. No intervention of interest studied. [pmid: 12653381]. [pmcid: 2640632].
Kinoshita T, Okudera T, Tamura H, et al. Assessment of lacunar hemorrhage associated with hypertensive stroke by echo-planar gradient-echo T2*-weighted MRI. Stroke. 2000;31(7):1646-1650. No intervention of interest studied. [pmid: 10884467].
Kirby RL. Rehabilitation and stroke. CMAJ Canadian Medical Association Journal. 1999;160(6):784-785. No human participants.
Kisly CA. Striking back at stroke. Hospitals. 1973;47(22):64-72. No original empirical evidence presented. [pmid: 4747614].
Kissela B, Broderick J, Woo D, et al. Greater Cincinnati/Northern Kentucky Stroke Study: volume of first-ever ischemic stroke among blacks in a population-based study. Stroke. 2001;32(6):1285-1290. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11387488].
Kjeldsen SE, Fossum E, Reims HM, et al. Hypertension treatment and stroke prevention. Blood Press. 2003;12(56):264-268. No original empirical evidence presented. [pmid: 14763656].
Kleiman CS. Assisting the stroke patient. Dent Assist J. 1981;50(3):22-23. No human participants.
Klijn CJ, Hankey GJ. American Stroke, et al. Management of acute ischaemic stroke: new guidelines from the American Stroke Association and European Stroke Initiative. [Review] [6 refs]. Lancet. 2003;2(11):698-701. No original empirical evidence presented.
Knapp P, Young J, House A, et al. Non-drug strategies to resolve psycho-social difficulties after stroke. [Review] [26 refs]. Age & Ageing. 2000;29(1):23-30. No original empirical evidence presented. [pmid: 10690691].
Kobayashi S, Okada K, Koide H, et al. Subcortical silent brain infarction as a risk factor for clinical stroke. Stroke. 1997;28(10):1932-1939. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9341698].
Koennecke HC, Nohr R, Leistner S, et al. Intravenous tPA for ischemic stroke team performance over time, safety, and efficacy in a single-center, 2-year experience. Stroke. 2001;32(5):1074-1078. No intervention of interest studied. [pmid: 11340212].
Kohara K, Igase M, Yinong J, et al. Asymptomatic cerebrovascular damages in essential hypertension in the elderly. Am J Hypertens. 1997;10(8):829-835. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9270076].
Koller RL, Anderson DC. Intravenous thrombolytic therapy for acute ischemic stroke. Weighing the risks and benefits of tissue plasminogen activator. [Review] [10 refs]. Postgrad Med. 1998;103(4):221-224. No original empirical evidence presented. [pmid: 9553597].
Koops L, Lindley RI. Thrombolysis for acute ischaemic stroke: consumer involvement in design of new randomised controlled trial.[see comment]. BMJ. 2002;325(7361):415. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12193356]. [pmcid: 119434].
Koudstaal PJ, van Gijn J, Frenken CW, et al. TIA, RIND, minor stroke: a continuum, or different subgroups? Dutch TIA Study Group. Journal of Neurology, Neurosurgery & Psychiatry. 1992;55(2):95-97. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Koutlas E, Rudolf J, Grivas G, et al. Factors influencing the pre- and in-hospital management of acute stroke - Data from a Greek tertiary care hospital. Eur Neurol. 2004;51(1):35-37. No intervention of interest studied. [pmid: 14685017].
Krespi Y, Gurol ME, Coban O, et al. Stroke unit versus neurology ward--a before and after study. J Neurol. 2003;250(11):1363-1369. No intervention of interest studied. [pmid: 14648154].
Krieger DW, De Georgia MA, Abou-Chebl A, et al. Cooling for acute ischemic brain damage (cool aid): an open pilot study of induced hypothermia in acute ischemic stroke. Stroke. 2001;32(8):1847-1854. No intervention of interest studied. [pmid: 11486115].
Krieger DW, Demchuk AM, Kasner SE, et al. Early clinical and radiological predictors of fatal brain swelling in ischemic stroke. Stroke. 1999;30(2):287-292. No intervention of interest studied. [pmid: 9933261].
Kristensen BO, Lindsten H, Malm J, et al. [Hemicraniectomy in malignant mid-cerebral infarction. Further trials needed before its acceptance in clinical practice]. [Swedish]. Lakartidningen. 3–11. 1998;95(11):1145-1148. Non-English publication. [pmid: 9542824].
Krogsgaard AR, McNair A, Hilden T, et al. Reversibility of cerebral symptoms in severe hypertension in relation to acute antihypertensive therapy. Danish Multicenter Study. Acta Med Scand. 1986;220(1):25-31. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 3532694].
Krueger K, Kugel H, Grond M, et al. Late resolution of diffusion-weighted MRI changes in a patient with prolonged reversible ischemic neurological deficit after thrombolytic therapy. Stroke. 2000;31(11):2715-2718. No intervention of interest studied. [pmid: 11062299].
Kunnel B, Heller M. Thrombolytics and stroke: what do emergency medicine residents perceive?. Acad Emerg Med. 1999;6(11):1174-1176. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10569393].
Kupersmith MJ, Vargas ME, Yashar A, et al. Occipital arteriovenous malformations: visual disturbances and presentation.[see comment]. Neurology. 1996;46(4):953-957. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8780071].
Kuramoto K, Matsushita S, Kuwajima I. The pathogenetic role and treatment of elderly hypertension. Jpn Circ J. 1981;45(7):833-843. No original empirical evidence presented. [pmid: 7265455].
Kwan J, Hand P, Sandercock P. A systematic review of barries to delivery of thrombolysis for acute stroke. Age & Ageing. 2004;33(2):116-121. No original empirical evidence presented. [pmid: 14960425].
Kwan J, Sandercock P. In-hospital care pathways for stroke: A cochrane systematic review. Stroke. 2003;34(2):587-588. No original empirical evidence presented. [pmid: 12574581].
Kwan J, Hand P, Sandercock P. Improving the efficiency of delivery of thrombolysis for acute stroke: a systematic review. [Review] [39 refs]. QJM. 2004;97(5):273-279. Unable to obtain by final date for inclusion. [pmid: 15100420].
Kwiatkowski TG, Libman RB, Frankel M, et al. Effects of tissue plasminogen activator for acute ischemic stroke at one year. National Institute of Neurological Disorders and Stroke Recombinant Tissue Plasminogen Activator Stroke Study Group.[see comment]. N Engl J Med. 1999;340(23):1781-1787. No intervention of interest studied. [pmid: 10362821].
Labiche LA, Al Senani F, Wojner AW, et al. Is the benefit of early recanalization sustained at 3 months? A prospective cohort study. Stroke. 2003;34(3):695-698. No intervention of interest studied. [pmid: 12624293].
LaCombe DM, Gordon DL, Issenberg SB, et al. Stroke on the mend.[see comment]. J Emerg Med Serv JEMS. 2000;25(10):32-41. No original empirical evidence presented.
Laloux P. [Medical treatment for cerebral atherothrombosis]. [Review] [27 refs] [French]. J Pharm Belg. 2004;59(1):35-37. Unable to obtain by final date for inclusion. [pmid: 15129578].
LaMonte MP, Bahouth MN, Hu P, et al. Telemedicine for acute stroke: triumphs and pitfalls. Stroke. 2003;34(3):725-728. No intervention of interest studied. [pmid: 12624298].
Landahl S, Lernfelt B. Cardiac function and cerebral blood flow in elderly hypertensive patients. Nephron 1990;55 Suppl 198. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Lang W, Domanovits H, Gorzer H et al. Thrombolysis in acute ischemic stroke. Acta Anaesthesiol Scand 1997;Supplementum. 11134–37. No original empirical evidence presented.
Langhorne P. Editorial comment--Early supported discharge: an idea whose time has come?[comment]. Stroke. 2003;34(11):2691-2692. No original empirical evidence presented. [pmid: 14576365].
Langhorne P. Developing comprehensive stroke services: an evidence-based approach. Postgrad Med J. 1995;71(842):733-737. No human participants. [pmid: 8552537]. [pmcid: 2398274].
Langhorne P, Cadilhac D, Feigin V, et al. How should stroke services be organised? [Review] [45 refs]. Lancet. 2002;1(1):62-68. No original empirical evidence presented.
Langhorne P, Dennis MS. Stroke units: the next 10 years. Lancet. 2004;363(9412):834-835. No original empirical evidence presented. [pmid: 15031023].
Langhorne P, Pollock A. What are the components of effective stroke unit care?. Age & Ageing. 2002;31(5):365-371. No original empirical evidence presented. [pmid: 12242199].
Langhorne P, Tong BL, Stott DJ. Association between physiological homeostasis and early recovery after stroke. Stroke. 2000;31(10):2518-2519. No original empirical evidence presented. [pmid: 11022093].
Langhorne P, Williams BO, Gilchrist W, et al. A formal overview of stroke unit trials. Rev Neurol. 1995;23(120):394-398. No original empirical evidence presented. [pmid: 7497198].
Langhorne P, Williams BO, Gilchrist W, et al. Do stroke units save lives?[see comment]. Lancet. 1993;342(8868):395-398. No original empirical evidence presented. [pmid: 8101901].
Lansberg MG, Tong DC, Norbash AM, et al. Intra-arterial rtPA treatment of stroke assessed by diffusion- and perfusion-weighted MRI. Stroke. 1999;30(3):678-680. No intervention of interest studied. [pmid: 10066870].
Lapchak PA. Development of thrombolytic therapy for stroke: a perspective. [Review] [72 refs]. Expert Opin Investig Drugs. 2002;11(11):1623-1632. No original empirical evidence presented.
Lapchak PA, Araujo DM. Development of the nitrone-based spin trap agent NXY-059 to treat acute ischemic stroke. [Review] [59 refs]. CNS Drug Rev. 2003;9(3):253-262. No human participants. [pmid: 14530797].
Larkin M. Heart association urges passage of US stroke legislation. Lancet Neurology. 2004;3(5):260. Unable to obtain by final date for inclusion. [pmid: 15132139].
Larrue V, von Kummer R, del Zoppo G, et al. Hemorrhagic transformation in acute ischemic stroke. Potential contributing factors in the European Cooperative Acute Stroke Study. Stroke. 1997;28(5):957-960. No original empirical evidence presented. [pmid: 9158632].
Launois R, Giroud M, Megnigbeto AC, et al. Estimating the cost-effectiveness of stroke units in France compared with conventional care. Stroke. 2004;35(3):770-775. No intervention of interest studied. [pmid: 14976321].
Lavine SD, Masri LS, Levy ML, et al. Temporary occlusion of the middle cerebral artery in intracranial aneurysm surgery: time limitation and advantage of brain protection. J Neurosurg. 1997;87(6):817-824. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9384389].
Le Roux, PD Newell, DW Lam et al. Cerebral arteriovenous oxygen difference: a predictor of cerebral infarction and outcome in patients with severe head injury.[see comment]. J Neurosurg 1997;87(1):1–8. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Leary MC, Saver JL, Gobin YP, et al. Beyond tissue plasminogen activator: mechanical intervention in acute stroke. [Review] [32 refs]. Ann Emerg Med. 2003;41(6):838-846. No original empirical evidence presented. [pmid: 12764340].
Lee K. Aneurysm precautions: a physiologic basis for minimizing rebleeding. Heart & Lung: Journal of Acute & Critical Care. 1980;9(2):336-343. No human participants.
Lee KH, Cho SJ, Byun HS, et al. Triphasic perfusion computed tomography in acute middle cerebral artery stroke: a correlation with angiographic findings. Arch Neurol. 2000;57(7):990-999. No intervention of interest studied. [pmid: 10891981].
Lee SH, Bae HJ, Yoon BW, et al. Low concentration of serum total cholesterol is associated with multifocal signal loss lesions on gradient-echo magnetic resonance imaging: analysis of risk factors for multifocal signal loss lesions. Stroke. 2002;33(12):2845-2849. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12468780].
Lee TM, Ho DS, Chan CC. Preliminary neuropsychological outcomes of angioplasty and stenting of extracranial cerebral arteries. Perceptual & Motor Skills. 1999;88(1):267-270. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10214653].
Leeman M, Naeije R, Degaute JP, et al. Acute central and renal haemodynamic responses to tertatolol and propranolol in patients with arterial hypertension following head injury. J Hypertens. 1986;4(5):581-587. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 2878953].
Lees KR. Therapeutic interventions in acute stroke. [Review] [92 refs]. Br J Clin Pharmacol. 1992;34(6):486-493. No original empirical evidence presented. [pmid: 1493080]. [pmcid: 1381449].
Lees KR, Dyker AG. Blood pressure control after acute stroke. [Review] [22 refs]. Journal of Hypertension - Supplement. 1996;14(6):S35-S38. No original empirical evidence presented.
Lees KR, Dyker AG, Dykes AG. Diagnosis and therapeutic aspects of stroke.[erratum appears in Neth J Med 1996 Mar;48(3):123 Note: Dykes AG[corrected to Dyker AG]]. [Review] [22 refs]. Neth J Med. 1995;47(4):195-198. No original empirical evidence presented. [pmid: 8538824].
Lehmann A, Van Gelder NM, Anders C C. Hamberger: A man of all seasons. Neurochem Res. 2003;28(2):171-172. No human participants.
Lemieux-Charles L, McGuire W, Blidner I. Building interorganizational knowledge for evidence-based health system change.[see comment]. Health Care Manage Rev. 2002;27(3):48-59. No human participants. [pmid: 12146783].
Lenzer J. Controversial stroke trial is under review following BMJ report.[comment]. BMJ. 2002;325(7373):1131. No original empirical evidence presented. [pmid: 12433750].
Lenzer J. Alteplase for stroke: money and optimistic claims buttress the “brain attack” campaign.[see comment]. [Review] [54 refs]. BMJ. 2002;324(7339):723-729. No original empirical evidence presented. [pmid: 11909792]. [pmcid: 1122648].
Lenzi GL, Argentino C. SPREADing the stroke units? PROSIT!. Shinkei Kenkyu No Shimpo 2004;25(1). No original empirical evidence presented.
Leonard AD, Brey RL. Patient page. Blood pressure control and stroke: an ounce of prevention is worth a pound of cure.[original report in Neurology. 2002 Jul 9;59(1):23–5; PMID: 12105296]. Neurology. 2002;59(1):E1-E2. No human participants. [pmid: 12105335].
Lepore MRJ, Sternbergh WC, Salartash K, et al. Influence of NASCET/ACAS trial eligibility on outcome after carotid endarterectomy. Eur J Vasc Surg. 2001;34(4):581-586. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Levi CR. Australasian Stroke, Unit Network, et al. Tissue plasminogen activator (tPA) in acute ischaemic stroke: time for collegiate communication and consensus. Med J Aust. 6–21. 2004;180(12):634-636. Unable to obtain by final date for inclusion. [pmid: 15200362].
Levine SR, Brott TG. Thrombolytic therapy in cerebrovascular disorders. [Review] [231 refs]. Prog Cardiovasc Dis. 1992;34(4):235-262. No original empirical evidence presented. [pmid: 1728786].
Levine SR, Gorman M. “Telestroke” : the application of telemedicine for stroke. [Review] [74 refs]. Stroke. 1999;30(2):464-469. No original empirical evidence presented. [pmid: 9933289].
Levy DE, Brott TG, Haley ECJ, et al. Factors related to intracranial hematoma formation in patients receiving tissue-type plasminogen activator for acute ischemic stroke. Stroke. 1994;25(2):291-297. No intervention of interest studied. [pmid: 8303734].
Lewin A, Blaufox MD, Castle H, et al. Apparent prevalence of curable hypertension in the Hypertension Detection and Follow-up Program. Arch Intern Med. 1985;145(3):424-427. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 3872106].
Leys D, Kwiecinski H, Bogousslavsky J, et al. Prevention. European Stroke Initiative. Cerebrovasc Dis. 2004;17 Suppl:215-29. No original empirical evidence presented.
Liapis CD, Kakisis JD, Kostakis AG. Carotid stenosis: factors affecting symptomatology.[see comment]. Stroke. 2001;32(12):2782-2786. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11739973].
Libman RB, Wirkowski E, Alvir J, et al. Conditions that mimic stroke in the emergency department. Implications for acute stroke trials.[see comment]. Arch Neurol. 1995;52(11):1119-1122. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7487564].
Liebson PR. VISP and INVEST. Prev Cardiol. 2004;7(2):93-96. Unable to obtain by final date for inclusion. [pmid: 15133377].
Lin TCC. Impact of the high-risk and mass strategies on hypertension control and stroke mortality in primary health care. J Hum Hypertens. 2004;18(2):97-105. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14730324].
Lin CS, Tsai J, Woo P, et al. Prehospital delay and emergency department management of ischemic stroke patients in Taiwan, R.O.C. Prehosp Emerg Care. 1999;3(3):194-200. [pmid: 10424855].
Lindley RI. Further randomized controlled trials of tissue plasminogen activator within 3 hours are required. Stroke. 2001;32(11):2708-2709. No original empirical evidence presented. [pmid: 11692040].
Lindley RI. Drug therapy for acute ischaemic stroke: risks versus benefits. [Review] [40 refs]. Drug Saf. 1998;19(5):373-382. No original empirical evidence presented. [pmid: 9825950].
Lindsberg PJ, Kaste M. Thrombolysis for acute stroke. [Review] [41 refs]. Curr Opin Neurol. 2003;16(1):73-80. No original empirical evidence presented. [pmid: 12544860].
Lindsberg PJ, Soinne L, Roine RO, et al. Community-based thrombolytic therapy of acute ischemic stroke in Helsinki. Stroke. 2003;34(6):1443-1449. No intervention of interest studied. [pmid: 12738891].
Linfante I, Hirsch JA, Selim M, et al. Safety of Latest-Generation Self-expanding Stents in Patients with NASCET-Ineligible Severe Symptomatic Extracranial Internal Carotid Artery Stenosis. Arch Neurol. 2004;61(1):39-43. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14732618].
Linfante I, Llinas RH, Selim M, et al. Clinical and vascular outcome in internal carotid artery versus middle cerebral artery occlusions after intravenous tissue plasminogen activator. Stroke. 2002;33(8):2066-2071. No intervention of interest studied. [pmid: 12154264].
Link J, Manke C, Rosin L, et al. [Carotid endarterectomy and carotid stenting. A pilot study of a prospective, randomized and controlled comparison]. [German]. Radiologe. 2000;40(9):813-820. Non-English publication. [pmid: 11056973].
Lip GY, Beevers DG. ACE inhibitors in vascular disease: some PROGRESS, more HOPE. [Review] [10 refs]. J Hum Hypertens. 2001;15(12):833-835. No original empirical evidence presented. [pmid: 11773984].
Lisboa RC, Jovanovic BD, Alberts MJ. Analysis of the safety and efficacy of intra-arterial thrombolytic therapy in ischemic stroke. Stroke. 2002;33(12):2866-2871. No original empirical evidence presented. [pmid: 12468783].
Lisk DR, Grotta JC, Lamki LM, et al. Should hypertension be treated after acute stroke? A randomized controlled trial using single photon emission computed tomography. Arch Neurol. 1993;50(8):855-862. No intervention of interest studied. [pmid: 8352673].
Liu L, Gong L, Guang WJ, et al. Blood pressure lowering in patients with cerebrovascular disease: results of the randomized Post-stroke Antihypertensive Treatment Study (PATS). J Am Coll Cardiol. 1998;31(Suppl 2A):211A. [defined as adult (>16) with acute stroke].
Liu L, Wang JG, Celis H, et al. Implications of the Systolic Hypertension in China trial. [Review] [10 refs]. Clinical & Experimental Hypertension (New York). 1999;21(56):499-505. No original empirical evidence presented.
Liu M, Wardlaw J. Thrombolysis (different doses, routes of administration and agents) for acute ischaemic stroke. [Review][11 refs]. Cochrane Database Syst Rev 2000;(2):CD000514. No original empirical evidence presented.
Liu BY, Li XQ, Chen CH. [Effects of nao-yi-an on tumor necrosis factor alpha and insulin resistance of acute intracerebral hemorrhagic patients]. [Chinese]. Hunan Yi Ke Da Xue Xue Bao. 2–28. 2002;27(1):41-42. Non-English publication. [pmid: 12575232].
Livingston S. NSF for older people: (4) Stroke. Can Pharm J. 2003;270(7256):19-21. No original empirical evidence presented.
Livingston S. NSF for older people: (1) What does the NSF for older people mean for pharmacy practice?. Can Pharm J. 2003;270(7253):830-832. No original empirical evidence presented.
Longstreth WT, Tirschwell DL. The next 30 years of stroke for patients, providers, planners, and politicians. Stroke. 2003;34(9):2113N. o human participants. [pmid: 12920266].
Lorencowicz R, Zderkiewicz E. [Problems of patient care after surgical treatment for intracranial aneurysm with regard to independent living at home]. [Polish]. Pol Merkuriusz Lek. 1997;2(10):247-249. Non-English publication.
Losito A, Gaburri M, Errico R, et al. Survival of patients with renovascular disease and ACE inhibition. Clin Nephrol. 1999;52(6):339-343. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10604640].
Loulidi J, Sztajzel R. [Cerebrovascular accident: a medical emergency]. [Review] [26 refs] [French]. Rev Med Suisse Romande. 2003;123(1):5-9. Unable to obtain by final date for inclusion. [pmid: 15095720].
Lu SR, Liao YC, Fuh JL, et al. Nimodipine for treatment of primary thunderclap headache. Neurology. 4–27. 2004;62(8):1414-1416. Unable to obtain by final date for inclusion. [pmid: 15111686].
Luders S, Effenberger K, Venneklaas U, et al. ACCESS-study: acute candesartan cilexetil evaluation in stroke survivors. Dtsch Med Wochenschr. 1999;124(Suppl 3):S119. No intervention of interest studied.
Luepker RV, Rastam L, Hannan PJ, et al. Community education for cardiovascular disease prevention. Morbidity and mortality results from the Minnesota Heart Health Program. Am J Epidemiol. 1996;144(4):351-362. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8712192].
Luisi A, Hume AL. Thrombolysis in acute ischemic stroke.[see comment]. [Review] [20 refs]. J Am Board Fam Pract. 1998;11(2):145-151. No original empirical evidence presented. [pmid: 9542706].
Lyden P. Lingual angioedema, ACE inhibitors, and tPA: Commentary. Neurology. 2003;60(9):1403U. nable to obtain by final date for inclusion.
Lyden P. Pilot study of tenecteplase (TNK) in acute ischaemic stroke: preliminary report. Stroke. 2003;34(1):246. No intervention of interest studied.
Lyden P. the CLASS, IHT Investigators. Combined clomethiazole and tPA for acute stroke in TACS patients - CLASS-T functional outcome results. Stroke. 2000;31(11):2864N. o intervention of interest studied.
Lyden P. the CLASS, IHT Investigators. Effect of combined clomethiazole and tPA for acute stroke on CT outcomes: edema, hemorrhage and hematoma volume in CLASS-T. Stroke. 2000;31(11):2886-2887. No intervention of interest studied.
Lyden P, Lu M, Jackson C, et al. Underlying structure of the National Institutes of Health Stroke Scale: results of a factor analysis. NINDS tPA Stroke Trial Investigators. Stroke. 1999;30(11):2347-2354. No intervention of interest studied. [pmid: 10548669].
Lyden P, Lu M, Kwiatkowski T, et al. Thrombolysis in patients with transient neurologic deficits. Neurology. 2001;57(11):2125-2128. No intervention of interest studied. [pmid: 11739841].
Lyden P, Shuaib A, Ng K, et al. Clomethiazole Acute Stroke Study in ischemic stroke (CLASS-I): final results.[see comment]. Stroke. 2002;33(1):122-128. No intervention of interest studied. [pmid: 11779900].
Lyden PD. Further randomized controlled trials of tPA within 3 hours are required-not!. Stroke. 2001;32(11):2709-2710. No original empirical evidence presented. [pmid: 11692041].
Lyden PD, the CLASS, IHT Investigators. Safety and efficacy of combined clomethiazole and tPA for acute stroke - CLASS-T: a pilot study. Neurology 2000;54(Suppl 3). No intervention of interest studied.
Mackenzie AF, Colvin Kenny, Bisset GN, et al. Closed loop control of arterial hypertension following intracranial surgery using sodium nitroprusside. A comparison of intra-operative halothane or isoflurane. Anaesthesia. 1993;48(3):202-204. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8460795].
Macko RF, Kittner SJ, Ivey FM, et al. Effects of vitamin therapy on plasma total homocysteine, endothelial injury markers, and fibrinolysis in stroke patients. Journal of Stroke & Cerebrovascular Diseases. 2002;11(1):1-8. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 17903848].
MacMahon S. Will ACE inhibitor therapy reduce secondary stroke?. Cardiovascular Journal of Southern Africa. 2000;12(1):53-54. No original empirical evidence presented.
Madden K. Optimal timing of thrombolytic therapy in acute ischaemic stroke.[see comment]. [Review] [26 refs]. CNS Drugs. 2002;16(4):213-218. No original empirical evidence presented. [pmid: 11945105].
Madhavan R, Chaturvedi S. Transient ischaemic attacks : new approaches to management. [Review] [54 refs]. CNS Drugs. 2003;17(5):293-305. No original empirical evidence presented. [pmid: 12665389].
Madhavan R, Jacobs BS, Levine SR. Stroke trials: what have we learned? [Review] [24 refs]. Neurol Res. 2002;24 Suppl:1S27-S32. No original empirical evidence presented.
Mahaffey KW, Harrington RA, Simoons ML, et al. Stroke in patients with acute coronary syndromes: incidence and outcomes in the platelet glycoprotein IIb/IIIa in unstable angina. Receptor suppression using integrilin therapy (PURSUIT) trial. The PURSUIT Investigators. Circulation. 1999;99(18):2371-2377. No intervention of interest studied. [pmid: 10318656].
Mahla K, Rizk T, Fischer C, et al. [Intracranial cavernoma. Surgical results of 47 cases]. [French]. Neurochirurgie. 1999;45(4):286-292. Non-English publication. [pmid: 10599056].
Mahon BR, Nesbit GM, Barnwell SL, et al. North American clinical experience with the EKOS MicroLysUS infusion catheter for the treatment of embolic stroke. AJNR Am J Neuroradiol. 2003;24(3):534-538. No original empirical evidence presented. [pmid: 12637311].
Mancia G, Brown M, Castaigne A, et al. Outcomes with nifedipine GITS or Co-amilozide in hypertensive diabetics and nondiabetics in Intervention as a Goal in Hypertension (INSIGHT).[see comment]. Hypertension. 2003;41(3):431-436. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12623939].
Manelfe C, Larrue V, von Kummer R, et al. Association of hyperdense middle cerebral artery sign with clinical outcome in patients treated with tissue plasminogen activator. Stroke. 1999;30(4):769-772. No intervention of interest studied. [pmid: 10187877].
Mann H. Thrombolysis for acute ischaemic stroke. Trial participants need to be informed of uncertainty principle.[comment]. BMJ. 2002;325(7376):1363. No original empirical evidence presented.
Mann J. Truths about the NINDS study: setting the record straight. West J Med. 2002;176(3):192-194. No original empirical evidence presented. [pmid: 12016245]. [pmcid: 1071714].
Manor DE, Richardson LD. Shen. Assessing urban community knowledge of acute stroke: results with a culturally sensitive instrument. Acad Emerg Med. 2003;10(5):490-491. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Mant J, Carter J, Wade DT, et al. The impact of an information pack on patients with stroke and their carers: a randomized controlled trial. Clin Rehabil. 1998;12(6):465-476. No intervention of interest studied. [pmid: 9869250].
Manzella SM, Galante K. Establishment of stroke treatment plans: one hospital"s experience. J Neurosci Nurs. 2000;32(6):306-310. No original empirical evidence presented. [pmid: 11155344].
Marder VJ, Stewart D. Towards safer thrombolytic therapy. [Review] [106 refs]. Semin Hematol. 2002;39(3):206-216. No original empirical evidence presented. [pmid: 12124683].
Mariak ZA. [In Process Citation]. Neurol Neurochir Pol. 2004;38(1):51-54. Non-English publication. [pmid: 15049169].
Marks MP, Holmgren EB, Fox AJ, et al. Evaluation of early computed tomographic findings in acute ischemic stroke. Stroke. 1999;30(2):389-392. No intervention of interest studied. [pmid: 9933276].
Marks MP, Tong DC, Beaulieu C, et al. Evaluation of early reperfusion and i.v. tPA therapy using diffusion- and perfusion-weighted MRI.[see comment]. Neurology. 1999;52(9):1792-1798. No intervention of interest studied. [pmid: 10371525].
Markus HS, Clifton A, Buckenham T, et al. Improvement in cerebral hemodynamics after carotid angioplasty. Stroke. 1996;27(4):612-616. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8614916].
Marler Brott T, Haley EC, Levy D. Evaluation of tissue plasminogen activator early in the course of acute ischemic stroke. Thrombolytic Therapy in Acute Ischemic Stroke Berlin. Springer-Verlag. 1991;1st ed.:152-160p. No intervention of interest studied.
Marler Goldstein LB. Medicine. Stroke--tPA and the clinic. Science. 2003;301(5640):1677. No original empirical evidence presented. [pmid: 14500967].
Marshall RS, Rundek T, Sproule DM, et al. Monitoring of cerebral vasodilatory capacity with transcranial Doppler carbon dioxide inhalation in patients with severe carotid artery disease. Stroke. 2003;34(4):945-949. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12624217].
Martin BJ, Yip B, Hearty M, et al. Outcome, functional recovery and unmet needs following acute stroke. Experience of patient follow up at 6 to 9 months in a newly established stroke service. Scott Med J. 2002;47(6):136-137. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12616970].
Martin JB, Pache JC, Treggiari-Venzi M, et al. Role of the distal balloon protection technique in the prevention of cerebral embolic events during carotid stent placement. Stroke. 2001;32(2):479-484. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11157186].
Martin JF, Hamdy N, Nicholl J, et al. Double-blind controlled trial of prostacyclin in cerebral infarction. Stroke. 1985;16(3):386-390. No intervention of interest studied. [pmid: 3890279].
Masten Y, Gary A. Is anyone listening? Does anyone care? Menopausal and postmenopausal health risks, outcomes, and care. [Review] [20 refs]. Nurse Pract Forum. 1999;10(4):195-200. No human participants. [pmid: 10776259].
Matias-Guiu J, Molto JM, Galiano L, et al. Pilot double blind placebo controlled trial of nicardipine versus placebo for cognitive impairment in minor stroke patients. J Neurol. 1992;239(Suppl 2):39. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 1541968].
Matsumoto M. [Cerebrovascular disease: Impact of INDANA meta-analysis and PROGRESS trial]. [Review] [18 refs] [Japanese]. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2004;62 Suppl:3605-611. Unable to obtain by final date for inclusion.
Matthews PM. Finding Landmarks for Understanding White Matter Stroke. Stroke. 2004;35(1):92-93. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14699170].
Maxwell MH, Ford CE. Cardiovascular morbidity and mortality in HDFP patients 50–69 years old at entry. J Cardiovasc Pharmacol. 1985;7 Suppl:2S5-S9. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Maze LM, Bakas T. Factors associated with hospital arrival time for stroke patients. J Neurosci Nurs. 6–20. 0155;36(3):136-141. Unable to obtain by final date for inclusion.
Mazouz H, Makdassi R, Tribouilloy C, et al. Risk reduction for stroke and coronary events.[comment]. Lancet. 2002;359(9313):1249-1250. No original empirical evidence presented.
Mc GR, Rudd A. Management of stroke. [Review] [58 refs]. Postgrad Med J. 2003;79(928):87-92. No original empirical evidence presented. [pmid: 12612323]. [pmcid: 1742605].
McAlister FA. Primary prevention of heart disease and stroke.[comment]. CMAJ Canadian Medical Association Journal. 1998;158(1):24-25. No human participants.
McAlister FA, Zarnke KB, Campbell NR, et al. The 2001 Canadian recommendations for the management of hypertension: Part two--Therapy. Can J Cardiol. 2002;18(6):625-641. No original empirical evidence presented. [pmid: 12107420].
McCormack J, Rangno R, Wright JM. Thiazides first-line treatment for hypertension. Can Fam Physician. 2003;49(JULY):879N. o original empirical evidence presented. [pmid: 12901483]. [pmcid: 2214266].
McDonald PS, Mayer P, Dunn L. Adult/elderly care nursing. National Service Framework for Older People: stroke coordinators. Br J Nurs. 2002;11(19):1259-1261. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12419980].
McKernan MG. One-stop shopping: A CT protocol for imaging of acute stroke. Appl Radiol. 2003;32(6 SUPPL.):18-23. No original empirical evidence presented.
McNair A, Krogsgaard AR, Hilden T, et al. Severe hypertension with cerebral symptoms treated with furosemide, fractionated diazoxide or dihydralazine. Danish Multicenter Study. Acta Med Scand. 1986;220(1):15-23. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 3532693].
McNair A, Krogsgaard AR, Hilden T et al. Reversibility of cerebral symptoms in severe hypertension in relation to acute antihypertensive therapy. Danish Multicenter study. Acta Medica Scandinavica - Supplementum 1985;693107–110. Study did not involve relevant population [defined as adult (>16) with acute stroke].
McNaughton H, McPherson K, Taylor W, et al. Relationship between process and outcome in stroke care. Stroke. 2003;34(3):713-717. No intervention of interest studied. [pmid: 12624296].
McPherson KM, Kersten P. Knowledge and action in stroke--are either good enough?. Qual Saf Health Care. 2004;13(3):166-167. Unable to obtain by final date for inclusion. [pmid: 15175482]. [pmcid: 1743852].
Medicare initiates public education re stroke (MAPS). J Med Assoc Ga 1997;86(3):171. No original empirical evidence presented.
Mehler PS, Coll Estacio R, Esler A, et al. Intensive blood pressure control reduces the risk of cardiovascular events in patients with peripheral arterial disease and type 2 diabetes. Circulation. 2003;107(5):753-756. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12578880].
Menapace RH, Lana RE. Physical rehabilitation and attitudes of CVA and pulmonary patients. Psychol Rep. 1971;28(3):763-768. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 5091443].
Mendelow AD, Investigators the, Steering Committee. The International Surgical Trial in Intracerebral Haemorrhage (ISTICH). Acta Neurochir Suppl 2003;86441–443. No intervention of interest studied.
Mendelow AD, Teasdale GM, Barer D, et al. Outcome assignment in the International Surgical Trial of Intracerebral Haemorrhage. [Review] [10 refs]. Acta Neurochir (Wien). 2003;145(8):679-681. No human participants. [pmid: 14520548].
Mendis S. Workshop on secondary prevention of myocardial infarction and stroke and management of cardiovascular risk. Anadolu Kardiyol Derg. 2003;3(4):366-367. No original empirical evidence presented. [pmid: 14675893].
Meredith P. Do pharmacologic differences among antihypertensive agents point to clinical benefits? [Review] [22 refs]. Am J Cardiol. 1999;84(10A):22S-27S. No original empirical evidence presented. [pmid: 10588091].
Merino JG, Silver B, Wong E, et al. Physician knowledge of the benefits, risks, and contraindications of tissue plasminogen activator for acute ischemic stroke. Stroke. 2001;32(9):2208-2209. No original empirical evidence presented.
Merino JG, Silver B, Wong E, et al. Extending tissue plasminogen activator use to community and rural stroke patients. Stroke. 2002;33(1):141-146. No intervention of interest studied. [pmid: 11779903].
Meschia JF, Brott TG. New insights on thrombolytic treatment of acute ischemic stroke. [Review] [36 refs]. Current Neurology & Neuroscience Reports. 2001;1(1):19-25. No original empirical evidence presented. [pmid: 11898496].
Mesotten D, Van den BG. Clinical potential of insulin therapy in critically ill patients. [Review] [86 refs]. Drugs. 2003;63(7):625-636. No human participants. [pmid: 12656643].
Messe SR, Tanne D, Demchuk AM, et al. Dosing Errors May Impact the Risk of rt-PA for Stroke: The Multicenter rt-PA Acute Stroke Survey. Journal of Stroke & Cerebrovascular Diseases. 2004;13(1):35-40. No intervention of interest studied. [pmid: 17903947].
Messerli FH. The LIFE study: the straw that should break the camel's back. Eur Heart J. 2003;24(6):487-489. No original empirical evidence presented. [pmid: 12643877].
Messerli FH, Jacoby DS, Rader DJ. Vascular Protection of ACE Inhibitors [6] (multiple letters). Arch Intern Med. 2003;163(22):2791-2793. No original empirical evidence presented.
Meyer JS, Eadie GA, Ericsson AD, et al. A pilot study of antihypertensive therapy in cerebrovascular disease. J Am Geriatr Soc. 1967;15(4):313-321. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 5335634].
Meyer JS, Rauch GM. Why emergency XeCT-CBF should become routine in acute ischemic stroke before thrombolytic therapy. Keio J Med. 2000;49 Suppl:1A25-A28. No original empirical evidence presented.
Mickey RM, Goodwin GD. The magnitude and variability of design effects for community intervention studies. Am J Epidemiol. 1993;137(1):9-18. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8434577].
Miller JE. Knowledge of stroke risk factors, symptoms, and treatment among New Jersey adults. N J Med. 2001;98(7):47-53. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Miller PR, Fabian TC, Croce MA, et al. Prospective screening for blunt cerebrovascular injuries: analysis of diagnostic modalities and outcomes. Ann Surg. 2002;236(3):386-393. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12192325]. [pmcid: 1422592].
Miller RM, Woo D. Stroke: current concepts of care. [Review] [8 refs]. Geriatr Nurs (Minneap). 1999;20(2):66-69. No original empirical evidence presented.
Minchin A, Wensley M. The medical nurse practitioner"s role in early stroke recognition. Nurs Times. 2003;99(7):33-35. No original empirical evidence presented.
Miranda LS, Turkel RA, Ahmed O, et al. Anticoagulation for stroke prevention in a Medicare population with atrial fibrillation. J Fla Med Assoc. 1997;84(4):227-231. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9342908].
Mitchell. Does aspirin prevent stroke?. Br J Gen Pract. 1979;223(1337):668-672. No original empirical evidence presented.
Mitka M. Efforts needed to foster participation of blacks in stroke studies. JAMA. 2004;291(11):1311-1312. No original empirical evidence presented. [pmid: 15026380].
Mitka M. Tensions Remain over tPA for Stroke. J Am Med Assoc. 2003;289(11):1363-1364. No human participants.
Miyazawa N, Toyama K, Arbab AS, et al. Evaluation of crossed cerebellar diaschisis in 30 patients with major cerebral artery occlusion by means of quantitative I-123 IMP SPECT. Ann Nucl Med. 2001;15(6):513-519. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11831399].
Mohr JP. Thrombolytic therapy for ischemic stroke: from clinical trials to clinical practice.[comment]. JAMA. 2000;283(9):1189-1191. No original empirical evidence presented. [pmid: 10703782].
Molina CA, Alexandrov AV, Demchuk AM, et al. Improving the predictive accuracy of recanalization on stroke outcome in patients treated with tissue plasminogen activator.[see comment]. Stroke. 2004;35(1):151-156. No intervention of interest studied. [pmid: 14671245].
Molina CA, Alvarez-Sabin J, Montaner J, et al. Thrombolysis-related hemorrhagic infarction: a marker of early reperfusion, reduced infarct size, and improved outcome in patients with proximal middle cerebral artery occlusion.[see comment]. Stroke. 2002;33(6):1551-1556. No intervention of interest studied. [pmid: 12052990].
Molina CA, Montaner J, Abilleira S, et al. Time course of tissue plasminogen activator-induced recanalization in acute cardioembolic stroke: a case-control study. Stroke. 2001;32(12):2821-2827. No intervention of interest studied. [pmid: 11739980].
Molina CA, Montaner J, Arenillas JF, et al. Differential pattern of tissue plasminogen activator-induced proximal middle cerebral artery recanalization among stroke subtypes. Stroke. 2004;35(2):486-490. No intervention of interest studied. [pmid: 14707233].
Moloney A, Critchlow B, Jones K. A multi-disciplinary care pathway in stroke - does it improve care? (abstract). Age & Ageing. 1999;28(Suppl 1):42. No intervention of interest studied.
Monitoring your blood pressure. Postgrad Med 1999;105(5):209–210. No original empirical evidence presented.
Monger C, Carr JH, Fowler V. Evaluation of a home-based exercise and training programme to improve sit-to-stand in patients with chronic stroke. Clin Rehabil. 2002;16(4):361-367. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12061469].
Montaner J, Fernandez-Cadenas I, Molina CA, et al. Safety profile of tissue plasminogen activator treatment among stroke patients carrying a common polymorphism (C-1562T) in the promoter region of the matrix metalloproteinase-9 gene. Stroke. 2003;34(12):2851-2855. No intervention of interest studied. [pmid: 14605329].
Montaner J, Molina CA, Monasterio J, et al. Matrix metalloproteinase-9 pretreatment level predicts intracranial hemorrhagic complications after thrombolysis in human stroke. Circulation. 2003;107(4):598-603. No intervention of interest studied. [pmid: 12566373].
Montaner J, Vidal C, Molina C, et al. Selecting the target and the message for a stroke public education campaign: a local survey conducted by neurologists. Eur J Epidemiol. 2001;17(6):581-586. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11949732].
Moonis M. Imaging in acute ischemic stroke : relevance to management. Neurol India. 2002;50 Suppl:S30-S36. No original empirical evidence presented. [pmid: 12665876].
Moore LW, Maiocco G, Schmidt SM, et al. Research for practice. Perspectives of caregivers of stroke survivors: implications for nursing. Medsurg Nurs. 2002;11(6):289-295. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12520977].
Mori E, Lajolla CA, Yoneda Y, et al. Double-blind, placebo-controlled trial of recombinant tissue plasminogen activator (rt-PA) in acute stroke. Neurology. 1991;41(Suppl.1):347. No intervention of interest studied.
Mori E, Yoneda Y, Tabuchi M, et al. Intravenous recombinant tissue plasminogen activator in acute carotid artery territory stroke.[see comment]. Neurology. 1992;42(5):976-982. No intervention of interest studied. [pmid: 1579252].
Morris DC, Silver B, Mitsias P, et al. Treatment of acute stroke with recombinant tissue plasminogen activator and abciximab. Acad Emerg Med. 2003;10(12):1396-1399. No intervention of interest studied. [pmid: 14644794].
Morris DL, Rosamond W, Madden K, et al. Prehospital and emergency department delays after acute stroke: the Genentech Stroke Presentation Survey. Stroke. 2000;31(11):2585-2590. No intervention of interest studied. [pmid: 11062279].
Morris DL, Shah SM, Huff JS. Future trends. [Review] [38 refs]. Emerg Med Clin North Am. 2002;20(3):717-729. No original empirical evidence presented. [pmid: 12379970].
Morrison VL, Johnston M, MacWalter RS, et al. Improving emotional outcomes following acute stroke: a preliminary evaluation of work-book based intervention. Scott Med J. 1998;43(2):52-53. No intervention of interest studied. [pmid: 9717206].
Mosca L. Cardiology patient page. Heart disease prevention in women. American Heart Association. Circulation. 3–16. 2004;109(10):e158-e160. Unable to obtain by final date for inclusion. [pmid: 15023896].
Moser M. No surprises in blood pressure awareness study findings: We can do a better job. Arch Intern Med. 2003;163(6):654-656. No original empirical evidence presented. [pmid: 12639193].
Mountz JM, Liu HG, Deutsch G. Neuroimaging in cerebrovascular disorders: measurement of cerebral physiology after stroke and assessment of stroke recovery. [Review] [46 refs]. Semin Nucl Med. 2003;33(1):56-76. No original empirical evidence presented. [pmid: 12605357].
MRC trial of treatment of mild hypertension: principal results. Medical Research Council Working Party.[see comment]. British Medical Journal Clinical Research Ed 1985;291(6488):97–104. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Muir KW, Lees KR. Initial experience with remacemide hydrochloride in patients with acute ischemic stroke. Ann N Y Acad Sci 1995;765322–323. No intervention of interest studied.
Muir KW, Lees KR, Ford I, et al. Magnesium for acute stroke (Intravenous Magnesium Efficacy in Stroke trial): randomised controlled trial.[see comment]. Lancet Neurol. 2004;363(9407):439-445. No intervention of interest studied.
Murphy J. Pharmacological treatment of acute ischemic stroke. [Review] [33 refs]. Crit Care Nurs Q. 2003;26(4):276-282. No original empirical evidence presented. [pmid: 14604126].
Murphy N, Kazek MP, Van Vleymen B, et al. Economic evaluation of Nootropil in the treatment of acute stroke in France. Pharmacol Res. 1997;36(5):373-380. No intervention of interest studied. [pmid: 9441728].
Murray K. Put a stop to stroke. Nurs Stand Spec Suppl. 2002;16(36):13-28. No original empirical evidence presented.
Myco F. Stroke patients. A new way of living. Nurs Times. 1986;82(14):24-27. No original empirical evidence presented. [pmid: 3635092].
Nabavi DG, Droste DW, Kemeny V, et al. Potential and limitations of echocontrast-enhanced ultrasonography in acute stroke patients: a pilot study.[see comment]. Stroke. 1998;29(5):949-954. No intervention of interest studied. [pmid: 9596241].
Nabavi DG, Kloska SP, Nam EM, et al. MOSAIC: Multimodal Stroke Assessment Using Computed Tomography: novel diagnostic approach for the prediction of infarction size and clinical outcome. Stroke. 2002;33(12):2819-2826. No intervention of interest studied. [pmid: 12468776].
Nagai M, Onaka U, Abe I, et al. Comparison of the efficacy of nilvadipine and terazosin in elderly hypertensive patients with stroke. J Hypertens. 1994;12(Suppl 3):87. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Naidech A, Khasani S, Lafaye K, et al. Chart review and pilot study of blood pressure control in acute ischemic stroke. J La State Med Soc. 2003;155(2):99-102. No intervention of interest studied. [pmid: 12778994].
Naish J. One pill fits all. Nurs Stand Spec Suppl. 2002;17(50):17. -Sep. No original empirical evidence presented.
Nakano S, Iseda T, Kawano H, et al. Parenchymal hyperdensity on computed tomography after intra-arterial reperfusion therapy for acute middle cerebral artery occlusion: incidence and clinical significance. Stroke. 2001;32(9):2042-2048. No intervention of interest studied. [pmid: 11546895].
Naylor AR, Bolia A, Abbott RJ, et al. Randomized study of carotid angioplasty and stenting versus carotid endarterectomy: a stopped trial.[see comment]. Eur J Vasc Surg. 1998;28(2):326-334. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Naylor AR, Sandercock PA, Sellar RJ, et al. Patterns of vascular pathology in acute, first-ever cerebral infarction. Scott Med J. 1993;38(2):41-44. No intervention of interest studied. [pmid: 8502976].
Nazarian SM, Sanders PL, Thomas SL. Stroke education by utility bill inserts. J Ark Med Soc. 2001;98(5):150-152. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11685809].
Nazir FS. Overell Bolster. The effect of losartan on global and focal cerebral perfusion and on renal function in hypertensives in mild early ischaemic stroke. J Hypertens. 2004;22(5):989-995. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 15097240].
Nazir FS, Overell Hilditch, Less TE, et al. The effect of losartan on global and focal cerebral perfusion and renal function in hypertensives in early ischaemic stroke. Cerebrovasc Dis. 2003;16(suppl 4):31. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12766359].
Neal B, Anderson C, Chalmers J, et al. Blood pressure lowering in patients with cerebrovascular disease: results of the PROGRESS (Perindopril Protection Against Recurrent Stroke Study) pilot phase. Clinical & Experimental Pharmacology & Physiology. 1996;23(5):444-446. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8713688].
Neal B, MacMahon S. An overview of 37 randomised trials of blood pressure lowering agents among 270,000 individuals. World Health Organization-International Society of Hypertension Blood Pressure Lowering Treatment Trialists" Collaboration. Clinical & Experimental Hypertension (New York). 1999;21(56):517-529. No original empirical evidence presented.
Neal B, MacMahon S. PROGRESS (perindopril protection against recurrent stroke study): rationale and design. PROGRESS Management Committee [corrected][erratum appears in J Hypertens. Apr. J Hypertens. 1995. 13. 12 Pt 2. 1869. 1996;14(4):535-1873. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Nedeltchev K, Arnold M, Brekenfeld C, et al. Pre- and in-hospital delays from stroke onset to intra-arterial thrombolysis. Stroke. 2003;34(5):1230-1234. No intervention of interest studied. [pmid: 12702836].
Nedeltchev K, Mattle HP. Diabetes and stroke. Cerebrovasc Dis. 2003;15(SUPPL. 2):25-30. No original empirical evidence presented.
Neilson GH, Seldon WA. Propranolol in angina pectoris. Med J Aust. 1969;1(17):856-857. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 4891931].
Nesbit GM, Clark WM, O"Neill OR, et al. Intracranial intraarterial thrombolysis facilitated by microcatheter navigation through an occluded cervical internal carotid artery. J Neurosurg. 1996;84(3):387-392. No original empirical evidence presented. [pmid: 8609548].
Newcommon N. TPA in acute ischemic stroke. A Calgary experience. Axone. 2000;21(4):73-75. No human participants. [pmid: 11249297].
Newell SDJ, Englert J, Box-Taylor A, et al. Clinical efficiency tools improve stroke management in a rural southern health system. Stroke. 1998;29(6):1092-1098. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9626277].
Ng PP, Higashida RT, Cullen SP, et al. Intraarterial thrombolysis trials in acute ischemic stroke. Journal of Vascular & Interventional Radiology. 2004;15(1 Pt 2):S77-S85. No original empirical evidence presented. [pmid: 15101517].
Nicol MF. Barriers to effective stroke care out of hours need to be broached.[comment]. BMJ. 2002;325(7364):596N. o human participants. [pmid: 12228142].
Nighoghossian N, Berthezene Y, Meyer R, et al. Assessment of cerebrovascular reactivity by dynamic susceptibility contrast-enhanced MR imaging. J Neurol Sci. 1997;149(2):171-176. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9171326].
Nighoghossian N, Hermier M, Adeleine P, et al. Baseline magnetic resonance imaging parameters and stroke outcome in patients treated by intravenous tissue plasminogen activator. Stroke. 2003;34(2):458-463. No intervention of interest studied. [pmid: 12574560].
Nighoghossian N, Hermier M, Berthezene Y, et al. Early diagnosis of hemorrhagic transformation: diffusion/perfusion-weighted MRI versus CT scan. Cerebrovasc Dis. 2001;11(3):151-156. No intervention of interest studied. [pmid: 11306760].
Nolan S, Naylor G, Burns M. Code Gray -- an organized approach to inpatient stroke. Crit Care Nurs Q. 2003;26(4):296-302. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14604128].
Nomura H, Morita C, Kuwano S, et al. Efficacy of combination antiplatelet therapy and nicardipine for chronic cerebral infarction. Clin Ther. 1996;18(3):483-490. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8829024].
Norris JS, Valiante TA, Wallace MC, et al. A simple relationship between radiological arteriovenous malformation hemodynamics and clinical presentation: a prospective, blinded analysis of 31 cases. J Neurosurg. 1999;90(4):673-679. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10193612].
Norris JW, Buchan A, Cote R, et al. Canadian guidelines for intravenous thrombolytic treatment in acute stroke. A consensus statement of the Canadian Stroke Consortium. Can J Neurol Sci. 1998;25(3):257-259. No original empirical evidence presented. [pmid: 9706731].
No stroke center? Give tPA in ER. Senior Care Management. 2003;6(3):37-40. No original empirical evidence presented.
not found, in reference. [Therapy of hypertension. Lasting organ protection moves into the foreground]. [German]. MMW Fortschr Med 11-20-2003;145(47):62Unable to obtain by final date for inclusion.
Nowak G, Schwachenwald D, Schwachenwald R, et al. Intracerebral hematomas caused by aneurysm rupture. Experience with 67 cases. Neurosurg Rev. 1998;21(1):5-9. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9584279].
O"Connell JE, Gray CS. Treatment of post-stroke hypertension. A practical guide. [Review] [50 refs]. Drugs Aging. 1996;8(6):408-415. No original empirical evidence presented. [pmid: 8736624].
O"Farrell B, Evans D. The continuum of care: the process and development of a nursing model for stroke education. Axone. 1998;20(1):16-18. No original empirical evidence presented. [pmid: 9849138].
O"Mahony PG, Rodgers H, Thomson RG, et al. Satisfaction with information and advice received by stroke patients. Clin Rehabil. 1997;11(1):68-72. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9065362].
O"Neal TB, Landry B, Chehardy P, et al. Update on American Heart Association education and information initiatives. J La State Med Soc. 1997;149(5):172-174. No original empirical evidence presented. [pmid: 9154755].
O"Rourke M. Accurate measurement of arterial pressure. J Hum Hypertens. 2003;17(7):445-447. No human participants. [pmid: 12821949].
O"Very DI. Stroke=brain attack. Ochsner Journal. 2003;5(1):58. No original empirical evidence presented.
Ogasawara K, Noda A, Yasuda S, et al. Effect of calcium antagonist on cerebral blood flow and oxygen metabolism in patients with hypertension and chronic major cerebral artery occlusion: a positron emission tomography study. Nucl Med Commun. 2003;24(1):71-76. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12501022].
Ogasawara K, Ogawa A, Doi M, et al. Prediction of acute embolic stroke outcome after local intraarterial thrombolysis: value of pretreatment and posttreatment 99mTc-ethyl cysteinate dimer single photon emission computed tomography. Journal of Cerebral Blood Flow & Metabolism. 2000;20(11):1579-1586. No intervention of interest studied. [pmid: 11083233].
Ogasawara K, Ogawa A, Konno H, et al. Combination of early and delayed SPET imaging using technetium-99m ethyl cysteinate dimer immediately after local intra-arterial thrombolysis. Eur J Nucl Med. 2001;28(4):498-505. No intervention of interest studied. [pmid: 11357501].
Ogilvy CS, Stieg PE, Awad I, et al. AHA Scientific Statement: Recommendations for the management of intracranial arteriovenous malformations: a statement for healthcare professionals from a special writing group of the Stroke Council, American Stroke Association. Stroke. 2001;32(6):1458-1471. No original empirical evidence presented. [pmid: 11387517].
Ogungbo B. Stroke website and world stroke mailing list. QJM. 2003;96(1):81-82. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Ohta H, Nakano S, Yokogami K, et al. Appearance of early venous filling during intra-arterial reperfusion therapy for acute middle cerebral artery occlusion: a predictive sign for hemorrhagic complications. Stroke. 2004;35(4):893-898. No intervention of interest studied. [pmid: 14976322].
Ohtani R, Kazui S, Tomimoto H, et al. Clinical and radiographic features of lobar cerebral hemorrhage: hypertensive versus non-hypertensive cases. Adv Intern Med. 2003;42(7):576-580. No intervention of interest studied.
Okwumabua JO, Martin B, Clayton-Davis J, et al. Stroke Belt initiative: the Tennessee experience. Journal of Health Care for the Poor & Underserved. 1997;8(3):292-299. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9253220].
Oliver MF. Sounding board. Risks of correcting the risks of coronary disease and stroke with drugs. N Engl J Med. 1982;306(5):297-298. No human participants. [pmid: 7033786].
Oosterga M, Voors AA, Pinto YM, et al. Effects of quinapril on clinical outcome after coronary artery bypass grafting (The QUO VADIS Study). QUinapril on Vascular Ace and Determinants of Ischemia. Am J Cardiol. 2001;87(5):542-546. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11230836].
Opinion and evidence in neurology and psychiatry. CNS Drugs 2003;17(4):285–291. No original empirical evidence presented.
Optimal criteria for care of patients with stroke. JAMA 1973;226(2):164–168. No original empirical evidence presented.
Oradei DM, Waite NS. Group psychotherapy with stroke patients during the immediate recovery phase. Am J Orthopsychiatry. 1974;44(3):386-395. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 4824186].
Organised inpatient (stroke unit) care for stroke. Stroke Unit Trialists" Collaboration.[update in Cochrane Database Syst Rev. 2002;(1):CD000197; PMID: 11869570]. [Review][33 refs]. Cochrane Database Syst Rev 2000;(2):CD000197. No original empirical evidence presented.
Osaki Y, Matsubayashi K, Yamasaki M, et al. Post-stroke hypertension correlates with neurologic recovery in patients with acute ischemic stroke. Hypertension Research - Clinical & Experimental. 1998;21(3):169-173. No intervention of interest studied.
Ozeren A, Acarturk E, Koc F, et al. Silent cerebral lesions on magnetic resonance imaging in subjects with coronary artery disease. Jpn Heart J. 1998;39(5):611-618. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9925992].
Padma MV, Gaikwad S, Jain S, et al. Distribution of vascular lesions in ischaemic stroke: a magnetic resonance angiographic study. Natl Med J India. 1997;10(5):217-220. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9401380].
Page for patients. Hormone replacement therapy. Prev Med 2001;32(4):311–312. No human participants.
Pancioli AM, Broderick J, Kothari R, et al. Public perception of stroke warning signs and knowledge of potential risk factors.[see comment]. JAMA. 1998;279(16):1288-1292. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9565010].
Panella M, Marchisio S, Di Stanislao F. Reducing clinical variations with clinical pathways: Do pathways work?. Int J Qual Health Care. 2003;15(6):509-521. No intervention of interest studied. [pmid: 14660534].
Paoni NF, Steinmetz HG, Gillett N, et al. An experimental model of intracranial hemorrhage during thrombolytic therapy with t-PA. Thrombosis & Haemostasis. 1996;75(5):820-826. No human participants. [pmid: 8725730].
Parahoo K, Thompson K, Cooper M, et al. Stroke: awareness of the signs, symptoms and risk factors--a population-based survey. Cerebrovasc Dis. 2003;16(2):134-140. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12792171].
Parmar MS. Preventing stroke with ramipril. Presentation of data is misleading.[comment]. BMJ. 2002;325(7361):439. No original empirical evidence presented.
Parsons MW, Barber PA, Chalk J, et al. Diffusion- and perfusion-weighted MRI response to thrombolysis in stroke.[see comment]. Ann Neurol. 2002;51(1):28-37. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11782981].
Parsons MW, Barber PA, Desmond PM, et al. Acute hyperglycemia adversely affects stroke outcome: a magnetic resonance imaging and spectroscopy study.[see comment]. Ann Neurol. 2002;52(1):20-28. No intervention of interest studied. [pmid: 12112043].
Parving HH. Diabetic hypertensive patients. Is this a group in need of particular care and attention? [Review] [27 refs]. Diabetes Care. 1999;22 Suppl:2B76-B79. No original empirical evidence presented.
Pasquarello MA. Measuring the impact of an acute stroke program on patient outcomes. J Neurosci Nurs. 1990;22(2):76-82. No intervention of interest studied. [pmid: 2139685].
Pasquarello MA. Developing, implementing, and evaluating a stroke recovery group. Rehabil Nurs. 1990;15(1):26-29. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 2300694].
Passero S, Filosomi G. Posterior circulation infarcts in patients with vertebrobasilar dolichoectasia. Stroke. 1998;29(3):653-659. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9506608].
Pearson RM, Griffith DN, Woollard M, et al. Comparison of effects on cerebral blood flow of rapid reduction in systemic arterial pressure by diazoxide and labetalol in hypertensive patients: preliminary findings. Br J Clin Pharmacol. 1979;8(Suppl 2):195S-198S. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 526401]. [pmcid: 1429753].
Pelz DM. Advances in interventional neuroradiology. Stroke. 2003;34(2):357-358. No original empirical evidence presented. [pmid: 12574535].
Penney JB, Hahn JL. Stroke and heart attack prevention education. Medsurg Nurs. 1994;3(6):459-464. No intervention of interest studied. [pmid: 7874208].
Pepe PE, Zachariah BS, Sayre MR, et al. Ensuring the chain of recovery for stroke in your community. Chain of Recovery Writing Group. [Review] [19 refs]. Prehosp Emerg Care. 1998;2(2):89-95. No original empirical evidence presented. [pmid: 9709325].
Pepe PE, Zachariah BS, Sayre MR, et al. Ensuring the chain of recovery for stroke in your community. Acad Emerg Med. 1998;5(4):352-358. No original empirical evidence presented. [pmid: 9562203].
Pereira AC, Martin PJ, Warburton EA. Thrombolysis in acute ischaemic stroke. [Review] [62 refs]. Postgrad Med J. 2001;77(905):166-171. No original empirical evidence presented. [pmid: 11222823]. [pmcid: 1741956].
Perkin GD. New approach to treatment of recent stroke?. BMJ. 1979;1(6173):1283. No original empirical evidence presented. [pmid: 378323].
Perren F, Bogousslavsky J. Hypertension and lowering blood pressure. Cerebrovasc Dis. 2003;15(SUPPL. 2):19-23. No original empirical evidence presented. [pmid: 12649609].
Perry HMJ, Davis BR, Price TR, et al. Effect of treating isolated systolic hypertension on the risk of developing various types and subtypes of stroke: the Systolic Hypertension in the Elderly Program (SHEP). JAMA. 2000;284(4):465-471. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10904510].
Pessina AC, Pigato R, Palu CD. Clinical experiences with methyldopa. Clinical & Experimental Pharmacology & Physiology - Supplement. 1978:451-54. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Pettersen JA, Hudon ME, Hill MD. Intra-arterial thrombolysis in acute ischemic stroke: a review of pharmacologic approaches. [Review] [107 refs]. Expert Review of Cardiovascular Therapy. 2004;2(2):285-299. Unable to obtain by final date for inclusion. [pmid: 15151476].
Phatouros CC, Sasaki TY, Higashida RT, et al. Stent-supported coil embolization: the treatment of fusiform and wide-neck aneurysms and pseudoaneurysms. Neurosurgery. 2000;47(1):107-113. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10917353].
Phelps MA, Rodriguez RM, Passanante M, et al. EMS activation in a cohort of critically ill patients. Am J Emerg Med. 2002;22(2):127-131. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Phillips SJ, Eskes GA, Gubitz GJ, et al. Description and evaluation of an acute stroke unit.[see comment]. CMAJ Canadian Medical Association Journal. 2002;167(6):655-660. No original empirical evidence presented.
Piepgras A, Roth H, Schurer L, et al. Rapid active internal core cooling for induction of moderate hypothermia in head injury by use of an extracorporeal heat exchanger. Neurosurgery. 1998;42(2):311-317. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9482181].
Pierce LL, Gordon M, Steiner V. Families dealing with stroke desire information about self-care needs. Rehabil Nurs. 2004;29(1):14-17. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14727471].
Pikus HJ, Heros RC. Stroke: indications for emergent surgical intervention. [Review][122 refs]. Clin Neurosurg 1999;45113–127. No original empirical evidence presented.
Pillekamp F, Grune M, Brinker G, et al. Magnetic resonance prediction of outcome after thrombolytic treatment. Magn Reson Imaging. 2001;19(2):143-152. No human participants. [pmid: 11358651].
Pittock SJ, Meldrum D, Hardiman O, et al. Patient and hospital delays in acute ischaemic stroke in a Dublin teaching hospital.[see comment]. Ir Med J. 2003;96(6):167-168. No intervention of interest studied. [pmid: 12926756].
Pittock SJ, Meldrum D, Hardiman O, et al. The Oxfordshire Community Stroke Project Classification: Correlation with imaging, associated complications, and prediction of outcome in acute ischemic stroke. Journal of Stroke & Cerebrovascular Diseases. 2003;12(1):1-7. No intervention of interest studied. [pmid: 17903897].
Pollman PJ. A 29-year-old soldier with heat stroke. J Emerg Nurs. 2001;27(2):119-123. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11275858].
Popa C, Lugoji G, Popescu A, et al. Calcium blockers in ischemic stroke. Romanian Journal of Neurology & Psychiatry. 1992;30(3):189-196. No intervention of interest studied. [pmid: 1476911].
Popa G, Voiculescu V, Popa C, et al. Stroke and hypertension. Antihypertensive therapy withdrawal. Romanian Journal of Neurology & Psychiatry. 1995;33(1):29-35. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7547368].
Porteous GH, Corry MD, Smith WS. Emergency medical services dispatcher identification of stroke and transient ischemic attack. Prehosp Emerg Care. 1999;3(3):211-216. No intervention of interest studied. [pmid: 10424858].
Post-stroke antihypertensive treatment study. A preliminary result. PATS Collaborating Group. Chin Med J 1995;108(9):710–717. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Poulias GE, Skoutas B, Doundoulakis N, et al. Kinking and coiling of internal carotid artery with and without associated stenosis. Surgical considerations and long-term follow-up. Panminerva Med. 1996;38(1):22-27. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8766875].
Pound P, Sabin C, Ebrahim S. Observing the process of care: a stroke unit, elderly care unit and general medical ward compared. Age & Ageing. 1999;28(5):433-440. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10529036].
Powers WJ. 10 Most commonly asked questions about carotid artery occlusion. Proc Aust Assoc Neurol. 2003;9(3):167-169. No original empirical evidence presented.
Prabhakar S, Das CP. Ischaemic stroke: new frontiers. [Review] [59 refs]. Neurol India. 1999;47(3):168-177. No original empirical evidence presented. [pmid: 10514574].
Pranesh MB, Dinesh NS, Mathew V, et al. Hemicraniectomy for large middle cerebral artery territory infarction: outcome in 19 patients.[see comment]. J Neurol Neurosurg Psychiatry. 2003;74(6):800-802. No intervention of interest studied. [pmid: 12754357]. [pmcid: 1738467].
Prevention, education programs head off high cost of stroke. Healthc Demand Dis Manag 1998;4(6):85–91. No original empirical evidence presented.
Prinsley DM. Effects of industrial action by the ambulance service on day hospital patients. BMJ. 1971;3(767):170-171. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 5557871]. [pmcid: 1800247].
Progress and stroke--it''s time to translate evidence into action. Cardiovascular Journal of Southern Africa 2002;13(5):267-Oct. No original empirical evidence presented.
PROGRESS - Perindopril Protection Against Recurrent Stroke Study: characteristics of the study population at baseline. Progress Management Committee. J Hypertens 1999;17(11):1647–1655. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Protocol for prospective collaborative overviews of major randomized trials of blood-pressure-lowering treatments. World Health Organization-International Society of Hypertension Blood Pressure Lowering Treatment Trialists'' Collaboration.[see comment]. J Hypertens 1998;16(2):127–137. No original empirical evidence presented.
Psaty BM, Lumley T, Furberg CD, et al. Health outcomes associated with various antihypertensive therapies used as first-line agents: a network meta-analysis.[see comment]. JAMA. 2003;289(19):2534-2544. No original empirical evidence presented. [pmid: 12759325].
Puca A. Thrombolysis in cerebral ischemia. A review of clinical and experimental data. [Review] [65 refs]. J Neurosurg Sci. 1993;37(2):63-70. No original empirical evidence presented. [pmid: 8301372].
Puranen J, Laakso M, Riekkinen PJS, et al. Efficacy of antiplatelet treatment in hypertensive patients with TIA or stroke. J Cardiovasc Pharmacol. 1998;32(2):291-294. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9700992].
Qiu Y, Lin Y, Tian X, et al. Hypertensive intracranial hematomas: Endoscopic-assisted keyhole evacuation and application of patent viewing dissector. Chin Med J. 2003;116(2):195-199. Unable to obtain by final date for inclusion. [pmid: 12775228].
Quaglini S, Caffi E, Cavallini A, et al. Simulation of a stroke unit careflow. Medinfo. 2001;10(Pt 2):1190-1191. No intervention of interest studied. [pmid: 11604918].
Qureshi AI, Bliwise DL, Bliwise NG, et al. Rate of 24-hour blood pressure decline and mortality after spontaneous intracerebral hemorrhage: a retrospective analysis with a random effects regression model.[see comment]. Crit Care Med. 1999;27(3):480-485. No intervention of interest studied. [pmid: 10199525].
Qureshi AI, Siddiqui AM, Kim SH, et al. Reocclusion of recanalized arteries during intra-arterial thrombolysis for acute ischemic stroke. Ajnr: American Journal of Neuroradiology. 2004;25(2):322-328. No intervention of interest studied. [pmid: 14970040].
Rabinov J, Schwamm L, Putman C, et al. Image-guided vascular recanalization in acute stroke. [Review] [47 refs]. Semin Roentgenol. 2002;37(3):237-248. No original empirical evidence presented. [pmid: 12226903].
Ramrakha S, Giles A. Take a letter ... an audit of GP referrals in south west Sydney. Aust Fam Physician. 2001;30(4):395-398. No intervention of interest studied. [pmid: 11355232].
Rapp K, Bratina P, Barch C, et al. Code Stroke: rapid transport, triage and treatment using rt-PA therapy. The NINDS rt-PA Stroke Study Group. [Review] [10 refs]. J Neurosci Nurs. 1997;29(6):361-366. No original empirical evidence presented. [pmid: 9479657].
Rasool AHG, Rahman ARA, Choudhury SR, et al. Blood pressure in acute intracerebral haemorrhage. J Hum Hypertens. 2004;18(3):187-192. No original empirical evidence presented. [pmid: 14973513].
Rasool AH, Rahman AR, Choudhury SR, et al. Blood pressure in acute intracerebral haemorrhage. [Review] [55 refs]. J Hum Hypertens. 2004;18(3):187-192. Unable to obtain by final date for inclusion. [pmid: 14973513].
Ratnasabapathy Y, Lawes CM, Anderson CS. The Perindopril Protection Against Recurrent Stroke Study (PROGRESS): clinical implications for older patients with cerebrovascular disease. [Review] [62 refs]. Drugs Aging. 2003;20(4):241-251. No original empirical evidence presented. [pmid: 12641480].
Rausch M, Turkoski B. Developing realistic treatment standards in today"s economic climate: stroke survivor education. J Adv Nurs. 1999;30(2):329-334. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10457234].
Raymond J, Roy D. Safety and efficacy of endovascular treatment of acutely ruptured aneurysms. Neurosurgery. 1997;41(6):1235-1245. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9402574].
Redman AR, Ryan GJ. Aggrenox versus other pharmacotherapy in preventing recurrent stroke. Expert Opin Pharmacother. 2004;5(1):117-123. No original empirical evidence presented. [pmid: 14680441].
Rees J, Wilcox Cuddihy RA. Psychology in rehabilitation of older adults. Rev Clin Gerontol. 2003;12(4):343-356. No original empirical evidence presented.
Reid JL. The role of clinical pharmacology in the development and assessment of drugs for cerebrovascular disease and stroke. [Review] [6 refs]. Br J Clin Pharmacol. 1993;35(4):341-342. No original empirical evidence presented. [pmid: 8485012]. [pmcid: 1381542].
Reker DM, Hoenig H, Zolkewitz MA, et al. The structure and structural effects of VA rehabilitation bedservice care for stroke. Journal of Rehabilitation Research & Development. 2000;37(4):483-491. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11028704].
Reports from the American College of Cardiology 53rd Annual Scientific Session. British Journal of Cardiology 2004;11(2):99–104. No original empirical evidence presented.
Report of the Joint Committee for Stroke Facilities. II. Stroke rehabilitation. Stroke 1972;3(3):375–407. No original empirical evidence presented.
Report of the joint committee for stroke facilities. IX. Strokes in children. 2. [Review][237 refs]. Stroke 1973;4(6):1007–1052. No original empirical evidence presented.
Report of The Joint Committee For Stroke Facilities. X. Community health services for stroke. [Review][69 refs]. Stroke 1974;5(1):114–133. No original empirical evidence presented
Ricauda NA, Pla LF, Marinello R, et al. Feasibility of an acute stroke home care service for elderly patients. Archives of Gerontology & Geriatrics. 1998;27(Suppl 6):17-22. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Richardson BK. Overview of geriatric emergencies. Mt Sinai J Med. 2003;70(2):75-84. No original empirical evidence presented. [pmid: 12634899].
Richardson E, Warburton F, Wolfe CD, et al. Family support services for stroke patients. Pap Natl Conf Prof Nurses Physicians. 1999;12(2):92-96. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Richardson-Nassif K, Swartz R, Reardon M. Implementing a community education program on stroke for health care providers and consumers. Education for Health. 2002;15(1):59-64. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14741988].
Richter RW, Bengen B, Bruun B, et al. Example of a community model for comprehensive stroke services: the Harlem Regionaal Stroke Program. Stroke. 1974;5(1):135-144. No human participants. [pmid: 4811306].
Richter RW, Bengen B, Bruun B, et al. The Harlem regional stroke program: an overview. Archives of Physical Medicine & Rehabilitation. 1977;58(5):224-229. No original empirical evidence presented. [pmid: 192174].
Rieke K, Schwab S, Krieger D, et al. Decompressive surgery in space-occupying hemispheric infarction: results of an open, prospective trial. [Review] [46 refs]. Crit Care Med. 1995;23(9):1576-1587. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7664561].
Riggs JE. Tissue-type plasminogen activator should not be used in acute ischemic stroke. Arch Fam Med. 1997;6(2):102-104. No original empirical evidence presented. [pmid: 9075439].
Riggs JE. Tissue-type plasminogen activator should not be used in acute ischemic stroke. Arch Neurol. 1996;53(12):1306-1308. Unable to obtain by final date for inclusion. [pmid: 8970462].
Riggs JE. Cost-effectiveness of tissue plasminogen activator for acute ischemic stroke. Neurology. 1999;52(4):895-896. No original empirical evidence presented.
Rigler SK, Webb MJ, Patel AT, et al. Use of antihypertensive and antithrombotic medications after stroke in community-based care. Ann Pharmacother. 2001;35(78):811-816. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11485125].
Rincon FMS. Novel therapies for intracerebral hemorrhage. Curr Opin Crit Care. 2004;10(2):94-100. No original empirical evidence presented. [pmid: 15075717].
Ringel SP, Hughes RL. Evidence-based medicine, critical pathways, practice guidelines, and managed care. Reflections on the prevention and care of stroke.[see comment]. Arch Neurol. 1996;53(9):867-871. No original empirical evidence presented. [pmid: 8815851].
Ringer AJ, Hopkins LN. Endovascular treatment of acute stroke. [Review] [36 refs]. J Am Coll Surg. 2002;194(1 Suppl):S15-S21. No original empirical evidence presented. [pmid: 11800350].
Ringleb PA, Schellinger PD, Schranz C, et al. Thrombolytic therapy within 3 to 6 hours after onset of ischemic stroke: useful or harmful? [Review] [29 refs]. Stroke. 2002;33(5):1437-1441. No original empirical evidence presented. [pmid: 11988629].
Robins M, Weinfeld FD. The National Survey of Stroke. Survey evaluation. Stroke. 1981;12(2 Pt 2 Suppl 1):I89-I91. No original empirical evidence presented. [pmid: 7222170].
Robinson L. Ischemic strokes arriving too late for tPA are an ideal and ethical control group for continuing studies of tPA efficacy.[comment]. Stroke. 1998;29(7):1476-1477. No original empirical evidence presented. [pmid: 9660407].
Robinson SK. Letter: Antihypertensive drugs and stroke. JAMA. 1974;230(3):374-375. No original empirical evidence presented. [pmid: 4606726].
Robinson TGP. Blood pressure in acute stroke. Age & Ageing. 2004;33(1):6-12. No original empirical evidence presented. [pmid: 14695858].
Robinson TG, Potter JF. Blood pressure in acute stroke. [Review] [125 refs]. Age & Ageing. 2004;33(1):6-12. Unable to obtain by final date for inclusion. [pmid: 14695858].
Rocca WA, Dorsey FC, Grigoletto F, et al. Design and baseline results of the monosialoganglioside early stroke trial. The EST Study Group. Stroke. 1992;23(4):519-526. No intervention of interest studied. [pmid: 1561683].
Roccella EJ. Meeting the 1990 hypertension objectives for the nation--a progress report. Public Health Rep. 1985;100(6):652-656. No original empirical evidence presented. [pmid: 3934702]. [pmcid: 1425312].
Rodgers A, MacMahon S, Gamble G, et al. Blood pressure and risk of stroke in patients with cerebrovascular disease. The United Kingdom Transient Ischaemic Attack Collaborative Group. BMJ. 1996;313(7050):147S. [defined as adult (>16) with acute stroke].
Rodgers H, Atkinson C, Bond S, et al. Randomized controlled trial of a comprehensive stroke education program for patients and caregivers. Stroke. 1999;30(12):2585-2591. No intervention of interest studied. [pmid: 10582982].
Rodgers H, Bond S, Curless R. Inadequacies in the provision of information to stroke patients and their families.[see comment]. [Review] [42 refs]. Age & Ageing. 2001;30(2):129-133. No original empirical evidence presented. [pmid: 11395342].
Rodgers H, Dennis M, Cohen D, et al. British Association of Stroke Physicians: benchmarking survey of stroke services. Age & Ageing. 2003;32(2):211-217. No human participants. [pmid: 12615567].
Rohde V, Rohde I, Thiex R, et al. Fibrinolysis therapy achieved with tissue plasminogen activator and aspiration of the liquefied clot after experimental intracerebral hemorrhage: rapid reduction in hematoma volume but intensification of delayed edema formation. J Neurosurg. 2002;97(4):954-962. No human participants. [pmid: 12405387].
Rohde V, Schaller C, Hassler WE. Intraventricular recombinant tissue plasminogen activator for lysis of intraventricular haemorrhage. Journal of Neurology, Neurosurgery & Psychiatry. 1995;58(4):447-451. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Ronning OM, Guldvog B. Stroke unit versus general medical wards, II: neurological deficits and activities of daily living: a quasi-randomized controlled trial. Stroke. 1998;29(3):586-590. No intervention of interest studied. [pmid: 9506597].
Ronning OM, Guldvog B. Stroke units versus general medical wards, I: twelve- and eighteen-month survival: a randomized, controlled trial. Stroke. 1998;29(1):58-62. No intervention of interest studied. [pmid: 9445329].
Ronning OM, Guldvog B, Stavem K. The benefit of an acute stroke unit in patients with intracranial haemorrhage: a controlled trial. Journal of Neurology, Neurosurgery & Psychiatry. 2001;70(5):631-634. No intervention of interest studied.
Rook AR. Acetylcholine-induced cardiac arrest during cerebrovascular surgery: a clinical trial. J Am Osteopath. ssoc. 1973;73(4):287-295. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Roquer J, Lorenzo JL, Pou A. The anterior inferior cerebellar artery infarcts: a clinical-magnetic resonance imaging study. Acta Neurol Scand. 1998;97(4):225-230. No intervention of interest studied. [pmid: 9576636].
Rosa G, Pinto G, Orsi P, et al. Control of post anaesthetic shivering with nefopam hydrochloride in mildly hypothermic patients after neurosurgery. Acta Anaesthesiol Scand. 1995;39(1):90-95. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7725889].
Rosenbaum D, Zabramski J, Frey J, et al. Early treatment of ischemic stroke with a calcium antagonist. Stroke. 1991;22(4):437-441. No intervention of interest studied. [pmid: 2024271].
Rosenthal SG, Pituch MJ, Greninger LO, et al. Perceived needs of wives of stroke patients. Rehabil Nurs. 1993;18(3):148-153. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8502839].
Rosenwasser RH. Re: Safety of intraventricular sodium nitroprusside and thiosulfate for the treatment of cerebral vasospasm in the intensive care unit setting.[comment]. Stroke. 2002;33(4):1165-1166. No original empirical evidence presented. [pmid: 11935079].
Ross SD, Kupelnick B, Kumashiro M, et al. Risk of serious adverse events in hypertensive patients receiving isradipine: a meta-analysis. J Hum Hypertens. 1997;11(11):743-751. No original empirical evidence presented. [pmid: 9416985].
Rother J. CT and MRI in the diagnosis of acute stroke and their role in thrombolysis. [Review] [62 refs]. Thromb Res. 2001;103 Suppl:1S125-S133. No original empirical evidence presented.
Rother J. Imaging-guided extension of the time window: Ready for application in experienced stroke centers?. Stroke. 2003;34(2):582-583. No original empirical evidence presented.
Rother J, Schellinger PD, Gass A, et al. Effect of intravenous thrombolysis on MRI parameters and functional outcome in acute stroke <6 hours. Stroke. 2002;33(10):2438-2445. No intervention of interest studied. [pmid: 12364735].
Rothwell PM. Incidence, risk factors and prognosis of stroke and TIA: the need for high-quality, large-scale epidemiological studies and meta-analyses. [Review] [99 refs]. Cerebrovasc Dis. 2003;16 Suppl:32-10. No original empirical evidence presented.
Rothwell PM, Howard SC, Spence JD, et al. Relationship between blood pressure and stroke risk in patients with symptomatic carotid occlusive disease.[see comment]. Stroke. 2003;34(11):2583-2590. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14593126].
Rowe AK, Frankel MR, Sanders KA. Stroke awareness among Georgia adults: epidemiology and considerations regarding measurement. South Med J. 2001;94(6):613-618. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11440330].
Ruland S, Gorelick PB, Schneck M, et al. Acute stroke care in Illinois: a statewide assessment of diagnostic and treatment capabilities.[see comment]. Stroke. 2002;33(5):1334-1339. No intervention of interest studied. [pmid: 11988612].
Ruland S, Raman R, Chaturvedi S, et al. Awareness, treatment, and control of vascular risk factors in African Americans with stroke. Neurology. 2003;60(1):64-68. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12525719].
Ryan M, Rhoney DH, Luer MS, et al. New and investigational treatment options for ischemic stroke. [Review] [104 refs]. Pharmacotherapy. 1997;17(5):959-969. No original empirical evidence presented. [pmid: 9324184].
Rymer MM, Thurtchley D, Summers D, et al. Expanded modes of tissue plasminogen activator delivery in a comprehensive stroke center increases regional acute stroke interventions. Stroke. 2003;34(6):e58-e60. No intervention of interest studied. [pmid: 12511751].
Rx for stroke: aspirin, within 48 hours. Heart Advis 2002;5(9):2No original empirical evidence presented.
Sacco RL. Preventing Stroke among Blacks: The Challenges Continue. J Am Med Assoc. 2003;289(22):3005-3007. No original empirical evidence presented.
Sacco RL, Ellenberg JH, Mohr JP, et al. Infarcts of undetermined cause: the NINCDS Stroke Data Bank. Ann Neurol. 1989;25(4):382-390. No intervention of interest studied. [pmid: 2712533].
Sacco S, Marini C, Carolei A. Medical treatment of intracerebral hemorrhage. Shinkei Kenkyu No Shimpo. 2004;25(SUPPL. 1):S6-S9. No original empirical evidence presented.
Sae-Sia W. Chinese elderly patients" perceptions of their rehabilitation needs following a stroke.[comment]. J Adv Nurs. 2000;31(4):751N. o original empirical evidence presented. [pmid: 10836862].
Saito Y. Angiographic findings of vertebral basilar arterial thrombosis. Yonago Acta Med. 1965;9(2):67-76. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 5322241].
Salazar J, Vaquero J, Martinez P, et al. Clinical and CT scan assessment of benign versus fatal spontaneous cerebellar haematomas. Acta Neurochir (Wien). 1986;79(24):80-86. No human participants. [pmid: 3962747].
Samama M. Haemorrhagic aspects of thrombolytic therapy. [Review] [23 refs]. Eur Heart J. 1990;11 Suppl:F15-18. No original empirical evidence presented.
Samuelsson O, Wilhelmsen L, Elmfeldt D, et al. Predictors of cardiovascular morbidity in treated hypertension: results from the primary preventive trial in Goteborg, Sweden. J Hypertens. 1985;3(2):167-176. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 4020124].
Sandercock P. Managing stroke: the way forward.[see comment]. BMJ. 1993;307(6915):1297-1298. No original empirical evidence presented. [pmid: 8257881]. [pmcid: 1679414].
Sanders KA, Frankel MR. Stroke care and prevention in Georgia: current status and challenges. J Med Assoc Ga. 2001;90(1):29-31. No original empirical evidence presented.
Sansing LH, Kaznatcheeva EA, Perkins CJ, et al. Edema after intracerebral hemorrhage: correlations with coagulation parameters and treatment. J Neurosurg. 2003;98(5):985-992. No intervention of interest studied. [pmid: 12744358].
Sareen D. Current concepts in the management of acute ischemic stroke. [Review][47 refs]. J Assoc Physicians India 2002;50407–414. No original empirical evidence presented.
Saunders FW, Marshall WJ. Diltiazem: dose it affect vasospasm?. Surg Neurol. 1986;26(2):155-158. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 3523805].
Saver JL. Coping with an embarrassment of riches. How stroke centers may participate in multiple, concurrent clinical stroke trials.[see comment]. Stroke. 1995;26(7):1289-1292. No original empirical evidence presented. [pmid: 7604428].
Saver JL, Kalafut M. Combination therapies and the theoretical limits of evidence-based medicine.[erratum appears in Neuroepidemiology 2001 Aug;20(3):211]. [Review] [53 refs]. Neuroepidemiology. 2001;20(2):57-64. No human participants. [pmid: 11359071].
Saver JLK. Prehospital neuroprotective therapy for acute stroke: results of the Field Administration of Stroke Therapy-Magnesium (FAST-MAG) pilot trial. Stroke. 2004;35(5):e106-e108. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 15017009].
Saxena R, Wijnhoud AD, Carton H, et al. Controlled safety study of a hemoglobin-based oxygen carrier, DCLHb, in acute ischemic stroke.[see comment]. Stroke. 1999;30(5):993-996. No intervention of interest studied. [pmid: 10229733].
Sbarigia E, Toni D, Speziale F, et al. Emergency and early carotid endarterectomy in patients with acute ischemic stroke selected with a predefined protocol. A prospective pilot study. Int Angiol. 2003;22(4):426-430. No intervention of interest studied. [pmid: 15153829].
Schaefer E, Hacke W, Fieschi C, et al. ECASS-II: a placebo controlled trial of alteplase (rt-PA) in acute ischemic hemispheric stroke where thrombolysis is initiated up to 6 hours following the onset of symptoms. Cerebrovasc Dis. 1996;6(suppl 2):74N. o intervention of interest studied.
Schellinger PD, Fiebach JB, Hacke W. Imaging-based decision making in thrombolytic therapy for ischemic stroke: present status.[see comment]. [Review] [92 refs]. Stroke. 2003;34(2):575-583. No original empirical evidence presented.
Schellinger PD, Fiebach JB, Mohr A, et al. Thrombolytic therapy for ischemic stroke--a review. Part II--Intra-arterial thrombolysis, vertebrobasilar stroke, phase IV trials, and stroke imaging. [Review] [83 refs]. Crit Care Med. 2001;29(9):1819-1825. No original empirical evidence presented. [pmid: 11546994].
Schellinger PD, Fiebach JB, Mohr A, et al. Thrombolytic therapy for ischemic stroke--a review. Part I--Intravenous thrombolysis. [Review] [47 refs]. Crit Care Med. 2001;29(9):1812-1818. No original empirical evidence presented. [pmid: 11546993].
Schenkel J, Weimar C, Knoll T, et al. R1--systemic thrombolysis in German stroke units--the experience from the German Stroke data bank. J Neurol. 2003;250(3):320-324. No intervention of interest studied. [pmid: 12638023].
Schmidt SM, Guo L, Scheer S, et al. Epidemiologic determination of community-based nursing case management for stroke. Can J Nurs Adm. 1999;29(6):40-47. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Schmidt SM, Guo L, Scheer SJ. Changes in the status of hospitalized stroke patients since inception of the prospective payment system in 1983. Archives of Physical Medicine & Rehabilitation. 2002;83(7):894-898. No intervention of interest studied. [pmid: 12098145].
Schmulling S, Grond M, Rudolf J, et al. One-year follow-Up in acute stroke patients treated with rtPA in clinical routine. Stroke. 2000;31(7):1552-1554. No intervention of interest studied. [pmid: 10884452].
Schneider AT, Pancioli AM, Khoury JC, et al. Trends in community knowledge of the warning signs and risk factors for stroke. JAMA. 2003;289(3):343-346. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12525235].
Schoser BG, Becker VU, Eckert B, et al. Clinical and ultrasonic long-term results of percutaneous transluminal carotid angioplasty. A prospective follow-up of 30 carotid angioplasties. Cerebrovasc Dis. 1998;8(1):38-41. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9645980].
Schrader J. Early antihypertensive therapy cuts risk after stroke. Medscape (neurology 2001;Unable to obtain by final date for inclusion.
Schrader J. Acute Candesartan Cilexetil Evaluation in Stroke Survivors (ACCESS Study). Stroke. 1999;30(2):487. No intervention of interest studied. [pmid: 9933294].
Schrader J, Luders S, Kulschewski A, et al. ACCESS Study: Acute Candesartan Cilexetil Evaluation in Stroke Survivors. Am J Hypertens. 2002;15(4 Part 2):17A. No intervention of interest studied.
Schrader J, Luders S, Kulschewski A, et al. ACCESS-study: acute candesartan cilexetil evaluation in stroke survivors - final results. Dtsch Med Wochenschr. 2001;126(Suppl 3):S155S. [defined as adult (>16) with acute stroke].
Schrader J, Rothemeyer M, Luders S, et al. Hypertension and stroke--rationale behind the ACCESS trial. Acute Candesartan Cilexetil Evaluation in Stroke Survivors. [Review] [61 refs]. Basic Res Cardiol. 1998;93 Suppl:269-78. No original empirical evidence presented. [pmid: 9782369].
Schrader J, Diener HC, Luders S. [Treating high blood pressure in acute stroke]. [German]. MMW Fortschr Med. 3–11. 2004;146(11):45-48. Unable to obtain by final date for inclusion.
Schretzman D. Acute ischemic stroke. [Review] [34 refs]. J Am Acad Nurse Pract. 1975;24(2):71-72. No original empirical evidence presented.
Schroeder EB, Rosamond WD, Morris DL, et al. Determinants of use of emergency medical services in a population with stroke symptoms: the Second Delay in Accessing Stroke Healthcare (DASH II) Study. Stroke. 2000;31(11):2591-2596. No intervention of interest studied. [pmid: 11062280].
Schroth G, Berlis A, Mayer T, et al. [Therapeutic interventional neuroradiology in acute stroke]. [Review] [32 refs] [German]. Ther Umsch. 2003;60(9):569-583. Non-English publication. [pmid: 14579626].
Schwab S, Steiner T, Aschoff A, et al. Early hemicraniectomy in patients with complete middle cerebral artery infarction. Stroke. 1998;29(9):1888-1893. No intervention of interest studied. [pmid: 9731614].
Schwammenthal Y, Drescher MJ, Merzeliak O, et al. Intravenous recombinant tissue plasminogen activator therapy for acute ischemic stroke: Initial israeli experience. Israel Medical Association Journal: Imaj. 2004;6(2):70-74. No intervention of interest studied.
Scott JF, Robinson GM, French JM, et al. Blood pressure response to glucose potassium insulin therapy in patients with acute stroke with mild to moderate hyperglycaemia. J Neurol Neurosurg Psychiatry. 2001;70(3):401-404. No intervention of interest studied. [pmid: 11181869]. [pmcid: 1737285].
Scott PA, Silbergleit R. Misdiagnosis of stroke in tissue plasminogen activator-treated patients: characteristics and outcomes. Ann Emerg Med. 2003;42(5):611-618. No intervention of interest studied. [pmid: 14581912].
Seestedt RCF. Intracerebral Hemorrhage. Curr Treat Options Neurol. 1999;1(2):127-137. No original empirical evidence presented. [pmid: 11096702].
Segura T, Vega G, Lopez S, et al. Public perception of stroke in Spain. Cerebrovasc Dis. 2003;16(1):21-26. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12766357].
Selim M, Fink JN, Kumar S, et al. Predictors of hemorrhagic transformation after intravenous recombinant tissue plasminogen activator: prognostic value of the initial apparent diffusion coefficient and diffusion-weighted lesion volume. Stroke. 2002;33(8):2047-2052. No intervention of interest studied. [pmid: 12154261].
Selim M, Kumar S, Fink J, et al. Seizure at stroke onset: should it be an absolute contraindication to thrombolysis?. Cerebrovasc Dis. 2002;14(1):54-57. No intervention of interest studied. [pmid: 12097852].
Semplicini A, Maresca A, Simonella C, et al. Cerebral perfusion in hypertensive patients: effects of lacidipine and hydrochlorothiazide. J Cardiovasc Pharmacol. 2000;35(3 Suppl 1):S13-S18. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Sever P. ALLHAT: Definitive answers or continuing uncertainty?. J Renin Angiotensin Aldosterone Syst. 2003;4(1):3-5. No original empirical evidence presented. [pmid: 12692746].
Shafqat S. Clinical Practice Guidelines for the Management of Ischemic Stroke in Pakistan. J Pak Med Assoc. 2003;53(12):600-603. No original empirical evidence presented. [pmid: 14765941].
Shapiro J, Bessette M, Levine SR, et al. HandiStroke: a handheld tool for the emergent evaluation of acute stroke patients. Acad Emerg Med. 2003;10(12):1325-1328. No intervention of interest studied. [pmid: 14644783].
Shaughnessy AS, Scow DT. t-PA for treating acute ischemic stroke. J Fam Pract. 1996;42(5):458-459. No original empirical evidence presented. [pmid: 8642361].
Shih LC, Saver JL, Alger Starkman S, et al. Perfusion-weighted magnetic resonance imaging thresholds identifying core, irreversibly infarcted tissue. Stroke. 2003;34(6):1425-1430. No intervention of interest studied. [pmid: 12738899].
Shintani S, Tsuruoka S, Satoh Y. Spurious hyperfixation of hexamethylpropyleneamine oxime in acute embolic stroke.[see comment]. Ajnr: American Journal of Neuroradiology. 1995;16(7):1532-1535. No intervention of interest studied. [pmid: 7484649].
Silagy CA, Weller DP, Lapsley H, et al. The effectiveness of local adaptation of nationally produced clinical practice guidelines. Fam Pract. 2002;19(3):223-230. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11978710].
Silliman SL, Quinn B, Huggett V, et al. Use of a field-to-stroke center helicopter transport program to extend thrombolytic therapy to rural residents. Stroke. 2003;34(3):729-733. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12624299].
Silver B, Weber J, Fisher M. Medical therapy for ischemic stroke. [Review] [272 refs]. Clin Neuropharmacol. 1996;19(2):101-128. No original empirical evidence presented. [pmid: 8777766].
Silver FL, Rubini F, Black D, et al. Advertising strategies to increase public knowledge of the warning signs of stroke.[see comment]. Stroke. 2003;34(8):1965-1968. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12855823].
Simon JE, Sandler DL, Pexman JHW, et al. Is intravenous recombinant tissue plasminogen activator (rt-PA) safe for use in patients over 80 years old with acute ischaemic stroke? - The Calgary experience. Age & Ageing. 2004;33(2):143-149. No intervention of interest studied. [pmid: 14960429].
Singer RB. Stroke in the elderly treated for systolic hypertension (SHEP). Journal of Insurance Medicine (Seattle). 1991;23(4):265-269. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Singh V. Critical Care Assessment and Management of Acute Ischemic Stroke. Journal of Vascular & Interventional Radiology. 2004;15(1 II):S21-S27. No original empirical evidence presented. [pmid: 15101513].
Skolnick BE. Guidelines for acute stroke treatment centers. [Review] [35 refs]. Physical Medicine & Rehabilitation Clinics of North America. 1999;10(4):801-813. No original empirical evidence presented. [pmid: 10573708].
Sloan MA, Price TR, Petito CK, et al. Clinical features and pathogenesis of intracerebral hemorrhage after rt-PA and heparin therapy for acute myocardial infarction: the Thrombolysis in Myocardial Infarction (TIMI) II Pilot and Randomized Clinical Trial combined experience. Neurology. 1995;45(4):649-658. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7723950].
Sloan MA, Price TR, Terrin ML, et al. Ischemic cerebral infarction after rt-PA and heparin therapy for acute myocardial infarction. The TIMI-II pilot and randomized clinical trial combined experience. Stroke. 1997;28(6):1107-1114. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9183334].
Sloan MA, Sila CA, Mahaffey KW, et al. Prediction of 30-day mortality among patients with thrombolysis-related intracranial hemorrhage. Circulation. 1998;98(14):1376-1382. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9760291].
Smalling RW. Molecular biology of plasminogen activators: what are the clinical implications of drug design? [Review] [38 refs]. Am J Cardiol. 1996;78(12A):2-7. No original empirical evidence presented.
Smith RD. Extracranial-intracranial bypass in cerebral ischemia. Ochsner Journal. 2003;5(1):31-36. No original empirical evidence presented.
Smith RG, McLeod I, Clark DH. Evaluation of the volunteer stroke service in Scotland. Health Bull (Edinb). 1997;55(5):285-289. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11769105].
Snyder DW. The American Heart Association. Focus on public advocacy issues. J La State Med Soc. 1997;149(5):161-163. No human participants. [pmid: 9154752].
Sobel BE, Collen D. Strokes, statistics and sophistry in trials of thrombolysis for acute myocardial infarction. Am J Cardiol. 1993;71(5):424-427. No original empirical evidence presented. [pmid: 8430631].
Song SJ, Fei Z, Zhang X. [Comparison of the intracranial pressure value in patients with hypertensive intracerebral hemorrhage treated with traditional craniotomy and puncture drainage]. [Chinese]. Zhongguo Wei Zhong Bing Ji Jiu Yi Xue/Chinese Critical Care Medicine/Zhongguo Weizhongbing Jijiuyixue. 2003;15(9):532-534. Non-English publication.
SoRelle R. Recent clinical trial updates.[comment]. Circulation. 2002;106(12):e9029-e9032. No original empirical evidence presented. [pmid: 12234969].
Spedding M. Reasons why stroke trials underestimate the neuroprotective effects of drugs. Stroke. 2002;33(1):324-325. No human participants. [pmid: 11779937].
Spreadborough J, Atkinson D. The Chest, Heart and Stroke Association. Br J Hosp Med. 1991;46(6):360N. o human participants. [pmid: 1760660].
Srivastava AK, Prasad K. A study of factors delaying hospital arrival of patients with acute stroke. Neurol India. 2001;49(3):272-276. No intervention of interest studied. [pmid: 11593245].
Staessen JA, Fagard R, Thijs L, et al. Randomised double-blind comparison of placebo and active treatment for older patients with isolated systolic hypertension. The Systolic Hypertension in Europe (Syst-Eur) Trial Investigators.[see comment]. Lancet. 1997;350(9080):757-764. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9297994].
Stahl JE, Furie KL, Gleason S, et al. Stroke: Effect of implementing an evaluation and treatment protocol compliant with NINDS recommendations. [Review] [83 refs]. Radiology. 2003;228(3):659-668. No original empirical evidence presented. [pmid: 12954888].
Stamler J, Stamler R, Neaton JD. Blood pressure, systolic and diastolic, and cardiovascular risks. US population data. [Review] [77 refs]. Arch Intern Med. 1993;153(5):598-615. No original empirical evidence presented. [pmid: 8439223].
Stavropoulos SW, Solomon JA, Soulen MC, et al. Use of abciximab during infrainguinal peripheral vascular interventions: Initial experience. Radiology. 2003;227(3):657-661. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12773673].
Stead LG. Blood Pressure Control in Acute Stroke. Ann Emerg Med. 2004;43(1):129-132. No original empirical evidence presented. [pmid: 14707952].
Steg PG, Bonnefoy E, Chabaud S, et al. Impact of time to treatment on mortality after prehospital fibrinolysis or primary angioplasty: data from the CAPTIM randomized clinical trial.[see comment]. Circulation. 2003;108(23):2851-2856. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14623806].
Stegmayr B, Asplund K, Hulter-Asberg K, et al. Stroke units in their natural habitat: can results of randomized trials be reproduced in routine clinical practice? Riks-Stroke Collaboration. Stroke. 1999;30(4):709-714. No original empirical evidence presented. [pmid: 10187866].
Steiger HJ. Carotid endarterectomy--when to do it, how to do it? [Review] [65 refs]. Acta Neurochir (Wien). 1995;137(34):121-127. No original empirical evidence presented. [pmid: 8789651].
Steiner I, Gomori JM, Melamed E. The prognostic value of the CT scan in conservatively treated patients with intracerebral hematoma. Stroke. 1984;15(2):279-282. No intervention of interest studied. [pmid: 6701936].
Steiner MM, Brainin M, Austrian Stroke, et al. The quality of acute stroke units on a nation-wide level: the Austrian Stroke Registry for acute stroke units. [Review] [17 refs]. Eur J Neurol. 2003;10(4):353-360. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12823485].
Stern EB, Berman M, Thomas JJ, et al. Community education for stroke awareness: An efficacy study. Stroke. 1999;30(4):720-723. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10187868].
Sterzi R V. Treatment of intracerebral hemorrhage: the clinical evidences. Neurol Sci 2004;25 Suppl 1S12No original empirical evidence presented.
Stijnen T. Tutorial in biostatistics. Meta-analysis: formulating, evaluating, combining, and reporting by S-L. Normand, Statistics in Medicine, 18, 321–359 (1999). Stat Med. 2000;19(5):759-761. No human participants. [pmid: 10700745].
Stingele R, Bluhmki E, Hacke W. Bootstrap statistics of ECASS II data: just another post hoc analysis of a negative stroke trial?. Cerebrovasc Dis. 2001;11(1):30-33. No original empirical evidence presented. [pmid: 11173791].
Stingele R, Hacke W. Results of the Second European-Australasian Acute Stroke Study (ECASS II): How do they influence the use of thrombolytic therapy in acute ischemic stroke?. Intensivmedizin und Notfallmedizin. 1999;36(7):606-611. Non-English publication.
Stollberger C, Slany J, Brainin M, et al. Angiotensin-converting enzyme inhibitors and stroke prevention: what about the influence of atrial fibrillation and antithrombotic therapy?. Stroke. 2003;34(11):e208. No original empirical evidence presented. [pmid: 14563959].
Stolz E, Trittmacher S, Rahimi A, et al. Influence of recanalization on outcome in dural sinus thrombosis: a prospective study. Stroke. 2004;35(2):544-547. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 14715977].
Stone GW, Cox DA, Low R, et al. Safety and efficacy of a novel device for treatment of thrombotic and atherosclerotic lesions in native coronary arteries and saphenous vein grafts: Results from the multicenter X-sizer for treatment of thrombus and atherosclerosis in coronary applications trial (X-TRACT) study. Catheterization & Cardiovascular Interventions. 2003;58(4):419-427. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12652487].
Stone S. Stroke units: more trials needed. Age & Ageing. 1999;28(2):95-97. No original empirical evidence presented. [pmid: 10350402].
Stone SP. A trial of stroke unit (SU) versus comprehensive geriatric service (CGS) management of all stroke patients. Neurorehabilitation & Neural Repair. 1999;13(1):49. Unable to obtain by final date for inclusion.
Stordahl NJ, Back MR. The efficacy of carotid endarterectomy: a vascular surgery perspective reducing hospital stay.[erratum appears in Medsurg Nurs 2000 Aug;9(4):207]. [Review] [29 refs]. Medsurg Nurs. 2000;9(3):113-121. No original empirical evidence presented. [pmid: 11033700].
Strand T, Asplund K, Eriksson S, et al. A non-intensive stroke unit reduces functional disability and the need for long-term hospitalization. Stroke. 1985;16(1):29-34. No intervention of interest studied. [pmid: 3917584].
Straub S, Junghans U, Jovanovic V, et al. Systemic thrombolysis with recombinant tissue plasminogen activator and tirofiban in acute middle cerebral artery occlusion. Stroke. 2004;35(3):705-709. No intervention of interest studied. [pmid: 14752128].
Straznicky I, White HD, Granger CB, et al. Effects of four thrombolytic regimens in elderly patients. Cardiology Review. 1998;15(1):22-28. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Stroke centers can cut LOS, boost outcomes. Healthcare Benchmarks & Quality Improvement 2003;10(11):127–129. No original empirical evidence presented.
Stroke centers can cut LOS, boost outcomes: complicated process needs multidisciplinary team. Hosp Case Manag 2003;11(12):185–186. No original empirical evidence presented.
Stroke victims need to get to the hospital faster. Minn Med 1998;81(9):43. No original empirical evidence presented.
Sudlow C, Gubitz G, Sandercock P et al. Stroke prevention.[update in Clin Evid. 2002 Dec;(8):184–208; PMID: 12603877]. [Review][91 refs]. Clin Evid 2002;(7):175–198. No original empirical evidence presented.
Sug YS, Heller RF, Levi C, et al. Knowledge of stroke risk factors, warning symptoms, and treatment among an Australian urban population.[see comment]. Stroke. 2001;32(8):1926-1930. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11486127].
Sugiyama T, Lee JD, Shimizu H, et al. Influence of treated blood pressure on progression of silent cerebral infarction. J Hypertens. 1999;17(5):679-684. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10403612].
Sulch D, Evans A, Melbourn A, et al. Does an integrated care pathway improve processes of care in stroke rehabilitation? A randomized controlled trial. Age & Ageing. 2002;31(3):175-179. No intervention of interest studied. [pmid: 12006305].
Sulch D, Melbourn A, Perez I, et al. Integrated care pathways and quality of life on a stroke rehabilitation unit. Stroke. 2002;33(6):1600-1604. No intervention of interest studied. [pmid: 12052998].
Sulch D, Perez I, Melbourn A, et al. Evaluation of an integrated care pathway for stroke unit rehabilitation [4]. Age & Ageing. 2000;29(1):87N. o original empirical evidence presented. [pmid: 10690706].
Summers D, Soper PA. Implementation and evaluation of stroke clinical pathways and the impact on cost of stroke care. Can J Cardiovasc Nurs. 1998;13(1):69-87. No original empirical evidence presented.
Suyama J, Crocco T. Prehospital care of the stroke patient. [Review] [50 refs]. Emerg Med Clin North Am. 2002;20(3):537-552. No original empirical evidence presented. [pmid: 12379960].
Suzuki S, Kelley RE, Dandapani BK, et al. Acute leukocyte and temperature response in hypertensive intracerebral hemorrhage. Stroke. 1995;26(6):1020-1023. No intervention of interest studied. [pmid: 7762017].
Swarnkar AS, Jungreis CA, Wechsler LR, et al. Combined intravenous and intraarterial thrombolytic therapy for treatment of an acute ischemic stroke: a case report. Journal of Stroke & Cerebrovascular Diseases. 1999;8(4):264-267. Unable to obtain by final date for inclusion. [pmid: 17895175].
Szoeke CE, Parsons MW, Butcher KS, et al. Acute stroke thrombolysis with intravenous tissue plasminogen activator in an Australian tertiary hospital.[see comment]. Med J Aust. 2003;178(7):324-328. No intervention of interest studied. [pmid: 12670274].
Taguchi J, Freis ED. Partial versus complete control of blood pressure in the prevention of hypertensive complications. Circ Res. 1975;36(6 Suppl 1):257-260. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 1093757].
Takagi R, Kobayashi H, Hayashi H, et al. [A new three-dimensional CT reconstruction method for cerebral arteriovenous malformation: development and clinical evaluation of see-through view method]. [Japanese]. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica. 1996;56(9):676-678. Non-English publication.
Takayasu M, Nagatani T, Noda A, et al. Clinical safety and performance of Sugita titanium aneurysm clips. Acta Neurochir (Wien). 2000;142(2):159-162. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10795889].
Tan LB. Interpretation of IST and CAST stroke trials. International Stroke Trial. Chinese Acute Stroke Trial.[comment]. Lancet. 1997;350(9075):443-444. No human participants.
Tang Y, Chen S. Health promotion behaviors in Chinese family caregivers of patients with stroke. Health Promot Int. 2002;17(4):329-339. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12406921].
Tanne D, Reicher-Reiss H, Boyko V, et al. Stroke risk after anterior wall acute myocardial infarction. SPRINT Study Group. Secondary Prevention Reinfarction Israeli Nifedipine Trial. Am J Cardiol. 1995;76(11):825-826. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 7572664].
Tanne D, Schwammenthal Y. Hyperglycemia and early reperfusion therapy.[comment]. Stroke. 2003;34(5):1235-1241. No intervention of interest studied.
Tanne D, Turgeman D, Adler Y. Management of acute ischaemic stroke in the elderly: tolerability of thrombolytics. [Review] [97 refs]. Drugs. 2001;61(10):1439-1453. No original empirical evidence presented. [pmid: 11558833].
Taylor DW, Barnett HJ, Haynes RB, et al. Low-dose and high-dose acetylsalicylic acid for patients undergoing carotid endarterectomy: a randomised controlled trial. ASA and Carotid Endarterectomy (ACE) Trial Collaborators.[see comment]. Lancet. 1999;353(9171):2179-2184. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10392981].
Taylor KS. Patient software: consultation at the stroke of a key. Hosp Health Netw. 1994;68(17):72. No human participants. [pmid: 8069353].
Tellez H, Bauer RB. Dexamethasone as treatment in cerebrovascular disease. 1. A controlled study in intracerebral hemorrhage. Stroke. 1973;4(4):541-546. No intervention of interest studied. [pmid: 4579368].
Teach patients to recognize warning signs of stroke. [Review][0 refs]. RN 2002;65(10):24hf16–24hf18. No original empirical evidence presented.
Terashi A, Kobayashi Y, Katayama Y, et al. Clinical effects and basic studies of thrombolytic therapy on cerebral thrombosis. Seminars in Thrombosis & Hemostasis. 1990;16(3):236-241. No intervention of interest studied. [pmid: 2122521].
The PROGRESS trial was it unfairly reported by prescrire? Prescrire Int 2003;12(63):38–39. Unable to obtain by final date for inclusion.
Thijs VN. Imaging strategy for acute stroke therapy. [Review][26 refs]. Jbr-Btr: Organe de la Societe Royale Belge de Radiologie 2003;86(6):350–353. No original empirical evidence presented.
Thomas SH, Kociszewski C, Schwamm LH, et al. The evolving role of helicopter emergency medical services in the transfer of stroke patients to specialized centers. Prehosp Emerg Care. 2002;6(2):210-214. No intervention of interest studied. [pmid: 11962569].
Thomas V. An open evening for stroke patients and relatives. Br J Nurs. 1992;1(11):557-559. No original empirical evidence presented. [pmid: 1472843].
Thomas WA, Cole PV, Etherington NJ, et al. Electrical activity of the cerebral cortex during induced hypotension in man. A comparison of sodium nitroprusside and trimetaphan. Br J Anaesth. 1985;57(2):134-141. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 3882108].
Thomassen L, Waje-Andreassen U, Morsund AH, et al. Thrombolytic therapy in acute ischaemic stroke. Cerebrovasc Dis. 2002;13(3):163-167. No intervention of interest studied. [pmid: 11914532].
Thompson PL. Thrombolytic therapy for coronary occlusion.[comment]. Med J Aust. 1992;157(2):75-77. No original empirical evidence presented. [pmid: 1630392].
Thornton H. Thrombolysis for acute ischaemic stroke. Good quality research that addresses patients" needs is required.[comment]. BMJ. 2002;325(7376):1363. No original empirical evidence presented.
Thurston SE. Neuroprotective therapy in acute ischemic stroke. [Review] [10 refs]. Va Med Q. 1998;125(2):131-132. No original empirical evidence presented. [pmid: 9577717].
Tiffany BR, Carrubba CL. Emergency medical services and the acute stroke: changing the paradigm. J Fla Med Assoc. 1997;84(4):253-257. No original empirical evidence presented. [pmid: 9342913].
Tilley BC, Marler J, Geller NL, et al. Use of a global test for multiple outcomes in stroke trials with application to the National Institute of Neurological Disorders and Stroke t-PA Stroke Trial. Stroke. 1996;27(11):2136-2142. No intervention of interest studied. [pmid: 8898828].
Tilling K, Wolfe C. Re: Randomized controlled study of stroke unit versus stroke team care in different stroke subtypes.[comment]. Stroke. 2002;33(7):1741-1742. No original empirical evidence presented. [pmid: 12105338].
Timsit SG, Sacco RL, Mohr JP, et al. Brain infarction severity differs according to cardiac or arterial embolic source. Neurology. 1993;43(4):728-733. No intervention of interest studied. [pmid: 8469331].
Timsit SG, Sacco RL, Mohr JP, et al. Early clinical differentiation of cerebral infarction from severe atherosclerotic stenosis and cardioembolism. Stroke. 1992;23(4):486-491. No intervention of interest studied. [pmid: 1561677].
Tissue plasminogen activator for acute ischemic stroke. The National Institute of Neurological Disorders and Stroke rt-PA Stroke Study Group.[see comment]. N Engl J Med 1995;333(24):1581–1587. No intervention of interest studied.
Todo K, Watanabe M, Fukunaga R, et al. Imaging of distal internal carotid artery by ultrasonography with a 3.5-MHz convex probe. Stroke. 2002;33(7):1792-1794. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12105354].
Tohmo H, Karanko M, Scheinin M, et al. Enalapril premedication attenuates the blood pressure response to tracheal intubation and stabilizes postoperative blood pressure after controlled hypotension with sodium nitroprusside in neurovascular patients. J Neurosurg Anesthesiol. 1993;5(1):13-21. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8431665].
Tong DC. Intravenous rt-PA for stroke. [Review] [41 refs]. Current Medical Research & Opinion. 2002;18 Suppl:2s35-s43. No original empirical evidence presented.
Toni D, Argentino C, Gentile M, et al. Circadian variation in the onset of acute cerebral ischemia: ethiopathogenetic correlates in 80 patients given angiography. Chronobiol Int. 1991;8(5):321-326. No intervention of interest studied. [pmid: 1818782].
Toni D, Chamorro A, Kaste M, et al. Acute treatment of ischaemic stroke. Cerebrovasc Dis. 2004;17(SUPPL. 2):30-46. No original empirical evidence presented. [pmid: 14707405].
Toni D, Fiorelli M, De Michele M, et al. Clinical and prognostic correlates of stroke subtype misdiagnosis within 12 hours from onset.[erratum appears in Stroke 1996 Jan;27(1):152]. Stroke. 1995;26(10):1837-1840. No intervention of interest studied. [pmid: 7570735].
Toni D, Gallo V, Falcou A, et al. Treatment of cerebrovascular diseases: state of the art and perspectives. J Cardiovasc Pharmacol. 2001;38 Suppl:2S83-S86. No original empirical evidence presented.
Toni D, Iweins F, von Kummer R, et al. Identification of lacunar infarcts before thrombolysis in the ECASS I study. Neurology. 2000;54(3):684-688. No intervention of interest studied. [pmid: 10680804].
Traub YM, Ayache AS, Groshar D. The effect of enalapril and calcium antagonists on blood pressure and cerebral perfusion in elderly hypertensives. Journal of Hypertension - Supplement. 1991;9(6):S378-S379. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Travis LH, Flemming KD, Brown RD, et al. Awareness of Stroke Risk Factors, Symptoms, and Treatment is Poor in People at Highest Risk. Journal of Stroke & Cerebrovascular Diseases. 2003;12(5):221-227. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 17903931].
Trenkwalder P. Antihypertensive treatment with calcium channel blockers: Pharmacological pornography or useful intervention?. Nephrology Dialysis Transplantation. 2004;19(1):17-20. No original empirical evidence presented.
Trial of secondary prevention with atenolol after transient ischemic attack or nondisabling ischemic stroke. The Dutch TIA Trial Study Group. Stroke
Trotter G. Why were the benefits of tPA exaggerated?. West J Med. 2002;176(3):194-197. No original empirical evidence presented. [pmid: 12016246]. [pmcid: 1071715].
Trouillas P, Nighoghossian N, Getenet JC, et al. Open trial of intravenous tissue plasminogen activator in acute carotid territory stroke. Correlations of outcome with clinical and radiological data. Stroke. 1996;27(5):882-890. No intervention of interest studied. [pmid: 8623108].
Tubler T, Schluter M, Dirsch O, et al. Balloon-protected carotid artery stenting: relationship of periprocedural neurological complications with the size of particulate debris. Circulation. 2001;104(23):2791-2796. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11733396].
Tuomilehto J, Puska P, Nissinen A. Hypertension programme of the North Karelia Project. Scand J Soc Med. 1976;4(2):67-70. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 959785].
Turnbull GB. The power of knowledge. Ostomy Wound Management. 2004;50(6):14-16. Unable to obtain by final date for inclusion.
Turner JM, Powell D, Gibson RM, et al. Intracranial pressure changes in neurosurgical patients during hypotension induced with sodium nitroprusside or trimetaphan. Br J Anaesth. 1977;49(5):419-425. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 861108].
Ueda T, Yuh WT, Taoka T. Clinical application of perfusion and diffusion MR imaging in acute ischemic stroke. [Review] [51 refs]. J Magn Reson Imaging. 1999;10(3):305-309. No original empirical evidence presented. [pmid: 10508290].
Umemura K, Kondo K, Ikeda Y, et al. Pharmacokinetics and safety of the novel amino-3-hydroxy-5-methylisoxazole-4-propionate receptor antagonist YM90K in healthy men. J Clin Pharmacol. 1997;37(8):719-727. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9378844].
Ushering in a new era in stroke care. Hosp Technol Ser 1997;16(12):8–9. No original empirical evidence presented.
van den Bos GA, Smits JP, et al. Socioeconomic variations in the course of stroke: unequal health outcomes, equal care?. Journal of Epidemiology & Community Health. 2002;56(12):943-948. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12461116]. [pmcid: 1756981].
Van Der LH, Boers G, Tange H, et al. PropeR: A multi disciplinary EPR system. Int J Med Inf. 2003;70(23):149-160. No human participants.
van der, Worp HB, Kappelle LJ, et al. The effect of tirilazad mesylate on infarct volume of patients with acute ischemic stroke. Neurology. 2002;58(1):133-135. No intervention of interest studied. [pmid: 11781420].
van Gijn J. Thrombolysis in ischemic stroke: double or quits? [Review] [21 refs]. Circulation. 1996;93(9):1616-1617. No original empirical evidence presented. [pmid: 8653863].
van Heesewijk, HP Vos, JA Louwerse et al. New brain lesions at MR imaging after carotid angioplasty and stent placement. Radiology 2002;224(2):361–365. Study did not involve relevant population [defined as adult (>16) with acute stroke].
van Loon J, Waerzeggers Y, Wilms G, et al. Early endovascular treatment of ruptured cerebral aneurysms in patients in very poor neurological condition. Neurosurgery. 2002;50(3):457-464. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11841712].
van Veenendaal H, Grinspun DR, Adriaanse HP. Educational needs of stroke survivors and their family members, as perceived by themselves and by health professionals. Patient Education & Counseling. 1996;28(3):265-276. No original empirical evidence presented. [pmid: 8852102].
Vanderschueren S, Dens J, Kerdsinchai P, et al. Randomized coronary patency trial of double-bolus recombinant staphylokinase versus front-loaded alteplase in acute myocardial infarction. Am Heart J. 1997;134(2 Pt 1):213-219. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9313600].
Venketasubramanian N. Stroke in Singapore--an overview. Singapore Med J. 1999;40(1):48-52. No original empirical evidence presented. [pmid: 10361488].
Venketasubramanian N, Chan BP, Lim E, et al. Stroke disease management--a framework for comprehensive stroke care. [Review] [30 refs]. Ann Acad Med Singapore. 2002;31(4):452-460. No original empirical evidence presented. [pmid: 12161880].
Verdecchia P, Schillaci G, Reboldi G, et al. Ambulatory monitoring for prediction of cardiac and cerebral events. Blood Press Monit. 2001;6(4):211-215. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11805472].
Vlcek M, Schillinger M, Lang W, et al. Association between course of blood pressure within the first 24 hours and functional recovery after acute ischemic stroke. Ann Emerg Med. 2003;42(5):619-626. No intervention of interest studied. [pmid: 14581913].
Vo KD, Santiago F, Lin W, et al. MR imaging enhancement patterns as predictors of hemorrhagic transformation in acute ischemic stroke. AJNR Am J Neuroradiol. 2003;24(4):674-679. No intervention of interest studied. [pmid: 12695202].
von Kummer R. Brain hemorrhage after thrombolysis: good or bad?[comment]. Stroke. 2002;33(6):1446-1447. No original empirical evidence presented. [pmid: 12052965].
von Kummer R, Forsting M, Hutschenreuter M, et al. Angiography in acute stroke due to occlusions of intracerebral arteries before and after treatment with intravenous recombinant tissue plasminogen activator. Stroke. 1990;21(Suppl I):94-95. No intervention of interest studied. [pmid: 2300997].
von Kummer R, Hacke W. Safety and efficacy of intravenous tissue plasminogen activator and heparin in acute middle cerebral artery stroke. Stroke. 1992;23(5):646-652. No intervention of interest studied. [pmid: 1579960].
Wachters-Kaufmann CS. A Dutch “Poststroke Guide”: distribution and use. Patient Education & Counseling. 1999;37(1):81-88. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10640122].
Wade DT. Cognitive assessment and neurological rehabilitation. Clin Rehabil. 2002;16(2):117-118. No original empirical evidence presented. [pmid: 11911509].
Waigand J, Gross CM, Uhlich F, et al. Elective stenting of carotid artery stenosis in patients with severe coronary artery disease.[see comment]. Eur Heart J. 1998;19(9):1365-1370. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9792262].
Warach S. Stroke neuroimaging. [Review] [20 refs]. Stroke. 2003;34(2):345-347. No original empirical evidence presented. [pmid: 12574531].
Wardlaw JM. The place of thrombolysis in the management of cerebral embolism after heart valve replacement. [Review] [8 refs]. J Heart Valve Dis. 1994;3(6):611-612. No original empirical evidence presented. [pmid: 8000603].
Wardlaw JM, Lewis SC, Sandercock PA, et al. Why do Italian stroke patients receive CT scans earlier than UK patients? International Stroke Trial Collaborators in Italy and the UK. Postgrad Med J. 1999;75(879):18-21. No intervention of interest studied. [pmid: 10396581]. [pmcid: 1741095].
Wardlaw JM, Lindley RI, Lewis S. Thrombolysis for acute ischemic stroke: still a treatment for the few by the few. West J Med. 2002;176(3):198-199. No original empirical evidence presented. [pmid: 12016247]. [pmcid: 1071716].
Wardlaw JM, Sandercock PA, Berge E. Thrombolytic therapy with recombinant tissue plasminogen activator for acute ischemic stroke: where do we go from here? A cumulative meta-analysis. Stroke. 2003;34(6):1437-1442. No original empirical evidence presented. [pmid: 12730560].
Wardlaw JM, Warlow CP, Counsell C. Systematic review of evidence on thrombolytic therapy for acute ischaemic stroke.[see comment]. Lancet. 1997;350(9078):607-614. No original empirical evidence presented. [pmid: 9288042].
Wardlaw JM, Zoppo G, Yamaguchi T et al. Thrombolysis for acute ischaemic stroke.[update of Cochrane Database Syst Rev. 2000;(2):CD000213; PMID: 10796329]. [Review][54 refs]. Cochrane Database Syst Rev 2003;(3):CD000213No original empirical evidence presented.
Warlow C, Sudlow C, Dennis M, et al. Stroke.[see comment]. [Review] [101 refs]. Lancet. 2003;362(9391):1211-1224. No original empirical evidence presented. [pmid: 14568745].
Wasay M. Neurological Care in Pakistan: Actions are needed. J Pak Med Assoc. 2003;53(12):576. No original empirical evidence presented. [pmid: 14765934].
Weaver WD, White HD, Wilcox RG, et al. Comparisons of characteristics and outcomes among women and men with acute myocardial infarction treated with thrombolytic therapy. GUSTO-I investigators.[comment]. JAMA. 1996;275(10):777-782. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8598594].
Weber CE. Stroke: brain attack, time to react. [Review] [36 refs]. AACN Clin Issues. 1995;6(4):562-575. No original empirical evidence presented. [pmid: 7493260].
Weber J, Remonda L, Mattle HP, et al. Selective intra-arterial fibrinolysis of acute central retinal artery occlusion. Stroke. 1998;29(10):2076-2079. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9756585].
Weber MA. The ALLHAT report: a case of information and misinformation. J Clin Hypertens. 2003;5(1):9-13. No original empirical evidence presented.
Wechsler LR. Innovative strategies in the management of acute stroke. [Review] [42 refs]. Curr Cardiol Rep. 2002;4(2):135-140. No original empirical evidence presented. [pmid: 11827637].
Weder AB. Best bang for the buck?. Curr Hypertens Rep. 2003;5(1):3-5. No original empirical evidence presented. [pmid: 12530929].
Wein TH, Hickenbottom SL, Morgenstern LB, et al. Safety of tissue plasminogen activator for acute stroke in menstruating women. [Review] [11 refs]. Stroke. 2002;33(10):2506-2508. No intervention of interest studied. [pmid: 12364745].
Wein TH, Staub L, Felberg R, et al. Activation of emergency medical services for acute stroke in a nonurban population: the T.L.L. Temple Foundation Stroke Project. Stroke. 2000;31(8):1925-1928. No intervention of interest studied. [pmid: 10926958].
Weir CJ, Lees KR. Comparison of stratification and adaptive methods for treatment allocation in an acute stroke clinical trial. Stat Med. 2003;22(5):705-726. No human participants. [pmid: 12587101].
Weir CJ, Murray GD, Dyker AG, et al. Is hyperglycaemia an independent predictor of poor outcome after acute stroke? Results of a long-term follow up study.[see comment]. BMJ. 1997;314(7090):1303-1306. No intervention of interest studied. [pmid: 9158464]. [pmcid: 2126557].
Weisberg LA. “Stroke and struck”: Protecting the brain from cerebrovascular disease. South Med J. 2003;96(4):331. No original empirical evidence presented. [pmid: 12916549].
Weiss PLT, Naveh Y, Katz N. Design and testing of a virtual environment to train stroke patients with unilateral spatial neglect to cross a street safely. Occup Ther Int. 2003;10(1):39-55. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12830318].
Wester P, Strand T, Wahlgren NG, et al. An open study of clomethiazole in patients with acute cerebral infarction. Cerebrovasc. Dis. 1998;8(3):188-190. No intervention of interest studied.
Westrick E. National initiatives: management of heart disease and stroke. [Review] [3 refs]. Medicine & Health, Rhode Island. 1999;82(5):176-177. No original empirical evidence presented.
Whisnant JP. Effectiveness versus efficacy of treatment of hypertension for stroke prevention. [Review] [22 refs]. Neurology. 1996;46(2):301-307. No original empirical evidence presented. [pmid: 8614485].
White HD, Barbash GI, Califf RM, et al. Age and outcome with contemporary thrombolytic therapy: Results from the GUSTO-I trial. Circulation. 1996;94(8):1826-1833. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 8873656].
White WB, LaRocca GM. Chronopharmacology of cardiovascular therapy. [Review] [65 refs]. Blood Press Monit. 2002;7(4):199-207. No original empirical evidence presented. [pmid: 12198335].
Whitney F. Drug therapy for acute stroke. [Review] [21 refs]. J Neurosci Nurs. 1994;26(2):111-117. No original empirical evidence presented. [pmid: 8077772].
Widjaja LS, Chan BP, Chen H, et al. Variance analysis applied to a stroke pathway: how this can improve efficiency of healthcare delivery. Ann Acad Med Singapore. 2002;31(4):425-430. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12161876].
Wiegand N, Luthy R, Vogel B, et al. Intravenous thrombolysis for ischaemic stroke is also safe and efficient without a specialised neuro-intensive care unit. Swiss Med Wkly. 2004;134(12):14-17. No intervention of interest studied. [pmid: 14745662].
Wiegand N, Luthy R, Vogel B, et al. Intravenous thrombolysis for acute ischaemic stroke in a hospital without a specialised neuro-intensive care unit. Swiss Med Wkly. 1–10. 2004;134(12):14-17. Unable to obtain by final date for inclusion. [pmid: 14745662].
Wilcox RG. Clinical trials in thrombolytic therapy: what do they tell us? INJECT 6-month outcomes data. [Review] [8 refs]. Am J Cardiol. 1996;78(12A):20-23. No original empirical evidence presented.
Wildemann B, Hutschenreuter M, Krieger D, et al. Infusion of recombinant tissue plasminogen activator for treatment of basilar artery occlusion. Stroke. 1990;21(10):1513-1514. No original empirical evidence presented. [pmid: 2120803].
Wildermuth S, Knauth M, Brandt T, et al. Role of CT angiography in patient selection for thrombolytic therapy in acute hemispheric stroke.[see comment]. Stroke. 1998;29(5):935-938. No intervention of interest studied. [pmid: 9596238].
Wiles R, Pain H, Buckland S, et al. Providing appropriate information to patients and carers following a stroke. J Adv Nurs. 1998;28(4):794-801. No intervention of interest studied. [pmid: 9829668].
Wilkinson G, Parcell M, MacDonald A. Cerebrovascular accident clinical pathway. J Qual Clin Pract. 2000;20(23):109-112. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11057994].
Williams B. Drug specific benefits and cardiovascular and stroke outcomes.[comment]. J Hypertens. 2003;21(9):1609-1610. No original empirical evidence presented. [pmid: 12923385].
Williams B. Drug treatment of hypertension: Implications of ALLHAT. Heart. 2003;89(6):589-590. No original empirical evidence presented. [pmid: 12748205]. [pmcid: 1767664].
Williams LS, Bruno A, Rouch D, et al. Stroke patients" knowledge of stroke. Influence on time to presentation. Stroke. 1997;28(5):912-915. No intervention of interest studied. [pmid: 9158624].
Williams LS, Rotich J, Qi R, et al. Effects of admission hyperglycemia on mortality and costs in acute ischemic stroke. Neurology. 2002;59(1):67-71. No intervention of interest studied. [pmid: 12105309].
Willmot M, Leonardi-Bee J, Bath PM. High blood pressure in acute stroke and subsequent outcome: a systematic review. [Review] [57 refs]. Hypertension. 2004;43(1):18-24. No original empirical evidence presented. [pmid: 14662649].
Willmot MR, Bath PMW. The potential of nitric oxide therapeutics in stroke. Expert Opin Investig Drugs. 2003;12(3):455-470. No original empirical evidence presented.
Willoughby DF, Sanders L, Privette A. The impact of a stroke screening program. Public Health Nurs. 2001;18(6):418-423. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11737810].
Wills AJ. Letter from Cuba. Journal of Neurology, Neurosurgery & Psychiatry. 2003;74(3):285-286. No original empirical evidence presented.
Wilson E. First International Conference on Women, Heart Disease and Stroke: science and policy in action. Can J Cardiol. 2000;16(6):726-727. No original empirical evidence presented. [pmid: 10863162].
Wilson E, Taylor G, Phillips S, et al. Creating a Canadian stroke system. [Review] [21 refs]. CMAJ Canadian Medical Association Journal. 2001;164(13):1853-1855. No human participants.
Wintermark M, Reichhart M, Cuisenaire O, et al. Comparison of admission perfusion computed tomography and qualitative diffusion- and perfusion-weighted magnetic resonance imaging in acute stroke patients.[see comment]. Stroke. 2002;33(8):2025-2031. No intervention of interest studied. [pmid: 12154257].
Wittkowsky AK. The stroke pharmacopeia: current medical therapies. [Review] [15 refs]. Pharmacotherapy. 1998;18(3 Pt 2):94S-100S. No original empirical evidence presented. [pmid: 9619493].
Wittkowsky AK. Pharmacists and stroke prevention. Am J Health Syst Pharm. 1996;53(9):1009. No original empirical evidence presented. [pmid: 8744461].
Woessner R, Grauer MT, Dieterich H-J, et al. Influence of long-term volume therapy with hydroxyethyl starch on leukocytes in patients with acute stroke. Arzneimittelforschung. 2003;53(6):402-406. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 12872610].
Woisetschlager C, Kittler H, Oschatz E, et al. Out-of-hospital diagnosis of cerebral infarction versus intracranial hemorrhage. Intensive Care Med. 2000;26(10):1561-1565. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11126273].
Wojner AW, Morgenstern L, Alexandrov AV, et al. Paramedic and emergency department care of stroke: baseline data from a citywide performance improvement study. Am J Crit Care. 2003;12(5):411-417. No intervention of interest studied. [pmid: 14503424].
Wolfe C, Rudd A, Dennis M, et al. Taking acute stroke care seriously. In the absence of evidence we should manage acute stroke as a medical emergency.[see comment]. BMJ. 2001;323(7303):5-6. No original empirical evidence presented. [pmid: 11440924]. [pmcid: 1120679].
Wolfe CD. Studies of death and disability from stroke: how can they effect change in service provision?. Int J Epidemiol. 1995;24 Suppl:1S60-S64. No original empirical evidence presented.
Wolpert SM. An open multicenter study of the radiologic changes seen after various doses of r-TPA in patients with acute stroke: preliminary results. AJNR Am J Neuroradiol. 1988;9(5):1038. No intervention of interest studied.
Wong W-K, Kuo C-H, Hou CJY, et al. Successful local thrombolytic therapy and percutaneous transluminal angioplasty for acute brachial artery occlusion in a case with recent stroke. Acta Cardiologica Sinica. 2003;19(1):48-52. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Woo D. Ischemic versus hemorrhagic stroke: Rating the risk factors. J Crit Illn. 2003;18(5):194-195. No original empirical evidence presented.
Woo D, Broderick JP, Kothari RU, et al. Does the National Institutes of Health Stroke Scale favor left hemisphere strokes? NINDS t-PA Stroke Study Group. Stroke. 1999;30(11):2355-2359. No intervention of interest studied. [pmid: 10548670].
Wood VA, Hewer RL. The prevention and management of stroke. [Review] [72 refs]. J Public Health Med. 1996;18(4):423-431. No original empirical evidence presented. [pmid: 9023801].
Wood-Dauphinee S. A Trial Of Team Care In The Treatment Of Acute Stroke [Dissertation]. 1982. Unable to obtain by final date for inclusion.
Woods A. Patient-teaching aid. “Am I having a stroke?”. Nursing (Brux). 1999;29(12):32h. n8No human participants.
Wright V, Horvath R, Baird AE. Aortic dissection presenting as acute ischemic stroke. Neurology. 2003;61(4):581-582. No intervention of interest studied. [pmid: 12939452].
Xavier AR, Siddiqui AM, Kirmani JF, et al. Clinical potential of intra-arterial thrombolytic therapy in patients with acute ischaemic stroke. [Review] [58 refs]. CNS Drugs. 2003;17(4):213-224. No original empirical evidence presented. [pmid: 12665395].
Xi G, Keep RF, Hoff JT. Pathophysiology of brain edema formation. [Review] [107 refs]. Neurosurg Clin N Am. 2002;13(3):371-383. No original empirical evidence presented. [pmid: 12486926].
Yamada JY, Yee H, Fitzgerald M, et al. Community education on stroke. World Health Forum. 1992;13(1):44-46. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 1379049].
Yamaguchi T, Kikuchi H, Hayakawa T, et al. Clinical efficacy and safety of intravenous tissue plasminogen activator in acute embolic stroke: a randomized, double-blind, dose-comparison study of duteplase. Thrombolytic Therapy in Acute Ischemic Stroke III Tokyo : Springer-Verlag. 1995;1995:1s. t ed. 223–229p. Unable to obtain by final date for inclusion.
Yamaguchi T, Kikuchi H, Hayakawa T, et al. Efficacy and safety of tissue plasminogen activator in patients with acute embolic stroke. J Clin Neurosci. 1995;2(1):90-91. No intervention of interest studied.
Yamaguchi T, Sano K, Takakura K, et al. Ebselen in acute ischemic stroke: a placebo-controlled, double-blind clinical trial. Ebselen Study Group. Stroke. 1998;29(1):12-17. No intervention of interest studied. [pmid: 9445321].
Yamashita LF, Fukujima MM, Granitoff N, et al. [Patients with ischemic stroke are taken care quickly in Sao Paulo Hospital]. [Portuguese]. Arq Neuropsiquiatr. 2004;62(1):96-102. Unable to obtain by final date for inclusion. [pmid: 15122441].
Yoon PH, Kim DI, Jeon P, et al. Cerebral cavernous malformations: serial magnetic resonance imaging findings in patients with and without gamma knife surgery. Neurol Med Chir (Tokyo). 1998;38 Suppl:255-261. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 10235015].
Yoon SS, Byles J. Perceptions of stroke in the general public and patients with stroke: a qualitative study.[see comment]. BMJ. 2002;324(7345):1065-1068. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 11991910]. [pmcid: 104333].
Yoon W, Seo JJ, Kim JK, et al. Contrast enhancement and contrast extravasation on computed tomography after intra-arterial thrombolysis in patients with acute ischemic stroke. Stroke. 2004;35(4):876-881. No intervention of interest studied. [pmid: 14988575].
York KA. Rural case management for stroke: the development of a community-based screening and education program. Lippincotts Case Manag. 2003;8(3):98-114. No intervention of interest studied. [pmid: 12777970].
Young C, Summerfield R, Schwartz M, et al. Radiosurgery for arteriovenous malformations: the University of Toronto experience. Can J Neurol Sci. 1997;24(2):99-105. Study did not involve relevant population [defined as adult (>16) with acute stroke]. [pmid: 9164684].
Young J. My place or yours--what is the best place for early stroke care?[comment]. Age & Ageing. 2001;30(3):185-186. No original empirical evidence presented. [pmid: 11443017].
Young J, Murray J, Forster A. Review of longer-term problems after disabling stroke. Rev Clin Gerontol. 2003;13(1):55-65. No original empirical evidence presented.
Young JB. The primary care stroke gap. Br J Gen Pract. 2001;51(471):787-788. No original empirical evidence presented. [pmid: 11677699]. [pmcid: 1314121].
Yu RF, San Jose MC, Manzanilla, et al. Sources and reasons for delays in the care of acute stroke patients. J Neurol Sci. 2002;199(12):49-54. No intervention of interest studied. [pmid: 12084442].
Yudkin JS. Preventing stroke with ramipril. Superiority of particular class of antihypertensive agent remains to be shown.[see comment][comment]. BMJ. 2002;325(7361):439. No original empirical evidence presented.
Yuh WT, Taoka T, Ueda T, et al. Imaging helps identify who benefits from stroke intervention. Diagn Imaging (San Franc). 1999;21(12):77-82. No original empirical evidence presented. [pmid: 10724845].
Yusuf S, Lonn E. Anti-ischaemic effects of ACE inhibitors: review of current clinical evidence and ongoing clinical trials. [erratum appears in Eur Heart J. Nov. 1998;19(11):1742. ]. [Review][44 refs]. Eur Heart J 1998;19 Suppl JJ36–J44. No original empirical evidence presented.
Zahn D. Preventing and treating stroke. Can Pharm J. 2003;136(10):32. No original empirical evidence presented.
Zahn D. Stroke - A medical emergency. Can Pharm J. 2003;136(10):3. No human participants.
Zetterling MR-E. High intraoperative blood loss may be a risk factor for postoperative hematoma. J Neurosurg Anesthesiol. 2004;16(2):151-155. Study did not involve relevant population [defined as adult (>16) with acute stroke].
Zhang SF, He MD, Li C. [Clinical curative effect of dengzhanhua injection on acute cerebral infarction: a report of 100 cases]. [Chinese]. Hunan Yi Ke Da Xue Xue Bao. 6–28. 2002;27(3):235-238. Non-English publication. [pmid: 12575301].
Zhu XL, Chan MS, Poon WS. Spontaneous intracranial hemorrhage: which patients need diagnostic cerebral angiography? A prospective study of 206 cases and review of the literature. [Review] [27 refs]. Stroke. 1997;28(7):1406-1409. No intervention of interest studied. [pmid: 9227692].
Zingmark P-H, Ekblom M, Odergren T, et al. Population pharmacokinetics of clomethiazole and its effect on the natural course of sedation in acute stroke patients. Br J Clin Pharmacol. 2003;56(2):173-183. No intervention of interest studied. [pmid: 12895190]. [pmcid: 1884288].
Zivin JA. Diffusion-weighted MRI for diagnosis and treatment of ischemic stroke.[comment]. Ann Neurol. 1997;41(5):567-568. No original empirical evidence presented. [pmid: 9153516].
Zivin JA, Choi DW. Stroke therapy. Sci Am. 1991;265(1):56-63. No original empirical evidence presented.
Zuger A. A big study yields big questions. N Engl J Med. 2003;349(3):213-214. No original empirical evidence presented. [pmid: 12867605].