# References and Included Studies

1 The World Health Organization MONICA Project (monitoring trends and determinants in cardiovascular disease): a major international collaboration. WHO MONICA Project Principal Investigators. J Clin Epidemiol 1988; 41(2):105–114.
2 van GJ, Rinkel GJ. Subarachnoid haemorrhage: diagnosis, causes and management. [Review] [288 refs]. Brain. 2001;124(Pt 2):249-278. [pmid: 11157554].
3 Matchar, D. B. and Samsa, G. P. Secondary and Teritary Prevention of Stroke. Patient Outcomes Research Team(PORT) Final Report Phase 1. Rockville, MD USA: Agency for Healthcare Research and Quality., 2000.
4 The surveillance of Stroke The WHO STEPwise Approach. 2002.
5 Alberts MJ, Hademenos G, Latchaw RE, et al. Recommendations for the establishment of primary stroke centers. Brain Attack Coalition. JAMA. 2000;283(23):3102-3109. [pmid: 10865305].
6 Brice JH, Griswell JK, Delbridge TR, et al. Stroke: from recognition by the public to management by emergency medical services. [Review] [32 refs]. Prehosp Emerg Care. 2002;6(1):99-106. [pmid: 11789659].
7 American Heart Association. Heart Disease and Stroke Statistics - 2004 Update. Available at: http://www.americanheart.org/ Dallas, Texas: American Heart Association. 2003.
8 Broderick JP. William M. Feinberg Lecture: stroke therapy in the year 2025: burden, breakthroughs, and barriers to progress. Stroke. 2004;35(1):205-211. [pmid: 14671248].
9 Heart and Stroke Foundation of Canada. The Changing Face of Heart Disease and Stroke in Canada. 1999. Ottawa, Canada, Heart and Stroke Foundation of Canada.
10 Bonita R, Stewart A, Beaglehole R. International trends in stroke mortality: 1970-1985. Stroke. 1990;21(7):989-992. [pmid: 2368114].
11 McGovern PG, Burke GL, Sprafka JM, et al. Trends in mortality, morbidity, and risk factor levels for stroke from 1960 through 1990. The Minnesota Heart Survey. JAMA. 1992;268(6):753-759. [pmid: 1640576].
12 Wolf PA, D'Agostino RB, O'Neal MA, et al. Secular trends in stroke incidence and mortality. The Framingham Study. Stroke. 1992;23(11):1551-1555. [pmid: 1440701].
13 Wolfe CD, Burney PG. Is stroke mortality on the decline in England?. Am J Epidemiol. 1992;136(5):558-565. [pmid: 1442719].
14 Whisnant JP. The decline of stroke. Stroke. 1984;15(1):160-168. [pmid: 6364462].
15 Ostfeld AM. A review of stroke epidemiology. Epidemiol Rev. 1980;2:136-152. [pmid: 7000533].
16 Broderick JP, Phillips SJ, Whisnant JP, et al. Incidence rates of stroke in the eighties: the end of the decline in stroke?. Stroke. 1989;20(5):577-582. [pmid: 2718196].
17 Brown RD, Whisnant JP, Sicks JD, et al. Stroke incidence, prevalence, and survival: secular trends in Rochester, Minnesota, through 1989. Stroke. 1996;27(3):373-380. [pmid: 8610298].
18 Khaw KT. Epidemiology of stroke. J Neurol Neurosurg Psychiatry. 1996;61(4):333-338. [pmid: 8890767]. [pmcid: 486569].
19 Kissela B, Schneider A, Kleindorfer D, et al. Stroke in a biracial population: the excess burden of stroke among blacks. Stroke. 2004;35(2):426-431. [pmid: 14757893].
20 Schneider AT, Kissela B, Woo D, et al. Ischemic stroke subtypes: a population-based study of incidence rates among blacks and whites. Stroke. 2004;35(7):1552-1556. [pmid: 15155974].
21 Kissela B, Broderick J, Woo D, et al. Greater Cincinnati/Northern Kentucky Stroke Study: volume of first-ever ischemic stroke among blacks in a population-based study. Stroke. 2001;32(6):1285-1290. [pmid: 11387488].
22 Howard G, Anderson R, Sorlie P, et al. Ethnic differences in stroke mortality between non-Hispanic whites, Hispanic whites, and blacks. The National Longitudinal Mortality Study. Stroke. 1994;25(11):2120-2125. [pmid: 7974531].
23 Stewart JA, Dundas R, Howard RS, et al. Ethnic differences in incidence of stroke: prospective study with stroke register. BMJ. 1999;318(7189):967-971. [pmid: 10195965]. [pmcid: 27822].
24 Gale CR, Martyn CN. The conundrum of time trends in stroke. J R Soc Med. 1997;90(3):138-143. [pmid: 9135611]. [pmcid: 1296178].
25 Stegmayr B, Asplund K. Exploring the declining case fatality in acute stroke. Population-based observations in the northern Sweden MONICA Project. J Intern Med. 1996;240(3):143-149. [pmid: 8862123].
26 Stegmayr B, Asplund K, Wester PO. Trends in incidence, case-fatality rate, and severity of stroke in northern Sweden, 1985-1991. Stroke. 1994;25(9):1738-1745. [pmid: 8073452].
27 Kurtzke JF. Epidemiology of Cerebrovascular Disease. 1969.
28 Garraway WM, Whisnant JP, Furlan AJ, et al. The declining incidence of stroke. N Engl J Med. 1979;300(9):449-452. [pmid: 759935].
29 MacMahon S, Peto R, Cutler J, et al. Blood pressure, stroke, and coronary heart disease. Part 1, Prolonged differences in blood pressure: prospective observational studies corrected for the regression dilution bias. Lancet. 1990;335(8692):765-774. [pmid: 1969518].
30 Cholesterol, diastolic blood pressure, and stroke: 13,000 strokes in 450,000 people in 45 prospective cohorts. Prospective studies collaboration. Lancet 1995; 346(8991–8992):1647–1653.
31 MacMahon S, Cutler JA, Stamler J. Antihypertensive drug treatment. Potential, expected, and observed effects on stroke and on coronary heart disease. [Review] [27 refs]. Hypertension. 1989;13(5 Suppl):I45-I50. [pmid: 2490828].
32 Chapman N, Huxley R, Anderson C, et al. Effects of a perindopril-based blood pressure-lowering regimen on the risk of recurrent stroke according to stroke subtype and medical history: the PROGRESS Trial. Stroke. 2004;35(1):116-121. [pmid: 14671247].
33 Major cardiovascular events in hypertensive patients randomized to doxazosin vs chlorthalidone: the antihypertensive and lipidlowering treatment to prevent heart attack trial (ALLHAT). ALLHAT Collaborative Research Group.[see comment][erratum appears in JAMA 2002 Dec 18;288(23):2976]. JAMA 2000; 283(15):1967–1975.
34 Fagard R, Lijnen P, Vanhees L, et al. Hemodynamic response to converting enzyme inhibition at rest and exercise in humans. Journal of Applied Physiology: Respiratory, Environmental & Exercise Physiology. 1982;53(3):576-581.
35 Abbott RD, Donahue RP, MacMahon SW, et al. Diabetes and the risk of stroke. The Honolulu Heart Program. JAMA. 1987;257(7):949-952. [pmid: 3806877].
36 Tuomilehto J, Rastenyte D, Jousilahti P, et al. Diabetes mellitus as a risk factor for death from stroke. Prospective study of the middle-aged Finnish population. Stroke. 1996;27(2):210-215. [pmid: 8571411].
37 Robbins AS, Manson JE, Lee IM, et al. Cigarette smoking and stroke in a cohort of U.S. male physicians. Ann Intern Med. 1994;120(6):458-462. [pmid: 8311368].
38 Shinton R, Beevers G. Meta-analysis of relation between cigarette smoking and stroke. BMJ. 1989;298(6676):789-794. [pmid: 2496858]. [pmcid: 1836102].
39 Stegmayr B, Asplund K. Diabetes as a risk factor for stroke. A population perspective. Diabetologia. 1995;38(9):1061-1068. [pmid: 8591820].
40 Perry IJ, Refsum H, Morris RW, et al. Prospective study of serum total homocysteine concentration and risk of stroke in middle-aged British men. Lancet. 1995;346(8987):1395-1398. [pmid: 7475822].
41 Iso H, Jacobs DR Jr., Wentworth D, et al. Serum cholesterol levels and six-year mortality from stroke in 350,977 men screened for the multiple risk factor intervention trial. N Engl J Med. 1989;320(14):904-910. [pmid: 2619783].
42 Lawrence I. Continuing education. Diabetic Medicine. 2004;21(Suppl. 1):1-2.
43 Kiely DK, Wolf PA, Cupples LA, et al. Familial aggregation of stroke. The Framingham Study. Stroke. 1993;24(9):1366-1371. [pmid: 8362432].
44 Wade DT. Stroke (acute cerebrovascular disease). Health Care Needs Asessment. 1994. Oxford, Radcliffe Medical Press.
45 Stegmayr B, Asplund K, Kuulasmaa K, et al. Stroke incidence and mortality correlated to stroke risk factors in the WHO MONICA Project. An ecological study of 18 populations. Stroke. 1997;28(7):1367-1374. [pmid: 9227685].
46 The Brain Attack Coalition. Available at: www.stroke-site.org 2004.
47 Lee SJ, Lee KH, Na DG, et al. Multiphasic helical computed tomography predicts subsequent development of severe brain edema in acute ischemic stroke. Arch Neurol. 2004;61(4):505-509. [pmid: 15096397].
48 Ministry of Health and Long-Term Care and the Heart and Stroke Foundation of Ontario. Towards an integrated Stroke Strategy for Ontario: The Report of the Joint Stroke Strategy Working Group. 2000.
49 Tissue plasminogen activator for acute ischemic stroke. The National Institute of Neurological Disorders and Stroke rt-PA Stroke Study Group.[see comment]. N Engl J Med 1995; 333(24):1581–1587.
50 Barber M, Langhorne P, Stott DJ. Barriers to delivery of thrombolysis for acute stroke. Age Ageing. 2004;33(2):94-95. [pmid: 14960419].
51 Barber PA, Zhang J, Demchuk AM, et al. Why are stroke patients excluded from TPA therapy? An analysis of patient eligibility. Neurology. 2001;56(8):1015-1020. [pmid: 11320171].
52 Silver FL, Rubini F, Black D, et al. Advertising strategies to increase public knowledge of the warning signs of stroke.[see comment]. Stroke. 2003;34(8):1965-1968. [pmid: 12855823].
53 Ingall TJ, O'Fallon WM, Asplund K, et al. Findings from the reanalysis of the NINDS tissue plasminogen activator for acute ischemic stroke treatment trial. Stroke. 2004;35(10):2418-2424. [pmid: 15345796].
54 Johnston KC, Connors AJ, Wagner DP, et al. Risk adjustment effect on stroke clinical trials. Stroke. 2004;35(2):e43-e45. [pmid: 14715975].
55 Marler J, Tilley BC, Lu Y, et al. Early stroke treatment associated with better outcome: the NINDS rt-PA stroke study. Neurology. 2000;55(11):1649-1655. [pmid: 11113218].
56 Hakim AM, Hogan MJ, Carpenter S. Time course of cerebral blood flow and histological outcome after focal cerebral ischemia in rats. Stroke. 1992;23(8):1138-1143. [pmid: 1636189].
57 Hakim AM. The cerebral ischemic penumbra. Can J Neurol Sci. 1987;14(4):557-559. [pmid: 2446732].
58 Marler G, LB. Medicine. Stroke--tPA and the clinic. Science. 2003;301(5640):1677. [pmid: 14500967].
59 Hill MD. The Canadian Activase in Stroke Effectiveness Study (CASES). 2004.
60 Engelstein E, Margulies J, Jeret JS. Lack of t-PA use for acute ischemic stroke in a community hospital: high incidence of exclusion criteria.[see comment]. Am J Emerg Med. 2000;18(3):257-260. [pmid: 10830678].
61 Dafer RM, Tietjen GE, Korsnack A. Experience with rtPA at a Small Medical Center. Neurology. 1998;50:A115.
62 Pepe PE, Zachariah BS, Sayre MR, et al. Ensuring the chain of recovery for stroke in your community. Chain of Recovery Writing Group. [Review] [19 refs]. Prehosp Emerg Care. 1998;2(2):89-95. [pmid: 9709325].
63 Schneider AT, Pancioli AM, Khoury JC, et al. Trends in community knowledge of the warning signs and risk factors for stroke. JAMA. 2003;289(3):343-346. [pmid: 12525235].
64 Williams LS, Bruno A, Rouch D, et al. Stroke patients' knowledge of stroke. Influence on time to presentation. Stroke. 1997;28(5):912-915. [pmid: 9158624].
65 Wein TH, Staub L, Felberg R, et al. Activation of emergency medical services for acute stroke in a nonurban population: the T.L.L. Temple Foundation Stroke Project. Stroke. 2000;31(8):1925-1928. [pmid: 10926958].
66 Carrozzella J, Jauch EC. Emergency stroke management: a new era. [Review] [27 refs]. Nursing Clinics of North America. 2002;37(1):35-57. [pmid: 11818260].
67 Clark WM, Wissman S, Albers GW, et al. Recombinant tissue-type plasminogen activator (Alteplase) for ischemic stroke 3 to 5 hours after symptom onset. The ATLANTIS Study: a randomized controlled trial. Alteplase Thrombolysis for Acute Noninterventional Therapy in Ischemic Stroke.[see comment]. JAMA. 1999;282(21):2019-2026. [pmid: 10591384].
68 Goldstein LB, Edwards MG, Wood DP. Delay between stroke onset and emergency department evaluation. Neuroepidemiology. 2001;20(3):196-200. [pmid: 11490166].
69 Luepker RV, Raczynski JM, Osganian S, et al. Effect of a community intervention on patient delay and emergency medical service use in acute coronary heart disease: The Rapid Early Action for Coronary Treatment (REACT) Trial. JAMA. 2000;284(1):60-67. [pmid: 10872014].
70 Castaldo JE, Nelson JJ, Reed JF, et al. The delay in reporting symptoms of carotid artery stenosis in an at-risk population. The Asymptomatic Carotid Atherosclerosis Study experience: a statement of concern regarding watchful waiting. Arch Neurol. 1997;54(10):1267-1271. [pmid: 9341573].
71 DeLemos CD, Atkinson RP, Croopnick SL, et al. How effective are “community” stroke screening programs at improving stroke knowledge and prevention practices? Results of a 3-month follow-up study. Stroke. 2003;34(12):e247-e249. [pmid: 14631093].
72 Katzan IL, Furlan AJ, Lloyd LE, et al. Use of tissue-type plasminogen activator for acute ischemic stroke: the Cleveland area experience.[see comment]. JAMA. 2000;283(9):1151-1158. [pmid: 10703777].
73 Katzan IL, Hammer MD, Furlan AJ, et al. Quality improvement and tissue-type plasminogen activator for acute ischemic stroke: a Cleveland update. Stroke. 2003;34(3):799-800. [pmid: 12624312].
74 Moher D, Pham B, Lawson ML, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
75 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. 2000;53(9):964-972. [pmid: 11004423].
76 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
77 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
78 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-613. [pmid: 9746022].
79 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-186. [pmid: 9250191].
80 Neely KW, Norton RL. Survey of health maintenance organization instructions to members concerning emergency department and 911 use.[see comment]. Annals of Emergency Medicine. 1999;34(1):19-24. [pmid: 10381990].
81 Moher D, Cook DJ, Jadad AR et al. Assessing the quality of reports of randomised trials: implications for the conduct of meta-analyses. Health Technol Assess 1999; 3(12):i–98.
82 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
83 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-412. [pmid: 7823387].
84 The Newcastle-Ottawa Scale(NOS)for assessing the quality of nonrandomised studies in meta-analyses. 3rd Symposium on Systematic Reviews: Beyond the Basics, Oxford 2000. 00 Jan 7; 2000.
85 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-1558. [pmid: 12111919].
86 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
87 Morgenstern LB, Frankowski RF, Shedden P, et al. Surgical treatment for intracerebral hemorrhage (STICH): a single-center, randomized clinical trial. Neurology. 1998;51(5):1359-1363. [pmid: 9818860].
88 Teernstra OP, Evers SM, Lodder J, et al. Stereotactic treatment of intracerebral hematoma by means of a plasminogen activator: a multicenter randomized controlled trial (SICHPA). Stroke. 2003;34(4):968-974. [pmid: 12649510].
89 Zuccarello M, Brott T, Derex L, et al. Early surgical treatment for supratentorial intracerebral hemorrhage: a randomized feasibility study.[see comment]. Stroke. 1999;30(9):1833-1839. [pmid: 10471432].
90 Kay R, Poon WS, Nicholls MG. Effect of intravenous ketanserin on arterial and intracranial pressures in patients with systemic hypertension following intracerebral haemorrhage. J Hum Hypertens. 1993;7(4):369-371. [pmid: 8410928].
91 Nishiyama T, Yokoyama T, Matsukawa T, et al. Continuous nicardipine infusion to control blood pressure after evacuation of acute cerebral hemorrhage. Can J Anaesth. 2000;47(12):1196-1201. [pmid: 11132741].
92 Furlan A, Higashida R, Wechsler L, et al. Intra-arterial prourokinase for acute ischemic stroke. The PROACT II study: a randomized controlled trial. Prolyse in Acute Cerebral Thromboembolism.[see comment]. JAMA. 1999;282(21):2003-2011. [pmid: 10591382].
93 Keris V, Rudnicka S, Vorona V, et al. Combined intraarterial/intravenous thrombolysis for acute ischemic stroke. AJNR Am J Neuroradiol. 2001;22(2):352-358. [pmid: 11156782].
94 Lewandowski CA, Frankel M, Tomsick TA, et al. Combined intravenous and intra-arterial r-TPA versus intra-arterial therapy of acute ischemic stroke: Emergency Management of Stroke (EMS) Bridging Trial. Stroke. 1999;30(12):2598-2605. [pmid: 10582984].
95 Gray CS, Hildreth AJ, Alberti GK, et al. Poststroke hyperglycemia: natural history and immediate management. Stroke. 2004;35(1):122-126. [pmid: 14671236].
96 Scott JF, Robinson GM, French JM, et al. Glucose potassium insulin infusions in the treatment of acute stroke patients with mild to moderate hyperglycemia: the Glucose Insulin in Stroke Trial (GIST). Stroke. 1999;30(4):793-799. [pmid: 10187881].
97 Eggers J, Koch B, Meyer K, et al. Effect of ultrasound on thrombolysis of middle cerebral artery occlusion. Ann Neurol. 2003;53(6):797-800. [pmid: 12783427].
98 Schmidt H, Fazekas F, Kostner GM, et al. Angiotensinogen gene promoter haplotype and microangiopathy-related cerebral damage: results of the Austrian Stroke Prevention Study. Stroke. 2001;32(2):405-412. [pmid: 11157174].
99 Albers GW, Clark WM, Madden KP, et al. ATLANTIS trial: results for patients treated within 3 hours of stroke onset. Alteplase Thrombolysis for Acute Noninterventional Therapy in Ischemic Stroke.[see comment]. Stroke. 2002;33(2):493-495. [pmid: 11823658].
100 Hermier M, Nighoghossian N, Adeleine P, et al. Early magnetic resonance imaging prediction of arterial recanalization and late infarct volume in acute carotid artery stroke. J Cereb Blood Flow Metab. 2003;23(2):240-248. [pmid: 12571455].
101 Suarez JI, Zaidat OO, Sunshine JL, et al. Endovascular administration after intravenous infusion of thrombolytic agents for the treatment of patients with acute ischemic strokes. Neurosurgery. 2002;50(2):251-259. [pmid: 11844259].
102 Kilpatrick MM, Yonas H, Goldstein S, et al. CT-based assessment of acute stroke: CT, CT angiography, and xenon-enhanced CT cerebral blood flow.[see comment]. Stroke. 2001;32(11):2543-2549. [pmid: 11692014].
103 Morgenstern LB, Bartholomew LK, Grotta JC, et al. Sustained benefit of a community and professional intervention to increase acute stroke therapy. Arch Intern Med. 2003;163(18):2198-2202. [pmid: 14557217].
104 Hill MD, Barber PA, Demchuk AM, et al. Building a “brain attack” team to administer thrombolytic therapy for acute ischemic stroke. CMAJ. 2000;162(11):1589-1593. [pmid: 10862236]. [pmcid: 1231342].
105 Lattimore SU, Chalela J, Davis L, et al. Impact of establishing a primary stroke center at a community hospital on the use of thrombolytic therapy: the NINDS Suburban Hospital Stroke Center experience. Stroke. 2003;34(6):e55-e57. [pmid: 12750543].
106 Smith RW, Scott PA, Grant RJ, et al. Emergency physician treatment of acute stroke with recombinant tissue plasminogen activator: a retrospective analysis. Acad Emerg Med. 1999;6(6):618-625. [pmid: 10386679].
107 Hacke W, Kaste M, Fieschi C, et al. Randomised double-blind placebo-controlled trial of thrombolytic therapy with intravenous alteplase in acute ischaemic stroke (ECASS II). Second European-Australasian Acute Stroke Study Investigators.[see comment]. Lancet. 1998;352(9136):1245-1251. [pmid: 9788453].
108 Hacke W, Kaste M, Fieschi C, et al. Intravenous thrombolysis with recombinant tissue plasminogen activator for acute hemispheric stroke. The European Cooperative Acute Stroke Study (ECASS)[see comment]. JAMA. 1995;274(13):1017-1025. [pmid: 7563451].
109 Kase CS, Furlan AJ, Wechsler LR, et al. Cerebral hemorrhage after intra-arterial thrombolysis for ischemic stroke: the PROACT II trial. Neurology. 2001;57(9):1603-1610. [pmid: 11706099].
110 del Zoppo GJ, Higashida RT, Furlan AJ, et al. PROACT: a phase II randomized trial of recombinant pro-urokinase by direct arterial delivery in acute middle cerebral artery stroke. PROACT Investigators. Prolyse in Acute Cerebral Thromboembolism.[see comment]. Stroke. 1998;29(1):4-11. [pmid: 9445320].
111 t AV, Molina CA, Grotta JC, et al. Ultrasound-enhanced systemic thrombolysis for acute ischemic stroke. N Engl J Med. 2004;351(21):2170-2178. [pmid: 15548777].
112 Clark WM, Albers GW, Madden KP, et al. The rtPA (alteplase) 0- to 6-hour acute stroke trial, part A (A0276g) : results of a double-blind, placebo-controlled, multicenter study. Thromblytic therapy in acute ischemic stroke study investigators. Stroke. 2000;31(4):811-816. [pmid: 10753980].
113 Haley EJ, Brott TG, Sheppard GL, et al. Pilot randomized trial of tissue plasminogen activator in acute ischemic stroke. The TPA Bridging Study Group. Stroke. 1993;24(7):1000-1004. [pmid: 8322373].
114 Patel SC, Levine SR, Tilley BC, et al. Lack of clinical significance of early ischemic changes on computed tomography in acute stroke.[see comment]. JAMA. 2001;286(22):2830-2838. [pmid: 11735758].
115 Roberts HC, Dillon WP, Furlan AJ, et al. Computed tomographic findings in patients undergoing intra-arterial thrombolysis for acute ischemic stroke due to middle cerebral artery occlusion: results from the PROACT II trial.[see comment]. Stroke. 2002;33(6):1557-1565. [pmid: 12052991].
116 Agarwal PK. Hyperdense middle cerebral artery sign: can it be used to select intra-arterial versus intravenous thrombolysis in acute ischemic stroke?. Cerebrovasc Dis. 2004;17(23):182-190. [pmid: 14707420].
117 Akins PT, Delemos C, Wentworth D, et al. Can emergency department physicians safely and effectively initiate thrombolysis for acute ischemic stroke?. Neurology. 2000;55(12):1801-1805. [pmid: 11134376].
118 Jahnke HK, Zadrozny D, Garrity T, et al. Stroke teams and acute stroke pathways: one emergency department's two-year experience. J Emerg Nurs. 2003;29(2):133-139. [pmid: 12660695].
119 Auer LM, Deinsberger W, Niederkorn K, et al. Endoscopic surgery versus medical treatment for spontaneous intracerebral hematoma: a randomized study. J Neurosurg. 1989;70(4):530-535. [pmid: 2926492].
120 Batjer HH, Reisch JS, Allen BC, et al. Failure of surgery to improve outcome in hypertensive putaminal hemorrhage. A prospective randomized trial. Arch Neurol. 1990;47(10):1103-1106. [pmid: 2222242].
121 Juvela S, Heiskanen O, Poranen A, et al. The treatment of spontaneous intracerebral hemorrhage. A prospective randomized trial of surgical and conservative treatment.[see comment]. J Neurosurg. 1989;70(5):755-758. [pmid: 2651586].
122 Mendelow AD, Gregson BA, Fernandes HM, et al. Early surgery versus initial conservative treatment in patients with spontaneous supratentorial intracerebral haematomas in the International Surgical Trial in Intracerebral Haemorrhage (STICH): a randomised trial. Lancet. 2005;365(9457):387-397. [pmid: 15680453].
123 Tan SH, Ng PY, Yeo TT, et al. Hypertensive basal ganglia hemorrhage: a prospective study comparing surgical and nonsurgical management. Surg Neurol. 2001;56(5):287-292. [pmid: 11749988].
124 Hardemark HG, Wesslen N, Persson L. Influence of clinical factors, CT findings and early management on outcome in supratentorial intracerebral hemorrhage. Cerebrovasc Dis. 1999;9(1):10-21. [pmid: 9873158].
125 Schaller C, Rohde V, Meyer B, et al. Stereotactic puncture and lysis of spontaneous intracerebral hemorrhage using recombinant tissue-plasminogen activator. Neurosurgery. 1995;36(2):328-333. [pmid: 7731513].
126 Da PR, Bazzan A, Pasqualin A. Surgical versus medical treatment of spontaneous posterior fossa haematomas: a cooperative study on 205 cases. Neurol Res. 1984;6(3):145-151. [pmid: 6151139].
127 Kaya RA, Turkmenoglu O, Ziyal IM, et al. The effects on prognosis of surgical treatment of hypertensive putaminal hematomas through transsylvian transinsular approach. Surg Neurol. 2003;59(3):176-183. [pmid: 12681546].
128 Muiz AJ, Abdullah J, Naing NN, et al. Spontaneous intracerebral hemorrhage in northeast Malaysian patients: a four-year study. Neuroepidemiology. 2003;22(3):184-195. [pmid: 12711851].
129 Deinsberger W, Lang C, Hornig C, et al. Stereotactic aspiration and fibrinolysis of spontaneous supratentorial intracerebral hematomas versus conservative treatment: a matched-pair study. Zentralbl Neurochir. 2003;64(4):145-150. [pmid: 14634878].
130 Kurtsoy A, Oktem IS, Koc RK, et al. Surgical treatment of thalamic hematomas via the contralateral transcallosal approach. Neurosurg Rev. 2001;24(23):108-113. [pmid: 11485230].
131 Mahaffey KW, Granger CB, Sloan MA, et al. Neurosurgical evacuation of intracranial hemorrhage after thrombolytic therapy for acute myocardial infarction: experience from the GUSTO-I trial. Global Utilization of Streptokinase and tissue-plasminogen activator (tPA) for Occluded Coronary Arteries. Am Heart J. 1999;138(3 Pt 1):493-499. [pmid: 10467200].
132 McCarron MO, Nicoll JA, Love S, et al. Surgical intervention, biopsy and APOE genotype in cerebral amyloid angiopathy-related haemorrhage. Br J Neurosurg. 1999;13(5):462-467. [pmid: 10627776].
133 Sakas DE, Singounas EG, Karvounis PC. Spontaneous intracerebral haematomas: surgical versus conservative treatment based on Glascow Coma Scale score and computer tomography data. J Neurosurg Sci. 1989;33(2):165-172. [pmid: 2795189].
134 Cohen ZR, Ram Z, Knoller N, et al. Management and outcome of non-traumatic cerebellar haemorrhage. Cerebrovasc Dis. 2002;14(34):207-213. [pmid: 12403953].
135 Iwamoto N, Kusaka M, Tsurutani T, et al. Ultrasound imaging for stereotactic evacuation of hypertension-associated intracerebral hematomas with aqua-stream and aspiration. Stereotact Funct Neurosurg. 1993;60(4):194-204. [pmid: 8327798].
136 Roux FE, Boetto S, Tremoulet M. Third ventriculocisternostomy in cerebellar haematomas. Acta Neurochir (Wien). 2002;144(4):337-342. [pmid: 12021879].
137 Siddique MS, Fernandes HM, Arene NU, et al. Changes in cerebral blood flow as measured by HMPAO SPECT in patients following spontaneous intracerebral haemorrhage. Acta Neurochir Suppl. 2000;76:517-520. [pmid: 11450081].
138 Tyler D, Mandybur G. Interventional MRI-guided stereotactic aspiration of acute/subacute intracerebral hematomas. Stereotact Funct Neurosurg. 1999;72(24):129-135. [pmid: 10853064].
139 Ziai WC, Port JD, Cowan JA, et al. Decompressive craniectomy for intractable cerebral edema: experience of a single center. J Neurosurg Anesthesiol. 2003;15(1):25-32. [pmid: 12499979].
140 Kim MH, Kim EY, Song JH, et al. Surgical options of hypertensive intracerebral hematoma: stereotactic endoscopic removal versus stereotactic catheter drainage. J Korean Med Sci. 1998;13(5):533-540. [pmid: 9811185].
141 Juvela S. Risk factors for impaired outcome after spontaneous intracerebral hemorrhage. Arch Neurol. 1995;52(12):1193-1200. [pmid: 7492294].
142 Brott T, Broderick J, Kothari R, et al. Early hemorrhage growth in patients with intracerebral hemorrhage. Stroke. 1997;28(1):1-5. [pmid: 8996478].
143 Mendelow AD. Investigators and the Steering Committee. The International Surgical Trial in Intracerebral Haemorrhage (ISTICH). Acta Neurochir Suppl. 2003;86:441-443. [pmid: 14753482].
144 Kuroda K, Kuwata N, Sato N, et al. Changes in cerebral blood flow accompanied with reduction of blood pressure treatment in patients with hypertensive intracerebral hemorrhages. Neurol Res. 1997;19(2):169-173. [pmid: 9175147].
145 Ito H, Arakawa M, Shibasaki T, et al. Acute antihypertensive effect of nifedipine by sublingual route in cases with clinically severe systolic hypertension. A study up to 4 h after administration. Arzneimittelforschung. 1984;34(5):630-636. [pmid: 6380506].
146 Patel RV, Kertland HR, Jahns BE, et al. Labetalol: response and safety in critically ill hemorrhagic stroke patients. Ann Pharmacother. 1993;27(2):180-181. [pmid: 8439694].
147 Powers WJ, Zazulia AR, Videen TO, et al. Autoregulation of cerebral blood flow surrounding acute (6 to 22 hours) intracerebral hemorrhage.[see comment]. Neurology. 2001;57(1):18-24. [pmid: 11445622].
148 Wagenknecht LE, Furberg CD, Hammon JW, et al. Surgical bleeding: unexpected effect of a calcium antagonist. BMJ. 1995;310(6982):776-777. [pmid: 7711582]. [pmcid: 2549165].
149 Arnold M, Schroth G, Nedeltchev K, et al. Intra-arterial thrombolysis in 100 patients with acute stroke due to middle cerebral artery occlusion. Stroke. 2002;33(7):1828-1833. [pmid: 12105361].
150 Bourekas EC, Slivka AP, Shah R, et al. Intraarterial thrombolytic therapy within 3 hours of the onset of stroke. Neurosurgery. 2004;54(1):39-44. [pmid: 14683539].
151 Egan R, Clark W, Lutsep H, et al. Efficacy of intraarterial thrombolysis of basilar artery stroke. J Stroke Cardiovasc Dis. 1999;8(1):22-27.
152 IMS Study Investigators. Combined intravenous and intra-arterial recanalization for acute ischemic stroke: the Interventional Management of Stroke Study.[see comment]. Stroke 2004; 35(4):904–911.
153 Qureshi AI, Ali Z, Suri MF, et al. Intra-arterial third-generation recombinant tissue plasminogen activator (reteplase) for acute ischemic stroke. Neurosurgery. 2001;49(1):41-48. [pmid: 11440458].
154 Sylaja PN, Kuruttukulam G, Joseph S, et al. Selective intra arterial thrombolysis in acute carotid territory stroke. Neurol India. 2001;49(2):153-157. [pmid: 11447435].
155 Qureshi AI, Siddiqui AM, Suri MF, et al. Aggressive mechanical clot disruption and low-dose intra-arterial third-generation thrombolytic agent for ischemic stroke: a prospective study. Neurosurgery. 2002;51(5):1319-1327. [pmid: 12383381].
156 Suwanwela NC, Phanthumchinda K, Suwanwela N, et al. Thrombolytic treatment for acute ischemic stroke: a 2 year-experience at King Chulalongkorn Memorial Hospital. J Med Assoc Thai. 2001;84(Suppl 1):S428-S436. [pmid: 11529370].
157 Hill MD, Barber PA, Demchuk AM, et al. Acute intravenous--intra-arterial revascularization therapy for severe ischemic stroke. Stroke. 2002;33(1):279-282. [pmid: 11779923].
158 Yoneda Y, Mori E, Uehara T, et al. Intracarotid regional infusion of recombinant tissue plasminogen activator for acute hemispheric stroke. Cerebrovasc Dis. 1998;8:357-359. [pmid: 9845842].
159 Barr JD, Mathis JM, Wildenhain SL, et al. Acute stroke intervention with intraarterial urokinase infusion. J Vasc Interv Radiol. 1994;5(5):705-713. [pmid: 8000119].
160 Ueda T, Hatakeyama T, Kumon Y, et al. Evaluation of risk of hemorrhagic transformation in local intra-arterial thrombolysis in acute ischemic stroke by initial SPECT. Stroke. 1994;25(2):298-303. [pmid: 8303735].
161 Baltacioglu F, Afsar N, Ekinci G, et al. Intraarterial thrombolysis with r-tPA for treatment of anterior circulation acute ischemic stroke: Technical and clinical results. Intervent Neuroradiol. 2003;9(3):273-282.
162 Fitt GJ, Farrar J, Baird AE, et al. Intra-arterial streptokinase in acute ischaemic stroke. A pilot study. Med J Aust. 1993;159(5):331-334. [pmid: 8361430].
163 Gonner F, Remonda L, Mattle H, et al. Local intra-arterial thrombolysis in acute ischemic stroke. Stroke. 1998;29(9):1894-1900. [pmid: 9731615].
164 Kase CS, Furlan AJ, Wechsler LR et al. Symptomatic intracranial hemorrhage after intraarterial thrombolysis with recombinant prourokinase in acute ischemic stroke: the PROACT II Study. Neurology 2000; 54(Suppl 3).
165 Kidwell CS, Saver JL, Carneado J, et al. Predictors of hemorrhagic transformation in patients receiving intra-arterial thrombolysis.[see comment]. Stroke. 2002;33(3):717-724. [pmid: 11872894].
166 Kidwell CS, Saver JL, Starkman S, et al. Late secondary ischemic injury in patients receiving intraarterial thrombolysis.[see comment]. Ann Neurol. 2002;52(6):698-703. [pmid: 12447922].
167 Moazami N, Smedira NG, McCarthy PM, et al. Safety and efficacy of intraarterial thrombolysis for perioperative stroke after cardiac operation.[see comment]. Ann Thorac Surg. 2001;72(6):1933-1937. [pmid: 11789774].
168 Qureshi AI, Suri MF, Shatla AA, et al. Intraarterial recombinant tissue plasminogen activator for ischemic stroke: an accelerating dosing regimen.[see comment]. Neurosurgery. 2000;47(2):473-476. [pmid: 10942026].
169 Tong DD. Intra-arterial thrombolytic therapy for acute stroke: the debate continues.[comment]. Stroke. 2002;33(7):1827. [pmid: 12109492].
170 Zaidat OO, Suarez JI, Santillan C, et al. Response to intra-arterial and combined intravenous and intra-arterial thrombolytic therapy in patients with distal internal carotid artery occlusion.[see comment]. Stroke. 2002;33(7):1821-1826. [pmid: 12105360].
171 Hahnel S, Schellinger PD, Gutschalk A, et al. Local intra-arterial fibrinolysis of thromboemboli occurring during neuroendovascular procedures with recombinant tissue plasminogen activator. Stroke. 2003;34(7):1723-1728. [pmid: 12805492].
172 Comerota AJ, Eze AR. Intraoperative high-dose regional urokinase infusion for cerebrovascular occlusion after carotid endarterectomy. J Vasc Surg. 1996;24(6):1008-1016. [pmid: 8976354].
173 Restrepo L, Pradilla G, Llinas R, et al. Perfusion- and diffusion-weighted MR imaging-guided therapy of vertebral artery dissection: intraarterial thrombolysis through an occipital vertebral anastomosis. AJNR Am J Neuroradiol. 2003;24(9):1823-1826. [pmid: 14561610].
174 Wardlaw JM, Lindley RI, Warlow CP, et al. A pilot study of intra-arterial thrombolysis for acute ischaemic stroke. J Neurol Neurosurg Psychiatry. 1994;57:251.
175 Ducrocq X, Anxionnat R, Taillandier L et al. Intravenous versus intra-arterial urokinase thrombolysis in acute ischemic stroke. Randomised study of 27 patients. Cerebrovasc Dis 2000; 10(Suppl 2).
176 The E.M.S.Bridging Trial Investigators. Combined intravenous/intra-arterial thrombolytic therapy: safety, time to treatment, and frequency of clot. Stroke 1996 27 (1):165.
177 Emergency Management of Stroke (EMS) Investigators. Combined intra-arterial and intravenous tPA for stroke. Stroke 1997; 28(1):273.
178 Lee DH, Jo KD, Kim HG, et al. Local intraarterial urokinase thrombolysis of acute ischemic stroke with or without intravenous abciximab: a pilot study. J Vasc Interv Radiol. 2002;13(8):769-774. [pmid: 12171979].
179 Zeumer H, Freitag HJ, Zanella F, et al. Local intra-arterial fibrinolytic therapy in patients with stroke: urokinase versus recombinant tissue plasminogen activator (r-TPA). Neuroradiology. 1993;35(2):159-162. [pmid: 8433796].
180 Wechsler LR, Roberts R, Furlan AJ, et al. Factors influencing outcome and treatment effect in PROACT II. Stroke. 2003;34(5):1224-1229. [pmid: 12677011].
181 Ueda T, Sakaki S, Nochide I, et al. Angioplasty after intra-arterial thrombolysis for acute occlusion of intracranial arteries. Stroke. 1998;29(12):2568-2574. [pmid: 9836769].
182 Alexandrov AV, Demchuk AM, Burgin WS, et al. Ultrasound-enhanced thrombolysis for acute ischemic stroke: Phase I. findings of the CLOTBUST trial. J Neuroimaging. 2004;14(2):113-117. [pmid: 15095555].
183 Kerber CW, Barr JD, Berger RM, et al. Snare retrieval of intracranial thrombus in patients with acute stroke. J Vasc Interv Radiol. 2002;13(12):1269-1274. [pmid: 12471193].
184 Yoneyama T, Nakano S, Kawano H, et al. Combined direct percutaneous transluminal angioplasty and low-dose native tissue plasminogen activator therapy for acute embolic middle cerebral artery trunk occlusion. AJNR Am J Neuroradiol. 2002;23(2):277-281. [pmid: 11847054].
185 Mayer TE, Hamann GF, Brueckmann HJ. Treatment of basilar artery embolism with a mechanical extraction device: necessity of flow reversal.[see comment]. Stroke. 2002;33(9):2232-2235. [pmid: 12215592].
186 Lin DDM, Gailloud P, Beauchamp NJ, et al. Combined stent placement and thrombolysis in acute vertebrobasilar ischemic stroke. AJNR Am J Neuroradiol. 2003;24(9):1827-1833. [pmid: 14561611].
187 Nakano S, Iseda T, Yoneyama T, et al. Direct percutaneous transluminal angioplasty for acute middle cerebral artery trunk occlusion: an alternative option to intra-arterial thrombolysis.[see comment]. Stroke. 2002;33(12):2872-2876. [pmid: 12468784].
188 Alexandrov AV. Ultrasound-enhanced thrombolysis for stroke: clinical significance. Eur J Ultrasound. 2002;16(12):131-140. [pmid: 12470858].
189 Alexandrov AV, Wojner AW, Grotta JC, et al. CLOTBUST: design of a randomized trial of ultrasound-enhanced thrombolysis for acute ischemic stroke. J Neuroimaging. 2004;14(2):108-112. [pmid: 15095554].
190 Marler J, Tilley BC, Lu M, et al. Earlier treatment associated with better outcomes in the NINDS tPA stroke study [Abstract]. Stroke. 1999;30(1):244.
191 Albers GW, Clark WM, for the ATLANTIS Study Investigators. The ATLANTIS rt-PA (Alteplase) acute stroke trial: final results. Cerebrovasc Dis 1999; 9(Suppl 1).
192 Steiner T, Bluhmki E, Kaste M, et al. The ECASS 3-hour cohort. Secondary analysis of ECASS data by time stratification. ECASS Study Group. European Cooperative Acute Stroke Study. Cerebrovasc Dis. 1998;8(4):198-203. [pmid: 9684058].
193 Brott TG, Haley EJ, Levy DE, et al. Urgent therapy for stroke. Part I. Pilot study of tissue plasminogen activator administered within 90 minutes. Stroke. 1992;23(5):632-640. [pmid: 1579958].
194 Collins DR, O'Neill D, McCormack PM. Potential for treatment with thrombolysis in an Irish stroke unit. Ir Med J. 1999;92(1):236-238. [pmid: 10360096].
195 Hacke W, Donnan G, Fieschi C, et al. Association of outcome with early stroke treatment: pooled analysis of ATLANTIS, ECASS, and NINDS rt-PA stroke trials. Lancet. 2004;363(9411):768-774. [pmid: 15016487].
196 Haring HP, Dilitz E, Pallua A, et al. Attenuated corticomedullary contrast: An early cerebral computed tomography sign indicating malignant middle cerebral artery infarction. A case-control study.[see comment]. Stroke. 1999;30(5):1076-1082. [pmid: 10229747].
197 Silver B, Demaerschalk B, Merino JG, et al. Improved outcomes in stroke thrombolysis with pre-specified imaging criteria.[see comment]. Can J Neurol Sci. 2001;28(2):113-119. [pmid: 11383934].
198 Lev MH, Segal AZ, Farkas J, et al. Utility of perfusion-weighted CT imaging in acute middle cerebral artery stroke treated with intra-arterial thrombolysis: prediction of final infarct volume and clinical outcome. Stroke. 2001;32(9):2021-2028. [pmid: 11546891].
199 von Kummer R, Allen KL, Holle R, et al. Acute stroke: usefulness of early CT findings before thrombolytic therapy.[see comment]. Radiology. 1997;205(2):327-333. [pmid: 9356611].
200 Barber PA, Demchuk AM, Hudon ME, et al. Hyperdense sylvian fissure MCA “dot” sign: A CT marker of acute ischemia. Stroke. 2001;32(1):84-88. [pmid: 11136919].
201 Larrue V, von K, RR MA, et al. Risk factors for severe hemorrhagic transformation in ischemic stroke patients treated with recombinant tissue plasminogen activator: a secondary analysis of the European-Australasian Acute Stroke Study (ECASS II). Stroke. 2001;32(2):438-441. [pmid: 11157179].
202 von Kummer R. , Bourquain H, Bastianello S et al. Early prediction of irreversible brain damage after ischemic stroke at CT. Radiology. 2001;219(1):95-100. [pmid: 11274542].
203 Pexman JH, Barber PA, Hill MD, et al. Use of the Alberta Stroke Program Early CT Score (ASPECTS) for assessing CT scans in patients with acute stroke. AJNR Am J Neuroradiol. 2001;22(8):1534-1542. [pmid: 11559501].
204 Hill MD, Rowley HA, Adler F, et al. Selection of acute ischemic stroke patients for intra-arterial thrombolysis with pro-urokinase by using ASPECTS.[see comment]. Stroke. 2003;34(8):1925-1931. [pmid: 12843342].
205 Wardlaw JM, Lindley RI, Lewis S. Thrombolysis for acute ischemic stroke: still a treatment for the few by the few. Western Journal of Medicine. 2002;176(3):198-199. [pmid: 12016247]. [pmcid: 1071716].
206 Chalela JA, Kang DW, Luby M, et al. Early magnetic resonance imaging findings in patients receiving tissue plasminogen activator predict outcome: Insights into the pathophysiology of acute stroke in the thrombolysis era. Ann Neurol. 2004;55(1):105-112. [pmid: 14705118].
207 Neumann-Haefelin T, Du Mesnil, Fiebach DR, et al. Effect of incomplete (spontaneous and postthrombolytic) recanalization after middle cerebral artery occlusion: a magnetic resonance imaging study. Stroke. 2004;35(1):109-114. [pmid: 14671246].
208 Tong DC, Adami A, Moseley ME, et al. Prediction of hemorrhagic transformation following acute stroke: role of diffusion- and perfusion-weighted magnetic resonance imaging.[see comment]. Arch Neurol. 2001;58(4):587-593. [pmid: 11295989].
209 O'Rourke F, Akhtar N, Emery D, et al. Use of MRI in the identification and treatment of early ischemic stroke lesions. CMAJ. 2004;170(3):335-336. [pmid: 14757667]. [pmcid: 331381].
210 Kim Y-B, Lee K-H, Lee SJ, et al. Safety and efficacy of intravenous thrombolysis with tissue plasminogen activator using triphasic perfusion CT in acute ischemic stroke. Cerebrovasc Dis. 2000;10(Suppl 2):78.
211 Lee K, Lee S, Kim Y, et al. Usefulness of triphasic perfusion CT for intravenous thrombolysis with tissue plasminogen activator in acute ischemic stroke. Stroke. 2000;31(11):2889.
212 Koenig M, Kraus M, Theek C, et al. Quantitative assessment of the ischemic brain by means of perfusion-related parameters derived from perfusion CT. Stroke. 2001;32(2):431-437. [pmid: 11157178].
213 Lee KH, Lee SJ, Cho SJ, et al. Usefulness of triphasic perfusion computed tomography for intravenous thrombolysis with tissue-type plasminogen activator in acute ischemic stroke. Arch Neurol. 2000;57(7):1000-1008. [pmid: 10891982].
214 Barsan WG, Brott TG, Broderick JP, et al. Urgent therapy for acute stroke. Effects of a stroke trial on untreated patients. Stroke. 1994;25(11):2132-2137. [pmid: 7974533].
215 Smith WS, Corry MD, Fazackerley J, et al. Improved paramedic sensitivity in identifying stroke victims in the prehospital setting. Prehosp Emerg Care. 1999;3(3):207-210. [pmid: 10424857].
216 Becker K, Fruin M, Gooding T, et al. Community-based education improves stroke knowledge. Cerebrovasc Dis. 2001;11(1):34-43. [pmid: 11173792].
217 Morgenstern LB, King M, Staub L, et al. Community and professional intervention to increase FDA-approved acute stroke therapy: final main results of the TLL Temple Foundation stroke project. Neurology. 2001;56(Suppl 3):A77.
218 Weinhardt J, Parker C. Developing a patient education video as a tool to case manage patients who have had strokes. Nurs Case Manag. 1999;4(4):198-200. [pmid: 10690108].
219 Alberts MJ, Perry A, Dawson DV, et al. Effects of public and professional education on reducing the delay in presentation and referral of stroke patients. Stroke. 1992;23(3):352-356. [pmid: 1542895].
220 Williams JE, Rosamond WD, Morris DL. Stroke symptom attribution and time to emergency department arrival: the delay in accessing stroke healthcare study. Acad Emerg Med. 2000;7(1):93-96. [pmid: 10894250].
221 Morgenstern LB, Staub L, Chan W, et al. Improving delivery of acute stroke therapy: The TLL Temple Foundation Stroke Project. Stroke. 2002;33(1):160-166. [pmid: 11779906].
222 Tuomilehto J, Sarti C, Narva EV, et al. The FINMONICA Stroke Register. Community-based stroke registration and analysis of stroke incidence in Finland, 1983-1985. Am J Epidemiol. 1992;135(11):1259-1270. [pmid: 1626542].
223 Buchan AM, Barber PA, Newcommon N, et al. Effectiveness of t-PA in acute ischemic stroke: outcome relates to appropriateness. Neurology. 2000;54(3):679-684. [pmid: 10680803].
224 Rapp K, Bratina P, Barch C, et al. Code Stroke: rapid transport, triage and treatment using rt-PA therapy. The NINDS rt-PA Stroke Study Group. [Review] [10 refs]. Journal of Neuroscience Nursing. 1997;29(6):361-366. [pmid: 9479657].
225 Albers GW, Bates VE, Clark WM, et al. Intravenous tissue-type plasminogen activator for treatment of acute stroke: the Standard Treatment with Alteplase to Reverse Stroke (STARS) study.[see comment]. JAMA. 2000;283(9):1145-1150. [pmid: 10703776].
226 Figueira FF. Stroke study group. Preliminary results. Early intensive care improves functional outcome. Arq Neuropsiquiatr. 1994;52(3):330-338. [pmid: 7893206].
227 Wester P, Radberg J, Lundgren B, et al. Factors associated with delayed admission to hospital and in-hospital delays in acute stroke and TIA: a prospective, multicenter study. Seek-Medical-Attention-in-Time Study Group. Stroke. 1999;30(1):40-48. [pmid: 9880386].
228 Moulin T, Sablot D, Vidry E, et al. Impact of emergency room neurologists on patient management and outcome. Eur Neurol. 2003;50(4):207-214. [pmid: 14634264].
229 Pearson BJ, Bath PM, Spence JD. Hypertension in patients presenting with stroke. [Review] [66 refs]. Current Hypertension Reports. 2000;2(6):551-557. [pmid: 11062601].
230 Tilley BC, Lyden PD, Brott TG, et al. Total quality improvement method for reduction of delays between emergency department admission and treatment of acute ischemic stroke. The National Institute of Neurological Disorders and Stroke rt-PA Stroke Study Group. Arch Neurol. 1997;54(12):1466-1474. [pmid: 9400355].
231 Chiu D, Krieger D, Villar-Cordova C, et al. Intravenous tissue plasminogen activator for acute ischemic stroke: feasibility, safety, and efficacy in the first year of clinical practice.[see comment]. Stroke. 1998;29(1):18-22. [pmid: 9445322].
232 Oswald N, Bateman H. Applying research evidence to individuals in primary care: a study using non-rheumatic atrial fibrillation. Family Practice. 1999;16(4):414-419. [pmid: 10493714].
233 Fernandes HM, Gregson B, Siddique S, et al. Surgery in intracerebral hemorrhage. The uncertainty continues. Stroke. 2000;31(10):2511-2516. [pmid: 11022087].
234 Qureshi AI, Tuhrim S, Broderick JP, et al. Spontaneous intracerebral hemorrhage. N Engl J Med. 2001;344(19):1450-1460. [pmid: 11346811].
235 Barnett HJ, Mohr JP, Stein BM et al. Stroke Pathophysiology, Diagnosis, and Management. 3rd Edition. 1989. New York, Churchill Livingstone.
236 Stroke pathophysiology, diagnosis, and management. 3.1998. New York, Chruchill Livingstone. 1998.
237 Safar P. Amelioration of post-ischemic brain damage with barbiturates. Stroke. 1980;11(5):565-568. [pmid: 6775398].
238 Thomas DJ. Treatment of acute stroke. Br Med J (Clin Res Ed). 1984;288(6410):2-3.
239 Haley EC Jr. High-dose tirilazad for acute stroke (RANTTAS II). RANTTAS II Investigators. Stroke. 1998;29(6):1256-1257. [pmid: 9626304].
240 McDonald ES, Windebank AJ. Mechanisms of neurotoxic injury and cell death. Neurol Clin. 2000;18(3):525-540. [pmid: 10873229].
241 Gladstone DJ, Black SE, Hakim AM. Toward wisdom from failure: lessons from neuroprotective stroke trials and new therapeutic directions. Stroke. 2002;33(8):2123-2136. [pmid: 12154275].
242 Hoyte L, Kaur J, Buchan AM. Lost in translation: taking neuroprotection from animal models to clinical trials. Exp Neurol. 2004;188(2):200-204. [pmid: 15246820].
243 Weir CJ, Kaste M, Lees KR. Targeting neuroprotection clinical trials to ischemic stroke patients with potential to benefit from therapy. Stroke. 2004;35(9):2111-2116. [pmid: 15243146].
244 Recommendations for ensuring early thrombolytic therapy for acute myocardial infarction. The Heart and Stroke Foundation of Canada, the Canadian Cardiovascular Society and the Canadian Association of Emergency Physicians for the Emergency Cardiac Care Coalition.[see comment]. CMAJ 1996; 154(4):483–487.
245 Davis SM. Emergency management of stroke. - Australasian Journal of Emergency Care. 1998;5(2):10-12.
246 Norris JW, Buchan A, Cote R, et al. Canadian guidelines for intravenous thrombolytic treatment in acute stroke. A consensus statement of the Canadian Stroke Consortium. Can J Neurol Sci. 1998;25(3):257-259. [pmid: 9706731].
247 Hill MD, Buchan AM. Methodology for the Canadian Activase for Stroke Effectiveness Study (CASES). CASES Investigators.[erratum appears in Can J Neurol Sci 2002 Feb;29(1):103]. Can J Neurol Sci. 2001;28(3):232-238. [pmid: 11513342].
248 Dishaw A. Ontario Stroke Strategy Monitoring and Evaluation Committee Draft Report. 2003.
249 Wardlaw JM, Zoppo G, Yamaguchi T et al. Thrombolysis for acute ischaemic stroke. Cochrane Database Syst Rev 2003;(3):CD000213.
250 Graham GD. Tissue plasminogen activator for acute ischemic stroke in clinical practice: a meta-analysis of safety data. Stroke. 2003;34(12):2847-2850. [pmid: 14605319].
251 Broderick JP, Adams HP Jr., Barsan W, et al. Guidelines for the management of spontaneous intracerebral hemorrhage: A statement for healthcare professionals from a special writing group of the Stroke Council, American Heart Association. Stroke. 1999;30(4):905-915. [pmid: 10187901].
252 Weir CJ, Murray GD, Dyker AG, et al. Is hyperglycaemia an independent predictor of poor outcome after acute stroke? Results of a long-term follow up study.[see comment]. BMJ. 1997;314(7090):1303-1306. [pmid: 9158464]. [pmcid: 2126557].
253 Adams HP, Adams RJ, Brott T, et al. Guidelines for the early management of patients with ischemic stroke: A scientific statement from the Stroke Council of the American Stroke Association. Stroke. 2003;34(4):1056-1083. [pmid: 12677087].
254 Gobin YP, Starkman S, Duckwiler GR, et al. MERCI 1: a phase 1 study of Mechanical Embolus Removal in Cerebral Ischemia14564. Stroke. 2004;35(12):2848-2854. [pmid: 15514171].
255 CASES Investigators. The Canadian Alteplase for Stroke Effectiveness Study (CASES) 14563. CMAJ. In press.
256 Barber PA, Demchuk AM, Zhang J, et al. Validity and reliability of a quantitative computed tomography score in predicting outcome of hyperacute stroke before thrombolytic therapy. ASPECTS Study Group. Alberta Stroke Programme Early CT Score. Lancet. 2000;355(9216):1670-1674. [pmid: 10905241].
257 Ostergaard L, Weisskoff RM, Chesler DA, et al. High resolution measurement of cerebral blood flow using intravascular tracer bolus passages. Part I: Mathematical approach and statistical analysis. Magn Reson Med. 1996;36(5):715-725. [pmid: 8916022].
258 Baird AE, Warach S. Magnetic resonance imaging of acute stroke. J Cereb Blood Flow Metab. 1998;18(6):583-609. [pmid: 9626183].
259 Butcher K, Parsons M, Baird T, et al. Perfusion thresholds in acute stroke thrombolysis. Stroke. 2003;34(9):2159-2164. [pmid: 12893953].
260 Statistics Canada. Age Standardized Mortality Rates. Available at: Internet 2004.
261 Newby LK, Rutsch WR, Califf RM, et al. Time from symptom onset to treatment and outcomes after thrombolytic therapy. GUSTO-1 Investigators. J Am Coll Cardiol. 1996;27(7):1646-1655. [pmid: 8636549].
262 White HD, Van de Werf FJ. Thrombolysis for acute myocardial infarction. Circulation. 1998;97(16):1632-1646. [pmid: 9593569].
263 Indications for fibrinolytic therapy in suspected acute myocardial infarction: collaborative overview of early mortality and major morbidity results from all randomised trials of more than 1000 patients. Fibrinolytic Therapy Trialists' (FTT) Collaborative Group. Lancet 1994; 343(8893):311–322.
264 Effectiveness of intravenous thrombolytic treatment in acute myocardial infarction. Gruppo Italiano per lo Studio della Streptochinasi nell'Infarto Miocardico (GISSI). Lancet 1986; 1(8478):397–402.
265 Raczynski JM, Finnegan JR Jr., Zapka JG, et al. REACT theory-based intervention to reduce treatment-seeking delay for acute myocardial infarction. Rapid Early Action for Coronary Treatment. Am J Prev Med. 1999;16(4):325-334. [pmid: 10493291].
266 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342(25):1887-1892. [pmid: 10861325]. [pmcid: 1557642].
267 Benson K, Hartz AJ. A comparison of observational studies and randomized, controlled trials. N Engl J Med. 2000;342(25):1878-1886. [pmid: 10861324].
268 Deeks JJ, Dinnes J, D'Amico R et al. Evaluating non-randomised intervention studies. Health Technol Assess 2003; 7(27):iii-173.
269 Evaluating non-randomized intervention studies. European Carotid Surgery Trial Collaborative Group. Health Technol Assess 7(27), 1–173. 2003.
270 Marshall M, Lockwood A, Bradley C, et al. Unpublished rating scales: a major source of bias in randomised controlled trials of treatments for schizophrenia. Br J Psychiatry. 2000;176:249-252. [pmid: 10755072].
271 Engels EA, Schmid CH, Terrin N, et al. Heterogeneity and statistical significance in meta-analysis: an empirical study of 125 meta-analyses. Stat Med. 2000;19(13):1707-1728. [pmid: 10861773].
272 Hardy RJ, Thompson SG. Detecting and describing heterogeneity in meta-analysis. Stat Med. 1998;17(8):841-856. [pmid: 9595615].