# Acknowledgments

Authors gratefully acknowledge the assistance of the Canadian Stroke Network (CSN) which was instrumental in assembling the review team.

Dr. Isabella Steffensen provided invaluable assistance in her role as technical writer on this evidence report, and Linda Brown skillful and swift transcription.