# Appendix F. Additional Acknowledgments

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgment does not reflect endorsement of this report.

Lawrence Brass, MD Professor of Neurology, Epidemiology & Public Health Yale University School of Medicine New Haven, Connecticut, USA Associate Professor of Neurology, University of Western Ontario London, Ontario, Canada

Vladimir Hachinski, MD Editor-in-Chief, STROKE (American Heart Association); Associate Professor of Neurology, University of Western Ontario London, Ontario, Canada

Peter Langehorne, MD Professor of Stroke Care, Academic Section of Geriatric Medicine Royal Infirmary Glasgow, Scotland, UK

Wieslaw Oczkowski, MD Neurologist, Hamilton Health Sciences Medical Centre; Director, Regional Stroke Program; Associate Clinical Professor, McMaster University Hamilton, Ontario, Canada

Dr.Gerald Peden, Medical Director Technology Evaluation and Medical Policy Claim Payment Policy Unit Independence Blue Cross Philadelphia, PA, USA

Ashfaq Shuaib, MD Professor and Director, Division of Neurology Department of Medicine University of Alberta Edmonton, Alberta, Canada

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

David Atkins, MD, MPH Chief Medical Officer Center for Outcomes and Evidence Agency for Healthcare Research Quality Rockville, MD, USA

Dean C.C. Johnston, MD Practice of Cerebrovascular/General Neurology St. Paul's Hospital Vancouver, BC, Canada

Randall T. Higashida, MD Clinical Professor Radiology & Neurosurgery U.C.S.F. Medical Center Department of Radiology University of California San Fransisco, CA, USA

Peter Langehorne, MD Professor of Stroke Care, Academic Section of Geriatric Medicine Royal Infirmary Glasgow, Scotland, UK

Wieslaw Oczkowski, MD Neurologist, Hamilton Health Sciences Medical Centre; Director, Regional Stroke Program; Associate Clinical Professor, McMaster University Hamilton, Ontario, Canada