# Appendix E. Evidence Tables

Evidence Table 1. Randomized clinical trials

Study Identification | Population Characteristics | Intervention (I)/Comparator (C) | Technique /Dose /Timing | Reported Outcomes (follow-up interval) | Quality Assessment (Jadad) | Funding Source
Albers, 2002, US^1^ | n= 61 | I: Timing of thrombolytic therapy in IS (n=23) | I: tPA / 0.9 mg/kg | - Mortality (90 d); - NIHSS, mRS, BI, GCS (30, 90d); - Rate of ICH | 1/5 | Genentech, Inc.
Design: RCT Parallel | Age: IG 66 (10)y; CG; 66 (11)y | C: Control (n=38) | C: Placebo
| % Male: IG 82.6; CG 57.9
| Race: White IG 95.7%; CG 84.2%e; Black IG 0%; CG 10.5%; Hispanic IG 0%; CG 5.3%; Asian IG 4.3%; CG 0%
| Inclusion Criteria: Acute IS defined by sudden onset of an acute focal neurological deficit due to ischemia with no sign of hemorrhage by CT; MCA origin with measurable focal neurological deficit; age 18–79y; within 3–5 hr post onset
| Exclusion Criteria: ICH by CT; sign of ischemia in > 1/3 of the territory of MCA; other exclusion as ATLANTIS A trial^2^
Alexandrov, 2004, US & Canada^3^ | n=126 | I: Mechanical clot disruption for IS (n=63) | I: Continuous 2-MHz transcranial Doppler ultrasonography / 750 mW & 3–6 mm insonation for 2hr + tPA/ 0.9 mg/kg, up to 90 mg/ within 3 hr post onset | - Complete recanalization rate; - Clinical recovery | 4/5 | US sites by NINDS grants & Canadian sites by the Canadian Institutes of Health Research & the Alberta Heritage Foundation
Design: RCT Parallel | Age: IG 67(12)y; CG 70(13)y | C: Control (n=63) | C: tPA/ same as IG + placebo (inactive channel with no continuous insonation)
| % Male: NR
| Race: NR
| Inclusion Criteria: Acute IS of MCA, within 3 hr post onset; IG Abnormal flow through MCA, with TIBI scale grade 0–3 (Thrombolysis in Brain Ischemia flow-grading system) before TPA tx
| Exclusion Criteria: NR
Auer, 1989, Austria^4^ | n=100 | I: Surgery for ICH, (n=50) | I: Hematoma evacuation through burr hole/<24h | - Mortality rate (1 wk*, 6 mo*); - Neurological recovery by clinical & CT signs (6 wk, 6 mo) | 1/5 | NR
Design: RCT Parallel | Age: 30–80y | C: Medical tx (n=50) | C: Medical tx, endoscopy
| % Male: IG 56; CG 66
| Race: NR
| Inclusion Criteria: Acute, hematoma > 10 cm^3^; within 48 hr of hemorrhage with neurological deficits, consciousness impairment, approved for surgery / angiography,
| Exclusion Criteria: aneurysm, arteriovenous malformation, tumor as the bleeding source, post-traumatic intracerebral hematomas
Batjer, 1999, US^5^ | n=21 | I: Surgery for ICH (n=8) | I: Frontotemporal or pterional craniotomy | - Mortality rate (6 mo); - Functional recovery (6 mo) | 1/5 | NR
Design: RCT Parallel | Age: IG 53.3 (3.4)y; CG1 54.9 (3.5) y; CG2 53.3 (5.9) y | C1: Best medical management (n=9) | C1: IV dexamethasone/ 4mg tapered over 7–14 d
| % Male: NR | C2: Best medical management + intracranial pressure monitoring (n=4) | C2: Antihypertensive same as C1 arm + placement of frontal ventriculostomy
| Race: NR
| Inclusion Criteria: Acute hypertensive putaminal ICH ≥3cm in diameter, moderate to severe hemiparesis/ uniform hemiplegia (grade 1–3)< 24hr post onset
| Exclusion Criteria: Un-associated neurologic illness, end-stage systemic disease; coagulopathy of any cause; aneurysm; arterioveous malformation, or tumour; decorticate or decerebrate posturing
Clark, 1999, US^6^ | n= 547 | I: Timing of thrombolytic therapy in IS (n=272) | I: TPA / 0.9 mg/kg, up to 90 mg (10% IV bolus over 1–2 min & 90% IV infusion over 1 hr)/ 1 hr | - Mortality (90 d); - NIHSS, mRS, BI, GCS (30, 90d) | 2/5 | Genentech, Inc.
Design: RCT Parallel | Age: IG: 66 (12)y; CG; 65 (11)y | C: Control (n=275) | C: Placebo/ matching dose for 1 hr
| % Male: IG: 54.8; CG: 63.6
| Race: White IG: 84.6%; CG: 83.6%
| Inclusion Criteria: Acute IS defined by sudden onset of an acute focal neurological deficit due to ischemia with no sign of hemorrhage by CT; MCA origin with measurable focal neurological deficit; age 18–79y; within 3–5 hr post onset
| Exclusion Criteria: ICH by CT; sign of ischemia in > 1/3 of the territory of MCA; other exclusion as ATLANTIS A trial^2^
Clark, 2000, US^2^ | n=142 | I: Timing of thrombolytic therapy in IS (n=71) | I: TPA / 0.9 mg/kg, up to 90 mg (10% IV bolus over 1–2 min & 90% IV infusion over 1 hr)/ 1 hr | - Recanalization* (negative effect of TPA); - NIHSS, mRS, Barthel Index; - Mortality (90 d); - Symptomatic ICH rate | 2/5 | Genentech, Inc.
Design: RCT Parallel | Age: I 67 (13)y; C 65 (12)y | C: Control (n=71) | C: Placebo/ matching dose for 1 hr
| % Male: NR
| Race: I = 82% White; C = 86% White
| Inclusion Criteria: Acute stroke with neurological deficit, within 6 hr post symptom onset
| Exclusion Criteria: Coma, severe obtundation, fixed eye deviation, complete hemiplegia; NIHSS <4; seizure; known ICH; hypertension; septic embolus; pericarditis or ventricular thrombus or aneurysm; trauma within 30 d; head trauma within 90 d; diathesis; pregnancy, lactation or parturition within 30 d; glucose <50 or >400, platelets <100,000, hematocrit <25; terminal illness; S hazard to tx
del Zoppo, 1998, US & Canada^7^ | n=40 | I: Timing of thrombolytic therapy in IS (n=26) | I: IA Pro-Urokinase/ 6 mg + Heparin/ 100 IU/kg bolus + 1000–2000 I.U./hr infusion/ median 5.5 hr post symptom onset | - MCA recanalization*; - Hemorrhage frequencies; - Mortality; - Functional outcomes (mRS, Barthel Index, NIHSS) | 3/5 | Abbott Laboratories
Design: RCT parallel | Age: full 64.2 (12.1)y; IG 66.5 (11)y, CG 69.6 (11.1)y | C: Placebo (n=14) | C: Saline placebo/ matching heparin/ matching time
| % Male: IG 54; CG 36
| Race: White IG 77%; CG 71%
| Inclusion Criteria: Acute carotid artery stroke; new focal neurological signs in the MCA within 6 hr of onset, NIHSS score ≥4; (except for isolated aphasia or hemianopsia; age 18–85y
| Exclusion Criteria: NIHSS score >30; coma; minor stroke symptoms; history of stroke within 6 wk; seizure; hypertension; head trauma within 90 d; active or recent hemorrhage within 14 d; diathesis; oral anticoagulation international normalized ratio >1.5
Eggers, 2003, Germany^8^ | n=25 | I: Mechanical clot disruption for IS (n=11) | I: Ultrasound/ continues 2 MHz transcranial Doppler mode + TPA/ 0.9 mg/kg IV over 1 hr | - Barthel Index (90 d)*; - NIHSS/ mRS; - Mortality | 1/5 | NR
Design: RCT Parallel | Age: full 61.3 (9.1)y; IG 60.3 (10.3)y; CG 62.1 (8.3)y | C: Control (n=14) | C: Matching IV TPA tx for 1 hr
| % Male: full 76; IG 73; CG 79
| Race: NR
| Inclusion Criteria: Acute IS in MCA/ M1; 18–80y, within 3 hr symptom onset (according to NINDS criteria)
| Exclusion Criteria: age <18y; pregnancy or lactation; insufficient acoustic window no allowing identification of the main basal cerebral arteries
Furlan, 1999, US & Canada^9^ | n=180 | I: Timing of thrombolytic therapy in IS: IA Urokinase tx (n=121) | I: IA Urokinase/ 9 mg + heparin/NR for 2 hr | - mRS (90 d); - MCA recanalization*; - Frequency of ICH; - Mortality (90 d) | 3/5 | Abbott Laboratories
Design: RCT parallel | Age: full 64 (14)y (groups identical in age) | C: Placebo (n=59) | C: Saline + Heparin for 2 hr
| % Male: full 59; IG 58, CG 61
| Race: White 80%
| Inclusion Criteria: Acute IS (MCA), 18–85y, with new neurological symptoms < 6 hr post symptom onset; NIHSS score ≥4
| Exclusion Criteria: NIHSS score >30; coma; improving neurological signs; history of stroke; seizure at onset; subarachnoid hemorrhage; history of ICH; neoplasm or subarachnoid hemorrhage; septic embolism; lacunar stroke; surgery; organ biopsy; head trauma within 90 d; active or recent hemorrhage within 30 d; known hemorrhagic diathesis; uncontrolled hypertension
Gray, 2004 UK^10^ | n=452 | I: Normalization of blood glucose levels for IS (n=221) | I: (GKI) Dextrose / continuous IV of 10% + Potassium chloride /20 mmol + Human soluble Actrapid / variable dose starting with 16 U/L for 24 hr | - Difference in mean plasma glucose values at subsequent time intervals in 24 h | 1/5 | NHS Northern & Yorkshire Research & Development Directorate; PPP Foundation
Design: RCT Parallel | Age: IG 75.2y; CG 74.4y | C: Control (n=231) | C: Saline/ 0.9% at 100 mL/hr for 24 hr
| % Male: IG 50.6; CG 54.1
| Race: NR
| Inclusion Criteria: Acute stroke< 24 hr post symptom onset, with admission glucose level >6 to <17 mmol/L
| Exclusion Criteria: Coma; hx of insulin-requiring diabetes; anemia; renal failure; congestive heart failure; S pre-existing disability
Hacke, 1998, Europe, Austrialia, New Zealanc^11^ | n=800 | I: rtPA (n=409) | I: Alteplase 0.9 mg/kg bodyweight, maximum of 90 mg/pts; bolus of 10% of the total dose over 1–2 min followed by a 60 min IV infusion of the remaining dose. (admin of anticoagulants, antiplatelet agents, haemorrheological agents, potential neuro-protective drugs & volume expanders were prohibited during 1^st^ 24 hr) | - Mortality; - mRS; - ICH rate | 4/5 | NR
Design: RCT Parallel | Age: median, IG=CG 68 y | C: Placebo (n=391) | C: Identical tx with placebo agent
| % Male: IG 60.6; CG 56.2
| Race: NR
| Inclusion Criteria: Acute ischemic stroke within 6 hrs of onset, early infarct change on CT less than 33% of the MCA territory
| Exclusion Criteria: signs of ICH or parenchymal hypoattenuation > 1/3 MCA territory; brain swelling > 33% of MCA; subarachnoid haemorrhage; unknown time of onset; coma or stupor; hemiplegia + fixed eye deviation; minor stroke symptoms (> 50 of the maximum 58 points on the SSS before randomization, or rapid improvement of symptoms); seizure < 6 mo; hypertension at randomization; traumatic brain injury < 14 d; recent surgery on the central nervous system; gastrointestinal or urinary tract haemorrhage; current tx with IA or subcutaneous heparin to raise the clotting time; known hereditary or acquired haemorrhagic diathesis; lactation; pregnancy or recent parturition < 30 d; lack of medically approved means of concentrations
Hacke, 1995, Europe^12^ | n=620 | I: rtPA (n=313) | I: rtPA 1.1 mg/kg | - Primary: Barthel, mRS (90 d); - Secondary: Combined Barthel & mRS, SSS (90 d)/ Mortality (30 d); - Tertiary: Early neurological recovery (SSS), and duration of hospital stay | 4/5 | Sponsored by Dr Karl Thomae GmbH (a member of Boehringer Ingelheim, Biberach, Germany)
Design: RCT Parallel | Age: IG 65 (12)y; CG 65 (11) | C: Placebo (n=307) | C: Placebo
| % Male: IG 60.1; CG 65.5
| Race: NR
| Inclusion Criteria: Acute ischemic stroke, 18–80 y; 0–6 hrs, early infarct change on CT less than 33% of the MCA territory
| Exclusion Criteria: See the eligibility criteria listed for Hacke 1998^11^
Haley, 1993, US^13^ | n=27 | I: Timing of thrombolytic therapy in IS (n=14) | I: IV tPA / 0.85 mg/kg for 1 hr | - NIHSS (baseline, 30 min, 1, 2 hr post infusion & 24 hr* post stroke), mRS, Barthel Index, GCS; - Mortality; - Onset to treatment time (OTT) interaction | 5/5 | Genentech Inc.
Design: RCT Parallel | Age: Within 90 min: IG 65 (11)y; CG 64 (8) y; 91–180 min: IG 72 (1)y, CG 67 (9)y | C: Control (n=13) | C: IV placebo/ matching dose for 1 hr
| % Male: NR
| Race: NR
| Inclusion Criteria: Acute IS causing neurological deficit, age 18–80, within 90 min or 91–180 min post symptom onset
| Exclusion Criteria: Mild stroke; symptoms only of sensory loss or ataxia; IC or subarachnoid hemorrhage; pregnancy, lactation; platelet < 100 000/mm3; protrombin time >15 s; elevated partial thromboplastin time due to heparin tx; major surgery or serious trauma within 14 d; gastrointestinal or urinary tract hemorrhage within 21d; arterial puncture at noncompressible site within 7 d; mean BP ≥135 mmHg; brain infarction within 90 d; serious medical illness
Juvela, 1989, Finland {1124} | n=52 | I: Surgery for ICH (n=26) | I: Surgery within 48 hr post bleeding (methods NR) | - Mortality rate (6 mo); - Morbidity; - GCS | 1/5 | NR
Design: RCT Parallel | Age: IG 54 (8.9)y, CG 49.3 (10.1)y | C: Conservative tx (n=26) | C1: NR/ within 48 hr post bleeding
| % Male: full 58; IG 65; CG 50
| Race: NR
| Inclusion Criteria: Acute ICH within 24 hr post bleed; unconscious &/or severe hemiparesis or dysphasia
| Exclusion Criteria: Cerebellar hematomas; traumatic hemorrhages; hemorrhages into brain tumors, & hemorrhages from cerebral aneurysms & arteriovenous malformations; malignant diseases; severe heart, lung or endocrine diseases; improving clinical condition or no reaction to pain
Kase, 2001, US^14^ | n=174 | I: Timing of thrombolytic therapy in IS (n=110) | I: IA Urokinase/ 9 mg directly into clot for 2 hr + Heparin/2000 IU bolus followed by 500 IU/hr for 2 hr | - Symptomatic ICH (relationship with baseline characteristics); - Mortality following symptomatic ICH; - Serum glucose level | 2/5 | NR
Design: RCT Parallel | Age: 64.2 (12.1)y | C: Placebo (n=64) | C: Saline + Heparin/ matching dose & timing
| % Male: NR
| Race: NR
| Inclusion Criteria: Acute IS M1 or M2 segments of MCA <6 hr post symptom onset; NIHSS score 4–30
| Exclusion Criteria: NR
Keris, 2001, Latvia^15^ | n=45 | I: Timing of thrombolytic therapy in IS (n=12) | I: IA TPA/ 25 mg for 5–10 min; IV TPA/25 mg for 60 min + Heparin/ 5000 U initially & twice a day for several days | - mRS (1, 12 mo, rated as good/poor); - Mortality | 1/5 | Supported in part by Medical Academy of Latvia
Design: RCT Parallel | Age: IG 53 (9)y; CG 65 (8)y | C: Conventional tx (n=33) | C: Heparin/ matching dose & frequency
| % Male: IG 83; CG 51.5
| Race: NR
| Inclusion Criteria: Acute severe hemiparetic IS within 6 hr post symptom onset
| Exclusion Criteria: sulcal effacement, mass effect, edema, or possible hemorrhage on CT
Lewandowski, 1999, US^16^ | n=35 | I: Timing of thrombolytic therapy in IS (n=17) | I: IV TPA/ 0.6 mg/kg for 30 min; IA TPA/ 0.6 mg/kg max 20 mg for max 2 hr | - NIHSS (7–10 d); - Barthel Index, mRS, GCS (3mo); - ICH & recanalization rate | 4/5 | Genetech, Inc
Design: RCT Parallel | Age: IG 65.6 (11.2)y; CG 67.3 (12.3)y | C: Placebo+ IA thrombolytic tx (n=18) | C: IV placebo + IA TPA/ matching dose for 2 hr max
| % Male: full 54.3; IG 53; CG 56
| Race: White, full 48.6%; IG 41%; CG 56%
| Inclusion Criteria: Acute focal IS within 3 hr of symptom onset (based on NINDS TPA stroke study)
| Exclusion Criteria: based on NINDS tPA stroke study, also excluded pts with hx of stroke within 6 wk; surgery biopsy or haemorrhage within 30 d of randomization
Marler, 2000, US^17^ (Part A) | n=302 | I: Timing of thrombolytic therapy in IS (n=157) | I: IV TPA/ 0.9 mg/kg (10% bolus & 90% as infusion), max 90 mg, for 1 hr | - NIHSS mRS, Barthel Index, GCS (baseline, 24 hr, 3 mo); - Time to tx & outcome | 1/5 | NINDS; Genetech Inc.
Design: RCT Parallel | Age: NR | C: Control (n=145) | C: Placebo powder/ 0.9 mg/kg 10% bolus & 90% as IV infusion for 1 hr
| % Male: NR
| Race: NR
| Inclusion Criteria: Acute stroke 0–90 min post symptom onset (based on NINDS TPA study for stroke)
| Exclusion Criteria: based on NINDS TPA study for stroke
Marler, 2000, US^17^ Part B | n=320 | I: Timing of thrombolytic therapy in IS (n=153) | I: IV TPA/ 0.9 mg/kg (10% bolus & 90% as infusion), max 90 mg, for 1 hr | - NIHSS, mRS, Barthel Index, GCS (baseline, 24 hr, 3 mo),; - Time to tx & outcome | 1/5 | NINDS; Genetech Inc.
Design: RCT Parallel | Age: NR | C: Control (n=167) | C: Placebo powder/ 0.9 mg/kg 10% bolus & 90% as IV infusion for 1 hr
| % Male: NR
| Race: NR
| Inclusion Criteria: Acute stroke 91–180 min post symptom onset (based on NINDS TPA study for stroke)
| Exclusion Criteria: based on NINDS TPA study for stroke
Mendelow, 2005, UK^18^ | n=1033 | I: Surgery for ICH (n=503) | I: Early surgery combined haematoma evacuation within 24 hr of randomization | - Mortality; - Functional outcomes (BI, mRS) | 3/5 | MRC (UK), the Stroke Association (UK), & the Northern Brainwave Appeal
Design: RCT Parallel | Age: IG 62 (52–70)y; CG 62 (53–71)y | C: Conservative tx (n=530) | C: Medical tx followed by evacuation if necessary
(Reviewer nominated; published beyond search dates) | % male: full 57.2; IG 57; 58CG | Baseline differences: NR
| Race: NR | Comments: Cross over from IG to CG n=31; from CG to IG n=140
| Inclusion Criteria: CT evidence of spontaneous supratentorial ICH, within 72 hr; uncertainty by neurosurgeon about benefits of either tx; hematoma ≥ 2 cm; GCS >=5
| Exclusion Criteria: haemorrhage due to an aneurysm or an angiographically proven arterobenous malformation; haemorrhage secondary ot a tumour or trauma; pts with cerebellar haemorrhage or extension of a supratentorial haelorrhage intor the brainstem; pts with severe pre-existing physical or mental diability or severe comorbidity that might intrerfer with the assessment of outcome; or if the surgery could not be undertaken within 24 hr of randomization
Morgenstern, 1998, US^19^ | n=34 | I: Surgery for ICH (n=17) | I: Open craniotomy & hematoma evacuation/ <12 hr post onset | - Mortality; - Barthel Index, GCS | 1/5 | AHA Clinician-Scientist Award (L.B.M.)
Design: RCT Parallel | Age: IG 56 (22–72) y; CG 51 (37–77) y | C: Standard medical tx (n=17) | C1: Standard medical tx /NR
| % Male: full 65; IG 29.4; CG 41
| Race: 32.4 % non-White, 67.6% White
| Inclusion Criteria: Acute ICH > 9 mL diagnosed by CT within 3 hr screening, <12 hr; GCS 5–15
| Exclusion Criteria: Secondary ICH; brainstem or cerebellar ICH, or ICH of thalamus or ventricular system; pre-hemorrhage low functional level; coagulopathy (>15 s; elevated partial thromboplastin time, platelet <100,000/mm^3^); precluded 6 mo survival; biopsy-proved amyloid angiopathy; hematoma volume 10–19 mL; GCS >15; better than antigravity strength on the affected side; ventricular extension >1/2 of one lateral ventricle or 1/3 of both lateral ventricles
Patel, 2001, US^20^ | n=624 | I: Pretreatment CT scoring system for IS (n=312) | I: CT/ within 3h symptom onset + IV tPA | - Frequency of EIC on baseline CT/ association of EIC with other baseline variables; effect of EIC on deterioration at 24 hr; - NIHSS, Barthel Index, mRS, GCS (3 mo); - Mortality (3 mo); - ICH rate (within 36 hr of tx) | 2/5 | NINDS - NIH Awards, Genentech Inc.
Design: RCT Parallel | Age: 61–68y | C: Control (n=312) | C: CT /within 3 hr symptom onset + placebo
| % Male: NR
| Race: NR
| Enrolment: Jan 1991–Oct 1994
| Inclusion Criteria: Acute IS < 3 hr (0–90 & 91–180 min) post onset
| Exclusion Criteria: NR
Roberts, 2002, US^21^ | n=159 | I: Pre-tx CT scoring system for IS (n=107) | I: CT, angiography /baseline, 24 hr, 7–10 d + recombinant pro-Urokinase/ 9 mg + IV heparin/2000 U bolus & 500U/hr for 4 hr at beginning of angiography | - Correlation of baseline CT with clinical outcomes; - NIHSS, mRS (90 d); - Mortality (90 d) | 1/5 | Abbott Laboratories
Design: RCT Parallel | Age: NR | C: Control (n=52) | C: CT/ matching intervals + IV heparin/ matching dose
| % Male: NR
| Race: NR
| Inclusion Criteria: Acute IS of MCA origin within 6 hr of onset; angiography: complete occlusion or contrast penetration with minimal perfusion of M1 or and M2 (based on PROACT II trial criteria segment of MCA)
| Exclusion Criteria: based on PROACT II trial criteria
Scott, 1999, UK^22^ | n=53 | I: Normalization of blood glucose levels for IS (n=28) | I: (GKI) Dextrose/ 500 mL 10% + Potassium chloride 20 mmol + Human soluble Actrapid insulin/16 U/L | - Mortality; - Plasma glucose level | 2/5 | Grant from Stroke Association of England & Wales; & a Northern & Yorkshire NHS Regional Training Fellowship
Design: RCT Parallel | Age: median IG 74 (11)y; CG 74 (9.6)y | C: Control (n=25) | C: Same as I/ glucoscans q2h for 24 hr
| % Male: full 44; IG 52; CG 36
| Race: NR
| Inclusion Criteria: Acute IS with neurological deficit lasting >24 hr, age >18 y; within 24 hr of onset
| Exclusion Criteria: > 24 hr post onset; coma; pneumonia; heart failure (New York Heart Association grades 3 or 4), renal failure (creatinine level of > 200 micro sing-mol/l; anemia (Hb 3); dementia; isolated posterior circulation syndromes without physical disability; pure language disorders; previously diagnosed insulin treated diabetes (type 1 or 2); or subarachnoid hemorrhage
Teernstra, 2003, The Netherlands^23^ | n=71 | I: Surgery for ICH (n=36) | I: Stereotactic tx of ICH by plasminogen activator, Urokinase/ 5000 IU, 8 x in 6 hr intervals over 48 hr | - ICH volume reduction (immediate*); - mRS; - Mortality (6mo) | 2/5 | Grant from the Fund for Developmental Medicine, Health Insurance Executive Board
Design: RCT Parallel | Age: IG 67 (± 68, range 47–84) y; CG 69 (±71, range 49–89) y | C: No-Surgery (n=35) | C1: Standard medical care
| % Male: full 56.3; IG 58; CG 56
| Race: NR
| Inclusion Criteria: Pts with expected mortality of 88%; age >45 y, ICH >10 cm^3^, within 72 hrs of ictus, Glasgow Eye Motor Score 2–10
| Exclusion Criteria: Arterioveous malformation
Zuccarello, 1999, US^24^ | n=20 | I: Surgery for ICH (n=9) | I: Varied techniques i.e. open craniotomy or CT-guided Stereotactic aspiration with 6000 U Urokinase in 12 hr intervals/ median 8 hr 35 min post onset | - NIHSS (median 3 mo)*; - Mortality; - Barhel Index; - ICH volume | 2/5 | NINDS
Design: RCT Parallel | Age: 62.4 (NR)y, 27–80y | C: Control (n=11) | C: Medical tx/ varied according to tx regiment/ median 3 hr 17 min onset to admission & 3 hr 10 min admission to randomization
| % Male: 55
| Race: White 60%; Black 40%
| Inclusion Criteria: Acute supratentorial ICH >10 cm^3^, diagnosed by CT, with focal neurological deficit; age >18y; GCS >4, within 24 hr of onset; surgery within 3 hr of randomization
| Exclusion Criteria: Lack of neurological deficit; infratentorial ICH; vascular abnormality proven by CT; terminal illness; coagulopathy; traumatic ICH; pregnancy
Morgenstern, 2003, US^25^ | n=1427 (for all 3 phases); phase 3 only: n=238 | I: Community education program for acute stroke (n=748/ phase 3: n=130) | I: Community education + professional development & organizational change/ 15 mo | - Frequency of IV TPA tx in IS*; - Frequency of IV TPA in eligible candidates* | 1/3 | NR
Design: Controlled Clinical Trial | Age: phase 1: >21y | C: Control (n=679/ phase 3: n=108) | C: No intervention/15 mo
| % Male: phase 1: IG 42.6, CG 38.2; phase 2: IG 43.3, CG 41.9; phase 3: IG 43.1, CG 43.5
| Race: Non-White/ phase 1: IG 23.4%, CG 34%; phase 2: IG 20.8%, CG 28%; phase 3: IG 25.4%, CG 31.5%
| Inclusion Criteria: County residents experience of cerebrovascular event; IV tPA inclusion according to NINDS
| Exclusion Criteria: non-résidents; age < 21y

US = United States; NR = not reported; NA = not available; n = number of participants; pts = patients; y = year; mo = month; hr = hour; min = minutes; s = seconds; mg = milligrams; mL = millilitres; mmHg = millimetres of mercury; kg = kilogram; IU = international units; mmol/l = millimoles / litre; MHz = megahertz; IG = intervention group; CG = control group; BP = blood pressure; HR = heart rate; IS = ischemic stroke; ICH = intracranial hemorrhage; ER = emergency room; IV = intravenous; CT = computed tomography; MRI = magnetic resonance imaging; tx = treatment; hx = history; IV = intravenous; IA = intra arterial; tPA = recombinant tissue plasminogen activator; S = significance; * = Significance (S) of statistical analysis; MCA = middle cerebral artery; AVM = arteriovenous malformation; Vmca = velocity in the middle cerebral artery; NINDS = National Institute of Neurological Disorders and Stroke; NIHSS = National Institute of Health and Stroke Scale; ECASS = European Cooperative Acute Stroke Study; GCS = Glasgow Coma Scale; mRS = Modified Rankin Scale; GCS = Glasgow Coma Scale; NOS = Newcastle-Ottawa Scale; HSF = Heart and Stroke Foundation; AHA = American Heart Association; NHS = National Health Service; NIH = National Institutes of Health; TOAST = Trial of Org 10172 in Acute Stroke Treatment

NOTE: Numerical values are mean (standard deviation) unless otherwise indicated

## Observational Studies

Evidence Table 2. Multiple prospective cohort

Study Identification | Population Characteristics | Intervention | Technique /Dose /Timing | Reported Outcomes | Quality Assessment | Funding Source
Suarez, 2002, US^26^ | n =45 | I: Pre-treatment MRI scoring system for IS (n=45) | I: IV TPA/ 0.6 mg/Kg /completed within 5 hr of onset + Emergency MRI (Diffusion weighted & Perfusion weighted) + Angiography in case of acute cortical infarction and when determined with vessel occlusion, IA Urokinase/ up to 750,000 units or IA tPA for maximum 0.3 mg/kg | - Correlation between abnormal perfusion-weighted imaging findings and cerebral angiographic findings; - Symptomatic ICH; - Mortality; - NIHSS, Barthel Index (3 mo post tx) | 9/19 | NR
Design: Multiple Prospective Cohort | Age: 67 (13)y
| % Male: 42
| Race: NR
| Inclusion Criteria: Acute IS <3hrs post symptom onset; no improvement on clinical sign; no ICH on CT; age 18–80; NIHSS score ≥4
| Exclusion Criteria: Evidence of cerebral hemorrhage or mass effect on CT; questionable diagnosis (e.g., seizure; high risk hemorrhage; pregnancy or delivery < 14 d; diastolic BP>120 mmHg)
Akins, 2000, US^27^ | n = NR | Use of ER protocols for management of acute stroke | Observational study examining ED physicians' ability to initiate thrombolysis | - Protocol deviation for ED physicians compared to neurologists; - Number of pts treated by two tx groups | 9/19 | NR
Design: Single Retrospective Cohort | Age: 73 (11)y | Note: Data is broken for two groups treated by ER physician (n=23) /or by neurologist (n=20)
| % Male: NR
| Race: NR
| Inclusion Criteria: Consecutive acute IS treated with IV TPA according to NINDS protocol treated by ER physician or neurologist
| Exclusion Criteria: NR
Hermier, 2003, France^28^ | n=28 | Pre-treatment MRI scoring system for IS (recanalization n=18; persistent occlusion n=10) | CT + MRI (included three dimensional time of flight tube MRA; echoplanar imaging isotropic diffusion; and Perfusion MRI) | - NIHSS (60 d); - Relative & absolute time to peak/ 60 d lesion volume | 7/19 | Délégation à la Recherche des Hospices Civilis de Lyon
Design: Single Prospective Cohort | Age: 65 (14)y | | | Note: Observational study correlating outcome with measured parameters
| % Male: 55.2
| Race: NR
| Inclusion Criteria: Acute IS, with pre-tx & within 6 hr MRI; NIHSS >4 & no contraindication to tPA tx; with recanalization on MRI, or persistent occlusion on MRI
| Exclusion Criteria: Preexisting neurologic, psychiatric, or other illness confounding neurological evaluation; contraindications to MRI; movement artifacts precluding MRI interpretation; lacunar syndromes; presence of factors affecting time-to-peak analysis
Hill, 2000, Canada29 | n=NR | Use of designated centers for acute stroke | Restructuring health care services, centralizing neurosurgical & neurological staff, using a modified model of NIHSS study with the aim of decrease time to tx | - Improvement in time intervals of onset to ER; onset to CT; ER to CT; ER to tx; CT to tx | 5/19 | Grants from HSF of Canada/ Alberta/ North West Territories; Medical Research Council of Canada & the Alberta Heritage Foundation for Medical Research Incentive Award
Design: Single Prospective Cohort | Age: mean 69.3y
| % Male: 55
| Race: NR
| Inclusion Criteria: Acute IS, treated within 3 hr of symptom onset
| Exclusion Criteria: TIA (transient ischemic attack) or mild stroke; hx of subarachnoid hemorrhage; hypertension; hemorrhage, mass effect or edema, tumour or AVM on pre-tx CT; major surgery or trauma within 14 d; active internal bleeding; arterial puncture at a non-compressible site in the last 7 d; hx of hematological abnormality or coagulopathy or anticoagulation (PT > 15s, INR >1.4, PTT >4s, platelets <100,000/L)
Jahnke, 2003, US^30^ | Age: NR | Use of ER protocols for management of acute stroke | Observational study examining ED protocol | - Number of pts treated; - Door-to-needle time decreased following implementation of the protocol | 6/19 | NR
Design: Single Retrospective Cohort | % Male: NR | Note: number of pts treated n=65
| Race: NR
| Inclusion Criteria: Acute stroke with mild to severe neurological deficits
| Exclusion Criteria: NR
Kilpatrick, 2001, US^31^ | n =51 | CT perfusion/ angiography for IS (n=51) | CT+ CT-Angiography + XeCT CBF/ within 24 hr post onset / completed at mean 44.5 min, range 15–223 min post onset | - Association of CBF, and infarction rates; - Association of CT angiogram occlusion with infarction rate | 5/19 | Praxair
Design: Single Retrospective Cohort | Age: 61.7 (19–89)y
| % Male: 63
| Race: NR
| Inclusion Criteria: Acute hemispheric IS within 24 hr post symptom onset, undergone CT, CT-Angiography & XeCT(xenon-enhanced-CT ), CBF(cerebral blood flow); NIHSS score 1–26
| Exclusion Criteria: posterior circulation symptoms
Smith, 1999, US^33^ | n=37 (treated pts) | Use of ER protocols for management of acute stroke (n=37) | Observational study examining the ability of ED physicians to treat thrombolysis | - Onset-to-ED; onset-to needle time; - Door to needle time (also: door-to physician; door-to-CT) | 8/19 | NR
Design: Single Prospective Cohort | Age: 63 (16)y, 22–87y
| % Male: 68
| Race: White 86%; Black 11%; Asian 3%
| Inclusion Criteria: Acute IS treated with TPA, presented to ER 64 (29) min post onset
| Exclusion Criteria: NR
Agarwal, 2004, US^34^ | n=83 | CT perfusion/ angiography for IS (n=66) | I: CT/ 1.4 (0.7) hr & at 24 hr post onset + IV tPA/ 46–90 mg (0.9 mg/kg, max 90 mg)/ 2.3 (15) hr post onset | - Correlation with hyperdense middle cerebral artery signs (HCMAS) and outcomes; - NIHSS (baseline, 24 hr post onset, discharge); - mRS (90 d) | 8/19 | NINDS grant
Design: Case Control | Age: IG 70 (15)y; CG 71 (15)y | C: Control (n=17) | C: CT/ 1.8 (1.1) hr & at 24 hr post onset + IA tPA/ 14–20 mg/ 4.4 (1.1) hr post onset
| % Male: IG 61; CG 47
| Race: White IG 79%; CG 88%
| Inclusion Criteria: Acute IS (according to TOAST) <3 hr post symptom onset (IG) or 3–6 hr post onset & pts excluded for IV TPA based on NINDS criteria (CG)
| Exclusion Criteria: Cerebral hemorrhage/ NINDS criteria for thrombolytic tx

US = United States; NR = not reported; NA = not available; n = number of participants; pts = patients; y = year; mo = month; hr = hour; min = minutes; s = seconds; mg = milligrams; mL = millilitres; mmHg = millimetres of mercury; kg = kilogram; IU = international units; mmol/l = millimoles / litre; MHz = megahertz; IG = intervention group; CG = control group; BP = blood pressure; HR = heart rate; IS = ischemic stroke; ICH = intracranial hemorrhage; ER = emergency room; IV = intravenous; CT = computed tomography; MRI = magnetic resonance imaging; tx = treatment; hx = history; IV = intravenous; IA = intra arterial; tPA = recombinant tissue plasminogen activator; S = significance; * = Significance (S) of statistical analysis; MCA = middle cerebral artery; AVM = arteriovenous malformation; Vmca = velocity in the middle cerebral artery; NINDS = National Institute of Neurological Disorders and Stroke; NIHSS = National Institute of Health and Stroke Scale; ECASS = European Cooperative Acute Stroke Study; GCS = Glasgow Coma Scale; mRS = Modified Rankin Scale; GCS = Glasgow Coma Scale; NOS = Newcastle-Ottawa Scale; HSF = Heart and Stroke Foundation; AHA = American Heart Association; NHS = National Health Service; NIH = National Institutes of Health; TOAST = Trial of Org 10172 in Acute Stroke Treatment

NOTE: Numerical values are mean (standard deviation) unless otherwise indicated

## Pre-Post Studies

Evidence Table 3. Pre-post design

Study Identification | Population Characteristics | Intervention (I)/Comparator (C) | Technique /Dose /Timing | Reported Outcomes | Quality Assessment | Funding Source
Kay, 1993, Hong Kong^35^ | n=10 | Antihypertensive therapy for ICH | IV Ketanserin injection/ single does up to 10 mg/ 10–52 hrs post symptom onset | - Systolic arterial pressure (0–2 hr)^*^; - Mean intracranial pressure; - Cerebral perfusion pressure (0–2hr)^*^ | NA | NR
Design: Pre-Post | Age: 49–64y | (n=10)
| % Male: 50
| Race: NR
| Inclusion Criteria: ICH confirmed by CT 8–48 hr pre-recruitment; systolic BP >180 mmHg, diastolic BP >100 mmHg
| Exclusion Criteria: NR
Lattimore, 2003, US^32^ | n=327/511 pts admitted to the hospital met inclusion criteria for IS from Jan 2000 to Dec 2001 | I: Use of designated centers for acute stroke | I: Around the clock coverage by stroke team | - Time to tx; - Correlation of establishment of stroke center and number of pts treated with tPA | NA | NR
Design: Pre-Post | Age: 76 (range 27–95)y
| % Male: 51
| Race: NR
| Inclusion Criteria: Acute IS < 6 hr (53% within 3 hr post onset), with persistent neurological deficits, & all inclusion criteria based on NINDS & guidelines from a Special Writing Group of the AHA
| Exclusion Criteria: Based on NINDS & guidelines from a Special Writing Group of the AHA
Nishiyama, 2000, Japan^36^ | n=22 | I: Antihypertensive therapy for ICH (n=22) | I: Nicardipine infusion/ 484 ± 343 (138–826) mg for 213 ± 114 (92–323) hr | - BP^*^, HR, conscious level, Vmca, pulsatility index; - Intracranial pressure; - Cerebral perfusion pressure; - Platelet counts; - CT signs of change in bleeding and/or brain edema | NA | NR
Design: Pre-post | Age: 64 (±15, range 47–79) y
| % Male: 50
| Race: NR
| Inclusion Criteria: Acute putaminal hemorrhage secondary to hypertension, with surgical drainage of hematoma
| Exclusion Criteria: history of liver or renal damage

US = United States; NR = not reported; NA = not available; n = number of participants; pts = patients; y = year; mo = month; hr = hour; min = minutes; s = seconds; mg = milligrams; mL = millilitres; mmHg = millimetres of mercury; kg = kilogram; IU = international units; mmol/l = millimoles / litre; MHz = megahertz; IG = intervention group; CG = control group; BP = blood pressure; HR = heart rate; IS = ischemic stroke; ICH = intracranial hemorrhage; ER = emergency room; IV = intravenous; CT = computed tomography; MRI = magnetic resonance imaging; tx = treatment; hx = history; IV = intravenous; IA = intra arterial; tPA = recombinant tissue plasminogen activator; S = significance; * = Significance (S) of statistical analysis; MCA = middle cerebral artery; AVM = arteriovenous malformation; Vmca = velocity in the middle cerebral artery; NINDS = National Institute of Neurological Disorders and Stroke; NIHSS = National Institute of Health and Stroke Scale; ECASS = European Cooperative Acute Stroke Study; GCS = Glasgow Coma Scale; mRS = Modified Rankin Scale; GCS = Glasgow Coma Scale; NOS = Newcastle-Ottawa Scale; HSF = Heart and Stroke Foundation; AHA = American Heart Association; NHS = National Health Service; NIH = National Institutes of Health

NOTE: Numerical values are mean (standard deviation) unless otherwise indicated; TOAST = Trial of Org 10172 in Acute Stroke Treatment

Quality of Pre-post studies was not determined.

Summary Table: Intervention J: Community education for stroke (excluded pre-post studies)

Study Identification | Setting | Population Characteristics | Intervention /Outcome | Limitations
Alberts,1992, US^37^ | University Hospital (Duke/Durham) | Cerebral infarction; stroke-in-evolution; (ICH); subarachnoid hemorrhage | Community education program, professional education and helicopter transport/ | Intervention mixed with other program changes; Lacks clinical outcomes; diagnoses differed pre and post
Design: Pre-post | | Pre-educational: n=290 | Time delay in presentation & referral
| | Post-educational: n=189
Barsan, 1994, US^38^ | 3 university & 9 community hospitals (including 2 teaching hospitals) | Pts within 24 hrs post onset (NIH tPA pilot study: Feb 1987-Aug 1989); n=1948 | Community education program / | Retrospective evaluation of delay times coincident with program implementation; Unable to separate secular trends; Stroke severity was not accounted for at baseline
Design: Pre-post | | | Time of onset to hospital arrival
Becker, 2001, US^39^ | King County (Washington) resident community | English speaking residents, randomly chosen & willing to participate in a telephone survey: n=1058 | Community base education campaign/ | No measurement of clinical outcomes
Design: Pre-post | | | Stroke knowledge (questionnaire based)
Smith, 1999, US^40^ | 2 university hospitals | Paramedic Trainees: n=22 | Educational program on stroke to improve paramedic accuracy in stroke recognition/ | No measurement of clinical outcomes; Program directed at paramedics not general public
Design: Pre-post | | Stroke pts transferred by paramedics: n=84 (32 were transported by trained paramedics; 29/32 had stroke dx) | Paramedic test scores/ accuracy in identification of stroke victims
Weinhardt, 1999, US^41^ | NR | Stroke patients: n=28 | Education video to improve case management of stroke pts | No clinical outcomes
Design: Pre-post | | | Pts knowledge of stroke (4 items from NIHSS)

US = United States; NR = not reported; NA = not available; n = number of participants; pts = patients; y = year; mo = month; hr = hour; min = minutes; s = seconds; mg = milligrams; mL = millilitres; mmHg = millimetres of mercury; kg = kilogram; IU = international units; mmol/l = millimoles / litre; MHz = megahertz; IG = intervention group; CG = control group; BP = blood pressure; HR = heart rate; IS = ischemic stroke; ICH = intracranial hemorrhage; ER = emergency room; IV = intravenous; CT = computed tomography; MRI = magnetic resonance imaging; tx = treatment; hx = history; IV = intravenous; IA = intra arterial; tPA = recombinant tissue plasminogen activator; S = significance; * = Significance (S) of statistical analysis; MCA = middle cerebral artery; AVM = arteriovenous malformation; Vmca = velocity in the middle cerebral artery; NINDS = National Institute of Neurological Disorders and Stroke; NIHSS = National Institute of Health and Stroke Scale; ECASS = European Cooperative Acute Stroke Study; GCS = Glasgow Coma Scale; mRS = Modified Rankin Scale; GCS = Glasgow Coma Scale; NOS = Newcastle-Ottawa Scale; HSF = Heart and Stroke Foundation; AHA = American Heart Association; NHS = National Health Service; NIH = National Institutes of Health

NOTE: Numerical values are mean (standard deviation) unless otherwise indicated; TOAST = Trial of Org 10172 in Acute Stroke Treatment

Quality of Pre-post studies could not be determined.

### Listing of Studies Included in Evidence Tables

Agarwal PK. Hyperdense middle cerebral artery sign: can it be used to select intra-arterial versus intravenous thrombolysis in acute ischemic stroke?. Cerebrovasc Dis. 2004;17(23):182-90. [pmid: 14707420].
Akins PT, Delemos C, Wentworth D, Byer J, Schorer SJ, Atkinson RP. Can emergency department physicians safely and effectively initiate thrombolysis for acute ischemic stroke?. Neurology. 2000;55(12):1801-5. [pmid: 11134376].
Albers GW, Clark WM, Madden KP, Hamilton SA. ATLANTIS trial: results for patients treated within 3 hours of stroke onset. Alteplase Thrombolysis for Acute Noninterventional Therapy in Ischemic Stroke. Stroke. 2002;33(2):493-95. [pmid: 11823658].
Alexandrov AV, Molina CA, Grotta JC, Garami Z, Ford SR, Alvarez-Sabin J, et al. Ultrasound-enhanced systemic thrombolysis for acute ischemic stroke. N Engl J Med. 2004;351(21):2170-8. [pmid: 15548777].
Auer LM, Deinsberger W, Niederkorn K, Gell G, Kleinert R, Schneider G, et al. Endoscopic surgery versus medical treatment for spontaneous intracerebral hematoma: a randomized study. J Neurosurg. 1989;70(4):530-5. [pmid: 2926492].
Batjer HH, Reisch JS, Allen BC, Plaizier LJ, Su CJ. Failure of surgery to improve outcome in hypertensive putaminal hemorrhage. A prospective randomized trial. Arch Neurol. 1990;47(10):1103-6. [pmid: 2222242].
Clark WM, Wissman S, Albers GW, Jhamandas JH, Madden KP, Hamilton S. Recombinant tissue-type plasminogen activator (Alteplase) for ischemic stroke 3 to 5 hours after symptom onset. The ATLANTIS Study: a randomized controlled trial. Alteplase Thrombolysis for Acute Noninterventional Therapy in Ischemic Stroke.[see comment]. JAMA. 1999;282(21):2019-26. [pmid: 10591384].
Clark WM, Albers GW, Madden KP, Hamilton S. The rtPA (alteplase) 0- to 6-hour acute stroke trial, part A (A0276g): results of a double-blind, placebo-controlled, multicenter study. Thromblytic therapy in acute ischemic stroke study investigators. Stroke. 2000;31(4):811-6. [pmid: 10753980].
del Zoppo GJ, Higashida RT, Furlan AJ, Pessin MS, Rowley HA, Gent M. PROACT: a phase II randomized trial of recombinant pro-urokinase by direct arterial delivery in acute middle cerebral artery stroke. PROACT Investigators. Prolyse in Acute Cerebral Thromboembolism.[see comment]. Stroke. 1998;29(1):4-11. [pmid: 9445320].
Eggers J, Koch B, Meyer K, Konig I, Seidel G. Effect of ultrasound on thrombolysis of middle cerebral artery occlusion. Ann Neurol. 2003;53(6):797-800. [pmid: 12783427].
Furlan A, Higashida R, Wechsler L, Gent M, Rowley H, Kase C, et al. Intra-arterial prourokinase for acute ischemic stroke. The PROACT II study: a randomized controlled trial. Prolyse in Acute Cerebral Thromboembolism.[see comment]. JAMA. 1999;282(21):2003-11. [pmid: 10591382].
Gray CS, Hildreth AJ, Alberti GK, O'Connell JE. Collaboration GIST. Poststroke hyperglycemia: natural history and immediate management. Stroke. 2004;35(1):122-6. [pmid: 14671236].
Haley EJ, Brott TG, Sheppard GL, Barsan W, Broderick J, Marler K, et al. Pilot randomized trial of tissue plasminogen activator in acute ischemic stroke. The TPA Bridging Study Group. Stroke. 1993;24(7):1000-4. [pmid: 8322373].
Hermier M, Nighoghossian N, Adeleine P, Berthezene Y, Derex L, Yilmaz H, et al. Early magnetic resonance imaging prediction of arterial recanalization and late infarct volume in acute carotid artery stroke. J Cereb Blood Flow Metab. 2003;23(2):240-8. [pmid: 12571455].
Hill MD, Barber PA, Demchuk AM, Sevick RJ, Newcommon NJ, Green T, et al. Building a “brain attack” team to administer thrombolytic therapy for acute ischemic stroke. CMAJ. 2000;162(11):1589-93. [pmid: 10862236]. [pmcid: 1231342].
Jahnke HK, Zadrozny D, Garrity T, Hopkins S, Frey JL, Christopher M. Stroke teams and acute stroke pathways: one emergency department's two-year experience. J Emerg Nurs. 2003;29(2):133-9. [pmid: 12660695].
Juvela S, Heiskanen O, Poranen A, Valtonen S, Kuurne T, Kaste M, et al. The treatment of spontaneous intracerebral hemorrhage. A prospective randomized trial of surgical and conservative treatment.[see comment]. J Neurosurg. 1989;70(5):755-8. [pmid: 2651586].
Kase CS, Furlan AJ, Wechsler LR, Higashida RT, Rowley HA, Hart RG, et al. Cerebral hemorrhage after intra-arterial thrombolysis for ischemic stroke: the PROACT II trial. Neurology. 2001;57(9):1603-10. [pmid: 11706099].
Kay R, Poon WS, Nicholls MG. Effect of intravenous ketanserin on arterial and intracranial pressures in patients with systemic hypertension following intracerebral haemorrhage. J Hum Hypertens. 1993;7(4):369-71. [pmid: 8410928].
Keris V, Rudnicka S, Vorona V, Enina G, Tilgale B, Fricbergs J. Combined intraarterial/intravenous thrombolysis for acute ischemic stroke. AJNR Am J Neuroradiol. 2001;22(2):352-8. [pmid: 11156782].
Kilpatrick MM, Yonas H, Goldstein S, Kassam AB, Gebel JJ, Wechsler LR, et al. CT-based assessment of acute stroke: CT, CT angiography, and xenon-enhanced CT cerebral blood flow.[see comment]. Stroke. 2001;32(11):2543-9. [pmid: 11692014].
Lattimore SU, Chalela J, Davis L, DeGraba T, Ezzeddine M, Haymore J, et al. Impact of establishing a primary stroke center at a community hospital on the use of thrombolytic therapy: the NINDS Suburban Hospital Stroke Center experience. Stroke. 2003;34(6):e55-e57. [pmid: 12750543].
Lewandowski CA, Frankel M, Tomsick TA, Broderick J, Frey J, Clark W, et al. Combined intravenous and intra-arterial r-TPA versus intra-arterial therapy of acute ischemic stroke: Emergency Management of Stroke (EMS) Bridging Trial. Stroke. 1999;30(12):2598-605. [pmid: 10582984].
Lin CS, Tsai J, Woo P, Chang H. Prehospital delay and emergency department management of ischemic stroke patients in Taiwan, R.O.C. Prehosp Emerg Care. 1999;3(3):194-200. [pmid: 10424855].
Marler J, Tilley BC, Lu Y, Brott TG, Lyden PC, Grotta JC, et al. Early stroke treatment associated with better outcome: the NINDS rt-PA stroke study. Neurology. 2000;55(11):1649-55. [pmid: 11113218].
Morgenstern LB, Frankowski RF, Shedden P, Pasteur W, Grotta JC. Surgical treatment for intracerebral hemorrhage (STICH): a single-center, randomized clinical trial. Neurology. 1998;51(5):1359-63. [pmid: 9818860].
Morgenstern LB, Bartholomew LK, Grotta JC, Staub L, King M, Chan W. Sustained benefit of a community and professional intervention to increase acute stroke therapy. Arch Intern Med. 2003;163(18):2198-2202. [pmid: 14557217].
Nishiyama T, Yokoyama T, Matsukawa T, Hanaoka K. Continuous nicardipine infusion to control blood pressure after evacuation of acute cerebral hemorrhage. Can J Anaesth. 2000;47(12):1196-1201. [pmid: 11132741].
Patel SC, Levine SR, Tilley BC, Grotta JC, Lu M, Frankel M, et al. Lack of clinical significance of early ischemic changes on computed tomography in acute stroke.[see comment]. JAMA. 2001;286(22):2830-2838. [pmid: 11735758].
Roberts HC, Dillon WP, Furlan AJ, Wechsler LR, Rowley HA, Fischbein NJ, et al. Computed tomographic findings in patients undergoing intra-arterial thrombolysis for acute ischemic stroke due to middle cerebral artery occlusion: results from the PROACT II trial.[see comment]. Stroke. 2002;33(6):1557-65. [pmid: 12052991].
Scott JF, Robinson GM, French JM, O'Connell JE, Alberti KG, Gray CS. Glucose potassium insulin infusions in the treatment of acute stroke patients with mild to moderate hyperglycemia: the Glucose Insulin in Stroke Trial (GIST). Stroke. 1999;30(4):793-9. [pmid: 10187881].
Smith RW, Scott PA, Grant RJ, Chudnofsky CR, Frederiksen SM. Emergency physician treatment of acute stroke with recombinant tissue plasminogen activator: a retrospective analysis. Acad Emerg Med. 1999;6(6):618-25. [pmid: 10386679].
Suarez JI, Zaidat OO, Sunshine JL, Tarr R, Selman WR, Landis DM. Endovascular administration after intravenous infusion of thrombolytic agents for the treatment of patients with acute ischemic strokes. Neurosurgery. 2002;50(2):251-9. [pmid: 11844259].
Teernstra OP, Evers SM, Lodder J, Leffers P, Franke CL, Blaauw G, et al. Stereotactic treatment of intracerebral hematoma by means of a plasminogen activator: a multicenter randomized controlled trial (SICHPA). Stroke. 2003;34(4):968-74. [pmid: 12649510].
Zuccarello M, Brott T, Derex L, Kothari R, Sauerbeck L, Tew J, et al. Early surgical treatment for supratentorial intracerebral hemorrhage: a randomized feasibility study.[see comment]. Stroke. 1999;30(9):1833-9. [pmid: 10471432].

## Reference List

1 Albers GW, Clark WM, Madden KP, Hamilton SA. ATLANTIS trial: results for patients treated within 3 hours of stroke onset. Alteplase Thrombolysis for Acute Noninterventional Therapy in Ischemic Stroke.[see comment]. Stroke. 2002;33(2):493-495. [pmid: 11823658].
2 Clark WM, Albers GW, Madden KP, Hamilton S. The rtPA (alteplase) 0- to 6-hour acute stroke trial, part A (A0276g): results of a double-blind, placebo-controlled, multicenter study. Thromblytic therapy in acute ischemic stroke study investigators. Stroke. 2000;31(4):811-816. [pmid: 10753980].
3 t AV, Molina CA, Grotta JC, Garami Z, Ford SR, Alvarez-Sabin J, et al. Ultrasound-enhanced systemic thrombolysis for acute ischemic stroke. N Engl J Med. 2004;351(21):2170-2178. [pmid: 15548777].
4 Auer LM, Deinsberger W, Niederkorn K, Gell G, Kleinert R, Schneider G, et al. Endoscopic surgery versus medical treatment for spontaneous intracerebral hematoma: a randomized study. J Neurosurg. 1989;70(4):530-535. [pmid: 2926492].
5 Batjer HH, Reisch JS, Allen BC, Plaizier LJ, Su CJ. Failure of surgery to improve outcome in hypertensive putaminal hemorrhage. A prospective randomized trial. Arch Neurol. 1990;47(10):1103-1106. [pmid: 2222242].
6 Clark WM, Wissman S, Albers GW, Jhamandas JH, Madden KP, Hamilton S. Recombinant tissue-type plasminogen activator (Alteplase) for ischemic stroke 3 to 5 hours after symptom onset. The ATLANTIS Study: a randomized controlled trial. Alteplase Thrombolysis for Acute Noninterventional Therapy in Ischemic Stroke.[see comment]. JAMA. 1999;282(21):2019-2026. [pmid: 10591384].
7 del Zoppo GJ, Higashida RT, Furlan AJ, Pessin MS, Rowley HA, Gent M. PROACT: a phase II randomized trial of recombinant pro-urokinase by direct arterial delivery in acute middle cerebral artery stroke. PROACT Investigators. Prolyse in Acute Cerebral Thromboembolism.[see comment]. Stroke. 1998;29(1):4-11. [pmid: 9445320].
8 Eggers J, Koch B, Meyer K, Konig I, Seidel G. Effect of ultrasound on thrombolysis of middle cerebral artery occlusion. Ann Neurol. 2003;53(6):797-800. [pmid: 12783427].
9 Furlan A, Higashida R, Wechsler L, Gent M, Rowley H, Kase C, et al. Intra-arterial prourokinase for acute ischemic stroke. The PROACT II study: a randomized controlled trial. Prolyse in Acute Cerebral Thromboembolism.[see comment]. JAMA. 1999;282(21):2003-2011. [pmid: 10591382].
10 Gray CS, Hildreth AJ, Alberti GK, O'Connell JE, Collaboration GIST. Poststroke hyperglycemia: natural history and immediate management. Stroke. 2004;35(1):122-126. [pmid: 14671236].
11 Hacke W, Kaste M, Fieschi C, von KR, Davalos A, Meier D, et al. Randomised double-blind placebo-controlled trial of thrombolytic therapy with intravenous alteplase in acute ischaemic stroke (ECASS II). Second European-Australasian Acute Stroke Study Investigators.[see comment]. Lancet. 1998;352(9136):1245-1251. [pmid: 9788453].
12 Hacke W, Kaste M, Fieschi C, Toni D, Lesaffre E, von KR, et al. Intravenous thrombolysis with recombinant tissue plasminogen activator for acute hemispheric stroke. The European Cooperative Acute Stroke Study (ECASS)[see comment]. JAMA. 1995;274(13):1017-1025. [pmid: 7563451].
13 Haley EJ, Brott TG, Sheppard GL, Barsan W, Broderick J, Marler K, et al. Pilot randomized trial of tissue plasminogen activator in acute ischemic stroke. The TPA Bridging Study Group. Stroke. 1993;24(7):1000-1004. [pmid: 8322373].
14 Kase CS, Furlan AJ, Wechsler LR, Higashida RT, Rowley HA, Hart RG, et al. Cerebral hemorrhage after intra-arterial thrombolysis for ischemic stroke: the PROACT II trial. Neurology. 2001;57(9):1603-1610. [pmid: 11706099].
15 Keris V, Rudnicka S, Vorona V, Enina G, Tilgale B, Fricbergs J. Combined intraarterial/intravenous thrombolysis for acute ischemic stroke. AJNR Am J Neuroradiol. 2001;22(2):352-358. [pmid: 11156782].
16 Lewandowski CA, Frankel M, Tomsick TA, Broderick J, Frey J, Clark W, et al. Combined intravenous and intra-arterial r-TPA versus intra-arterial therapy of acute ischemic stroke: Emergency Management of Stroke (EMS) Bridging Trial. Stroke. 1999;30(12):2598-2605. [pmid: 10582984].
17 Marler J, Tilley BC, Lu Y, Brott TG, Lyden PC, Grotta JC, et al. Early stroke treatment associated with better outcome: the NINDS rt-PA stroke study. Neurology. 2000;55(11):1649-1655. [pmid: 11113218].
18 Mendelow AD, Gregson BA, Fernandes HM, Murray GD, Teasdale GM, Hope DT, et al. Early surgery versus initial conservative treatment in patients with spontaneous supratentorial intracerebral haematomas in the International Surgical Trial in Intracerebral Haemorrhage (STICH): a randomised trial. Lancet. 2005;365(9457):387-397. [pmid: 15680453].
19 Morgenstern LB, Frankowski RF, Shedden P, Pasteur W, Grotta JC. Surgical treatment for intracerebral hemorrhage (STICH): a single-center, randomized clinical trial. Neurology. 1998;51(5):1359-1363. [pmid: 9818860].
20 Patel SC, Levine SR, Tilley BC, Grotta JC, Lu M, Frankel M, et al. Lack of clinical significance of early ischemic changes on computed tomography in acute stroke.[see comment]. JAMA. 2001;286(22):2830-2838. [pmid: 11735758].
21 Roberts HC, Dillon WP, Furlan AJ, Wechsler LR, Rowley HA, Fischbein NJ, et al. Computed tomographic findings in patients undergoing intra-arterial thrombolysis for acute ischemic stroke due to middle cerebral artery occlusion: results from the PROACT II trial.[see comment]. Stroke. 2002;33(6):1557-1565. [pmid: 12052991].
22 Scott JF, Robinson GM, French JM, O'Connell JE, Alberti KG, Gray CS. Glucose potassium insulin infusions in the treatment of acute stroke patients with mild to moderate hyperglycemia: the Glucose Insulin in Stroke Trial (GIST). Stroke. 1999;30(4):793-799. [pmid: 10187881].
23 Teernstra OP, Evers SM, Lodder J, Leffers P, Franke CL, Blaauw G, et al. Stereotactic treatment of intracerebral hematoma by means of a plasminogen activator: a multicenter randomized controlled trial (SICHPA). Stroke. 2003;34(4):968-974. [pmid: 12649510].
24 Zuccarello M, Brott T, Derex L, Kothari R, Sauerbeck L, Tew J, et al. Early surgical treatment for supratentorial intracerebral hemorrhage: a randomized feasibility study.[see comment]. Stroke. 1999;30(9):1833-1839. [pmid: 10471432].
25 Morgenstern LB, Bartholomew LK, Grotta JC, Staub L, King M, Chan W. Sustained benefit of a community and professional intervention to increase acute stroke therapy. Arch Intern Med. 2003;163(18):2198-2202. [pmid: 14557217].
26 Suarez JI, Zaidat OO, Sunshine JL, Tarr R, Selman WR, Landis DM. Endovascular administration after intravenous infusion of thrombolytic agents for the treatment of patients with acute ischemic strokes. Neurosurgery. 2002;50(2):251-259. [pmid: 11844259].
27 Akins PT, Delemos C, Wentworth D, Byer J, Schorer SJ, Atkinson RP. Can emergency department physicians safely and effectively initiate thrombolysis for acute ischemic stroke?. Neurology. 2000;55(12):1801-1805. [pmid: 11134376].
28 Hermier M, Nighoghossian N, Adeleine P, Berthezene Y, Derex L, Yilmaz H, et al. Early magnetic resonance imaging prediction of arterial recanalization and late infarct volume in acute carotid artery stroke. J Cereb Blood Flow Metab. 2003;23(2):240-248. [pmid: 12571455].
29 Hill MD, Barber PA, Demchuk AM, Sevick RJ, Newcommon NJ, Green T, et al. Building a “brain attack” team to administer thrombolytic therapy for acute ischemic stroke. CMAJ. 2000;162(11):1589-1593. [pmid: 10862236]. [pmcid: 1231342].
30 Jahnke HK, Zadrozny D, Garrity T, Hopkins S, Frey JL, Christopher M. Stroke teams and acute stroke pathways: one emergency department's two-year experience. J Emerg Nurs. 2003;29(2):133-139. [pmid: 12660695].
31 Kilpatrick MM, Yonas H, Goldstein S, Kassam AB, Gebel JJ, Wechsler LR, et al. CT-based assessment of acute stroke: CT, CT angiography, and xenon-enhanced CT cerebral blood flow.[see comment]. Stroke. 2001;32(11):2543-2549. [pmid: 11692014].
32 Lattimore SU, Chalela J, Davis L, DeGraba T, Ezzeddine M, Haymore J, et al. Impact of establishing a primary stroke center at a community hospital on the use of thrombolytic therapy: the NINDS Suburban Hospital Stroke Center experience. Stroke. 2003;34(6):e55-e57. [pmid: 12750543].
33 Smith RW, Scott PA, Grant RJ, Chudnofsky CR, Frederiksen SM. Emergency physician treatment of acute stroke with recombinant tissue plasminogen activator: a retrospective analysis. Acad Emerg Med. 1999;6(6):618-625. [pmid: 10386679].
34 Agarwal PK. Hyperdense middle cerebral artery sign: can it be used to select intra-arterial versus intravenous thrombolysis in acute ischemic stroke?. Cerebrovasc Dis. 2004;17(23):182-190. [pmid: 14707420].
35 Kay R, Poon WS, Nicholls MG. Effect of intravenous ketanserin on arterial and intracranial pressures in patients with systemic hypertension following intracerebral haemorrhage. J Hum Hypertens. 1993;7(4):369-371. [pmid: 8410928].
36 Nishiyama T, Yokoyama T, Matsukawa T, Hanaoka K. Continuous nicardipine infusion to control blood pressure after evacuation of acute cerebral hemorrhage. Can J Anaesth. 2000;47(12):1196-1201. [pmid: 11132741].
37 Alberts MJ, Perry A, Dawson DV, Bertels C. Effects of public and professional education on reducing the delay in presentation and referral of stroke patients. Stroke. 1992;23(3):352-356. [pmid: 1542895].
38 Barsan WG, Brott TG, Broderick JP, Haley EJ, Levy DE, Marler J. Urgent therapy for acute stroke. Effects of a stroke trial on untreated patients. Stroke. 1994;25(11):2132-2137. [pmid: 7974533].
39 Becker K, Fruin M, Gooding T, Tirschwell D, Love P, Mankowski T. Community-based education improves stroke knowledge. Cerebrovasc Dis. 2001;11(1):34-43. [pmid: 11173792].
40 Smith WS, Corry MD, Fazackerley J, Isaacs SM. Improved paramedic sensitivity in identifying stroke victims in the prehospital setting. Prehosp Emerg Care. 1999;3(3):207-210. [pmid: 10424857].
41 Weinhardt J, Parker C. Developing a patient education video as a tool to case manage patients who have had strokes. Nurs Case Manag. 1999;4(4):198-200. [pmid: 10690108].