# Appendix D. Modified QUOROM Flow Chart

## Modified QUOROM Flow Chart

*Note: some items were eligible for both reviews, therefore, the sum does not add up to the number of included studies.