# Appendix A. Search Strategies

## Search Strategy 1

Ovid Medline

1 Intracranial Thrombosis/ or Cerebral Infarction/ or Cerebral Hemorrhage/ or Cerebrovascular Accident/
2 “Intracranial Embolism and Thrombosis”/
3 Intracranial Embolism/
4 Brain Ischemia/
5 ischemic stroke$.tw.
6 cva.mp.
7 or/1–6
8 Intracranial Thrombosis/ or Cerebral Infarction/ or Cerebral Hemorrhage/ or Cerebrovascular Accident/ or “Intracranial Embolism and Thrombosis”/ or Intracranial Embolism/ or Stroke/ or Brain Ischemia/
9 (stroke or cva).mp.
10 or/8–9
11 Intracranial Thrombosis/ or Cerebral Infarction/ or Cerebral Hemorrhage/ or Cerebrovascular Accident/ or “Intracranial Embolism and Thrombosis”/ or Intracranial Embolism/
12 stroke/
13 exp Intracranial Hemorrhages/
14 (cerebrovascular$ or cerebral vascular or stroke).tw.
15 (haemorrhag$ or hemorrhag$ or haematom$ or hematom$).mp.
16 (ich or cva).mp.
17 (primary intracerebral hemorrhage or pich).mp.
18 (haemorrhag$ or hemorrhag$ or haematom$ or hematom$).mp.
19 exp brain/
20 (cerebr$ or intracerebral or intracran$ or parenchymal or brain).tw.
21 18 and (19 or 20)
22 or/11–17,21
23 *subarachnoid hemorrhage/ or *subarachnoid hemorrhage, traumatic/
24 *Tissue Plasminogen Activator/
25 22 not (23 or 24)
26 exp surgery/
27 surgery.hw. or surgery.kw.
28 surg$.mp.
29 endoscop$.mp.
30 craniotom$.mp.
31 stereotactic.mp.
32 ventricular drain$.mp.
33 intraoperative ultras$.mp.
34 neuroprotective.mp.
35 or/26–34
36 25 and 35
37 *Cardiac Surgical Procedures/
38 *Coronary Artery Bypass/
39 *Coronary Disease/
40 *Aortic Valve Stenosis/
41 *Endarterectomy, Carotid/
42 or/37–41
43 42 not (11 or 12 or 13)
44 36 not 43
45 Antihypertensive Agents/ or Hypertension/ or Angiotensin-Converting Enzyme Inhibitors/
46 antihypertensive treatment.mp.
47 antihypertensive$.tw.
48 (angiotensin-converting enzyme or ace).tw.
49 Labetalol/
50 36894-69-6.rn.
51 (Chlortalidone or Hydrochlorotiazide).tw.
52 (Atenolol or Propranolol or metoprolol or carvedilol or labetalol or pindolol or bisoprolol).tw.
53 (Enalapril or lisinopril or captopril or ramipril or benazepril).tw.
54 (losartan or candesartan or valsartan).tw.
55 (nifedipine or nicardipine or amlodipine or isradipine or varapamil or felodipine or diltiazem).tw.
56 (nitroprusside or clonidine or terazosin$ or doxazosin$).tw.
57 or/45–56
58 *subarachnoid hemorrhage/ or *subarachnoid hemorrhage, traumatic/
59 *Tissue Plasminogen Activator/
60 57 not (58 or 59)
61 60 and 25
62 injections, intra-arterial/
63 intraarterial.tw.
64 intra arterial.tw.
65 or/62–64
66 thromboly$.tw.
67 thrombolytic therapy/
68 (iat or ia).tw.
69 exp Tissue Plasminogen Activator/
70 tPA.mp.
71 Activase.tw.
72 alteplase.tw.
73 clot dissolv$.tw.
74 reperfusion therapy.tw.
75 reteplase.tw.
76 tenecteplase.tw.
77 tissue plasminogen activator.tw.
78 tPA.tw.
79 EC-3-4-21-68.rn.
80 or/66–79
81 65 and 80
82 blood glucose.mp.
83 Blood Glucose/
84 serum glucose.mp.
85 blood sugar.tw.
86 ((blood or serum) adj2 (sugar or glucose)).mp.
87 Hyperglycemia/
88 Hypoglycemia/
89 or/82–88
90 ((mechanical or ultrason$) adj (clot$ or disrupt$)).mp.
91 ultrasonic therapy/
92 Angioplasty/ or Angioplasty, Balloon/
93 endovascular intervention$.tw.
94 snare manipulation.tw.
95 guidewire.tw.
96 mechanical thromboly$.tw.
97 mechanical recanalization.mp.
98 (percutaneous transluminal angioplast$ or pta).tw.
99 cerebral angiograph$/
100 or/90–99
101 exp Tissue Plasminogen Activator/
102 tPA.mp.
103 Activase.tw.
104 alteplase.tw.
105 clot dissolv$.tw.
106 reperfusion therapy.tw.
107 reteplase.tw.
108 tenecteplase.tw.
109 tissue plasminogen activator.tw.
110 tPA.tw.
111 EC-3-4-21-68.rn.
112 or/101–111
113 exp Tissue Plasminogen Activator/
114 tPA.mp.
115 Activase.tw.
116 alteplase.tw.
117 clot dissolv$.tw.
118 reperfusion therapy.tw.
119 reteplase.tw.
120 tenecteplase.tw.
121 tissue plasminogen activator.tw.
122 tPA.tw.
123 EC-3-4-21-68.rn.
124 or/113–123
125 mri.mp.
126 mr imag$.mp.
127 magnetic resonance imag$.mp.
128 magnetic resonance imaging/
129 124 and (or/125–128)
130 health promotion/
131 health education/
132 Health Knowledge, Attitudes, Practice/
133 health behavior/
134 Attitude to Health/
135 delivery of health care/
136 program evaluation/
137 Marketing of Health Services/
138 Information Services/
139 advertising/
140 patient education/
141 community health planning/
142 area health education centers/
143 outreach.tw.
144 communications media/
145 health promotion.tw.
146 (community adj8 intervention).tw.
147 (advocacy adj5 program).tw.
148 ((public or communty) adj2 (aware$ or promot$ or educat$)).mp.
149 or/130–148
150 Patient Care Team/
151 (psc or primary stroke cent$).tw.
152 (stroke adj3 (service$ or center$ or centre$ or team$)).tw.
153 stroke centre.mp.
154 Intensive Care Units/
155 Hospital Units/
156 or/150–155
157 emergency medical services/
158 Emergency Medicine/
159 (ems or emergency medical services).tw.
160 Emergency Service, Hospital/
161 emergency care/
162 (emergency room or er).tw.
163 emergency treatment/
164 (“911” or “999”).tw.
165 Paramedic$.mp.
166 or/157–165
167 clinical protocols/
168 program evaluation/
169 exp patient care planning/
170 (protocol$ or care plan$).mp.
171 ((critical or clinical) adj2 path$).mp.
172 treatment plan$.mp.
173 or/167–172
174 166 and 173
175 RANDOMIZED CONTROLLED TRIAL.pt.
176 CONTROLLED CLINICAL TRIAL.pt.
177 RANDOMIZED CONTROLLED TRIALS.sh.
178 RANDOM ALLOCATION.sh.
179 DOUBLE BLIND METHOD.sh.
180 SINGLE-BLIND METHOD.sh.
181 or/175–180
182 (ANIMALS not HUMAN).sh.
183 181 not 182
184 CLINICAL TRIAL.pt.
185 exp CLINICAL TRIALS/
186 (clin$ adj25 trial$).ti,ab.
187 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
188 PLACEBOS.sh.
189 placebo$.ti,ab.
190 random$.ti,ab.
191 versus.tw.
192 RESEARCH DESIGN.sh.
193 or/184–192
194 193 not 182
195 194 not 183
196 183 or 195
197 44 and 196
198 61 and 196
199 81 and 7 and 196
200 89 and 10 and 196
201 100 and 7 and 196
202 112 and 7 and 196
203 129 and 7
204 149 and 10
205 156 and 10 and 196
206 174 and 10
207 or/197,199–203
208 limit 207 to all adult <19 plus years>
209 or/198,204–206
210 or/208–209