# Appendixes

Appendix A. Search Strategies

Appendix B. Correspondence to Targeted Trial Investigators

Appendix C. Data Assessment and Data Abstraction Forms

Appendix D. Modified QUOROM Flow Chart

Appendix E. Evidence Tables

Appendix F. Additional Acknowledgments