# Abbreviations

Abbreviation | Description
Quality Score: A | Good quality study, least susceptible to bias. See Chapter 2, Methods.
Quality Score: B | Fair quality study, more susceptible to bias. See Chapter 2, Methods.
Quality Score: C | Poor quality study, most susceptible to bias. See Chapter 2, Methods.
| Broadly applicable study (referable to population category)
| Moderately applicable study (referable to population category)
| Narrowly applicable study (referable to population category)
♀ | Women (all)
♂ | Men
5-OHmdU | 5-Hydroxymethyl-2'-deoxyuridine
apo(a) | Apolipoprotein(a)
apoB-100 | Apolipoprotein B-100
AHRQ | Agency for Healthcare Research and Quality
ASVD | Atherosclerotic vascular disease
bAP | Bone-specific alkaline phosphatase (serum)
BMC | Bone mineral content
BMD | Bone mineral density
BP | Blood pressure
Breast CA | History of breast cancer
CAB | Commonwealth Agricultural Bureau (database)
CI | Confidence Interval
CKD | Chronic kidney disease
CRP | C-reactive protein
CTx | C-telopeptide
CVD | Cardiovascular disease
d | Days
DC | Digit cancellation
DHEA | Dehydroepiandrosterone
DHEAS | Dehydroepiandrosterone sulfate
DHT | Dihydrotestosterone
DM | Diabetes mellitus
D-pyr | Deoxypyridinoline (urinary)
E2 | Estradiol
EPC | Evidence-based Practice Center
FDA | Food and Drug Administration
FSH | Follicle stimulating hormone
FTI | Free thyroxine index
GI | Gastrointestinal
HDL | High density lipoprotein
HP | Hydroxyproline (urinary)
hs-CRP | High sensitivity CRP
HTN | Hypertension
IGF | Insulin-like growth factor
IGFBP-3 | Insulin-like growth factor binding protein-3
Iso | Isoflavones
ISP | Isolated soy protein
LDL | Low density lipoprotein
LH | Luteinizing hormone
Lp(a) | Lipoprotein (a)
mo | Month(s)
N | Number of subjects
NCCAM | National Center for Complementary and Alternative Medicine
NCI | National Cancer Institute
nd | No data
NF-κB | Nuclear factor-κB
NIH | National Institutes of Health
NRCT | Non-randomized controlled trial
NS | Non-significant
NTx | Collagen type I cross linked N-telopeptide (urinary)
OC | Osteocalcin (serum)
P within | P value of within-cohort change
P btw Soy | P value of difference in effect between soy treatments
P vs Control | P value of effect compared to control (net change)
PDGF | Platelet-derived growth factor
peri♀ | Peri-menopausal women
post♀ | Post-menopausal women
pre♀ | Pre-menopausal women
PSA | Prostate specific antigen
PTH | Parathyroid hormone
PTI | Protein Technology Institute, Inc
Pyr | Pyridinoline (urinary)
RCT | Randomized controlled trial (parallel design)
SE | Standard error
SHBG | Sex hormone-binding globulin
t | Text only, no data reported
T max | Time of maximal concentration
T.Isoflav | Total isoflavones
T3 | Triiodothyronine
T4 | Thyroxine
TBARs | Thiobarbituric acid reactive substances
TBG | Thyroid binding globulin
TEP | Technical expert panel
Tg | Triglycerides
TSH | Thyroid stimulating hormone
Tufts-NEMC | Tufts-New England Medical Center
UI | Unique Identifier (from MEDLINE, Used when multiple studies have the same first author and year)
w/ | With
w/o | Without
WHO | World Health Organization
wk | Weeks
Xover | Cross-over studies (randomized)
yr | Year(s)