# List of Excluded Studies

Abel RM, Fisch D, Grossman ML. Hemodynamic effects of intravenous 20% soy oil emulsion following coronary bypass surgery. J Parenter Enter Nutr. 1983;7(6):534-40. Soy oil intervention.
Acharya S, Maskarinec G, Williams AE, et al. Nutritional changes among premenopausal women undertaking a soya based dietary intervention study in Hawaii. J Hum Nutr Diet. Oct. 2004;17(5):413-9. No outcomes of interest. [pmid: 15357694].
Ahn YO. Diet and stomach cancer in Korea. Int J Cancer 1997;Suppl(10):7–9. Review of case-control.
Akaza H, Miyanaga N, Takashima N, et al. Comparisons of percent equol producers between prostate cancer patients and controls: case-controlled studies of isoflavones in Japanese, Korean and American residents. Jpn J Clin Oncol. Feb. 2004;34(2):86-0. Case-control study. [pmid: 15067102].
Almendingen K, Jordal O, Kierulf P, et al. Effects of partially hydrogenated fish oil, partially hydrogenated soybean oil, and butter on serum lipoproteins and Lp[a] in men. J Lipid Res. Jun. 1995;36(6):1370-84. Soy oil intervention. [pmid: 7666013].
Almendingen K, Seljeflot I, Sandstad B, et al. Effects of partially hydrogenated fish oil, partially hydrogenated soybean oil, and butter on hemostatic variables in men. Arterioscler Thromb Vasc Biol. Mar. 1996;16(3):375-80. Soy oil intervention. [pmid: 8630662].
Amato P, Marcus DM. Review of alternative therapies for treatment of menopausal symptoms. Climacteric. 2003;6(4):278-84. Abstract. [pmid: 15006249].
Anderson JW, Johnstone BM, CookNewell ME. Meta-analysis of the effects of soy protein intake on serum lipids. N Engl J Med. Aug 3. 1995;333(5):276-82. Meta-analysis. [pmid: 7596371].
Anderson JW, Major AW. Pulses and lipaemia, short- and long-term effect: potential in the prevention of cardiovascular disease. Br J Nutr. Dec. 2002;88(Suppl 3):S263-S271. Review. [pmid: 12498626].
Andrioli G, Carletto A, Guarini P, et al. Differential effects of dietary supplementation with fish oil or soy lecithin on human platelet adhesion. Thromb Haemost. Nov. 1999;82(5):1522-7. No soy intervention. [pmid: 10595648].
Anonymous. Cardiovascular benefits of soy. Consultant. 2001;41(6):797. Review.
Anonymous. Controlled trial of soya-bean oil in myocardial infarction. Lancet. Sep 28. 1968;2(7570):693-9. Soy oil intervention. [pmid: 4175085].
Appelboom T, Schuermans J, Verbruggen G, et al. Symptoms modifying effect of avocado/soybean unsaponifiables (ASU) in knee osteoarthritis. A double blind, prospective, placebo-controlled study. Scand J Rheumatol. 2001;30(4):242-7. No soy intervention. [pmid: 11578021].
Arai Y, Watanabe S, Kimira M, et al. Dietary intakes of flavonols, flavones and isoflavones by Japanese women and the inverse correlation between quercetin intake and plasma LDL cholesterol concentration. J Nutr. 2000;130(9):2243-50. Cross-sectional study. [pmid: 10958819].
Arjmandi BH, Khan DA, Juma SS, et al. The ovarian hormone deficiency-induced hypercholesterolemia is reversed by soy protein and the synthetic isoflavone, ipriflavone. Nutr Res. 1997;17(5):885-94. Animal study.
Asato L, Wang MF, Chan YC, et al. Effect of egg white on serum cholesterol concentration in young women. J Nutr Sci Vitaminol. 1996;42(2):87-96. N < 10 for lipid outcomes. [pmid: 8780967].
Baber RJ, Templeman C, Morton T, et al. Randomized placebo-controlled trial of an isoflavone supplement and menopausal symptoms in women. Climacteric. Jun. 1999;2(2):85-92. No soy intervention. [pmid: 11910672].
Baumer JH, Drakeford JA, Wadsworth J, et al. Effects of dietary fibre and exercise on mid-morning diabetic control--a controlled trial. Arch Dis Child. Dec. 1982;57(12):905-9. Children < 13 years. [pmid: 6295286]. [pmcid: 1628056].
Bazzano LA, He J, Ogden LG, et al. Legume consumption and risk of coronary heart disease in US men and women: NHANES I Epidemiologic Follow-up Study. Archives of Internal Medicine. Nov 26. 2001;161(21):2573-8. No soy intervention. [pmid: 11718588].
Beer WH, Murray E, Oh SH, et al. A long-term metabolic study to assess the nutritional value of and immunological tolerance to two soy-protein concentrates in adult humans. Am J Clin Nutr. Nov. 1989;50(5):997-1007. No outcomes of interest. [pmid: 2554716].
Berrino F, Bellati C, Ooldani S, et al. DIANA trials on diet and endogenous hormones. In: Riboli E and Lambert R, editors. Nutrition and lifestyle: opportunities for cancer prevention. France on 21–24 June, 2003. International Agency for Research on Cancer (IARC), Lyon, France: European Conference on Nutr Cancer held in Lyon; 2002. p. 439–44. Soy combined with other intervention.
Berrino F, Bellati C, Secreto G, et al. Reducing bioavailable sex hormones through a comprehensive change in diet: the diet and androgens (DIANA) randomized trial. Cancer Epidemiol Biomarkers Prev. Jan. 2001;10(1):25-33. Large change in diet. [pmid: 11205485].
Bilo HJG, Schaap GH, Blaak E, et al. Effects of chronic and acute protein administration on renal function in patients with chronic renal insufficiency. Nephron. 1989;533(3):181-7. No soy intervention. [pmid: 2797339].
Bingham M, Gibson G, Gottstein N, et al. Gut metabolism and cardioprotective effects of dietary isoflavones. Curr Top Nutrac Res. 2003;1(1):31-48. Review.
Bodwell CE, Miles CW, Morris E, et al. Long-term consumption of beef extended with soy protein by men, women and children: II. Effects on iron status. Plant Foods Hum Nutr. 1987;37(4):361-76. Soy combined with other intervention. [pmid: 3507007].
Bosello O, Cominacini L, Zocca I, et al. Short- and long-term effects of hypocaloric diets containing proteins of different sources on plasma lipids and apoproteins of obese subjects. Ann Nutr Metab. 1988;32(4):206-14. Soy intervention less than 4 weeks. [pmid: 3143302].
Bosland MC, Kato I, Melamed J, et al. Chemoprevention trials in men with prostate-specific antigen failure or at high risk for recurrence after radical prostatectomy: Application to efficacy assessment of soy protein. Urology. Apr. 2001;57(4:Suppl 1):202-4. Review. [pmid: 11295628].
Bricarello LP, Kasinski N, Bertolami MC, et al. Comparison between the effects of soy milk and non-fat cow milk on lipid profile and lipid peroxidation in patients with primary hypercholesterolemia. Nutrition. 2004;20(2):200-4. Duplicate publication. [pmid: 14962687].
Brook JG, Linn S, Aviram M. Dietary soya lecithin decreases plasma triglyceride levels and inhibits collagen- and ADP-induced platelet aggregation. Biochem Med Metab Biol. 1986;35(1):31-9. Soy lecithin – intervention not of interest. [pmid: 3778675].
Brussaard JH, van Raaij JM, StasseWolthuis M, et al. Blood pressure and diet in normotensive volunteers: absence of an effect of dietary fiber, protein, or fat. Am J Clin Nutr. Oct. 1981;34(10):2023-9. Soy not quantified. [pmid: 6270996].
Brzezinski, A., Adlercreutz, H., Shaoul, R., Rosler, A., Shmueli, A., Tanos, V., and Schenker, J. G. Short-term effects of phytoestrogen-rich diet on postmenopausal women. Menopause 4(2), 89–94. 1997. Soy combined with other intervention.
Bukar J, Mezitis NH, Saitas V, et al. Frozen desserts and glycemic response in well-controlled NIDDM patients. Diabetes Care. Apr. 1990;13(4):382-5. No quantification of soy. [pmid: 2180658].
Buzio C, Mutti A, Perazzoli F, et al. Protein-induced changes in kidney function depend on the time of administration but not on the dietary source. Nephron 199+;56(3):234–40. Soy intervention less than 4 weeks.
Calvert GD, Blight L, Illman RJ, et al. A trial of the effects of soya-bean flour and soya-bean saponins on plasma lipids, faecal bile acids and neutral sterols in hypercholesterolaemic men. Br J Nutr. Mar. 1981;45(2):277-81. Soybean flour. [pmid: 7011362].
Capristo E, Mingrone G, Addolorato G, et al. Effect of a vegetable-protein-rich polymeric diet treatment on body composition and energy metabolism in inactive Crohn's disease. Eur J Gastroenterol Hepatol. Jan. 2000;12(1):5-11. No outcomes of interest. [pmid: 10656203].
Caron MF, White CM. Evaluation of the antihyperlipidemic properties of dietary supplements. [Review] [44 refs]. Pharmacotherapy. Apr. 2001;21(4):481-7. Review. [pmid: 11310521].
Caso G, Scalfi L, Marra M, et al. Albumin synthesis is diminished in men consuming a predominantly vegetarian diet. J Nutr. Mar. 2000;130(3):528-33. No outcomes of interest. [pmid: 10702580].
Chen C, Wang X, Chen D, et al. Tofu consumption and blood lead levels in young Chinese adults. Am J Epidemiol. Jun 15. 2001;153(12):1206-12. No outcomes of interest. [pmid: 11415956].
Chen HL, Huang YC. Fiber intake and food selection of the elderly in Taiwan. Nutrition. Apr 1. 2003;19(4):332-6. No outcomes of interest. [pmid: 12679167].
Chester EA. Soy for cardiovascular indications. Am J Health-Syst Pharm. Jan 15. 2001;58(8):663-6. Not primary study. [pmid: 11329758].
Childs MT, Bowlin JA, Ogilvie JT, et al. The contrasting effects of a dietary soya lecithin product and corn oil on lipoprotein lipids in normolipidemic and familial hypercholesterolemic subjects. Atherosclerosis. Jan. 1981;38(12):217-28. Soy lecithin – intervention not of interest. [pmid: 7193460].
Chu FL, Kies C, Clemens ET. Studies of human diets with pork, beef, fish, soybean, and poultry: Nitrogen and fat utilization, and blood serum chemistry. J Appl Nutr. 1995;47(3):51-66. Soy intervention less than 4 weeks.
Chyou PH, Nomura AM, Stemmermann GN. Diet, alcohol, smoking and cancer of the upper aerodigestive tract: a prospective study among Hawaii Japanese men. Int J Cancer. Mar 3. 1995;60(5):616-21. Cancer patients, observational study. [pmid: 7860134].
Cicero AF, Fiorito A, Panourgia MP, et al. Effects of a new soy/beta-sitosterol supplement on plasma lipids in moderately hypercholesterolemic subjects. J Am Diet Assoc. Dec. 2002;102(12):1807-11. Soy not quantified. [pmid: 12487546].
Cook A, Pennington G. Phytoestrogen and multiple vitamin/mineral effects on bone mineral density in early postmenopausal women: a pilot study. J Womens Health Gend Based Med. Jan. 2002;11(1):53-60. No soy intervention. [pmid: 11860725].
Cotter A, Cashman KD. Genistein appears to prevent early postmenopausal bone loss as effectively as hormone replacement therapy. [Review] [22 refs]. Nutr Rev. Oct. 2003;61(10):346-51. Review. [pmid: 14604267].
Cupisti A, D'Alessandro C, Ghiadoni L, et al. Effect of a soy protein diet on serum lipids of renal transplant patients. J Ren Nutr. Jan. 2004;14(1):31-5. Case-control study. [pmid: 14740328].
Dai Q, Shu XO, Jin F, et al. Population-based case-control study of soyfood intake and breast cancer risk in Shanghai. Br J Cancer. Aug 3. 2001;85(3):372-8. Cancer patients, observational study. [pmid: 11487268].
Dalais FS, Meliala A, Wattanapenpaiboon N, et al. Effects of a diet rich in phytoestrogens on prostate-specific antigen and sex hormones in men diagnosed with prostate cancer. Urology. Sep. 2004;64(3):510-5. Cancer patients. [pmid: 15351581].
D'Amico G, Gentile MG. Effect of dietary manipulation on the lipid abnormalities and urinary protein loss in nephrotic patients. Miner Electrolyte Metab. 1992;18(25):203-6. Review of 2 studies. [pmid: 1465059].
Davis JN, Kucuk O, Djuric Z, et al. Soy isoflavone supplementation in healthy men prevents NF-kappaB activation by TNF-a in blood lymphocytes. Free Radic Biol Med. Jun 1. 2001;30(11):1293-302. Soy intervention less than 4 weeks. [pmid: 11368927].
De Kleijn MJ, van der Schouw YT, Wilson PW, et al. Dietary intake of phytoestrogens is associated with a favorable metabolic cardiovascular risk profile in postmenopausal U.S.women: the Framingham study. J Nutr. Feb. 2002;132(2):276-82. Cross-sectional study. [pmid: 11823590].
Deibert P, Konig D, SchmidtTrucksaess A, et al. Weight loss without losing muscle mass in pre-obese and obese subjects induced by a high-soy-protein diet. Int J Obes Relat Metab Disord. Oct. 2004;28(10):1349-52. Soy not quantified. [pmid: 15303108].
Del Carmen CM, Olveira G, Ruiz De Adana MS, et al. Metabolic effects of an enteral nutrition formula for diabetes: Comparison with standard formulas in patients with type 1 diabetes. Clin Nutr. 2003;22(5):483-7. Soy not quantified. [pmid: 14512036].
Descovich GC, Ceredi C, Gaddi A. Multicentre study of soybean protein diet for outpatient hypercholesterolaemic patients. Lancet. 1980;2(8197):709-12. CVD study with no control. [pmid: 6106825].
Desroches S, Mauger JF, Ausman LM, et al. Soy protein favorably affects LDL size independently of isoflavones in hypercholesterolemic men and women. J Nutr. 2004;134(3):574-9. Subset of Lichenstein #12426215, no new relevant data. [pmid: 14988449].
DeVere White RW, Hackman RM, Soares SE, et al. Effects of a genistein-rich extract on PSA levels in men with a history of prostate cancer. Urology. Feb. 2004;63(2):259-63. Cancer patients. [pmid: 14972467].
Dragan I, Stroescu V, Stoian I, et al. Studies regarding the efficiency of Supro isolated soy protein in Olympic athletes. Rev Roum Physiol. Jul. 1992;29(34):63-70. Data uninterpretable. [pmid: 1306084].
Duane WC. Effects of soybean protein and very low dietary cholesterol on serum lipids, biliary lipids, and fecal sterols in humans. Metabolism. Apr. 1999;48(4):489-94. N < 10 for lipid outcomes. [pmid: 10206443].
Duncan AM, MerzDemlow BE, Xu X, et al. Premenopausal equol excretors show plasma hormone profiles associated with lowered risk of breast cancer. Cancer Epidemiol Biomarkers Prev. 2000;9(6):581-6. Soy not quantified. [pmid: 10868692].
Dunn AV. Incorporating soy protein into a low-fat, low-cholesterol diet. [Review] [9 refs]. Cleve Clin J Med. Oct. 2000;67(10):767-72. Review. [pmid: 11060963].
Exner M, Hermann M, Hofbauer R, et al. Genistein prevents the glucose autoxidation mediated atherogenic modification of low density lipoprotein. Free Radic Res. 2001;34(1):101-12. In vitro study. [pmid: 11234992].
Fanti P, Sawaya BP, Custer LJ, et al. Serum levels and metabolic clearance of the isoflavones genistein and daidzein in hemodialysis patients. J Am Soc Nephrol. Apr. 1999;10(4):864-71. No outcomes of interest. [pmid: 10203372].
Fanti P, Stephenson TJ, Kaariainen IM, et al. Serum isoflavones and soya food intake in Japanese, Thai and American end-stage renal disease patients on chronic haemodialysis. Nephrol Dial Transplant. Sep. 2003;18(9):1862-8. No outcomes of interest. [pmid: 12937236].
Faughnan MS, Hawdon A, AhSingh E, et al. Urinary isoflavone kinetics: the effect of age, gender, food matrix and chemical composition. Br J Nutr. Apr. 2004;91(4):567-74. No outcomes of interest. [pmid: 15035683].
Fisler JS, Drenick EJ, Yoshimura NN, et al. Plasma concentration of amino acids in obese men consuming very-low-calorie diets composed of soy or collagen protein. Int J Obes. 1985;9(5):335-46. N < 5. [pmid: 4077377].
Fisler JS, Drenick EJ. Calcium, magnesium, and phosphate balances during very low calorie diets of soy or collagen protein in obese men: comparison to total fasting. Am J Clin Nutr. Jul. 1984;40(1):14-25. Not relevant study. [pmid: 6540047].
Fritz KL, Seppanen CM, Kurzer MS, et al. The in vivo antioxidant activity of soybean isoflavones in human subjects. Nutr Res. Apr 1. 2003;23(44):479-87. No outcomes of interest.
Fujita H, Yamagami T, Ohshima K. Fermented soybean-derived water-soluble touchi extract inhibits a-glucosidase and is antiglycemic in rats and humans after single oral treatments. J Nutr. 2001;131(4):1211-3. No soy intervention. [pmid: 11285328].
Fujita H, Yamagami T, Ohshima K. Long-term ingestion of a fermented soybean-derived Touchi-extract with alpha-glucosidase inhibitory activity is safe and effective in humans with borderline and mild type-2 diabetes. J Nutr. Aug. 2001;131(8):2105-8. No soy intervention. [pmid: 11481402].
Fujita T, Fukase M. Comparison of osteoporosis and calcium intake between Japan and the United States. Proc Soc Exp Biol Med. Jun. 1992;200(2):149-52. Not study of interest – background material. [pmid: 1579574].
Fumagalli R, Soleri L, Farina R. Fecal cholesterol excretion studies in type II hypercholesterolemic patients treated with the soybean protein diet. Atherosclerosis. 1982;43(23):341-53. No outcomes of interest. [pmid: 6889431].
Fung WP. Effect of soya bean milk on the healing of gastric ulcers -- a controlled endoscopic study. Med J Aust. Jun 7. 1975;1(23):717-8. Soy intervention less than 4 weeks. [pmid: 1097866].
Gaddi A, Sangiorgi Z, Ciarrocchi A, et al. Hypocholesterolemic soy protein diet and resistance to warfarin therapy. Curr Ther Res Clin Exp. 1989;45(6):1006-10. Cohort for lipid outcomes.
Galanis DJ, Kolonel LN, Lee J, et al. Intakes of selected foods and beverages and the incidence of gastric cancer among the Japanese residents of Hawaii: a prospective study. Int J Epidemiol. Apr. 1998;27(2):173-80. Cancer patients, observational study. [pmid: 9602395].
Gambacciani M, Ciaponi M, Cappagli B, et al. Effects of combined low dose of the isoflavone derivative ipriflavone and estrogen replacement on bone mineral density and metabolism in postmenopausal women. Maturitas. Sep. 1997;28(1):75-81. Ipriflavone. [pmid: 9391998].
GarciaMartinez MC, Hermenegildo C, Tarin JJ, et al. Phytoestrogens increase the capacity of serum to stimulate prostacyclin release in human endothelial cells. Acta Obstet Gynecol Scand. Aug. 2003;82(8):705-10. In vitro, cohort study. [pmid: 12848640].
Garrel DR, Verdy M, PetitClerc C, et al. Milk- and soy-protein ingestion: Acute effect on serum uric acid concentration. Am J Clin Nutr. 1991;53(3):665-9. Soy intervention less than 4 weeks. [pmid: 2000819].
Goodman MT, Wilkens LR, Hankin JH, et al. Association of soy and fiber consumption with the risk of endometrial cancer. Am J Epidemiol. Aug 15. 1997;146(4):294-306. Cancer patients, observational study. [pmid: 9270408].
GoodmanGruen D, KritzSilverstein D. Usual dietary isoflavone intake is associated with cardiovascular disease risk factors in postmenopausal women. J Nutr. Apr. 2001;131(4):1202-6. Cross-sectional study. [pmid: 11285326].
Grace PB, Taylor JI, Low YL, et al. Phytoestrogen concentrations in serum and spot urine as biomarkers for dietary phytoestrogen intake and their relation to breast cancer risk in European prospective investigation of cancer and nutrition-norfolk. Cancer Epidemiol Biomarkers Prev. May. 2004;13(5):689-708. Observational study.
Greendale GA, FitzGerald G, Huang MH, et al. Dietary soy isoflavones and bone mineral density: results from the study of women's health across the nation. Am J Epidemiol. Apr 15. 2002;155(8):746-54. Observational study. [pmid: 11943693].
Grundy SM, Abrams JJ. Comparison of actions of soy protein and casein on metabolism of plasma lipoproteins and cholesterol in humans. Am J Clin Nutr. Aug. 1983;38(2):245-52. Not RCT, lipids only. [pmid: 6683926].
Guthrie JR, Ball M, Murkies A, et al. Dietary phytoestrogen intake in mid-life Australian-born women: relationship to health variables. Climacteric. Dec. 2000;3(4):254-61. No outcomes of interest. [pmid: 11910585].
Habito RC, Ball MJ. Postprandial changes in sex hormones after meals of different composition. Metabolism. May. 2001;50(5):505-11. Soy intervention less than 4 weeks. [pmid: 11319710].
Hale G, PaulLabrador M, Dwyer JH, et al. Isoflavone supplementation and endothelial function in menopausal women. Clin Endocrinol. Jun. 2002;56(6):693-701. Soy intervention less than 4 weeks.
Harris PF, Remington PL, TrenthamDietz A, et al. Prevalence and treatment of menopausal symptoms among breast cancer survivors. J Pain Symptom Manage. Jun. 2002;23(6):501-9. No outcomes of interest. [pmid: 12067774].
Haselkorn T, Stewart SL, HornRoss PL. Why are thyroid cancer rates so high in southeast asian women living in the United States? The bay area thyroid cancer study. Cancer Epidemiol Biomarkers Prev. Feb. 2003;12(2):144-50. Cancer patients, observational study. [pmid: 12582024].
Hirayama T. Relationship of soybean paste soup intake to gastric cancer risk. Nutr Cancer. 1982;3(4):223-33. Cancer patients, observational study. [pmid: 6890671].
Ho SC, Chan SG, Yi Q, et al. Soy intake and the maintenance of peak bone mass in Hong Kong Chinese women. J Bone Miner Res. Jul. 2001;16(7):1363-9. Observational study. [pmid: 11450713].
Ho SC, Woo J, Lam S, et al. Soy protein consumption and bone mass in early postmenopausal Chinese women. Osteoporos Int. 2003;14(10):835-42. Observational study. [pmid: 12920508].
Ho SC, Woo JL, Leung SS, et al. Intake of soy products is associated with better plasma lipid profiles in the Hong Kong Chinese population. J Nutr. Oct. 2000;130(10):2590-3. Cross-sectional study. [pmid: 11015494].
Hodgson JM, Puddey IB, Beilin LJ, et al. Effects of isoflavonoids on blood pressure in subjects with high-normal ambulatory blood pressure levels: a randomized controlled trial. Am J Hypertens. Jan. 1999;12(1:Pt 1):47-53. No soy intervention. [pmid: 10075384].
Hodgson JM, Puddey IB, Beilin LJ, et al. Supplementation with isoflavonoid phytoestrogens does not alter serum lipid concentrations: a randomized controlled trial in humans. J Nutr. Apr. 1998;128(4):728-32. No soy intervention. [pmid: 9521635].
Horiuchi T, Onouchi T, Takahashi M, et al. Effect of soy protein on bone metabolism in postmenopausal Japanese women. Osteoporos Int. 2000;11(8):721-4. Observational study. [pmid: 11095177].
Horn Lv, Liu K, Gerber J, et al. Oats and soy in lipid-lowering diets for women with hypercholesterolemia: is there synergy. J Am Diet Assoc. 2001;101(11):1319-25. Duplicate publication. [pmid: 11716313].
HornRoss PL, Hoggatt KJ, Lee MM. Phytoestrogens and thyroid cancer risk: the San Francisco Bay Area thyroid cancer study. Cancer Epidemiol Biomarkers Prev. Jan. 2002;11(1):43-9. Cancer patients, observational study. [pmid: 11815400].
HornRoss PL, John EM, Canchola AJ, et al. Phytoestrogen intake and endometrial cancer risk. J Natl Cancer Inst. Aug 6. 2003;95(15):1158-64. Cancer patients, observational study. [pmid: 12902445].
HornRoss PL, John EM, Lee M, et al. Phytoestrogen consumption and breast cancer risk in a multiethnic population: the Bay Area Breast Cancer Study. Am J Epidemiol. Sep 1. 2001;154(5):434-41. Cancer patients, observational study. [pmid: 11532785].
HornRoss PL, Lee M, John EM, et al. Sources of phytoestrogen exposure among non-Asian women in California, USA. Cancer Causes Control. Apr. 2000;11(4):299-302. Cancer patients, observational study. [pmid: 10843441].
Hsu CS, Shen WW, Hsueh YM, et al. Soy isoflavone supplementation in postmenopausal women: Effects on plasma lipids, antioxidant enzyme activities and bone density. J Reprod Med Obstet Gynecol. 2001;46(3):221-6. CVD study with no control.
Hu JF, Zhang SF, Jia EM, et al. Diet and cancer of the stomach: a case-control study in China. Int J Cancer. Mar 15. 1988;41(3):331-5. Cancer patients, observational study. [pmid: 3346096].
Huang XE, Tajima K, Hamajima N, et al. Effects of dietary, drinking, and smoking habits on the prognosis of gastric cancer. Nutr Cancer. 2000;38(1):30-6. Cancer patients, observational study. [pmid: 11341041].
Huntley AL, Ernst E. Soy for the treatment of perimenopausal symptoms--a systematic review. [Review] [35 refs]. Maturitas. Jan 20. 2004;47(1):1-9. Review. [pmid: 14706760].
Hussain, M, Banerjee, M., Sarkar, F. H., Djuric, Z., Pollak, M. N., Doerge, D., Fontana, J., Chinni, S., Davis, J., Forman, J., Wood, D. P., and Kucuk, O. Soy isoflavones in the treatment of prostate cancer. Nutr Cancer 47, 111–117. 2003. Not population of interest – cancer patients.
Iida T, Ishizaki F, Koyama T, et al. The effect of middle and old age women's lifestyle on bone mineral density (BMD). Ther Res. 2003;24(2):289-300. Cross-sectional study.
Ingram D, Sanders K, Kolybaba M, et al. Case-control study of phyto-oestrogens and breast cancer. Lancet. Oct 4. 1997;350(9083):990-4. Study of urine isoflavone without quantification of soy. [pmid: 9329514].
Ingram DM, Hickling C, West L, et al. A double-blind randomized controlled trial of isoflavones in the treatment of cyclical mastalgia. Breast. 2002;11(2):170-4. No soy intervention. [pmid: 14965665].
IshikawaTakata K, Ohta T. Relationship of lifestyle factors to bone mass in Japanese women. J Nutr, Health & Aging. 2003;7(1):44-53. Observational study. [pmid: 12679840].
Ito LS, Inoue M, Tajima K, et al. Dietary factors and the risk of gastric cancer among Japanese women: a comparison between the differentiated and non-differentiated subtypes. Ann Epidemiol. Jan. 2003;13(1):24-31. Observational study. [pmid: 12547482].
Jakes RW, Alexander L, Duffy SW, et al. Dietary intake of soybean protein and menstrual cycle length in pre-menopausal Singapore Chinese women. Public Health Nutr. Apr. 2001;4(2):191-6. Cross-sectional study. [pmid: 11299091].
Jakes RW, Duffy SW, Ng FC, et al. Mammographic parenchymal patterns and self-reported soy intake in Singapore Chinese women. Cancer Epidemiol Biomarkers Prev. Jul. 2002;11(7):608-13. Cancer patients, observational study. [pmid: 12101107].
Jenkins DJ, Kendall CW, Marchie A, et al. Effects of a dietary portfolio of cholesterol-lowering foods vs lovastatin on serum lipids and C-reactive protein. JAMA. Jul 23. 2003;290(4):502-10. Soy not quantified. [pmid: 12876093].
Jenkins DJ, Kendall CW, Marchie A, et al. The effect of combining plant sterols, soy protein, viscous fibers, and almonds in treating hypercholesterolemia. Metabolism. Nov. 2003;52(11):1478-83. Soy combined with other intervention. [pmid: 14624410].
Jenkins DJ, Kendall CW, Vidgen E, et al. Effect of soy-based breakfast cereal on blood lipids and oxidized low-density lipoprotein. Metabolism. Nov. 2000;49(11):1496-500. Soy intervention less than 4 weeks. [pmid: 11092518].
Jenkins DJA, Kendall CWC, Faulkner D, et al. A dietary portfolio approach to cholesterol reduction: Combined effects of plant sterols, vegetable proteins, and viscous fibers in hypercholesterolemia. Metabolism. Dec 1. 2002;51(12):1596-604. Soy combined with other intervention. [pmid: 12489074].
Ji BT, Chow WH, Yang G, et al. Correspondence re: A. H. Wu et al., A meta-analysis of soyfoods and risk of stomach cancer: The problem of potential confounders [2]. Cancer Epidemiol Biomarkers Prev. 2001;10(5):570-1. Letter. [pmid: 11352874].
Jones G, Dwyer T, Hynes K, et al. A randomized controlled trial of phytoestrogen supplementation, growth and bone turnover in adolescent males. Eur J Clin Nutr. Feb. 2003;57(2):324-7. Population not of interest. [pmid: 12571667].
Kajiyama G, Kawamoto T, Fujiyama M, et al. Effect of the purified unsaponifiable fraction of soybean in combination with ursodeoxycholic acid on cholesterol saturation of bile and stone dissolution in gallstone patients. Hiroshima J Med Sci. Jun. 1981;30(2):71-83. No outcomes of interest. [pmid: 7028684].
Kam IW, Dennehy CE, Tsourounis C. Dietary supplement use among menopausal women attending a San Francisco health conference. Menopause. Jan. 2002;9(1):72-8. Soy not quantified. [pmid: 11791089].
Kanazawa T, Tanaka M, Uemura T, et al. Anti-atherogenicity of soybean protein. Ann N Y Acad Sci. 1993;676:202-14. Nonhuman study. [pmid: 8489132].
Kanda A, Hoshiyama Y, Kawaguchi T. Association of lifestyle parameters with the prevention of hypertension in elderly Japanese men and women: a four-year follow-up of normotensive subjects. Asia Pac J Public Health. 1999;11(2):77-81. Observational study. [pmid: 11195162].
Kandiah J. Impact of tofu or tofu + orange juice on hematological indices of lacto-ovo vegetarian females. Plant Foods Hum Nutr. 2002;57(2):197-204. No outcomes of interest. [pmid: 12049152].
Kaneko K, Masaki U, Aikyo M, et al. Urinary calcium and calcium balance in young women affected by high protein diet of soy protein isolate and adding sulfur-containing amino acids and/or potassium. J Nutr Sci Vitaminol. 1990;36(2):105-16. No outcomes of interest. [pmid: 2388095].
Katsuyama H, Ideguchi S, Fukunaga M, et al. Usual dietary intake of fermented soybeans (Natto) is associated with bone mineral density in premenopausal women. J Nutr Sci Vitaminol. Jun. 2002;48(3):207-15. Soy quantified by questionnaire. [pmid: 12350079].
KeinanBoker L, Der Schouw YT, Grobbee DE, et al. Dietary phytoestrogens and breast cancer risk. Am J Clin Nutr. Feb. 2004;79(2):282-8. Diet includes all plant phytoestrogens & mammalian legnans, soy not quantified. [pmid: 14749235].
Key TJ, Sharp GB, Appleby PN, et al. Soya foods and breast cancer risk: a prospective study in Hiroshima and Nagasaki, Japan. Br J Cancer. Dec. 1999;81(7):1248-56. Cancer patients, observational study. [pmid: 10584890].
Kies C, Fox HM, Nelson L. Triticale, soy-TVP and millet based diets as protein suppliers for human adults. J Food Sci. 1975;40(1):90-3. No outcomes of interest.
Kim HJ, Chang WK, Kim MK, et al. Dietary factors and gastric cancer in Korea: a case-control study. Int J Cancer. Feb 1. 2002;97(4):531-5. Cancer patients, observational study. [pmid: 11802218].
Kirk P, Patterson RE, Lampe J. Development of a soy food frequency questionnaire to estimate isoflavone consumption in US adults. J Am Diet Assoc. May. 1999;99(5):558-63. No outcomes of interest. [pmid: 10333777].
Klevay LM, Potter SM, Erdman Jr JW. Soy protein may affect plasma cholesterol through copper [2]. Am J Clin Nutr. 1994;60(2):300-1. Letter. [pmid: 8030612].
Knight DC, Eden JA. A review of the clinical effects of phytoestrogens. [Review][90 refsObstet Gynecol. May. 1996;87(5:Pt 2):897-904. Review.
Knight DC, Howes JB, Eden JA. The effect of Promensil, an isoflavone extract, on menopausal symptoms. Climacteric. Jun. 1999;2(2):79-84. No soy intervention. [pmid: 11910671].
Kok L, KreijkampKaspers S, Grobbee DE, et al. Design and baseline characteristics of a trial on health effects of soy protein with isoflavones in postmenopausal women. Maturitas. Jan 20. 2004;47(1):21-9. No outcomes of interest. [pmid: 14706762].
Kolb S, Sailer D. Soybean protein crispbread ad additional dietetic measure in hypercholesterolaemia. Nutr Rep Int. 1984;30(3):719-24. CVD study with no control.
Kolonel LN, Hankin JH, Whittemore AS, et al. Vegetables, fruits, legumes and prostate cancer: a multiethnic case-control study. Cancer Epidemiol Biomarkers Prev. Aug. 2000;9(8):795-804. Cancer patients, observational study. [pmid: 10952096].
Kontessis P, Jones S, Dodds R, et al. Renal, metabolic and hormonal responses to ingestion of animal and vegetable proteins. Kidney International. Jul. 1990;38(1):136-44. Soy intervention less than 4 weeks. [pmid: 2166857].
Koo LC. Dietary habits and lung cancer risk among Chinese females in Hong Kong who never smoked. Nutr Cancer. 1988;11(3):155-72. Cancer patients, observational study. [pmid: 2841651].
KritzSilverstein D, GoodmanGruen DL. Usual dietary isoflavone intake, bone mineral density, and bone metabolism in postmenopausal women. J Womens Health Gend Based Med. Jan. 2002;11(1):69-78. Observational study. [pmid: 11860727].
Kronenberg F, FughBerman A. Complementary and alternative medicine for menopausal symptoms: a review of randomized, controlled trials. [Review] [58 refs]. Ann Intern Med. Nov 19. 2002;137(10):805-13. Review. [pmid: 12435217].
Laidlaw M, Mercer NJH. Serum cholesterol, triglyceride and lipoprotein response in hypercholesterolemic males to replacement of cow's milk with a soy beverage. Fed Proc 1985;44(5). Abstract.
Le Marchand L, Hankin JH, Wilkens LR, et al. Dietary fiber and colorectal cancer risk. Epidemiology. Nov. 1997;8(6):658-65. Cancer patients, observational study. [pmid: 9345666].
Lee HP, Gourley L, Duffy SW, et al. Dietary effects on breast-cancer risk in Singapore. Lancet. May 18. 1991;337(8751):1197-200. Cancer patients, observational study. [pmid: 1673746].
Lee HP, Gourley L, Duffy SW, et al. Preserved foods and nasopharyngeal carcinoma: a case-control study among Singapore Chinese. Int J Cancer. Dec 1. 1994;59(5):585-90. Cancer patients, observational study. [pmid: 7960230].
Lee HP, Gourley L, Duffy SW, et al. Risk factors for breast cancer by age and menopausal status: a case-control study in Singapore. Cancer Causes Control. Jul. 1992;3(4):313-22. Cancer patients, observational study. [pmid: 1617118].
Lee JK, Park BJ, Yoo KY, et al. Dietary factors and stomach cancer: a case-control study in Korea. Int J Epidemiol. Feb. 1995;24(1):33-41. Cancer patients, observational study. [pmid: 7797354].
Lee MM, Gomez SL, Chang JS, et al. Soy and isoflavone consumption in relation to prostate cancer risk in China. Cancer Epidemiol Biomarkers Prev. Jul. 2003;12(7):665-8. Cancer patients, observational study. [pmid: 12869409].
Lee SA, Kang D, Shim KN, et al. Effect of diet and Helicobacter pylori infection to the risk of early gastric cancer. J Epidemiol. May. 2003;13(3):162-8. Cancer patients, observational study. [pmid: 12749604].
Lei B, Roncaglia V, Vigano R, et al. Phytoestrogens and liver disease. Molecular & Cellular Endocrinology. Jul 31. 2002;193(12):81-4. Cancer patients, observational study. [pmid: 12161005].
Lequesne M, Maheu E, Cadet C, et al. Structural effect of avocado/soybean unsaponifiables on joint space loss in osteoarthritis of the hip. Arthritis & Rheumatism. Feb. 2002;47(1):50-8. No soy intervention. [pmid: 11932878].
Librenti MC, Cocchi M, Orsi E, et al. Effect of soya and cellulose fibers on postprandial glycemic response in type II diabetic patients. Diabetes Care. Jan. 1992;15(1):111-3. No outcomes of interest. [pmid: 1310645].
Lichtenstein AH, Ausman LM, Jalbert SM, et al. Effects of different forms of dietary hydrogenated fats on serum lipoprotein cholesterol levels.[erratum appears in N Engl J Med 1999 Sep 9;341(11):856]. N Engl J Med. Jun 24. 1999;340(25):1933-40. Soy oil intervention. [pmid: 10379016].
Lichtenstein AH, Erkkila AT, Lamarche B, et al. Influence of hydrogenated fat and butter on CVD risk factors: Remnant-like particles, glucose and insulin, blood pressure and C-reactive protein. Atherosclerosis. 2003;171(1):97-107. No soy intervention. [pmid: 14642411].
Little A, Levy R, ChuaquiKidd P, et al. A double-blind, placebo controlled trial of high-dose lecithin in Alzheimer's disease. Journal of Neurology, Neurosurgery & Psychiatry. Aug. 1985;48(8):736-42. No outcomes of interest.
Little CV, Parsons T. Herbal therapy for treating osteoarthritis. [Review][50 refs]. Cochrane Database of Systematic Reviews 2001;2001(1):CD002947. Systematic review.
Liu B, Wu Z, Liu W, et al. Effects of bean meal on serum cholesterol and triglycerides. Chinese Medical Journal. 1981;94(7):455-8. Soy not quantified. [pmid: 6796350].
Liu XQ, Li YH. Epidemiological and nutritional research on prevention of cardiovascular disease in China. Br J Nutr 2000;84(SUPPL. 2):S199–S203. Review.
Lo GS, Cole TG. Soy cotyledon fiber products reduce plasma lipids. Atherosclerosis. May. 1990;82(12):59-67. Soy fiber – intervention not of interest. [pmid: 2163253].
Lo GS, Goldberg AP, Lim A. Soy fiber improves lipid and carbohydrate metabolism in primary hyperlipidemic subjects. Atherosclerosis. 1986;62(33):239-48. Soy fiber – intervention not of interest. [pmid: 3026411].
Long JM, III, Wilmore DW, Mason AD Jr., et al. Effect of carbohydrate and fat intake on nitrogen excretion during total intravenous feeding. Annals of Surgery. Apr. 1977;185(4):417-22. No outcomes of interest. [pmid: 402892]. [pmcid: 1396128].
Lovati MR, Manzoni C, Canavesi A, et al. Soybean protein diet increases low density lipoprotein receptor activity in mononuclear cells from hypercholesterolemic patients. Journal of Clinical Investigation. 1987;80(5):1498-502. Soy not quantified. [pmid: 3680510]. [pmcid: 442410].
Lu LJW, Anderson KE, Gomez G, et al. Decreased plasma levels of cholecystokinin in healthy males after chronic ingestion of a heat-treated soya product. Cancer Letters. 1995;90(2):149-55. Soy not quantified. [pmid: 7736450].
Lu LJW, Grady JJ, Marshall MV, et al. Altered time course of urinary daidzein and genistein excretion during chronic soya diet in healthy male subjects. Nutr Cancer. 1995;24(3):311-23. No outcomes of interest. [pmid: 8610050].
Lu LJW, Lin SN, Grady JJ, et al. Altered kinetics and extent of urinary daidzein and genistein excretion in women during chronic soya exposure. Nutr Cancer. 1996;26(3):289-302. No outcomes of interest. [pmid: 8910911].
Lu Z, Hendrich S, Shen N, et al. Low linolenate and commercial soybean oils diminish serum HDL cholesterol in young free-living adult females. J Am Coll Nutr. Dec. 1997;16(6):562-9. Soy oil intervention. [pmid: 9430084].
Luz LJW, Cree M, Josyula S, et al. Increased urinary excretion of 2-hydroxyestrone but not 16alpha- hydroxyestrone in premenopausal women during a soya diet containing isoflavones. Cancer Res. Mar 1. 2000;60(5):1299-305. No outcomes of interest. [pmid: 10728690].
Lyu L. A journey of discovery in functional dietary components and epidemiology. Nutritional Sciences Journal. 2001;26(2):69-76. Study unavailable for retrieval.
Mahalko JR, Sandstead HH, Johnson LK, et al. Effect of consuming fiber from corn bran, soy hulls, or apple powder on glucose tolerance and plasma lipids in type II diabetes. Am J Clin Nutr. Jan. 1984;39(1):25-34. No soy protein. [pmid: 6318545].
Maheu E, Mazieres B, Valat JP, et al. Symptomatic efficacy of avocado/soybean unsaponifiables in the treatment of osteoarthritis of the knee and hip: a prospective, randomized, double-blind, placebo-controlled, multicenter clinical trial with a six-month treatment period and a two-month followup demonstrating a persistent effect. Arthritis & Rheumatism. Jan. 1998;41(1):81-91. No soy intervention. [pmid: 9433873].
Malaveille C, Fiorini L, Bianchini M, et al. Randomized controlled trial of dietary intervention: association between level of urinary phenolics and anti-mutagenicity. Mutation Research. Jul 11. 2004;561(12):83-90. Soy not quantified. [pmid: 15238233].
Maskarinec G, Franke AA, Williams AE, et al. The effects of an isoflavone intervention on the urinary excretion of hormone metabolites in premenopausal women. IARC Sci Publ. 2002;156:375-7. No outcomes of interest. [pmid: 12484210].
Maskarinec G, Lyu LC, Meng L, et al. Determinants of mammographic densities among women of Asian, Native Hawaiian, and Caucasian ancestry. Ethnicity & Disease. 2001;11(1):44-50. Cancer patients, observational study. [pmid: 11289250].
Maskarinec G, Meng L. An investigation of soy intake and mammographic characteristics in Hawaii. Breast Cancer Research. 2001;3(2):134-41. Cancer patients, observational study. [pmid: 11250760]. [pmcid: 13924].
Maskarinec G, Novotny R, Tasaki K. Dietary patterns are associated with body mass index in multiethnic women. J Nutr. 2000;130(12):3068-72. No outcomes of interest. [pmid: 11110871].
Maskarinec G, Robbins C, Riola B, et al. Three measures show high compliance in a soy intervention among premenopausal women. J Am Diet Assoc. Jul. 2003;103(7):861-6. No outcomes of interest. [pmid: 12830025].
Maskarinec G, Singh S, Meng L, et al. Dietary soy intake and urinary isoflavone excretion among women from a multiethnic population. Cancer Epidemiol Biomarkers Prev. 1998;7(7):613-9. No outcomes of interest. [pmid: 9681530].
Matvienko OA, Lewis DS, Swanson M, et al. A single daily dose of soybean phytosterols in ground beef decreases serum total cholesterol and LDL cholesterol in young, mildly hypercholesterolemic men. Am J Clin Nutr. Jul. 2002;76(1):57-64. No soy intervention. [pmid: 12081816].
Maubach J, Bracke ME, Heyerick A, et al. Quantitation of soy-derived phytoestrogens in human breast tissue and biological fluids by high-performance liquid chromatography. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. Jan 25. 2003;784(1):137-44. No outcomes of interest.
Maughan RJ, Leiper JB, Vist GE. Gastric emptying and fluid availability after ingestion of glucose and soy protein hydrolysate solutions in man. Experimental Physiology. 2004;89(1):101-8. No outcomes of interest. [pmid: 15109215].
McBurney MI, Thompson LU. Dietary fiber and total enteral nutrition: fermentative assessment of five fiber supplements. J Parenter Enter Nutr. May. 1991;15(3):267-70. In vitro study.
McFadyen IJ, Chetty U, Setchell KDR, ZimmerNechemias L, Stanley E, Miller WR. A randomized double blind-cross over trial of soya protein for the treatment of cyclical breast pain. Breast. 2000;9(5):271-276. Population with symptomatic breast disease. [pmid: 14732177].
Mei J, Yeung SS, Kung AW. High dietary phytoestrogen intake is associated with higher bone mineral density in postmenopausal but not premenopausal women. J Clin Endocrinol Metab. Nov. 2001;86(11):5217-21. Observational study. [pmid: 11701680].
Mendis S, Kumarasunderam R. The effect of daily consumption of coconut fat and soya-bean fat on plasma lipids and lipoproteins of young normolipidaemic men. Br J Nutr. May. 1990;63(3):547-52. Soy fat – intervention not of interest. [pmid: 2383532].
Meng QH, Lewis P, Wahala K, et al. Incorporation of esterified soybean isoflavones with antioxidant activity into low density lipoprotein. Biochim Biophys Acta-Molecular & Cell Biology of Lipids. Jun 10. 1999;1438(3):369-76. In vitro study.
Mercer NJH, Carroll KK, Giovannetti PM, et al. Effects on human plasma lipids of substituting soybean protein isolate for milk protein in the diet. Nutr Rep Int. 1987;35(2):279-87. CVD study with no control.
Meredith L, Liebman M, Graves K. Alterations in plasma lipid levels resulting from tofu and cheese consumption in adult women. J Am Coll Nutr. 1989;8(6):573-9. Soy intervention less than 4 weeks. [pmid: 2621294].
Merritt, J. C. Metabolic syndrome: soybean foods and serum lipids. Journal of the National Medical Association 96[8], 1032-1041. 2004. Review.
Messina M, Hughes C. Efficacy of soyfoods and soybean isoflavone supplements for alleviating menopausal symptoms is positively related to initial hot flush frequency. [Review] [86 refs]. Journal of Medicinal Food. 2003;6(1):1-11. Review. [pmid: 12804015].
Messina MJ. Emerging evidence on the role of soy in reducing prostate cancer risk. Nutr Rev. Apr 1. 2003;61(4):117-31. Review. [pmid: 12795445].
Messina MJ. Potential public health implications of the hypocholesterolemic effects of soy protein. Nutrition. Mar 1. 2003;19(3):280-1. Editorial. [pmid: 12620535].
Mikkelsen PB, Toubro S, Astrup A. Effect of fat-reduced diets on 24-h energy expenditure: comparisons between animal protein, vegetable protein, and carbohydrate. Am J Clin Nutr. Nov. 2000;72(5):1135-41. No outcomes of interest. [pmid: 11063440].
Miles CW, Bodwell CE, Morris E, et al. Long-term consumption of beef extended with soy protein by men, women and children: I. Study design, nutrient intakes, and serum zinc levels. Plant Foods Hum Nutr. 1987;37(4):341-59. Soy in combination with other intervention. [pmid: 3507006].
Miltyk W, Craciunescu CN, Fischer L, et al. Lack of significant genotoxicity of purified soy isoflavones (genistein, daidzein, and glycitein) in 20 patients with prostate cancer. Am J Clin Nutr. Apr. 2003;77(4):875-82. Cancer population. [pmid: 12663286].
Mitchell JH, Collins AR. Effects of a soy milk supplement on plasma cholesterol levels and oxidative DNA damage in men - A pilot study. European J Nutr. 1999;38(3):143-8. N < 5 per arm. [pmid: 10443336].
Miyahara T, Fujiwara H, Yae Y. Abnormal lipoprotein appearing in plasma of patients who received a ten percent soybean oil emulsion infusion. Surgery. 1979;85(5):566-74. Soy oil intervention. [pmid: 107609].
Miyanaga N, Akaza H, Takashima N, et al. Higher consumption of green tea may enhance equol production. Asian Pac J Cancer Prev. Aug. 2003;4(4):297-301. No outcomes of interest. [pmid: 14728586].
Moeller LE, Peterson CT, Hanson KB, et al. Isoflavone-rich soy protein prevents loss of hip lean mass but does not prevent the shift in regional fat distribution in perimenopausal women. Menopause. Jul. 2003;10(4):322-31. No outcomes of interest. [pmid: 12851515].
Morens C, Bos C, Pueyo ME, et al. Increasing habitual protein intake accentuates differences in postprandial dietary nitrogen utilization between protein sources in humans. J Nutr. Sep 1. 2003;133(9):2733-40. No outcomes of interest. [pmid: 12949358].
Morton MS, Arisaka O, Miyake N, et al. Phytoestrogen concentrations in serum from Japanese men and women over forty years of age. J Nutr. Oct. 2002;132(10):3168-71. Soy not quantified. [pmid: 12368413].
Morton MS, Chan PS, Cheng C, et al. Lignans and isoflavonoids in plasma and prostatic fluid in men: samples from Portugal, Hong Kong, and the United Kingdom. Prostate. Jul 1. 1997;32(2):122-8. Soy not ingested. [pmid: 9215400].
Morton MS, Wilcox G, Wahlqvist ML, et al. Determination of lignans and isoflavonoids in human female plasma following dietary supplementation. J Endocrinol. Aug. 1994;142(2):251-9. No outcomes of interest. [pmid: 7930998].
Mulligan AA, Luben RN, Welch AA, et al. Daidzein and genistein intakes in England (the EPIC Norfolk cohort). IARC Sci Publ. 2002;156:369-70. No outcomes of interest. [pmid: 12484208].
Murkies AL, Wilcox G, Davis SR. Clinical review 92: Phytoestrogens. [Review] [93 refs]. J Clin Endocrinol Metab. Feb. 1998;83(2):297-303. Review. [pmid: 9467531].
MurrayKolb LE, Welch R, Theil EC, et al. Women with low iron stores absorb iron from soybeans. Am J Clin Nutr. Jan. 2003;77(1):180-4. Soy not quantified. [pmid: 12499339].
Nagata C, Hirokawa K, Shimizu N, et al. Soy, fat and other dietary factors in relation to premenstrual symptoms in Japanese women. Int J Obstet Gynecol. Jun. 2004;111(6):594-9. Cross-sectional study.
Nagata C, Inaba S, Kawakami N, et al. Inverse association of soy product intake with serum androgen and estrogen concentrations in Japanese men. Nutr Cancer. 2000;36(1):14-8. Cross-sectional study. [pmid: 10798211].
Nagata C, Kabuto M, Kurisu Y, et al. Decreased serum estradiol concentration associated with high dietary intake of soy products in premenopausal Japanese women. Nutr Cancer. 1997;29(3):228-33. Cancer patients, observational study. [pmid: 9457744].
Nagata C, Shimizu H, Takami R, et al. Association of blood pressure with intake of soy products and other food groups in Japanese men and women. Prev Med. Jun 1. 2003;36(6):692-7. Cross-sectional study. [pmid: 12744912].
Nagata C, Shimizu H, Takami R, et al. Dietary soy and fats in relation to serum insulin-like growth factor-1 and insulin-like growth factor-binding protein-3 levels in premenopausal Japanese women. Nutr Cancer. 2003;45(2):185-9. Cancer patients, observational study. [pmid: 12881012].
Nagata C, Shimizu H, Takami R, et al. Hot flushes and other menopausal symptoms in relation to soy product intake in Japanese women. Climacteric. 1999;2(1):6-12. Cross-sectional study. [pmid: 11910681].
Nagata C, Shimizu H, Takami R, et al. Serum concentrations of estradiol and dehydroepiandrosterone sulfate and soy product intake in relation to psychologic well-being in peri- and postmenopausal Japanese women. Metabolism. 2000;49(12):1561-4. Cross-sectional study. [pmid: 11145117].
Nagata C, Shimizu H, Takami R, et al. Soy product intake and serum isoflavonoid and estradiol concentrations in relation to bone mineral density in postmenopausal Japanese women. Osteoporos Int. 2002;13(3):200-4. Observational study. [pmid: 11991438].
Nagata C, Takatsuka N, Kawakami N, et al. A prospective cohort study of soy product intake and stomach cancer death. Br J Cancer. Jul 1. 2002;87(1):31-6. Observational study. [pmid: 12085252].
Nagata C, Takatsuka N, Kawakami N, et al. Soy product intake and premenopausal hysterectomy in a follow-up study of Japanese women. Eur J Clin Nutr. Sep. 2001;55(9):773-7. Observational study. [pmid: 11528492].
Nagata C, Takatsuka N, Kawakami N, et al. Soy product intake and hot flashes in Japanese women: results from a community-based prospective study. Am J Epidemiol. Apr 15. 2001;153(8):790-3. Observational study. [pmid: 11296152].
Nagata C, Takatsuka N, Kurisu Y, et al. Decreased serum total cholesterol concentration is associated with high intake of soy products in Japanese men and women. J Nutr. Feb. 1998;128(2):209-13. Cross-sectional study. [pmid: 9446845].
Nagata C, Takatsuka N, Shimizu H. Soy and fish oil intake and mortality in a Japanese community. Am J Epidemiol. Nov 1. 2002;156(9):824-31. Observational study. [pmid: 12397000].
Nagata C. Ecological study of the association between soy product intake and mortality from cancer and heart disease in Japan. Int J Epidemiol. Oct. 2000;29(5):832-6. Cancer patients, observational study. [pmid: 11034965].
Naik HR, Lehr JE, Pienta KJ. An in vitro and in vivo study of antitumor effects of genistein on hormone refractory prostate cancer. Anticancer Res. 1994;14(6 B):2617-9. In vitro, animal study. [pmid: 7872690].
Nakachi K, Imai K. Environmental and physiological influences on human natural killer cell activity in relation to good health practices. Jpn J Cancer Res. Aug. 1992;83(8):798-805. Cancer patients, no intervention. [pmid: 1399816].
Nakamura H, Yamazaki M, Chiba Y, et al. Acute loading with proteins from different sources in healthy volunteers and diabetic patients. J Diabet Complications. Apr. 1991;5(23):140-2. Cross-sectional study. [pmid: 1770024].
Nakamura M, Aoki N, Yamada T, et al. Feasibility and effect on blood pressure of 6-week trial of low sodium soy sauce and miso (fermented soybean paste). Circ J. Jun. 2003;67(6):530-4. No soy comparison, general population for blood pressure study. [pmid: 12808272].
Nakashima Y, Nakamura T, Aramaki Y, et al. Effect of the purified unsaponifiable fraction of soybean on primary type II hyperlipoproteinemia. Artery. 1983;12(3):199-211. CVD study with no control. [pmid: 6687319].
Nestel PJ, Pomeroy S, Kay S, et al. Isoflavones from red clover improve systemic arterial compliance but not plasma lipids in menopausal women.[erratum appears in J Clin Endocrinol Metab 1999 Oct;84(10):3647]. J Clin Endocrinol Metab. Mar. 1999;84(3):895-8. No soy intervention. [pmid: 10084567].
Nettleton JA, Greany KA, Thomas W, et al. Plasma phytoestrogens are not altered by probiotic consumption in postmenopausal women with and without a history of breast cancer. J Nutr. Aug. 2004;134(8):1998-2003. No outcomes of interest. [pmid: 15284389].
Newton KM, Buist DS, Keenan NL, et al. Use of alternative therapies for menopause symptoms: results of a population-based survey. [erratum appears in Obstet Gynecol 2003 Jan;101(1):205 Obstet Gynecol. Jul. 2002;100(1):18-25. Soy not quantified.
Ngoan LT, Mizoue T, Fujino Y, et al. Dietary factors and stomach cancer mortality. Br J Cancer. Jul 1. 2002;87(1):37-42. Soy not quantified. [pmid: 12085253].
Nicholls J, Lasley BL, Nakajima ST, et al. Effects of soy consumption on gonadotropin secretion and acute pituitary responses to gonadotropin-releasing hormone in women. J Nutr. Apr. 2002;132(4):708-14. Soy intervention less than 4 weeks. [pmid: 11925465].
Normen L, Dutta P, Lia A, et al. Soy sterol esters and beta-sitostanol ester as inhibitors of cholesterol absorption in human small bowel. Am J Clin Nutr. Apr. 2000;71(4):908-13. No soy protein. [pmid: 10731496].
North K, Golding J. A maternal vegetarian diet in pregnancy is associated with hypospadias. The ALSPAC Study Team. Avon Longitudinal Study of Pregnancy and Childhood. BJU Int. Jan. 2000;85(1):107-13. Soy not quantified. [pmid: 10619956].
O'Brien BC, Andrews VG. Influence of dietary egg and soybean phospholipids and triacylglycerols on human serum lipoproteins. Lipids Vol. 1993;28(1):7-12. Soy phospholipid intervention.
Odes HS, Lazovski H, Stern I, et al. Double-blind trial of a high dietary fiber, mixed grain cereal in patients with chronic constipation and hyperlipidemia. Nutr Res. 1993;13(9):979-85. Soy not quantified.
Ohba S, Nishi M, Miyake H. Eating habits and pancreas cancer.[erratum appears in Int J Pancreatol 1996 Oct;20(2):153]. Int J Pancreatol. Aug. 1996;20(1):37-42. Cancer patients, observational study. [pmid: 8872522].
Omura T, Hisamatsu S, Takizawa Y, et al. Geographical distribution of cerebrovascular disease mortality and food intakes in Japan. Soc Sci Med. 1987;24(5):401-7. Cross-sectional study. [pmid: 3576256].
Oosthuizen W, Vorster HH, Vermaak WJ, et al. Lecithin has no effect on serum lipoprotein, plasma fibrinogen and macro molecular protein complex levels in hyperlipidaemic men in a double-blind controlled study. Eur J Clin Nutr. Jun. 1998;52(6):419-24. No soy protein. [pmid: 9683394].
Ornish DM, Lee KL, Fair WR, et al. Dietary trial in prostate cancer: Early experience and implications for clinical trial design. Urology. Apr. 2001;57(4:Suppl 1):200-1. Soy not quantified. [pmid: 11295627].
Ota DM, Jessup JM, Babcock GF, et al. Immune function during intravenous administration of a soybean oil emulsion. J Parenter Enter Nutr. Jan. 1985;9(1):23-7. Soy oil intervention.
Ovesen L, Allingstrup L. Different quantities of two commercial liquid diets consumed by weight-losing cancer patients. J Parenter Enter Nutr. May. 1992;16(3):275-8. No soy intervention.
Ovesen L, Ebbesen K, Olesen ES. The effects of oral soybean phospholipid on serum total cholesterol, plasma triglyceride, and serum high-density lipoprotein cholesterol concentrations in hyperlipidemia. J Parenter Enter Nutr. Nov. 1985;9(6):716-9. Soy phospholipid intervention.
Ozasa K, Nakao M, Watanabe Y, et al. Serum phytoestrogens and prostate cancer risk in a nested case-control study among Japanese men. Cancer Sci. 2004;95(1):65-71. Soy not ingested. [pmid: 14720329].
Ozasa K, Watanabe Y, Ito Y, et al. Dietary habits and risk of lung cancer death in a large-scale cohort study (JACC Study) in Japan by sex and smoking habit. Jpn J Cancer Res. Dec. 2001;92(12):1259-69. Cancer patients, observational study. [pmid: 11749690].
Pap A, Berger Z, Varro V. Comparison of the trophic effect of cholecystokinin-octapeptide (CCK-OP) and soy flour treatment in chronic pancreatitis. Gastroenterol Clin Biol. 1981;5(10):938. Abstract.
Passi SJ, Manchanda SC, Suri S, et al. Lipid lowering effect of dietary fibre supplementation through food based approach. Asia Pac J Clin Nutr. 2004;13(Suppl):S155. Study unavailable for retrieval.
Pelletier X, Belbraouet S, Mirabel D, et al. A diet moderately enriched in phytosterols lowers plasma cholesterol concentrations in normocholesterolemic humans. Ann Nutr Metab. 1995;39(5):291-5. Soy oil intervention. [pmid: 8585698].
Peterson J, Lagiou P, Samoli E, et al. Flavonoid intake and breast cancer risk: a case--control study in Greece. Br J Cancer. Oct 6. 2003;89(7):1255-9. Soy not quantified. [pmid: 14520456].
Phipps WR, Wangen KE, Duncan AM, et al. Lack of effect of isoflavonic phytoestrogen intake on leptin concentrations in premenopausal and postmenopausal women. Fertil Steril. Jun. 2001;75(6):1059-64. No outcomes of interest. [pmid: 11384628].
Pino AM, Valladares LE, Palma MA, et al. Dietary isoflavones affect sex hormone-binding globulin levels in postmenopausal women. J Clin Endocrinol Metab. Aug. 2000;85(8):2797-800. No quantification of soy. [pmid: 10946884].
Potter JD, Illman RJ, Calvert GD, et al. Soya saponins, plasma lipids, lipoproteins and fecal bile acids: a double blind cross-over study. Nutr Rep Int. 1980;22(4):521-8. NonRCT study with Chol/Tg outcomes only.
Ranich T, Bhathena SJ, Velasquez MT. Protective effects of dietary phytoestrogens in chronic renal disease. [Review] [93 refs]. J Ren Nutr. Oct. 2001;11(4):183-93. Review. [pmid: 11679998].
Raptis S, Dollinger HC, von Berger L, et al. Effect of lipids on insulin, growth hormone and exocrine pancreatic secretion in man. Eur J Clin Invest. Nov 21. 1975;5(6):521-6. No soy intervention. [pmid: 1201769].
RauchJanssen A, Grobner W, Zollner N. Comparison of serum uric acid and urinary uric acid excretion under a soy protein diet low in purines and under a formula diet virtually free of purines. Nutr Metab. 1977;21(Suppl 1):94-7. No outcomes of interest. [pmid: 562493].
Reginster JY, Gillot V, Bruyere O, et al. Evidence of nutriceutical effectiveness in the treatment of osteoarthritis. [Review] [50 refs]. Curr Rheumatol Rep. Dec. 2000;2(6):472-7. Review. [pmid: 11123100].
Resnicow K, Barone J, Engle A, et al. Diet and serum lipids in vegan vegetarians: A model for risk reduction. J Am Diet Assoc. 1991;91(4):447-53. No soy intervention. [pmid: 1849932].
Rimbach G, Weinberg PD, de PascualTeresa S, et al. Sulfation of genistein alters its antioxidant properties and its effect on platelet aggregation and monocyte and endothelial function. Biochim Biophys Acta. Feb 24. 2004;1670(3):229-37. In vitro study. [pmid: 14980449].
RisticMedic D, Ristic V, Tepsic V, et al. Effect of soybean Leci-Vita product on serum lipids and fatty acid composition in patients with elevated serum cholesterol and triglyceride levels. Nutr Res. 2003;23(4):465-77. Duplicate publication.
Rossi AL, BlosteinFujii A, DiSilvestro RA. Soy beverage consumption by young men: Increased plasma total antioxidant status and decreased acute, exercise-induced muscle damage. J Nutraceuticals Funct Med Foods. 2000;3(1):33-44. Soy intervention less than 4 weeks.
Sacks FM, Wood PG, Kass EH. Stability of blood pressure in vegetarians receiving dietary protein supplements. Hypertension. Mar. 1984;6(2:Pt 1):199-201. Soy not quantified. [pmid: 6724661].
Samman S, Lyons Wall PM, Chan GS, et al. The effect of supplementation with isoflavones on plasma lipids and oxidisability of low density lipoprotein in premenopausal women. Atherosclerosis. Dec. 1999;147(2):277-83. No soy intervention. [pmid: 10559513].
Sammartino A, Di Carlo C, Mandato VD, et al. Effects of genistein on the endometrium: ultrasonographic evaluation. Gynecol Endocrinol. Feb. 2003;17(1):45-9. No soy intervention. [pmid: 12724018].
Sanchez A, Blomstedt M, Hubbard RW. Glucose intolerance as an additional test of the protein effect on serum cholesterol: clinical cases. Atherosclerosis. 1987;65(3):273-5. Letter. [pmid: 3619990].
Sanders TA, Dean TS, Grainger D, et al. Moderate intakes of intact soy protein rich in isoflavones compared with ethanol-extracted soy protein increase HDL but do not influence transforming growth factor beta(1) concentrations and hemostatic risk factors for coronary heart disease in healthy subjects. Am J Clin Nutr. Aug. 2002;76(2):373-7. Soy intervention less than 4 weeks. [pmid: 12145009].
Sasazuki S. Fukuoka Heart Study Group. Case-control study of nonfatal myocardial infarction in relation to selected foods in Japanese men and women. Jpn Circ J. Mar. 2001;65(3):200-6. Case-control study. [pmid: 11266195].
Scheiber MD, Rebar RW. Isoflavones and postmenopausal bone health: a viable alternative to estrogen therapy?. [Review] [61 refs]. Menopause. 1999;6(3):233-41. Review. [pmid: 10486794].
Schouw YT, Pijpe A, Lebrun CEI, et al. Higher usual dietary intake of phytoestrogens is associated with lower aortic stiffness in postmenopausal women. Arterioscler Thromb Vasc Biol. 2002;22(8):1316-22. Observational study. [pmid: 12171794].
Schweizer TF, Bekhechi AR, Koellreutter B, et al. Metabolic effects of dietary fiber from dehulled soybeans in humans. Am J Clin Nutr. Jul. 1983;38(1):1-11. No soy intervention. [pmid: 6305183].
See D, Mason S, Roshan R. Increased Tumor Necrosis Factor alpha (TNF-a) and Natural Killer Cell (NK) function using an integrative approach in late stage cancers. Immunol Invest. 2002;31(2):137-53. Mixed soy product. [pmid: 12148949].
Seidl MM, Stewart DE. Alternative treatments for menopausal symptoms. Systematic review of scientific and lay literature.[erratum appears in Can Fam Physician 1998 Aug;44:1598]. [Review] [115 refs]. Can Fam Physician. Jun. 1998;44:1299-308. Review. [pmid: 9640524]. [pmcid: 2278276].
Seow A, Poh WT, Teh M, et al. Diet, reproductive factors and lung cancer risk among Chinese women in Singapore: evidence for a protective effect of soy in nonsmokers. Int J Cancer. Jan 20. 2002;97(3):365-71. Cancer patients, observational study. [pmid: 11774290].
Seow A, Quah SR, Nyam D, et al. Food groups and the risk of colorectal carcinoma in an Asian population. Cancer. Dec 1. 2002;95(11):2390-6. Soy not quantified. [pmid: 12436447].
Severson RK, Nomura AM, Grove JS, et al. A prospective study of demographics, diet, and prostate cancer among men of Japanese ancestry in Hawaii. Cancer Research. Apr 1. 1989;49(7):1857-60. Cancer patients, observational study. [pmid: 2924323].
Shaw NS, Chin CJ, Pan WH. A vegetarian diet rich in soybean products compromises iron status in young students. J Nutr. Feb. 1995;125(2):212-9. Soy not quantified. [pmid: 7861248].
Shige H, Ishikawa T, Higashi K, et al. Effects of soy protein isolate (SPI) and casein on the postprandial lipemia in normolipidemic men. J Nutr Sci Vitaminol. 1998;44(1):113-27. Soy intervention less than 4 weeks. [pmid: 9591239].
Shinchi K, Ishii H, Imanishi K, et al. Relationship of cigarette smoking, alcohol use, and dietary habits with Helicobacter priori infection in japanese men. Scand J Gastroenterol V. 1997;32(7):651-5. No intervention.
Shorey RL, Day PJ, Willis RA, et al. Effects of soybean polysaccharide on plasma lipids. J Am Diet Assoc. Nov. 1985;85(11):1461-5. Insufficient soy protein. [pmid: 2997315].
Shu XO, Jin F, Dai Q, et al. Soyfood intake during adolescence and subsequent risk of breast cancer among Chinese women. Cancer Epidemiol Biomarkers Prev. May. 2001;10(5):483-8. Cancer patients, observational study. [pmid: 11352858].
Sirtori CR, Agradi E, Conti F, et al. Soybean-protein diet in the treatment of type-II hyperlipoproteinaemia. Lancet. Feb 5. 1977;1(8006):275-7. Soy intervention less than 4 weeks. [pmid: 64804].
Sirtori CR, Gatti E, Mantero O, et al. Clinical experience with the soybean protein diet in the treatment of hypercholesterolemia. Am J Clin Nutr. Aug. 1979;32(8):1645-58. Soy intervention less than 4 weeks. [pmid: 380318].
Slavin JL, Karr SC, Hutchins AM, et al. Influence of soybean processing, habitual diet, and soy dose on urinary isoflavonoid excretion. Am J Clin Nutr. Dec. 1998;68(6:Suppl):1492S-5S. No outcomes of interest. [pmid: 9848522].
Slavin JL, Nelson NL, McNamara EA, et al. Bowel function of healthy men consuming liquid diets with and without dietary fiber. : J Parenter Enter Nutr. May. 1985;9(3):317-21. Soy fiber – intervention not of interest.
Soeken KL. Selected CAM therapies for arthritis-related pain: the evidence from systematic reviews. [Review] [24 refs]. Clin J Pain. Jan. 2004;20(1):13-8. No soy intervention. [pmid: 14668651].
Somekawa Y, Chiguchi M, Ishibashi T, et al. Soy intake related to menopausal symptoms, serum lipids, and bone mineral density in postmenopausal Japanese women. Obstet Gynecol. 2001;97(1):109-15. Cancer patients, observational study. [pmid: 11152918].
Soroka N, Silverberg DS, Greemland M, Birk Y, Blum M, Peer G, et al. Comparison of a vegetable-based (soya) and an animal-based low-protein diet in predialysis chronic renal failure patients. Nephron. 1998;79(2):173-180. Final N < 10. [pmid: 9647497].
Spentzos D, Mantzoros C, Regan MM, et al. Minimal effect of a low-fat/high soy diet for asymptomatic, hormonally naive prostate cancer patients. Clin Cancer Res. Sep 1. 2003;9(9):3282-7. Not population of interest. [pmid: 12960113].
Spilburg CA, Goldberg AC, McGill JB, et al. Fat-free foods supplemented with soy stanol-lecithin powder reduce cholesterol absorption and LDL cholesterol. J Am Diet Assoc. May. 2003;103(5):577-81. No outcomes of interest. [pmid: 12728215].
Steele, M. G. The effect of serum cholesterol levels of substituting milk with a soya beverage. Austrialian Journal of Nutrition and Dietetics 49[1], 24–28. 1992. Soy not quantified.
Strazzulla G, Piazzini M, Guazzelli R. Textured vegetable proteins in the weight control of obesity. Curr Ther Res Clin Exp. 1983;33(2):219-24. Soy not quantified.
Strom SS, Yamamura Y, Duphorne CM, et al. Phytoestrogen intake and prostate cancer: a case-control study using a new database.[erratum appears in Nutr Cancer 2000;36(2):243]. Nutr Cancer. 1999;33(1):20-5. Cancer patients, observational study. [pmid: 10227039].
Stumpf K, Pietinen P, Puska P, et al. Changes in serum enterolactone, genistein, and daidzein in a dietary intervention study in Finland. Cancer Epidemiol Biomarkers Prev. 2000;9(12):1369-72. Soy not quantified. [pmid: 11142423].
Sturmer W, Kramer E, Kasper H, et al. Favourable glycaemic effects of a new balanced liquid diet for enteral nutrition - Results of a short-term study in 30 type II diabetic patients. Clin Nutr. 1994;13(4):221-7. No soy intervention. [pmid: 16843389].
Su SJ, Chow NH, Kung ML, et al. Effects of soy isoflavones on apoptosis induction and G2-M arrest in human hepatoma cells involvement of caspase-3 activation, Bcl-2 and Bcl-X<inf>L</inf> downregulation, and Cdc2 kinase activity. Nutr Cancer. 2003;45(1):113-23. In vitro study. [pmid: 12791511].
Suarez FL, Springfield J, Furne JK, et al. Gas production in human ingesting a soybean flour derived from beans naturally low in oligosaccharides. Am J Clin Nutr. Jan. 1999;69(1):135-9. No outcomes of interest. [pmid: 9925135].
Sun CL, Yuan JM, Arakawa K, et al. Dietary soy and increased risk of bladder cancer: the Singapore Chinese Health Study. Cancer Epidemiol Biomarkers Prev. Dec. 2002;11(12):1674-7. Cancer patients, observational study. [pmid: 12496060].
Sun J. Morning/evening menopausal formula relieves menopausal symptoms: A pilot study. J Altern Complement Med. 2003;9(3):403-9. Soy in combination with other intervention. [pmid: 12816628].
Takezaki T, Hirose K, Inoue M, et al. Dietary factors and lung cancer risk in Japanese: with special reference to fish consumption and adenocarcinomas. Br J Cancer. May 4. 2001;84(9):1199-206. Soy not quantified. [pmid: 11336471].
Talbot JR, Guardo P, Seccia S, et al. Calcium bioavailability and parathyroid hormone acute changes after oral intake of dairy and nondairy products in healthy volunteers. Osteoporos Int. 1999;10(2):137-42. No soy intervention. [pmid: 10501794].
Taudorf E, Bundgaard A, Hancke S, et al. Non-hydrolysed and hydrolysed soy protein. A human immunological study. Allergy. Apr. 1984;39(3):203-9. No outcomes of interest. [pmid: 6538766].
Teede HJ, McGrath BP, DeSilva L, et al. Isoflavones reduce arterial stiffness: a placebo-controlled study in men and postmenopausal women. Arterioscler Thromb Vasc Biol. Jun 1. 2003;23(6):1066-71. No soy intervention. [pmid: 12714433].
Tompkins RK, Parkin LG. Effects of long-term ingestion of soya phospholipids on serum lipids in humans. Am J Surg. Sep. 1980;140(3):360-4. N < 5. [pmid: 7191641].
Tonkelaar Id, KeinanBoker L, Veer Pv, et al. Urinary phytoestrogens and postmenopausal breast cancer risk. Cancer Epidemiol Biomarkers Prev. 2001;10(3):223-8. Case-control study, soy not quantified. [pmid: 11303591].
TorresSanchez L, LopezCarrillo L, LopezCervantes M, et al. Food sources of phytoestrogens and breast cancer risk in Mexican women. Nutr Cancer. 2000;37(2):134-9. Cancer patients, observational study. [pmid: 11142084].
Tsai AC, Mott EL, Owen GM, et al. Effects of soy polysaccharide on gastrointestinal functions, nutrient balance, steroid excretions, glucose tolerance, serum lipids, and other parameters in humans. Am J Clin Nutr. Oct. 1983;38(4):504-11. No soy intervention. [pmid: 6312791].
Tsai AC, Vinik A, Lasichak A, et al. Effects of soy polysaccharide in diabetic subjects. Fed Proc 1984;43(4). Abstract.
Tsai AC, Vinik AI, Lasichak A, et al. Effects of soy polysaccharide on postprandial plasma glucose, insulin, glucagon, pancreatic polypeptide, somatostatin, and triglyceride in obese diabetic patients. Am J Clin Nutr. Mar. 1987;45(3):596-601. Soy intervention less than 4 weeks. [pmid: 2881482].
Tsimberidou AM, Paterakis G, Androutsos G, et al. Evaluation of the clinical relevance of the expression and function of P-glycoprotein, multidrug resistance protein and lung resistance protein in patients with primary acute myelogenous leukemia. Leuk Res. Feb. 2002;26(2):143-54. No soy intervention. [pmid: 11755464].
Tsuchida K, Mizushima S, Toba M, et al. Dietary soybeans intake and bone mineral density among 995 middle-aged women in Yokohama. J Epidemiol. Feb. 1999;9(1):14-9. Cross-sectional study. [pmid: 10098348].
Tsugane S, Kabuto M, Imai H, et al. Helicobacter pylori, dietary factors, and atrophic gastritis in five Japanese populations with different gastric cancer mortality. Cancer Causes Control. Jul. 1993;4(4):297-305. Cancer patients, observational study. [pmid: 8347778].
Tsugane S, Tei Y, Takahashi T, et al. Salty food intake and risk of Helicobacter pylori infection. Jpn J Cancer Res. May. 1994;85(5):474-8. Cancer patients, observational study. [pmid: 8014104].
Tsukamoto Y, Ichise H, Kakuda H, et al. Intake of fermented soybean (natto) increases circulating vitamin K2 (menaquinone-7) and gamma-carboxylated osteocalcin concentration in normal individuals. J Bone Miner Metab. 2000;18(4):216-22. Soy combined with other intervention. [pmid: 10874601].
Tsunoda N, Pomeroy S, Nestel P. Absorption in humans of isoflavones from soy and red clover is similar. J Nutr. Aug. 2002;132(8):2199-201. No outcomes of interest. [pmid: 12163662].
Uenishi T, Sugiura H, Uehara M. Role of foods in irregular aggravation of atopic dermatitis. J Dermatol. Feb 1. 2003;30(2):91-7. No outcomes of interest. [pmid: 12692374].
Valsta LM, Kilkkinen A, Mazur W, et al. Phyto-oestrogen database of foods and average intake in Finland. Br J Nutr. Jun. 2003;89(Suppl 1):S31-S38. Report, not study. [pmid: 12725654].
Valtuen~a S, Cashman K, Robins SP, et al. Investigating the role of natural phyto-oestrogens on bone health in postmenopausal women. Br J Nutr. Jun 1. 2003;89(Suppl. 1):S87-S99. Review. [pmid: 12725658].
van der Schouw YT, Pijpe A, Lebrun CE, et al. Higher usual dietary intake of phytoestrogens is associated with lower aortic stiffness in postmenopausal women. Arterioscler Thromb Vasc Biol. Aug 1. 2002;22(8):1316-22. Observational study. [pmid: 12171794].
van Stratum P, Rudrum M, ten Hoor F, et al. Physiological effects of a high soya-bean protein diet in man. Proc Nutr Soc. May. 1978;37(1):11A. Abstract.
Vecchia Cl, Negri E, Franceschi S, et al. Olive oil, other dietary fats, and the risk of breast cancer (Italy). Cancer Causes Control. 1995;6(6):545-50. Soy not quantified. [pmid: 8580304].
Verkasalo PK, Appleby PN, Allen NE, et al. Validation study of soya intake and plasma isoflavone levels among British women. In: Riboli E and Lambert R, editors. Nutrition and lifestyle: opportunities for cancer prevention. France on 21–24 June, 2003. International Agency for Research on Cancer (IARC), Lyon, France: Eur Conf on Nutr Cancer held in Lyon; 2002. p. 135–6. Intake levels only.
Verkasalo PK, Appleby PN, Allen NE, et al. Validation study of soya intake and plasma isoflavone levels among British women. IARC Sci Publ. 2002;156:135-6. No outcomes given. [pmid: 12484146].
Vessby B, Karlstrom B, Lithell H. The effects on lipid and carbohydrate metabolism of replacing some animal protein by soy-protein in a lipid-lowering diet for hypercholesterolaemic patients. Hum Nutr Appl Nutr. 1982;36(3):179-89. Soy not quantified. [pmid: 6889589].
Volgarev MN, Vysotsky VG, Meshcheryakova VA, et al. Evaluation of isolated soy protein foods in weight reduction with obese hypercholesterolemic and normocholesterolemic obese individuals. Nutr Rep Int. 1989;39(1):61-73. No outcomes of interest.
Volpe R, Niittynen L, Korpela R, et al. Effects of yoghurt enriched with plant sterols on serum lipids in patients with moderate hypercholesterolaemia. Br J Nutr. Aug. 2001;86(2):233-9. No soy intervention. [pmid: 11502237].
Wakai K, Ohno Y, Genka K, et al. Risk modification in lung cancer by a dietary intake of preserved foods and soyfoods: findings from a case-control study in Okinawa, Japan. Lung Cancer. Sep. 1999;25(3):147-59. Cancer patients, observational study. [pmid: 10512125].
Walcott FL, Hauptmann M, Duphorne CM, et al. A case-control study of dietary phytoestrogens and testicular cancer risk. Nutr Cancer. 2002;44(1):44-51. Cancer patients, observational study. [pmid: 12672640].
Wang MF, Kishi K, Takahashi T, et al. Efficiency of utilization of soy protein isolate in Japanese young men. J Nutr Sci Vitaminol. Apr. 1983;29(2):201-16. No outcomes of interest. [pmid: 6684153].
Wang MF, Yamamoto S, Chung HM, et al. Antihypercholesterolemic effect of undigested fraction of soybean protein in young female volunteers. J Nutr Sci Vitaminol. Apr. 1995;41(2):187-95. N < 10 for lipid outcomes, intervention less than 4 weeks. [pmid: 7562112].
Watanabe S, Haba R, Terashima K, et al. Antioxidant activity of soya hypocotyl tea in humans. Biofactors. 2000;12(14):227-32. No outcomes of interest. [pmid: 11216490].
Weggemans RM, Trautwein EA. Relation between soy-associated isoflavones and LDL and HDL cholesterol concentrations in humans: A meta-analysis. Eur J Clin Nutr. Aug 1. 2003;57(8):940-6. Meta-analysis. [pmid: 12879088].
White LR, Petrovitch H, Ross GW, et al. Brain aging and midlife tofu consumption. J Am Coll Nutr. Apr. 2000;19(2):242-55. No intervention. [pmid: 10763906].
Widhalm K, Kohl S, Hammerle A. The clinical application of two newly developed lipid emulsions (Solipid 20% S&E) in critically ill patients. Infusionsther Transfusionsmed. Feb. 1996;23(1):8-12. Soy derivative not available. [pmid: 8653019].
Wiseman H, O'Reilly JD, Adlercreutz H, et al. Isoflavone phytoestrogens consumed in soy decrease F(2)-isoprostane concentrations and increase resistance of low-density lipoprotein to oxidation in humans. Am J Clin Nutr. Aug. 2000;72(2):395-400. Soy intervention less than 4 weeks. [pmid: 10919933].
Witte JS, Longnecker MP, Bird CL, et al. Relation of vegetable, fruit, and grain consumption to colorectal adenomatous polyps. Am J Epidemiol. Dec 1. 1996;144(11):1015-25. Soy not quantified. [pmid: 8942431].
Witte JS, Ursin G, Siemiatycki J, et al. Diet and premenopausal bilateral breast cancer: a case-control study. Breast Cancer Res Treat. Feb. 1997;42(3):243-51. No soy intervention. [pmid: 9065608].
Wojcicki J, Pawlik A, Samochowiec L, et al. Clinical evaluation of lecithin as a lipid-lowering agent. Phytother Res. 1995;9(8):597-9. Soy derivative not available.
Wolfe BM, Giovannetti PM. Elevation of VLDL-cholesterol during substitution of soy protein for animal protein in diets of hypercholesterolemic Canadians. Nutr Rep Int. 1985;32(5):1057-65. Soy intervention less than 4 weeks.
Wolfe, B., Giovannetti, P. M., Cheng, DCH, Roberts, D. C., and Carroll, K. K. Hypolipidemic Effect Of Substituting Soybean Protein Isolate For All Meat And Dairy Protein In The Diets Of Hypercholesterolemic Men. Nutr Rep Int 24[6], 1187–1198. 1981. Woburn, MA, Butterworth-Heinemann. N < 10 for lipid outcomes.
Woods RK, Walters EH, Raven JM, et al. Food and nutrient intakes and asthma risk in young adults. Am J Clin Nutr. Sep. 2003;78(3):414-21. Observational study. [pmid: 12936923].
Wu AH, Stanczyk FZ, Seow A, et al. Soy intake and other lifestyle determinants of serum estrogen levels among postmenopausal Chinese women in Singapore. Cancer Epidemiol Biomarkers Prev. 2002;11(9):844-51. Cancer patients, observational study. [pmid: 12223428].
Wu AH, Wan P, Hankin J, et al. Adolescent and adult soy intake and risk of breast cancer in Asian-Americans. Carcinogenesis. Sep. 2002;23(9):1491-6. Cancer patients, observational study. [pmid: 12189192].
Wu AH, Yu MC, Tseng CC, et al. Green tea and risk of breast cancer in Asian Americans. Int J Cancer. Sep 10. 2003;106(4):574-9. Cancer patients, observational study. [pmid: 12845655].
Wu AH, Ziegler RG, HornRoss PL, et al. Tofu and risk of breast cancer in Asian-Americans. Cancer Epidemiol Biomarkers Prev. Nov. 1996;5(11):901-6. Cancer patients, observational study. [pmid: 8922298].
Wu AH, Ziegler RG, Nomura AM, et al. Soy intake and risk of breast cancer in Asians and Asian Americans. [Review] [46 refs]. Am J Clin Nutr. Dec. 1998;68(6:Suppl):1437S-43S. Review. [pmid: 9848513].
Wu AH. Soy and risk of hormone-related and other cancers. Adv Exp Med Biol. 2001;492:19-28. Review. [pmid: 11480666].
Xu WH, Zheng W, Xiang YB, et al. Soya food intake and risk of endometrial cancer among Chinese women in Shanghai: population based case-control study. BMJ. May 29. 2004;328(7451):1285. Cancer patients, observational study. [pmid: 15136343]. [pmcid: 420166].
Xu X, Duncan AM, Merz BE, et al. Effects of soy isoflavones on estrogen and phytoestrogen metabolism in premenopausal women. Cancer Epidemiol Biomarkers Prev. Dec. 1998;7(12):1101-8. No outcomes of interest. [pmid: 9865428].
Yamaguchi M, Ono R, Zhong JM. Prolonged intake of isoflavone- and saponincontaining soybean extract (Nijiru) supplement enhances circulating gamma-carboxylated osteocalcin concentrations in healthy individuals. J Health Sci2001;47(6):579–82. CVD study with no control.
Yamakita JI, Yamamoto T, Moriwaki Y, et al. Effect of tofu (bean curd) ingestion on uric acid metabolism in healthy and gouty subjects. Adv Exp Med Biol. 1998;431:839-42. Soy intervention less than 4 weeks. [pmid: 9598181].
Yamamoto S, Sobue T, Kobayashi M, et al. Soy, isoflavones, and breast cancer risk in Japan. J Natl Cancer Inst. Jun 18. 2003;95(12):906-13. Cancer patients, observational study. [pmid: 12813174].
Yang G, Shu XO, Jin F, et al. Soyfood consumption and risk of glycosuria: a cross-sectional study within the Shanghai Women's Health Study. Eur J Clin Nutr. 2004;58(4):615-20. Observational study. [pmid: 15042129].
Young VR, Puig M, Queiroz E, et al. Evaluation of the protein quality of an isolated soy protein in young men: relative nitrogen requirements and effect of methionine supplementation. Am J Clin Nutr. Jan. 1984;39(1):16-24. No outcomes of interest. [pmid: 6537870].
Young VR, Wayler A, Garza C, et al. A long-term metabolic balance study in young men to assess the nutritional quality of an isolated soy protein and beef proteins. Am J Clin Nutr. Jan. 1984;39(1):8-15. No outcomes of interest. [pmid: 6537872].
Yu MC, Mo CC, Chong WX, et al. Preserved foods and nasopharyngeal carcinoma: a case-control study in Guangxi, China. Cancer Research. Apr 1. 1988;48(7):1954-9. Cancer patients, observational study. [pmid: 3349469].
Yuan JM, Wang QS, Ross RK, et al. Diet and breast cancer in Shanghai and Tianjin, China. Br J Cancer. Jun. 1995;71(6):1353-8. Cancer patients, observational study. [pmid: 7779738].
Zanker KS, Daftary GV, Gottschalk G, et al. Genistein and Daidzein: Mode of Action and Bioavailability as Chemopreventive Agents in a Soy-Enriched Diet. Dtsch Z Onkol. 2001;33(2):37-44. CVD study with no control.
Zhang X, Shu XO, Gao YT, et al. Soy food consumption is associated with lower risk of coronary heart disease in Chinese women. J Nutr. Sep. 2003;133(9):2874-8. Observational study. [pmid: 12949380].
Zhuo XG, Melby MK, Watanabe S. Soy isoflavone intake lowers serum LDL cholesterol: a meta-analysis of 8 randomized controlled trials in humans. J Nutr. Sep. 2004;134(9):2395-400. Meta-analysis. [pmid: 15333734].
Zou J, Sun Q, Akiba S, et al. A case-control study of nasopharyngeal carcinoma in the high background radiation areas of Yangjiang, China. J Radiat Res. Oct. 2000;41(Suppl):53-62. Observational study. [pmid: 11142212].