# Bibliography

Adams KF, Newton KM, Chen C, et al. Soy isoflavones do not modulate circulating insulin-like growth factor concentrations in an older population in an intervention trial. J Nutr. May. 2003;133(5):1316-9. [pmid: 12730416].
Akiyama T, Ishida J, Nakagawa S, et al. Genistein, a specific inhibitor of tyrosine-specific protein kinases. J Biol Chem. Apr 25. 1987;262(12):5592-5. [pmid: 3106339].
Albert A, Altabre C, Baro F, et al. Efficacy and safety of a phytoestrogen preparation derived from Glycine max (L.) Merr in climacteric symptomatology: a multicentric, open, prospective and non-randomized trial. Phytomedicine. Mar. 2002;9(2):85-92. [pmid: 11995954].
Albertazzi P, Pansini F, Bonaccorsi G, et al. The effect of dietary soy supplementation on hot flushes. Obstetrics & Gynecology. Jan. 1998;91(1):6-11. [pmid: 9464712].
Albertazzi P, Pansini F, Bottazzi M, et al. Dietary soy supplementation and phytoestrogen levels. Obstetrics & Gynecology. Aug. 1999;94(2):229-31. [pmid: 10432133].
Alekel DL, Germain AS, Peterson CT, et al. Isoflavone-rich soy protein isolate attenuates bone loss in the lumbar spine of perimenopausal women. American Journal of Clinical Nutrition. Sep. 2000;72(3):844-52. [pmid: 10966908].
Allison DB, Gadbury G, Schwartz LG, et al. A novel soy-based meal replacement formula for weight loss among obese individuals: a randomized controlled clinical trial. Eur J Clin Nutr. Apr. 2003;57(4):514-22. [pmid: 12700612].
Allred CD, Allred KF, Ju YH, et al. Soy processing influences growth of estrogen-dependent breast cancer tumors. Carcinogenesis. Sep. 2004;25(9):1649-57. [pmid: 15131010].
Altman DG, Schulz KF, Moher D, et al. The Revised CONSORT Statement for Reporting Randomized Trials: Explanation and Elaboration. Ann Intern Med. 2001;134(8):663-94. [pmid: 11304107].
Anderson JJ, Chen X, Boass A, et al. Soy isoflavones: no effects on bone mineral content and bone mineral density in healthy, menstruating young adult women after one year. J Am Coll Nutr. Oct. 2002;21(5):388-93. [pmid: 12356779].
Anderson JW, Blake JE, Turner J, et al. Effects of soy protein on renal function and proteinuria in patients with type 2 diabetes. Am J Clin Nutr. Dec. 1998;68(6 Suppl):1347S-53S. [pmid: 9848497].
Anderson JW, Johnstone BM, Cook-Newell ME. Meta-analysis of the effects of soy protein intake on serum lipids. N Engl J Med. Aug 3. 1995;333(5):276-82. [pmid: 7596371].
Arjmandi BH, Khalil DA, Smith BJ, et al. Soy protein has a greater effect on bone in postmenopausal women not on hormone replacement therapy, as evidenced by reducing bone resorption and urinary calcium excretion. Journal of Clinical Endocrinology & Metabolism. Mar. 2003;88(3):1048-54. [pmid: 12629084].
Arora A, Nair MG, Strasburg GM. Antioxidant activities of isoflavones and their biological metabolites in a liposomal system. Archives of Biochemistry & Biophysics. Aug 15. 1998;356(2):133-41. [pmid: 9705203].
Ashton EL, Dalais FS, Ball MJ. Effect of meat replacement by tofu on CHD risk factors including copper induced LDL oxidation (UI 11194529). J Am Coll Nutr. Nov. 2000;19(6):761-7. [pmid: 11194529].
Axelson M, Kirk DN, Farrant RD, et al. The identification of the weak oestrogen equol [7-hydroxy-3-(4'-hydroxyphenyl)chroman] in human urine. J Biochem. Feb 1. 1982;201(2):353-7.
Axelson M, Sjovall J, Gustafsson BE, et al. Soya--a dietary source of the non-steroidal oestrogen equol in man and animals. J Endocrinol. Jul. 1984;102(1):49-56. [pmid: 6539804].
Azadbakht L, Shakerhosseini R, Atabak S, et al. Beneficiary effect of dietary soy protein on lowering plasma levels of lipid and improving kidney function in type II diabetes with nephropathy. Eur J Clin Nutr. Oct. 2003;57(10):1292-4. [pmid: 14506491].
Baird DD, Umbach DM, Lansdell L, et al. Dietary intervention study to assess estrogenicity of dietary soy among postmenopausal women. Journal of Clinical Endocrinology & Metabolism. May. 1995;80(5):1685-90. [pmid: 7745019].
Bakhit RM, Klein BP, Essex Sorlie D, et al. Intake of 25 g of soybean protein with or without soybean fiber alters plasma lipids in men with elevated cholesterol concentrations. J Nutr. Feb. 1994;124(2):213-22. [pmid: 8308570].
Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. Jun 12. 2002;287(22):2973-82. [pmid: 12052127].
Balk JL, Whiteside DA, Naus G, et al. A pilot study of the effects of phytoestrogen supplementation on postmenopausal endometrium. J Soc Gynecol Investig. Jul. 2002;9(4):238-42.
Ballantyne JC, Carr DB, deFerranti S, et al. The comparative effects of postoperative analgesic therapies on pulmonary outcome: cumulative meta-analyses of randomized, controlled trials. Anesth Analg. 1998;86(3):598-612. [pmid: 9495424].
Baum JA, Teng H, Erdman JW Jr., et al. Long-term intake of soy protein improves blood lipid profiles and increases mononuclear cell low-density-lipoprotein receptor messenger RNA in hypercholesterolemic, postmenopausal women. American Journal of Clinical Nutrition. Sep. 1998;68(3):545-51. [pmid: 9734729].
Bazzoli DL, Hill S, DiSilvestro RA. Soy protein antioxidant actions in active, young adult women. Nutrition Research. 2002;22(7):807-15.
Bell DSH, Ovalle F. Use of soy protein supplement and resultant need for increased dose of levothyroxine. Endocrine Practice. 2001;7(3):193-4. [pmid: 11421567].
Bennink MR. Dietary soy reduces colon carcinogenesis in human and rats. Soy and colon cancer. Adv Exp Med Biol. 2001;492:11-7. [pmid: 11480660].
Berkey CS, Hoaglin DC, Mosteller F, et al. A random-effects regression model for meta-analysis. Stat Med. 1995;14:395-411. [pmid: 7746979].
Bloedon LT, Jeffcoat AR, Lopaczynski W, et al. Safety and pharmacokinetics of purified soy isoflavones: single-dose administration to postmenopausal women. American Journal of Clinical Nutrition. Nov. 2002;76(5):1126-37. [pmid: 12399289].
Blum A, Lang N, Vigder F, et al. Effects of soy protein on endothelium-dependent vasodilatation and lipid profile in postmenopausal women with mild hypercholesterolemia (UI 12659466). Clinical & Investigative Medicine. Feb. 2003;26(1):20-6. [pmid: 12659466].
Boushey CJ, Beresford SA, Omenn GS, et al. A quantitative assessment of plasma homocysteine as a risk factor for vascular disease. Probable benefits of increasing folic acid intakes. JAMA. Oct 4. 1995;274(13):1049-57. [pmid: 7563456].
Breslau NA, Brinkley L, Hill KD, et al. Relationship of animal protein-rich diet to kidney stone formation and calcium metabolism. Journal of Clinical Endocrinology & Metabolism. Jan. 1988;66(1):140-6. [pmid: 2826524].
Bricarello LP, Kasinski N, Bertolami MC, et al. Comparison between the effects of soy milk and non-fat cow milk on lipid profile and lipid peroxidation in patients with primary hypercholesterolemia. Nutrition. 2004;20(2):200-4. [pmid: 14962687].
Brooks JD, Ward WE, Lewis JE, et al. Supplementation with flaxseed alters estrogen metabolism in postmenopausal women to a greater extent than does supplementation with an equal amount of soy. American Journal of Clinical Nutrition. Feb. 2004;79(2):318-25. [pmid: 14749240].
Brown BD, Thomas W, Hutchins A, et al. Types of dietary fat and soy minimally affect hormones and biomarkers associated with breast cancer risk in premenopausal women. Nutrition & Cancer. 2002;43(1):22-30. [pmid: 12467131].
Bruce B, Messina M, Spiller GA. Isoflavone Supplements Do Not Affect Thyroid Function in Iodine-Replete Postmenopausal Women. Journal of Medicinal Food. 2003;6(4):309-16. [pmid: 14977438].
Brynin R. Soy and its isoflavones: a review of their effects on bone density. Altern Med Rev. Aug. 2002;7(4):317-27. [pmid: 12197783].
Burke BE, Olson RD, Cusack BJ. Randomized, controlled trial of phytoestrogen in the prophylactic treatment of menstrual migraine. Biomedicine & Pharmacotherapy. Aug. 2002;56(6):283-8.
Burke GL, Legault C, Anthony M, et al. Soy protein and isoflavone effects on vasomotor symptoms in peri- and postmenopausal women: the Soy Estrogen Alternative Study. Menopause. Mar. 2003;10(2):147-53. [pmid: 12627040].
Burke V, Hodgson JM, Beilin LJ, et al. Dietary protein and soluble fiber reduce ambulatory blood pressure in treated hypertensives. Hypertension. Oct. 2001;38(4):821-6. [pmid: 11641293].
Busby MG, Jeffcoat AR, Bloedon LT, et al. Clinical characteristics and pharmacokinetics of purified soy isoflavones: single-dose administration to healthy men. American Journal of Clinical Nutrition. Jan. 2002;75(1):126-36. [pmid: 11756070].
Cai Q, Wei H. Effect of dietary genistein on antioxidant enzyme activities in SENCAR mice. Nutrition & Cancer. 1996;25(1):1-7. [pmid: 8837857].
Cambria-Kiely JA. Effect of soy milk on warfarin efficacy. Ann Pharmacother. Dec 1. 2002;36(12):1893-6. [pmid: 12452752].
Capristo E, Mingrone G, Addolorato G, et al. Effect of a vegetable-protein-rich polymeric diet treatment on body composition and energy metabolism in inactive Crohn's disease. Eur J Gastroenterol Hepatol. Jan. 2000;12(1):5-11. [pmid: 10656203].
Carroll KK, Giovannetti PM, Huff MW, et al. Hypocholesterolemic effect of substituting soybean protein for animal protein in the diet of healthy young women. American Journal of Clinical Nutrition. Aug. 1978;31(8):1312-21. [pmid: 567007].
Cassidy A, Bingham S, Setchell K. Biological effects of isoflavones in young women: importance of the chemical composition of soyabean products. Br J Nutr. Oct. 1995;74(4):587-601. [pmid: 7577895].
Cassidy A, Bingham S, Setchell KD. Biological effects of a diet of soy protein rich in isoflavones on the menstrual cycle of premenopausal women. American Journal of Clinical Nutrition. Sep. 1994;60(3):333-40. [pmid: 8074062].
Cassileth BR, Vickers AJ. Soy: an anticancer agent in wide use despite some troubling data. Cancer Invest. 2003;21(5):817-8. [pmid: 14628440].
Chen YM, Ho SC, Lam SS, et al. Soy isoflavones have a favorable effect on bone loss in Chinese postmenopausal women with lower bone mass: a double-blind, randomized, controlled trial. Journal of Clinical Endocrinology & Metabolism. Oct. 2003;88(10):4740-7. [pmid: 14557449].
Chen YM, Ho SC, Lam SS, et al. Beneficial effect of soy isoflavones on bone mineral content was modified by years since menopause, body weight, and calcium intake: a double-blind, randomized, controlled trial. Menopause. May. 2004;11(3):246-54. [pmid: 15167303].
Chiechi LM, Putignano G, Guerra V, et al. The effect of a soy rich diet on the vaginal epithelium in postmenopause: a randomized double blind trial. Maturitas. Aug 20. 2003;45(4):241-6. [pmid: 12927310].
Chiechi LM, Secreto G, D'Amore M, et al. Efficacy of a soy rich diet in preventing postmenopausal osteoporosis: the Menfis randomized trial (UI 12191852). Maturitas. Aug 30. 2002;42(4):295-300. [pmid: 12191852].
Chiechi LM, Secreto G, Vimercati A, et al. The effects of a soy rich diet on serum lipids: the Menfis randomized trial (UI 11836040). Maturitas. Feb 26. 2002;41(2):97-104. [pmid: 11836040].
Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
Crisafulli A, Marini H, Bitto A, et al. Effects of genistein on hot flushes in early postmenopausal women: a randomized, double-blind EPT- and placebo-controlled study. Menopause: The Journal of The North American Menopause Society. 2004;11(4):400-4.
Crouse JR, III, Morgan T, Terry JG, et al. A randomized trial comparing the effect of casein with that of soy protein containing varying amounts of isoflavones on plasma concentrations of lipids and lipoproteins. Arch Intern Med. Sep 27. 1999;159(17):2070-6. [pmid: 10510993].
Cuevas AM, Irribarra VL, Castillo OA, et al. Isolated soy protein improves endothelial function in postmenopausal hypercholesterolemic women. Eur J Clin Nutr. Aug. 2003;57(8):889-94. [pmid: 12879082].
D'Amico G, Gentile MG, Manna G, et al. Effect of vegetarian soy diet on hyperlipidaemia in nephrotic syndrome. Lancet. 1992;339(8802):1131-4. [pmid: 1349366].
Dalais FS, Ebeling PR, Kotsopoulos D, et al. The effects of soy protein containing isoflavones on lipids and indices of bone resorption in postmenopausal women. Clin Endocrinol (Oxf). Jun. 2003;58(6):704-9. [pmid: 12780746].
Dalais FS, Rice GE, Wahlqvist ML, et al. Effects of dietary phytoestrogens in postmenopausal women. Climacteric. Jun. 1998;1(2):124-9. [pmid: 11907915].
Davis JN, Kucuk O, Djuric Z, et al. Soy isoflavone supplementation in healthy men prevents NF-kappaB activation by TNF-a in blood lymphocytes. Free Radical Biology & Medicine. Jun 1. 2001;30(11):1293-302. [pmid: 11368927].
Davis JN, Kucuk O, Sarkar FH. Expression of prostate-specific antigen is transcriptionally regulated by genistein in prostate cancer cells. Mol Carcinog. Jun. 2002;34(2):91-101. [pmid: 12112315].
Dent SB, Peterson CT, Brace LD, et al. Soy protein intake by perimenopausal women does not affect circulating lipids and lipoproteins or coagulation and fibrinolytic factors. J Nutr. Sep. 2001;131(9):2280-7. [pmid: 11533267].
DeVere White RW, Hackman RM, Soares SE, et al. Effects of a genistein-rich extract on PSA levels in men with a history of prostate cancer. Urology. Feb. 2004;63(2):259-63. [pmid: 14972467].
Dewell A, Hollenbeck CB, Bruce B. The effects of soy-derived phytoestrogens on serum lipids and lipoproteins in moderately hypercholesterolemic postmenopausal women. Journal of Clinical Endocrinology & Metabolism. Jan. 2002;87(1):118-21. [pmid: 11788633].
Djuric Z, Chen G, Doerge DR, et al. Effect of soy isoflavone supplementation on markers of oxidative stress in men and women. Cancer Lett. Oct 22. 2001;172(1):1-6. [pmid: 11595123].
Dogan E, Posaci C. Monitoring hormone replacement therapy by biochemical markers of bone metabolism in menopausal women. Postgrad Med J. Dec. 2002;78(926):727-31. [pmid: 12509689]. [pmcid: 1757944].
Dragan I, Stroescu V, Stoian I, et al. Studies regarding the efficiency of Supro isolated soy protein in Olympic athletes. Revue Roumaine de Physiologie. Jul. 1992;29(34):63-70. [pmid: 1306084].
Duffy R, Wiseman H, File SE. Improved cognitive function in postmenopausal women after 12 weeks of consumption of a soya extract containing isoflavones. Pharmacology, Biochemistry & Behavior. Jun. 2003;75(3):721-9.
Duncan AM, Merz BE, Xu X, et al. Soy isoflavones exert modest hormonal effects in premenopausal women (UI 9920082). Journal of Clinical Endocrinology & Metabolism. Jan. 1999;84(1):192-7. [pmid: 9920082].
Duncan AM, Underhill KE, Xu X, et al. Modest hormonal effects of soy isoflavones in postmenopausal women (UI 10522983). Journal of Clinical Endocrinology & Metabolism. Oct. 1999;84(10):3479-84. [pmid: 10522983].
Faure ED, Chantre P, Mares P. Effects of a standardized soy extract on hot flushes: a multicenter, double-blind, randomized, placebo-controlled study. Menopause. Sep. 2002;9(5):329-34. [pmid: 12218721].
File SE, Jarrett N, Fluck E, et al. Eating soya improves human memory. Psychopharmacology (Berl). Oct. 2001;157(4):430-6. [pmid: 11605103].
Foth D, Nawroth F. Effect of soy supplementation on endogenous hormones in postmenopausal women. Gynecologic & Obstetric Investigation. 2003;55(3):135-8. [pmid: 12865591].
Fritz WA, Coward L, Wang J, et al. Dietary genistein: perinatal mammary cancer prevention, bioavailability and toxicity testing in the rat. Carcinogenesis 1998;(12):2151-8.
Gaddi A, Ciarrocchi A, Matteucci A, et al. Dietary treatment for familial hypercholesterolemia - differential effects of dietary soy protein according to the apolipoprotein E phenotypes. American Journal of Clinical Nutrition. 1991;53(5):1191-6. [pmid: 1902348].
Gallagher JC, Satpathy R, Rafferty K, et al. The effect of soy protein isolate on bone metabolism. Menopause. May. 2004;11(3):290-8. [pmid: 15167308].
Gardner CD, Newell KA, Cherin R, et al. The effect of soy protein with or without isoflavones relative to milk protein on plasma lipids in hypercholesterolemic postmenopausal women. American Journal of Clinical Nutrition. Apr. 2001;73(4):728-35. [pmid: 11273847].
Gardner-Thorpe D, O'Hagen C, Young I, et al. Dietary supplements of soya flour lower serum testosterone concentrations and improve markers of oxidative stress in men. Eur J Clin Nutr. Jan. 2003;57(1):100-6. [pmid: 12548304].
Gentile MG, Fellin G, Cofano F, et al. Treatment of proteinuric patients with a vegetarian soy diet and fish oil. Clin Nephrol. Dec. 1993;40(6):315-20. [pmid: 8299238].
Goldberg AP, Lim A, Kolar JB. Soybean protein independently lowers plasma cholesterol levels in primary hypercholesterolemia. Atherosclerosis. 1982;43(23):355-68. [pmid: 6889432].
Gooderham MH, Adlercreutz H, Ojala ST, et al. A soy protein isolate rich in genistein and daidzein and its effects on plasma isoflavone concentrations, platelet aggregation, blood lipids and fatty acid composition of plasma phospholipid in normal men. J Nutr. Aug. 1996;126(8):2000-6. [pmid: 8759372].
Grady D, Herrington D, Bittner V, et al. Cardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. Jul 3. 2002;288(1):49-57. [pmid: 12090862].
Gruber CJ, Tschugguel W, Schneeberger C, et al. Production and actions of estrogens. N Engl J Med. Jan 31. 2002;346(5):340-52. [pmid: 11821512].
Gunn RA, Taylor PR, Gangarosa EJ. Gastrointestinal illness associated with consumption of a soy protein extender. J Food Prot. 1980;43(7):525-7.
Habito RC, Montalto J, Leslie E, et al. Effects of replacing meat with soyabean in the diet on sex hormone concentrations in healthy adult males. Br J Nutr. Oct. 2000;84(4):557-63. [pmid: 11103227].
Ham JO, Chapman KM, Essex Sorlie D, et al. Endocrinological response to soy protein and fiber in mildly hypercholesterolemic men. Nutrition Research. 1993;13(8):873-84.
Han KK, Soares JM Jr., Haidar MA, et al. Benefits of soy isoflavone therapeutic regimen on menopausal symptoms. Obstetrics & Gynecology. Mar. 2002;99(3):389-94. [pmid: 11864664].
Hargreaves DF, Potten CS, Harding C, et al. Two-week dietary soy supplementation has an estrogenic effect on normal premenopausal breast. Journal of Clinical Endocrinology & Metabolism. Nov. 1999;84(11):4017-24. [pmid: 10566643].
Harris RM, Wood DM, Bottomley L, et al. Phytoestrogens are potent inhibitors of estrogen sulfation: implications for breast cancer risk and treatment. Journal of Clinical Endocrinology & Metabolism. Apr. 2004;89(4):1779-87. [pmid: 15070945].
Henkel J. Soy: Health Claims for Soy Protein, Questions About Other Components. FDA Consumer magazine 34[3]. 2000.
Hermansen K, Sondergaard M, Hoie L, et al. Beneficial effects of a soy-based dietary supplement on lipid levels and cardiovascular risk markers in type 2 diabetic subjects. Diabetes Care. Feb. 2001;24(2):228-33. [pmid: 11213870].
Hsu CS, Shen WW, Hsueh YM, et al. Soy isoflavone supplementation in postmenopausal women: Effects on plasma lipids, antioxidant enzyme activities and bone density. Journal of Reproductive Medicine for the Obstetrician & Gynecologist Vol 46(3)()(pp 221–226), 2001 2001;(3):221–6.
Huff MW, Giovannetti PM, Wolfe BM. Turnover of very low-density lipoprotein-apoprotein B is increased by substitution of soybean protein for meat and dairy protein in the diets of hypercholesterolemic men. American Journal of Clinical Nutrition. Jun. 1984;39(6):888-97. [pmid: 6539062].
Jayagopal V, Albertazzi P, Kilpatrick ES, et al. Beneficial effects of soy phytoestrogen intake in postmenopausal women with type 2 diabetes. Diabetes Care. Oct. 2002;25(10):1709-14. [pmid: 12351466].
Jenkins DJ, Kendall CW, Connelly PW, et al. Effects of high- and low-isoflavone (phytoestrogen) soy foods on inflammatory biomarkers and proinflammatory cytokines in middle-aged men and women (UI 12077742). Metabolism: Clinical & Experimental. Jul. 2002;51(7):919-24. [pmid: 12077742].
Jenkins DJ, Kendall CW, Garsetti M, et al. Effect of soy protein foods on low-density lipoprotein oxidation and ex vivo sex hormone receptor activity--a controlled crossover trial (UI 10778882). Metabolism: Clinical & Experimental. Apr. 2000;49(4):537-43. [pmid: 10778882].
Jenkins DJ, Kendall CW, Jackson CJ, et al. Effects of high- and low-isoflavone soyfoods on blood lipids, oxidized LDL, homocysteine, and blood pressure in hyperlipidemic men and women (UI 12145008). American Journal of Clinical Nutrition. Aug. 2002;76(2):365-72. [pmid: 12145008].
Jenkins DJ, Kendall CW, Mehling CC, et al. Combined effect of vegetable protein (soy) and soluble fiber added to a standard cholesterol-lowering diet. Metabolism: Clinical & Experimental. Jun. 1999;48(6):809-16. [pmid: 10381159].
Jenkins DJ, Kendall CW, Vidgen E, et al. The effect on serum lipids and oxidized low-density lipoprotein of supplementing self-selected low-fat diets with soluble-fiber, soy, and vegetable protein foods (UI 10647066). Metabolism: Clinical & Experimental. Jan. 2000;49(1):67-72. [pmid: 10647066].
Jenkins DJ, Wolever TM, Spiller G, et al. Hypocholesterolemic effect of vegetable protein in a hypocaloric diet. Atherosclerosis. Aug. 1989;78(23):99-107. [pmid: 2783209].
Jenkins DJA, Kendall CWC, D'Costa MA, et al. Soy consumption and phytoestrogens: Effect on serum prostate specific antigen when blood lipids and oxidized low-density lipoprotein are reduced in hyperlipidemic men. J Urol. Feb 1. 2003;169(2):507-11. [pmid: 12544298].
Jones G, Dwyer T, Hynes K, et al. A randomized controlled trial of phytoestrogen supplementation, growth and bone turnover in adolescent males. European Journal of Clinical Nutrition. Feb. 2003;57(2):324-7. [pmid: 12571667].
Kanazawa T, Osanai T, Zhang XS, et al. Protective effects of soy protein on the peroxidizability of lipoproteins in cerebrovascular diseases. J Nutr. Mar. 1995;125(3:Suppl):639S-46S. [pmid: 7884546].
Katsuyama H, Ideguchi S, Fukunaga M, et al. Promotion of bone formation by fermented soybean (Natto) intake in premenopausal women. Journal of Nutritional Science & Vitaminology. Apr. 2004;50(2):114-20. [pmid: 15242015].
Key TJ, Sharp GB, Appleby PN, et al. Soya foods and breast cancer risk: a prospective study in Hiroshima and Nagasaki, Japan. Br J Cancer. Dec. 1999;81(7):1248-56. [pmid: 10584890].
Khalil DA, Lucas EA, Juma S, et al. Soy protein supplementation increases serum insulin-like growth factor-I in young and old men but does not affect markers of bone metabolism. J Nutr. Sep. 2002;132(9):2605-8. [pmid: 12221217].
Kim H, Peterson TG, Barnes S. Mechanisms of action of the soy isoflavone genistein: emerging role for its effects via transforming growth factor beta signaling pathways. American Journal of Clinical Nutrition. Dec. 1998;68(6 Suppl):1418S-25S. [pmid: 9848510].
Knight DC, Eden JA. A review of the clinical effects of phytoestrogens. Obstetrics & Gynecology. May. 1996;87(5 Pt 2):897-904. [pmid: 8677131].
Knight DC, Howes JB, Eden JA, et al. Effects on menopausal symptoms and acceptability of isoflavone-containing soy powder dietary supplementation. Climacteric. Mar. 2001;4(1):13-8. [pmid: 11379373].
Kotsopoulos D, Dalais FS, Liang YL, et al. The effects of soy protein containing phytoestrogens on menopausal symptoms in postmenopausal women. Climacteric. Sep. 2000;3(3):161-7. [pmid: 11910617].
Kreijkamp-Kaspers S, Kok L, Bots ML, et al. Randomized controlled trial of the effects of soy protein containing isoflavones on vascular function in postmenopausal women. American Journal of Clinical Nutrition. Jan. 2005;81(1):189-95. [pmid: 15640479].
Kreijkamp-Kaspers S, Kok L, Grobbee DE, et al. Effect of soy protein containing isoflavones on cognitive function, bone mineral density, and plasma lipids in postmenopausal women: a randomized controlled trial. JAMA. Jul 7. 2004;292(1):65-74. [pmid: 15238592].
Kritz-Silverstein D, Von Muhlen D, Barrett-Connor E, et al. Isoflavones and cognitive function in older women: the SOy and Postmenopausal Health In Aging (SOPHIA) Study. Menopause. May. 2003;10(3):196-202. [pmid: 12792289].
Kumar NB, Cantor A, Allen K, et al. The specific role of isoflavones on estrogen metabolism in premenopausal women. Cancer. Feb 15. 2002;94(4):1166-74. [pmid: 11920488]. [pmcid: 2377415].
Kurowska EM, Jordan J, Spence JD, et al. Effects of substituting dietary soybean protein and oil for milk protein and fat in subjects with hypercholesterolemia. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. Jun. 1997;20(3):162-70. [pmid: 9189647].
Laskowski R, Antosiewicz J. Increased adaptability of young judo sportsmen after protein supplementation. Journal of Sports Medicine & Physical Fitness. Sep. 2003;43(3):342-6. [pmid: 14625516].
Lenn J, Uhl T, Mattacola C, et al. The effects of fish oil and isoflavones on delayed onset muscle soreness. Medicine & Science in Sports & Exercise. Oct. 2002;34(10):1605-13. [pmid: 12370562].
Lichtenstein AH, Jalbert SM, Adlercreutz H, et al. Lipoprotein response to diets high in soy or animal protein with and without isoflavones in moderately hypercholesterolemic subjects. Arteriosclerosis, Thrombosis & Vascular Biology. Nov 1. 2002;22(11):1852-8.
Linassier C, Pierre M, Le Pecq JB, et al. Mechanisms of action in NIH-3T3 cells of genistein, an inhibitor of EGF receptor tyrosine kinase activity. Biochem Pharmacol. Jan 1. 1990;39(1):187-93. [pmid: 2153378].
Lissin LW, Oka R, Lakshmi S, et al. Isoflavones improve vascular reactivity in post-menopausal women with hypercholesterolemia. Vasc Med. Feb. 2004;9(1):26-30. [pmid: 15230485].
Liu J, Burdette JE, Xu H, et al. Evaluation of estrogenic activity of plant extracts for the potential treatment of menopausal symptoms. Journal of Agricultural & Food Chemistry. May. 2001;49(5):2472-9. [pmid: 11368622].
Lu LJ, Anderson KE, Grady JJ, et al. Decreased ovarian hormones during a soya diet: implications for breast cancer prevention. Cancer Res. Aug 1. 2000;60(15):4112-21. [pmid: 10945618].
Lu LJ, Anderson KE, Grady JJ, et al. Effects of an isoflavone-free soy diet on ovarian hormones in premenopausal women. Journal of Clinical Endocrinology & Metabolism. Jul. 2001;86(7):3045-52. [pmid: 11443166].
Lu LJW, Anderson KE, Grady JJ, et al. Effects of soya consumption for one month on steroid hormones in premenopausal women: Implications for breast cancer risk reduction. Cancer Epidemiology, Biomarkers & Prevention. 1996;5(1):63-70.
Luijten M, Thomsen AR, van den Berg JA, et al. Effects of soy-derived isoflavones and a high-fat diet on spontaneous mammary tumor development in Tg.NK (MMTV/c-neu) mice. Nutrition & Cancer. 2004;50(1):46-54. [pmid: 15572297].
Luz LJW, Cree M, Josyula S, et al. Increased urinary excretion of 2-hydroxyestrone but not 16alpha- hydroxyestrone in premenopausal women during a soya diet containing isoflavones. Cancer Res. 2000;60(5):1299-305. [pmid: 10728690].
Lydeking-Olsen E, Beck-Jensen JE, Setchell KD, et al. Soymilk or progesterone for prevention of bone loss: A 2 year randomized, placebo-controlled trial. Eur J Nutr. Aug. 2004;43(4):246-57. [pmid: 15309425].
Mackey R, Ekangaki A, Eden JA. The effects of soy protein in women and men with elevated plasma lipids. Biofactors. 2000;12(14):251-7. [pmid: 11216493].
Maki KC, Dicklin MR, Cyrowski M, et al. Improved calcium absorption from a newly formulated beverage compared with a calcium carbonate tablet. Nutrition Research. 2002;22(10):1163-76.
Martini MC, Dancisak BB, Haggans CJ, et al. Effects of soy intake on sex hormone metabolism in premenopausal women. Nutrition & Cancer. 1999;34(2):133-9. [pmid: 10578479].
Maskarinec G, Franke AA, Williams AE, et al. Effects of a 2-year randomized soy intervention on sex hormone levels in premenopausal women. Cancer Epidemiology, Biomarkers & Prevention. Nov. 2004;13(11Pt 1):1736-44.
Maskarinec G, Williams AE, Carlin L. Mammographic densities in a one-year isoflavone intervention. Eur J Cancer Prev. Apr. 2003;12(2):165-9. [pmid: 12671541].
Maskarinec G, Williams AE, Inouye JS, et al. A randomized isoflavone intervention among premenopausal women. Cancer Epidemiology, Biomarkers & Prevention. Feb. 2002;11(2):195-201.
McMichael Phillips DF, Harding C, Morton M, et al. Effects of soy-protein supplementation on epithelial proliferation in the histologically normal human breast. American Journal of Clinical Nutrition. Dec. 1998;68(6:Suppl):1431S-5S. [pmid: 9848512].
Medic Ristic D. , Ristic V, Tepsic V, et al. Effect of soybean Leci-Vita product on serum lipids and fatty acid composition in patients with elevated serum cholesterol and triglyceride levels. Nutrition Research. Apr 1. 2003;23(4):465-77.
Meinertz H, Faergeman O, Nilausen K, et al. Effects of soy protein and casein in low cholesterol diets on plasma lipoproteins in normolipidemic subjects. Atherosclerosis. 1988;72(1):63-70. [pmid: 3214460].
Meinertz H, Nilausen K, Faergeman O. Soy protein and casein in cholesterol-enriched diets: effects on plasma lipoproteins in normolipidemic subjects. American Journal of Clinical Nutrition. Oct. 1989;50(4):786-93. [pmid: 2801583].
Meinertz H, Nilausen K, Hilden J. Alcohol-extracted, but not intact, dietary soy protein lowers lipoprotein(a) markedly. Arteriosclerosis, Thrombosis & Vascular Biology. Feb 1. 2002;22(2):312-6.
Merz-Demlow BE, Duncan AM, Wangen KE, et al. Soy isoflavones improve plasma lipids in normocholesterolemic, premenopausal women. American Journal of Clinical Nutrition. Jun. 2000;71(6):1462-9. [pmid: 10837286].
Meyer BJ, Larkin TA, Owen AJ, et al. Limited lipid-lowering effects of regular consumption of whole soybean foods. Annals of Nutrition & Metabolism. 2004;48(2):67-78. [pmid: 14679315].
Mishra SI, Dickerson V, Najm W. Phytoestrogens and breast cancer prevention: what is the evidence?. American Journal of Obstetrics & Gynecology. May. 2003;188(5 Suppl):S66-S70. [pmid: 12748453].
Mitchell JH, Cawood E, Kinniburgh D, et al. Effect of a phytoestrogen food supplement on reproductive health in normal males. Clin Sci. Jun. 2001;100(6):613-8. [pmid: 11352776].
Moher D, Schulz KF, Altman DG, et al. The CONSORT Statement: Revised Recommendations for Improving the Quality of Reports of Parallel-Group Randomized Trials. Ann Intern Med. 2001;134(8):657-62. [pmid: 11304106].
Morabito N, Crisafulli A, Vergara C, et al. Effects of genistein and hormone-replacement therapy on bone loss in early postmenopausal women: a randomized double-blind placebo-controlled study. Journal of Bone & Mineral Research. Oct. 2002;17(10):1904-12. [pmid: 12369794].
Murata M, Midorikawa K, Koh M, et al. Genistein and daidzein induce cell proliferation and their metabolites cause oxidative DNA damage in relation to isoflavone-induced cancer of estrogen-sensitive organs. Biochemistry (Mosc). Mar 9. 2004;43(9):2569-77.
Murkies AL, Lombard C, Strauss BJ, et al. Dietary flour supplementation decreases post-menopausal hot flushes: effect of soy and wheat. Maturitas. Apr. 1995;21(3):189-95. [pmid: 7616867].
Murray MJ, Meyer WR, Lessey BA, et al. Soy protein isolate with isoflavones does not prevent estradiol-induced endometrial hyperplasia in postmenopausal women: a pilot trial. Menopause. Sep. 2003;10(5):456-64. [pmid: 14501608].
Murrill WB, Brown NM, Zhang JX, et al. Prepubertal genistein exposure suppresses mammary cancer and enhances gland differentiation in rats. Carcinogenesis. Jul. 1996;17(7):1451-7. [pmid: 8706248].
Nagata C, Takatsuka N, Inaba S, et al. Effect of soymilk consumption on serum estrogen concentrations in premenopausal Japanese women. J Natl Cancer Inst. Dec 2. 1998;90(23):1830-5. [pmid: 9839524].
Nagata C, Takatsuka N, Shimizu H, et al. Effect of soymilk consumption on serum estrogen and androgen concentrations in Japanese men. Cancer Epidemiology, Biomarkers & Prevention. Mar. 2001;10(3):179-84.
National Cholesterol Education Program (NCEP) Expert Panel on Detection Evaluation and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circlulation. 2002;106(25):3143-421.
National Kidney Foundation. K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Kidney Disease Outcome Quality Initiative. American Journal of Kidney Diseases 2002 Feb;39(2:Suppl 2):Suppl-246.
Nestel PJ, Yamashita T, Sasahara T, et al. Soy isoflavones improve systemic arterial compliance but not plasma lipids in menopausal and perimenopausal women. Arteriosclerosis, Thrombosis & Vascular Biology. Dec. 1997;17(12):3392-8.
Nikander E, Metsa Heikkila M, Tiitinen A, et al. Evidence of a lack of effect of a phytoestrogen regimen on the levels of C-reactive protein, E-selectin, and nitrate in postmenopausal women (UI 14602747). Journal of Clinical Endocrinology & Metabolism. Nov. 2003;88(11):5180-5. [pmid: 14602747].
Nikander E, Metsa Heikkila M, Ylikorkala O, et al. Effects of phytoestrogens on bone turnover in postmenopausal women with a history of breast cancer (UI 15001611). Journal of Clinical Endocrinology & Metabolism. Mar. 2004;89(3):1207-12. [pmid: 15001611].
Nikander E, Tiitinen A, Laitinen K, et al. Effects of isolated isoflavonoids on lipids, lipoproteins, insulin sensitivity, and ghrelin in postmenopausal women (UI 15240647). Journal of Clinical Endocrinology & Metabolism. Jul. 2004;89(7):3567-72. [pmid: 15240647].
Nilausen K, Meinertz H. Lipoprotein(a) and dietary proteins: casein lowers lipoprotein(a) concentrations as compared with soy protein. American Journal of Clinical Nutrition. Mar. 1999;69(3):419-25. [pmid: 10075325].
Okura A, Arakawa H, Oka H, et al. Effect of genistein on topoisomerase activity and on the growth of [Val 12]Ha-ras-transformed NIH 3T3 cells. Biochem Biophys Res Commun. Nov 30. 1988;157(1):183-9. [pmid: 2848517].
Onning G, Akesson B, Oste R, et al. Effects of consumption of oat milk, soya milk, or cow's milk on plasma lipids and antioxidative capacity in healthy subjects. Annals of Nutrition & Metabolism. 1998;42(4):211-20. [pmid: 9745107].
Paganini-Hill A, Henderson VW. Estrogen deficiency and risk of Alzheimer's disease in women. Am J Epidemiol. Aug 1. 1994;140(3):256-61. [pmid: 8030628].
Pap A, Berger Z, Varro V. Beneficial effect of a soy flour diet in chronic pancreatitis. Mt Sinai J Med. 1983;50(33):208-12. [pmid: 6312297].
Pap A, Berger Z, Varro V. Complementary effect of cholecystokinin-octapeptide and soy flour treatment in chronic pancreatitis. Mt Sinai J Med. 1984;51(3):254-7. [pmid: 6087129].
Penotti M, Fabio E, Modena AB, et al. Effect of soy-derived isoflavones on hot flushes, endometrial thickness, and the pulsatility index of the uterine and cerebral arteries. Fertility & Sterility. May 1. 2003;79(5):1112-7. [pmid: 12738504].
Persky VW, Turyk ME, Wang L, et al. Effect of soy protein on endogenous hormones in postmenopausal women. American Journal of Clinical Nutrition. Jan. 2002;75(1):145-53. [pmid: 11756072].
Pesciatini F, Cefis M, Lazzaroni A. Treatment of dyslipidaemia with a simple low fat diet and with a combination of a low fat diet and a formulation containing soybean protein. International Journal of Clinical Pharmacology Research. 1985;5(3):199-204. [pmid: 4018955].
Petrakis NL, Barnes S, King EB, et al. Stimulatory influence of soy protein isolate on breast secretion in pre- and postmenopausal women. Cancer Epidemiology, Biomarkers & Prevention. Oct. 1996;5(10):785-94.
Petri NE, Nahas NJ, De Luca L, et al. Benefits of soy germ isoflavones in postmenopausal women with contraindication for conventional hormone replacement therapy. Maturitas. Aug 20. 2004;48(4):372-80. [pmid: 15283929].
Potter SM, Bakhit RM, Essex Sorlie DL, et al. Depression of plasma cholesterol in men by consumption of baked products containing soy protein. American Journal of Clinical Nutrition. 1993;58(4):501-6. [pmid: 8379506].
Potter SM, Baum JA, Teng H, et al. Soy protein and isoflavones: their effects on blood lipids and bone density in postmenopausal women. American Journal of Clinical Nutrition. Dec. 1998;68(6:Suppl):1375S-9S. [pmid: 9848502].
Pouilles JM, Tremollieres F, Ribot C. Effect of menopause on femoral and vertebral bone loss. Journal of Bone & Mineral Research. Oct. 1995;10(10):1531-6. [pmid: 8686509].
Puska P, Korpelainen V, Hoie LH, et al. Soy in hypercholesterolaemia: a double-blind, placebo-controlled trial. Eur J Clin Nutr. Apr. 2002;56(4):352-7. [pmid: 11965512].
Puska P, Korpelainen V, Hoie LH, et al. Isolated soya protein with standardised levels of isoflavones, cotyledon soya fibres and soya phospholipids improves plasma lipids in hypercholesterolaemia: a double-blind, placebo-controlled trial of a yoghurt formulation. Br J Nutr. Mar. 2004;91(3):393-401. [pmid: 15005825].
Quella SK, Loprinzi CL, Barton DL, et al. Evaluation of soy phytoestrogens for the treatment of hot flashes in breast cancer survivors: A North Central Cancer Treatment Group Trial. J Clin Oncol. Mar. 2000;18(5):1068-74. [pmid: 10694559].
Ridker PM. High-sensitivity C-reactive protein, inflammation, and cardiovascular risk: from concept to clinical practice to clinical benefit. Am Heart J. Jul. 2004;148(1 Suppl):S19-26. [pmid: 15211329].
Ridker PM, Hennekens CH, Rifai N, et al. Hormone replacement therapy and increased plasma concentration of C-reactive protein. Circulation. Aug 17. 1999;100(7):713-6. [pmid: 10449692].
Riggs BL, Khosla S, Melton LJ, III. A unitary model for involutional osteoporosis: estrogen deficiency causes both type I and type II osteoporosis in postmenopausal women and contributes to bone loss in aging men. J Bone Miner Res. May. 1998;13(5):763-73. [pmid: 9610739].
Rivas M, Garay RP, Escanero JF, et al. Soy milk lowers blood pressure in men and women with mild to moderate essential hypertension. J Nutr. Jul. 2002;132(7):1900-2. [pmid: 12097666].
Ross JA, Davies SM, Wentzlaff KA, et al. Dietary modulation of serum platelet-derived growth factor-AB levels. Cancer Epidemiology, Biomarkers & Prevention. Jul. 1995;4(5):485-9.
Rossi AL, Blostein Fujii A, DiSilvestro RA. Soy beverage consumption by young men: Increased plasma total antioxidant status and decreased acute, exercise-induced muscle damage. Journal of Nutraceuticals, Functional & Medical Foods. 2000;3(1):33-44.
Ruiz Larrea MB, Mohan AR, Paganga G, et al. Antioxidant activity of phytoestrogenic isoflavones. Free Radic Res. Jan. 1997;26(1):63-70. [pmid: 9018473].
Russo R, Corosu R. The clinical use of a preparation based on phyto-oestrogens in the treatment of menopausal disorders. Acta Biomed Ateneo Parmense. Dec. 2003;74(3):137-43. [pmid: 15055018].
Sagara M, Kanda T, Njelekera M, et al. Effects of dietary intake of soy protein and isoflavones on cardiovascular disease risk factors in high risk, middle-aged men in Scotland. J Am Coll Nutr. Feb. 2004;23(1):85-91. [pmid: 14963058].
Saxena R, Choudhry VP, Mishra DK, et al. Clinico-haematological profile of isolated PF3 availability defect: Therapeutic potential of soya bean - A pilot study. Eur J Haematol. 1999;62(5):327-31. [pmid: 10359061].
Scambia G, Mango D, Signorile PG, et al. Clinical effects of a standardized soy extract in postmenopausal women: a pilot study. Menopause. Mar. 2000;7(2):105-11. [pmid: 10746892].
Scheiber MD, Liu JH, Subbiah MT, et al. Dietary inclusion of whole soy foods results in significant reductions in clinical risk factors for osteoporosis and cardiovascular disease in normal postmenopausal women. Menopause. Sep. 2001;8(5):384-92. [pmid: 11528367].
Schweizer TF, Bekhechi AR, Koellreutter B, et al. Metabolic effects of dietary fiber from dehulled soybeans in humans. American Journal of Clinical Nutrition. Jul. 1983;38(1):1-11. [pmid: 6305183].
Secreto G, Chiechi LM, Amadori A, et al. Soy isoflavones and melatonin for the relief of climacteric symptoms: A multicenter, double-blind, randomized study. Maturitas. Jan 20. 2004;47(1):11-20. [pmid: 14706761].
Setchell KD, Brown NM, Lydeking Olsen E. The clinical importance of the metabolite equol-a clue to the effectiveness of soy and its isoflavones. J Nutr. Dec. 2002;132(12):3577-84. [pmid: 12468591].
Shige H, Ishikawa T, Higashi K, et al. Effects of soy protein isolate (SPI) and casein on the postprandial lipemia in normolipidemic men. Journal of Nutritional Science & Vitaminology Vol 44(1)()(pp 113–127), 1998 1998;(1):113–27.
Shorey RL, Bazan B, Lo GS, et al. Determinants of hypocholesterolemic response to soy and animal protein-based diets. American Journal of Clinical Nutrition. Sep. 1981;34(9):1769-78. [pmid: 7197116].
Simons LA, von Konigsmark M, Simons J, et al. Phytoestrogens do not influence lipoprotein levels or endothelial function in healthy, postmenopausal women. Am J Cardiol. Jun 1. 2000;85(11):1297-301. [pmid: 10831943].
Sirtori CR, Agradi E, Conti F, et al. Soybean-protein diet in the treatment of type-II hyperlipoproteinaemia. Lancet. Feb 5. 1977;1(8006):275-7. [pmid: 64804].
Sirtori CR, Bosisio R, Pazzucconi F, et al. Soy milk with a high glycitein content does not reduce low-density lipoprotein cholesterolemia in type II hypercholesterolemic patients. Annals of Nutrition & Metabolism. 2002;46(2):88-92. [pmid: 12011578].
Sirtori CR, Pazzucconi F, Colombo L, et al. Double-blind study of the addition of high-protein soya milk v. cows' milk to the diet of patients with severe hypercholesterolaemia and resistance to or intolerance of statins. Br J Nutr. Aug. 1999;82(2):91-6. [pmid: 10743480].
Sirtori CR, Zucchi Dentone C, Sirtori M. Cholesterol-lowering and HDL-raising properties of lecithinate soy proteins in type II hyperlipidemic patients. Annals of Nutrition & Metabolism. 1985;29(6):348-57. [pmid: 4062245].
Squadrito F, Altavilla D, Crisafulli A, et al. Effect of genistein on endothelial function in postmenopausal women: a randomized, double-blind, controlled study. Am J Med. Apr 15. 2003;114(6):470-6. [pmid: 12727580].
Squadrito F, Altavilla D, Morabito N, et al. The effect of the phytoestrogen genistein on plasma nitric oxide concentrations, endothelin-1 levels and endothelium dependent vasodilation in postmenopausal women. Atherosclerosis. Aug. 2002;163(2):339-47. [pmid: 12052481].
St Germain A, Peterson CT, Robinson JG, et al. Isoflavone-rich or isoflavone-poor soy protein does not reduce menopausal symptoms during 24 weeks of treatment. Menopause. Jan. 2001;8(1):17-26. [pmid: 11201510].
Stamler J, Caggiula A, Grandits GA, et al. Relationship to blood pressure of combinations of dietary macronutrients. Findings of the Multiple Risk Factor Intervention Trial (MRFIT). Circulation. Nov 15. 1996;94(10):2417-23. [pmid: 8921782].
Stamler J, Elliott P, Kesteloot H, et al. Inverse relation of dietary protein markers with blood pressure. Findings for 10,020 men and women in the INTERSALT Study. INTERSALT Cooperative Research Group. INTERnational study of SALT and blood pressure. Circulation. Oct 1. 1996;94(7):1629-34. [pmid: 8840854].
Steinberg FM, Guthrie NL, Villablanca AC, et al. Soy protein with isoflavones has favorable effects on endothelial function that are independent of lipid and antioxidant effects in healthy postmenopausal women. American Journal of Clinical Nutrition. Jul. 2003;78(1):123-30. [pmid: 12816781].
Stroescu V, Dragan J, Simionescu L, et al. Hormonal and metabolic response in elite female gymnasts undergoing strenuous training and supplementation with SUPRO Brand Isolated Soy Protein. Journal of Sports Medicine & Physical Fitness. Mar. 2001;41(1):89-94. [pmid: 11317154].
Swain JH, Alekel DL, Dent SB, et al. Iron indexes and total antioxidant status in response to soy protein intake in perimenopausal women. American Journal of Clinical Nutrition. Jul. 2002;76(1):165-71. [pmid: 12081830].
Takatsuka N, Nagata C, Kurisu Y, et al. Hypocholesterolemic effect of soymilk supplementation with usual diet in premenopausal normolipidemic Japanese women. Prev Med. Oct. 2000;31(4):308-14. [pmid: 11006055].
Takimoto CH, Glover K, Huang X, et al. Phase I pharmacokinetic and pharmacodynamic analysis of unconjugated soy isoflavones administered to individuals with cancer. Cancer Epidemiology, Biomarkers & Prevention. Nov. 2003;12(11:Pt 1):1213-21.
Teede HJ, Dalais FS, Kotsopoulos D, et al. Dietary soy has both beneficial and potentially adverse cardiovascular effects: a placebo-controlled study in men and postmenopausal women. Journal of Clinical Endocrinology & Metabolism. Jul. 2001;86(7):3053-60. [pmid: 11443167].
Teede HJ, Dalais FS, McGrath BP. Dietary soy containing phytoestrogens does not have detectable estrogenic effects on hepatic protein synthesis in postmenopausal women. American Journal of Clinical Nutrition. Mar. 2004;79(3):396-401. [pmid: 14985213].
Teixeira SR, Potter SM, Weigel R, et al. Effects of feeding 4 levels of soy protein for 3 and 6 wk on blood lipids and apolipoproteins in moderately hypercholesterolemic men. American Journal of Clinical Nutrition. May. 2000;71(5):1077-84. [pmid: 10799368].
Teixeira SR, Tappenden KA, Carson L, et al. Isolated soy protein consumption reduces urinary albumin excretion and improves the serum lipid profile in men with type 2 diabetes mellitus and nephropathy. J Nutr. Aug. 2004;134(8):1874-80. [pmid: 15284369].
Tonstad S, Smerud K, Hoie L. A comparison of the effects of 2 doses of soy protein or casein on serum lipids, serum lipoproteins, and plasma total homocysteine in hypercholesterolemic subjects. American Journal of Clinical Nutrition. Jul. 2002;76(1):78-84. [pmid: 12081819].
Uesugi T, Fukui Y, Yamori Y. Beneficial effects of soybean isoflavone supplementation on bone metabolism and serum lipids in postmenopausal japanese women: a four-week study. J Am Coll Nutr. Apr. 2002;21(2):97-102. [pmid: 11999549].
Uesugi T, Toda T, Okuhira T, et al. Evidence of estrogenic effect by the three-month-intervention of isoflavone on vaginal maturation and bone metabolism in early postmenopausal women. Endocr J. Oct. 2003;50(5):613-9. [pmid: 14614218].
Upmalis DH, Lobo R, Bradley L, et al. Vasomotor symptom relief by soy isoflavone extract tablets in postmenopausal women: a multicenter, double-blind, randomized, placebo-controlled study. Menopause. Jul. 2000;7(4):236-42. [pmid: 10914616].
USDA. Iowa State University Database on the Isoflavones Contents of Foods, Release 1.3. www.nal.usda.gov/fnic/foodcomp/Data/Isoflav/isoflav.html. 2002. 1-16-2004.
Van Horn L, Liu K, Gerber J, et al. Oats and soy in lipid-lowering diets for women with hypercholesterolemia: is there synergy?. J Am Diet Assoc. Nov. 2001;101(11):1319-25. [pmid: 11716313].
Van Patten CL, Olivotto IA, Chambers GK, et al. Effect of soy phytoestrogens on hot flashes in postmenopausal women with breast cancer: a randomized, controlled clinical trial. J Clin Oncol. Mar 15. 2002;20(6):1449-55. [pmid: 11896091].
Velasquez MT, Bhathena SJ. Dietary phytoestrogens: a possible role in renal disease protection. Am J Kidney Dis. May. 2001;37(5):1056-68. [pmid: 11325691].
Verrillo A, de Teresa A, Carandente GP, et al. Soybean protein diets in the management of type II hyperlipoproteinaemia. Atherosclerosis. Mar. 1985;54(3):321-31. [pmid: 4039593].
Vigna GB, Pansini F, Bonaccorsi G, et al. Plasma lipoproteins in soy-treated postmenopausal women: a double-blind, placebo-controlled trial. Nutrition Metabolism & Cardiovascular Diseases. Dec. 2000;10(6):315-22.
Wang D, Gutkowska J, Marcinkiewicz M, et al. Genistein supplementation stimulates the oxytocin system in the aorta of ovariectomized rats. Cardiovasc Res. Jan. 2003;57(1):186-94. [pmid: 12504828].
Wangen KE, Duncan AM, Merz Demlow BE, et al. Effects of soy isoflavones on markers of bone turnover in premenopausal and postmenopausal women. Journal of Clinical Endocrinology & Metabolism. Sep. 2000;85(9):3043-8. [pmid: 10999783].
Wangen KE, Duncan AM, Xu X, et al. Soy isoflavones improve plasma lipids in normocholesterolemic and mildly hypercholesterolemic postmenopausal women. American Journal of Clinical Nutrition. Feb. 2001;73(2):225-31. [pmid: 11157317].
Washburn S, Burke GL, Morgan T, et al. Effect of soy protein supplementation on serum lipoproteins, blood pressure, and menopausal symptoms in perimenopausal women. Menopause. 1999;6(1):7-13. [pmid: 10100174].
Watanabe S, Terashima K, Sato Y, et al. Effects of isoflavone supplement on healthy women. Biofactors. 2000;12(14):233-41. [pmid: 11216491].
Weggemans RM, Trautwein EA. Relation between soy-associated isoflavones and LDL and HDL cholesterol concentrations in humans: a meta-analysis. Eur J Clin Nutr. Aug. 2003;57(8):940-6. [pmid: 12879088].
White LR, Petrovitch H, Ross GW, et al. Brain aging and midlife tofu consumption. J Am Coll Nutr. Apr. 2000;19(2):242-55. [pmid: 10763906].
Williams JK, Clarkson TB. Dietary soy isoflavones inhibit in-vivo constrictor responses of coronary arteries to collagen-induced platelet activation. Coron Artery Dis. 1998;9(11):759-64. [pmid: 9919424].
Wong WW, Hachey DL, Clarke LL, et al. Cholesterol synthesis and absorption by 2H2O and 18O-cholesterol and hypocholesterolemic effect of soy protein. J Nutr. Mar. 1995;125(3:Suppl):612S-8S. [pmid: 7884542].
Wong WW, Smith EO, Stuff JE, et al. Cholesterol-lowering effect of soy protein in normocholesterolemic and hypercholesterolemic men. American Journal of Clinical Nutrition. Dec. 1998;68(6:Suppl):1385S-9S. [pmid: 9848504].
Wu AH, Stanczyk FZ, Hendrich S, et al. Effects of soy foods on ovarian function in premenopausal women. Br J Cancer. 2000;82(11):1879-86. [pmid: 10839307].
Wu AH, Yang D, Pike MC. A meta-analysis of soyfoods and risk of stomach cancer: the problem of potential confounders. Cancer Epidemiol Biomarkers Prev. Oct. 2000;9(10):1051-8. [pmid: 11045787].
Xu X, Duncan AM, Wangen KE, et al. Soy consumption alters endogenous estrogen metabolism in postmenopausal women. Cancer Epidemiology, Biomarkers & Prevention. Aug. 2000;9(8):781-6.
Yamaguchi M, Ono R, Zhong JM. Prolonged intake of isoflavone- and saponincontaining soybean extract (Nijiru) supplement enhances circulating gamma-carboxylated osteocalcin concentrations in healthy individuals. Journal of Health Science Vol 47(6)()(pp 579–582), 2001 2001;(6):579–82.
Yamashita T, Sasahara T, Pomeroy SE, et al. Arterial compliance, blood pressure, plasma leptin, and plasma lipids in women are improved with weight reduction equally with a meat-based diet and a plant-based diet. Metabolism: Clinical & Experimental. Nov. 1998;47(11):1308-14. [pmid: 9826205].
Yamori Y, Moriguchi EH, Teramoto T, et al. Soybean isoflavones reduce postmenopausal bone resorption in female Japanese immigrants in Brazil: a ten-week study. J Am Coll Nutr. Dec. 2002;21(6):560-3. [pmid: 12480802].
Yang G, Shu XO, Jin F, et al. Soyfood consumption and risk of glycosuria: a cross-sectional study within the Shanghai Women's Health Study. Eur J Clin Nutr. Apr. 2004;58(4):615-20. [pmid: 15042129].
Yildirir A, Tokgozoglu L, Oduncu T, et al. Soy protein diet significantly improves endothelial function and lipid parameters. Clin Cardiol. 2001;24(11):711-6. [pmid: 11714128].
Zhuo XG, Melby MK, Watanabe S. Soy isoflavone intake lowers serum LDL cholesterol: a meta-analysis of 8 randomized controlled trials in humans. J Nutr. Sep. 2004;134(9):2395-400. [pmid: 15333734].