# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report.

## Technical Expert Panel

- J. Mark Cline, DVM, PhD, DACVP
- Associate Professor of Pathology/Comparative Medicine
- Comparative Medicine Clinical Research Center
- Wake Forest University School of Medicine
- Winston-Salem, NC

- Alice H. Lichtenstein, DSc
- Stanley N. Gershoff Professor of Nutrition Science and Policy
- Friedman School of Nutrition Science and Policy, Tufts University, Boston, MA
- Cardiovascular Nutrition Laboratory, Jean Mayer USDA Human Nutrition Research Center on Aging, Boston, MA

- Christopher Gardner, PhD
- Assistant Professor of Medicine
- Stanford Prevention Research Center
- Stanford University School of Medicine
- Stanford, CA

- Mark Messina, PhD
- Adjunct Associate Professor
- Department of Nutrition
- Loma Linda University
- President, Nutrition Matters, Inc,
- Port Townsend, WA

- Jay R. Kaplan, PhD
- Professor of Comparative Medicine and Anthropology
- Wake Forest University School of Medicine
- Medical Center Boulevard
- Winston-Salem, NC

- Heather Miller, PhD, MFS
- Senior Advisor for Women's Health
- National Center for Complementary and Alternative Medicine
- National Institutes of Health
- Bethesda, MD

- Donna Kritz-Silverstein, PhD
- Professor, Family and Preventive Medicine
- University of California School of Medicine
- University of California, San Diego
- La Jolla, CA

- Richard Nahin, PhD, MPH
- Senior Advisor for Scientific Coordination
- National Center for Complementary and Alternative Medicine
- National Institutes of Health
- Bethesda, MD

- Anne L. Thurn, PhD
- Director, Evidence-based Review Program
- Office of Dietary Supplements
- National Institutes of Health
- Bethesda, MD