# Discussion

## Overview

Many health benefits have been attributed to soy. Mechanisms that have been proposed for the effects of soy in promoting health include: estrogenic and anti-estrogenic effects, and antioxidant and cancer-enzyme inhibitor properties. Many studies have been conducted investigating the effects of a variety of soy products and soy foods on a range of health conditions. We summarized the results of these studies in this report.

We identified 4,471 potentially relevant citations and retrieved 599 full articles based on screening of abstracts, of which 178 clinical trials were included in this report. A little over half of all the studies were cross-over trials. Eight additional studies not analyzed for health effects were included in the analysis of adverse events associated with soy intake. Health conditions considered in this report include: cardiovascular, menopausal symptoms, endocrine function and menstrual cycle length, cancer and tumor related biomarkers, bone, kidney function, neurocognitive function, and glucose metabolism. Several of these conditions have multiple endpoints. The cardiovascular topic included the largest number of studies that evaluated low and high density lipoproteins (LDL and HDL), triglycerides, lipoprotein(a) [Lp(a)], blood pressure (BP), C reactive protein (CRP), homocysteine, endothelial function, systemic arterial compliance, and oxidized LDL. Altogether, about 40 endpoints or clinical outcomes were summarized in this report. We performed meta-analyses on several cardiovascular endpoints because these topics have a large number of available studies. However, for most other health conditions, the heterogeneity of the types of interventions and outcomes precluded meta-analysis.

The study quality was generally fair to poor. Overall, less than 5% of the studies were rated to be good quality (A), about 40% were rated to be fair quality (B), and about 55% were rated to be poor quality (C). Also, among the fair quality studies, about 5% reported data sufficiently poorly for particular secondary outcomes that study quality was downgraded for these outcomes. Among the common reasons that studies were rated fair quality were small sample size (less than 30 subjects consuming soy, unclear reporting regarding subject dropouts or somewhat high dropout rates (approximately 10–20%), incomplete reporting regarding soy composition or control, data reported only in figures, and minor discrepancies between text, tables, and/or figures. One-third of the poor quality studies were either uncontrolled, single cohort studies, non-randomized comparative studies, or comparative studies that were unclear whether they were randomized. Another third of the poor quality studies had dropout rates that exceeded 20%, including studies with over a 50% dropout rate, or unequal dropout rates between soy and control. Among other reasons studies were graded poor quality were lack of reporting of baseline data (i.e., initial level of outcome measure), inadequate accounting of important confounders (e.g., major differences in fat and protein consumption between study arms, medication use that affects outcomes), major discrepancies between text, tables, and/or figures or irreconcilable data that indicate likely improper statistical analysis, and substantial missing data.

## Main Findings

### Soy products

Soy supplements were used in about three quarters of all the trials analyzed in this report; soy foods were used in the remaining trials. In this report, soy milk/drinks were categorized as soy supplement. Fifty-seven percent of the soy supplement trials used soy protein with isoflavones, 36% used isoflavones alone, and 6% as soy protein without isoflavones. In about one-half of the soy foods trials, textured soy protein was used. Soy flour was used in about one-quarter of the soy foods trials. There are 146 separate treatment arms of soy supplementations and 68 separate treatment arms of soy foods or diets. The total isoflavones range from 0 mg to 185 mg per day. The total protein intake from soy ranges from 0 g to 154 g per day. The average study evaluated a large quantity of soy product. The median soy protein dose is 36 g per day, equivalent to over a pound of typical tofu or 3 typical soy shakes per day. Also of note is that most studies were of relatively short duration. Approximately half the studies were shorter than 12 weeks and one-third shorter than 6 weeks. With few exceptions, though, studies of less than 4 weeks' duration were excluded.

### Overall Effects

Meta-analysis revealed a statistically significant reduction of LDL and triglycerides across a heterogeneous range of soy interventions, but no effect on HDL or BP. Meta-regression suggested a possible association between soy protein dose and LDL reduction, but no dose-response for soy isoflavones for any lipids or BP. However, the few studies that directly compared different types and doses of soy products did not consistently find a soy protein dose effect.

Some evidence suggests that soy isoflavone supplements may reduce menopausal symptoms in post-menopausal women. Other soy products did not show an effect, and the evidence does not support a benefit of soy products for peri-menopausal women or women undergoing breast cancer chemotherapy.

Overall, studies have found no benefit of soy products on other evaluated CVD risk factors, endocrine function, tumor biomarkers, bone health, or other evaluated conditions. However, no study evaluated clinical outcomes for cardiovascular disease, endocrine disease, cancer incidence, or osteoporosis. Furthermore, heterogeneity of soy products, comparators and populations, along with often poor study quality and frequent small numbers of studies hampered definitive evaluation of the effect of soy products.

Among studies that reported adverse events, the overall frequency of adverse events in subjects consuming soy was similar to that of subjects in control arms. However, gastrointestinal complaints were substantially higher among subjects consuming soy. Menstrual complaints were also higher among post-menopausal women consuming isoflavone supplements. Adverse events were almost universally minor.

### Cardiovascular Endpoints

A total of 68 randomized studies reported data on total cholesterol, LDL, HDL, and/or triglycerides. The total isoflavones range from 0 mg to 185 mg per day, with a median of 80 mg. The total protein intake from soy ranges from 14 to 113 g per day, with a median of 36 g. There is a great deal of heterogeneity of effects found on lipoprotein and triglyceride levels. Overall, the majority of studies reported small to moderate effects on the lipids, despite a wide range of net effects for total cholesterol, LDL, and triglycerides. Sixty-one studies reported data on the effect of consumption of soy products on total cholesterol levels. The median net change compared to control found was approximately 6 mg/dL decrease (2.5%). A meta-analysis of 52 studies that reported data on the effect of soy consumption on LDL levels yielded a statistically, though not clinically, significant net decrease of 5 mg/dL (approximately 3%). A meta-analysis of 56 studies that reported data on the effect of soy consumption on HDL levels found a non-significant net increase of less than 1 mg/dL. A meta-analysis combining 54 studies that reported data on the effect of soy consumption on triglyceride levels yielded a statistically significant net decrease of 8 mg/dL (approximately 6%). These small benefits to lipid levels may have a debatable benefit in individuals to reduce the risk of clinical cardiovascular disease (CVD), though on a population level - assuming that a whole population increased its soy consumption - these lipid changes could possibly have a substantial effect on incidence of CVD.

However, the majority of studies used large doses of soy equivalent to over a pound of tofu or over 3 servings of a typical soy protein shake daily. Across studies there is some indication that increasing doses of soy protein may be associated with increasing LDL benefit, although this effect is statistically significant only from studies with elevated mean baseline LDL and only if studies with marginal amounts of soy protein are also included. No association was found between soy protein dose and effect on either HDL or triglycerides, or between soy isoflavone dose and effect on any lipid. Studies that investigated possible dose effects generally also found no association.

A total of 22 studies reported data on the effect of consumption of soy products on systolic and diastolic BP. Meta-analysis of blood pressure (BP) found no effect of soy consumption. The net effect on systolic BP was -1 (95% CI -3, +1) mm Hg, and on diastolic BP -1, (-2, +0) mm Hg. No association was found between baseline BP, soy protein or isoflavone dose and effect on BP.

Some of the well known emerging risk factors for CVD included for analysis in this report are: Lp(a), CRP, homocysteine, endothelial function, systemic arterial compliance, oxidized LDL. The total number of studies that reported data on the effect of soy consumption are: 18 studies on Lp(a), 3 on CRP, 5 on homocysteine, 10 on endothelial function, 3 on systemic arterial compliance, and 13 on oxidized LDL. Across these studies, there is no discernable effect based on the type of soy products. Majority of studies were of poor quality with a narrow range of applicability. Given the limited evidence and poor quality studies, no conclusions could be drawn on the beneficial or harmful effects of consumption of soy protein on these (non-lipid, non-BP) putative risk factors for CVD.

### Menopausal Symptoms

A total of 21 trials examine the effects of soy and/or its isoflavones on hot flashes and night sweats in women. These trials generally measured frequency and severity of the symptoms. However, a large number of vasomotor symptom scores or indexes that employed a variety of frequency intervals were used by the investigators. These factors made meta-analyses unsuitable and limited the comparisons of results across studies. Furthermore, many of the studies had high withdrawal or dropout rates that were frequently uneven between soy treatment and control arm; this further limits the validity of these clinical trials. Overall, soy isoflavones supplements might reduce hot flashes in symptomatic post-menopausal women, compared to the placebo. Among the 6 randomized trials showing the positive results, the net reduction in weekly hot flash frequency ranges from 7% to 40%. However, these trials are mostly low quality due to high dropout rates. No significant effect was found for soy and/or its isoflavones treatments compared to the control treatments on vasomotor symptoms in peri-menopausal women or women who had breast cancer therapies.

### Endocrine Function

Forty-seven papers included endocrine measurements as primary or secondary endpoints. Testosterone was an outcome of clinical importance both as a risk factor for cancer and as part of the initial evaluation of male infertility. Five studies with a total of 179 participants reported testosterone levels in healthy males before and after soy consumption. Four out of the five studies found a non-significant decrease in testosterone levels. The small total number of subjects as well as the low quality of these studies precluded any meaningful conclusion. Follicle stimulating hormone (FSH) level is measured at the initial evaluation of male and female infertility. Results were conflicting and no significant effect was found.

Twelve studies reported estradiol levels in 434 pre-menopausal women. The overall effect of soy on estradiol levels was not consistent. Most of the studies showed a trend for soy in reducing estradiol, although they failed to demonstrate a significant effect. Six randomized trials reported the effect of soy on thyroid stimulating hormone (TSH). No overall effect of soy on TSH and thyroid function is clear.

A total of 11 trials in 10 publications evaluated the effect of soy on menstrual cycle length in pre-menopausal women. A wide range of soy interventions was used in these trials made a conclusion of the effects from soy difficult, because of the limited number of studies in each comparison category. These trials did not show significant changes in menstrual cycle length after treatments of soy and/or its isoflavones.

### Cancer and Tumor-Related Biomarkers

Twenty-four studies evaluated subjects without a history of cancer for effects of soy on tumor-related biomarkers. None of the trials reported the development of cancer as the outcome. Most studies measured the effect of soy on estrogens and estrogen metabolites as well as on estrogenicity indicators. There were also trials, which aimed at correlating soy with other possible cellular pathways of cancer prevention. No causal relationship could be actually established between these markers and cancer because they do not represent risk factors for cancer disease. Only 2 studies reported on testosterone levels, which is a risk factor for prostate cancer, as an endpoint.

### Bone Endpoints

A total of 26 studies were included in this section. Ten trials examined the effects of soy and/or its isoflavones on bone mineral density and/or bone mineral contents, and 22 trials examined the effects of soy and/or its isoflavones on bone biomarkers related to bone turnover or bone remodeling. There were few randomized trials of long-term duration and a wide variety of soy interventions were used across studies, therefore it is difficult to draw reliable conclusions about the effects of soy on bone endpoints. No consistent effect was found between soy protein with isoflavones and that of isolated soy protein without isoflavones.

Nine studies each reported data on the effects of soy on bone formation markers, serum osteocalcin (OC) and bone specific alkaline phosphatase (bAP), respectively. The majority of these trials enrolled pre- and post-menopausal women. No significant effect was reported by most of the studies.

In the studies that evaluated bone resorption biomarkers, 2 randomized trials of urinary hydroxyproline in post-menopausal women reported no significant differences between soy protein with isoflavones diets, and the control diets. There is no consistent effect of soy protein and/or its isoflavones on urinary cross-linked N-telopeptide (NTx) levels when compared to the control treatments in both pre-menopausal and post-menopausal women.

Only a single study of genistein found consistently statistically significant benefits of soy consumption on measures of bone health.

### Neurocognitive and Kidney Functions, and Glucose Metabolism

Four studies examined the effects of soy on cognitive function of post-menopausal women and college students of both sex. Overall, no significant consistent effect on neurocognitive functions such as verbal episodic memory was noted. Only 1 small study in patients with type 2 diabetes assessed the effect of soy on kidney function. No significant changes in glomerular filtration rate as seen after 8 weeks of soy protein diet. Six studies evaluated the effect of soy on fasting blood glucose. No significant changes were reported.

### Adverse Effects

Overall, the numbers and rates of adverse events reported were similar between the soy treatment arms and their respective controls (151 vs 113, 8.6% vs 7.2%). However there were no differences according to the types of soy consumed.

The most frequently reported adverse events among a total of 3,518 subjects in 49 trials that reported adverse events were gastrointestinal in nature, reported in 30 of 41 comparison studies of soy diets and beverages, soy proteins, isoflavones, and phytoestrogen supplements. Mostly the gastrointestinal complaints were reported in soy diet and soy protein trials. The amount of soy protein in these trials ranged from 20 to 60 g/day, but there was no clear dose relationship. In the comparison trials of purified isoflavone interventions as well as soy diets and beverages, there were more gastrointestinal complaints (46 vs 12). Overall, there were 116 complaints in the soy arms, compared to the controls. Menstrual complaints were also common, reported in 15 studies , especially in those 12 that used purified isoflavone in dosages ranging from 40 to 100 mg/day (13 adverse events vs 6), but overall, in all types of soy consumption, the numbers of adverse menstrual events were 35 versus 26 in soy arms and controls, respectively. The majority of these patients were post-menopausal women, and the controls frequently included hormone therapy regimens. Other adverse events included musculoskeletal complaints, headache, dizziness, and rashes. There were also more withdrawals from the soy arms due to aversion of taste.

## Limitations

Despite the large number of trials that have been performed, the health effects of soy for many conditions that have been studied remain uncertain. The methodological quality of many studies evaluated in this report was poor (Grade C). There was great heterogeneity among studies, particularly among the interventions analyzed. Comparisons across the myriad types of soy are intrinsically very difficult. This difficulty was compounded by the use of soy as both a supplement and as an integral part of the diet; furthermore for numerous studies, it is difficult to distinguish between supplement and diet. It is likely that studies of supplements and diet are not easily comparable. Most studies also involved a small number of study subjects and were of short duration. The universal issue of possible publication bias, where negative studies are less likely to be published and are more likely to be published later, is a potential concern. However, for most outcomes, the majority of studies reported negative outcomes, and there was no obvious evidence of publication bias among the lipid studies (where there is evidence of a positive effect).

Most of the studies evaluated the effects of soy on various biomarkers or measures, not clinical outcomes. Several of these endpoints evaluated in the studies, such as BP, LDL-cholesterol, and bone mineral density, do have meaningful correlations with clinical outcomes. Cardiovascular endpoints were assessed by the largest number of studies. Overall, soy was found to have only a small effect on lipids. However, the duration of these studies were generally short, and it is uncertain whether the results would be sustained. Few studies directly compared soy products, mostly comparing soy protein with varying amounts of soy isoflavones. Only one study, Lichtenstein 2002 ^56^ performed a factorial design study comparing both present and absent soy protein and present and absent soy isoflavones, thus allowing analysis of both the effect of soy protein and soy product.

Reduction of hot flashes by soy was seen in trials involving post-menopausal women. Most of the trials lasted only 3 to 4 months, thus their long-term benefits remain unclear. In addition, different measurements were used to assess benefits across studies thus making comparisons and synthesis difficult. Soy phytoestrogens are seen by some as an alternative to estrogen replacement therapy to treat post-menopausal symptoms. However, the estrogenic effect of soy in potentially promoting tumor recurrence raises the concern for its use by breast cancer survivors. The current literature provides no data to address this issue. It remains unclear whether there is a real hormonal effect of isoflavones in women or men, either on hormone levels or hormonal effects; this could be a subject of future research.

Some of the conditions and outcomes were evaluated by only a few studies. The question of whether long-term consumption of soy impairs neurocognitive function cannot be answered with the current data.

## Future Research

This report dealt with a broad range of health conditions and endpoints, thus it is difficult to focus research recommendations on a specific area. Common to most bodies of evidence regarding medical fields, better quality, well-reported, larger and longer duration studies are needed to address the questions of interest.

It is generally very difficult to evaluate different effects due to different products or in different populations when these differences can be found only across studies. Additional studies are needed that directly compare different doses and types of soy products, and that perform appropriate sub-group analyses such as by sex or age or baseline risk.

Given the complexity of food products, it is particularly important that future studies of soy products (and all food products) report complete and thorough descriptions of the products under investigation. In the case of soy, this includes quantity (and possibly type) of soy protein, quantity and type of isoflavones, and quantity and type of other constituents of the soy product that may exert an effect.

Since the evidence does not strongly suggest a dose-response for either soy protein or isoflavones, it may be appropriate to investigate other soy constituents as possible active factors.

Consideration (and full reporting) is needed of what foods are being replaced by the consumption of the soy products (whether they be used as part of the diet or as supplements) and this needs to be controlled for. This includes care being taken that appropriate controls are used. Otherwise, interpretation of the study can be fraught with difficulties. It should be clear that the comparison is between soy and an alternative, not, for example, low-fat versus high-fat diets, high-protein versus low protein diets, or plant versus animal protein diets.

We strongly recommend that all future randomized trials - including those of soy and other nutritional products - use the CONSORT statement as a guide to reporting (http://www.consort-statement.org). ^238,^ ^239^ This will not only improve the readers' understanding of the trials, but should also improve the quality of published studies. About 10% of studies on soy products failed to adequately report that they were randomized; many studies failed to completely and accurately report their data, including baseline data, numbers of subjects, numbers of dropouts, and statistical methods used; and over 20% of studies had very high dropout rates, from 20% to more than 50%. These are examples of issues that could be greatly improved by conscientious adherence to proper study design and reporting.

While we reviewers of the evidence are not in a position to make specific recommendations about how research in the field of nutrition should fundamentally change, we offer the following observations for consideration by experts in nutrition research when planning future research. We suggest that these issues be discussed at future workshops that either plan future studies or review the needs of future food-related research. Examples of these include the working group on future clinical research directions on omega-3 fatty acids and CVD, convened by the Office of Dietary Supplements and the National Heart, Lung, and Blood Institute on June 2, 2004 in Bethesda, MD (www.nhlbi.nih.gov/meetings/workshops/omega-3/omega-3-rpt.htm, accessed April 28, 2005) and the workshop “Assessing the Health Effects of Bioactive Food Components” sponsored by the Office of Dietary Supplements and held in conjunction with the Experimental Biology 2005 meeting in San Diego).

Conducting clinical trials in the area of health effects of food substance is fraught with difficulties. There is a complex interplay among the various components and potentially active substances within the foods and with other foods, dietary variations, as well as with other lifestyle and clinical variations among individuals. Controlling for these factors is difficult within a trial. Interpreting discrepant results among trials is even more difficult. Isoflavones are believed to be the key active substance in soy, but this is by no means certain. Little data suggest that the amount of soy isoflavones is associated with an incremental effect and studies of soy protein with little or no isoflavones frequently had similar effects as isoflavone studies. It may be that neither soy protein nor soy isoflavones are the active component of soy. No studies that we reviewed examined this possibility. Nevertheless, difficulties with attempting to ascribe a food health benefit to a specific component of the food are highlighted by the recent spate of disappointing results from antioxidant trials, which suggest that the evaluation of potential nutrient benefits may need a paradigm different from the traditional clinical trial model.

The bioavailability of an ingested nutrient may also be an important factor in the determination of the beneficial effect. Several factors may affect the bioavailability of ingested nutrients: 1) absorption rate, affected by the interactions with competitive nutrients, the usual diet compositions, and types of foods or supplements; 2) incorporation rate into the blood stream, in which complex mechanisms might be involved, such as the functions of facilitated transporters, receptors on the membrane, or cellular binding proteins; 3) metabolism of the intestinal bacterial environment. Any one of these factors alone does not determine the bioavailability. In order to gain insights on the question of dose-response relationship, we not only need the information on the soy isoflavone contents, including types and amount, but also on the bioavailability of the ingested soy isoflavones.

Unfortunately studies that attempt to control for the myriad factors that interfere with clear interpretation of the effect of food products such as soy tend to be highly artificial, with little applicability to the average person. Clarity is needed to define what study questions are of interest. Metabolic laboratory studies or investigations of highly structured or restricted diets (such as those where soy protein constitutes the bulk of daily protein consumption) are of potential value only to possibly determine which components of soy are bioactive or to determine what extremes of diet may be necessary to achieve a benefit. Studies that substitute practical amounts of soy products into average people's diets would better address the question of whether people should make the effort to include more soy in their diets, but these studies will invariably be difficult to interpret. An exception to this may be studies of soy isoflavone supplements (e.g., non-food capsules), which may be interpreted more like usual drug trials.

Carefully controlled efficacy studies (those conducted under the artificial conditions of a clinical trial) may still be useful to pin down the relative effects of various components of soy. Once this is better clarified, more practical effectiveness studies (that aim to test the value of an intervention in more real-world scenarios) with feasible interventions might be more important.