# Results

Searches in EMBASE and MEDLINE yielded 2,639 and 2,650 citations, respectively, with an additional 10 citations from the supplemental search. After removal of overlapping and duplicate publications, the final yield was 4,471 citations. An updated search conducted in early December yielded an additional 308 citations.

After screening of the titles and abstracts, 599 articles were retrieved for examination. A total of 178 clinical trials publications were included in sections of the report regarding soy effects. In addition to these studies, 5 prospective cohorts and 3 pharmacokinetics studies reported data on adverse events. The results are summarized in this chapter in the following order: soy products used in the trials (Section 3.1), effects of soy on cardiovascular endpoints (3.2), menopausal symptoms (3.3), endocrine endpoints (3.4), cancer and tumor related biomarkers (3.5), bone endpoints (3.6), reproductive health (3.7), and a miscellaneous category that includes kidney, neurocognitive, and glucose metabolism endpoints (3.8). Following is an overview of association of dose and product type with effect (3.9). Finally, adverse events from clinical trials and observational studies are summarized following the review of evidence on health outcomes (3.10).

All qualifying studies are presented in summary tables in the appropriate sections. Details regarding these studies are available in the evidence table.* Some additional studies that contained pertinent information, but did not qualify for inclusion are also discussed.

## 3.1. Soy Products Used

(Tables 1–4)

Table 1 Soy supplements or soy protein powders and beverages used in the experimental arm of the studies

Outcome Categories | Isoflavones Alone | Soy Protein with Isoflavones | Soy Protein without Isoflavones | Unclear Amount of Soy Protein and/or Isoflavones | Total # of Studies*
Cardiovascular | Total: 23 | Total: 60 | Total: 7 | Total: 4 | 94
| Advanced Care Products (1) | Abacor (2) | Essential Nutrition (1) | ADM (1)
| Bonette (Novomed, Helsinki) (2) | Abalon (Nutri Pharma, Oslo) (1) | Protein Technologies International (6) ^b^ | ISP powder (not specific) (2)
| Eugenbio (1) | Altima HP-20 (Protein Technologies International) (2) ^b^ | | Scan Diet Shakes (1)
| Genistein, Lab Plant (2) | Calcimel (1)
| NovaSoy (ADM) (3) | Eden (1)
| Novogen (1) | FXP HO 159 (1)
| PhytoLife (1) | ISP powder (not specific) (19)
| Protoveg (2) | Proderma (ALPRO, Belgium) (2)
| Soya hypocotyl Iso (Fuji Oil Co) (2) | Solae - powder (2) ^b^
| Soycreme (1) | Supro - powder (12) ^b^
| Total Life Co (1) | Supro - liquid/beverage (6)
| No brand name tablet (6) | Supro - tablet/cap (1) ^b^
| | Soymilk (8)
| | Tofuline (1)
| | Unilever Best Foods, Brazil (1)
Menopausal Symptoms and Menstrual Cycle Length | Total: 12 | Total: 15 | | | 27
| Advanced Care (1) | Banyang Foods (2)
| Bonette (Novomed, Helsinki) (1) | ISP powder (ADM) (1)
| Genistein, Lab Plant (1) | ISP powder—Protein Technologies International (5) ^b^
| PharmaVite (2) | ISP powder (not specified) (1)
| PHYTO SOYA (Glycine max. L. Merr.) (1) | Kibun Food Chimifa (1)
| Phytosoya (1) | Soya World (1)
| Protoveg (2) | Supro - powder (1) ^b^
| Solgar Italia (1) | Supro 675 powder (1) ^b^
| Soylife™ (Netherlands) (1) | TakeCare™ (PTI) (2) ^b^
| SOYSELECT™ (1)
Endocrine | Total: 21 | Total: 17 | Total: 1 | | 39
| Advanced Care Products (1) | ADM Euro-port (1) | Essential Nutrition (1)
| Bonette (Novomed, Helsinki) (1) | Banyang Foods (1)
| Eugenbio (1) | ISP powder (not specific) (2)
| Genistein, Lab Plant (4) | Kibun Food Chemifa, Tokyo (3)
| Genistein-combined polysaccharide (GCP, Amino Up Chem Co) (1) | Soymilk (2)
| NovaSoy (ADM) (4) | Supro - powder (6) ^b^
| PharmaVite (1) | TakeCare™ (PTI) (2) ^b^
| Regen soy extract (Novogen Ltd) (1)
| SOYSELECT™ (1)
| Total Life Co (1)
| No brand name tablet (5)
Tumor related | Total: 7 | Total: 9 | | | 16
| NovaSoy (ADM) (2) | Banyang Foods (2)
| PharmaVite (1) | Protein Technologies International- powder (5) ^b^
| Protoveg (1) | Soymilk (1)
| SOYSELECT™ (1) | Supro - powder (1) ^b^
| Total Life Co (1)
| No brand name tablet (1)
Bone | Total: 7 | Total: 12 | Total: 4 | | 23
| Advanced Care Products (1) | ISP powder—Protein Technologies International (7) ^b^ | ISP powder—Protein Technologies International (4) ^b^
| Bonette (Novomed, Helsinki) (1) | ISP powder—Solae (1) ^b^
| Genistein, Lab Plant (1) | Proderma, ALPRO Belgium (1)
| NovaSoy (ADM) (1) | SoGood Soymilk drinks (1)
| Total Life Co (1) | Supro 675 (2) ^b^
| Isoflavone extracts (No brand) (2)
All other outcomes | Total: 3 | Total: 5 | | | 8
| Healthy Woman soy menopause supplement (1) | DuPont Protein Technologies—powder (1) ^b^
| PHYTO SOYA (Glycine max. L. merr.) (1) | Fortimel (1)
| Solgen (Solbar Plant Extracts) (1) | Soy beverage (1)
| | Supro - powder (2)
Total # of Studies ^ a ^ | 74 | 118 | 12 | 4 | 207

a The numbers do not add up to the total due to single study may examine multiple outcome categories

b In October 1997 Ralson Purina completed its sale of Protein Technologies International (PTI) to DuPont. Solae is the trademark for PTI.

Table 2 Soy foods or diets used in the experimental arm of the studies

Outcome Categories | Tofu Alone | Soybean Alone | Soy Flour or Foods Made from Soy Flour | Other Soy Food | Texture Soy protein or Soy Diet (Mixed Soy Foods) | Total N of Studies*
Cardiovascular | Total: 4 | Total: 2 | Total: 5 | Total: 3 | Total: 22 | 36
| Blue Lotus Foods (2) | Soybean diet (2) | Nutrisoy flour (ADM Europort) (2) | Isosoy Soy germ (1) | Texture Soy protein - Cholsoy L (3)
| Mori-nu Silken Extra Firm tofu (1) | | Soy crisp bread (1) | Nijiru (1) | Texture Soy protein (1)
| Tofu (1) | | Soy flour (1) | SoGood Soy nuts (1) | Soy protein and/or Isoflavone Unclear (18)
| | | Soy flour (Soy Pro-ducts of Australia) (1)
Menopausal Symptoms and Menstrual Cycle Lengths | | | Total: 3 | | Total: 2 | 5
| | | Nutlettes® -soy flour and corn cereal (1) | | Soy protein and/or Isoflavone Unclear (2)
| | | Soy flour (1)
| | | Soy-grits bread (George Weston Foods) (1)
Endocrine | Total: 3 | Total: 1 | Total: 3 | Total: 2 | Total: 4 | 13
| Blue Lotus Foods (2) | Soybean product (1) | ADM Euro-port (1) | Isosoy Soy germ (1) | Soy protein and/or Isoflavone Unclear (4)
| Tofu (1) | | Soy flour (2) | Soy nuts (1)
Cancer | | | Total: 3 | | Total: 2 | 5
| | | Nutrisoy flour (ADM Europort) (1) | | Soy protein and/or Isoflavone Unclear (2)
| | | Soy Bread (1)
| | | Soy flour (1)
Bone | | Total: 1 | Total: 2 | Total: 4 | Total: 1 | 8
| | Soybean diet (1) | Soy flour (1) | Natto (1) | Soy protein and/or Isoflavone Unclear (1)
| | | Soy-grits bread (George Weston Foods) (1) | Nijiru (1)
| | | | Roasted hypocotyl germ of soybean & sesame(1)
| | | | Soy nuts (1)
All other outcomes | | Total: 1 | Total: 1 | Total: 1 | Total: 4 | 7
| | Soya Bean (1) | Soy Flour, Rakosvolgye Co (1) | Almased (1) | Soy protein and/or Isoflavone Unclear (4)
Total # of Studies ^ a ^ | 7 | 5 | 17 | 10 | 35 | 74

a The numbers do not add up to the totals due to studies examining multiple outcome categories.

w/ = with; w/o= without; SP and/or Isoflavone Unclear = Unclear Amount of Soy Protein and/or Isoflavones

Table 3 Isoflavone content of soy products with isolated soy protein and isoflavones

| Daily Dose of Isoflavones (mg/ day) per gram of Soy Protein
| Genistein | Daidzein | Glycitein | Total Isoflavones
Abacor ISP (PTI) | -- | -- | -- | 3.70
Abacor yogurt (PTI) | -- | -- | -- | 1.85
Abalon (Nutri Pharma, Oslo, Norway) | -- | -- | -- | >3.3
Calcimel | 4.44 | 3.50 | -- | 7.94
Essential Nutrition ISP(Brough, UK) | 2.33 | 1.63 | 0.43 | 4.40
FXP HO 159 (PTI) | -- | -- | -- | 3.70
ISP96 powder (PTI) | 1.30 | 0.70 | -- | 2.40
ISP90 powder (PTI) | 0.98 | 0.65 | 0.18 | 1.80
ISP80 powder (PTI) | 1.20 | 0.60 | 0.20 | 2.00
ISP56 powder (PTI) | 0.65 | 0.35 | 0.10 | 1.08
ISP38 powder (PTI) | 1.74 | 1.16 | 0.26 | 3.16
Protoveg, Direct Foods (Manchester UK) | 0.33 | 0.42 | -- | 0.75
Solae ISP powder | 2.00 | 1.58 | 0.23 | ≥3.81
Soymilk (Kibun Food Chimica,Tokyo, Japan) | -- | -- | -- | 6.42
Soymilk (Proderma/ALPRO, Belgium) | 1.00 | 1.12 | 0.97 | 3.08
Soymilk (Unilever Best Foods, Brazil) | 2.00 | 1.32 | 0.20 | 3.48
Soymilk (Banyang Foods, Houston, TX) | 2.25 | 1.82 | -- | 4.06
Supro powder high in isoflavones | 1.32 | 0.89 | 0.19 | 2.42
Supro powder low in isoflavones | 0.66 | 0.45 | 0.09 | 1.21
TakeCare™ (PTI) | 1.40 | 0.71 | 0.09 | 2.20

Individual isoflavone doses may not add up to total due to rounding errors and presence of other isoflavones.

ISP = isolated soy protein, PTI = Protein Technology Institute, Inc.

Table 4 Isoflavone content of soy products with isoflavones only

| mg/day
| Genistein | Daidzein | Glycitein | Total Isoflavones
Acatris high-dose isoflavones (Netherlands) | 12 | 38 | 31 | 80
Acatris low-dose isoflavones (Netherlands) | 6 | 19 | 16 | 40
Bonette (Novomed, Helsinki, Finland) | 6 | 42 | 66 | 114
Eugenbio (Seoul, South Korea) | 70 | 19 | 11 | 100
Genistein, Lab Plant (Messina, Italy) | 54 | 0 | 0 | 54
Healthy Woman soy menopause supplement | -- | -- | -- | 110
Novasoy (ADM) | 44 | 44 | 2 | 90
PharmaVite (San Fernando, CA) | -- | -- | -- | 76
Regen soy extract (Novogen, N.Ryde, Australia) | -- | -- | -- | 40
Solgar Italia (Padua, Italy) | 11 | 36 | 25 | 76
Solgen (Solbar Plant Extracts, Ashdod, Israel) | -- | -- | -- | 60
Soya hypocotyls isoflavones (Fuji Oil Co, Japan) | 2 | 17 | 10 | 40
Soylife soy extract (Netherlands) | 12 | 40 | 28 | 80
Total Life Co (Taipei, Taiwan) | -- | -- | -- | 150

Individual isoflavone doses may not add up to total due to rounding errors and presence of other isoflavones.

Key Question 1: In the clinical trial literature, what formulations of soy were used? At what dose? For what purpose(s) (e.g., trial endpoints)?

Table 1 summarizes soy supplements or soy protein powders and beverages. Table 2 summarizes soy foods or diets used in the experimental arms of the studies by each outcome category. Many of the soy protein products derive from the same manufacturer presumably, due to merger and acquisition. Specific study endpoints and the formulations of soy supplements and soy foods are described in both evidence tables^*^ and summary tables later in this chapter. Studies in the category of “unclear amount of soy protein and/or isoflavones” did not quantify the amount of soy interventions used.

Appendix C (Evidence Table) is available electronically at www.ahrq.gov/clinic/tp/soytp.htm.

A total of 281 comparisons were made with soy supplements or with soy foods/diets in the experimental arms. About three-quarters of these were trials of soy supplements, as isoflavones alone, soy protein with or without isoflavones. About one-half of the trials of soy supplements or soy foods and diets focused on one or more of the many cardiovascular endpoints. About 20% of the trials studied endocrine function. About 10–15% each, of the trials, evaluated menopausal symptoms or menstrual cycle length, bone outcomes, or cancer markers/risk factors. Less than 5% of the trials evaluated neurocognitive function, kidney function, or glucose metabolism. Over 90% of the soy supplement trials used isoflavones alone or soy protein with isoflavones; there were more trials of soy protein with isoflavones than trials of isoflavones alone.

Across studies, the total isoflavones ranged from 0 mg to 185 mg per day and the total protein intake from soy ranged from 0 g to 154 g per day. Of note, the median soy product dose across studies (36 g soy protein per day) was equivalent to over a pound of tofu daily or about 3 soy protein shakes daily.

The isoflavone content of evaluated soy products is presented in Tables 3 and 4.

Key Question 2 : Does current clinical trial evidence indicate that whole soy products and individual constituents of soy have an effect on:

a. cardiovascular events, risk factors, and measures (Section 3.2);

b. menopausal symptoms (Section 3.3);

c. endocrine function (Section 3.4);

d. cancer and tumor-related biomarkers (Section 3.5);

e. osteoporosis and osteoporosis risk factors (Section 3.6);

f. reproductive health (Section 3.7);

g. kidney function (Section 3.8.1); and

h. other outcomes, based on results of Key Question 1 above (Sections 3.8.2–4)?

## 3.2. Cardiovascular Events, Risk Factors, and Measures

### 3.2.1. Summary of Studies Found

(Tables 5–6)

Table 5 Number of studies that reported on each cardiovascular outcome

Analyzed Outcomes | Number of Studies ^a^ | Section | Other Outcomes | Number of Studies ^b^
Total cholesterol ^c^ | 66 | 3.2.2 | Cardiovascular events or disease | 0
Low density lipoprotein (LDL) ^c^ | 56 | 3.2.3
High density lipoprotein (HDL) ^c^ | 62 | 3.2.4 | Apolipoprotein A-1 | 24
Triglycerides ^c^ | 58 | 3.2.5 | Apolipoprotein B | 27
Lipoprotein (a) [Lp(a)] | 21 | 3.2.7 | Apolipoprotein C-III | 0
Blood pressure (BP) | 25 | 3.2.8 | Apolipoprotein E | 2
C-reactive protein (CRP) | 3 | 3.2.9 | Endothelin | 4
Homocysteine (Hcy) | 5 | 3.2.1 | E-selectin | 3
Endothelial function | 10 | 3.2.11 | Factor VII | 3
Systemic arterial compliance | 3 | 3.2.12 | Factor VIII | 0
Oxidized LDL | 13 | 3.2.13 | Factor XII | 0
Total | 83 | | Fibrinogen | 4
| | | Free or non-esterified fatty acids | 1
| | | Intercellular adhesion molecule (ICAM) | 2
| | | Interleukin 2R or 6 | 3
| | | Nitrous oxide (NO) | 0
| | | P-selectin | 1
| | | Remnant-like particles | 0
| | | Thrombomodulin | 0
| | | Vascular cell adhesion molecule (VCAM) | 2
| | | von Willebrand Factor (vWF) | 1
| | | Ankle-brachial index | 0
| | | Bleeding time | 0
| | | Carotid ultrasound/Doppler | 0
| | | Coronary angiography | 0
| | | Echocardiography | 0
| | | Electrocardiogram (ECG) parameters | 0
| | | Exercise tolerance testing (ETT) | 0
| | | Heart rate variability | 0
| | | Intima-media thickness (IMT) | 0
| | | Platelet aggregation | 1

a Studies reported in multiple articles are not double-counted.

b Estimates. Studies reported in multiple articles may be double-counted.

c Only randomized trials with a minimum of 10 subjects who consumed soy products.

Table 6 Summary of studies reporting cardiovascular outcomes

Author Year (UI) | TC | LDL | HDL | Tg | Lp(a) | BP | CRP | Hcy | Endothelial Function | Systemic Arterial Compliance | Oxidized LDL
Ashton 2000 10694766 | | x
Ashton 2000 11194529 | x | | x | x | x | | | | | | x
Azadbakht 2003 | x | x | x | x
Bakhit 1994 | x | x | x | x
Baum 1998 | x | | x | x
Blum 2003 12659466 | x | x | x | x | | | | | x
Bricarello 2004 | x | x | x | x | | | | | | | x
Burke 2001 | | | | | | x
Carroll 1978 | x
Chiechi 2002 11836040 | x | x | x | x | | x
Crouse 1999 | x | x | x | x | t
Cuevas 2003 | x | x | x | x | | x | | | x
D'Amico 1992 | | | | | | x
Dent 2001 | x | x | x | x | x
Dewell 2002 | x | | x | x
Gallagher 2004 | x | x | x | x
Gardner 2001 | x | x | x | x
Gardner-Thorpe 2003 | x | x | x | x | | | | | | | x
Gentile 1993 | | | | | | x
Goldberg 1982 | x | x | x | x
Gooderham 1996 | t | | t
Han 2002 | x | x | x | x | | x
Hermansen 2001 | x | x | x | x | x | x | | x
Hill 2004 | | | | | | | | | | | x
Jayagopal 2002 | x | x | x | x | | x
Jenkins 1999 | x | x | x | x | x | x | | | | | x
Jenkins 2000 10647066 | | | | | | | | | | | x
Jenkins 2000 10778882 | | | | | | | | | | | x
Jenkins 2002 12077742 | | | | | | | x
Jenkins 2002 12145008 | x | x | x | x | x | x | | x | | | x
Kanazawa 1995 | | | | | | | | | | | x
Kreijkamp-Kaspers 2004 | x | x | x | x | x
Kreijkamp-Kaspers 2005 | | | | | | x | | | x
Kurowska 1997 | x | x | x | x | | x | | | | | x
Lichtenstein 2002 | x | x | x | x
Lissin 2004 | x | x | | | | | | | x
Mackey 2000 | x | x | x | x
Meinertz 1988 | x | x | x | x
Meinertz 1989 | x | x | x | x
Meinertz 2002 | x | x | x | x | t
Merz-Demlow 2000 | x | x | x | x | x
Meyer 2004 | x | x | x | x | x | x | | | | x
Murkies 1995 | x | | x | x
Murray 2003 | x | x | x | x
Nestel 1997 | x | x | x | x | | | x | x | | | x
Nikander 2003 14602747 | | | | | | | | | x
Nikander 2004 15240647 | x | x | x | x | x | t
Nilausen 1999 | | | | | x
Onning 1998 | x | x | x | x
Petri 2004 | x | x | x | x
Potter 1993 | x | x | x | x
Puska 2002 | x | x | x | x | x | | | | | x
Puska 2004 | x | x | x | x | | x | | | | x
Rivas 2002 | | | | | | x
Sagara 2004 | x | | x | | | x
Scambia 2000 | t | t | t | t
Scheiber 2001 | | | | | | | | | | | x
Shorey 1981 | x | | x | x
Simons 2000 | x | x | x | x | x | x | x
Sirtori 1999 | x | x | t | t | | t
Sirtori 2002 | x | x
Squadrito 2002 | x | x | x | x | | x
Squadrito 2003 | | | | | | | x
Steinberg 2003 | x | x | x | x | | | x | | | | x
Swain 2002 | x | x | x | x | x
Takatsuka 2000 | x | x | x | x
Teede 2001 | x | x | x | x | x | x | x | x
Teede 2004 | | | | | | | | | x
Teixeira 2000 | x | | x | x | x
Tonstad 2002 | x | x | x | x | x | | | | | x
Uesugi 2002 | x | x | x | x
Uesugi 2003 | x | | x | x
Upmalis 2000 | t | t | t | t
Van Horn 2001 | x | x | x
Verrillo 1985 | x | x | x | x
Vigna 2000 | x | x | x | x | x | x
Wangen 2001 | x | x | x | x | x
Washburn 1999 | x | x | x | x | | x
Watanabe 2000 11216491 | t | t | t
Wong 1995 | x
Wong 1998 Hyperlipidemia | x | x | x | x
Wong 1998 Normolipidemia | x | x | x | x
Yildirir 2001 | | | | | x | | x

t = results reported in text only, no data reported

TC = total cholesterol; LDL = low density lipoprotein; HDL = high density lipoprotein; Tg = triglycerides; Lp(a) = lipoprotein (a); BP = blood pressure; CRP = C-reactive protein; Hcy = Homocysteine; UI = MEDLINE, EMBASE, or CAB Abstracts unique identifier.

A very large number of cardiovascular risk factors and measures have been investigated in the medical literature. In consultation with the Technical Expert Panel (TEP), we have focused our review to those outcomes that have either been commonly examined in studies of soy consumption or are of particular interest in relation to soy consumption. We also tracked the number studies that have investigated a defined list of outcomes of secondary interest. Table 5 lists the outcomes included here and the other tracked outcomes, along with the number of studies found for each outcome. The numbers of non-analyzed, tracked studies are estimates only, as errors in tracking these outcomes were not systematically searched for.

The reviewed risk factors and measures are discussed in the following, largely arbitrary, order: lipids [total cholesterol, low density lipoprotein (LDL), high density lipoprotein (HDL), triglycerides, lipoprotein (a) [Lp(a)]], blood pressure, C-reactive protein (CRP), homocysteine, non-serum diagnostic tests (endothelial function and systemic arterial compliance), followed by oxidized LDL. All analyzed studies are shown in Table 6. Those studies indicated with the letter “t” reported qualitative data on the given outcomes (e.g., “no significant effect”), but did not report quantitative data.

We also searched for prospectively designed studies that investigated the effectiveness of soy consumption for reducing clinical cardiovascular disease or events. However, no such studies were found.

Studies of low-calorie diets designed to promote weight loss were excluded from analyses of cardiovascular risk factors and measures because of the strong effect such diets exert on all analyzed cardiovascular outcomes. None of the remaining studies reported substantial weight loss by study subjects; thus, we did not attempt to further exclude studies based on weight loss. Furthermore, because of the great number of studies that reported data on total cholesterol, LDL, HDL, and triglycerides, we employed stricter eligibility criteria for these outcomes. We analyzed only randomized trials that analyzed at least 10 subjects who consumed a soy product. Tables 5 and 6 reflect these eligibility criteria.

### 3.2.2. Lipids: Total Cholesterol

(Tables 7–10)

Table 7 Effect of soy product diets on total cholesterol (mg/dL) in subjects with hyperlipidemia (Baseline LDL>130 mg/dL or TC>200 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 12145008 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 41 | 261 | -17 | | NS | -9 | <0.01 | post♀♂ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | 258 | -18 | | | -10 | <0.01
| | Low fat dairy+egg protein | | | | | | | 264 | -8
Potter 1993 | 4 wk | ISP + cellulose | | | | | 50 | 25 | 228 | -18 | <0.5 | nd | -26 | <0.01 ^ b ^ | ♂ | | C
| | ISP + cotyledon | | | | | 50 | | | -17 | <0.05 | | -25 | <0.01 ^ b ^
| | Soy flour | | | | | 0 | | | -11 | NS | | -19 | <0.05 ^ b ^
| | Non-fat dry milk +cellulose | | | | | | | | +8 | NS
Diet | RCT | Dairy
Crouse 1999 | 9 wk | ISP w/Isoflavones | | | | 62 | 25 | 30 | 243^c^ | -10 | | NS | -11 | <0.05 | ♀♂ | | B
| | ISP w/Isoflavones | | | | 37 | 25 | 30 | 235 | -4 | | | -5 | NS | (LDL 140–200)
| | ISP w/Isoflavones | | | | 27 | 25 | 27 | 248 | -8 | | | -9 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 28 | 239 | -3 | | | -4 | NS
| | Casein | | | | | | 31 | 240 | +1
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 261^c^ | -24 | | <0.04 Trend | -24 | <0.03 | ♀♂
| | ISP w/Isoflavones | | | | 37 | 25 | 12 | 260 | -20 | | | -20 | <0.03 | LDL 166–200
| | ISP w/Isoflavones | | | | 27 | 25 | 15 | 264 | -14 | | | -14 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 12 | 261 | -9 | | | -9 | NS
| | Casein | | | | | | 16 | 258 | 0
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 226 | +4 | | NS | +3 | NS | ♀♂
| | ISP w/Isoflavones | | | | 37 | 25 | 18 | 219 | +6 | | | +5 | NS | LDL 140–166
| | ISP w/Isoflavones | | | | 27 | 25 | 12 | 229 | -2 | | | -3 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 16 | 223 | +1 | | | 0 | NS
| | Casein | | | | | | 15 | 221 | +1
Teixeira 2000 | 6 wk | ISP w/Isoflavones | | | | 95 | 50 | 15 | 242 | -8 | | nd | -16 | 0.03 | ♂ | | A
| | ISP w/Isoflavones | | | | 76 | 40 | 18/17 ^d^ | 230 | -1 | | | -9 | NS
| | ISP w/Isoflavones | | | | 57 | 30 | 18 | 232 | -4 | | | -12 | 0.04
| | ISP w/Isoflavones | | | | 38 | 20 | 15 | 231 | -4 | | | -12 | 0.04
| | Calcium caseinate | | | | | | 16 | 235 | +8 | NS
Van Horn 2001 | 6 wk | ISP w/Isoflavones + oats | 39 | 19 | | | 19 | 32 | 238 | -8 | <0.02 | | +1 | NS | post♀ | | B
| | Milk+ oats | | | | | | 32 | 244 | -9 | <0.02
| | ISP w/Isoflavones + wheat | 39 | 19 | | | 19 | 31 | 234 | 0 | NS | | 0 | NS
| | Milk+wheat | | | | | | 32 | 240 | 0 | NS
Baum 1998 | 24 wk | ISP w/Isoflavones | 35 | 23 | 6 | 90 | 40 | 21 | 250 | -13 | | nd | -6 | NS | post♀ | | B
| | ISP w/o Isoflavones | 2 | 1 | 2 | 56 | 40 | 23 | 254 | -15 | | | -8 | NS
| | Casein +non-fat dry milk | | | | | | 22 | 242 | -7
Vigna 2000 | 12 wk | ISP w/Isoflavones | | | | 76 | 40 | 40 | 246 | -16 | <0.01 | | 0 | | post♀ | | C
| | Caseinate | | | | | | 37 | 253 | -16 | <0.01
Diet | Xover | Animal/Usual
Lichtenstein 2002 ^e^ | 6 wk | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^f^ | 42 | 238 | +3 | | NS | -9 | Soy: 0.02 | post♀♂ | | B
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^f^ | | | +8 | | | -4 | Iso: NS ^ b ^
| | Animal w/Isoflavones ^e^ | 27 | 21 | 4 | 52 | 0 | | | +10 | | | -2
| | Animal w/o Isoflavones | | | | | | | | +12
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^f^ | 22 | nd | 258^g^ | | nd | -19 ^ b ^ | Soy: 0.001 | post♀♂
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^f^ | | | 268^g^ | | | -9 ^ b ^ | Iso: 0.02 ^ b ^
| | Animal w/Isoflavones ^e^ | 27 | 21 | 4 | 52 | 0 | | | 272^g^ | | | -5 ^ b ^ | | LDL>160
| | Animal w/o Isoflavones | | | | | | | | 277^g^
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^f^ | 20 | nd | 222^g^ | | nd | +2 ^ b ^ | Soy: NS | post♀
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^f^ | | | 222^g^ | | | +2 ^ b ^ | Iso: NS ^ b ^ | ♂
| | Animal w/Isoflavones ^e^ | 27 | 21 | 4 | 52 | 0 | | | 221^g^ | | | +1 ^ b ^ | | LDL<160
| | Animal w/o Isoflavones | | | | | | | | 220^g^
Ashton 2000 11194529 | 4 wk | ISP diet | 84 | 35 | | 120 | 36 | 42 | 224 | -14 | | | -9 | 0.03 ^ b ^ | ♂ | | C
| | Lean meat diet | | | | | | | | -5
Azadbakht 2003 | 7 wk | ISP diet | | | | | 19 | 14 | 201 | -13 | <0.05 | | -16 | <0.01 | ♀♂ DM Proteinuria | | B
| | Usual diet | | | | | | | 197 | +4 | <0.05
Wong 1998 ^h^ | 5 wk | ISP diet | | | | | >15% | 13 | 262 | -15 | | | +4 | NS | ♂ | | B
| | Animal diet | | | | | | | 264 | -11
Goldberg 1982 | 6 wk | ISP diet | | | | | 91 | 12 | 260 | -40 | <0.0001 | | -8 | <0.05 ^ b ^ | ♀♂ | | B
| | Animal diet | | | | | | | | -32 | <0.0001
Wong 1995 | 4 wk | ISP diet | | | | | >15% | 12 | 273 | -41 ^j^ | | | -33 | | ♂ | | C
| | Animal diet | | | | | | | | -8 ^j^
Diet | RCT | Animal/Usual
Chiechi 2002 11836040 | 26 wk | ISP diet ^k^ | | | | 47 | | 58/24 ^d^ | 236 | -9 | NS | | +6 | 0.07 | post♀ | | C
| | Usual diet ^k^ | | | | | | 55/43 ^d^ | 220 | -3 | NS
Shorey 1981 | 6 wk | ISP diet | | | | | 55 | 13 | 241 | -16 | 0.03 | | +6 | | ♂ | | C
| | Animal diet | | | | | | 11 | 221 | -22 | 0.002
Diet | Xover | Miscellaneous
Jenkins 1999 | 4 wk | ISP diet | | | | | 33 | 31 | 250 | -27 | | | - 16 | <0.001 | post♀♂ | | B
| | Vegetarian diet | | | | | | | 248 | -10
Diet | RCT | Miscellaneous
Sagara 2004 | 5 wk | Soy powder baked goods | | | | 80 | 20 | 25 | 240 | -15 | <0.05 | | -10 | NS | ♂ | | B
| | Usual baked goods | | | | | | 25 | 232 | -5 | NS
Murkies 1995 | 12 wk | Soy flour | | | | | | 23 | 235 | -10 | NS | | -1 | NS | post♀ | | B
| | Wheat flour | | | | | | 24 | 229 | -9 | NS
Diet | RCT | No Control
Verrillo 1985 ^L^ | 16 wk | ISP, supplement ^L^ | | | | | 31 | 38 | 336 | -100 | <0.01 | NS | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein | | | | | 31 | 19 | 340 | -100 | <0.01 | | --
| | No control group | | | | | | --

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Difference of final values (cross-over study)

c Minor discrepancy between text and table. In text baseline value for all subjects reported as 241 mg/dL; within-cohort change the same. In text baseline value for “high-LDL” subjects reported as 260 mg/dL; within-cohort change the same.

d N: baseline/final.

e Lichtenstein: In both Isoflavone and ISP tables.

f Women/Men

g Final values. No data on baseline or change from baseline.

h Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

j Graph

k No data on how fat content of 2 diets compare.

L Verrillo: In both diet and supplement tables.

Table 8 Effect of soy product supplements on total cholesterol (mg/dL) in subjects with hyperlipidemia (Baseline LDL>130 mg/dL or TC>200 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Dairy
Bricarello 2004 | 6 wk | Soy milk^b^ | 50 | 33 | 5 | 87 | 25 | 60 | 241 | -4 | NS | | -4 | NS | ♀♂ | | C
| | Non-fat milk^b^ | | | | | | | | 0 | NS
Kurowska 1997 | 4 wk | Soy milk | | | | | 31 | 34 | 265 | +2 | | | -3 | NS | ♀♂ | | B
| | Milk, 2% fat | | | | | | | | +5
Blum 2003 12659466 | 6 wk | ISP w/Isoflavones | | | | 85 | 25 | 24 | 270 | -30 | 0.0001 | | + 2 | NS ^ c ^ | post♀ | | C
| | Total milk protein | | | | | | | | -32
Meyer 2004 | 5 wk | Soy milk/yogurt | | | | 80 | 30 | 23 | 232 | -7 | | | 0 | NS ^ c ^ | post♀♂ | | B
| | Low fat milk/yogurt | | | | | | | | -7
Bakhit 1994 | 4 wk | ISP + cellulose | | | | | 25 | 21 | 222 | -4 | NS | | -8 | NS ^ d ^ | ♂ | | C
| | ISP + cotyledon | | | | | 25 | | | 0 | NS | | + 2
| | Casein + cellulose | | | | | | | | +4 | NS
| | Casein + cotyledon | | | | | | | | -2 | NS
| | ISP + cellulose | | | | | 25 | 11 | 239 | -16 | <0.05 | | -9 | 0.04 ^ d ^ | ♂
| | ISP + cotyledon | | | | | 25 | | | -19 | <0.05 | | -5 | | TC>220
| | Casein + cellulose | | | | | | | | -7 | NS
| | Casein + cotyledon | | | | | | | | -14 | NS
Sirtori 1999 | 4 wk | Soy milk | 20 | 11 | 1 | 32 | 35 | 21 | 337 ^e^ | -21 ^f^ | <0.05 | | -12 | <0.05 | ♀♂ | | C
| | Milk, high protein | | | | | | | | -9 ^ g ^ | NS
Hermansen 2001 | 6 wk | ISP w/Isoflavones | | | | >165 | 50 | 20 | 219 | -22 | | | -17 | 0.08 ^ h ^ | ♀♂ DM | | C
| | Casein | | | | | | | 216 | -5
Sirtori 2002 | 4 wk | Soy milk | 25 | 28 | 24 | 77 | 25 | 20 | 314 | -6 | NS | | -9 | NS | ♀♂ | | B
| | Milk | | | | | | | 318 | +3 | NS
Cuevas 2003 | 8 wk | ISP w/Isoflavones | 48 | 24 | 8 | 80 | <40 | 18 | 286 | -46 | <0.05 | | +4 | NS ^ c ^ | post♀ | | B
| | Caseinate | | | | | | | | -42 | <0.05
Supplement | RCT | Dairy
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 86 | 228 | -21 | <0.05 | | -6 | NS | post♀♂ | | B
| | Casein | | | | | | 93 | 228 | -15 | <0.05
Kreijkamp-Kaspers 2004 | 52 wk | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88^j^ | 240 | -1 | | | +6 | NS | post♀ | | A
| | Total milk protein | | | | | | 87^j^ | 236 | -3
Puska 2004 | 8 wk | ISP w/Isoflavones | | | | 153 | 41 | 69 | 291 | -16 | | | -15 | <0.001 | post♀♂ | | B
| | Yogurt | | | | | | 74 | 293 | -1
Supplement | RCT | Dairy
Tonstad 2002 | 16 wk | ISP w/Isoflavones | | | | 185 | 50 | 31 | 252 | -35 | | nd | -9 | 0.01 | post♀♂ | | B
| | ISP w/Isoflavones | | | | 111 | 30 | 34 | 265 | -33
| | Casein, 50 g | | | | | | 36 | 264 | -21
| | Casein 30 g | | | | | | 29 | 266 | -30
Gardner 2001 | 12 wk | ISP w/Isoflavones | 52 | 25 | 4 | 80 | 42 | 31 | 228 | -10 | | 0.03 | -2 | NS | post♀ | | B
| | ISP w/o Isoflavones | 2 | 1 | 0 | 3 | 42 | 33 | 228 | -1 | | | 7 | NS
| | Milk protein | | | | | | 30 | 236 | -8
Dent 2001 | 24 wk | ISP w/Isoflavones | | | | 80 | 40 | 24 | 209 ^e^ | 0 | | NS | 0 | NS | peri♀ | | B
| | ISP w/o Isoflavones | | | | 4 | 40 | 24 | 217 ^e^ | -6 | | | -6
| | Whey protein | | | | | | 21 | 212 ^e^ | 0
Puska 2002 | 6 wk | ISP w/Isoflavones | | | | 96 | 52 | 24 | 290 | -25 | | | -10 | 0.05 | post♀♂ | | C
| | Calcium caseinate | | | | | | 28 | 297 | -15
Supplement | Xover | Miscellaneous
Jayagopal 2002 | 12 wk | ISP w/Isoflavones | 70 | 49 | 13 | 132 | 30 | 31 | 223 | -9 | <0.05 | | -15 | 0.004 | post♀ DM | | B
| | Cellulose | | | | | | | 217 | +6 | NS
Gardner-Thorpe 2003 | 6 wk | Soy flour biscuits | 45 | 75 | | 120 | | 19 | 212 | -8 | | | 0 | NS^ c ^ | ♂ | | B
| | Wheat flour biscuits | | | | | | | | -8
Supplement | Xover | No Control
Wangen 2001 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 18 | 215 | -22 | 0.0004 | NS ^c^ | -- | | post♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | 18/17 ^k^ | | -24 | 0.0004 | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | 18 | | -18 | 0.0006 | | --
| | No control group | | | | | | --
Supplement | RCT | No Control
Gallagher 2004 | 39 wk | ISP w/Isoflavones | 52 | 28 | | 96 | 40 | 17 | 221 | 3 | NS | nd | -- | | post♀ | | C
| | ISP w/Isoflavones | 28 | 20 | | 52 | 40 | 19 | 220 | -7 | NS | | --
| | ISP w/o Isoflavones | 4 | 0 | | 4 | 40 | 14 | 213 | 0 | NS | | --
| | No control group | | | | | | --
Mackey 2000 | 12 wk | ISP w/Isoflavones | | | | 65 | 28 | 25 | 281 | -14 | NS | nd | -- | | post♀ | | B
Female study | | ISP w/o Isoflavones | | | | 4 | 28 | 24 | 288 | -12 | | | --
| | No control group | | | | | | --
Verrillo 1985 ^L^ | 16 wk | ISP, supplement | | | | | 31 | 38 | 336 | -100 | <0.01 | NS | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein | | | | | 31 | 19 | 340 | -100 | <0.01 | | --
| | No control group | | | | | | --

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors inestimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Unequal amounts of fat in soy milk (17.5 g/day) and cow milk (0 g/day).

c Difference of final values (cross-over study)

d Main effect of soy protein

e Graph

f Reported that 2 soy cross-over arms combined had decrease in total cholesterol of 6.2% (number used in this table), but that first arm had 6.5% reduction and second arm had 7.4% reduction.

g Average reduction in 2 milk cross-over arms (-3.9% and –1.6%), assuming baselines were the same for both arms.

h P=0.004 for difference between final values.

j Intention-to-treat analysis (75 completed soy protocol, 78 completed control protocol)

k N: baseline/final.

L Verrillo: In both diet and supplement tables.

Table 9 Effect of soy isoflavones (without soy protein) on total cholesterol (mg/dL) in subjects with hyperlipidemia (Baseline LDL>130 mg/dL or TC>200 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | Base value | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Animal/Usual
Lichtenstein 2002 ^b^ | 6 wk | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 42 | 238 | +3 | | NS | -9 | Soy: 0.02 Iso: NS^d^ | post♀ ♂ | | B
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | +8 | | | -4
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | +10 | | | -2
| | Animal w/o Isoflavones | | | | | | | | +12
| | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 22 | nd | 258^e^ | | nd | -19 ^ d ^ | Soy: 0.001 Iso: 0.02 ^d^ | post♀ ♂
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | 268^e^ | | | -9 ^ d ^ | | LDL>160
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 272^e^ | | | -5 ^ d ^
| | Animal w/o Isoflavones | | | | | | | | 277^e^
| | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 20 | nd | 222^e^ | | nd | +2 ^ d ^ | Soy: NS Iso: NS ^d^ | post♀ ♂
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | 222^e^ | | | +2 ^ d ^ | | LDL<160
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 221^e^ | | | +1 ^ d ^
| | Animal w/o Isoflavones | | | | | | | | 220^e^
Supplement | Xover | Placebo
Nikander 2004 15240647 | 13 wk | Isoflavones | 6 | 42 | 66 | | 0 | 56 | 227 | +5 | NS | | +3 | | post♀ Breast CA | | A
| | Placebo | | | | | | | 225 | +2 | NS
Nestel 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 21 | 214 | -7 | NS | | +4 | | post♀ | | C
| | Placebo | | | | | | | | -11 | NS
Simons 2000 | 8 wk | Isoflavones | | | | 80 | 0 | 20 | 226 | -16 | | | +3 | NS ^d^ | post♀ | | B
| | Placebo | | | | | | | | -13
Supplement | RCT | Placebo
Han 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 226 | -27 | <0.001 | | -27 | <0.001 | post♀ | | A
| | Placebo | | | | | | 40 | 227 | 0 | NS
Squadrito 2002 | 26 wk | Genistein | 54 | | | | 0 | 30 | 205 | +8 | NS | | +4 | NS | post♀ | | A
| | Placebo | | | | | | 30 | 208 | +4 | NS
Petri 2004 | 26 wk | Soy germ capsules | | | | 60 | 0.8 | 25 | 230 ^f,g^ | -13 | NS | | -13 | | post♀ | | C ^h^
| | Lactose capsules | | | | | | 25 | 204 ^f,g^ | 0 | NS
Lissin 2004 | 6 wk | Isoflavones | 44 | 44 | 2 | 90 | 0 | 20 | 243 | -5 | NS | | +7 | NS | post♀ | | B
| | Placebo | | | | | | 20 | 236 | -12 | <0.05
Dewell 2002 | 26 wk | Isoflavones | 40 | 50 | | 90 | 0 | 20/18 ^j^ | 263 | -15 | | | -3 | NS | post♀ | | C
| | Placebo | | | | | | 16 | 243 | -12
Uesugi 2002 | 4 wk | Isoflavones | 0 | 0 | 0 | 62 ^k^ | 0 | 12 | 226 | -11 | <0.05 | | -14 | NS | peri♀ | | B
| | Placebo | | | | | | 11 | 238 | +3 | NS
Uesugi 2003 | 13 wk | Isoflavones | 0 | 0 | 0 | 62 ^k^ | 0 | 11 | 224 | -5 | | | -4 | NS | post♀ | | B
| | Dextrin | | | | | | 10 | 221 | -1

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Lichtenstein: In both Isoflavone and ISP tables.

c Women/Men

d Difference of final values (cross-over study)

e Final values. No data on baseline or change from baseline.

f Significantly different (P<0.05) at baseline.

g Graph

h In contrast with other outcomes in this article, soy and control ams had significantly different LDL levels.

j N: baseline/final.

k 31 mg daidzin, 7 mg genistin, 21 mg glycitin

Table 10 Effect of soy products on total cholesterol (mg/dL) in subjects with normolipidemia (Baseline LDL<130 mg/dL or TC<200 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Meinertz 2002 | 4.5 wk | ISP w/Isoflavones, liquid | | | | 2.39/g ^b^ | 20% | 12 | 160 | -29 | <0.001 | NS ^c^ | +5 | NS ^c^ | ♀♂ | | C
| | ISP w/o Isoflavones, liquid | | | | 0.11/g ^b^ | 20% | | 161 | -35 | <0.001 | | -1 | NS ^c^
| | Casein diet, liquid | | | | | | | 155 | -34 | <0.001
Meinertz 1989 | 4.5 wk | ISP diet, liquid cholesterol enriched | | | | | 112 | 11 | 171 | -39 | | | -7 | NS ^c^ | ♀♂ | | C
| | Calcium caseinate | | | | | | | | -33
Meinertz 1988 | 4 wk | ISP diet, liquid low cholesterol | | | | | 113 | 10 | 171 | -44 | | | +2 | NS ^c^ | ♀♂ | | C
| | Casein diet, liquid low cholesterol | | | | | | | | -46
Diet | Xover | Animal/Usual
Carroll 1978 | ~5.5 wk | ISP diet | | | | | 75 | 10 | 163 ^d^ | -2 | | | -9 | <0.05 ^c^ | pre♀ | | C
| | Usual diet | | | | | | | | +7
Diet | Xover | Miscellaneous
Wong 1998 ^e^ | 5 wk | ISP diet | | | | | >15% | 13 | 170 | -15 | | | +6 | NS | ♂ | | B
| | Animal diet | | | | | | | 169 | -9
Supplement | Xover | Dairy
Steinberg 2003 | 6 wk | ISP w/Isoflavones | 55 | 47 | 5 | 107 | 25 | 24 | 190 | -3 | | NS | 0 | NS | post♀ | | C
| | ISP w/o Isoflavones | 1 | 0.5 | 0.5 | 2 | 24 | | | 0 | | | +3 | NS
| | Total milk protein | | | | | | | | -3
Supplement | RCT | Dairy
Murray 2003 | 26 wk | ISP + Estradiol 0.5 mg | 66 | 44 | 10 | 120 | 38 | 8 | 212 | +1 | NS | | +3 | NS | post♀ | | C
| | Total milk protein + Estradiol 0.5 mg | | | | | | 7 | 211 | -2 | NS
| | ISP + Estradiol 1.0 mg | 66 | 44 | 10 | 120 | 38 | 8 | 216 | -13 | NS | | +4
| | Total milk protein + Estradiol 1.0 mg | | | | | | 7 | 261 ^f^ | -17 | NS
Supplement | Xover | Miscellaneous
Washburn 1999 | 6 wk | ISP w/Isoflavones once daily | | | | 34 | 14 | 42 | 208 | -9 | | nd | -9 | <0.01 ^c^ | peri♀ | | B
| | ISP w/Isoflavones twice daily | | | | 34 | 14 | | | -12 | | | -12 | <0.01 ^c^
| | Carbohydrates | | | | | | | | 0
Onning 1998 | 4 wk | Soy milk | | | | | 23/30 ^g^ | 12 | 170 | -4 | NS | | +4 | | ♀♂ | | B
| | Oat milk | | | | | | | | -8 | NS
Supplement | RCT | Miscellaneous
Takatsuka 2000 | 9 wk | Soy milk | | | | 109 | 17 | 27 | 177 | -11 | 0.004 | | -11 | 0.02 | pre♀ | | B
| | No supplement | | | | | | 25 | 177 | 0 | NS
Supplement | Xover | No Control
Merz-Demlow 2000 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 13 | 144 | -5 | | NS | -- | | pre♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | | | +2 | | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | | | +4 | | | --
| | No control group | | | | | | --

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors inestimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Per gram protein. No data on number of grams of protein.

c Difference of final values (cross-over study)

d Calculated mean of graphically displayed values for each cross-over arm. “Final” results are mean value of levels measured twice weekly.

e Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

f Significantly higher at baseline than other study arms because of single outlier with hypertriglyceridemia.

g Women/Men

h Measurements made at 4 menstrual cycle phases: early follicular, midfollicular, periovulatory, midluteal. Data extracted for periovulatory only. LDL change was greatest during this phase in high isoflavone group.

Abnormal levels of serum lipids, primarily low density lipoprotein (LDL), high density lipoprotein (HDL), and triglycerides (Tg) have long been recognized as an independent risk factor for cardiovascular disease (CVD). Of interest is whether soy protein and isoflavone consumption would be of value for improving lipid levels as part of a therapeutic lifestyle change, or at least that it would not be detrimental. Recent National Cholesterol Education Program (NCEP) guidelines recommend a goal for fasting total cholesterol of less than 200 mg/dL in all adults with lower levels recommended for people at elevated risk for CVD, including diabetics, smokers, people with hypertension or family history of premature CVD, or beyond middle age. ^44^

#### Study Descriptions

Lipid levels are the most commonly measured CVD risk factor in trials of soy consumption. We found 67 unique randomized trials that met eligibility criteria and reported data on the effect of soy products on lipid levels in at least 10 subjects who consumed soy [not including studies of Lp(a)]; of these 63 reported quantitative data (See Tables 5 and 6).

We found 65 studies that reported on the effect of the consumption of soy products on total cholesterol. Of these, 4 reported only that there was no effect on total cholesterol.^45^– ^48^ The remaining 61 studies are described below. ^23,^ ^24,^ ^49^ – ^106^

For ease of categorization, we have divided the studies into separate tables as follows: 19 studies investigated dietary soy protein in subjects with abnormal lipids (mean LDL > 130 mg/dL or total cholesterol > 200 mg/dL, Table 7); 22 studies investigated soy protein used as dietary supplements in subjects with abnormal lipids (Table 8); 11 studies investigated pure soy isoflavones in subjects with abnormal lipids (Table 9); 11 studies investigated soy protein in subjects with normolipidemia (Table 10). No studies investigated pure isoflavones in subjects with normolipidemia. Some studies included cohorts of subjects in multiple categories.

The range of daily soy isoflavone intake among studies of soy products with isoflavones was approximately 10 to 185 mg, with a median of 80 mg per day. The range of daily soy protein intake among relevant studies was approximately 14 to 113 g, with a median of 38 g per day. Most studies of hyperlipidemic subjects included post-menopausal women and/or men. The studies of normolipidemic subjects were more likely to include both men and women or be restricted to pre-menopausal women. The large majority of studies were of limited applicability, even within the categories of pre- or post-menopausal women, or men. Only 12 of the studies were graded as being broadly applicable. Among the 61 studies, 5 were rated good quality (A), 32 were rated fair quality (B), and 24 were rated poor quality (C)..

#### Overall Effect

Across the 61 studies there was a wide range of effects of soy products on total cholesterol, although in most studies the net effect was negative, indicating that compared to control consumption of soy products resulted in reductions in total cholesterol. Approximately two-thirds of the cohorts of subjects consuming soy had a net reduction of total cholesterol compared to control. Across studies, net change ranged from -33 to +7 mg/dL, with the median net change equal to -6 mg/dL. In terms of percent net change (using the baseline level in the soy intervention cohort as the denominator), net change ranged from approximately -12% to +4%, with a median net change equal to -2.5%.

#### Soy Product, Dose, Other Variables

Analyses across studies

Figure 2 graphs the net change compared to non-soy control of all cohorts evaluated (that included a non-soy cohort). The left-most graph displays net change in total cholesterol in relationship the baseline total cholesterol level; this graph includes all studies. The middle graph compares net change to daily soy isoflavone consumption (among those studies that report isoflavone content). The right-most graph compares net change to daily soy protein consumption (among those studies that report soy protein content). Study cohorts who consumed soy with isoflavones are indicated by squares; cohorts who consumed soy without isoflavones are indicated by circles; and cohorts who consumed soy isoflavone without soy protein are indicated by triangles. Black symbols represent cohorts where the soy product was consumed as part of the regular diet; open symbols represent cohorts where the soy product was consumed as a supplement to the diet (including soy milk products). Larger symbols indicate cohorts whose mean total cholesterol or LDL was elevated at baseline; smaller symbols indicate cohorts with normal total cholesterol and/or LDL at baseline.

Figure 2. Net change of total cholesterol with soy product consumption compared to control, by baseline level, isoflavone content, and soy protein content. Studies without non-soy control are not included. Studies without data on isoflavone or protein content are omitted from relevant graphs. ISP w/Iso = soy protein with isoflavones; ISP w/o Iso = soy protein without isoflavones; suppl = supplement

Visual inspection of the graphs reveal no difference across studies in net effect on total cholesterol (as mg/dL or % change) based on baseline total cholesterol levels, amount of soy isoflavones consumed, or amount of soy protein consumed. Likewise, there are no clear differences across studies based on whether the soy products were consumed as part of the diet (i.e., specifically replacing other sources of protein) or as a supplement (consumed in addition to regular diet). Also comparing the net effects of soy protein with isoflavones to soy protein without isoflavones to isoflavones without soy protein reveals similar ranges of effects for all 3 types of products. Because of the relative weakness of total cholesterol as a cardiovascular risk factor as compared to LDL, HDL, and triglycerides, meta-analysis was not performed.

Effect of baseline total cholesterol on net change total cholesterol in individual studies

Three studies performed sub-analyses comparing the effect of soy products on total cholesterol in subjects with different baseline levels. In contrast to the apparent lack of a relationship across studies, all 3 studies - Crouse 1999 ^51^ (Table 7) in a study of hyperlipidemic men and women, Bakhit 1994 ^72^ (Table 8) in a study of mildly hyperlipidemic men, and Lichtenstein 2002 ^56^ (Tables 7 and 9) in a study of men and post-menopausal women - found significantly greater reductions in total cholesterol among the subjects with worse lipid levels (LDL above 166 mg/dL or total cholesterol above 220 mg/dL, or LDL above 160 mg/dL, respectively).

Effect of soy isoflavone dose on net change total cholesterol in individual studies

Fourteen studies ^49,^ ^51,^ ^52,^ ^54,^ ^56,^ ^80^ – ^82,^ ^86^ – ^88,^ ^98,^ ^102,^ ^106^ directly compared soy products with different levels of isoflavones, ranging from 0 mg/day to 185 mg/day. Most studies found similar within-cohort or net effects regardless of isoflavone dose. Only 2 studies reported statistically significant differences among cohorts with different isoflavone doses. Gardner 2001 ^81^ (Table 8) found that post-menopausal women who consumed soy protein with 80 mg isoflavones had a decrease in total cholesterol of 10 mg/dL, while those who consumed soy protein without isoflavones had a decrease of only 1 mg/dL; while neither of the changes was statistically different than control, the cohort with higher isoflavone consumption had a significantly greater reduction than the cohort with lower isoflavone consumption. Crouse 1999 ^51^ (Table 7) also reported a statistically significant relationship between soy isoflavone intake (ranging from 3 mg/day to 62 mg/day) and change in total cholesterol, but only among those men and women with above-median (166 mg/dL) LDL. Among those subjects with less severely abnormal lipids, the trend was not evident.

Effect of soy protein dose on net change total cholesterol in individual studies

Four studies directly compared soy products with different amounts of soy protein. ^50,^ ^52,^ ^56,^ ^80^ The doses compared ranged from 0 g/day to 55 g/day in women and 71 g/day in men. The conclusions regarding the relative effects of different doses of soy protein were mixed. Both Teixera 2000 ^52^ (Table 7) who compared 4 doses between 20 and 50 mg/day in men, and Tonstad 2002 ^80^ (Table 8) who compared 30 and 50 mg/day in men and post-menopausal women reported no clinically or statistically significant relationship between soy protein dose and effect on total cholesterol. In Potter 1993 ^50^ (Table 7) a greater and more statistically significant effect occurred when the men consumed 50 mg/day of soy protein compared to when they consumed soy flour without protein; however, the study did not report whether the difference among cohorts was statistically significant. Finally, Lichtenstein 2002 ^56^ (Tables 7 and 9) in a study of factorial design in men and post-menopausal women found that the consumption of soy protein significantly decreased total cholesterol (as opposed to the consumption of soy isoflavones).

Effect of soy as diet vs. supplement on net change total cholesterol in individual studies

Only a single study directly compared consumption of soy product as a replacement of dietary protein to soy product as a supplement to usual diet. Verrillo 1985 ^67^ (Tables 7 and 8) found very large reductions in total cholesterol in men and women with very elevated baseline levels; however, the same effect was seen regardless of the mode of soy consumption. Since there was no non-soy control arm, it is difficult to ascertain the explanation for the one-third drop in cholesterol levels.

Effect of sex and menopausal status on net change total cholesterol

Across studies, there was no clear difference in effect evident based on sex or menopausal status of the subjects. Four studies directly compared effects in different populations (data not included in summary tables). Crouse 1999 ^51^ (Table 7) reported that post-menopausal women consuming soy protein with the highest dose of isoflavones (62 mg) had borderline significant reduction (-7%, P=0.06) in total cholesterol in contrast to the pre-menopausal women. Jenkins 2002 ^49^ (Table 7) reported no significant difference in effect between men and women. Both Onning 1998 ^104^ (Table 10) and Teede 2001 ^77^ (Table 8) reported data suggesting no clinical difference in effect between men and women.

#### Summary

See Section 3.2.6.

### 3.2.3. Lipids: Low Density Lipoprotein

(Tables 11–15, Figures 3–5)

Table 11 Effect of soy product diets on low density lipoprotein (mg/dL) in subjects with hyperlipidemia (Baseline LDL>130 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | g/day | | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 12145008 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 41 | 176 | -16 | | NS | -10 | <0.01 | post♀ ♂ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | 175 | -13 | | | -7 | <0.01
| | Low fat dairy+egg protein | | | | | | | 178 | -6
Potter 1993 | 4 wk | ISP + cellulose | | | | | 50 | 24 | 175 | -14 | NS | nd | -18 | <0.01 ^ b ^ | ♂ | | C
| | ISP + cotyledon | | | | | 50 | | | -15 | <0.05 | | -19 | <0.01 ^ b ^
| | Soy flour | | | | | 0 | | | -9 | NS | | -13 | NS ^ b ^
| | Non-fat dry milk+cellulose | | | | | | | | +4 | NS
Diet | RCT | Dairy
Crouse 1999 | 9 wk | ISP w/Isoflavones | | | | 62 | 25 | 30 | 166^c^ | -10 | | NS | -10 | <0.05 | ♀♂ (LDL 140-200) | | B
| | ISP w/Isoflavones | | | | 37 | 25 | 30 | 161 | -5 | | | -5 | NS
| | ISP w/Isoflavones | | | | 27 | 25 | 28 | 170 | -5 | | | -4 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 27 | 164 | -4 | | | -5 | NS
| | Casein | | | | | | 31 | 165 | 0
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 185^c^ | -22 ^ c ^ | | <0.04 Trend | -20 ^ c ^ | <0.03 | ♀♂ LDL 166-200
| | ISP w/Isoflavones | | | | 37 | 25 | 12 | 182 | -17 | | | -15 | <0.03
| | ISP w/Isoflavones | | | | 27 | 25 | 12 | 186 | -12 | | | -10 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 15 | 185 | -10 | | | -8 | NS
| | Casein | | | | | | 16 | 182 | -2
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 147 | +1 | | NS | -2 | NS | ♀♂ LDL 140–166
| | ISP w/Isoflavones | | | | 37 | 25 | 16 | 146 | +4 | | | +1 | NS
| | ISP w/Isoflavones | | | | 27 | 25 | 18 | 150 | +4 | | | +1 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 12 | 148 | +1 | | | -2 | NS
| | Casein | | | | | | 15 | 146 | +3
Van Horn 2001 | 6 wk | ISP w/Isoflavones + oats | 39 | 19 | | | 19 | 32 | 150 | -10 | <0.02 | | -1 | | post♀ | | B
| | Milk+ oats | | | | | | 32 | 155 | -9 | <0.02
| | ISP w/Isoflavones + wheat | 39 | 19 | | | 19 | 31 | 147 | 0 | NS | | +1
| | Milk + wheat | | | | | | 32 | 151 | -1 | NS
Vigna 2000 | 12 wk | ISP w/Isoflavones | | | | 76 | 40 | 40 | 159 | -14 | <0.01 | | -2 | | post♀ | | C
| | Caseinate | | | | | | 37 | 167 | -12 | <0.01
Diet | Xover | Animal/Usual
Lichtenstein 2002 ^d^ | 6 wk | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^e^ | 42 | 160 | +6 | | <0.05 | -5 | Soy: 0.04 Iso: NS ^ b ^ | post♀ ♂
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^e^ | | | +8 | | | -3
| | Animal w/Isoflavones ^d^ | 27 | 21 | 4 | 52 | 0 | | | +12 | | | +1
| | Animal w/o Isoflavones | | | | | | | | +11
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^e^ | 22 | >160 | 181 ^f^ | | nd | -14 ^ b ^ | Soy: 0.003 Iso: NS ^ d ^ | post♀ ♂ LDL>160 | | B
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^e^ | | | 186 ^f^ | | | -9 ^ b ^
| | Animal w/Isoflavones ^d^ | 27 | 21 | 4 | 52 | 0 | | | 192 ^f^ | | | -3 ^ b ^
| | Animal w/o Isoflavones | | | | | | | | 195 ^f^
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^e^ | 20 | <160 | 148 ^f^ | | nd | +5 ^ b ^ | Soy: NS Iso: NS ^ d ^ | post♀ ♂ LDL<160
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^e^ | | | 147 ^f^ | | | +4 ^ b ^
| | Animal w/Isoflavones ^d^ | 27 | 21 | 4 | 52 | 0 | | | 149 ^f^ | | | +6 ^ b ^
| | Animal w/o Isoflavones | | | | | | | | 143 ^f^
Ashton 2000 10694766 | 4 wk | ISP diet | 84 | 35 | | 120 | 36 | 42 | 142 | -8 | <0.05 | | +3 | <0.05 ^ b ^ | ♂ | | B
| | Lean meat diet | | | | | | | | -5 | NS
Azadbakht 2003 | 7 wk | ISP diet | | | | | 19 | 14 | 145 | -6 | <0.05 | | -8 | <0.04 | ♀♂ DM Proteinuria | | B
| | Usual diet | | | | | | | 144 | +2 | NS
Wong 1998 ^g^ | 5 wk | ISP diet | | | | | >15% | 13 | 181 | -23 | | | -9 | 0.03 | ♂ | | B
| | Animal diet | | | | | | | 182 | -14
Goldberg 1982 | 6 wk | ISP diet | | | | | 91 | 12 | 191 | -33 | <0.0001 | | -10 | <0.05 ^ b ^ | ♀♂ | | B
| | Animal diet | | | | | | | | -23 | <0.001
Diet | RCT | Animal/Usual
Chiechi 2002 11836040 | 26 wk | ISP diet^h^ | | | | 47 | | 58/24 ^j^ | 159 | -6 | NS | | -6 | | post♀ | | C
| | Usual diet^h^ | | | | | | 55/43 ^j^ | 145 | 0 | NS
Diet | Xover | Miscellaneous
Jenkins 1999 | 4 wk | ISP diet | | | | | 33 | 31 | 170 | -21 | | | -11 | <0.001 | post♀ ♂ | | B
| | Vegetarian diet | | | | | | | 169 | -9
Diet | RCT | No Control
Verrillo 1985 ^k^ | 16 wk | ISP, supplement ^k^ | | | | | 31 | 38 | 243 | -89 | <0.01 | NS | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein | | | | | 31 | 19 | 259 | -100 | <0.01 | | --
| | No control group | | | | | | --

a Or difference between final values, as noted.

b Difference of final values (cross-over study)

c Minor discrepancy between text and table. In text baseline value for all subjects reported as 165 mg/dL; within-cohort change the same. In text baseline value for “high-LDL” subjects reported as 181 mg/dL; within-cohort change reported as -18 mg/dL, implying a net change of -16 mg/dL.

d Lichtenstein: In both Isoflavone and ISP tables.

e Women/Men

f Final values. No data on baseline or change from baseline.

g Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

h No data on how fat content of 2 diets compare.

j N: baseline/final.

k Verrillo: In both diet and supplement tables.

Table 12 Effect of soy product supplements on low density lipoprotein (mg/dL) in subjects with hyperlipidemia (Baseline LDL>130 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P. btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Dairy
Bricarello 2004 | 6 wk | Soy milk^b^ | 50 | 33 | 5 | 87 | 25 | 60 | 157 | -9 | | | -10 | <0.05 | ♀♂ | | C
| | Non-fat milk^b^ | | | | | | | | +1
Kurowska 1997 | 4 wk | Soy milk | | | | | 31 | 34 | 172 | -7 | | | -4 | NS | ♀♂ | | B
| | Milk, 2% fat | | | | | | | | -3
Blum 2003 12659466 | 6 wk | ISP w/Isoflavones | | | | 85 | 25 | 24 | 178 | -36 | <0.0001 | | +5 | NS ^ c ^ | post♀ | | C
| | Total milk protein | | | | | | | | -41
Meyer 2004 | 5 wk | Soy milk/yogurt | | | | 80 | 30 | 23 | 159 | -8 | | | -2 | NS ^ c ^ | post♀ ♂ | | B
| | Low fat milk/yogurt | | | | | | | | -6
Bakhit 1994 | 4 wk | ISP + cellulose | | | | | 25 | 21 | 158 | -3 | NS | | -8 | NS ^ d ^ | ♂ | | C
| | ISP + cotyledon | | | | | 25 | | | 0 | NS | | +2
| | Casein + cellulose | | | | | | | | 5 | NS
| | Casein + cotyledon | | | | | | | | -2 | NS
| | ISP + cellulose | | | | | 25 | 11 | 169 | -9 | NS | | -8 | 0.07 ^ d ^ | ♂ TC>220
| | ISP + cotyledon | | | | | 25 | | | -11 | NS | | -1
| | Casein + cellulose | | | | | | | | -1 | NS
| | Casein + cotyledon | | | | | | | | -10 | NS
Sirtori 1999 | 4 wk | Soy milk | 20 | 11 | 1 | 32 | 35 | 21 | 247 ^e^ | -19 | <0.05 | | -11 | <0.05 | ♀♂ | | C
| | Milk, high protein | | | | | | | | -8 | NS
Hermansen 2001 | 6 wk | ISP w/Isoflavones | | | | >165 | 50 | 20 | 140 | -24 | | | -12 | 0.048 ^ f ^ | ♀♂ DM | | C
| | Casein | | | | | | | 141 | -12
Sirtori 2002 | 4 wk | Soy milk | 25 | 28 | 24 | 77 | 25 | 20 | 226 | +7 | NS | | -3 | NS | ♀♂ | | B
| | Milk | | | | | | | 225 | +10 | NS
Cuevas 2003 | 8 wk | ISP w/Isoflavones | 48 | 24 | 8 | 80 | <40 | 18 | 195 | -35 | <0.05 | | -1 | NS ^ c ^ | post♀ | | B
| | Caseinate | | | | | | | | -34 | <0.05
Supplement | RCT | Dairy
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 86 | 151 | -16 | <0.05 | | -5 | NS | post♀ ♂ | | B
| | Casein | | | | | | 93 | 147 | -11 | <0.05
Kreijkamp-Kaspers 2004 | 52 wk | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88^g^ | 161 | -1 | | | +5 | | post♀ | | A
| | Total milk protein | | | | | | 87^g^ | 159 | -6
Puska 2004 | 8 wk | ISP w/Isoflavones | | | | 153 | 41 | 69 | 197 | -14 | | | -15 | <0.001 | post♀ ♂ | | B
| | Yogurt | | | | | | 74 | 198 | +2
Tonstad 2002 | 16 wk | ISP w/Isoflavones | | | | 185 | 50 | 31 | 177 | -37 | | nd | -10 | 0.01 | post♀ ♂ | | B
| | ISP w/Isoflavones | | | | 111 | 30 | 34 | 186 | -34
| | Casein, 50 g | | | | | | 29 | 192 | -30
| | Casein 30 g | | | | | | 36 | 188 | -21
Gardner 2001 | 12 wk | ISP w/Isoflavones | 52 | 25 | 4 | 80 | 42 | 31 | 151 | -15 | | 0.01 | -3 | NS | post♀ | | B
| | ISP w/o Isoflavones | 2 | 1 | 0 | 3 | 42 | 33 | 151 | -3 | | | 9 | NS
| | Milk protein | | | | | | 30 | 154 | -12
Supplement | RCT | Dairy
Dent 2001 | 24 wk | ISP w/Isoflavones | | | | 80 | 40 | 24 | 127 ^e^ | +6 | | NS | +4 | NS | peri♀ | | B
| | ISP w/o Isoflavones | | | | 4 | 40 | 24 | 135 ^e^ | +1 | | | -1
| | Whey protein | | | | | | 21 | 134 ^e^ | +2
Puska 2002 | 6 wk | ISP w/Isoflavones | | | | 96 | 52 | 24 | 198 | -26 | | | -10 | <0.05 | post♀ ♂ | | C
| | Calcium caseinate | | | | | | 28 | 199 | -16
Supplement | Xover | Miscellaneous
Jayagopal 2002 | 12 wk | ISP w/Isoflavones | 70 | 49 | 13 | 132 | 30 | 31 | 140 | -10 | <0.05 | | -17 | 0.001 | post♀ DM | | B
| | Cellulose | | | | | | | 134 | +7 | 0.05
Gardner-Thorpe 2003 | 6 wk | Soy flour biscuits | 45 | 75 | | 120 | | 19 | 139 | -4 | | | +6 | NS ^ c ^ | ♂ | | B
| | Wheat flour biscuits | | | | | | | | -10
Supplement | Xover | No Control
Wangen 2001 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 18 | 136 | -20 | 0.0003 | 0.02 ^c^ | -- | | post♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | 18/17 ^h^ | | -18 | 0.0006 | 0.07 ^c^ | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | 18 | | -12 | 0.02 | -- | --
| | No control group | | | | | | --
Supplement | RCT | No Control
Gallagher 2004 | 39 wk | ISP w/Isoflavones | 52 | 28 | | 96 | 40 | 17 | 141 | +3 | NS | nd | -- | | post♀ | | C
| | ISP w/Isoflavones | 28 | 20 | | 52 | 40 | 19 | 138 | + 3 | NS | | --
| | ISP w/o Isoflavones | 4 | 0 | | 4 | 40 | 14 | 134 | -1 | NS | | --
| | No control group | | | | | | --
Mackey 2000 Female study | 12 wk | ISP w/Isoflavones | | | | 65 | 28 | 25 | 196 | -14 | 0.04 | nd | -- | | post♀ | | B
| | ISP w/o Isoflavones | | | | 4 | 28 | 24 | 197 | -13 | | | --
| | No control group | | | | | | --
Verrillo 1985 ^j^ | 16 wk | ISP, supplement | | | | | 31 | 38 | 243 | -89 | <0.01 | NS | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein ^j^ | | | | | 31 | 19 | 259 | -100 | <0.01 | | --
| | No control group | | | | | | --

a Or difference between final values, as noted.

b Unequal amounts of fat in soy milk (17.5 g/day) and cow milk (0 g/day).

c Difference of final values (cross-over study)

d Main effect of soy protein

e Graph

f P=0.004 for difference between final values.

g Intention-to-treat analysis (75 completed soy protocol, 78 completed control protocol)

h N: baseline/final.

j Verrillo: In both diet and supplement tables.

Table 13 Effect of soy isoflavones (without soy protein) on low density lipoprotein (mg/dL) in subjects with hyperlipidemia (Baseline LDL>130 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Animal/Usual
Lichtenstein 2002 ^b^ | 6 wk | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 42 | 160 | +6 | | <0.05 | -5 | Soy: 0.04 Iso: NS ^ d ^ | post♀ ♂ | | B
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | +8 | | | -3
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | +12 | | | +1
| | Animal w/o Isoflavones | | | | | | | | +11
| | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 22 | >160 | 181^e^ | | nd | -14 ^ d ^ | Soy: 0.003 Iso: NS ^ d ^ | post♀ ♂ LDL>160
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | 186^e^ | | | -9 ^ d ^
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 192^e^ | | | -3 ^ d ^
| | Animal w/o Isoflavones | | | | | | | | 195^e^
| | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 20 | <160 | 148^e^ | | nd | +5 ^ d ^ | Soy: NS Iso: NS ^ d ^ | post♀ ♂ LDL<160
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | 147^e^ | | | +4 ^ d ^
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 149^e^ | | | +6 ^ d ^
| | Animal w/o Isoflavones | | | | | | | | 143^e^
Supplement | Xover | Placebo
Nikander 2004 15240647 | 13 wk | Isoflavones | 6 | 42 | 66 | | 0 | 56 | 149 | +11 | NS | | +13 | NS | post♀ Breast CA | | A
| | Placebo | | | | | | | 147 | -2 | NS
| | Isoflavones | 6 | 42 | 66 | | 0 | 28 | >162 | +25 | | | +42 | 0.009 | post♀ Breast CA LDL>162
| | Placebo | | | | | | | | -17
Nestel 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 21 | 138 | -5 | NS | | +3 | | post♀ | | C
| | Placebo | | | | | | | | -8 | NS
Simons 2000 | 8 wk | Isoflavones | | | | 80 | 0 | 20 | 152 | -13 | | | -3 | NS ^ d ^ | post♀ | | B
| | Placebo | | | | | | | | -10
Supplement | RCT | Placebo
Han 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 134 | -13 | <0.001 | | -19 | <0.001 | post♀ | | A
| | Placebo | | | | | 0 | 40 | 134 | +6 | NS
Squadrito 2002 | 26 wk | Genistein | 54 | | | | 0 | 30 | 139 | 0 | NS | | +4 | NS | post♀ | | A
| | Placebo | | | | | | 30 | 147 | -4 | NS
Petri 2004 | 26 wk | Soy germ capsules | | | | 60 | 0.8 | 25 | 152 ^f,g^ | -20 | <0.05 | | -32 | | post♀ | | C ^h^
| | Lactose capsules | | | | | | 25 | 131 ^f,g^ | +12 | NS
Lissin 2004 | 6 wk | Isoflavones | 44 | 44 | 2 | 90 | 0 | 20 | 163 | -1 | NS | | +8 | NS | post♀ | | B
| | Placebo | | | | | | 20 | 165 | -9 | <0.05
Uesugi 2002 | 4 wk | Isoflavones | 0 | 0 | 0 | 62 ^j^ | 0 | 12 | 148 | -10 | <0.05 | | -12 | NS | peri♀ | | B
| | Placebo | | | | | | 11 | 162 | +2 | NS

a Or difference between final values, as noted.

b Lichtenstein: In both Isoflavone and ISP tables.

c Women/Men

d Difference of final values (cross-over study)

e Final values. No data on baseline or change from baseline.

f Significantly different (P<0.05) at baseline.

g Graph

h In contrast with other outcomes in this article, soy and control ams had significantly different LDL levels.

j 31 mg daidzin, 7 mg genistin, 21 mg glycitin

Table 14 Effect of soy products on low density lipoprotein (mg/dL) in subjects with normolipidemia (Baseline LDL<130 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Meinertz 2002 | 4.5 wk | ISP w/Isoflavones, liquid | | | | 2.39/g ^b^ | 20% | 12 | 83 | -21 | <0.001 | NS ^c^ | -6 | NS ^ c ^ | ♀♂ | | C
| | ISP w/o Isoflavones, liquid | | | | 0.11/g ^b^ | 20% | | 84 | -18 | <0.01 | | -3 | NS ^ c ^
| | Casein diet, liquid | | | | | | | 79 | -15 | <0.01
Meinertz 1989 | 4.5 wk | ISP diet, liquid cholesterol enriched | | | | | 112 | 11 | 102 | -32 | | | -16 | 0.02 ^ c ^ | ♀♂
| | Calcium caseinate | | | | | | | | -19
Meinertz 1988 | 4 wk | ISP diet, liquid low cholesterol | | | | | 113 | 10 | 110 | -42 | | | +1 | NS ^ c ^ | ♀♂ | | C
| | Casein diet, liquid low cholesterol | | | | | | | | -43
Diet | Xover | Animal/Usual
Wong 1998 ^d^ | 5 wk | ISP diet | | | | | >15% | 13 | 111 | -13 | | | -8 | 0.03 | ♂ | | B
| | Animal diet | | | | | | | 109 | -5
Supplement | Xover | Dairy
Steinberg 2003 | 6 wk | ISP w/Isoflavones | 55 | 47 | 5 | 107 | 25 | 24 | 112 | -1 | | NS | -3 | NS | post♀ | | C
| | ISP w/o Isoflavones | 1 | 0.5 | 0.5 | 2 | 24 | | | -1 | | | -3 | NS
| | Total milk protein | | | | | | | | +2
Supplement | RCT | Dairy
Murray 2003 | 26 wk | ISP + Estradiol 0.5 mg | 66 | 44 | 10 | 120 | 38 | 8 | 120 | 0 | NS | | +7 | NS | post♀ | | C
| | Total milk protein+ Estradiol 0.5 mg | | | | | | 7 | 125 | -7 | NS
| | ISP + Estradiol 1.0 mg | 66 | 44 | 10 | 120 | 38 | 8 | 129 | -22 | NS | | -26
| | Total milk protein + Estradiol 1.0 mg | | | | | | 7 | 164 ^e^ | +4 | NS
Supplement | Xover | Miscellaneous
Washburn 1999 | 6 wk | ISP w/Isoflavones once daily | | | | 34 | 14 | 42 | 127 | -8 | | nd | -9 | <0.05 ^ c ^ | peri♀ | | B
| | ISP w/Isoflavones twice daily | | | | 34 | 14 | | | -10 | | | -9 | <0.01 ^ c ^
| | Carbohydrates | | | | | | | | -2
Onning 1998 | 4 wk | Soy milk | | | | | 23/30 ^f^ | 12 | 112 | -8 | <0.05 | | -4 | | ♀♂ | | B
| | Oat milk | | | | | | | | -4 | NS
Supplement | RCT | Miscellaneous
Takatsuka 2000 | 9 wk | Soy milk | | | | 109 | 17 | 27 | 91 | -5 | NS | | -8 | NS | pre♀ | | B
| | No supplement | | | | | | 25 | 94 | +3 | NS
Supplement | Xover | No Control
Merz-Demlow 2000 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 13 | 84 ^g^ | -5 | | <0.05 | -- | | pre♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | | | +2 | | -- | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | | | +4 | | -- | --
| | No control group | | | | | | --

a Or difference between final values, as noted.

b Per gram protein. No data on number of grams of protein.

c Difference of final values (cross-over study)

d Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

e Non-significantly higher at baseline than other study arms because of single outlier with hypertriglyceridemia.

f Women/Men

g Measurements made at 4 menstrual cycle phases: early follicular, midfollicular, periovulatory, midluteal. Data extracted for periovulatory only. LDL change was greatest during this phase in high isoflavone group.

Table 15 Summary of sub-group analyses of adjusted linear regressions for low density lipoprotein (LDL)

Association Sub-group of studies | | No. of Studies ^a^ | Association Beta (95% CI) | P-value ^b^
Baseline LDL v Net Change LDL
All studies | All studies | 59 | | NS
| LDL >130 mg/dL | 45 | -0.14 (-0.28, +0.00) | 0.06
Isoflavone only | All studies | 11 | | NS
| LDL >130 mg/dL | 11 | | NS
Protein w/Isoflavones | All studies | 42 ^c^ | | NS ^c^
| LDL >130 mg/dL | 30 | -0.10 (-0.23, +0.02) | 0.09
Soy Isoflavone Dose v Net Change LDL
All studies | All studies | 43 | | NS
| LDL >130 mg/dL | 34 | | NS
Isoflavone only | All studies | 10 | | NS
| LDL >130 mg/dL | 10 | | NS
Protein w/Isoflavones | All studies | 27 | | NS
| LDL >130 mg/dL | 20 | | NS
Soy Protein Dose v Net Change LDL ^ c ^
All studies | All studies | 52 | -0.10 (-0.20, +0.01) | 0.08
| LDL >130 mg/dL | 41 | -0.14 (-0.27, -0.00) | 0.04
| Dose >10 g/day | 43 | | NS
Protein w/Isoflavones | All studies | 38 | | NS
| LDL >130 mg/dL | 28 | -0.16 (-0.33, +0.02) | 0.08
| Dose <80 g/day | 35 | -0.16 (-0.33, +0.02) | 0.07

a Studies with sufficient data for adjusted linear regression.

b All associations were non-significant in multivariate analysis with baseline LDL, isoflavone dose, and soy protein dose.

c With all 42 studies, beta = -0.07 (95% CI -0.13, -0.00), P=0.05; however, with the omission of a single study (Puska, 2004), which found a large net change (-15 mg/dL) with a high mean baseline (198 mg/dL), the association was non-significant (P=0.4)

Figure 3. Net change of low density lipoprotein (LDL) with soy product consumption compared to control, by baseline level, isoflavone content, and soy protein content. Studies without non-soy control are not included. Studies without data on isoflavone or protein content are omitted from relevant graphs. ISP w/Iso = soy protein with isoflavones; ISP w/o Iso = soy protein without isoflavones; suppl = supplement. Dashed lines represent adjusted regressions for studies with sufficient data for regression. Regression lines are drawn only within the range of independent variable (x-axis) data examined. P-values and number of studies included in regressions are shown. Both regression lines drawn are for all studies with abnormal baseline LDL

Figure 5. Meta-analysis summary estimates of net change low density lipoprotein (LDL) for different sub-analyses, as noted. Point estimate, 95% confidence interval, analysis group, and number of studies in each analysis group displayed

#### Study Descriptions

We found 55 studies that reported on the effect of the consumption of soy products on low density lipoprotein (LDL). Of these, 3 reported only that there was no effect on LDL. ^46^ – ^48^ The remaining 52 studies are described below. ^23,^ ^24,^ ^49^– ^51,^ ^53,^ ^55^ – ^60,^ ^62,^ ^64,^ ^67^ – ^94,^ ^96,^ ^98^ – ^100,^ ^102^ – ^106^

For ease of categorization, we have divided the studies into separate tables as follows: 13 studies investigated dietary soy protein in subjects with elevated LDL (mean >130 mg/dL, Table 11); 22 studies investigated soy protein used as dietary supplements in subjects with elevated LDL (Table 12); 9 studies investigated pure soy isoflavones in subjects with elevated LDL (Table 13); 10 studies investigated soy protein in subjects with normolipidemia (Table 14). No studies investigated pure isoflavones in subjects with normolipidemia. Some studies included cohorts of subjects in multiple categories.

The range of daily soy isoflavone intake among studies of soy products with isoflavones was approximately 10 to 185 mg, with a median of 80 mg per day. The range of daily soy protein intake among relevant studies was approximately 14 to 113 g, with a median of 34 g per day. Most studies of hyperlipidemic subjects included post-menopausal women and/or men. The studies of normolipidemic subjects were more likely to include both men and women or be restricted to pre-menopausal women. The large majority of studies were of limited applicability, even within the categories of pre- or post-menopausal women, or men. Only 11 of the studies were graded as being broadly applicable. Among the 52 studies, 4 were rated good quality (A), 28 were rated fair quality (B), and 20 were rated poor quality (C).

#### Overall Effect

Across the 52 studies there was a wide range of effects of soy products on LDL, although in most studies the net effect was negative, indicating that compared to control consumption of soy products resulted in reductions in LDL. Approximately three-quarters of the cohorts of subjects consuming soy had a net reduction of LDL compared to control (Figure 3). Across studies, net change ranged from -32 to +13 mg/dL, with the median net change equal to -5 mg/dL. In terms of percent net change (using the baseline level in the soy intervention cohort as the denominator), net change ranged from approximately -21% to +9%, with a median net change equal to -3%.

The summary estimate from a random-effects model meta-analysis of all soy cohorts with a non-soy control was statistically significant (Figure 4); the net change in LDL was -5 (95% confidence interval [CI] -7 to -3) mg/dL, where the adjusted summary mean baseline LDL was approximately 150 mg/dL. This finding is in agreement with a recent meta-analysis of the effect of soy products on LDL and HDL by Weggemans et al. (2003) ^107^ , who reported a net change in LDL of -7 (95% CI -10, -3) mg/dL. Our primary meta-analysis differed in that we used looser criteria for inclusion - thus we included about 3 times as many studies. Both of these meta-analyses differ markedly from an early meta-analysis by Anderson et al. (1995) ^1^ which reported a summary net change of -22 (95 % CI -32, -11) mg/dL. However, that meta-analysis used much looser inclusion criteria, including non-randomized trials, studies of children, very small sample sizes, and short intervention durations. Their findings were highly affected by several non-randomized trials and the inclusion of Verrillo 1985 ^67^ (Tables 11 and 12), a study that lacked randomization to a non-soy control.

Figure 4. Meta-analysis of the effect of soy products on low density lipoprotein (LDL) in all randomized trials with non-soy controls. Circles represent net effect on LDL of individual study cohorts vs. non-soy controls; their size is proportional to the square root of the sample size. Black diamond represents summary mean net change using a random effects model meta-analysis. Bars (and values in parentheses) represent 95% confidence intervals. Cohorts are ordered from lowest (top) to highest mean baseline LDL. Sub-analyses of studies with normal and elevated baseline LDL (>130 mg/dL) are also shown (open diamonds). N indicates sample size of subjects consuming soy products

#### Soy Product, Dose, Other Variables

Analyses across studies

Figure 3 graphs the net change compared to non-soy control of all cohorts evaluated (that included a non-soy cohort). In a similar manner as the total cholesterol graph, the left-most graph displays net change in LDL in relationship the baseline LDL; this graph includes all studies. The middle graph compares net change to daily soy isoflavone consumption (among those studies that report isoflavone content). The right-most graph compares net change to daily soy protein consumption (among those studies that report soy protein content). Adjusted regression lines are included.

We ran separate regressions of mean baseline LDL, total soy isoflavones consumed, and total soy protein consumed against net change LDL for studies with abnormal baseline LDL (Table 15). The regressions were adjusted using a random effects model technique; thus studies without sufficient data to estimate net change variance were excluded. Multivariate and univariate analyses were performed for the 3 covariates. Sub-analyses were also performed for studies with abnormal mean baseline LDL (>130 mg/dL) to focus on the effect on those people with hyperlipidemia. As appropriate, sub-analyses were also performed for consumption of isoflavones alone (without soy protein) and soy protein with isoflavones. Because of the small number of such studies, soy protein without isoflavones was not analyzed separately.

All multivariate analyses performed resulted in non-significant associations between the included covariates and net change LDL. Among the numerous univariate meta-regressions performed, only soy protein dose was statistically significantly associated with net change LDL, but only in the sub-group of studies with abnormal baseline LDL (Table 15 and Figure 3, left). Across studies, for each additional 10 grams of soy protein consumed per day, the average net reduction of LDL was 1.4 (95% CI 0.0, 2.7) mg/dL greater. Inclusion of studies with lower baseline LDL reduced the degree and significance of the association.

Furthermore, inclusion either of only studies with soy protein (dose >10 g/day) or only studies of protein with isoflavones yielded no association between protein dose and net change LDL. Excluding either soy protein with isoflavone studies of lower baseline LDL or the few outlier studies of higher protein dose (>80 g/day) yielded similar trends toward an association between higher dose soy protein and greater net reduction of LDL.

Evaluation of the effect of baseline LDL on net change LDL across studies revealed no association; however in sub-group of studies with elevated LDL (within the range of about 135 to 200 mg/dL), there was a trend suggesting that for studies with mean baseline LDL 10 mg/dL higher than other studies, the average net LDL reduction was 1.4 (95% CI 0, 2.8) mg/dL greater. This trend was similar for studies of protein with isoflavones and higher baseline LDL levels, but not for studies of isoflavones alone. No meta-regression analysis found an association between soy isoflavone dose and net change LDL.

These analyses, however, are subject to biases due to analyzing mean values across studies. In addition, these analyses are combining data from a very heterogeneous group of studies in regards to subject populations, soy products, and controls, among other factors. In all analyses, the studies were found to be statistically significantly heterogeneous. Associations may be either exaggerated or minimized because of the heterogeneity.

We also performed meta-analyses of sub-groups of studies based on study quality, baseline LDL, type of soy product, and soy diet versus soy supplement (Figure 5). All sub-group meta-analyses were grossly similar. While the studies rated of poor quality did, on average, find a larger effect of soy products than better quality studies, the difference in effects was not statistically significantly different (P=0.2). Of note, the studies that evaluated soy isoflavones without soy protein had a high degree of heterogeneity with mean net changes in LDL ranging from -32 mg/dL to +13 mg/dL (or +42 mg/dL in the subset of women with elevated baseline LDL).

Effect of baseline LDL on net change LDL in individual studies

The 4 studies that performed sub-analyses comparing the effect of soy products on LDL in subjects with different baseline levels came to a different conclusions. Crouse 1999 ^51^ (Table 11) found a greater benefit (with higher isoflavone-dose) in a study of hyperlipidemic men and women with above median LDL (166 mg/dL). Lichtenstein 2002 ^56^ (Tables 11 and 13) in a study of men and post-menopausal women also found a larger, significant effect among those with elevated LDL (>160 mg/dL) in contrast to those with lower LDL. Bakhit 1994 ^72^ (Table 12) in a study of mildly hyperlipidemic men found essentially the same effect among those with elevated total cholesterol (>220 mg/dL) as the whole cohort. Nikander 2004 ^89^ (Table 13) in a study of post-menopausal women with a history of treated breast cancer found that the sub-group of women who had above median LDL (162 mg/dL) soy isoflavone consumption resulted in a statistically significant increase in LDL. This was in contrast to a smaller, non-significant net increase for the cohort as a whole.

Effect of soy isoflavone dose on net change LDL in individual studies

Twelve studies ^49,^ ^51,^ ^56,^ ^80^ – ^82,^ ^86^ – ^88,^ ^98,^ ^102,^ ^106^ directly compared soy products with different levels of isoflavones, ranging from 0 mg/day to 185 mg/day. Most studies found similar within-cohort or net effects regardless of isoflavone dose. Only 4 studies reported statistically significant differences among cohorts with different isoflavone doses. Gardner 2001 ^81^ (Table 12) found that post-menopausal women who consumed soy protein with 80 mg isoflavones had a decrease in LDL of 15 mg/dL while those who consumed soy protein without isoflavones had a decrease of only 3 mg/dL; while neither of the changes was statistically different than control, the cohort with higher isoflavone consumption had a significantly greater reduction than the cohort with lower isoflavone consumption. Crouse 1999 ^51^ (Table 11) reported a statistically significant relationship between soy isoflavone intake (ranging from 3 mg/day to 62 mg/day) and change in LDL, but only among those men and women with above-median (166 mg/dL) LDL. Among those subjects with less severely elevated LDL, the trend was not evident, although the effect was greatest in the high isoflavone cohort. In a cross-over study, Merz-Demlow 2000 ^106^ (Table 14) compared 3 soy supplements with different levels of isoflavones in pre-menopausal, normolipidemic women. Only during the period where the women consumed the highest isoflavone supplement did their LDL levels fall, by an amount significantly different than changes during consumption of the other, lower isoflavone, periods. Similarly, Wangen 2001 ^86^ (Table 12) in a cross-over study of 3 soy supplements with different levels of isoflavone in post-menopausal women found progressively greater decreases in LDL during periods with higher isoflavone consumption. Of note, a meta-regression performed by Weggemans et al. (2003) ^107^ found no dose-response relation between changes in soy isoflavone intake and changes in LDL.

Meta-analysis of studies comparing 2 or more soy products with different levels of isoflavones

We performed random effects model meta-analyses of the 11 studies that reported sufficient data comparing 2 or more soy products with different levels of isoflavones. ^49,^ ^51,^ ^56,^ ^81,^ ^82,^ ^86^ – ^88,^ ^98,^ ^102,^ ^106^ In one analysis we included all cohorts with soy protein. This analysis is faulty in that it allows comparison of multiple high-isoflavone cohorts to the same low-isoflavone cohort, thus breaking the assumption of independence between all studies. Nevertheless, the summary net difference in effect on LDL was small and non-significant at -3 (95% CI -6, +1) mg/dL. In a second analysis, where we compared only the highest isoflavone dose cohort to the lowest, the net difference was similarly small and non-significant at -3 (95 % CI -8, +1) mg/dL. These results are in contrast to a recently published meta-analysis by Zhuo et al. (2004) ^43^ largely because of the addition of the recently published Gallagher 2004 ^87^ and Dent 2001, ^82^ which was excluded because of a too long study duration, and Meinertz 2002, ^98^ which might have been excluded because the amount of isoflavones is poorly reported. Importantly, all these studies found no difference in effect.

Effect of soy protein dose on net change LDL in individual studies

Three studies directly compared soy products with different amounts of soy protein. ^56,^ ^80,^ ^108^ The doses compared ranged from 0 g/day to 55 g/day in women and 71 g/day in men. Two of the 3 studies reported a difference in effect based on level of soy protein consumption. In Potter 1993 ^50^ (Table 11) a greater and more statistically significant effect occurred when the men consumed 50 mg/day of soy protein compared to when they consumed soy flour without protein; however, the study did not report whether the difference among cohorts was statistically significant. Lichtenstein 2002 ^56^ (Tables 11 and 13) in a study of factorial design in men and post-menopausal women found that the consumption of soy protein significantly decreased LDL (as opposed to the consumption of soy isoflavones). In contrast, Tonstad 2002 ^80^ (Table 12) who compared 30 and 50 mg/day in men and post-menopausal women reported no clinically or statistically significant relationship between soy protein dose and effect on LDL. Weggemans et al. (2003) ^107^ also found no association between dose of soy protein consumption and change in LDL.

Effect of soy as diet vs. supplement on net change LDL in individual studies

Only a single study directly compared consumption of soy product as a replacement of dietary protein to soy product as a supplement to usual diet. Verrillo 1985 ^67^ (Tables 11 and 12) found very large reductions in LDL in men and women with very elevated baseline levels; however, the same effect was seen regardless of the mode of soy consumption. Since there was no non-soy control arm, it is difficult to ascertain the explanation for the greater than one-third drop in LDL levels. Meta-analysis of the dietary soy products alone (Figure 5) yielded a summary net change in LDL of -7 (95% CI -9, -4) mg/dL, which was somewhat greater than the net change among the soy supplements studies, -4 (95% CI -7, -1) mg/dL.

Effect of sex and menopausal status on net change LDL

Across studies, there was no clear difference in effect evident based on sex or menopausal status of the subjects. Four studies directly compared effects in different populations (data not included in summary tables). Crouse 1999 ^51^ (Table 11) reported that post-menopausal women consuming soy protein with the highest dose of isoflavones (62 mg) had borderline significant reduction (–8%, P=0.07) in LDL in contrast to the pre-menopausal women. Jenkins 2002 ^49^ (Table 11) reported no significant difference in effect between men and women. Both Onning 1998 ^104^ (Table 14) and Teede 2001 ^77^ (Table 12) reported data suggesting no clinical difference in effect between men and women.

#### Summary

See Section 3.2.6.

### 3.2.4. Lipids: High Density Lipoprotein

(Tables 16–19, Figures 6–7)

Table 16 Effect of soy product on high density lipoprotein (mg/dL) in subjects with abnormal HDL (Baseline HDL<50 in women / <40 in men)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Potter 1993 | 4 wk | ISP + cellulose | | | | | 50 | 24 | 37 | -2 | NS | nd | 0 | NS ^b^ | ♂ | | C
| | ISP + cotyledon | | | | | 50 | | | -2 | NS | | 0 | NS ^b^
| | Soy flour | | | | | 0 | | | 0 | NS | | +2 | NS ^b^
| | Non-fat dry milk+ cellulose | | | | | | | | -2 | NS
Diet | Xover | Animal/Usual
Wong 1998 | 5 wk | ISP diet | | | | | >15% | 13 | 39 | -2 | | | +3 | NS | ♂ | | B
| | Animal diet | | | | | | | 41 | -5
Supplement | Xover | Miscellaneous
Gardner-Thorpe 2003 | 6 wk | Soy flour biscuits | 45 | 75 | | 120 | | 19 | 39 | +4 | | | 0 | NS ^b^ | ♂ | | B
| | Wheat flour biscuits | | | | | | | | +4
Onning 1998 | 4 wk | Soy milk | | | | | 23/30 ^d^ | 12 | 42 | 0 | NS | | 0 | | ♀♂ | | B
| | Oat milk | | | | | | | | 0 | NS
Supplement | Xover | No Control
Merz-Demlow 2000 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 13 | 48 ^e^ | +1 | | NS | -- | | pre♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | | | +1 | | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | | | 0 | | | --
| | No control group | | | | | | --

a Or difference between final values, as noted.

b Difference of final values (cross-over study)

c Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

d Women/Men

e Measurements made at 4 menstrual cycle phases: early follicular, midfollicular, periovulatory, midluteal. Data extracted for periovulatory only. LDL change was greatest during this phase in high isoflavone group.

Table 17 Effect of soy product diets on high density lipoprotein (mg/dL) in subjects with normal HDL (Baseline HDL>50 in women/>40 in men)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 12145008 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 41 | 51 | -3 | | NS | +1 | <0.01 | post♀ ♂ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | 51 | -2 | | | +2 | <0.05
| | Low fat dairy+egg protein | | | | | | | 51 | -4
Meinertz 2002 | 4.5 wk | ISP w/Isoflavones, liquid | | | | 2.39/g ^b^ | 20% | 12 | 61 | -7 | NS | NS ^c^ | +3 | <0.05 ^ c ^ | ♀♂ | | C
| | ISP w/o Isoflavones, liquid | | | | 0.11/g ^b^ | 20% | | 60 | -8 | NS | | +2 | NS ^ c ^
| | Casein diet, liquid | | | | | | | 59 | -10 | <0.05
Meinertz 1989 | 4.5 wk | ISP diet, liquid cholesterol enriched | | | | | 112 | 11 | 58 | -2 | | | +9 | <0.01 ^ c ^ | ♀♂ | | C
| | Calcium caseinate | | | | | | | | -10
Meinertz 1988 | 4 wk | ISP diet, liquid low cholesterol | | | | | 113 | 10 | 47 | 0 | | | +1 | NS ^ c ^ | ♀♂ | | C
| | Casein diet, liquid low cholesterol | | | | | | | | -1
Diet | RCT | Dairy
Crouse 1999 | 9 wk | ISP w/Isoflavones | | | | 62 | 25 | 30 | 46 | +1 | | NS | +2 | NS | ♀♂ (LDL 140-200) | | B
| | ISP w/Isoflavones | | | | 37 | 25 | 30 | 45 | +1 | | | +2 | NS
| | ISP w/Isoflavones | | | | 27 | 25 | 27 | 45 | 0 | | | +1 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 28 | 47 | -1 | | | 0 | NS
| | Casein | | | | | | 31 | 45 | -1
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 46 | -1 | | NS | +1 | NS | ♀♂ LDL 166–200
| | ISP w/Isoflavones | | | | 37 | 25 | 12 | 48 | -2 | | | 0 | NS
| | ISP w/Isoflavones | | | | 27 | 25 | 15 | 45 | +2 | | | +4 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 12 | 45 | -2 | | | 0 | NS
| | Casein | | | | | | 16 | 48 | -2
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 47 | +2 | | <0.04 Trend | +2 | NS | ♀♂ LDL 140–166
| | ISP w/Isoflavones | | | | 37 | 25 | 18 | 42 | +4 | | | +4 | NS
| | ISP w/Isoflavones | | | | 27 | 25 | 12 | 44 | 0 | | | 0 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 16 | 48 | 0 | | | 0 | NS
| | Casein | | | | | | 15 | 41 | 0
Teixeira 2000 | 6 wk | ISP w/Isoflavones | | | | 95 | 50 | 15 | 44 | +1 | | nd | +1 | NS | ♂ | | A
| | ISP w/Isoflavones | | | | 76 | 40 | 17 | 43 | +2 | | | +2 | NS
| | ISP w/Isoflavones | | | | 57 | 30 | 18 | 44 | +2 | | | +2 | NS
| | ISP w/Isoflavones | | | | 38 | 20 | 15 | 41 | +1 | | | +1 | NS
| | Calcium caseinate | | | | | | 16 | 42 | 0 | NS
Diet | RCT | Dairy
Baum 1998 | 24 wk | ISP w/Isoflavones | 35 | 23 | 6 | 90 | 40 | 21 | 53 | +2 | | nd | +4 | <0.03 | post♀ | | B
| | ISP w/o Isoflavones | 2 | 1 | 2 | 56 | 40 | 23 | 52 | +3 | | | +5 | <0.01
| | Casein + non-fat dry milk | | | | | | 22 | 53 | -2
Vigna 2000 | 12 wk | ISP w/Isoflavones | | | | 76 | 40 | 40 | 61 | 0 | NS | | +1 | | post♀ | | C
| | Caseinate | | | | | | 37 | 62 | -1 | NS
Van Horn 2001 | 6 wk | ISP w/Isoflavones + oats | 39 | 19 | | | 19 | 32 | 61 | 0 | NS | | +1 | | post♀ | | B
| | Milk + oats | | | | | | 32 | 67 | -1 | NS
| | ISP w/Isoflavones + wheat | 39 | 19 | | | 19 | 31 | 64 | 0 | NS | | +1
| | Milk + wheat | | | | | | 32 | 63 | -1 | NS
Diet | Xover | Animal/Usual
Lichtenstein 2002 ^d^ | 6 wk | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^e^ | 42 | 51 | 0 | | NS | -2 | Soy: 0.03 | post♀ | | B
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^e^ | | | 0 | | | -2 | Iso: NS ^ c ^ | ♂
| | Animal w/Isoflavones ^d^ | 27 | 21 | 4 | 52 | 0 | | | +2 | | | 0
| | Animal w/o Isoflavones | | | | | | | | +2
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^e^ | 22 | nd | 55 ^f^ | | nd | -1 ^ c ^ | Soy: NS | post♀
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^e^ | | | 56 ^f^ | | | 0 ^ c ^ | Iso: NS ^ c ^ | ♂
| | Animal w/Isoflavones ^d^ | 27 | 21 | 4 | 52 | 0 | | | 53 ^f^ | | | -3 ^ c ^ | | LDL>160
| | Animal w/o Isoflavones | | | | | | | | 56 ^f^
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71 ^e^ | 20 | nd | 49 ^f^ | | nd | +2 ^ c ^ | Soy: 0.04 | post♀
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^e^ | | | 49 ^f^ | | | +2 ^ c ^ | Iso: NS ^ c ^ | ♂
| | Animal w/Isoflavones ^d^ | 27 | 21 | 4 | 52 | 0 | | | 48 ^f^ | | | +1 ^ c ^ | | LDL<160
| | Animal w/o Isoflavones | | | | | | | | 47 ^f^
Ashton 2000 11194529 | 4 wk | ISP diet | 84 | 35 | | 120 | 36 | 42 | 48 | 0 | | | -3 | 0.01 ^ c ^ | ♂ | | C
| | Lean meat diet | | | | | | | | +3
Azadbakht 2003 | 7 wk | ISP diet | | | | | 19 | 14 | 47 | +3 | <0.05 | | +2 | NS | ♀♂ | | B
| | Usual diet | | | | | | | 46 | +1 | NS | | | | DM Proteinuria
Wong 1998 ^g^ | 5 wk | ISP diet | | | | | >15% | 13 | 41 | -3 | | | 0 | NS | ♂ | | B
| | Animal diet | | | | | | | 41 | -3
Goldberg 1982 | 6 wk | ISP diet | | | | | 91 | 12 | 45 | -1 | NS | | -1 | NS ^ c ^ | ♀♂ | | B
| | Animal diet | | | | | | | | 0 | | NS
Diet | RCT | Animal/Usual
Chiechi 2002 11836040 | 26 wk | ISP diet^h^ | | | | 47 | | 58/24 ^j^ | 52 | -2 | NS | | +2 | | post♀ | | C
| | Usual diet^h^ | | | | | | 55/43 ^j^ | 55 | -4 | <0.05
Shorey 1981 | 6 wk | ISP diet | | | | | 55 | 13 | 52 | -8 | 0.001 | | -4 | | ♂ | | C
| | Animal diet | | | | | | 11 | 46 | -4 | NS
Diet | Xover | Miscellaneous
Jenkins1999 | 4 wk | ISP diet | | | | | 33 | 31 | 49 | -3 | | | 0 | NS | post♀ | | B
| | Vegetarian diet | | | | | | | 48 | -3 | | | | | ♂
Diet | RCT | Miscellaneous
Murkies 1995 | 12 wk | Soy flour | 40 g of flour per day | | | | | 23 | 67 | -2 | NS | | 0 | NS | post♀ | | B
| | Wheat flour | | | | | | 24 | 63 | -2 | NS
Sagara 2004 | 5 wk | Soy powder baked goods | | | | 80 | 20 | 25 | 54 | +4 | <0.01 | | -1 | 0.06 | ♂ | | B
| | Usual baked goods | | | | | | 25 | 55 | +5 | <0.01
Diet | RCT | No Control
Verrillo 1985 ^k^ | 16 wk | ISP, supplement ^k^ | | | | | 31 | 38 | 54 | -4 | | nd | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein | | | | | 31 | 19 | 50 | 4 | | | --
| | No control group | | | | | | --

a Or difference between final values, as noted.

b Per gram protein. No data on number of grams of protein.

c Difference of final values (cross-over study)

d Lichtenstein: In both Isoflavone and ISP tables.

e Women/Men

f Final values. No data on baseline or change from baseline.

g Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

h No data on how fat content of 2 diets compare.

j N: baseline/final.

k Verrillo: In both diet and supplement tables.

Table 18 Effect of soy product supplements on high density lipoprotein (mg/dL) in subjects with normal HDL (Baseline HDL>50 in women / >40 in men)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Dairy
Bricarello 2004 | 6 wk | Soy milk^b^ | 50 | 33 | 5 | 87 | 25 | 60 | 58 | +4 | <0.05 | | +5 | <0.05 | ♀♂ | | C
| | Non-fat milk^b^ | | | | | | | | -1
Kurowska 1997 | 4 wk | Soy milk | | | | | 31 | 34 | 51 | +3 | | | +3 | 0.04 | ♀♂ | | B
| | Milk, 2% fat | | | | | | | | 0
Blum 2003 12659466 | 6 wk | ISP w/Isoflavones | | | | 85 | 25 | 24 | 60 | -1 | NS | | -3 | NS ^d^ | post♀ | | C
| | Total milk protein | | | | | | | | +2
Steinberg 2003 | 6 wk | ISP w/Isoflavones | 55 | 47 | 5 | 107 | 25 | 24 | 60 | -2 | | NS | -4 | NS | post♀ | | C
| | ISP w/o Isoflavones | 1 | 0.5 | 0.5 | 2 | 24 | | | 0 | | | -2 | NS
| | Total milk protein | | | | | | | | +2
Meyer 2004 | 5 wk | Soy milk/yogurt | | | | 80 | 30 | 23 | 49 | +3 | | | +2 | NS ^d^ | post♀ | | B
| | Low fat milk/yogurt | | | | | | | | 0 | | | | | ♂
Bakhit 1994 | 4 wk | ISP + cellulose | | | | | 25 | 21 | 51 | -1 | NS | | 0 | NS ^c^ | ♂ | | C
| | ISP + cotyledon | | | | | 25 | | | -1 | NS | | +1
| | Casein + cellulose | | | | | | | | -1 | NS
| | Casein + cotyledon | | | | | | | | -2 | NS
| | ISP + cellulose | | | | | 25 | 11 | 53 | -3 | NS | | -3 | NS ^c^ | ♂
| | ISP + cotyledon | | | | | 25 | | | -3 | NS | | 0 | | TC>220
| | Casein + cellulose | | | | | | | | 0 | NS
| | Casein + cotyledon | | | | | | | | -3 | NS
Hermansen 2001 | 6 wk | ISP w/Isoflavones | | | | >165 | 50 | 20 | 51 | +3 | | | +1 | NS | ♀♂ | | C
| | Casein | | | | | | | 49 | +2 | | | | | DM
Supplement | Xover | Dairy
Cuevas 2003 | 8 wk | ISP w/Isoflavones | 48 | 24 | 8 | 80 | <40 | 18 | 54 | -1 | NS | | +2 | NS ^d^ | post♀ | | B
| | Caseinate | | | | | | | | -3 | <0.05
Supplement | RCT | Dairy
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 86 | 56 | -2 | NS | | +2 | NS | post♀ | | B
| | Casein | | | | | | 93 | 58 | -4 | <0.05 | | | | ♂
Kreijkamp-Kaspers 2004 | 52 wk | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88^e^ | 59 | 0 | | | +2 | 0.09 | post♀ | | A
| | Total milk protein | | | | | | 87^e^ | 59 | -2
Puska 2004 | 8 wk | ISP w/Isoflavones | | | | 153 | 41 | 69 | 64 | +2 | | | 0 | NS | post♀ | | B
| | Yogurt | | | | | | 74 | 66 | +2 | | | | | ♂
Gardner 2001 | 12 wk | ISP w/Isoflavones | 52 | 25 | 4 | 80 | 42 | 31 | 58 | +4 | | NS | +4 | NS | post♀ | | B
| | ISP w/o Isoflavones | 2 | 1 | 0 | 3 | 42 | 33 | 54 | +4 | | | +4 | NS
| | Milk protein | | | | | | 30 | 58 | 0
Tonstad 2002 | 16 wk | ISP w/Isoflavones | | | | 185 | 50 | 31 | 52 | +5 | | nd | +2 | NS | post♀ | | B
| | ISP w/Isoflavones | | | | 111 | 30 | 34 | 57 | +3 | | | | | ♂
| | Casein, 50 g | | | | | | 29 | 51 | 0
| | Casein 30 g | | | | | | 36 | 49 | +3
Dent 2001 | 24 wk | ISP w/Isoflavones | | | | 80 | 40 | 24 | 58 ^f,g^ | -5 ^g^ | | NS | -3 ^g^ | NS | peri♀ | | B
| | ISP w/o Isoflavones | | | | 4 | 40 | 24 | 56 ^f,g^ | -1 ^g^ | | | +1 ^g^
| | Whey protein | | | | | | 21 | 57 ^f,g^ | -2 ^g^
Puska 2002 | 6 wk | ISP w/Isoflavones | | | | 96 | 52 | 24 | 61 | +3 | | | 0 | NS | post♀ | | C
| | Calcium caseinate | | | | | | 28 | 60 | +3 | | | | | ♂
Murray 2003 | 26 wk | ISP + Estradiol 0.5 mg | 66 | 44 | 10 | 120 | 38 | 8 | 64 | +4 | NS | | 0 | NS | post♀ | | C
| | Total millk protein + Estradiol 0.5 mg | | | | | | 7 | 67 | +4 | NS
| | ISP + Estradiol 1.0 mg | 66 | 44 | 10 | 120 | 38 | 8 | 69 | -5 | NS | | +3
| | Total millk protein + | | | | | | 7 | 62 | -2 | NS
| | Estradiol 1.0 mg
Supplement | Xover | Miscellaneous
Washburn 1999 | 6 wk | ISP w/Isoflavones once daily | | | | 34 | 14 | 42 | 55 | -3 | | nd | -1 | NS ^d^ | peri♀ | | B
| | ISP w/Isoflavones twice daily | | | | 34 | 14 | | | -3 | | | -1 | NS ^d^
| | Carbohydrates | | | | | | | | -2
Jayagopal 2002 | 12 wk | ISP w/Isoflavones | 70 | 49 | 13 | 132 | 30 | 31 | 51 | +0.4 | NS | | 0 | NS | post♀ | | B
| | Cellulose | | | | | | | 50 | +0.6 | NS | | | | DM
Supplement | RCT | Miscellaneous
Takatsuka 2000 | 9 wk | Soy milk | | | | 109 | 17 | 27 | 66 | -2 | NS | | -4 | | pre♀ | | B
| | No supplement | | | | | | 25 | 63 | +2 | NS
Supplement | Xover | No Control
Wangen 2001 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 18 | 52 | +1 | NS | NS ^d^ | -- | | post♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | 18/17 ^h^ | | +1 | NS | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | 18 | | 0 | NS | | --
| | No control group | | | | | | --
Supplement | RCT | No Control
Gallagher 2004 | 39 wk | ISP w/Isoflavones | 52 | 28 | | 96 | 40 | 17 | 53 | -2 | <0.05 | nd | -- | | post♀ | | C
| | ISP w/Isoflavones | 28 | 20 | | 52 | 40 | 19 | 52 | -5 | <0.05 | | --
| | ISP w/o Isoflavones | 4 | 0 | | 4 | 40 | 14 | 52 | -4 | <0.05 | | --
| | No control group | | | | | | --
Mackey 2000 | 12 wk | ISP w/Isoflavones | | | | 65 | 28 | 25 | 59 | 0 | NS | NS | -- | | post♀ | | B
| | ISP w/o Isoflavones | | | | 4 | 28 | 24 | 64 | +2 | | | --
Female study | | No control group | | | | | | --
Verrillo 1985 ^j^ | 16 wk | ISP, supplement | | | | | 31 | 38 | 54 | -4 | | nd | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein ^j^ | | | | | 31 | 19 | 50 | +4 | | | | --
| | No control group | | | | | | --

a Or difference between final values, as noted.

b Unequal amounts of fat in soy milk (17.5 g/day) and cow milk (0 g/day).

c Main effect of soy protein

d Difference of final values (cross-over study)

e Intention-to-treat analysis (75 completed soy protocol, 78 completed control protocol)

f Graph

g Median value, difference or net difference of median values.

h N: baseline/final.

j Verrillo: In both diet and supplement tables.

Table 19 Effect of soy isoflavones (without soy protein) on high density lipoprotein (mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | g/day | | | | Value | P within | P btw Soy | Value | P vs Control
Baseline HDL > 50 (Women) / 40 (Men)
Diet | Xover | Animal/Usual
Lichtenstein 2002 ^b^ | 6 wk | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 42 | 51 | 0 | | NS | -2 | Soy: 0.03 Iso: NS ^d^ | post♀♂ | | B
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | 0 | | | -2
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | +2 | | | 0
| | Animal w/o Isoflavones | | | | | | | | +2
| | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 22 | nd | 55^e^ | | nd | -1^d^ | Soy: NS Iso: NS ^d^ | post♀ ♂ LDL>160
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | 56^e^ | | | 0^d^
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 53^e^ | | | -3^d^
| | Animal w/o Isoflavones | | | | | | | | 56^e^
| | ISP w/Isoflavones ^b^ | 27 | 14 | 5 | 46 | 55/71 ^c^ | 20 | nd | 49^e^ | | nd | +2^d^ | Soy: 0.04 Iso: NS ^d^ | post♀ ♂ LDL<160
| | ISP w/o Isoflavones ^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71 ^c^ | | | 49^e^ | | | +2^d^
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 48^e^ | | | +1^d^
| | Animal w/o Isoflavones | | | | | | | | 47^e^
Supplement | Xover | Placebo
Nikander 2004 15240647 | 13 wk | Isoflavones | 6 | 42 | 66 | | 0 | 56 | 69 | -1 | NS | | -1 | | post♀ Breast CA | | A
| | Placebo | | | | | | | 68 | 0 | NS
Nestel 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 21 | 50 | -3 | NS | | -3 | | post♀ | | C
| | Placebo | | | | | | | | 0 | NS
Simons 2000 | 8 wk | Isoflavones | | | | 80 | 0 | 20 | 55 | -3 | | | 0 | NS ^d^ | post♀ | | B
| | Placebo | | | | | | | | -3
Supplement | RCT | Placebo
Uesugi 2002 | 4 wk | Isoflavones | 0 | 0 | 0 | 62 ^f^ | 0 | 12 | 66 | -1 | NS | | -4 | NS | peri♀ | | B
| | Placebo | | | | | | 11 | 65 | +3 | NS
Uesugi 2003 | 13 wk | Isoflavones | 0 | 0 | 0 | 62 ^f^ | 0 | 11 | 65 | -1 | | | -1 | NS | post♀ | | B
| | Dextrin | | | | | | 10 | 71 | 0
Baseline HDL < 50 (Women) / 40 (Men)
Supplement | RCT | Placebo
Han 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 40 | +4 | <0.05 | | 0 | NS | post♀ | | A
| | Placebo | | | | | | 40 | 40 | +4 | <0.05
Squadrito 2002 | 26 wk | Genistein | 54 | | | | 0 | 30 | 46 | 0 | NS | | -4 | NS | post♀ | | A
| | Placebo | | | | | | 30 | 46 | +4 | NS
Petri 2004 | 26 wk | Soy germ capsules | | | | 60 | 0.8 | 25 | 44 ^g^ | +13 | <0.05 | | +13 | | post♀ | | B
| | Lactose capsules | | | | | | 25 | 48 ^g^ | 0 | NS
Dewell 2002 | 9 wk | Isoflavones | 40 | 50 | | 90 | 0 | 20 | 46 | -8 | | | 0 | NS | post♀ | | C
| | Placebo | | | | | | 16 | 46 | -8

a Or difference between final values, as noted.

b Lichtenstein: In both Isoflavone and ISP tables.

c Women/Men

d Difference of final values (cross-over study)

e Final values. No data on baseline or change from baseline.

f 31 mg daidzin, 7 mg genistin, 21 mg glycitin

g Graph

Figure 6. Net change of high density lipoprotein (HDL) with soy product consumption compared to control, by baseline level, isoflavone content, and soy protein content. Studies without non-soy control are not included. Studies without data on isoflavone or protein content are omitted from relevant graphs. ISP w/Iso = soy protein with isoflavones; ISP w/o Iso = soy protein without isoflavones; suppl = supplement

Figure 7. Meta-analysis of the effect of soy products on high density lipoprotein (HDL) in all randomized trials with non-soy controls. Circles represent net effect on HDL of individual study cohorts vs. non-soy controls; their size is proportional to the square root of the sample size. Black diamond represents summary mean net change using a random effects model meta-analysis. Bars (and values in parentheses) represent 95% confidence intervals. Cohorts are ordered from lowest (top) to highest mean baseline HDL. Sub-analyses of studies with normal and low baseline HDL (<50 (women) / <40 (men) mg/dL) are also shown (open diamonds). N indicates sample size of subjects consuming soy products

#### Study Descriptions

We found 61 studies that reported on the effect of the consumption of soy products on high density lipoprotein (HDL). Of these, 5 reported only that there was no effect on HDL. ^45^ – ^48,^ ^73^ The remaining 56 studies are described below. ^23,^ ^24,^ ^49^ – ^60,^ ^62^ – ^72,^ ^74,^ ^76^ – ^93,^ ^95^ – ^100,^ ^102^ – ^106^

For ease of categorization, we have divided the studies into separate tables as follows: 5 studies investigated soy products in subjects with abnormally low HDL (mean <40 mg/dL in men or <50 mg/dL in women, Table 16); 20 studies investigated dietary soy protein in subjects with normal HDL (Table 17); 23 studies investigated soy protein used as dietary supplements in subjects with normal HDL (Table 18); and 10 studies investigated pure soy isoflavones in subjects with normal HDL (Table 19). Some studies included cohorts of subjects in multiple categories.

The range of daily soy isoflavone intake among studies of soy products with isoflavones was approximately 10 to 185 mg, with a median of 80 mg per day. The range of daily soy protein intake among relevant studies was approximately 14 to 113 g, with a median of 39 g per day. Three of the 5 studies of subjects with, on average, abnormal HDL were restricted to men; 1 included both men and women; 1 included only pre-menopausal women. The large majority of studies had, on average, subjects with normal HDL. These studies mostly included post-menopausal women or both men and post-menopausal women. The large majority of studies were of limited applicability, even within the categories of pre- or post-menopausal women, or men. Only 12 of the studies were graded as being broadly applicable. Among the 56 studies, 5 were rated good quality (A), 29 were rated fair quality (B), and 20 were rated poor quality (C).

#### Overall Effect

Across the 56 studies there was a wide and evenly distributed range of effects of soy products on HDL. Approximately half of the cohorts of subjects consuming soy had a net increase in HDL compared to control, implying a benefit of soy; one-quarter found a net effect of 0 mg/dL, and one-quarter found a small net decrease in HDL. Across studies, net change ranged from -4 to +13 mg/dL, with the median net change equal to +1 mg/dL, and a fairly even distribution of net changes across the studies (Figure 6). Random effects model meta-analysis of non-soy-controlled studies with sufficient data (Figure 7) estimated a summary net change of +0.6 (95% CI -0.5, +1.8) mg/dL.

#### Soy Product, Dose, Other Variables

Analyses across studies

Figure 6 graphs the net change compared to non-soy control of all cohorts evaluated (that included a non-soy cohort). The left-most graph displays net change in HDL in relationship the baseline HDL level; this graph includes all studies. The middle graph compares net change to daily soy isoflavone consumption (among those studies that report isoflavone content). The right-most graph compares net change to daily soy protein consumption (among those studies that report soy protein content). Study cohorts who consumed soy with isoflavones are indicated by squares; cohorts who consumed soy without isoflavones are indicated by circles; and cohorts who consumed soy isoflavone without soy protein are indicated by triangles. Black symbols represent cohorts where the soy product was consumed as part of the regular diet; open symbols represent cohorts where the soy product was consumed as a supplement to the diet (including soy milk products). Larger symbols indicate cohorts whose mean HDL was abnormally low at baseline; smaller symbols indicate cohorts with normal HDL at baseline.

Visual inspection of the graphs reveal no difference across studies in net effect on HDL based on baseline HDL levels, amount of soy isoflavones consumed, or amount of soy protein consumed. Likewise, there are no clear differences across studies based on whether the soy products were consumed as part of the diet (i.e., specifically replacing other sources of protein) or as a supplement (consumed in addition to regular diet). Also comparing the net effects of soy protein with isoflavones to soy protein without isoflavones to isoflavones without soy protein reveals similar ranges of effects for all 3 types of products.

Random effects model meta-regression across all studies yielded a statistically significant association between mean baseline HDL and net change HDL, such that each increase in baseline HDL of 1 mg/dL was associated with an additional net increase 0.12 (95% CI 0.07, 0.18) mg/dL HDL (P=0.00002). However, exclusion of the 2 studies with atypically small standard deviations (Kreijkamp-Kaspers 2004 and Onning 1998) yielded a non-significant association (P=0.6). Meta-regression of both isoflavone and soy protein dose revealed no association across studies with net change HDL.

Separate meta-analyses of those studies with normal and low baseline HDL (<40 mg/dL in men and/or <50 mg/dL in women) also suggested a larger net benefit of soy consumption among people with normal rather than low baseline HDL (Figure 7). However, again, the apparent differences in effect are largely driven by the 2 studies with atypically small standard deviations (Kreijkamp-Kaspers 2004 and Onning 1998). No difference in effect size was found comparing low quality studies (rated C) to studies of higher quality.

Effect of baseline level of abnormal lipids on net change HDL in individual studies

Two studies performed sub-analyses comparing the effect of soy products on HDL in subjects with different baseline levels of abnormal lipids. Both Crouse 1999 ^51^ (Table 17) and Lichtenstein 2002 ^56^ (Tables 17 and 19) found no overall difference in effect among subjects depending on lipidemia level, despite some significant effects or dose-effect trends in those with lower levels of LDL (LDL between 140 and 166 mg/dL, or LDL below 160 mg/dL, respectively).

Effect of soy isoflavone dose on net change HDL in individual studies

Fourteen studies ^49,^ ^51,^ ^52,^ ^54,^ ^56,^ ^80^ – ^82,^ ^86^ – ^88,^ ^98,^ ^102,^ ^106^ directly compared soy products with different levels of isoflavones, ranging from 0 mg/day to 185 mg/day. All reported no clinical difference in effect and, when reported, no statistically significant difference between isoflavone doses. In a single study by Crouse 1999 ^51^ (Table 17), only among subjects with lower levels of abnormal lipids, was the relationship between soy isoflavone intake (ranging from 3 mg/day to 62 mg/day) and change in HDL statistically significant; though the individual treatments were each non-significant and the actual net effects were similar (0 to +4 mg/dL).

Effect of soy protein dose on net change HDL in individual studies

Four studies directly compared soy products with different amounts of soy protein. ^50,^ ^52,^ ^56,^ ^80^ The doses compared ranged from 0 g/day to 55 g/day in women and 71 g/day in men. Three of the studies, Teixera 2000 ^52^ (Table 17), Tonstad 2002 ^80^ (Table 18), and Potter 1993 ^50^ (Table 16) reported no difference in effect related to soy protein dose. Lichtenstein 2002 ^56^ (Tables 17 and 19) reported a significant, though small, difference in effect related to the consumption of soy protein; however, those subjects who did not consume soy protein had an increase in HDL as opposed to those who did consume soy protein. Similar direction effects were seen among the majority of the other 3 studies.

Effect of soy as diet vs. supplement on net change HDL in individual studies

Only a single study directly compared consumption of soy product as a replacement of dietary protein to soy product as a supplement to usual diet. Verrillo 1985 ^67^ (Tables 17 and 18) found an approximately 8 percent increase in HDL among subjects with severe hypercholesterolemia who consumed isolated soy protein replacing part of their diet compared to a similar decrease in HDL among those who supplemented their diets with isolated soy protein. It was not reported whether either of these changes were statistically significant or different from each other.

Effect of sex and menopausal status on net change HDL

Across studies, there was no clear difference in effect evident based on sex or menopausal status of the subjects. Four studies directly compared effects in different populations (data not included in summary tables). Crouse 1999 ^51^ (Table 17) reported no difference in effect on HDL between post-menopausal women pre-menopausal women. Jenkins 2002 ^49^ (Table 17) reported no significant difference in effect between men and women. Both Onning 1998 ^104^ (Table 16) and Teede 2001 ^77^ (Table 18) reported data suggesting no clinical difference in effect between men and women.

#### Summary

See Section 3.2.6.

### 3.2.5. Lipids: Triglycerides

(Tables 20–24, Figures 8-9)

Table 20 Effect of soy product diets on triglycerides (mg/dL) in subjects with abnormal Tg (Baseline Tg>150 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change a | | Population | Applicability | Quality
Author | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs
Year | | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein | | | | | | | Control
Diet | Xover | Dairy
Jenkins 2002 12145008 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 41 | 173 | +7 | | NS | -3 | NS | post♀ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | 163 | -+12 | | | -22 | NS | ♂
| | Low fat dairy+egg protein | | | | | | | 173 | +10
Potter 1993 | 4 wk | ISP + cellulose | | | | | 50 | 23 | 173 | +4 | NS | nd | -26 | NS ^b^ | ♂ | | C
| | ISP + cotyledon | | | | | 50 | | | +4 | NS | | -26 | NS ^b^
| | Soy flour | | | | | 0 | | | +15 | NS | | -15 | NS ^b^
| | Non-fat dry milk + cellulose | | | | | | | | +30 | NS
Diet | RCT | Dairy
Crouse 1999 | 9 wk | ISP w/Isoflavones | | | | 62 | 25 | 30 | 153 | 0 | | NS | -14 | NS | ♀♂ | | B
| | ISP w/Isoflavones | | | | 37 | 25 | 30 | 150 | -5 | | | -19 | NS | (LDL 140-200)
| | ISP w/Isoflavones | | | | 27 | 25 | 27 | 166 | -12 | | | -26 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 28 | 144 | +8 | | | -6 | NS
| | Casein | | | | | | 31 | 153 | +14
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 146 | -7 | | NS | -37 | <0.03 | ♀♂
| | ISP w/Isoflavones | | | | 37 | 25 | 12 | 147 | -2 | | | -32 | NS | LDL 166–200
| | ISP w/Isoflavones | | | | 27 | 25 | 12 | 162 | -16 | | | -46 | <0.03
| | ISP w/o Isoflavones | | | | 3 | 25 | 15 | 156 | +15 | | | -15 | NS
| | Casein | | | | | | 16 | 141 | +30
| | ISP w/Isoflavones | | | | 62 | 25 | 15 | 161 | +5 | | NS | +8 | NS | ♀♂
| | ISP w/Isoflavones | | | | 37 | 25 | 18 | 151 | -7 | | | -4 | NS | LDL 140–166
| | ISP w/Isoflavones | | | | 27 | 25 | 12 | 171 | -13 | | | -10 | NS
| | ISP w/o Isoflavones | | | | 3 | 25 | 16 | 136 | +2 | | | +5 | NS
| | Casein | | | | | | 15 | 166 | -3
Diet | RCT | Dairy
Teixeira 2000 | 6 wk | ISP w/Isoflavones | | | | 95 | 50 | 15 | 193 | +32 | | nd | +16 | NS | ♂ | | A
| | ISP w/Isoflavones | | | | 76 | 40 | 17 | 181 | +7 | | | -9 | NS
| | ISP w/Isoflavones | | | | 57 | 30 | 18 | 223 | -22 | | | -38 | NS
| | ISP w/Isoflavones | | | | 38 | 20 | 15 | 157 | +14 | | | -2 | NS
| | Calcium caseinate | | | | | | 16 | 189 | +16 | NS
Baum 1998 | 24 wk | ISP w/Isoflavones | 35 | 23 | 6 | 90 | 40 | 21 | 154 | 0 | | nd | -1 | NS | post♀ | | B
| | ISP w/o Isoflavones | 2 | 1 | 2 | 56 | 40 | 23 | 167 | -14 | | | -15 | NS
| | Casein+non-fat dry milk | | | | | | 22 | 155 | +1
Diet | Xover | Animal/Usual
Ashton 2000 11194529 | 4 wk | ISP diet | 84 | 35 | | 120 | 36 | 42 | 173 | -30 | | | -13 | 0.02 ^b,c^ | ♂ | | C
| | Lean meat diet | | | | | | | | -17
Azadbakht 2003 | 7 wk | ISP diet | | | | | 19 | 14 | 243 | -10 | <0.05 | | -13 | <0.002 | ♀♂ DM Proteinuria | | B
| | Usual diet | | | | | | | 241 | +3 | <0.05
Wong 1998 ^d^ | 5 wk | ISP diet | | | | | >15% | 13 | 210 | +56 | | | +66 | NS | ♂ | | B
| | Animal diet | | | | | | | 260 | -10
Diet | Xover | Miscellaneous
Jenkins 1999 | 4 wk | ISP diet | | | | | 33 | 31 | 158 | -11 | | | -25 | 0.07 | post♀ | | B
| | Vegetarian diet | | | | | | | 158 | +14 | | | | | ♂
Diet | RCT | No Control
Verrillo 1985 ^e^ | 16 wk | ISP, supplement ^e^ | | | | | 31 | 38 | 195 | -35 | | NS | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein | | | | | 31 | 19 | 150 | -18 | | | --
| | No control group | | | | | | --

a Or difference between final values, as noted.

b Difference of final values (cross-over study)

c However 95% confidence interval of net change crosses 0.

d Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

e Verrillo: In both diet and supplement tables.

Table 21 Effect of soy product supplements on triglycerides (mg/dL) in subjects with abnormal Tg (Baseline Tg>150 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Dairy
Kurowska 1997 | 4 wk | Soy milk | | | | | 31 | 34 | 155 | +17 | | | +8 | NS | ♀♂ | | B
| | Milk, 2% fat | | | | | | | | +9
Bakhit 1994 | 4 wk | ISP + cellulose | | | | | 25 | 21 | 152 | -21 | NS | | -8 | NS ^ b ^ | ♂ | | C
| | ISP + cotyledon | | | | | 25 | | | -4 | NS | | +9
| | Casein + cellulose | | | | | | | | -13 | NS
| | Casein + cotyledon | | | | | | | | -13 | NS
| | ISP + cellulose | | | | | 25 | 11 | 175 | -49 | <0.05 | | -20 | NS ^ b ^ | ♂ TC>220
| | ISP + cotyledon | | | | | 25 | | | -16 | NS | | +5
| | Casein + cellulose | | | | | | | | -29 | NS
| | Casein + cotyledon | | | | | | | | -21 | NS
Hermansen 2001 | 6 wk | ISP w/Isoflavones | | | | >165 | 50 | 20 | 150 | -6 | | | +14 | 0.04 ^ c ^ | ♀♂ DM | | C
| | Casein | | | | | | | 150 | +8
Cuevas 2003 | 8 wk | ISP w/Isoflavones | 48 | 24 | 8 | 80 | <40 | 18 | 190 | -55 | <0.05 | | -25 | NS ^ d ^ | post♀ | | B
| | Caseinate | | | | | | | | -30 | NS
Supplement | RCT | Dairy
Puska 2002 | 6 wk | ISP w/Isoflavones | | | | 96 | 52 | 21 | 156 | -12 | | | +5 | NS | post♀ ♂ | | C
| | Calcium caseinate | | | | | | 28 | 160 | -17
Supplement | Xover | Miscellaneous
Jayagopal 2002 | 12 wk | ISP w/Isoflavones | 70 | 49 | 13 | 132 | 30 | 32 | 195 | -3 | NS | | -8 | NS | post♀ DM | | B
| | Cellulose | | | | | | | 193 | +5 | NS
Supplement | RCT | No Control
Verrillo 1985^e^ | 16 wk | ISP, supplement | | | | | 31 | 38 | 195 | -35 | | NS | -- | | ♀♂ | | B
| | ISP, 60 g replacing dietary protein^e^ | | | | | 31 | 19 | 150 | -18 | | | --
| | No control group | | | | | | --

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Main effect of soy protein

c NS for difference between final values.

d Difference of final values (cross-over study)

e Verrillo: In both diet and supplement tables.

Table 22 Effect of soy isoflavones (without soy protein) on triglycerides (mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Tg <150 mg/dL
Diet | Xover | Animal/Usual
Lichtenstein 2002^b^ | 6 wk | ISP w/Isoflavones^b^ | 27 | 14 | 5 | 46 | 55/71^c^ | 42 | 136^d^ | -24 | | <0.05 | -15 | Soy:<0.0001 Iso: NS ^ e ^ | post♀ ♂ | | B
| | ISP w/o Isoflavones^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71^c^ | | | -24 | | | -15
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | -7 | | | +2
| | Animal w/o Isoflavones | | | | | | | | -9
| | ISP w/Isoflavones^b^ | 27 | 14 | 5 | 46 | 55/71^c^ | 22 | nd | 119^d,f^ | | nd | -8 ^ e ^ | Soy:<0.0001 Iso: NS ^ e ^ | post♀ ♂ LDL>160
| | ISP w/o Isoflavones^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71^c^ | | | 110^d,f^ | | | -17 ^ e ^
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 126^d,f^ | | | -1 ^ e ^
| | Animal w/o Isoflavones | | | | | | | | 127^d,f^
| | ISP w/Isoflavones^b^ | 27 | 14 | 5 | 46 | 55/71^c^ | 20 | nd | 107^d,f^ | | nd | -21 ^ e ^ | Soy: 0.01 Iso: NS ^ e ^ | post♀ ♂ LDL<160
| | ISP w/o Isoflavones^b^ | 0.4 | 0.8 | 0 | 1.3 | 55/71^c^ | | | 114^d,f^ | | | -14 ^ e ^
| | Animal w/Isoflavones | 27 | 21 | 4 | 52 | 0 | | | 132^d,f^ | | | +4 ^ e ^
| | Animal w/o Isoflavones | | | | | | | | 128^d,f^
Supplement | Xover | Placebo
Nikander 2004 15240647 | 13 wk | Isoflavones | 6 | 42 | 66 | | 0 | 56 | 108 | +1 | NS | | +1 | | post♀ Breast CA | | A
| | Placebo | | | | | | | 111 | 0 | NS
Nestel 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 21 | 128 | +7 | NS | | +20 | | post♀ | | C
| | Placebo | | | | | | | | -13 | NS
Simons 2000 | 8 wk | Isoflavones | | | | 80 | 0 | 20 | 99 | 0 | | | +4 | NS ^ e ^ | post♀ | | B
| | Placebo | | | | | | | | -4
Supplement | RCT | Placebo
Squadrito 2002 | 26 wk | Genistein | 54 | | | | 0 | 30 | 133 | +27 | NS | | +36 | NS | post♀ | | A
| | Placebo | | | | | | 30 | 150 | -9 | NS
Petri 2004 | 26 wk | Soy germ capsules | | | | 60 | 0.8 | 25 | 150^g^ | 0 | NS | | -4 | | post♀ | | B
| | Lactose capsules | | | | | | 25 | 139^g^ | +4 | NS
Dewell 2002 | 26 wk | Isoflavones | 40 | 50 | | 90 | 0 | 20/17^h^ | 71 | +9 | | | 0 | NS | post♀ | | C
| | Placebo | | | | | | 16 | 115 | +9
Uesugi 2002 | 4 wk | Isoflavones | 0 | 0 | 0 | 62^j^ | 0 | 12 | 95 | +11 | NS | | +19 | NS | peri♀ | | B
| | Placebo | | | | | | 11 | 105 | -8 | NS
Uesugi 2003 | 13 wk | Isoflavones | 0 | 0 | 0 | 62^j^ | 0 | 11 | 127 | -14 | | | -32 | NS | post♀ | | B
| | Dextrin | | | | | | 10 | 118 | +18
Tg >=150 mg/dL
Supplement | RCT | Placebo
Han 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 204 | +7 | <0.05 | | -3 | NS | post♀ | | A
| | Placebo | | | | | | 40 | 176 | +10 | <0.05

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Lichtenstein: In both Isoflavone and ISP tables.

c Women/Men

d Values log-transformed prior to statistical analysis.

e Difference of final values (cross-over study)

f Final values. No data on baseline or change from baseline.

g Graph

h N: baseline/final.

j 31 mg daidzin, 7 mg genistin, 21 mg glycitin

Table 23 Effect of soy product diets on triglycerides (mg/dL) in subjects with normal Tg (Baseline Tg<150 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Meinertz 2002 | 4.5 wk | ISP w/Isoflavones, liquid | | | | 2.39/g^b^ | 20% | 12 | 88 | -15 | NS | <0.05^c^ | -3 | NS ^ c ^ | ♀♂ | | C
| | ISP w/o Isoflavones, liquid | | | | 0.11/g^b^ | 20% | | 81 | -23 | <0.01 | | -11 | NS ^ c ^
| | Casein diet, liquid | | | | | | | 77 | -12 | NS
Meinertz 1989 | 4.5 wk | ISP diet, liquid cholesterol enriched | | | | | 112 | 11 | 58 | -4 | | | +1 | NS ^ c ^ | ♀♂ | | C
| | Calcium caseinate | | | | | | | | -5
Meinertz 1988 | 4 wk | ISP diet, liquid low cholesterol | | | | | 113 | 10 | 68 | -5 | | | +7 | NS ^ c ^ | ♀♂ | | C
| | Casein diet, liquid low cholesterol | | | | | | | | -12
Diet | RCT | Dairy
Vigna 2000 | 12 wk | ISP w/Isoflavones | | | | 76 | 40 | 40 | 130 | -14 | NS | | -2 | | post♀ | | C
| | Caseinate | | | | | | 37 | 117 | -12 | NS
Diet | Xover | Animal/Usual
Lichtenstein 2002^d^ | 6 wk | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71^e^ | 42 | 136^f^ | -24 | | <0.05 | -15 | Soy:<0.0001 Iso: NS ^ c ^ | post♀ ♂ | | B
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71^e^ | | | -24 | | | -15
| | Animal w/Isoflavones^d^ | 27 | 21 | 4 | 52 | 0 | | | -7 | | | +2
| | Animal w/o Isoflavones | | | | | | | | -9
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71^e^ | 22 | nd | 119^f,g^ | | nd | -8 ^ c ^ | Soy:<0.0001 Iso: NS ^ e ^ | post♀ ♂ LDL>160
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71^e^ | | | 110^f,g^ | | | -17 ^ c ^
| | Animal w/Isoflavones^d^ | 27 | 21 | 4 | 52 | 0 | | | 126^f,g^ | | | -1 ^ c ^
| | Animal w/o Isoflavones | | | | | | | | 127^f,g^
| | ISP w/Isoflavones | 27 | 14 | 5 | 46 | 55/71^e^ | 20 | nd | 107^f,g^ | | nd | -21 ^ c ^ | Soy: 0.01 Iso: NS ^ e ^ | post♀ ♂ LDL<160
| | ISP w/o Isoflavones | 0.4 | 0.8 | 0 | 1.3 | 55/71^e^ | | | 114^f,g^ | | | -14 ^ c ^
| | Animal w/Isoflavones^d^ | 27 | 21 | 4 | 52 | 0 | | | 132^f,g^ | | | +4 ^ c ^
| | Animal w/o Isoflavones | | | | | | | | 128^f,g^
Wong 1998^h^ | 5 wk | ISP diet | | | | | >15% | 13 | 89 | +9 | | | +16 | NS | ♂ | | B
| | Animal diet | | | | | | | 92 | -7
Goldberg 1982 | 6 wk | ISP diet | | | | | 91 | 12 | 116 | -12 | NS | | +1 | NS ^ c ^ | ♀♂ | | B
| | Animal diet | | | | | | | | -13 | <0.05
Diet | RCT | Animal/Usual
Chiechi 2002 11836040 | 26 wk | ISP diet^j^ | | | | 47 | | 58/24^k^ | 120 | -3 | NS | | -7 | | post♀ | | C
| | Usual diet^j^ | | | | | | 55/43^k^ | 100 | +4 | NS
Shorey 1981 | 6 wk | ISP diet | | | | | 55 | 13 | 97 | +40 | 0.046 | | +28 | | ♂ | | C
| | Animal diet | | | | | | 11 | 130 | +12 | NS
Diet | RCT | Miscellaneous
Murkies 1995 | 12 wk | Soy flour | | | | | | 23 | 95 | -2 | NS | | -6 | NS | post♀ | | B
| | Wheat flour | | | | | | 24 | 96 | +4 | NS

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Per gram protein. No data on number of grams of protein.

c Difference of final values (cross-over study)

d Lichtenstein: In both Isoflavone and ISP tables.

e Women/Men

f Values log-transformed prior to statistical analysis.

g Final values. No data on baseline or change from baseline.

h Wong 1998: Sub-analyses of same study in LDL<130 and LDL>130 tables.

j No data on how fat content of 2 diets compare.

k N: baseline/final.

Table 24 Effect of soy product supplements on triglycerides (mg/dL) in subjects with normal Tg (Baseline Tg<150 mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Dairy
Bricarello 2004 | 6 wk | Soy milk^b^ | 50 | 33 | 5 | 87 | 25 | 60 | 136 | -3 | NS | | +2 | NS | ♀♂ | | C
| | Non-fat milk^b^ | | | | | | | | -1 | NS
Blum 2003 12659466 | 6 wk | ISP w/Isoflavones | | | | 85 | 25 | 24 | 133 | +60 | 0.04 | | -2 | NS ^ c ^ | post♀ | | C
| | Total milk protein | | | | | | | | +62
Steinberg 2003 | 6 wk | ISP w/Isoflavones | 55 | 47 | 5 | 107 | 25 | 24 | 91 | +1 | | NS | +5 | NS | post♀ | | C
| | ISP w/o Isoflavones | 1 | 0.5 | 0.5 | 2 | 24 | | | +4 | | | +8 | NS
| | Total milk protein | | | | | | | | -4
Meyer 2004 | 5 wk | Soy milk/yogurt | | | | 80 | 30 | 23 | 115 | -7 | | | -2 | NS ^ c ^ | post♀ ♂ | | B
| | Low fat milk/yogurt | | | | | | | | -4
Supplement | RCT | Dairy
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 86 | 106 | -17 | <0.05 | | -16 | NS | post♀ ♂ | | B
| | Casein | | | | | | 93 | 106 | -1 | NS
Kreijkamp-Kaspers 2004 | 52 wk | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88^d^ | 120 | +2 | | | -8 | NS | post♀ | | A
| | Total milk protein | | | | | | 87^d^ | 111 | +10
Puska 2004 | 8 wk | ISP w/Isoflavones | | | | 153 | 41 | 69 | 149 | +9 | | | 0 | NS | post♀ ♂ | | B
| | Yogurt | | | | | | 74 | 148 | +9
Tonstad 2002 | 16 wk | ISP w/Isoflavones | | | | 185 | 50 | 31 | 118 | -18 | | nd | -2 | NS | post♀ ♂ | | B
| | ISP w/Isoflavones | | | | 111 | 50 | 34 | 113 | -14
| | Casein, 50 g | | | | | | 29 | 129 | -9
| | Casein 30 g | | | | | | 36 | 139 | -15
Gardner 2001 | 12 wk | ISP w/Isoflavones | 52 | 25 | 4 | 80 | 42 | 31 | 115 | 0 | | NS | -9 | NS | post♀ ♂ | | B
| | ISP w/o Isoflavones | 2 | 1 | 0 | 3 | 42 | 33 | 115 | 0 | | | -9 | NS
| | Milk protein | | | | | | 30 | 115 | +9
Dent 2001 | 24 wk | ISP w/Isoflavones | | | | 80 | 40 | 24 | 94^e,f^ | +11 ^ f ^ | | NS | -33 ^ f ^ | NS | peri♀ | | B
| | ISP w/o Isoflavones | | | | 4 | 40 | 24 | 99^e,f^ | -5 ^ f ^ | | | -49 ^ f ^
| | Whey protein | | | | | | 21 | 72^e,f^ | +44 ^ f ^
Murray 2003 | 26 wk | ISP + Estradiol 0.5 mg | 66 | 44 | 10 | 120 | 38 | 8 | 116 | +3 | NS | | +15 | | post♀ | | C
| | Total millk protein+ Estradiol 0.5 mg | | | | | | 7 | 99 | -12 | NS
| | ISP + Estradiol 1.0 mg | 66 | 44 | 10 | 120 | 38 | 8 | 97 | +53 | 0.02 | | -14
| | Total millk protein + Estradiol 1.0 mg | | | | | | 7 | 191^g^ | +67 | NS
Supplement | Xover | Miscellaneous
Washburn 1999 | 6 wk | ISP w/Isoflavones once daily | | | | 34 | 14 | 42 | 131 | -3 | | nd | -28 | NS ^ c ^ | peri♀ | | B
| | ISP w/Isoflavones twice daily | | | | 34 | 14 | | | +10 | | | -15 | NS ^ c ^
| | Carbohydrates | | | | | | | | +25
Onning 1998 | 4 wk | Soy milk | | | | | 23/30^h^ | 12 | 80 | +9 | NS | | 0 | | ♀♂ | | B
| | Oat milk | | | | | | | | +9 | NS
Gardner-Thorpe 2003 | 6 wk | Soy flour biscuits | 45 | 75 | | 120 | | 19 | 106 | +27 | | | 0 | NS ^ c ^ | ♂ | | B
| | Wheat flour biscuits | | | | | | | | +27
Supplement | RCT | Miscellaneous
Takatsuka 2000 | 9 wk | Soy milk | | | | 109 | 17 | 27 | 98 | -17 | NS | | -1 | NS | pre♀ | | B
| | No supplement | | | | | | 25 | 96 | -16 | NS
Supplement | Xover | No Control
Wangen 2001 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 18 | 130 | -22 | NS | NS^c^ | -- | | post♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | 18/17^j^ | | -22 | NS | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | 18 | | -27 | NS | | --
| | No control group | | | | | | --
Merz-Demlow 2000 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 13 | 56^k^ | -4 | | NS | -- | | pre♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | | | -2 | | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | | | +7 | | | --
| | No control group | | | | | | --
Supplement | RCT | No Control
Gallagher 2004 | 39 wk | ISP w/Isoflavones | 52 | 28 | | 96 | 40 | 17 | 138 | +10 | NS | nd | -- | | post♀ | | C
| | ISP w/Isoflavones | 28 | 20 | | 52 | 40 | 19 | 135 | +6 | NS | | --
| | ISP w/o Isoflavones | 4 | 0 | | 4 | 40 | 14 | 110 | +24 | NS | | --
| | No control group | | | | | | --
Mackey 2000 | 12 wk | ISP w/Isoflavones | | | | 65 | 28 | 25 | 135 | +1 | NS | NS | -- | | post♀ | | B
Female study | | ISP w/o Isoflavones | | | | 4 | 28 | 24 | 136 | -7 | | | --
| | No control group | | | | | | --

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Unequal amounts of fat in soy milk (17.5 g/day) and cow milk (0 g/day).

c Difference of final values (cross-over study)

d Intention-to-treat analysis (75 completed soy protocol, 78 completed control protocol)

e Graph

f Median value, difference or net difference of median values.

g Significantly higher at baseline than other study arms because of single outlier with hypertriglyceridemia.

h Women/Men

j N: baseline/final.

k Measurements made at 4 menstrual cycle phases: early follicular, midfollicular, periovulatory, midluteal. Data extracted for periovulatory only. LDL change was greatest during this phase in high isoflavone group.

Figure 8. Net change of triglycerides (Tg) with soy product consumption compared to control, by baseline level, isoflavone content, and soy protein content. Studies without non-soy control are not included. Studies without data on isoflavone or protein content are omitted from relevant graphs. ISP w/Iso = soy protein with isoflavones; ISP w/o Iso = soy protein without isoflavones; suppl = supplement

Figure 9. Meta-analysis of the effect of soy products on triglycerides in all randomized trials with non-soy controls. Circles represent net effect on triglycerides of individual study cohorts vs. non-soy controls; their size is proportional to the square root of the sample size. Black diamond represents summary mean net change using a random effects model meta-analysis. Bars (and values in parentheses) represent 95% confidence intervals. Confidence intervals of several studies are truncated. Cohorts are ordered from lowest (top) to highest mean baseline triglyceride level. Sub-analyses of studies with normal and elevated baseline triglycerides (>150 mg/dL) are also shown (open diamonds). N indicates sample size of subjects consuming soy products

#### Study Descriptions

We found 57 studies that reported on the effect of the consumption of soy products on triglycerides. Of these, 3 reported only that there was no effect on triglycerides. ^46,^ ^47,^ ^73^ The remaining 54 studies are described below. ^23,^ ^24,^ ^49^ – ^52,^ ^54^ – ^60,^ ^62^ – ^64,^ ^66^ – ^72,^ ^74,^ ^76^ – ^93,^ ^95^ – ^100,^ ^102^ – ^106^

For ease of categorization, we have divided the studies into separate tables as follows: 10 studies investigated dietary soy protein in subjects with hypertriglyceridemia (mean triglycerides >150 mg/dL, Table 20); 7 studies investigated soy protein supplements in subjects with hypertriglyceridemia (Table 21); 10 studies investigated pure soy isoflavones (Table 22); 10 studies investigated dietary soy protein in subjects with normal triglyceride levels (Table 23); and 19 studies investigated soy protein supplements in subjects with normal triglyceride levels (Table 24). Some studies included cohorts of subjects in multiple categories.

The range of daily soy isoflavone intake among studies of soy products with isoflavones was approximately 10 to 185 mg, with a median of 80 mg per day. The range of daily soy protein intake among relevant studies was approximately 14 to 113 g, with a median of 38 g per day. Sixteen studies included subjects with, on average, abnormal triglycerides; the remainder included, on average, subjects with normal triglycerides. The large majority of studies were of limited applicability, even within the categories of pre- or post-menopausal women, or men. Only 12 of the studies were graded as being broadly applicable. Among the 54 studies, 5 were rated good quality (A), 27 were rated fair quality (B), and 22 were rated poor quality (C).

#### Overall Effect

Across the 54 studies there was a widely distributed range of effects of soy products on triglycerides (Figure 8). Approximately two-thirds of the cohorts of subjects consuming soy had a net decrease in triglycerides compared to control, implying a benefit of soy. Across studies, net change ranged from -49 to +66 mg/dL, with the median net change equal to -3 mg/dL. In terms of percent net change (using the baseline level in the soy intervention cohort as the denominator), net change ranged from approximately -49% to +31%, with a median net change equal to -2%. Random effects model meta-analysis of non-soy-controlled studies with sufficient data (Figure 9) resulted in a statistically significant net change estimate of -8 (95% CI -11, -5) mg/dL.

#### Soy Product, Dose, Other Variables

Analyses across studies

Figure 8 graphs the net change compared to non-soy control of all cohorts evaluated (that included a non-soy cohort). The left-most graph displays net change in triglycerides in relationship the baseline triglycerides level; this graph includes all studies. The middle graph compares net change to daily soy isoflavone consumption (among those studies that report isoflavone content). The right-most graph compares net change to daily soy protein consumption (among those studies that report soy protein content). Study cohorts who consumed soy with isoflavones are indicated by squares; cohorts who consumed soy without isoflavones are indicated by circles; and cohorts who consumed soy isoflavone without soy protein are indicated by triangles. Black symbols represent cohorts where the soy product was consumed as part of the regular diet; open symbols represent cohorts where the soy product was consumed as a supplement to the diet (including soy milk products). Larger symbols indicate cohorts whose mean triglycerides was abnormally low at baseline; smaller symbols indicate cohorts with normal triglycerides at baseline.

Visual inspection of the graphs reveal a possible negative association between baseline triglycerides levels and net change triglycerides across studies (net reductions are larger at higher baseline triglycerides. However, net reductions in triglyceride appear to be greater at both low doses of soy isoflavones and low doses of soy proteins. Similar patterns appear for all 3 types of products.

Separate meta-analyses of studies based on elevated (>150 mg/dL) or normal baseline triglycerides revealed a modest difference in effect between the 2 groups of studies, although both meta-analyses were statistically significant (Figure 9). Among studies with elevated baseline triglycerides, the net reduction with soy consumption was greater (–11 [95% CI -16, -7]) than among studies with normal baseline triglycerides (–5 [95% CI -9, 0]). Sub-analysis of poor quality studies (rated C) revealed no significant difference in effect compared to better quality studies.

Random effects model meta-regression across all studies found a similar effect, such that for each increase in mean baseline triglycerides of 10 mg/dL, the additional net change in triglycerides with soy consumption was -0.8 mg/dL (95% CI -0.13, -0.02). There was no clear threshold baseline level where there was a substantial, consistent change in the association between baseline triglycerides and net change triglycerides. By meta-regression, neither isoflavone or soy protein dose was associated with net effect on triglycerides.

Effect of baseline level of abnormal lipids on net change triglycerides in individual studies

Three studies performed sub-analyses comparing the effect of soy products on triglycerides in subjects with different baseline levels of abnormal lipids. Both Bakhit 1994 ^72^ (Table 21) and Lichtenstein 2002 ^56^ (Tables 22 and 23) found no overall difference in effect among subjects depending on lipid levels (thresholds of total cholesterol at 220 mg/dL or LDL at 160 mg/dL, respectively). Crouse 1999 ^51^ (Table 20) did report larger, statistically significant reductions among those with more elevated LDL (>166 mg/dL).

Effect of soy isoflavone dose on net change triglycerides in individual studies

Fourteen studies ^49,^ ^51,^ ^52,^ ^54,^ ^56,^ ^80^ – ^82,^ ^86^ – ^88,^ ^98,^ ^102,^ ^106^ directly compared soy products with different levels of isoflavones, ranging from 0 mg/day to 185 mg/day. Only 1 study reported a significantly different effect based on isoflavone dose. Consistent with the apparent association across studies, Meinertz 2002 ^98^ (Table 23) found a significantly larger reduction in triglycerides when subjects were consuming liquid isolated soy protein with minimal isoflavones than when they consumed equivalent soy protein with isoflavones.

Effect of soy protein dose on net change triglycerides in individual studies

Four studies directly compared soy products with different amounts of soy protein. ^50,^ ^52,^ ^56,^ ^80^ The doses compared ranged from 0 g/day to 55 g/day in women and 71 g/day in men. Three of the studies, Teixera 2000 ^52^ (Table 20), Tonstad 2002 ^80^ (Table 24), and Potter 1993 ^50^ (Table 20) reported no difference in effect related to soy protein dose. Lichtenstein 2002 ^56^ (Tables 22 and 23) reported a highly significant difference in effect related to the consumption of soy protein, where a larger net reduction was seen among subjects when they consumed soy products with soy protein than soy isoflavones alone.

Effect of soy as diet vs. supplement on net change triglycerides in individual studies

Only a single study directly compared consumption of soy product as a replacement of dietary protein to soy product as a supplement to usual diet. Verrillo 1985 ^67^ (Tables 20 and 21 found no difference in effect on triglycerides whether soy was consumed as a dietary replacement or as a supplement.

Effect of sex and menopausal status on net change triglycerides

Across studies, there was no clear difference in effect evident based on sex or menopausal status of the subjects. Four studies directly compared effects in different populations (data not included in summary tables). Crouse 1999 ^51^ (Table 20) reported no difference in effect on triglycerides between post-menopausal women pre-menopausal women. Jenkins 2002 ^49^ (Table 20) reported no significant difference in effect between men and women. Both Onning 1998 ^104^ (Table 24) and Teede 2001 ^77^ (Table 24) reported data suggesting no clinical difference in effect between men and women.

#### Summary

See Section 3.2.6.

### 3.2.6. Summary of Lipid Profile Studies

(Tables 25–28)

Table 25 Number of studies included with different study designs (and total)

Randomized Design | Total Cholesterol | LDL | HDL | Triglycerides
Parallel | 29 | 21 | 27 | 25
Cross-over | 32 | 31 | 29 | 29
Total | 61 | 52 | 56 | 54

HDL = high density lipoprotein; LDL = low density lipoprotein

Table 26 Number of studies included within each population and quality category, and within each baseline lipid and quality category

Quality | Total Cholesterol | | | | LDL | | | | HDL | | | | Triglycerides
Population Category | | A | B | C | | A | B | C | | A | B | C | | A | B | C
| Total | 5 | 32 | 24 | Total | 4 | 28 | 20 | Total | 5 | 31 | 20 | Total | 5 | 27 | 22
Women & Men | 13 | 0 | 7 | 6 | 13 | 0 | 7 | 6 | 11 | 0 | 6 | 5 | 11 | 0 | 6 | 5
Post-Menop Women & Men | 8 | 0 | 6 | 2 | 8 | 0 | 6 | 2 | 8 | 0 | 6 | 2 | 8 | 0 | 6 | 2
Post-Menop Women | 24 | 4 | 11 | 9 | 20 | 4 | 7 | 9 | 23 | 4 | 11 | 8 | 22 | 4 | 8 | 10
Peri-Menop Women | 3 | 0 | 3 | 0 | 3 | 0 | 3 | 0 | 3 | 0 | 3 | 0 | 3 | 0 | 3 | 0
Pre-Menop Women | 3 | 0 | 1 | 2 | 2 | 0 | 1 | 1 | 2 | 0 | 1 | 1 | 2 | 0 | 1 | 1
Men | 10 | 1 | 4 | 5 | 6 | 0 | 4 | 2 | 9 | 1 | 4 | 4 | 8 | 1 | 3 | 4
Baseline Lipid Category
Normal | 11 | 0 | 4 | 7 | 10 | 0 | 4 | 6 | 45 | 3 | 27 | 17 | 37 | 3 | 18 | 16
Abnormal | 50 | 5 | 28 | 17 | 42 | 4 | 24 | 14 | 9 | 2 | 4 | 3 | 17 | 2 | 9 | 6

HDL = high density lipoprotein; LDL = low density lipoprotein; Post-Menop = post-menopausal; Peri-Menop = peri-menopausal; Pre-Menop = pre-menopausal

Table 27 Number of studies (or study arms) included that used different types of soy products, controls, or soy consumption types (diet versus supplement)

| Total Cholesterol | LDL | HDL | Triglycerides
Soy Product (Study Arms)
Protein with Isoflavones | 67 | 57 | 63 | 60
Protein without Isoflavones | 11 | 10 | 11 | 11
Isoflavones | 11 | 9 | 10 | 10
Control Types (Study Arms)
Dairy | 32 | 30 | 30 | 28
Animal/Usual Diet | 10 | 8 | 8 | 8
Placebo | 10 | 8 | 9 | 9
Miscellaneous | 8 | 6 | 8 | 7
No Non-Soy Control | 5 | 5 | 5 | 5
Diet or Supplement (Studies) ^ a ^
Diet | 24 | 17 | 22 | 20
Supplement | 38 | 35 | 35 | 35

HDL = high density lipoprotein; LDL = low density lipoprotein

a One study is double counted because it compares diet to supplement.

Table 28 Number of studies that directly compared the effects of different soy product characteristics or study subject characteristics

Comparison Characteristics | Total Cholesterol | LDL | HDL | Triglycerides
Protein with v without Isoflavones ^a^ | 11 | 10 | 11 | 11
Different Soy Protein Dosages | 4 | 3 | 4 | 4
Different Soy Isoflavone Dosages | 14 | 12 | 14 | 14
Different Baseline LDL or TC Levels | 3 | 4 | 2 | 3
Different Population Categories | 4 | 4 | 4 | 4

HDL = high density lipoprotein; LDL = low density lipoprotein; TC = total cholesterol

a One study also included an isoflavone only treatment arm (for all lipids).

Characteristics of the 68 randomized studies that reported data on total cholesterol, LDL, HDL, and/or triglycerides are summarized in Tables 25–28. Approximately three-quarters of the treatments evaluated were soy protein with isoflavones; the remaining treatments evaluated were about evenly divided between soy protein without isoflavones and isoflavones alone (without soy protein). Among studies with soy protein, the range of soy protein consumed daily was 14 to 113 g, with a median of 36 g per day. Among studies with soy isoflavones, the range of isoflavones consumed daily was 10 to 185 mg, with a median of 80 mg per day. These ranges were the same for all lipid profile studies. Few studies directly compared soy products, mostly comparing soy protein with varying amounts of soy isoflavones. Only one study, Lichtenstein 2002 ^56^ performed a factorial design study comparing both present and absent soy protein and present and absent soy isoflavones, thus allowing analysis of both the effect of soy protein and soy product.

#### Total Cholesterol

A total of 61 studies reported data on the effect of consumption of soy products on total cholesterol levels. The median net change compared to control found was approximately -6 mg/dL (or -2.5%) with a wide range of effects, from -33 to +7 mg/dL (–12% to +4%). Across studies, there were no discernable differences in effect based on baseline total cholesterol, soy protein consumption, soy isoflavone consumption, soy incorporated into diet or as supplement, or population (post-menopausal women, pre-menopausal women, men). However, 2 studies reported greater net effect of soy in subjects with more severely elevated lipids. Most studies that directly compared different doses of soy protein or soy isoflavones found no significant difference in effect, although results were mixed. Most studies that also directly compared effect in men and women found no difference.

#### Low Density Lipoprotein

A total of 52 studies reported data on the effect of consumption of soy products on LDL levels. A wide range of effects were reported, ranging from -32 to +13 mg/dL (or -21% to +9%). While few studies found a statistically significant benefit of soy consumption, meta-analysis across the diverse studies yielded a statistically significant net change of -5 (95% CI -8 to -3) mg/dL (roughly -3%). Across studies, there is possible evidence that the beneficial effect of soy products increases with increasing baseline LDL, particularly among studies where mean baseline LDL was greater than 130 mg/dL; although these associations were not statistically significant. Similarly, there is possible evidence of an association between higher soy protein dose and greater net reduction in LDL; however, only in the sub-analysis of studies with elevated baseline LDL was this association statistically significant. When studies with minimal doses of soy protein (<10 g/day) were omitted, the association was non-significant. No association was found between soy isoflavone dose and net effect. Qualitative analysis across all studies revealed no other associations between net change and other variables, including differences among soy products, , soy incorporated into diet or as supplement, or population (post-menopausal women, pre-menopausal women, men). The 3 studies that compared effect to baseline LDL level came to conflicting conclusions. Most studies that directly compared different doses of soy protein or soy isoflavones found no significant difference in effect, although results were mixed. Most studies that also directly compared effect in men and women found no difference.

#### High Density Lipoprotein

A total of 56 studies reported data on the effect of consumption of soy products on HDL levels. The median net change compared to control found was +1 mg/dL. This estimate was in agreement with the meta-analysis estimate of +0.6 (95% CI -0.5, +1.8) mg/dL, which was not statistically significant. With only 2 exceptions, all studies reported a net effect on HDL of less than 10 percent, with an even distribution between net increases and net decreases or zero effect. Across studies, there were no consistent differences in effect based on baseline HDL, soy protein consumption, soy isoflavone consumption, soy incorporated into diet or as supplement, or population (post-menopausal women, pre-menopausal women, men). A possible associaton between baseline HDL and net change was found; although this association disappeared with the exclusion of 2 outlier studies. Studies that directly compared different baseline degree of abnormal lipids, doses of soy protein or soy isoflavones, or populations found no significant difference in effect.

#### Triglycerides

A total of 54 studies reported data on the effect of consumption of soy products on triglyceride levels. The median net change compared to control found was approximately -3 mg/dL (or -2%), although a wide range of effects were reported, ranging from -49 to +66 mg/dL (–49% to +31%). Meta-analysis estimated a significant net effect of -8 (95% CI -11, -5) mg/dL. Meta-regression revealed a possible association between increased mean baseline triglyceride level and greater net reduction in triglycerides. Neither isoflavone or soy protein dose was associated with net effect on triglycerides. Within specific studies that investigated these possible associations, though, most studies found no associations. There was no evident association with whether soy was incorporated into diet or as supplement, or based on population (post-menopausal women, pre-menopausal women, men).

#### Overall

There is a great deal of heterogeneity of effects found on lipoprotein and triglyceride levels. None of the factors we evaluated, including population, quality, applicability, soy isoflavone dose, soy protein dose, or baseline lipidemia level satisfactorily explained the heterogeneity. Overall, the majority of studies reported small to moderate effects on the lipids, despite a wide range of net effects for total cholesterol, LDL, and triglycerides. With few exceptions, studies consistently reported a small benefit on HDL. While we cannot exclude the possibility of publication bias (negative studies being less likely to be published) as an explanation for the effect of soy on LDL, there was no clear evidence that negative trials were “missing.” However, the clinical heterogeneity of the trials makes this analysis difficult. Since most studies reported multiple outcomes, including lipids, it is possible that publication bias is less likely among these studies. It is also probably less likely that negative trials for HDL and triglycerides have not been published, unless the effect on LDL (and other outcomes) was also negative.

In order to guide future research, we have identified those studies that had a large effect on lipids. We arbitrarily defined “large” as an increase or decrease of at least 10 percent for total cholesterol, LDL, or HDL, and of at least 20 percent for triglycerides. We excluded studies with unequal baseline lipid levels between soy and control, studies with net improvements in subjects with normal baseline values, and studies with net worsening that resulted in still-normal lipid levels. These studies might provide insight into which formulations of soy product or which populations may benefit or worsen lipid levels most. If such factors are discernible, it may be most worthwhile to focus future research on these factors.

Among randomized trials that compared soy products to non-soy controls, we identified 7 studies that reported large effects on lipids in 8 treatment arms. Three (4 arms) had net reductions of LDL ranging from 10 to 14 percent, ^50,^ ^84,^ ^91^ and 1 had a net reduction of total cholesterol of 12 percent. ^61^ We also identified 2 studies with large increases in triglycerides of 27 and 31 percent. ^59,^ ^92^ However, overall, there were no characteristics of these studies that distinguished them from studies with smaller or no effects on lipids.

### 3.2.7. Lipoprotein(a)

(Tables 29–31)

Table 29 Effect of soy product diets on lipoprotein (a) (mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 12145008 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 41 | 19.2 | +0.9 | | NS | -1.1 | NS | post♀ ♂ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | 20.2 | +1.5 | | | -0.5 | NS
| | Low fat dairy+egg protein | | | | | | | 19.6 | +2.0
Nilausen 1999 | 4.5 wk | ISP w/Isoflavones, liquid | | | | | 154 | 9 | 12.7 ^b^ | -2.7 | NS | | +4.5 | <0.002 ^ c ^ | ♂ | | C
| | Calcium caseinate | | | | | | | 12.0 ^b^ | -7.2 | <0.0002
Diet | RCT | Dairy
Teixeira 2000 | 6 wk | ISP w/Isoflavones | | | | 95 | 50 | 15 | 30.9 ^d^ | -7.0 ^e^ | NS | nd | -4.6 | NS | ♂ | | A
| | ISP w/Isoflavones | | | | 76 | 40 | 17 | 25.5 ^d^ | -4.8 ^e^ | NS | | -1.2 | NS
| | ISP w/Isoflavones | | | | 57 | 30 | 18 | 26.8 ^d^ | -16.8 ^e^ | NS | | -13.2 | NS
| | ISP w/Isoflavones | | | | 38 | 20 | 15 | 23.0 ^d^ | -11.3 ^e^ | NS | | -7.7 | NS
| | Calcium caseinate | | | | | | 16 | 17.8 ^d^ | -3.6 ^e^ | NS
Vigna 2000 | 12 wk | ISP w/Isoflavones | | | | 76 | 40 | 40 | 16 ^f^ | +1 ^g^ | NS | | -2 ^ g ^ | | ♀ | | C
| | Caseinate | | | | | | 37 | 17 ^f^ | +3 ^g^ | NS
Diet | Xover | Animal/Usual
Ashton 2000 11194529 | 4 wk | ISP diet | 84 | 35 | | 120 | 36 | 42 | nd | 24.5 ^h^ | | | -0.8 | NS ^ c ^ | ♂ | | C
| | Lean meat diet | | | | | | | | 25.3 ^h^
Diet | Xover | Miscellaneous
Jenkins 1999 | 4 wk | ISP diet | | | | | 33 | 30 | 31.8 ^j^ | -0.7 | | | -1.5 | NS | post♀ ♂ | | C ^k^
| | Vegetarian diet | | | | | | | 28.8 ^j^ | +0.8
Diet | NRCT | No Control
Yildirir 2001 | 6 wk | ISP diet | | | | | 20 | 20 | 23.4 | -1.2 | NS | | -- | | ♂ | | C
| | No control group | | | | | | --

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Graph.

c Difference of final values (cross-over study)

d Median. Reported in nmol/L; values divided by 2.4 (nmol/L per mg/dL).

e Mean change, adjusted for baseline value.

f Median.

g Difference or net difference of median values.

h Final values (baseline values not reported).

j Units reported to be mgl/L; however values most consistent with mg/dL.

k In contrast to other outcomes in this article, units for Lp(a) unclear.

Table 30 Effect of soy protein supplements on lipoprotein (a) (mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Dairy
Meyer 2004 | 5 wk | Soy milk/yogurt | | | | 80 | 30 | 23 | 26.0 | +1.2 | | | -0.9 | NS ^ b ^ | post♀ ♂ | | B
| | Low fat milk/yogurt | | | | | | | | +0.8
Hermansen 2001 | 6 wk | ISP w/Isoflavones | | | | >165 | 50 | 20 | 29.5 U/L | +4.4 | | | +4.3 | NS | ♀♂ DM | | C
| | Casein | | | | | | | 32.3 U/L | +0.1
Supplement | RCT | Dairy
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 86 | 28.6 ^c^ | +42 | | | +38 | <0.05 | post♀♂ | | B
| | Casein | | | | | | 93 | 34.1 ^c^ | +4
Kreijkamp-Kaspers 2004 | 52 wk | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88^d^ | 27 | +4 | | | +3 | NS | post♀ | | A
| | Total milk protein | | | | | | 87^d^ | 24 | 0
Tonstad 2002 | 16 wk | ISP w/Isoflavones | | | | 185 | 50 | 31 | 41.7 | +8.1 | | nd | +2.5 | NS | post♀ ♂ | | B
| | ISP w/Isoflavones | | | | 111 | 30 | 34 | 43.7 | +4.5
| | Casein, 50 g | | | | | | 29 | 36.7 | +12.2
| | Casein 30 g | | | | | | 36 | 40.5 | +3.8
Dent 2001 | 24 wk | ISP w/Isoflavones | | | | 80 | 40 | 24 | 8 ^e^ | 0 ^ f ^ | NS | NS | -10 ^ f ^ | 0.052 | peri♀ | | B
| | ISP w/o Isoflavones | | | | 4 | 40 | 24 | 8 ^e^ | 0 ^ f ^ | NS | | -10 ^ f ^
| | Whey protein | | | | | | 21 | 11 ^e^ | +10 ^ f ^
Puska 2002 | 6 wk | ISP w/Isoflavones | | | | 96 | 52 | 24 | 27.2 ^g^ | +5.7 | | | +4.4 | NS | post♀ ♂ | | C
| | Calcium caseinate | | | | | | 24 | 34.1 ^g^ | +1.4
Supplement | Xover | No Control
Merz-Demlow 2000 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 13 | nd | +14.6 ^h^ | | NS | -- | | pre♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | | | +15.2 ^h^ | | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | | | +14.6 ^h^ | | | --
| | No control group | | | | | | --
Wangen 2001 | 13 wk | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 18 | nd | 27.4 ^ j ^ | | NS ^b^ | -- | | post♀ | | C
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | 17 | | 27.2 ^ j ^ | | | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | 18 | | 26.8 ^ j ^ | | | --
| | No control group | | | | | | --

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Difference of final values (cross-over study)

c Mean of log transformed values.

d Intention-to-treat analysis (75 completed soy protocol, 78 completed control protocol)

e Median. Graph. Reported in nmol/L; values divided by 2.4 (nmol/L per mg/dL).

f Difference or net difference of median values.

g Units reported to be g/L; however values most consistent with mg/L.

h Reported as “Effect” and least-squared mean. Vague if these values truly represent within-cohort changes.

j Final values (baseline values not reported).

Table 31 Effect of soy isoflavones (without soy protein) on lipoprotein (a) (mg/dL)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change ^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Placebo
Nikander 2004 15240647 | 13 wk | Isoflavones | 6 | 42 | 66 | | 0 | 56 | 17.1 | +0.9 | NS | | +1.8 | NS | post♀ Breast CA | | A
| | Placebo | | | | | | | 17.6 | -0.9 | NS
Simons 2000 | 8 wk | Isoflavones | | | | 80 | 0 | 20 | nd | 16.6 ^b^ | | | -1.3 | NS ^ c ^ | post♀ | | C ^d^
| | Placebo | | | | | | | | 17.9 ^b^

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Or difference between final values, as noted.

b Final values (baseline values not reported).

c Difference of final values (cross-over study)

d In contrast with other outcomes in this article, no baseline Lp(a) value was reported.

Lipoprotein(a) [Lp(a)] is a low density lipoprotein (LDL)-like particle in which an apolipoprotein(a) [apo(a)] moiety is linked to apolipoprotein B-100. Lp(a) is an acute-phase reactant and has been postulated to be a highly atherothrombotic protein. The concentration of Lp(a) is under genetic control and varies among individuals depending on the apo(a) isoform. Diet and exercise have little influence on Lp(a) concentration. The only treatment to lower Lp(a) levels that has been shown to be effective is hormone replacement therapy in post-menopausal women.

#### Study Descriptions

We found 20 eligible studies, of which 18 reported numerical data on Lp(a) and are summarized here; ^49,^ ^52,^ ^55,^ ^57,^ ^64,^ ^71,^ ^74,^ ^77,^ ^78,^ ^80,^ ^82,^ ^83,^ ^86,^ ^89,^ ^90,^ ^106,^ ^109,^ ^110^ the remaining 2 did not report data. ^51,^ ^98^ Among these, 17 studies were RCTs - including 10 cross-over trials - and 1 was a non-randomized trial. Studies evaluated concentrations of Lp(a) after soy product consumption for 4 weeks to 1 year. Seven studies were conducted among post-menopausal women only, 4 studies included men only, and 7 studies included both men and women. One of these evaluated women with treated breast cancer, and one evaluated men and women with diabetes mellitus. Seven studies evaluated soy diets (Table 29); 9 evaluated soy protein supplements (Table 30); and 2 evaluated soy isoflavone supplements (Table 31).

Studies reported Lp(a) using different metrics, and we found several inconsistencies in reporting. The majority of the studies were assessed to a quality score of C (3 A, 3 B, 12 C) and were applicable to healthy, and/or breast cancer treated post-menopausal women and middle-aged hypercholesterolemic men. All studies had generally limited applicability even within categories.

#### Overall Effect

The large majority of studies reported non significant changes in Lp(a) from baseline after soy intervention. Among 18 studies, 2 found a net decrease of at least 4 mg/dL (or a statistically significant decrease) in Lp(a) concentration, 4 found a net increase of at least 4 mg/dL (or a statistically significant increase), and 12 found no effect. Only 3 studies reported significant or near significant net changes in Lp(a) after soy protein consumption compared to controls. Nilausen 1999 ^109^ (Table 29) reported a non-significant change in Lp(a) among men consuming soy, but a significant decrease in Lp(a) among controls consuming caseinate; this resulted in a statistically significant net increase in Lp(a). Teede 2001 ^77^ (Table 30) found a substantially greater, statistically significant, increase in Lp(a) among men and post-menopausal women supplemented with soy product compared to casein. Dent 2001 ^82^ (Table 30), reported a marginally significant net decrease in median Lp(a) among hypercholesterolemic peri-menopausal women supplemented with soy product with and without isoflavone compared to whey protein.

#### Soy Product, Dose, Other Variables

No study directly compared different soy products. The studies evaluated dietary tofu, soy protein isolate diet, soybean, bean sprout and soy flour diet, and isoflavone supplements with and without soy protein. Across the studies, there is no discernable difference in effect based on the type of soy product.

Likewise, there was no consistent difference across studies in effect based on either quantity of soy protein or quantity of isoflavones. Six studies ^49,^ ^52,^ ^80,^ ^82,^ ^86,^ ^106^ directly compared soy products with different levels of isoflavones ranging from 1 mg/day to 185 mg/day. All studies found no significant effect (within-cohort or net effect) regardless of isoflavone dose.

Two studies directly compared soy products with different amounts of soy protein. ^52,^ ^80^ Both Teixera 2000 ^52^ (Table 29) who compared 4 doses between 20 and 50 mg/day in men, and Tonstad 2002 ^80^ (Table 30)who compared 30 and 50 mg/day in men and post-menopausal women found no significant relationship between soy protein dose and effect on Lp(a).

Jenkins 2002 ^49^ (Table 29) also analyzed the effect of soy products in men and women separately (data not displayed in summary table) and reported no significant effect between sexes. Meyer 2004 ^71^ performed sub analysis based on the production of equol, and reported significantly lower Lp(a) concentration among equol-positive subjects after the consumption of soy diet (data not displayed in summary table), which according to the authors suggested that changes in Lp(a) might have been linked to equol.

#### Summary

A total of 18 studies reported data on the effect of consumption of soy products on Lp(a) concentration. Overall, across studies, there were no discernable differences in effect based on soy protein consumption, soy isoflavone consumption, soy incorporated into diet or as supplement, or population (post-menopausal women, pre-menopausal women, men). However, 2 studies reported significant increase in net effect of soy consumption on Lp(a) concentration. Based on the limited evidence, no definite conclusions can be made on the Lp(a)-raising effect of soy protein consumption.

### 3.2.8. Blood Pressure

(Tables 32–35, Figure 10)

Table 32 Effect of soy products on blood pressure (mm Hg) in subjects with hypertension (Baseline SBP>140 or DBP>90)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Changee | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | NRCT | No Control
Gentile ^a b^ 1993 | 8 wk | ISP diet | | | | | 0.7-0.8 g/kg bw ^c^ | 20 | 141 | +1 | NS | | -- | | ♀♂ CKD | | C
| | | | | | | | | 89 | -2 | NS | | --
| | No control group | | | | | | --
D'Amico ^a b^ 1992 | 8 wk | ISP diet | | | | | 0.7-0.8 g/kg bw ^c^ | 20 | 143 | -2 | NS | | -- | | ♀♂ CKD | | C
| | No control group | | | | | | --
Supplement | RCT | Dairy
Rivas^d^ 2002 | 12 wk | Soy milk | 8 | 6 | | 14 | 18 | 20 | 155 | -18.4 | <0.0001 | | -17.0 | | ♀♂ HTN^d^ | | B
| | | 0 | 3 | | 0 | | | 100 | -15.9 | <0.0001 | | -12.2
| | Milk | | | | | | | 152 | -1.4 | NS
| | | | | | | | | 99 | -3.7 | NS
Supplement | Xover | Miscellaneous
Jayagopal 2002 | 12 wk | ISP w/Isoflavones | 7 | 4 | 1 | 13 | 30 | 29 | 147 | -1.1 | | | -3.5 | NS ^d^ | post♀ DM | | B
| | | 0 | 9 | 3 | 2 | | | 82 | -0.3 | | | +0.1 | NS ^d^
| | Cellulose | | | | | | | 147 | +2.4
| | | | | | | | | 83 | -0.2

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Randomized cross-over trial, but not relevant control group (soy + fish oil)

b Same cohort, different study periods with different types of intervention

c bw: ideal body weight

d Subjects with hypertension: 50% treated and 50% untreated

e Or difference between final values, as noted.

Table 33 Effect of soy product diets on blood pressure (mm Hg) in subjects with pre-hypertension (Baseline SBP<140 or DBP<90)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Changef | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 12145008 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 41 | 123 | -1.0 | | NS^a^ | +1.0 | | post♀ ♂ | | C
| | | | | | | | | 78 | -1.0 | | | -1.0
| | ISP w/Isoflavones | | | | 10 | 52 | | 124 | -4.0 | | | -2.0
| | | | | | | | | 78 | -2.0 | | | -2.0
| | Low fat dairy + egg protein | | | | | | | 125 | -2.0
| | | | | | | | | 78 | 0
Diet | RCT | Dairy
Vigna 2000 | 12 wk | ISP w/Isoflavones | | | | 76 | 40 | 51/40^d^ | 127 | -3.2 | NS | | +5.4 | | post♀ | | C
| | | | | | | | | 82 | -0.1 | NS | | +3.0
| | Caseinate | | | | | | 53/37^d^ | 130 | -8.6 | NS
| | | | | | | | | 83 | -3.1 | NS
Diet | RCT | Animal/Usual
Chiechi 2002 11836040 | 26 wk | ISP diet | | | | 47 | | 58/24^d^ | 132 | -3.4 | NS | | -0.3 | | post♀ | | C
| | | | | | | | | 81 | +0.2 | NS | | -2.6
| | Usual diet | | | | | | 55/43^d^ | 130 | -3.1 | NS
| | | | | | | | | 81 | +2.8 | NS
Diet | Xover | Miscellaneous
Jenkins 1999 | 4 wk | ISP diet | | | | | 33 | 30 | 120 | +1.0 | | | +1.6 | NS ^ b ^ | post♀ ♂ | | B
| | | | | | | | | 79 | -2.0 | | | +1.7 | NS ^ b ^
| | Vegetarian diet | | | | | | | 120 | -1.0
| | | | | | | | | 80 | -4.0
Diet | RCT | Miscellaneous
Sagara 2004 | 5 wk | Soy powder baked goods | | | | 80 | 20 | 25 | 142 | -11 | <0.01 | | -7 | 0.05 ^ c ^ | ♂ | | B
| | | | | | | | | 87 | -5 | <0.01 | | -3 | NS
| | Usual baked goods | | | | | | 25 | 134 | -4 | NS
| | | | | | | | | 81 | -2 | NS
Burke^e^ 2001 | 8 wk | ISP w/psyllium | | | | | 66 | 9 | 135 | -8.4 | | nd | -5.9 -2.6 | 0.001 0.006 | ♀♂ HTN^e^ | | B
| | | | | | | | | 74 | -2.3
| | ISP | | | | | 66 | 9 | 134 | -0.1
| | | | | | | | | 77 | -1.0
| | Psyllium w/maltodextrin | | | | | | 9 | 132 | -0.5
| | | | | | | | | 78 | +0.6
| | Maltodextrin | | | | | | 9 | 132 | +2.3
| | | | | | | | | 75 | +1.4

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Significant differences between the sexes (Women/Men)

b Difference of final values (cross-over study)

c Net change reported non-significant in the text

d N: baseline/final

e All patients had hypertension and were on antihypertensive medications and successfully controlled baseline BP

f Or difference between final values, as noted.

Table 34 Effect of soy product supplements on blood pressure (mm Hg) in subjects with pre-hypertension (Baseline SBP<140 or DBP<90)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change!!! | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Dairy
Kurowska 1997 | 4 wk | Soy milk | | | | | 31 | 34 | 131 | -3.0 | 0.04 | | +5.0 | | ♀♂ | | B
| | | | | | | | | 77 | 0 | 0.02 | | +4.0
| | Milk, 2% fat | | | | | | | | -8.0 | 0.04
| | | | | | | | | | -4.0 | 0.02
Meyer 2004 | 5 wk | Soy milk/yogurt | | | | 80 | 30 | 23 | 132 | 0 | | | -0.6 | NS ^ a ^ | post♀ ♂ | | B
| | | | | | | | | 77 | 0 | | | -2.0 | NS ^ a ^
| | Low fat milk/yogurt | | | | | | | | +1.0
| | | | | | | | | | +2.0
Hermansen 2001 | 6 wk | ISP w/Isoflavones | | | | >165 | 50 | 20 | 130 | 0 | NS | | +1.0 | NS ^ a ^ | ♀♂ DM | | C
| | | | | | | | | 78 | 0 | NS | | 0 | NS ^ a ^
| | Casein | | | | | | | | -1.0 | NS
| | | | | | | | | | 0 | NS
Cuevas 2003 | 8 wk | ISP w/Isoflavones | 48 | 24 | 8 | 80 | <40 | 18 | 132 | -5.0 | NS | | 0 | | post♀ | | B
| | | | | | | | | 73 | -3.0 | NS | | +1.0
| | Caseinate | | | | | | | | -5.0 | NS
| | | | | | | | | | -4.0 | NS
Supplement | RCT | Dairy
Kreijkamp-Kaspers 2005 | 52 wk | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88^b^ | 138 | +0.8 | | | +4.3 | 0.04 | post♀ | | A
| | | | | | | | | 74 | +0.3 | | | +2.0 | NS
| | Total milk protein | | | | | | 87^b^ | 143 | -3.5
| | | | | | | | | 76 | -1.7
| | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 75 | 137 | -0.1 | | | +3.8 | NS | post♀ No Rx^c^
| | | | | | | | | 73 | -0.7 | | | +1.1 | NS
| | Total milk protein | | | | | | 63 | 140 | -3.9
| | | | | | | | | 74 | -1.9
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 86 | 130 | -7.5 | | | -3.9 | <0.05 ^ a ^ | post♀ ♂ | | B
| | | | | | | | | 76 | -4.3 | | | -2.4 | <0.05 ^ a ^
| | Casein | | | | | | 93 | 128 | -3.6
| | | | | | | | | 76 | -1.9
Puska 2004 | 8 wk | ISP | | | | 153 | 41 | 69 | 130 | 0 | | | +1.0 | | post♀ ♂ | | B
| | | | | | | | | 81 | 0 | | | 0
| | Yogurt | | | | | | 74 | 132 | -1.0
| | | | | | | | | 81 | 0
Supplement | Xover | Miscellaneous
Washburn 1999 | 6 wk | ISP w/Isoflavones once daily | | | | 34 | 14 | 42 | 132 82 | -8.0 | | NS | -2.0 | NS ^ a ^ | peri♀ | | B
| | | | | | | | | | -6.0 | | | -3.0 | NS ^ a ^
| | ISP w/Isoflavones twice daily | | | | 34 | 14 | | | -7.0 | | | -1.0 | NS ^ a ^
| | | | | | | | | | -8.0 | | | -4.9 | <0.01 ^ a ^
| | Carbohydrates | | | | | | | | -6.0
| | | | | | | | | | -3.0

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Difference of final values (cross-over study)

b Intention-to-treat analysis (75 completed soy protocol, 78 completed control protocol)

c Excluding women who were taking anti-hypertensives

Table 35 Effect of soy isoflavones (without soy protein) on blood pressure (mm Hg) in subjects with pre-hypertension (Baseline SBP<140 or DBP<90)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change!!! | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Supplement | Xover | Placebo
Nestel^b^ 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 21 | MAP 86 | -6 | <0.05 | | 0 | NS ^ a ^ | post♀ | | C
| | Placebo | | | | | | | | -6 | <0.05
Simons 2000 | 8 wk | Isoflavones | | | | 80 | 0 | 20 | 135 82 | -10.0 | | | -1.0 | NS ^ a ^ | post♀ | | B
| | | | | | | | | | -2.0 | | | 0 | NS ^ a ^
| | Placebo | | | | | | | | -9.0
| | | | | | | | | | -2.0
Supplement | RCT | Placebo
Han 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 131 | 0 | NS | | 0 | | post♀ | | A
| | | | | | | | | 84 | +1.0 | NS | | 1.0
| | Placebo | | | | | | 40 | 133 | 0 | NS
| | | | | | | | | 84 | 0 | NS
Squadrito^b^ 2002 | 26 wk | Genistein | 54 | | | | 0 | 30 | 113 | -3.0 | NS | | -4.0 | NS | post♀ | | A
| | | | | | | | | 80 | -1.0 | NS | | -2.0 | NS
| | Placebo | | | | | | 30 | 112 | +1.0 | NS
| | | | | | | | | 77 | +1.0 | NS

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Difference of final values (cross-over study)

b Studies with normal baseline blood pressure

Figure 10. Meta-analysis of the effect of soy products on systolic (SBP) and diastolic blood pressure (DBP) in all randomized trials with non-soy controls. Circles represent net effect on BP of individual study cohorts vs. non-soy controls; their size is proportional to the square root of the sample size. Diamonds represent summary mean net changes using a random effects model meta-analysis (and sub-analysis). Bars (and values in parentheses) represent 95% confidence intervals. Black symbols represent SBP, open symbols represent DBP. Cohorts are ordered from lowest (top) to highest mean SBP. N indicates sample size of subjects consuming soy products. Blood pressure units are mm Hg

* Effect is heterogeneous across all studies.** Effect is homogeneous across studies when Rivas 2002 excluded.

Blood pressure (BP) reduction is associated with decreased CVD, kidney disease, and mortality. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High blood pressure (JNC 7) recognizes the relationship of increased risk for CVD for each increment of 20 mm Hg of systolic BP or 10 mm Hg of diastolic BP across the range of 115–185/75–115 mm Hg. ^111^ This has led to the new classification of pre-hypertension as well as recommendation of health promoting lifestyle modifications for systolic BP >120 mm Hg or diastolic BP >80 mm Hg. Population studies have demonstrated an inverse relationship between dietary protein intake and blood pressure. ^112,^ ^113^

#### Study Descriptions

Among 25 eligible studies, we found 22 studies that reported numerical data on BP, which are summarized here; ^23,^ ^24,^ ^49,^ ^55,^ ^62,^ ^64,^ ^65,^ ^69,^ ^71,^ ^74,^ ^76,^ ^77,^ ^79,^ ^84,^ ^90^ – ^92,^ ^114^ – ^118^ the remaining 3 reported only no significant effect. ^48,^ ^73,^ ^89^ Only one study included subjects with a mean baseline systolic BP less than 120 mm Hg. Therefore, we have categorized those studies with mean baseline systolic BP under 140 mm Hg as “pre-hypertension.” We have categorized them into separate tables as follows: 4 studies included subjects whose mean baseline blood pressure was greater than 140/90 mm Hg (hypertension) (Table 32); and 18 studies of subjects with mean blood pressure less than 140/90 mm Hg (pre-hypertension), of which 6 evaluated soy product diets (Table 33); 8 evaluated soy product supplements (Table 34); and 4 evaluated soy isoflavones (Table 35).

All 18 studies that included subjects with pre-hypertension were RCTs including 9 cross-over trials. Studies evaluated BP changes after soy product consumption for 4 weeks to 6 months. The majority of studies included post-menopausal women. Notably, Burke 2001 ^117^ (Table 33) evaluated men and women diagnosed with hypertension and were receiving anti-hypertensive medication that was successfully controlling their BP.

The studies of hypertensive subjects included 2 RCTs, 1 trial with no control for soy, and 1 prospective cohort study. Two studies evaluated BP changes after soy product consumption for 8 weeks and two after 12 weeks. The study populations included men and women with chronic kidney disease, men with moderate hypertension, and post-menopausal women with diabetes mellitus.

The range of daily soy isoflavone intake among studies of soy products with isoflavones was approximately 10 to 165 mg, with a median of 80 mg per day. The range of daily soy protein intake among relevant studies was approximately 14 to 66 g, with a median of 33 g per day. The majority of studies were assessed to a quality score of B (3 A, 12 B, 6 C). Most studies included post-menopausal women; few included men and women. Ten studies have narrow applicability, 6 moderate applicability, and 6 broad applicability.

#### Overall Effect

Across the 22 studies, all but one (Rivas 2002, ^116^ Table 32) reported similar effects of soy products on systolic or diastolic BP, within the range of -7 to +5 mm Hg systolic BP and -5 to +4 mm Hg diastolic BP.

The summary estimates from random-effects model meta-analyses of all soy cohorts with a non-soy control for systolic and diastolic BP were not statistically significant (Figure 10). The net change in systolic BP was -1 (95% CI -3 to +1) mm Hg, where the summary mean baseline systolic BP was approximately 132 mm Hg. The net change in diastolic BP was -1 (95% CI -2 to +0) mm Hg, where the summary mean baseline DBP was approximately 80 mm Hg.

As noted, however, the study by Rivas 2002 ^116^ was clearly an outlier with a substantially greater (and statistically significant) net reduction in both systolic and diastolic BP. Exclusion of this study resulted in a meta-analysis of now statistically homogeneous studies. As shown in Figure 10, though, exclusion of this outlier study did not greatly affect the summary estimate of net effect.

Rivas 2002 ^116^ (Table 32) included both men and women with moderate essential hypertension, half of whom were untreated hypertensives; the remainder had a 4 week washout period without anti hypertensive medications. The authors attributed the beneficial effect of the intervention on BP level to the twice daily consumption of natural soy milk high in soy protein and isoflavones. However, the other study with twice-daily dosing (Washburn 1999, ^23^ Table 34) did not find a similarly large effect. While there was a statistically significant reduction in diastolic blood pressure with twice daily soy, the magnitude of the effect was similar to that for once daily soy. In addition, the Rivas 2002 ^116^ study did have potential flaws because of substantial differences in fat and carbohydrate composition between the soy and control arm; although this was a common flaw among studies.

#### Soy Product, Dose, Other Variables

The studies evaluated a wide range of soy products including soybean diet, soymilk, and isoflavone supplements with and without soy protein. Only 2 studies directly compared different soy products or regimens. Jenkins 2002 ^49^ (Table 33) compared the effect of soy products with different levels of isoflavones (73 mg vs 10 mg) and found no apparent difference in effect. Washburn 1999 ^23^ (Table 34) compared the same dose of isoflavone supplements as single and split doses and reported a significant decrease in diastolic BP after split dose consumption of isoflavone supplement, although there was no statistical difference between the 2 regimens.

Only Jenkins 2002 ^49^ (Table 33) compared BP effect in men and women. In response to soy consumption, there was a significant difference between men and women only for systolic BP. Analysis of the sexes separately indicated a tendency to lower systolic BP for men during the high-isoflavone soy phase, but a significant decrease during the low-isoflavone soy phase compared to the control phase.

As expected due to the statistical homogeneity among studies (bar Rivas 2002 ^116^ ), meta-regression and sub-analyses failed to find associations between effect and baseline BP or soy dose. Among the 18 studies of subjects with pre-hypertension, 5 found a net decrease of at least 3 mm Hg (or a statistically significant decrease) of either systolic or diastolic BP, 3 found a net increase of at least 3 mm Hg of either systolic or diastolic BP, and 10 found no effect. Only 4 studies found significant or near significant reductions of systolic and/or diastolic BP after soy protein consumption compared to controls. Burke 2001 ^117^ (Table 33), and Teede 2001 ^77^ (Table 34) reported significant reductions in BP with soy protein consumption compared to controls. Washburn 1999 ^23^ (Table 34) reported a significant decrease in diastolic BP from baseline in healthy peri-menopausal women during one phase of soy protein consumption compared to controls, but no significant effect on systolic BP. Sagara 2004 ^65^ (Table 33) reported a significant decrease in BP compared to baseline and a near significant decrease in systolic BP compared to controls.

One recent study ^118^ by Kreijkamp-Kaspers 2005 (Table 34), reported a trend towards increase in BP from baseline during soy protein consumption in post-menopausal women. The study also reported a statistically significant net increase in systolic BP compared to controls, but no significant effect on diastolic BP. Women consuming soy protein had a net increase, but a non-significant increase in systolic BP, when those taking anti-hypertensive medications were excluded from the analyses.

#### Summary

A total of 22 studies with mostly moderate quality reported data on the effect of consumption of soy products on systolic and diastolic BP. Overall, soy consumption does not appear to affect BP level. Across studies there were no discernable differences in effect based on baseline BP, soy protein consumption, soy isoflavone consumption, soy incorporated into diet or as supplement, or population (post-menopausal women, pre-menopausal women, men). The one outlier study attributed its large beneficial effect to twice daily consumption of soy protein. However, a separate study comparing once to twice daily soy found similar effects.

### 3.2.9. C-Reactive protein

(Table 36)

Table 36 Effect of soy products on C-reactive protein (mg/L)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 12077742 ^a^ | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 23 | 2.5 | -0.5 | | ND | -0.9 | NS ^b^ | ♂ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | 3.5 | -1.0 | | | -1.4 | NS ^b^
| | Low fat dairy + egg protein | | | | | | | 1.6 | +0.4
| | ISP w/Isoflavones | | | | 73 | 50 | 18 | 2.8 | +1.7 | | ND | +2.4 | NS ^b^ | post♀
| | ISP w/Isoflavones | | | | 10 | 52 | | 2.4 | +0.7 | | | +1.4 | NS ^b^
| | Low fat dairy + egg protein | | | | | | | 3.4 | -0.7
Supplement | RCT | Dairy
Teede 2004 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 52 | 30 | 1.91 | +0.42 | <0.05 | | -0.06 | NS | post♀ | | B
| | Casein | | | | | | 20 | 1.39 | +0.48 | <0.05
Supplement | Xover | Placebo
Nikander 2003 14602747 | 13 wk | Isoflavones | 6 | 42 | 66 | 114 | 0 | 56 | 1.16 | -0.06 | NS | | -0.06 | NS ^b^ | post♀ Breast CA | | A
| | Placebo | | | | | | | 1.10 | 0 | NS

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a Data available only for women and men separately

b Difference of final values (cross-over study)

C-reactive protein (CRP) is an acute phase reactant, and a protein synthesized by the liver. CRP in the upper range (>3.0 mg/L) assessed by the automated high sensitivity assays (hs-CRP) has been shown to be an independent and high risk factor for CVD. ^119^ CRP levels increase in acute and chronic inflammatory states. Conventional conjugated estrogen replacement therapy has shown to increase CRP levels. ^120^ Given the theory that soy phytoestrogens may have estrogenic activity, it is of interest whethersoy consumption may affect CRP levels.

#### Study Descriptions

We found 3 eligible studies that all reported data on hs-CRP. ^121^ – ^123^ All studies were RCTs including 2 cross-over trials. Two studies evaluated CRP levels after soy product consumption for 13 weeks, and one study after 4 weeks. All 3 studies were conducted among post-menopausal women. One of these evaluated women with treated breast cancer. One study also included hypercholesterolemic men.

All studies were assessed to a quality score of B/C. One study included both men and post-menopausal women (who were analyzed separately); one included only post-menopausal women; and the third study was restricted to post-menopausal women with a history of treated breast cancer.

#### Overall Effect

No study found a significant effect of soy protein consumption on CRP level. Two studies reported trends towards increases in CRP levels from baseline among women after soy intervention, but these effects were non-significant compared to controls. However, the rise in CRP levels was not seen in the sub-analysis of men.

#### Soy Product, Dose, Other Variables

No study directly compared different soy products. The 3 studies evaluated dietary tofu, soy protein isolate diet, and isoflavone supplements. Across the small number of studies, there is no discernable difference in effect based on the type of soy product.

Likewise, there was no consistent difference across studies in effect based on either quantity of soy protein or quantity of isoflavones. Jenkins 2002 ^121^ compared soy products with differing amounts of isoflavones. Changes in CRP were similar in both soy arms in this study.

Only Jenkins 2002 ^121^ analyzed the effect of soy products in both men and women. Although CRP levels rose in the soy arms in women (both within-cohort and compared to control) and decline in men, none of the changes was statistically significant.

#### Summary

Few studies have evaluated the effect of soy consumption on CRP level. The limited data available suggest that there is no effect on CRP level by the consumption of soy products.

### 3.2.10. Homocysteine

(Table 37)

Table 37 Effect of soy products on homocysteine (μmol/L)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 12145008 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 41 | 8.2 | -0.6 | | NS^a^ | -0.2 | <0.5 ^ b ^ | post♀♂ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | 8.2 | -0.8 | | | -0.4 | <0.5 ^ b ^
| | Low fat dairy + egg protein | | | | | | | 8.0 | -0.4
Supplement | Xover | Dairy
Hermansen 2001 | 6 wk | ISP w/Isoflavones | | | | >165 | 50 | 20 | 11.2 | +0.4 | | | -1.7 | 0.006 ^ b ^ | ♀♂ DM | | C
| | Casein | | | | | | | 10.6 | +2.1
Supplement | RCT | Dairy
Puska^d^ 2004 | 8 wk | ISP | | | | 153 | 41 | 69/59 ^e^ | 10.4 | +2.4 | | | +0.6 | NS | post♀♂ | | B
| | Calcium caseinate | | | | | | 74/73^e^ | 11.6 | +1.9
Tonstad 2002 | 16 wk | ISP w/Isoflavones | | | | 185 | 50 | 31 | 10.6 | -0.2 | | nd | -0.8 | 0.005 ^ c ^ | post♀♂ | | B
| | ISP w/Isoflavonessofalvones | | | | 111 | 30 | 34 | 10.0 | -0.2
| | Casein, 50 g | | | | | | 36 | 10.6 | +0.9
| | Casein 30 g | | | | | | 29 | 10.1 | +0.5
Puska 2002 | 6 wk | ISP w/Isoflavones | | | | 96 | 52 | 24 | 10.5 | -0.3 | | | -1.7 | <0.001 | post♀♂ | | C
| | Calcium caseinate | | | | | | 28 | 9.6 | +1.4

Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

a No significant response to treatment high and low isoflavone phases and between sexes

b Difference of final values (cross-over study)

c Significant for the interaction between treatment and time.

d Analyzed on a modified intention-to-treat population and treatment effect estimation for homocysteine by ANCOVA

e N: baseline/at 2 weeks of treatment

Increased homocysteine levels are associated with atherosclerotic disease and may induce vascular injury by primary atherogenic and prothrombotic effects. High homocysteine levels are an independent emerging risk factor for atherosclerotic vascular disease, ^124^ but its optimal use in screening and risk stratification has yet to be determined. To date, no treatment has been shown to lower homocysteine levels. Therefore, it is of interest whether consumption of soy products may effect homocysteine levels.

#### Study Descriptions

We found 5 eligible studies that reported data on homocysteine; ^49,^ ^74,^ ^79,^ ^80,^ ^83^ all randomized controlled trials, including 2 cross-over trials. Four studies had soy supplements and 1 had diet for the soy intervention; all studies compared to dairy for the control arm. The duration of intervention ranged from 4 to 16 weeks, with a range of 20 to 69 subjects in the soy intervention arm. All studies were assessed to a quality score of B/C. All studies included both men and (generally post-menopausal) women, one of which restricted inclusion to people with diabetes mellitus. The studies were assessed to have an applicability of 1 to 3.

#### Overall Effect

All but 2 studies ^74,^ ^79^ reported a decrease in homocysteine levels from baseline after soy consumption. All studies except Puska 2004 ^79^ reported a significant decrease in homocysteine levels after the soy consumption when compared to control arm.

#### Soy Product, Dose, Other Variables

The studies evaluated tofu diet, isolated soy protein diet, and isoflavone supplements with soy protein. Only 2 studies ^49,^ ^80^ compared different soy products. Jenkins 2002 ^49^ compared the effect of soy products with differing amounts of isoflavones (73 mg vs. 10 mg) and found no apparent difference in effect. The same study also compared effect of soy products in men and women and found no apparent difference in effect between genders.

Tonstad 2002 ^80^ combined the effect of 2 isolated soy proteins with different levels of isoflavones (185 mg vs. 111 mg) and compared to the 2 dairy groups to assess the net treatment effect.

Three studies ^79,^ ^80,^ ^83^ used the same type of isoflavone, and only 2 studies ^80,^ ^83^ found a significant decrease in homocysteine levels after the soy consumption; Puska 2004 ^79^ reported a non-significant effect.

#### Summary

Only 5 studies of moderate to poor quality reported data on the effect of consumption of soy products on homocysteine levels. Overall, across studies, there were no discernable differences in effect based on baseline levels, soy protein consumption, soy isoflavone consumption, soy incorporated into diet or as supplement, or population (post-menopausal women, pre-menopausal women, men). Four studies reported greater net effect of soy on homocysteine levels compared to controls. Given the small number of studies no definite conclusions can be made on the beneficial effect of soy protein consumption on this CVD risk factor.

### 3.2.11. Endothelial Function

(Table 38)

Table 38 Effect of soy products on measures of endothelial function

Diet/Supplement | Design | Control | Dose | | | | | N | Outcome (Stimulant) | Unit | Base value | Change | | Net Change^a^ | | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | | | Value | Pwithin | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Steinberg 2003 | 6 wk | ISP w/Isoflavones | 55 | 47 | 5 | 107 | 25 | 24 | PFV (RH) | % | nd | +13^b^ | | NS | -7 | 0.03 ^ c ^ | post♀ | | C
| | ISP w/oIsoflavones | 1 | 0.5 | 0.5 | 2 | 24 | | | | | +15^b^ | | | -5 | NS ^ c ^
| | Total milk protein | | | | | | | | | | +20^b^
Diet | Cohort | No Control
Yildirir 2001 | 6 wk | ISP w/Isoflavones | | | | | 20 | 20 | BAD (RH) | mm | 4.7 | +0.3 | <0.001 | | -- | | ♂ | | C
| | | | | | | | | FMD (RH) | % | 8.2 | +4.4 | 0.002 | | --
| | No control group | | | | | | --
Supplement | Xover | Dairy
Blum 2003 12659466 | 6 wk | ISP w/Isoflavones | | | | 85 | 25 | 24 | BAD (RH) | mm | nd | 3.94 ^d^ | | | +0.20 | NS ^ c ^ | post♀ | | C
| | Total milk protein | | | | | | | | | | 4.13 ^d^
| | ISP w/Isoflavones | | | | 85 | 25 | 24 | Flow | mL/min | nd | 76 ^d^ | | | -5 | NS ^ c ^
| | Total milk protein | | | | | | | | | | 81 ^d^
Cuevas 2003 | 8 wk | ISP w/Isoflavones | 48 | 24 | 8 | 80 | <40 | 18 | FMD (RH) | % | 5.3 | +3.9 | <0.03 | | +4.3 | <0.03 ^ c ^ | post♀ | | B
| | Caseinate | | | | | | | | | | -0.4 | NS
Supplement | RCT | Dairy
Kreijkamp-Kaspers 2005 | 52 wk | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88^e^ | FMD (RH) | % | 4.8 | +0.3 | | | +0.4 | NS | post♀ | | A
| | Total milk protein | | | | | | 87^e^ | | | 4.4 | 0
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 96^f^ | FMD (RH) | % | nd | -3.5^b^ | | | -3.5 | <0.02 | ♂ | | C^g^
| | Casein | | | | | | | | | nd | 0^b^
| | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 83^f^ | | | nd | +0.5^b^ | | | +1.5 | NS | post♀
| | Casein | | | | | | | | | nd | -1.0^b^
Supplement | Xover | Placebo
Simons 2000 | 8 wk | Isoflavones | | | | 80 | 0 | 19 | FMD (RH) | % | 2.1 | +2 | NS | | +0.8 | NS | post♀ | | B
| | Placebo | | | | | | | | | | +1.2 | NS
Nestel 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 9 | Flow (RH) | % | nd | +88 ^d^ | | | +0.3 | NS ^ c ^ | post♀ | | C
| | Placebo | | | | | | | | | | +87 ^d^
| | Isoflavones | 45 | 35 | 3 | 80 | 0 | 9 | Flow (Ach 37) | % | nd | +87 ^d^ | | | +2 | NS ^ c ^
| | Placebo | | | | | | | | | | +85 ^d^
Supplement | RCT | Placebo
Squadrito 2003 | 52 wk | Genistein | 54 | | | | 0 | 27 | BAD (RH) | mm | 3.5 | +0.5 | | | +0.5 | 0.02 | post♀ | | B
| | | | | | | | | | | 3.5 | 0
| | | | | | | | | Flow (RH) | mL/dL/min | 24 | +11 | | | +10 | <0.001
| | Placebo | | | | | | 26 | | | 24 | +1
| | Genistein | 54 | | | | 0 | 27 | BAD (RH) | mm | 3.5 | +0.5 | | | +0.5 | 0.02
| | Placebo | | | | | | 26 | | | 3.5 | 0
Lissin 2004 | 6 wk | Isoflavones | 44 | 44 | 2 | 90 | 0 | 20 | FMD (RH) | % | 1.3 | +3.4 | NS | | +4 | NS | post♀ | | B
| | Placebo | | | | | | 20 | | | 3.8 | -0.6 | NS

%, percent change from basal level; Ach 37, Acetylcholine 37 μg/min infusion; BAD, Brachial artery diameter (mm); FMD, Flow-mediated dilation; PFV, Peak flow velocity; RH, Reactive hyperemia.

a Or difference between final values, as noted.

b Graph

c Difference of final values (cross-over study)

d Final values. No data on change from start of study.

e Intention-to-treat analysis (75 completed soy protocol, 78 completed control protocol)

f No data on how many men and how many women completed the study in each arm.

g Outcomes reported separately for men and women did not report numbers of subjects.

Endothelial cells in the intima layer of blood vessels play a central role in inhibiting the development of atherosclerosis and its thrombotic consequences. Production of nitric oxide by endothelial cells inhibits monocyte, leukocyte, and platelet adhesion to the vessel wall; decreases permeability to LDL; inhibits smooth muscle cell proliferation; and causes vessel dilation. Endothelial function is determined by measuring the dilation of blood vessels or increased blood flow in response to stimuli that cause endothelial cells to release paracrine factors such as nitric oxide. Patients with risk factors for coronary heart disease as well as those with established coronary heart disease have been found to have impaired vasodilator responses. However there is no evidence that improvements in endothelial function as currently measured results in reduced risk of cardiovascular disease.

The endothelial function of coronary arteries is measured by coronary angiography. The measurement parameter generally used is percent change in coronary artery diameter in response to acetylcholine infusion. Peripheral artery endothelial function is measured either as flow-mediated vasodilation, blood flow rate (or peak flow velocity) in forearm blood vessels including the brachial artery, or as peripheral artery diameter. Endothelial-dependent function is measured in response to a vasodilatory stimulus to the endothelium such as reactive hyperemia after a period of ischemia caused by forearm tourniquet or acetylcholine.

#### Study Descriptions

Nine RCTs - 5 with a cross-over design - and one cohort study reported the results for peripheral endothelial function of brachial artery. ^24,^ ^70,^ ^76,^ ^77,^ ^90,^ ^94,^ ^102,^ ^110,^ ^118,^ ^125^ One RCT recruited men and post-menopausal women while the other 8 had only post-menopausal women. The cohort study included only men. The duration of the studies ranged between 6 weeks and 1 year and the studies ranged in size from 18 to 179 subjects. The studies were of poor to moderate quality (1 A, 4 B, 5 C) with generally limited applicability to post-menopausal women; 2 studies also analyzed men. Two studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. Six studies investigated isolated soy protein with isoflavone, one of which also investigated isolated soy protein without isoflavone. The remaining 4 studies investigated pure soy isoflavones.

#### Overall Effect

Almost all the studies reported either no effect with soy product consumption on endothelial-dependent function or improvements in function, as implied by either increased brachial artery diameter (mm), flow-mediated dilation (% change from basal), flow (mL/min), or decreased peak flow velocity (cm/sec). Only Teede 2001 ^77^ found a statistically significant worsening of endothelial function, as indicated by a net decrease in flow-mediated dilation among men. In contrast, 3 studies reported statistically significant improvements in endothelial function ^76,^ ^102,^ ^125^ and the remaining studies generally also found small, non-significant improvements.

#### Soy Product, Dose, Other Variables

Given the variety of outcome metrics used by different studies and the small number of studies, it is difficult to make cross-study comparisons in regards to different types or doses of soy products investigated. The largest, most statistically significant improvement in endothelial function was reported by Squadrito 2003 ^125^ in a study of pure genistein in post-menopausal women. However, Lissin 2004, ^94^ the other study with a similar amount of pure soy isoflavones did not find a significant effect.

Only Steinberg 2003 ^102^ directly compared different soy products. Two isolated soy protein products, one with and one without isoflavones, were compared to milk protein. While the soy product with isoflavones resulted in a statistically significant improvement and the soy product without isoflavones did not, the difference between the 2 soy products was small and non-significant.

Teede 2001 ^77^ performed separate sub-analyses of men and post-menopausal women. As noted above, the only finding of a detrimental effect was seen among the men. A small, non-significant improvement was found among the women consuming soy protein with isoflavones.

#### Summary

Nine randomized trials and 1 cohort study of generally poor to moderate quality and limited applicability investigated the effect of isolated soy protein or pure soy isoflavones on endothelial-dependent function. Overall, limited evidence suggests a possible small improvement in endothelial-dependent function with consumption of soy products by post-menopausal women. However, 1 of 2 studies of men reported a significant worsening of function with soy consumption. There is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

### 3.2.12. Systemic arterial compliance

(Table 39)

Table 39 Effect of soy products on measures of systemic arterial compliance

Diet/Supplement | Design | Control | Dose | | | | | N | Artery Unit | Base value | Change | | | Net Change^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Meyer 2004 | 5 wk | Soy milk/ yogurt | | | | 80 | 30 | 23 | Arterial resistance Distal /small artery x 100 mL/mm Hg | 5.8 | -0.6 | NS | | -0.05 | NS ^ b ^ | post♀♂ | | B
| | Low fat milk/ yogurt | | | | | | | | | -0.6 | NS
| | Soy milk/ yogurt | | | | 80 | 30 | | Arterial capacitance Proximal/ large artery mL/mm Hg | 13 | +0.5 | NS | | -0.4 | NS
| | Low fat milk/ yogurt | | | | | | | | | +0.9 | NS
Supplement | RCT | Dairy
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 86 | Total arterial tree mL/mm Hg | 0.53 | +0.04 | | | +0.03 | NS | post♀♂ | | B
| | Casein | | | | | | 93 | | 0.56 | +0.01
| | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 96^c^ | | 0.54 | +0.06 | | | +0.06 | NS | ♂
| | Casein | | | | | | | | 0.62 | 0
| | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 83^c^ | | 0.52 | +0.02 | | | 0 | NS | post♀
| | Casein | | | | | | | | 0.50 | +0.02
Supplement | Xover | Placebo
Nestel 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 21 | Total arterial tree mL/mm Hg | 0.67 | +0.32 | <0.05 | | +0.19 | 0.01 | post♀ | | C
| | Placebo | | | | | | | | | +0.13 | <0.05

a Or difference between final values, as noted

b Difference of final values (cross-over study)

c No data on how many men and how many women completed the study in each arm.

Coronary arterial perfusion and the distribution of peripheral arterial blood depend on the viscoelastic nature of the aorta. “Arterial compliance” describes the ability of the aorta to distend during the elevated pressure associated with systolic ejection and recoil during the resting diastolic phase of the cardiac cycle Progression atherosclerotic arterial disease leads to a gradual stiffening of the arterial walls. This gradual reduction in aortic viscoelasticity increases cardiac workload and promotes inefficient function. Estrogens have been shown to reduce arterial compliance, dilatation, and blood flow. A beneficial effect of soy is expected to decrease arterial compliance, due to its putative estrogenic effect.

Vascular compliance is calculated as the reciprocal of the slope of the pressure-volume relationship. Techniquest to measure pressure and volume can be evaluated invasively (e.g., arterial catheters) or non-invasively (e.g., echocardiography). The physical units for compliance are typically mL/mm Hg.

#### Study Descriptions

Three RCTs - 2 with a cross-over design - reported the results for systemic arterial compliance. ^24,^ ^71,^ ^77^ All 3 used non-invasive techniques to measure small and large artery or total arterial tree compliance. Two of the studies recruited men and post-menopausal women while the third had only post-menopausal women. The largest included 213 subjects while the other 2 trials had sample sizes of 23 and 21. The duration of the studies ranged between 5 and 13 weeks. The studies were of poor to moderate quality (2 B, 1 C) with generally limited applicability to post-menopausal women and men; 1 study analyzed only post-menopausal women. One study incorporated the soy products into the diet; the remaining supplemented diets with soy products. One study investigated isolated soy protein with isoflavone, one used soymilk and the last study provided pure soy isoflavones.

#### Overall Effect

All studies reported an improvement in systemic arterial compliance as implied by either the decrease of arterial resistance or the increase in arterial capacitance. Only the smallest trial ^24^ found a statistically significant effect as indicated by a net increase in systemic arterial compliance in the total arterial tree among post-menopausal women. The remaining studies found small, non-significant improvements.

#### Soy Product, Dose, Other Variables

Given the small number of studies, it is difficult to make cross-study comparisons in regards to different types or doses of soy products investigated. The only statistically significant improvement in systemic arterial compliance was reported by Nestel 1997 ^24^ in a study of pure isoflavones in post-menopausal women. However, Meyer 2004, ^71^ the other study with a similar amount of pure soy isoflavones did not find a significant effect.

No study directly compared different soy products. Teede 2001 ^77^ performed separate sub-analyses of men and post-menopausal women. A small, non-significant improvement was found among the men consuming soy protein with isoflavones.

#### Summary

Three randomized trials of generally poor to moderate quality and limited applicability investigated the effect of soy protein or pure soy isoflavones on systemic arterial compliance. Overall, limited evidence suggests a possible small improvement in systemic arterial compliance with consumption of soy products by men and post-menopausal women. There is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

### 3.2.13. Oxidized Low Density Lipoprotein

(Table 40)

Table 40 Effect of soy products on measures of oxidized low density lipoprotein

Diet/Supplement | Design | Control | Dose | | | | | N | Outcome (Unit) | Base value | Change | | | Net Change^a^ | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Xover | Dairy
Jenkins 2002 | 4 wk | ISP w/Isoflavones | | | | 73 | 50 | 37 | CD (pmol/L) | 97.9 | -37% | | NS | -46% | 0.03 | post♀♂ | | C
| | ISP w/Isoflavones | | | | 10 | 52 | | | 82.2 | -25% | | | -34%
| | Dairy + egg protein | | | | | | | | 71.3 | +9%
| | ISP w/Isoflavones | | | | 73 | 50 | nd | | nd | -16% | | NS | -16% | NS | ♂
| | ISP w/Isoflavones | | | | 10 | 52 | | | | -16% | | | -16% | <0.05
| | Low fat dairy+egg protein | | | | | | | | | +1%
| | ISP w/Isoflavones | | | | 73 | 50 | nd | | nd | -20% | | NS | -55% | <0.01 | post♀
| | ISP w/Isoflavones | | | | 10 | 52 | | | | -18% | | | -53% | <0.01
| | Low fat dairy+egg protein | | | | | | | | | +35%
Jenkins ^b^ 1999 | 4 wk | ISP w/Isoflavones | 17 | 34 | 4 | 86 | 33 | 31^b^ | CD (pmol/L) | 67 | -16% | | | -18% | <0.001 | post♀♂ | | B
| | Vegetarian diet | | | | | | | | 62 | +2%
| | ISP w/Isoflavones | 17 | 34 | 4 | 86 | 33 | | CD:LDL (μmol/mmol) | 15.7 | -4% | | | -12% | 0.03
Jenkins ^b^ 2000 10778882 | | Vegetarian diet | | | | | | | | 14.6 | +8%
| | ISP w/Isoflavones | 17 | 34 | 4 | 86 | 33 | | TBARs (μmol/L) | 6.08 | -1% | | | +1% | NS
| | Vegetarian diet | | | | | | | | 6.35 | -2%
Jenkins ^b^ 2000 10647066 | 4 wk | ISP w/Isoflavones | | | | 168 | 36 | 20^b^ | CD:LDL (μmol/mmol) | nd | 12.9^c^ | | | -8% | 0.02 ^ d ^ | post♀♂ | | C^e^
| | Low fat dairy protein | | | | | | | | | 14^c^
Diet | Xover | Animal diet
Ashton 2000 11194529 | 4 wk | Tofu | 84 | 35 | | 120 | 36 | 42 | Lag time (min) | nd | 49.23 ^ c ^ | | | -14% | 0.01 ^ d ^ | ♂ post♀ | | C
| | Lean meat | | | | | | | | | 42.45 ^ c ^
Diet | Xover | Miscellaneous
Gardner-Thorpe 2003 | 6 wk | Soya flour | 45 | 75 | | 120 | | 19 | Hydroperoxides (μmol/L) | 2.69 | -13% | | | -9% | 0.009 | ♂ | | B
| | Wheat flour | | | | | | | | | -4%
| | Soya flour | 45 | 75 | | 120 | | | Lag time (min) | 59 | +2% | | | 0% | NS
| | Wheat flour | | | | | | | | | +2%
Diet | Cohort | No control
Scheiber 2001 | 12 wk | Soy nuts & milk | | | | 60 | | 42 | Lag time (min) | 34.9 | +9% | <0.05 | | -- | | post♀ | | C
| | No control group | | | | | | -
Supplement | Xover | Dairy
Bricarello 2004 | 6 wk | Soy milk | 50 | 33 | 5 | 87 | 25 | 60 | TBARs (nmol/mL) | 1.82 | -18% | | | -23% | <0.05 | ♀♂ | | C
| | Non-fat milk | | | | | | | | | +5%
Kurowska 1997 | 4 wk | Soy milk | | | | | 31 | 34 | TBARs (μmol/mL) | 1.35 | +4% | | | +11% | 0.01 | ♀♂ | | B
| | Milk, 2% fat | | | | | | | | | -7%
Supplement | Xover | Placebo
Nestel 1997 | 5 wk | Isoflavones | 45 | 35 | 3 | 80 | 0 | 15 | Lag time (min) | nd | 53.2^c^ | | | -1% | NS ^ d ^ | post♀ | | C
| | Placebo | | | | | | | | | 53.5 ^c^
| | Isoflavones | 45 | 35 | 3 | 80 | 0 | | Ox Rate (nmol/mg) | nd | 14.1 ^c^ | | | -2% | NS ^ d ^
| | Placebo | | | | | | | | | 14.4 ^c^
| | Isoflavones | 45 | 35 | 3 | 80 | 0 | | Max Diene C (nmol/mg ) | nd | 406 ^c^ | | | -1% | NS ^ d ^
| | Placebo | | | | | | | | | 409 ^c^
| | Isoflavones | 45 | 35 | 3 | 80 | 0 | | TBARs (nmol/mg) | nd | 72 ^c^ | | | +3% | NS ^ d ^
| | Placebo | | | | | | | | | 70 ^c^

CD:LDL: Ratio of conjugated dienes (μmol) per mmol LDL; CD: conjugated dienes; TBARs: thiobarbituric acid reactive substances; Ox Rate: oxidation rate; Max Diene C: maximum diene concentration

a Or difference between final values, as noted

b Jenkins 2000 (UI 10647066) included a subset of subjects from Jenkins 1999 / Jenkins 2000 (UI 10778882), but in a separate study.

c Final values (baseline data not reported).

d Difference of final values (cross-over study)

e In contrast with other outcomes in this article, no baseline CD:LDL value was reported

LDL is normally oxidized to a highly injurious product that results in characteristic endothelial dysfunction in large arteries and resistance vessels. The administration of lipid-soluble antioxidants such as vitamin E or probucol is associated with an increase in the resistance of LDL to oxidative modification. However, trials have not supported the hypothesis that supplementation of vitamin E or probucol in humans reduces cardiovascular risk.

Oxidation of LDL is usually evaluated by studying the kinetics of copper-mediated LDL oxidation products in vitro. Typically purified LDL is mixed with copper ions and monitored by means of spectrophotometry for 5 to 6 hours. From the absorbance-over-time curve the following parameters can be estimated: the lag time (expressed in minutes) which is defined as the interval between the initial absorbance and the start of the oxidation phase (start of the propagation phase); the rate of protein-conjugated diene production which is defined as the slope during the oxidation of LDL; the maximal concentration of diene produced during LDL oxidation; and the time of maximal concentration (T max). These parameters can be used to indicate how soy consumption influences the susceptibility of LDL to oxidation.

A beneficial effect of soy on LDL oxidation is expected to decrease all or most of the four parameters above. However, there is little agreement as to which parameter is the best measure of LDL oxidizability. More importantly, it is not clear that any in vitro measure of LDL oxidizability truly measures LDL oxidizability in the body or levels of LDL oxidation in atherosclerotic lesions. There is currently no indication that reducing any measure of LDL oxidation is associated with clinical benefit.

#### Study Descriptions

Eight RCTs with a cross-over design (reported in 9 articles), and one cohort study reported the results for oxidized LDL. ^24,^ ^49,^ ^57,^ ^64,^ ^68,^ ^69,^ ^85,^ ^126^ – ^128^ Two RCTs recruited men and women, 4 men and post-menopausal women while 1 had only men, and 1 included only post-menopausal women. The cohort study recruited only post-menopausal women. The sample sizes for the RCTs ranged between 15 and 73. The cohort study had 42 participants. The duration of the studies ranged between 4–12 weeks. The metric used to determine oxidized LDL included ratio of conjugated diene concentration in 1 study, lag time when copper used as oxidative means in 2 studies, conjugated diene concentration in 1 study, and concentration of thiobarbituric acid reactive substances (TBARs) in 2 studies. One RCT reported conjugated diene concentration, and TBARs in 2 publications. There was also an RCT that used both hyperoxide concentration and lag time to evaluate LDL oxidation. Another trial reported lag time, oxidation rate, and maximum diene concentration as well as TBARs. The studies were generally of poor quality (3 B, 6 C) with moderate to good applicability to women and men; 1 study also analyzed men and another one post-menopausal women. Three studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. Four studies investigated isolated soy protein with isoflavone, 3 investigated soymilk, one of which added soy nuts, as well. One study provided tofu, and another one soy flour. The last study investigated pure soy isoflavones.

#### Overall Effect

Almost all the studies reported either no effect with soy product consumption on oxidation parameters or improvements in oxidized LDL, as implied by the decrease in all or in the majority of the markers measured in each trial. Only Kurowska 1997 ^69^ and Scheiber 2001 ^128^ found a statistically significant worsening of oxidation markers, as indicated by an 11 percent increase in TBARs among men and women, and a net increase in lag time within post-menopausal women, respectively in the 2 studies. In contrast, 7 controlled trials reported statistically significant improvements in oxidized LDL ^49,^ ^57,^ ^64,^ ^68,^ ^126,^ ^127^ and the remaining study ^24^ also found small, non-significant improvements in 3 out of 4 oxidation parameters.

Two additional studies reported findings that are not included in the Summary Table. A randomized cross-over study provided soycreme (10.6% protein, 180 ml of a 1:1 soycreme-water mixture) to patients with cerebral thrombosis. ^129^ Kanazawa 1995 ^129^ reported as outcomes the X1 and X2 spots, formulated by lipids when developed on thin-layer chromatography and was stained in standing iodine vapor. X1 and X2 spots reflect the lipoprotein peroxidation. Higher percentages of these spots were observed after CuCl_2_ oxidation in patients not consuming the soycreme compared with those who received soycreme (P<0.01 in 24, 48, and 72 hours). Steinberg 2003, ^102^ which measured lipid oxidation susceptibility by conjugated diene formation, found no significant differences among treatment groups either as absolute values or as the change in lag time from baseline. This study did not report specific data.

#### Soy Product, Dose, Other Variables

Given the variety of outcome metrics used by different studies and the small number of studies, it is difficult to make cross-study comparisons in regards to different types or doses of soy products investigated. Jenkins 2002 ^49^ reported the largest, most statistically significant improvement in LDL oxidation, as estimated by conjugated diene concentration, in a study of isolated soy protein with isoflavones in the group of post-menopausal women. All studies that reported isoflavone dose, administered higher doses of isoflavones than Jenkins 2002 ^49^ but did not reach an effect. Scheiber 2001, ^128^ however, mentioned a significant worsening for oxidized LDL.

Only Jenkins 2002 ^49^ directly compared different isoflavone doses. Two isolated soy protein products, one providing 73 mg per day and one 10 mg per day isoflavones, were compared to milk protein. Both isoflavone doses resulted in a statistically significant improvement.

Jenkins 2002 ^49^ also performed separate sub-analyses of men and post-menopausal women. As noted above, the largest significant improvement was seen in post-menopausal women. A smallest, significant improvement was found among the men consuming soy protein with 10 mg per day isoflavones while a similar but non-significant improvement was reported among the men with 73 mg of isoflavones per day.

#### Summary

Nine randomized trials and 1 cohort study of generally poor quality and moderate to good applicability investigated the effect of soy protein or pure soy isoflavones on LDL oxidation. Overall, evidence suggests a possible improvement in LDL oxidation with consumption of soy products by men or women. However, 1 of 2 studies of men and women found a significant worsening of LDL oxidation with soy consumption. There is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

## 3.3. Menopausal Symptoms

(Tables 41–45)

Table 41 Summary of studies included for outcomes of menopausal symptoms

Author, Year | Clinical Outcomes - Menopausal Symptoms | | | | Intermediate markers of menopausal symptoms
| Vasomotor symptoms | | Psychological symptoms | All other menopausal symptoms
| Hot Flash | Night Sweat
Albert, 2002 | X | | Depression, anxiety, insomnia | Vaginal dryness, bone pain, loss of libido
Albertazzi, 1998 | X
Balk, 2002 | X | X | Depression, insomnia | Urinary discomfort, headache, palpitations, loss of libido
Burke, 2001 | X | X
Crisafulli, 2004 | X
Dalais, 1998 | X | | | | Vaginal cytology maturation
Faure, 2002 | X | X
Han, 2002 | X | | Insomnia, nervousness, melancholia | Vertigo, weakness, arthralgia and myalgia, headache, palpitation, formication
Knight, 2001 | X | | Greene psychological and somatic score
Kotsopoulos, 2000 | X | | Irritability, depression, unloved feelings, anxiety, insomnia tiredness | Vaginal dryness, loss of libido, dyspareunia, headaches, joint pain, muscle pain, backache, facial hair, dry skin
Murkies, 1995 | X | | | | Vaginal maturation index
Nikander, 2004 | X | | Depression, Self-confidence | Menopausal visual analogue scale, work ability index
Penotti, 2003 | X
Quella, 2000 | X
Russo, 2003 | X
Scambia, 2000 | X | | | | Vaginal cytology maturation
Secreto, 2004 | Greene vasomotor subscale | | Greene psychological subscale | Greene somatic subscale | Occurrence of menstrual flow
St Germain, 2001 | X | X | Mood swings | Loss of libido, vaginal dryness, urinary frequency or urgency
Upmalis, 2000 | X | X | | | Endometrial thickness, vaginal maturation index
Van Patten, 2002 | X
Washburn, 1999 | X

Table 42 Number of women's health studies included with different study designs (and total)

Study Design | Vasomotor Symptoms
Parallel | 16
Cross-over | 4
Single-Cohort trial | 1
Total | 21

Table 43 Number of women's health studies included within each population and quality category

Quality | Vasomotor Symptoms
Population Category | | A | B | C
| Total
Post-Menop Women | 17 | 1 | 4 | 12
Pre-Menop Women | 0 | 0 | 0 | 0
Peri-Menop Women | 3 | 0 | 2 | 1
All Women | 1 | 0 | 0 | 1

Post-Menop = post-menopausal; Pre-Menop = pre-menopausal

Table 44 Number of women's health studies (or study arms) included that used different types of soy products, controls, or soy consumption types (diet versus supplement)

| Vasomotor Symptoms
Soy Product (Study Arms)
Protein with Isoflavones | 11
Protein without Isoflavones | 1
Isoflavones | 9
Control Types (Study Arms)
Casein | 3
Animal/Usual Diet | 0
Placebo | 10
Miscellaneous | 5
No Non-Soy Control | 2
Diet or Supplement (Studies)
Diet | 3
Supplement | 18

Table 45 Number of women's health studies that directly compared the effects of different soy product characteristics or study subject characteristics

Comparison Characteristics | Vasomotor Symptoms
Protein with v without Isoflavones | 2
Different Soy Protein Dosages | 0
Different Soy Isoflavone Dosages | 2
Different Population Categories | 0

A total of 21 trials examine the effects of soy and/or its isoflavones on clinical outcomes of menopausal symptoms (Tables 41–45). Menopausal symptoms usually include vasomotor (e.g., hot flashes and night sweat), psychological (e.g., depression, anxiety, insomnia), and various other symptoms (e.g. palpitations, loss of libido) associated with estrogen deficiency. Vasomotor symptoms are the most common and most studied symptoms of menopause.

## Vasomotor Symptoms

(Tables 46–47)

Table 46 Effects of soy products on vasomotor symptoms (e.g. hot flash frequencies or scores) in post-menopausal women

Diet Supplement | Design | Control | Dose | | | | | N | Base Value | Unit | % Change | | | Net % Change | | Base Prev (Hot Flash) | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | | Value | Pwithin | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Xover | Miscellaneous
Dalais 1998 | 12 wk | Soy bread | | | | 53 | | 44 | nd | Frequency per day | -23 ^a^ | NS | | +28 | | 100% | | C
| | Wheat bread | | | | | | | | | -51 | <0.01
Diet | RCT | Miscellaneous
Murkies 1995 | 12 wk | Soy flour | 40 g of flour per day | | | | | 23 | 42 | Frequency per week^n^ | -42 | <0.001 | | -17 | NS | 100% | | C
| | Wheat flour | | | | | | 24 | 37.1 | | -25 | <0.001
Balk 2002 | 6 mo | Soy cereal | | | | ~100 | | 13/7 ^b^ | 1.31 | Frequency per week | -33 | 0.06 | | +28 | | nd | | C
| | Corn cereal | | | | | | 14/12 ^b^ | 1.28 | | -61 | 0.01
Supplement | RCT | Miscellaneous
Van Patten, 2002 | 4 wk | Soy beverage | | | | 90^q^ | | 59 | 4.7 | Frequency per week | -26 | <0.05 | | +9 | NS | 100% | | C
| | Rice beverage | | | | | | 64 | 5.2 | | -35 | <0.05 | | | | | BrCA
Supplement | RCT | Casein
Albertazzi 1998; 1999 | 12 wk | ISP w/Isoflavones | 40 | 28 | | 76 | 40 | 40 | 11.4^c^ | Frequency per week | -44 ^r^ | <0.05 | | -13 | <0.01 | 100% | | B
| | Casein | | | | | | 39 | 10.9^c^ | | -31 ^r^ | <0.05
Kotsopoulos 2000 | 3 mo | ISP w/Isoflavones | | | | 96.3^d^ | 56^d^ | 31 | 0.82 | Hot flash score ^m^ | -6 | NS | | -4 | | 80% | | C
| | Casein | | | | | | 41 | 0.85 | | -2 | NS
Knight 2001 | 12 wk | ISP w/Isoflavones | 49 | 25 | 3 | 77 | 35 | 9 | 4.18 | Frequency per week^e^ | -43 | | | -23 | NS | nd | | C
| | Casein | | | | | | 11 | 4.68 | | -20
Supplement | Xover | Placebo
Russo 2003 | 3 mo | Isoflavones | | | | 32 | 0 | 47 | nd | Overall no improvement rate | -17 ^f^ | <0.05 | | +5 | | 100% | | B
| | Placebo | | | | | | | | | -22 ^f^ | <0.05
Nikander 2004 | 3 mo | Isoflavones | 7 | 41 | 66 | 114 | 0 | 28 | 2 | Hot flash score ^c^ | -10 | NS | | +4 | NS | 100% | | B
| | Placebo | | | | | | | 2.1 | | -14 | 0.006 | | | | | BrCA
Supplement | RCT | Placebo
Secreto 2004 | 3 mo | Isoflavones | 12 | 40 | 28 | 80 | 0 | 59 | 4 | Vasomotor score g | 25% no improve g | | | -6 | <0.05 | nd | | B
| | Placebo | | | | | | 58 | 4 | | 31% no improve g
| | Isoflavones + melatonin | 12 | 40 | 28 | 80 | 0 | 61 | 4 | | 38% no improve g | | | | -1 | NS
| | Melatonin | | | | | | 54 | 4 | | 39% no improve g
Upmalis 2000 | 12 wk | Isoflavones | 50 h | | | | 0 | 59 | 56.7 | Frequency per week n | -26^a^ | <0.05 | | -7 | 0.008 p | 100% | | C
| | Placebo | | | | | | 63 | 63.7 | | -19 ^a^ | <0.05
Han 2002 | 4 mo | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 11.3 | Hot flash score ^c^ | -27 | <0.01 | | -26 | <0.01 | nd | | A
| | Placebo | | | | | | 40 | 63.7 | | -1 | NS
Faure 2002 | 16 wk | Isoflavones | | | | 17.5 | 0 | 39/32 ^b^ | 10.1 | Frequency per week | -61 | | | -40 | 0.01 | 100% | | C
| | Placebo | | | | | | 35/22 ^b^ | 9.4 | | -21
Crisafulli 2004 | 1 yr | Genistein | 54 | | | | 0 | <30 ^i^ | 4.6 | Hot flash score ^o^ | -50 ^a^ | | | -24 | <0.01 | 100% | | C
| | Placebo | | | | | | <30 ^i^ | 4.7 | | -30 ^a^
Penotti 2003 | 6 mo | Isoflavones | 11 | 36 | 25 | 76 | 0 | 28/22 ^b^ | 2.48 | Frequency per week j | -54 | | | 0 | NS | nd | | C
| | Placebo | | | | | | 34/27 ^b^ | 2.15 | | -54
Scambia 2000 | 6 wk | Isoflavones | | | | 50 | 0 | 20 | 27 | Frequency per week | -45 ^a^ | | | -21 | <0.01 | nd | | C
| | Lactose | | | | | | 19 | 33 | | -24 ^a^
Supplement | NRCT | No Control
Albert 2002 | 4 mo | Isoflavones | | | | 35 ^k^ | 0 | 146 | 0.83 | Hot flash score ^l^ | -56 | <0.003 | -- | -- | | 100% | | C
| | No control | | | | | | --

Table 47 Effects of soy products on vasomotor symptoms (e.g. hot flash frequencies or scores) in peri-menopausal women

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Unit | % Change | | | Net % Change | | Population | Base Prev (Hot Flash) | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Supplement | Xover | Placebo
Quella 2000 | 4 wk | Isoflavones | 60~68 | 60~68 | 15~30 | 150 | 0 | 177/149^b^ | 12 | Hot flash score ^c^ | -30 ^ a ^ | | | +2 | NS | ♀ BrCA | 100% | | C
| | Placebo | | | | | | | 13 | | -32 ^ a ^
Washburn 1999 | 6 wk | ISP w/Isoflavones once daily | | | | 34 | 14 | 42 | nd | Frequency per week | 23 ^d^ | | NS | +2 ^ d ^ | NS | peri♀ | 100% | | C
| | ISP w/Isoflavones twice daily | | | | 34 | 14 | | | | 22 ^d^ | | | +1 ^ d ^ | NS
| | Carbohydrates | | | | | | | | | 21 ^d^
Supplement | RCT | Miscellaneous
St Germain 2001 | 24 wk | ISP w/Isoflavones | | | | 80 | 40 | 24 | 36 | Frequency per week | -50 | | nd | -3 | NS | peri♀ | 100% | | B
| | ISP w/o Isoflavones | | | | 4.4 | 40 | 24 | 36.5 | | 0 | | | +47 | NS
| | Wheat protein | | | | | | 21 | 32 | | -47
Supplement | RCT | No Control
Burke 2001 | 2 yr | ISP w/Isoflavones | | | | 58 | 25 | 65 | 22.4 | Frequency per week ^e^ | -59 | <0.0001 | NS | -- | | peri♀ | 96.9% | | B
| | ISP w/Isoflavones | | | | 42 | 25 | 76 | 18.2 | | -42 | <0.0001 | | -- | | | 94.7%
| | ISP w/o Isoflavones | | | | ≤4 | 25 | 70 | 24.5 | | -77 | <0.0001 | | -- | | | 98.6%
| | No control | | | | | | --

BrCA = breast cancer women who were suffering from hot flashes, as defined by their occurrence of> 14 times per week and of such severity to warrant intervention (tamoxifen or raloxifene therapy was allowed). Base Prev (Hot Flash) = baseline prevalence of hot flash in the study population.

a Values were estimated from graph

b Baseline / final number of subjects

c Daily frequency x severity

d Data are not % change but final hot flash frequency and calculated net change. No data are found on baseline frequency.

e Derived from vasomotor symptoms (hot flash and night sweat) reported per day

The common vasomotor symptoms associated with menopause include hot flashes (or flushes) and night sweats. The 21 trials that evaluated vasomotor symptoms generally measured frequency and severity of the symptoms using a wide variety of vasomotor symptom scores or indices. These factors make meta-analyses unsuitable and limited the comparisons of results across studies. Furthermore, many of the studies had high withdrawal or dropout rates that were frequently uneven between soy treatment and control arm; this further limits the validity of these clinical trials.

Due to different time intervals for hot flash frequencies and different measurement tools for hot flash scales (sometimes including night sweats), the baseline values are not comparable across studies. In order to gain insight on the effects of soy and/or its isoflavones from this group of variable studies, we first converted the different measurements to a standard unit (percent change from baseline) and, when possible, to the same time interval for hot flash frequencies. A negative percent change in the hot flash scores or frequency indicates a beneficial effect of the treatment, indicating that treatments of soy and/or its isoflavones treatment have net reductions of vasomotor symptoms. Since placebo effects (significant changes within the placebo or control groups) were observed in all studies, a positive net percent change indicates only that treatments of soy and/or its isoflavones were less effective than control in reducing vasomotor symptoms, not that symptoms worsened due to soy treatment.

### Hot Flash Frequencies or Scores in Post-Menopausal Women

(Table 46)

#### Study Descriptions

A total of 17 studies (in 18 articles) reported hot flash frequencies or scroes in post-menopausal women, including 3 soy diet trials and 14 soy supplement trials. ^46,^ ^47,^ ^66,^ ^91,^ ^130^ – ^143^ Twelve of the 17 studies are of poor quality (grade C); only 2 are high-quality studies (grade A); and the remaining studies are of medium quality (grade B).

Two RCTs and 1 cross-over study compared soy diet with different types of grains (wheat or corn) as controls. The methodological quality of these 3 studies was poor. No consistent effect was found in this group of studies.

Four trials examined the effects of soy protein supplements with isoflavones on vasomotor symptoms. One (Van Patten 2002) evaluated post-menopausal women with breast cancer. ^132^ The other trials compared soy to casein in healthy post-menopausal women. All studies reported that soy supplements decreased hot flash scores or frequency. However, in the study of women with breast cancer the control group had a statistically non-significant greater decrease in frequency, and only in the study by Albertazzi 1998, ^133^ was the decreas statistically significantly greater than control. Of note though, in Kotsopoulos 2000, 20% of the women had no hot flash symptoms at baseline, lowering the likelihood of finding a benefit. ^135^ In addition, all studies had small sample sizes and/or high dropout rates.

Nine trials (2 cross-over trials and 7 RCTs) examined the effects of soy isoflavones (without soy protein) on vasomotor symptoms. The 2 cross-over trials showed that placebo decreased hot flash symptoms as much as isoflavones. Six of the 7 RCTs found significant effects of soy isoflavones in reducing vasomotor symptoms in post-menopausal women. In contrast, Penotti 2003 found that both soy isoflavone treatment as well as the placebo decreased the same numbers of hot flashes per month. ^142^ However, the initial hot flash frequency in this study was lower compared to the other 6 RCTs of isoflavone supplements.

One non-controlled trial by Albert 2002 showed that 4-month soy isoflavone supplementation decreased the hot flash score significantly in 146 post-menopausal women who suffered at least 6 moderate or severe daily hot flashes during the 15 days prior to the study. ^143^ Since statistically significant decreases in vasomotor symptoms were common in the control arms of other studies, it cannot be concluded that this study supports a benefit of soy isoflavones.

#### Summary

Overall, the effects of soy protein and/or its isoflavones are inconsistent across studies. Every trial found a decrease in hot flash frequencies or scores in the treatment groups, as well as in the control or placebo groups. This makes the results difficult to be interpreted. Across studies, 6 (35%) studies showed no or worsening effects and 11 (65%) studies showed soy protein and/or its isoflavones non-significantly or significantly decreased hot flash frequencies or scores in post-menopausal woemen. The evidence of a benefit was stronger among the RCTs of isoflavone supplements, which mostly showed positive results - the net reduction in weekly hot flash frequency ranged from 7% to 40%. However, these trials are mostly rated as poor quality due to high dropout rates.

### Hot Flash Frequencies or Scores in Peri-Menopausal Women and Women who had Breast Cancer Therapies

(Table 47)

#### Study Descriptions

Four studies reported hot flash frequencies or scores in non-post-menopausal women, ^23,^ ^117,^ ^144,^ ^145^ including 3 studies in peri-menopausal women and 1 study in women who were on breast cancer therapies. Two were cross-over trials and 2 RCTs. Of these, 3 trials compared soy protein and/or its isoflavones to a placebo or casein control. No significant effect of soy protein and/or its isoflavones on vasomotor symptoms was found in peri-menopausal women or women who had breast cancer therapies, although 1 study (St Germain 2001) found that women who received isolated soy protein without isoflavones had no change in the weekly hot flash frequency while those who received soy protein with isoflavones or placebo had decreased frequency. ^145^

Burke 2001 compared the effects of high and medium dose isolated soy protein with isoflavones to isolated soy protein without isoflavones on vasomotor symptoms in peri-menopausal women. ^146^ It found that all 3 treatments significantly decreased the daily reported vasomotor symptoms (hot flashes and night sweats), but there was no significant difference of the effects among the 3 treatments and there was no non-soy control group.

#### Summary

There are only 4 studies that evaluated the effect of soy consumption on menopausal symptoms in peri-menopausal women or those receiveing breast cancer therapy. Among these studies there is no evidence that soy consumption is better than control to reduce menopausal symptoms. The range of changes in symptoms among women consuming soy was large, from -77% to +23%.

## 3.4. Endocrine Function

(Tables 48–50)

Table 48 Endocrine functions evaluated in soy studies (not including studies of menstrual cycle length)

Author Year | Testosterone | FSH | Estradiol | TSH | LH | Estrone | Estrone sulfate | Progesterone | Prolactin | Androstenedione | DHEA/DHEAS | Other Sex Hormone | 2-hydroxyestrone | 16-alpha-hydroxyestrone | Other U Sex Hormone | SHBG | T3 | T4 | TBG | PTH | Cortisol | IGF-1 | Other Endocrine
Duncan 1999 10522983 | x post | x | x | x | x | x | x | | x | x | x | | | | | x | x | x | x | | x
Scambia 2000 | | x nd | | | x | | | | x | | | | | | | | | | | x
Upmalis 2000 | | x
Lu 2000 | | x nd | x nd | | x | | | x
Xu 2000 | | | | | | | | | | | | | x | x | x
Watanabe 2000 | | | x
Mackey - Study 1 2000 (post-menop) | | x nd | | x nd | x | | | | | | | | | | | x
Mackey - Study 2 2000 (men) | x nd | x nd | | x nd | x | | | | | x | x | | | | | x
Gardner 2001 | | x nd | x nd | | | x | | | | x
Nagata 2001 | x | | x men | | | x | | | | | | | | | | x
Stroescu 2001 | x pre | | x | | | | | x | x | | | | | | x | | x | x
Knight 2001 | | x | | | | | | | | | | | | | | x | | | x
Teede 2001 | x | x | | | x
Scheiber 2001 | | x | x
Persky 2002 | | x | x | x | | x | x | | | | x | x | x | x | | x | x | x | | | x | | x
Han 2002 | | x | x | | x
Kumar 2002 | | | x | | | x | | | | | | | | | | x
Swain 2002 | | x nd | x nd | | | x
Khalil 2002 | | | | | | | | | | | | | | | | | | | | | | x
Jayagopal 2002 | x post | x | | x | x | | | | | x | x | | | | | x | x | x
Morabito 2002 | | | x | | | | | | | | | | | | | | | | | x
Brown 2002 | x pre | x | x nd | | x | x | x | x | x | x | x | | x | x | | x | | | | | x
Gardner-Thorpe 2003 | x | | x men | | | x | | | | | | x | | | | x
Arjmandi 2003 | | | x | | | | | | | | | | | | | | | | | | | x
Squadrito 2003 | | | x
Nikander 2003 | | x | x | | x | | | | | | | | | | | x
Cuevas 2003 | | x
Chiechi 2003 | | x | x
Cassidy 1995 Study 3 | | x | x | | x | | | x | | | | | | | x | x
Cassidy 1995 Study 4 | | x | x | | x | | | x | | | | | | | | x
Murkies 1995 | | x
Cassidy 1994 | x pre | x | x | | | | | x | | | | | | | x | x
Nagata 1998 | | | x | | | x | | | | | | | | | | x
Duncan 1999 9920082 | x pre | x | x | x nd | x | x | x | x | x | x | x | | | | | x | x | x | x | | x
Ham 1993 | | | | x | | | | | | | | | | | | | x | x
Lu 1996 | | | x nd | | | | | x | | | x
Wu 2000 | | | x nd | | | | | x | | | | | | | | x
Hsu 2001 | | | x
Foth 2003 | x post | x | x | | x | | | | x | | x
Uesugi 2003 | | x
Martini 1999 | | | x nd | | | x | | x | x | | x | x | | | x | x
Adams 2003 | | | | | | | | | | | | | | | | | | | | | | x
Bruce 2003 | | | | x
Mitchell 2001 | x | x | x men | | x
Baird 1995 | | x | | | x | | | | | | | | | | | x
Petrakis 1996 | | | x | | | | | x | x | | | | | | | x
Maskarinec 2004 | | | x | | | x | | x | | | x | | | | | x
Lu 2001 | | x | x | | x | | | x | | | | | | | | x
Habito 2000 | x | | x men | | | | | | | x | x | | | | | x | | | | | | | x
Lenn 2002 | | | | | | | | | | | | | | | | | | | | | x

nd: no data; pre: pre-menopausal women; post: post-menopausal women

Summary tables do not include studies that measured testosterone in women (pre or post), or estradiol in men; also studies with “nd” have not been analyzed in the summary tables

Other Sex Hormone: SHBG-bound estradiol (%); Dihydrotestosterone; Ratio: Progesterone/Estradiol

Other Urinary Sex Hormone: estrogens & estrogen metabolites; 17-ketosteroids metabolites of androgenic steroids; urinary LH; ratio: 2-OH-estrone/ 16-a-OH-estrone

Other endocrine outcomes: free thyroxine index (FTI); free androgen index; ratio: testosterone/estradiol.

Table 49 Number of endocrine studies included with different study designs (and total)

Study Design | Endocrine Trials ^a^ | Menstrual Cycle Length
Parallel | 21 | 7
Cross-over | 8 | 2
Single-cohort trial | 10 | 2
Total | 39 | 11

a Based on studies that have been included in the following tables: 51–56, 58

Table 50 Number of endocrine studies (or study arms) included that used different types of soy products, controls, or soy consumption types (diet versus supplement)

| Endocrine Trials ^a^ | Menstrual Cycle Length
Soy Product (Study Arms)
Protein with Isoflavones | 27 | 12
Protein without Isoflavones | 3 | 1
Isoflavones | 15 | 1
Control Types (Study Arms)
Dairy | 5 | 3
Animal/Usual Diet | 6 | 4
Placebo | 13 | 0
Miscellaneous | 3 | 0
No Non-Soy Control | 12 | 1
Diet or Supplement (Studies)
Diet | 14 | 8
Supplement | 25 | 4

a Based on studies that have been included in the following tables: 51–56, 58

Because of the structural similarity of soy isoflavones to estrogens, it has been suggested that these isoflavones might act as either an agonist or antagonist of estrogen. Several hypotheses have been developed for isoflavones that may have a potential effect on estrogens and their metabolites as well as on other hormones that interfere with estrogen metabolism and pathways of estrogen action. However, it should not be assumed that such effects based on biologically plausible mechanisms of action are also correlated to clinical consequences. Interpretations of soy-related effects on endocrine markers must equally be treated with caution.

Estrogen levels are different between men and women and they are also different between pre-menopausal and post-menopausal women. Therefore, a potential effect of soy isoflavones might be of different clinical importance according to gender and age. To avoid any misinterpretation, endocrine results have been analyzed separately for men, pre-menopausal, and post-menopausal women.

Menstrual cycle length is the number of days from the start of one menstrual bleeding period to the start of the next bleeding period. Normal menstrual cycles require a normal endocrine environment. This endogeous hormonal environment may play a role throughout a woman's life in determining her long-term risk of developing chronic disease ^78,^ ^147^ – ^149^ . In addition, a woman's menstrual cycle is an important indicator of her reproductive health.

Forty-seven papers included 50 trials and reported a large number of endocrine outcomes as primary or secondary endpoints (Table 48). In consultation with the TEP, we focused on the most clinically relevant sex hormones - testosterone, follicle stimulating hormone (FSH), and total estradiol (E2) - and thyroid stimulating hormone (TSH). Eleven studies in 10 articles also evaluated menstrual cycle length. All endocrine-related studies are summarized in Tables 49–50.

### 3.4.1. Testosterone

(Table 51)

Table 51 Effect of soy products on testosterone (nmol/L) in men

Diet /Supplement | Design | Control | Dose | | | | | N | Base Value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Xover | Miscellaneous
Habito 2001 | 4 wk | Tofu^a^ | | | | | | 15 | 15.1 | +0.4 | NS | | +0.1 | NS | ♂ | II | C^a^
| | Animal diet | | | | | | | | +0.3 | NS
Diet | Cohort^b^ | No control^b^
Gardner-Thorpe 2003 | 6 wk | Soy flour | 45 | 75 | | 120 | | 19 | 19.3 | -1.1 | NS | | nd | NS | ♂ | | C^b^
| | Wheat flour^b^ | | | | | | | | nd | NS
Supplement | RCT | Casein
Teede 2001 | 13.5 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 96^c^ | 16.8 | -1.5 | NS | | -0.5 | | ♂ | | C^c^
| | Casein | | | | | | | 15.8 | -1 | NS
Nagata 2001 | 8 wk | Soy milk | 2.4 | 2.4 | | 4.8 | 26.3 | 17 | 16.3 | -2.2 | NS | | -1.8 | NS | ♂ | | C
| | Usual diet | | | | | | 17 | 15.6 | -0.4 | NS
Supplement | Cohort | No control
Mitchell 2001 | 8 wk | Isoflavones | | | | 40 | 0 | 15 | 30.25 | -3.9 | NS | | -- | | ♂ | | C
| | No control group | | | | | | --

a 150g of tofu; no other ingredient is quantified

b Overall study is a randomized cross-over trial; however, testosterone data reported only for soy cohort (in contrast with other outcomes in this article).

c In contrast with other outcomes in this article, no data on how many men completed the study in each arm.

Higher testosterone level is considered a potential risk factor for prostate cancer by the National Cancer Institute (NCI) (www.nci.nih.gov/cancertopics/pdq/prevention/prostate/). A beneficial effect of soy on risk for prostate cancer is expected to decrease testosterone levels. The National Guideline Clearinghouse also has published guidelines that recommend testosterone should be measured in males as part of the initial evaluation for infertility (www.guideline.gov/summary/summary.aspx?doc_id=2924). Low testosterone levels have been related with clinical conditions that cause male infertility. A beneficial effect of soy on male infertility is expected to increase testosterone levels.

#### Study Descriptions

Three RCTs - one with a cross-over design - and 2 cohort studies reported the results for testosterone levels in healthy males as an outcome. ^77,^ ^85,^ ^150^ – ^152^ An additional study reported non-significant effect of soy in healthy male individuals but it did not provide specific results. ^88^ The 3 RCTs recruited a ramge between 15 and 96 participants in the soy arm. The cohort studies enrolled 19 and 15 men respectively. The duration of the studies ranged between 4 and 13.5 weeks. The studies were of poor quality (C) with generally limited applicability because of the small number of participants. Two studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. One study investigated isolated soy protein with isoflavone, one study used soy flour, one trial provided soy milk, another trial used tofu, and the last study provided pure soy isoflavones.

#### Overall Effect

Four out of the 5 studies found a decrease in the risk of prostate cancer as implied by the decrease in testosterone levels. However, this limited evidence showed no significant effect.

#### Soy Product, Dose, Other Variables

Given the small number of studies, it is difficult to make cross-study comparisons in regards to different types or doses of soy products investigated. No study directly compared different soy products.

#### Summary

Three randomized trial and 2 cohort studies of generally poor quality and limited applicability investigated the effect of soy protein or pure soy isoflavones on testosterone levels in healthy males. The limited evidence suggests a possible trend to lower risk for prostate cancer, with consumption of soy products by men. There is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

### 3.4.2. Follicle stimulating hormone (FSH)

(Tables 52–54)

Table 52 Effect of soy products on FSH (IU/L) in men

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Supplement | RCT | Casein
Teede 2001 | 12 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 96^a^ | 11.1 | +2.7 | NS | | -2 | | ♂ | | C ^a^
| | Casein | | | | | | | 9.2 | +4.7 | NS
Supplement | Cohort | No control
Mitchell 2001 | 8 wk | Isoflavones | | | | 40 | 0 | 15 | 4.44 | -0.04 | NS | | -- | | ♂ | | C
| | No control group | | | | | | --

a In contrast with other outcomes in this article, no data on how many men completed the study in each arm.

Table 53 Effect of soy products on FSH (IU/L) in pre-menopausal women

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Cohort | No Control
Cassidy 1994^a^ | ~4 wk | ISP w/Isoflavones | 20 | 25 | | | 60 | 6 | 7.8 | -6.8 | <0.01 | | -- | | pre♀ | | C
| | No control group
Cassidy 1995 (Study 4)^a^ | ~4 wk | ISP w/o Isoflavones | | | | | | 6 | 4.6 | 0 | NS | | -- | | pre♀ | | C
| | No control group
Cassidy 1995 (Study 3)^a^ | ~4 wk | ISP w/Isoflavones | | | | | | 5 | 4.9 | -0.7 | NS | | -- | | pre♀ | | C
| | No control group
Supplement | RCT | Placebo
Maskarinec 2002 | 48 wk | Isoflavones | | | | 74 | 0 | 17 | 3.2 | +0.6 | | | -0.82 | NS | pre♀ | | B
| | Maltodextrin | | | | | | 17 | 4.1 | +1.3
Supplement | Xover | No Control
Duncan 1999 9920082 | 13.5 wk | ISP w/Isoflavones | | | | 128 | | 14 | nd | 4.32 ^b^ | | NS | -- | | pre♀ | | C
| | ISP w/Isoflavones | | | | 64 | | | | 4.31 ^b^ | | | --
| | No control group | | | | | | --
Supplement | Cohort | No Control
Lu 2001 | ~4 wk | Soy milk w/o Isoflavones | | | | | 37.9 | 9 | 2.7 | -0.2 | NS | | -- | | pre♀ | | C
| | No control group | | | | | | --

a In the paper of Cassidy 1995, 4 cohort studies are included (S1–S4): the first has also been published as Cassidy 1994 (also reported in the table); the 2nd has been excluded because of inadequate sample size (< 5 women); the 3rd and 4th are reported in the table as Cassidy 1995 (Study 3) and Cassidy 1995 (Study 4) respectively

b Only final values are reported in the paper

Table 54 Effect of soy products on FSH (IU/L) in post-menopausal women

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | SProtein
Diet | Xover | Dairy
Cuevas 2003 | 8 wk | ISP w/Isoflavones | 48 | 24 | 8 | 80 | <40 | 18 | 56.5 | +2.1 | NS | | -1.8 | NS | post♀ | | B
| | Caseinate | | | | | | | | +3.9 | NS
Diet | RCT | Animal/Usual
Baird 1995 | 4 wk | ISP w/Isoflavones | | | | 165 | 38 | 66 | 61.1 | -2.7 | | | -0.9 | NS | post♀ | | B
| | Usual diet | | | | | | 25 | 63.4 | -1.8
Chiechi 2003 | 24 wk | ISP w/Isoflavones | 27 | 19 | 1 | 47 | | 53 | 60.9 | +0.9 | | | +1.6 | NS | post♀ | | C
| | Usual diet | | | | | | 58 | 59.1 | -0.7
Diet | RCT | Miscellaneous
Murkies 1995 | 12 wk | Soy flour^a^ | | | | | | 23 | 84.52 | -1.35 | NS | | +6.74 | NS | post♀ | | B
| | Wheat flour | | | | | | 24 | 82.93 | -8.09 | <0.05
Diet | Cohort | No Control
Scheiber 2001 | 12 wk | Soy nuts & milk | | | | 60 | | 42 | 54.1 | -1.6 | NS | | | | post♀ | | C
| | No control group
Supplement | RCT | Casein
Persky 2002 | 24 wk | ISP w/Isoflavones | 39 | 26 | 7 | 72 | 40 | 22 | 43.7 | +0.3 | | nd | +0.9 | NS | post♀ | | B
| | ISP w/Isoflavones | 26 | 14 | 4 | 43 | 40 | 24 | 39.7 | -2.9 | | | -2.3 | NS
| | Casein | | | | | | 24 | 41.6 | -0.6
Teede 2001 | 13 wk | ISP w/Isoflavones | 77 | 38 | 5 | 118 | 40 | 83^b^ | 97.4 | +1.1 | NS | | +3.7 | | post♀ | | C ^b^
| | Casein | | | | | | | 112.7 | -2.6 | NS
Supplement | Xover | Placebo
Jayagopal 2002 | 12 wk | ISP w/Isoflavones | 70 | 49 | 13 | 132 | 30 | 32 | 48.7 | -4.1 | | | -2.8 | NS | post♀ DM | | B
| | Cellulose | | | | | | | 49.2 | -1.3
Nikander 2003 14602747 | 12 wk | Isoflavones | 7 | 41 | 66 | 114 | 0 | 28 | 79.9 | -0.4 | NS | | +0.6 | NS | post♀ Breast CA | | B
| | Placebo | | | | | | | 78.8 | -1 | NS
Supplement | RCT | Placebo
Upmalis 2000 | 12 wk | Isoflavones | 25 | 25 | | 50 | 0 | 59 | 76.2 | +9.1 | NS | | +2.1 | | post♀ | | C
| | Placebo | | | | | | 63 | 79.3 | +7 | NS
Han 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 90.3 | -23.3 | <0.01 | | -4.4 | NS | post♀ | I | A
| | Placebo | | | | | | 40 | 84.3 | -18.9 | NS
Petri 2004 | 26 wk | Soy germ capsules | | | | 60 | 0.8 | 25 | 76.8 | +0.9 | | | -6.4 | NS | post♀ | | B
| | Lactose | | | | | | 25 | 75.2 | +7.3
Uesugi 2003 | 13 wk | Isoflavones | 0 | 0 | 0 | 62^c^ | 0 | 11 | 56.5 | -0.7 | NS | | +11.9 | NS | post♀ | | B
| | Dextrin | | | | | | 10 | 73.5 | -12.6 | NS
Knight 2001 | 12 wk | Isoflavones | | | | 77 | 0 | 9 | 74.7 | -7.3 | | | +3.1 | NS | post♀ | | C
| | Placebo | | | | | | 11 | 74.3 | -10.4
Supplement | Xover | No Control
Duncan 1999 10522983 | 13.5 wk | ISP w/Isoflavones | 77 | 44 | 12 | 132 | 63 | 18 | 56.2 | -2 | NS | nd | -- | | post♀ | | C
| | ISP w/Isoflavones | 38 | 22 | 6 | 65 | 63 | | | -3.6 | 0.01 | | --
| | No control group | | | | | | --
Supplement | Cohort | No Control
Foth 2003 | 24 wk | ISP w/Isoflavones | 20 | | | | 20 | 16 | 70.94 | +1.53 | NS | | -- | | post♀ | | C
| | No control group | | | | | | --

a Soy flour = 45g/d; no other soy ingredient is quantified

b In contrast with other outcomes in this article, no data on how many women completed the study in each arm.

c 31 mg daidzin, 7mg genistin, 21 mg glycitin

The National Guideline Clearinghouse has published guidelines that recommend FSH should be measured in males and females as part of the initial evaluation for infertility (www.guideline.gov/summary/summary.aspx?doc_id=2924; www.guideline.gov/summary/summary.aspx?doc_id=4742&nbr=3435). Marked elevation of serum FSH in men is clearly indicative of an abnormality in spermatogenesis. A beneficial effect of soy on male infertility is expected to decrease FSH levels. Among women, FSH levels greater than 10 mlU/mL are associated with an extremely low pregnancy rate. A beneficial effect of soy on female infertility is expected to decrease FSH levels. FSH in pre-menopausal women is evaluated during the follicular phase of the menstrual cycle. Although FSH level in post-menopausal women generally is not considered of clinical importance, this report also includes the results of studies on post-menopausal women.

#### Study Descriptions

One RCT and 1 cohort study reported FSH as an outcome in men (Table 52). ^77,^ ^152^ The soy arm in the RCT included 55 men and the cohort study recruited 15 men. The RCT lasted for 12 weeks while the cohort study lasted for 8 weeks. The studies were of poor quality (C) with generally limited applicability because of the small number of participants. Both studies supplemented diets with soy products. One study investigated isolated soy protein with isoflavone, and the other study provided pure soy isoflavones.

Two RCTs including 1 with a cross-over design, and 4 cohort studies (the 3 of them by a single set of researchers were published in 2 articles) reported FSH levels during the follicular phase of the menstrual cycle in pre-menopausal women as an outcome (Table 53). ^153^ – ^157^ The RCTs had 14 and 17 participants in the soy arm while the 4 cohorts reported a sample size of 5 to 9 participants. The duration of the RCTs was 13.5 to 48 weeks. Three of the cohort studies lasted for 2 menstrual cycles while the fourth for 1 menstrual cycle. The studies were generally of poor quality (1 B score, 5 C) with generally limited applicability because of the small number of participants. Three studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. Three of the cohort studies and one of the RCTs investigated isolated soy protein with isoflavone, the fourth cohort used isoflavone-free soy milk while the other RCT provided pure soy isoflavones.

Fourteen RCTs including 4 with cross-over design and 2 cohort studies reported FSH levels in post-menopausal women as an outcome (Table 54). ^47,^ ^66,^ ^76,^ ^77,^ ^84,^ ^91,^ ^93,^ ^97,^ ^123,^ ^128,^ ^136,^ ^158^ – ^162^ The RCTs recruited 9 to 66 participants in the soy arm while the cohort studies reported sample sizes of 42 and 16 participants. The duration of the RCTs ranged between 4 and 24 weeks. The cohort studies lasted 12 and 24 weeks. The studies were of poor to moderate quality (1 A, 9 B, 6 C) with generally limited applicability to post-menopausal women. Six studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. Eight studies investigated isolated soy protein with isoflavone, one study used soy nuts and milk, one study provided soy flour, and another soy germ capsules. The remaining 5 studies investigated pure soy isoflavones.

#### Overall Effect

Teede 2001, in the only RCT of effect on FSH in men (Table 52), reported a increase. ^77^ Mitchell 2001, in the cohort study, noted a very small decrease. ^152^ None of the effects were statistically significant.

Among pre-menopausal women (Table 53), the only trial with a non-soy control (Maskarinec 2002 ^155^ ) found a non-significant relative decrease with soy (although FSH rose in both arms of the study). Only the 1994 cohort study by Cassidy ^153^ reported a significant (and large) decrease in FSH. Duncan 1999 ^156^ found no difference in effect between 2 different formulations of soy product with different isoflavone contents. There was one more trial, which reported that daily consumption of soy milk had no effect on FSH levels without providing any specific results. ^163^

None of the trials among post-menopausal women (Table 54) found a significant difference in effect on FSH between soy and non-soy interventions, or between different soy interventions. There was a wide range of net effects, between -6.4 and +11.9 IU/L.

There were 6 more trials in 5 publications ^46,^ ^81,^ ^98,^ ^163,^ ^164^ that reported FSH level as outcome without providing with specific results. No significant effect is shown in any of these studies.

#### Soy Product, Dose, Other Variables

For men and pre-menopausal women, given the small number of studies, it is difficult to make cross-study comparisons in regards to different types or doses of soy products investigated. Only Duncan 1999, ^156^ in pre-menopausal women (Table 53), directly compared different soy products. Two isolated soy protein products, one providing 128 mg per day and one 64 mg per day isoflavones, were compared to each other. No significant change was reported between the 2 arms.

For post-menopausal women (Table 54), the only statistically significant decrease in FSH was reported within the soy arm by Han 2002 ^91^ in a study of pure isoflavones. This decrease was not significant when compared to the controls. However, no other study with a similar or higher amount of pure soy isoflavones found any significant effect.

Persky 2002 ^160^ (Table 54) and Duncan 1999 ^161^ (Table 53) directly compared different isoflavone doses among post-menopausal women. For Persky 2002, ^160^ 2 isolated soy protein products, one providing 72 mg per day and one 43 mg per day isoflavones, were compared to milk protein. The higher isoflavone dose resulted in a non-significant increase in FSH level while the lower dose resulted in non-significant decrease. In Duncan 1999, ^161^ 2 isolated soy protein products, one providing 132 mg per day and one 65 mg per day isoflavones, were compared to each other. The soy product with lower isoflavones resulted in a statistically significant decrease but the soy product with higher isoflavones did not. However, none of the 2 trials provided information whether the differences between the 2 soy products were significant.

#### Summary

One RCT and one cohort study, both of poor quality and limited applicability, investigated the effect of isolated soy protein or pure soy isoflavones on FSH levels among males. Overall, evidence is conflicting on the effect on FSH of soy product consumption by men. Additionally, there is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

Two RCTs and 4 cohort studies of generally poor quality and limited applicability investigated the effect of isolated soy protein or pure soy isoflavones on FSH levels among pre-menopausal women. Overall, evidence is conflicting on the effect on FSH of soy product consumption by pre-menopausal women. Additionally, there is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

Fourteen RCTs and 2 cohort studies of generally poor to moderate quality and limited applicability investigated the effect of isolated soy protein or pure soy isoflavones on FSH levels among post-menopausal women. Overall, evidence is conflicting on the effect on FSH levels of soy consumption by post-menopausal women. Additionally, there is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

### 3.4.3. Estradiol (E2)

(Tables 55–56)

Table 55 Effect of soy products on estradiol (pg/mL) in pre-menopausal women

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | Animal/Usual
Maskarinec 2004 | ~104 wk | ISP w/Isoflavones ^a^ | | | | 50 | | 100/91 | 150 | +2 | NS | | +16 | NS | pre♀ | | C
| | Usual diet | | | | | | 105/96 | 136 | -14 | NS
Diet | Cohort | No control
Cassidy 1994 ^b^ | ~4 wk | ISP w/Isoflavones | 20 | 25 | | 40 | 60 | 6 | 66.96 | +31.64 | <0.02 | | -- | | pre♀ | | C
| | No control group | | | | | | --
Cassidy 1995 (Study 4) ^b^ | ~4 wk | ISP w/o Isoflavones | | | | | | 6 | 81.7 | -11 | NS | | -- | | pre♀ | | C
| | No control group | | | | | | --
Cassidy 1995 (Study 3) ^b^ | ~4 wk | ISP w/Isoflavones | | | | | | 5 | 114.4 | -30 | NS | | -- | | pre♀ | | C
| | No control group | | | | | | --
Supplement | RCT | Animal/Usual
Nagata 1998 | ~12 wk | Soy milk | | | | 109 | | 31 | 87.5 | -23.9 | NS | | -20.5 | NS | pre♀ | | C
| | Usual diet | | | | | | 29 | 86.8 | +3.4 | NS
Supplement | RCT | Placebo
Kumar 2002 | 12 wk | Isoflavones | | | | 40 | 0 | 33 | 44.58 | +2.68 | NS | | -1.98 | NS | pre♀ | | C
| | Placebo | | | | | | 33 | 47.39 | +4.64 | NS
Maskarinec 2002 | 48 wk | Isoflavones | | | | 74 | 0 | 17 | 147 | -28 | | | -7 | NS | pre♀ | | B
| | Maltodextrin | | | | | | 17 | 136 | -21
Stroescu 2001 | 16 wk | ISP^c^ | | | | | | 7 | nd | -18.3 | <0.01 | | -7 | NS | pre♀ ^d^ | | C
| | Placebo | | | | | | 7 | nd | -17.4 | <0.01
Supplement | Xover | No control
Watanabe 2000 | 4 wk | Isoflavones | 2 | 17 | 10 | 40 | 0 | 19 | nd | ~20 | NS | nd | | | pre♀ | | C
| | Isoflavones | 1 | 9 | 5 | 20 | 0 | | | ~25 | NS
| | No control group
Duncan 1999 9920082 | 13.5 wk | ISP w/Isoflavones | | | | 128 | | 14 | nd | 43.24 ^ e ^ | | NS | -- | | pre♀ | | C
| | ISP w/Isoflavones | | | | 64 | | | | 44.9 ^ e ^ | | | --
| | No control group | | | | | | --
Supplement | Cohort | No control
Petrakis 1996 | 4 wk | ISP w/Isoflavones | 38 | | | | 38 | 14 | 81.2^f^ | +8.6 | NS | | -- | | pre♀ | | C
| | No control group | | | | | | --
Lu 2001 | ~4 wk | Soy milk w/o Isoflavones | | | | | 37.9 | 9 | 107 | 0 | NS | | -- | | pre♀ | | C
| | No control group | | | | | | --

a In Maskarinec 2004, 2 servings of soy per day were provided; the size of one serving was calculated to supply ~25 mg of isoflavones; soy foods that were used for the intervention included: tofu, soymilk, roasted soy nuts, soy protein powder, and soy bars. The amount of soy protein per serving ranged from 4.7–21.9 g; no data on the daily amount of soy protein consumption are given

b In the paper of Cassidy 1995, 4 cohort studies are included (S1–S4): the first has also been published as Cassidy 1994 (also reported in the table); the 2nd has been excluded because of inadequate sample size (< 5 women); the 3rd and 4th are reported in the table as Cassidy 1995 (S3) and Cassidy 1995 (S4) respectively

c 1g soy protein /kg body weight twice a day

d This study recruited 14 Romanian female gymnasts of the Olympic team with primary amenorrhea

e Only final values are reported in the paper

f No data on when the E2 measurements were performed regarding the menstrual cycle phase

Table 56 Effect of soy products on estradiol (pg/mL) in post-menopausal women

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | RCT | Dairy
Arjmandi 2003 | 12 wk | ISP w/Isoflavones | | | | 88 | 40 | 20 | 51.5 | +15.1 | NS | | +4.9 | NS | post♀ mixed^a^ | | C
| | Milk protein | | | | | | 22 | 84.8 | +10.2 | NS
| | ISP w/Isoflavones | | | | 88 | 40 | 20 | 93.4 | +23.5 | NS | | -11.96 | NS | post♀ on HRT
| | Milk protein | | | | | | 22 | 122.84 | +35.46 | NS
| | ISP w/Isoflavones | | | | 88 | 40 | 20 | 35.6 | +26.1 | NS | | -21.2 | NS | post♀ w/o HRT
| | Milk protein | | | | | | 22 | 45.9 | +47.3 | NS
Diet | RCT | Animal/Usual
Chiechi 2003 | 24 wk | ISP diet | 27 | 19 | 1 | 47 | | 53 | 10.1 | -3.9 | | | -6 | NS | post♀ | | C
| | Usual diet | | | | | | 58 | 13.6 | +2.1
Diet | RCT | Miscellaneous
Brooks 2004 | 16 wk | Soy flour | 26 | 16 | 1 | 42 | | 15 | 10.60 | +9.67 | | | +14.64 | NS | post♀ | | B
| | Wheat flour | | | | | | 15 | 20.11 | -4.97
Diet | Cohort | No control
Scheiber 2001 | 12 wk | Soy nuts /Soy milk | | | | 60 | | 42 | 17.4 | +1.5 | NS | | -- | | post♀ | | C
| | No control | | | | | | --
Supplement | RCT | Casein
Persky 2002 | 24 wk | ISP w/Isoflavones | 26 | 14 | 4 | 43 | 40 | 24 | 4.8 | +1.9 | NS | nd | +2.7 | NS | post♀ | | B
| | ISP w/Isoflavones | 39 | 26 | 7 | 72 | 40 | 22 | 2.6 | +0.3 | NS | | +1.1 | NS
| | Casein | | | | | | 24 | 4.3 | -0.8 | NS
Supplement | Xover | Placebo
Nikander 2003 14602747 | 12 wk | Isoflavones | 7 | 41 | 66 | 114 | 0 | 28 | 38.1 | -0.5 | NS | | -4.3 | NS | post♀ Breast CA | | B
| | Placebo | | | | | | | 34.6 | +3.8 | NS
Supplement | RCT | Placebo
Han 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 9 | +10 | <0.01 | | +8.7 | <0.01 | post♀ | | A
| | Placebo | | | | | | 40 | 9.6 | +1.3 | NS
Morabito 2002 | 48 wk | Genistein | 54 | | | 54 | 0 | 30 | 19.9 | +1.1 | | | +2.2 | NS | post♀ | | B
| | Placebo | | | | | | 30 | 21 | -1.1
Squadrito 2003 | 52 wk | Genistein | 54 | | | | 0 | 27 | 19.6 | +0.6 | | | +0.4 | NS | post♀ | | B
| | Placebo | | | | | | 26 | 19.1 | +0.2
Petri 2004 | 26 wk | Soy germ capsules | | | | 60 | 0.8 | 25 | 15.8 | +1.9 | | | +4.2 | NS | post♀ | | B
| | Lactose capsules | | | | | | 25 | 14.6 | -2.3
Supplement | Xover | No Control
Duncan 1999 10522983 | 13.5 wk | ISP w/Isoflavones | 77 | 44 | 12 | 132 | 63 | 18 | 9.7 | -0.2 | <0.05 | nd | -- | | post♀ | | C
| | ISP w/Isoflavones | 38 | 22 | 6 | 65 | 63 | | | -1.6 | <0.05 | | --
| | No control group | | | | | | --
Supplement | Cohort | No Control
Hsu 2001 | 24 wk | Isoflavones | | | | 150 | 0 | 37 | 9.6 | +11.8 | NS | | -- | | post♀ | | C
| | No control group | | | | | | --
Foth 2003 | 24 wk | ISP w/Isoflavones | 20 | | | | 20 | 16 | 32.3 | -4.9 | NS | | -- | | post♀ | | C
| | No control group | | | | | | --
Petrakis 1996 | 4 wk | ISP w/Isoflavones | 38 | | | | 38 | 10 | 53.3 | -0.5 | NS | | -- | | post♀ | | C
| | No control group | | | | | | --

Breast CA = history of breast cancer; HRT = hormone replacement therapy

a The authors report in the abstract that 22 women were on hormone therapy and 20 were not on hormone therapy. They provide incorrect numbers of subjects in their sub-analyses results tables

The National Guideline Clearinghouse has included guidelines that recommend E2 should be measured in females as part of the evaluation for basic infertility, especially in women older than 35 years (www.guideline.gov/summary/summary.aspx?doc_id=5567&nbr=3764). E2 in pre-menopausal women is evaluated during the follicular phase of the menstrual cycle. Although E2 level in post-menopausal women generally is not considered of clinical importance, this report also includes the results of studies on post-menopausal women.

#### Study Descriptions

Six RCTs including 2 with a cross-over design, 1 non-randomized controlled trial, and 5 cohort studies reported E2 levels in healthy pre-menopausal women as an outcome (Table 55). ^48,^ ^153^ – ^157,^ ^165^ – ^169^ All studies reported E2 levels during the follicular phase of the menstrual cycle except for Maskarinec 2004, ^165^ which measured E2 levels 5 days after ovulation and Petrakis 1996, ^169^ which reported variability during menstrual cycles that E2 samples were collected. The largest RCT assigned 109 women in the intervention arm. None of the other RCTs had more than 33 participants in the soy arm. The non-randomized controlled trial recruited 19 pre-menopausal women in the soy arm. The other 4 cohort studies reported a sample size of 5 to 14 participants. The duration of the RCTs ranged between 12 and 48 weeks. The non-randomized trial had duration of 4 weeks as well as the cohort studies that stated a trial duration of 1 menstrual cycle each. The studies were generally of poor quality (1 B score, 11 C) with limited applicability because of the small number of participants. Four studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. Seven studies investigated isolated soy protein with isoflavone, one study used only isolated soy protein, another trial used isoflavone-free soy milk, and 3 studies investigated pure soy isoflavones.

Ten RCTs including 2 with cross-over design and 4 cohort studies reported E2 levels in healthy post-menopausal women as an outcome (Table 56). ^91,^ ^93,^ ^123,^ ^125,^ ^128,^ ^159^ – ^162,^ ^169^ – ^173^ The RCTs recruited 11 to 53 participants in the soy arm while the cohort studies reported a sample size of 10 to 37 participants. The duration of the RCTs ranged between 12 and 52 weeks. The cohort studies lasted 4 to 24 weeks. The studies were of generally poor to moderate quality (1 A score, 6 B, 7 C) with generally limited to moderate applicability to post-menopausal women. Six studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. Five studies investigated isolated soy protein with isoflavone while 1 study reported isolated soy diet; there was 1 study that used soy nuts and milk, another study provided soy flour, and another soy germ capsules. The remaining 5 studies investigated pure soy isoflavones, 2 of which only genistein.

#### Overall Effect

Among studies with pre-menopausal women (Table 55), Stroescu 2001, in an RCT that recruited 14 female gymnasts with primary amenorrhea from the Olympic team in Romania, reported a significant decrease in E2 levels within each group. ^168^ Among the cohort studies, only Cassidy 1994 ^153^ reported a significant increase in E2 level. No other significant effect on E2 levels was found in the trials. There was one more trial, which reported that daily consumption of soy milk reduced circulating levels of estradiol by 25% (P<0.01) compared with levels during the home diet period but it doesn't report specific results. ^163^

Among trials with post-menopausal women (Table 56), 2 RCTs reported a significant effect on E2 level in the soy arm; however, Han 2002 ^91^ reported an increase and Duncan 1999 ^161^ reported a decrease. Han 2002 ^91^ also reported a significantly higher increase in E2 level in the soy arm compared with the controls. No other study showed any significant effects on E2 levels.

There were an additional 7 studies that reported E2 as an outcome without reporting specific results. ^81,^ ^163,^ ^164,^ ^174^ – ^177^ Only 1 cohort study on 6 healthy pre-menopausal women reported a statistically significant decrease in E2 levels after consuming soymilk for 1 month. ^175^

#### Soy Product, Dose, Other Variables

For pre-menopausal women, given the small number of studies, it is difficult to make cross-study comparisons in regards to different types or doses of soy products investigated.

Two studies directly compared different isoflavone doses in pre-menopausal women (Table 55). Watanabe 2000 ^48^ investigated 2 pure isoflavone products, one providing 40 mg per day and another 20 mg per day isoflavones. Both resulted in small non-significant decreases of E2 level. However, the trial did not provide information as to whether the difference between the 2 soy products was significant. Duncan 1999 ^156^ compared 2 isolated soy protein products, one providing 128 mg per day and one 64 mg per day isoflavones. No significant change was reported between the 2 arms.

For post-menopausal women (Table 56), the only statistically significant increase in E2 was reported by Han 2002 ^91^ in a study of pure isoflavones. However, no other study with a similar or higher amount of pure soy isoflavones found any significant effect. A small study, Duncan 1999, ^48,^ ^161^ reported the only significant decrease in E2 level after providing isolated soy protein with isoflavones in post-menopausal women. This result was not confirmed by any of the other studies that also investigated isolated soy protein with isoflavones.

Persky 2002 ^160^ (Table 56) and Duncan 1999 ^161^ (Table 55) directly compared different isoflavone doses in post-menopausal women. For Persky 2002 ^160^ 2 isolated soy protein products, one providing 72 mg per day and one 43 mg per day isoflavones, were compared to milk protein. Both doses resulted in a small non-significant increase in E2 levels. For Duncan 1999, ^161^ two isolated soy protein products, one providing 132 mg per day and one 65 mg per day isoflavones, were compared to each other. As noted above, both resulted in significant decreases in E2 levels. However, neither of the 2 trials provided information whether the differences between the 2 soy products were significant.

Arjmandi 2003 ^170^ (Table 56) performed separate sub-analyses of post-menopausal women who were receiving hormone therapy and those who were not on hormone therapy. A non-significant increase was found among women in both groups.

#### Summary

Six RCTs, 1 non-randomized controlled trial, and 5 cohort studies of generally poor quality and limited applicability investigated the effect of isolated soy protein or pure soy isoflavones on E2 levels among pre-menopausal women. Overall, evidence is conflicting on the effect on E2 levels of soy product consumption by pre-menopausal women. Additionally, there is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

Ten RCTs and 4 cohort studies of generally poor to moderate quality and limited to moderate applicability investigated the effect of isolated soy protein or pure soy isoflavones on E2 levels among post-menopausal women. Overall, evidence is conflicting on the effect on E2 level of soy consumption by post-menopausal women. Additionally, there is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

### 3.4.4. Menstrual Cycle Length

(Table 57)

Table 57 Effects of soy products on menstrual cycle length (days)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Martini, 1999 | 2 mo | ISP w/Isoflavones | 23 | 13 | | 38 | 20 | 16 | nd | 29.3 ^a^ | | | +0.1 | NS | pre♀ No OC | | C
| | Skim milk | | | | | | | nd | 29.2 ^a^
| | ISP w/Isoflavones | 23 | 13 | | 38 | 20 | 20 | nd | 28.1 ^a^ | | | +0.2 | NS | pre♀ OC
| | Skim milk | | | | | | | nd. | 27.9 ^a^
Diet | RCT | Animal/Usual
Nagata, 1998 | 2 mo | Soy milk | 2.86 | 2.86 | | 97 | | 31 | nd | 30.7 ^a^ | | | 0 | | pre♀ | | C
| | Usual diet | | | | | | 29 | nd | 30.7 ^a^
Diet | NRCT | Animal/Usual
Cassidy, 1994; Cassidy, 1995 (Study 1) | 1 mo | Soy diet | 20 ^c^ | 25 ^c^ | | 45 ^c^ | 60 | 6 | 28.5 | +0.5 | | | +1.5 | NS | pre♀ | | C
| | Control diet | | | | | | | | -1.0
Cassidy, 1995 (Study 4) | 1 mo | Soy diet | | | | 23 ^c^ | 28 | 6 | 32.0 | +2.0 | | | +1.0 | NS | pre♀ | | C
| | Control diet | | | | | | | | +1.0
Diet | NRCT | No Control
Lu, 2000 | 1 mo | Soy milk | 85.2 | 68.8 | | 154 | 37.9 | 10 | 26.6 | -0.6 | | | -- | | pre♀ | | C
| | No control
Lu, 1996 | 1 mo | Soy milk | ~100 ^b^ | ~100^b^ | | | nd | 6 | 28.3 | +3.5 | NS | | -- | | pre♀ | | C
| | No control
Wu, 2000 | 3 mo | Soy diet | | | | 32 ^c^ | nd | 20 | 29.2 | +0.1 | NS | | -- | | pre♀ | | C
| | No control
Supplement | RCT | Dairy
Kumar, 2002 | 12 wk | ISP w/Isoflavones | 40 | | | | nd | 33 | 26.3 | +3.52 | | | +3.6 | 0.04 | pre♀ | | C
| | Milk protein | | | | | | 33 | 27.8 | -0.06
Supplement | RCT | Animal/Usual
Brown, 2002 | 11 mo | ISP w/Isoflavones | 26 | 11 | 3 | 40 | 31 | 14 | nd | 31 ^a^ | | | +1.8 | NS | pre♀ | | C
| | Usual diet | | | | | | | nd | 29.2 ^a^
Supplement | RCT | Placebo
Maskarinec, 2002 | 12 mo | Isoflavones | | | | 76 | 0 | 14 | 29.1 | --1.4 | | | -1.5 | NS | pre♀ | | B
| | Placebo | | | | | | 14 | 27.4 | +0.1
Supplement | Xover | No Control
Duncan, 1999 9920082 | 3 mo | ISP w/Isoflavones | 70 | 47 | 10 | 128 | 53 | 14 | 29.7 | -0.4 | nd | NS | -- | | pre♀ | | B
| | ISP w/Isoflavones | 35 | 24 | 5 | 64 | 53 | | | -0.5 | | NS | --
| | ISP w/o Isoflavones | 5 | 4 | 1 | 10 | 53 | | | -0.8 | | NS | --
| | No control

OC = oral contraceptives

a Final values

b 15–19% of total isoflavones were aglycones

c Glucosides form of isoflavones

#### Study Descriptions

A total of 11 trials in 10 publications examined the effects of soy and/or its isoflavones on menstrual cycle length in pre-menopausal women. ^153^ – ^156,^ ^163,^ ^166,^ ^167,^ ^174^ – ^177^ The wide range of soy interventions and comparisons used in these trials makes synthesis of the data difficult; few studies were identified for each comparison category. Most of these trials are of quality C. Regardless of the large heterogeneity across the studies, 10 of the 11 trials did not show significant changes in menstrual cycle length after treatments of soy and/or its isoflavones. Only 1 RCT (Kumar 2002) showed that pre-menopausal women who took supplements of soy protein with isoflavones for 12 weeks had a significant net increase in their menstrual cycle lengths, compared with those who took the placebo (isocaloric milk protein). ^167^ One study by Duncan 1999 compared isolated soy protein with different doses of isoflavones and found no dose effect. ^156^

### Summary

No effect was observed in the studies of soy on menstrual cycle length.

### 3.4.5. Thyroid stimulating hormone (TSH)

(Table 58)

Table 58 Effect of soy products on TSH (mIU/L)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T Isoflav | Soy Protein
Diet | Xover | Dairy
Ham 1993 | 4 wk | Soy flour | | | | | 50 | 17 | 1.8 | -0.6 | NS | nd | +0.3 | | ♂ | | C
| | ISP w/Isoflavones + cotyledon | | | | | 50 | | 1.8 | -0.6 | NS | | +0.3
| | ISP w/Isoflavones + cellulose | | | | | 50 | | 1.8 | -0.7 | NS | | +0.4
| | Nonfat dry milk+cellulose | | | | | | | 1.8 | -0.3 | NS
Supplement | RCT | Casein
Persky 2002 | 24 wk | ISP w/Isoflavones | 39 | 26 | 7 | 72 | 40 | 22 | 2.04 | 0.18 | | nd | +0.43 | 0.01 | post♀ | | B
| | ISP w/Isoflavones | 26 | 14 | 4 | 43 | 40 | 24 | 2.22 | -0.17 | | | +0.08 | NS
| | Casein | | | | | | 24 | 2.25 | -0.25
Supplement | Xover | No Control
Duncan 1999 10522983 | 13.5 wk | ISP w/Isoflavones | 77 | 44 | 12 | 132 | 63 | 18 | 3.48 | +0.01 | NS | NS | +0.24 | | post♀ | | C
| | ISP w/Isoflavones | 38 | 22 | 6 | 65 | 63 | | | -0.15 | NS | | +0.08
| | No control | | | | | | | | -0.23 | NS
Duncan 1999 9920082 | 13.5 wk | ISP w/Isoflavones | | | | 128 | | 14 | nd | 1.41 ^ a ^ | | NS | -- | | pre♀ | | C
| | ISP w/Isoflavones | | | | 64 | | | | 1.52 ^ a ^ | | | --
| | No control group | | | | | | --
Supplement | Xover | Placebo
Jayagopal 2002 | 12 wk | ISP w/Isoflavones | 70 | 49 | 13 | 132 | 30 | 32 | 2.15 | +0.12 | | | +0.04 | NS | post♀ | | B
| | Cellulose | | | | | | | 2.18 | +0.08
Supplement | RCT | Placebo
Bruce 2003 | 24 wk | Isoflavones | | | | 90^b^ | 0 | 21 | 3 | +0.49 | NS | | +0.21 | | post♀ | | C
| | Maltodextrin | | | | | | 21 | 3.35 | +0.28 | NS

a Only final values are reported in the paper

b The glycosides genistin, daidzin, and glycitin are in the ratio of 1.3:1.0:0.3. No data on amount of aglycones.

TSH is clinically important as an indicator for thyroid function. TSH is increased in secondary hypothyroidism and is considered a valuable marker for its diagnosis. Previous reports have discussed soy-induced hypothyroidism as an adverse event of soy consumption. This report focused on studies that included TSH as an outcome to explore available evidence and investigate whether hypotheses on soy induced hypothyroidism could be confirmed.

#### Study Descriptions

Six RCTs including 4 with cross-over design reported TSH levels in healthy subjects as an outcome. ^84,^ ^156,^ ^160,^ ^161,^ ^178,^ ^179^ Four trials included only post-menopausal women, 1 trial recruited pre-menopausal women, and 1 study recruited males. No study had more than 32 participants in the soy arm. The duration of the studies ranged between 4 and 24 weeks. The studies were of poor to moderate quality (2 B, 4 C) with generally limited applicability to post-menopausal women. Two studies incorporated the soy products into the diet; the remaining supplemented diets with soy products. Five studies investigated isolated soy protein with isoflavones, one of which administered the soy protein with cotyledon in one arm and with cellulose in the other arm, and also had an additional arm of soy flour. The last study provided pure soy isoflavones.

#### Overall Effect

Only Persky 2002 ^160^ reported a statistically significant increase for TSH level in post-menopausal women. Although there was a trend for TSH increase in most trials with post-menopausal women, this result was not consistent for all soy arms. Ham 1993, ^178^ the only study that evaluated TSH level in men, reported a non-significant decrease for all the soy arms.

There were 2 additional studies both reported in single publication that described non-significant effects of soy in healthy post-menopausal women and male individuals but they did not provide specific results. ^88^

#### Soy Product, Dose, Other Variables

Only Persky 2002 ^160^ in a 24-week duration study reported a statistically significant increase for TSH level in the soy arm with the higher isoflavone intake compared to the casein control group. However, no significant increase was observed in other trials with even higher isoflavone intake but over a shorter duration. Only in Bruce 2003, ^179^ a 24-week duration study, did subjects consume approximately the same amount of isoflavones as in Persky 2002 ^160^ but without soy protein. This trial found no significant effect, as well.

Ham 1993 ^178^ directly compared different soy products. Soy flour and isolated soy protein with isoflavones were compared to milk protein and cellulose. All arms resulted in small non-significant decrease in TSH levels. Persky 2002 ^160^ and 2 studies by Duncan in 1999 (in post-menopausal women ^161^ and in pre-menopausal women ^156^ ) directly compared different isoflavone doses. For Persky 2002 ^160^ 2 isolated soy protein products, one providing 72 mg per day and one 43 mg per day isoflavones, were compared to milk protein. The soy product with higher isoflavones resulted in a statistically significant increase while the soy product with lower isoflavones did not. For Duncan 1999 on post-menopausal women, ^161^ 2 isolated soy protein products, one providing 132 mg per day and one 65 mg per day isoflavones, were compared to each other. The soy product with higher isoflavones resulted in an increase of TSH levels while the soy product with lower isoflavones decreased TSH. Both changes were not significant. For Duncan 1999 on pre-menopausal women, ^156^ 2 isolated soy protein products, one providing 128 mg per day and one 64 mg per day isoflavones, were compared to each other. No significant change was reported between the 2 arms.

#### Summary

Six randomized trials of generally poor to moderate quality and limited applicability investigated the effect of isolated soy protein or pure soy isoflavones on thyroid function. Overall, limited evidence suggests a possible small increase in TSH level with consumption of soy products by post-menopausal women. However, the only trial with men reported a decrease in TSH level with soy consumption. These differences were small and it is unlikely whether they could have a clinical effect on thyroid function. There is insufficient evidence regarding different types or doses of soy products to compare their relative effectiveness.

## 3.5. Cancer and Tumor-Related Biomarkers

(Table 59)

Table 59 Summary of tumor-related biomarker trials

Author year | Soy product | Study Design | Population | Target tissue | # subjects analyzed in soy arm(s) | Outcomes | Mechanism
Adams 2003 | Isolated soy protein w/isoflavone | RCT | healthy adults with adenomatous colorectal polyps | colorectal | 150 | insulin-like growth factors (IGF), low IGF binding protein-3 (IGFBP-3) | estrogenic activity
Baird 1995 | Textured soy protein + isoflavone | RCT | healthy post-menopausal women | ND | 66 | vaginal cytology, LH, FSH, SHBG, estradiol | estrogenic activity
Bazzoli 2002 | Isolated soy protein w/isoflavone | RCT | healthy pre-menopausal women | breast | 9 | Lipid peroxides, urinary 8-hydroxy-2'-deoxyguanosine, total antioxidant status | antioxidant properties
Cassidy 1995 | Textured soy protein (+/-) isoflavone | 2 Non controlled clinical trials 1 randomized cross-over | healthy pre-menopausal women | breast | 6 | menstrual cycle length, urinary LH, serum gonadotrophins, progesterone, oestradiol, SHBG | anti-estrogenic activity
| | | | | 6
| | | | | 5
Davis 2001 | Soy isoflavone mixture | Non controlled clinical trial | healthy men | prostate | 6 | NF-kB in human lymphocytes, 5-OHmdU levels (endogenous status of cellular oxidative stress) | antioxidant properties
Djuric 2001 | Soy isoflavone | Non controlled clinical trial | healthy adults | ND | 12 | 5-OHmdU levels | antioxidant properties
Duncan 1999 9920082 | Isolated soy protein w/isoflavone | Randomized cross-over | healthy pre-menopausal women | breast | 14 | urinary estrogens and estrogen metabolites, serum estrogens, androgens, thyroid hormones, Prolactin, gonadotrophins, SHBG, Insulin, cortisol, menstrual cycle length, endometrial biopsy histological dating | anti-estrogenic activity
Gardner-Thorpe 2003 | other soy food (soy flour) | Randomized cross-over (double blind) | healthy non-smoking men | prostate | 20 | dihydrotestosterone (DHT), testosterone, oestradiol, estrone, sex hormone-binding globulin (SHBG), hydroperoxides, lag time copper, lag time myeloperoxidase | estrogenic activity, antioxidant properties
Habito 2000 | tofu | RCT | Healthy Caucausian adult males | prostate | 42 | dihydrotestosterone (DHT), testosterone, oestradiol, androstanediol glucuronide, sex hormone-binding globulin (SHBG), free androgen index, testosterone/estradiol | estrogenic activity
Hargreaves 1999 | Isolated soy protein w/isoflavone | Non controlled clinical trial | Pre-menopausal women with benign or malignant breast disease | breast | 84 | nipple aspirate apolipoprotein D levels, ps2 protein levels, epithelial cell proliferation, estrogen and progesterone receptor status, apoptosis, mitosis, Bcl-2 expression | estrogenic activity
Hsu 2001 | Soy isoflavone | Non controlled clinical trial | normal post-menopausal women | breast | 37 | plasma estradiol | estrogenic activity
Jenkins 2003 | Soy-based diet | Randomized cross-over | middle-aged men | prostate | 46 | serum PSA | estrogenic activity
Kumar 2002 | Isolated soy protein w/isoflavone | RCT (double blind) | healthy pre-menopausal women | breast | 66 | serum estrone, estradiol and SHBG, menstrual cycle length | anti-estrogenic activity
Lu 2001 | Soy-milk without isoflavones | Non controlled clinical trial | healthy pre-menopausal women | breast | 9 | serum ovarian hormones, gonadotropins | anti-estrogenic activity
Lu 2000 | Soy-milk | Non controlled clinical trial | healthy pre-menopausal women | breast | 10 | serum ovarian hormones, gonadotropins | anti-estrogenic activity
Lu 1996 | Soy-milk | Non controlled clinical trial | healthy pre-menopausal women | breast | 6 | serum 17b-estradiol, progesterone and DHEA, menstrual cycle length | anti-estrogenic activity
Luz 2000 | Soy-milk | Non controlled clinical trial | healthy pre-menopausal women | breast | 8 | urinary estrogen metabolites | anti-estrogenic activity
Maskarinec 2004 | Tofu Soy-milk Other soy food (roasted soy nuts, soy protein powder, soy bars) | RCT | Pre-menopausal women | breast | 109 | mammogram density assessment estradiol, estrone, progesterone, SHBG, androstenedione | anti-estrogenic activity
Maskarinec 2003 | Soy isoflavone | RCT | Pre-menopausal women | breast | 15 | mammogram density assessment | anti-estrogenic activity
McMichael-Phillips 1998 | Isolated soy protein w/isoflavone | RCT | Pre-menopausal women with benign or malignant breast disease | breast | 48 | epithelial cell proliferation, progesterone receptor status | estrogenic activity
Murkies 1995 | other soy food (soy flour) | RCT (double blind) | Post-menopausal women | ND | 28 | vaginal maturation index | estrogenic activity
Murray 2003 | Isolated soy protein w/isoflavone | RCT (double blind) | healthy post-menopausal women | endometrial | 16 (2 arms) | endometrial thickness | anti-estrogenic activity
Nagata 2001 | Soy milk | RCT | Healthy men | prostate | 17 | total testosterone, free testosterone, estrone, estradiol,SHBG | estrogenic activity
Petrakis 1996 | Isolated soy protein w/ isoflavone | Non controlled clinical trial | Healthy caucasian pre- and postmenopausal women (2 cohorts) | breast | 37 | Nipple aspirate fluid (NAF) volume; gross cystic disease fluid protein (GCDFP-15) concentration; NAF cytology; estradiol, progesterone, prolactin, SHBG | anti-estrogenic activity
Ross 1995 | tofu | Non controlled clinical trial | healthy adults | ND | 23 | platelet-derived growth factor (PDGF) | inhibition of protein tyrosine kinases
Scambia 2000 | Soy extract w/isoflavone | RCT (double blind) | Post-menopausal women | ND | 20 | endometrial thickness, vaginal maturation index | estrogenic activity
Xu 2000 | Isolated soy protein w/ isoflavone | Randomized cross-over | healthy post-menopausal women | breast | 18 | urinary estrogens and estrogen metabolites | anti-estrogenic activity

Twenty-five trials evaluated soy in participants without a diagnosis of cancer for risk factors or tumor markers related to the following types of cancer: breast (13 studies), ^154,^ ^156,^ ^157,^ ^163,^ ^165,^ ^167,^ ^169,^ ^173,^ ^175,^ ^180^ – ^183^ prostate (5), ^85,^ ^150,^ ^151,^ ^184,^ ^185^ endometrial (1), ^103^ and colon (1). ^186^ Five studies did not specify the type of cancer. ^46,^ ^66,^ ^158,^ ^187,^ ^188^ Two additional trials that enrolled women with benign or malignant breast disease also evaluated soy for risk factors or tumor markers related to breast cancer. ^189^ , ^190^ These 2 trials used small portions of normal breast tissue at least 1 cm from the site of the benign or malignant breast lesion. While we include these 2 studies, it is important to note that we did not systematically look for studies of patients with cancer (where soy products may have been used as cancer treatment). Furthermore, this report does not attempt to systematically review in vitro or animal studies. None of the included 27 trials reported the development of cancer as an outcome.

Most of the studies investigated the effect of soy isoflavones on (serum or urinary) estrogens and estrogen metabolites as well as on estrogenicity indicators (e.g. vaginal cell maturation, increased estrogen receptor expression, increased endogenous prolactin concentration and mammary gland proliferation). Additionally, they have included biomarkers outcomes that may be related to anti-estrogenic or estrogenic activity such as progesterone receptor expression, ovarian hormone levels, (serum or urinary) gonadotrophin levels, progesterone levels, sex hormone-binding globulin (SHBG) levels, menstrual cycle length, endometrial biopsy histological dating, endometrial thickness, dehydroepiandrosterone (DHEA), free androgen index and prostate specific antigen (PSA) levels; they also have measured as outcomes insulin, insulin-like growth factor (IGF), insulin-like growth factor binding protein-3 (IGFBP-3), cortisol and thyroid hormone levels.

However, according to the National Cancer Institute (NCI), none of these markers is considered a risk factor relevant to these types of cancer (www.nci.nih.gov/cancertopics). The primary purpose of all these trials was not to examine a possible effect of soy on cancer risk factors. Instead, they mainly aimed at correlating soy protein and/or its isoflavones with the estrogen pathway, which may explain several cancer risk factors such as earlier age at menses, later age at menopause, obesity, hormone therapy, etc. There were only 3 studies that reported testosterone levels (which is a potential risk factor for prostate cancer according to NCI) as an outcome. These studies are analyzed in the endocrine results section of this report (Table 51).

There were also cancer trials that aimed to correlate soy with other possible pathways of cancer prevention. Some trials investigated the antioxidant properties of soy through outcomes such as nuclear transcription factor NF-κB in human lymphocytes and 5-hydroxymethyl-2'-deoxyuridine (5-OHmdU) in DNA from nucleated blood cells, or 8-hydroxy-2'-deoxyguanosine (8-OHdG) in urine. Phosphatidylcholine hydroperoxide (PCOOH) and phosphatidyl-ethanolamine hydroperoxide (PEOOH) in red blood cells were also outcomes in these studies. Another trial examined the potential of protein kinase inhibition by soy having as an outcome the platelet-derived growth factor (PDGF) levels. Most of these cellular tumor markers are in the experimental stage of research and are not considered cancer risk factors. Since no causal relationship could be actually established between these outcomes and cancer, their results were not considered for further analysis.

Whether soy plays a beneficial role in preventing certain types of cancer cannot be clearly hypothesized. ^191^ For example, despite the strong biological rationale to support a protective effect for soy in relation to breast cancer, data from human observational studies are inconclusive. In addition to the inconsistencies in human observational studies, some laboratory evidence suggests that the isoflavones genistein and daidzein increase cell proliferation and promote the growth of estrogen-dependent mammary tumors. ^192^ – ^195^

Three trials have also raised concerns that isoflavones may exert estrogenic effects on breast tissue. Petrakis 1996 reported an increase in the presence of epithelial hyperplasia in nipple aspirate fluid from pre-menopausal and post-menopausal healthy women following a 6-month soy protein intervention. ^169^ Hargreaves 1999 and McMichael-Phillips 1998 reported changes in estrogen-regulated proteins in nipple aspirate fluid that were indicative of an estrogenic response among pre-menopausal women with benign or malignant breast disease following a 14-day soy protein intervention. ^189,^ ^190^ Stimulation of cell proliferation in breast tissue increases breast density, which is suggested as a potential biomarker of estrogenic or anti-estrogenic effects of a treatment on breast tissue. Breast density is assessed by mammography as a percentage of the breast occupied by dense tissue, or as the absolute area of dense tissue. It is not yet clear, however, whether one method of expressing breast density is preferable over the other. Using mammographic breast density as an intermediate risk marker for breast cancer risk, the reports by Maskarinec 2003 and 2004 showed no significant differences in mammographic breast density that could be attributed to soy intervention. ^165,^ ^182^ However, neither breast cell proliferation as indicated by epithelial hyperplasia nor mammographic breast density are established risk factors for breast cancer and no further inferences can be drawn from these studies.

## 3.6. Osteoporosis and Osteoporosis Risk Factors

(Tables 60–64)

Table 60 Summary of studies evaluating bone endpoints

Author, Year | BMD | BMC^a^ | Bone biomarkers
| | | Resorption | | | | Formation | | All other markers reported in the study
| | | HP | Pyr | D-pyr | NTx | OC | bAP
Alekel, 2000 | X ^b^ | X ^b^ | | | | X ^d^ | | X ^d^ | Urinary calcium
Anderson, 2002 | X | X
Arjmandi, 2003 | | | | | X | | | X | Urinary calcium, phosphorus and magnesium
Brooks, 2004 | | | | | X | | | X
Chen, 2004 | X | X
Chiechi, 2002 12191852 | X ^b^ | X ^b^ | X | X | | X | X
Dalais, 2003 | | | | X | X
Gallagher, 2004 | X ^b^ | | | | | X | X
Jones, 2003 | | | | X | | | | X
Katsuyama, 2004 | | | | | | X | X | X | Urinary calcium, bone stiffness
Khalil, 2002 | | | | | X ^e^ | | | X ^e^
Kreijkamp-Kaspers, 2004 | X | | | | | | | X | Plasma calcium and phosphorus
Lydeking Olsen, 2004 | X | X | | | | | | | Serum type I procollagen-N-terminal-peptide, collagen type I cross linked C-telopeptide
Mackey, 2000 | | | | | X | | X ^c^ | X ^c^
Morabito, 2002 | X | | | X | X | | X | X | Urinary and blood calcium
Murkies, 1995 | | | X | | | | | | Urinary calcium
Murray, 2003 | | | | | | X
Nikander, 2004 | | | | X | X | X | | X | Procollagen type I carboxy terminal propeptide, procollagen type I amino terminal propeptide
Potter, 1998 | X ^b^ | X ^b^
Scheiber, 2001 | | | | | | X | X | X
Uesugi, 2002 | | | | X | X | | X | | Bone stiffness
Uesugi, 2003 | X ^b^ | | | X | | | | | Urinary calcium
Upmalis, 2000 | | | | | | X | X
Wangen, 2000 | | | | | X | | X | X | Collagen type I cross linked C-telopeptide
Yamaguchi, 2001 | | | | | | | X | | Urinary calcium
Yamori, 2002 | | | | X | X | | | | Bone stiffness
Total numbers of studies | 10 | 6 | 2 | 8 | 10 | 8 | 10 | 12

BMD = bone mineral density; BMC = bone mineral contents; HP = urinary hydroxyproline; Pyr = urinary pyridinoline; D-pyr = urinary deoxypyridinoline; NTx = urinary collagen type I cross linked N-telopeptide; OC = serum osteocalcin; bAP = serum bone specific alkaline phosphatase

a BMC was not evaluated in this report.

b Studies that did not meet criteria for BMD analyses due to short duration (< 1 year intervention).

c Results were not summarized in the summary tables due to lack of baseline and final data reported. The authors stated that there were no significant changes in both OC and bAP markers after the intervention.

d Results were not summarized in the summary tables due to lack of final data reported. The authors stated that there were no significant changes in both bAP and NTx markers after the intervention.

e Results were not summarized in the summary tables due to lack of final data reported. The authors stated that there were no significant changes in both deoxypyridinoline and NTx markers after the intervention.

Table 61 Number of bone studies included with different study designs (and total)

Study Design | BMD (1 year minimum duration) | Bone Formation Biomarkers | Bone Resorption Biomarkers
Parallel | 5 | 13 | 16
Cross-over | 0 | 2 | 2
Single-Cohort trial | 0 | 2 | 2
Total | 5 | 17 | 20

Table 62 Number of bone studies included within each population and quality category

| [underlined: BMD] (1 year minimum duration) | | | | [underlined: Bone Formation Biomarkers] | | | | [underlined: Bone Resorption Biomarkers]
Quality | | A | B | C | | A | B | C | | A | B | C
Population Category | Total | 0 | 3 | 2 | Total | 1 | 6 | 10 | Total | 1 | 6 | 13
Post-Menop Women | 4 | 1 | 2 | 1 | 12 | 2 | 2 | 8 | 15 | 1 | 4 | 10
Peri-Menop Women | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 1
Pre-Menop Women | 1 | 0 | 0 | 1 | 2 | 0 | 1 | 1 | 3 | 0 | 1 | 2
Men or Teenage Boys | 0 | 0 | 0 | 0 | 3 | 0 | 2 | 1 | 2 | 0 | 1 | 1

BMD = bone mineral density; BMC = bone mineral contents; Post-Menop = post-menopausal; Pre-Menop = pre-menopausal

Table 63 Number of bone studies (or study arms) included that used different types of soy products, controls, or soy consumption types (diet versus supplement)

| BMD (1 year minimum duration) | Bone Formation Biomarkers | Bone Resorption Biomarkers
Soy Product (Study Arms)
Protein with Isoflavones | 3 | 13 | 14
Protein without Isoflavones | 2 | 2 | 3
Isoflavones | 2 | 4 | 6
Control Types (Study Arms)
Dairy | 1 | 3 | 4
Animal/Usual Diet | 0 | 2 | 1
Placebo | 2 | 5 | 7
Miscellaneous | 0 | 2 | 4
No Non-Soy Control | 2 | 4 | 3
Diet or Supplement (Studies)
Diet | 0 | 5 | 7
Supplement | 5 | 13 | 14

BMD = bone mineral density; BMC = bone mineral contents

Table 64 Number of bone studies that directly compared the effects of different soy product characteristics or study subject characteristics

Comparison Characteristics | BMD (1 year minimum duration) | Bone Formation Biomarkers | Bone Resorption Biomarkers
Protein with v without Isoflavones | 2 | 4 | 3
Different Soy Protein Dosages | 0 | 1 | 1
Different Soy Isoflavone Dosages | 1 | 3 | 2
Different Population Categories | 0 | 1 | 1

BMD = bone mineral density; BMC = bone mineral contents

Bone mineral density (BMD) is a composite of bone mineral content (BMC) and cross sectional area of bone. Both BMD and BMC measurements are thought to be the best approach for screening individuals with risk of osteoporosis and the major determinant of fracture risk. Other factors affecting fracture risk are the bone turnover rate and the microarchitecture of the bone. BMD and BMC measurements, however, do not measure the actual bone turnover and a long follow-up time is required to detect any change. Bone turnover can be estimated from various biomarkers of bone formation (serum osteocalcin, total and bone specific alkaline phosphatase, procollagen type I carboxy terminal propeptide, and procollagen type I amino terminal propeptide) and that of bone resorption (urinary hydroxyproline, galactosyl hydroxylysine, total and free pyridinoline, total and free deoxypyridinoline, collagen type I cross linked N-telopeptide, and collagen type I cross linked C-telopeptide, tartrate resistant acid phosphatase, and serum type I collagen carboxy terminal telopeptide). ^196^

A total of 26 studies are included in this section. Ten trials examined the effects of soy and/or its isoflavones on bone mineral density (BMD) and/or bone mineral contents (BMC). Though 5 of these did not meet criteria because of their short duration for BMD (less than 1 year) they are also discussed briefly.The effects of soy and/or its isoflavones on bone biomarkers related to bone turnover or bone remodeling were reported in 22 studies. (Tables 60–64).

### 3.6.1. Bone Mineral Density (BMD)

(Tables 65–67)

Table 65 Effects of soy products on lumbar spine bone mineral density (g/cm^2^)

Diet /Supplement | Design | Control | Dose | | | | | N | Base value | % Change | | | Net % Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Supplement | RCT | Dairy
Kreijkamp-Kaspers 2004^ a^ | 1 yr | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88 | 0.92 | +0.02 | | | -0.01 | NS | post♀ | | A
| | Milk protein | | | | | | 87 | 0.90 | -0.02
Supplement | RCT | Placebo
Chen 2004; 2003^b^ | 1 yr | Isoflavones | 6 | 19 | 16 | 40 | 0 | 57 | | -0.5 | NS | NS | +0.2 | | post♀ | | C
| | Isoflavones | 12 | 38 | 31 | 80 | 0 | 50 | | -0.9 | NS | | -0.3
| | Placebo | | | | | | 53 | | -0.6 | NS
Morabito 2002 | 1 yr | Isoflavones | 54 | | | | 0 | 30 | 0.92 | +3 | | | +4.6 | <0.04 | post♀ | | B
| | Placebo | 0 | | | | | 30 | 0.93 | -1.6
Supplement | RCT | No Control
Lydeking-Olsen 2004 | 2 yr | Soymilk w/Isoflavones | | | | 76 | 18 | 23 | 0.93 | +1.1 | NS | 0.01 | -- | | post♀ | | B
| | Soymilk w/o Isoflavones | | | | 1 | 18 | 22 | 0.87 | -4.2 | .006 | | --
| | No control | | | | | | --
Anderson 2002 | 1 yr | ISP w/Isoflavones | >50 ^c^ | | | 90 ^c^ | | 15 | 1.04 | +1 | NS | NS | -- | | pre♀ (21-25 yr) | | C
| | ISP w/o Isoflavones | | | | 0 | | 13 | 1.01 | 0 | NS | | --
| | No control | | | | | | --

a Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

b Data reported for completers only. The noncompliant subjects or those lost to follow up had significantly higher BMD at all measured sites.

c Calculated from 59%:41% isoflavones as glucosides:aglycones

Table 66 Effects of soy products on femoral neck bone mineral density (g/cm^2^)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | % Change | | | Net % Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Supplement | RCT | Placebo
Chen 2004; 2003^a^ | 1 yr | Isoflavones | 12 | 38 | 31 | 80 | 0 | 50 | | +0.1 | NS | | +0.1 | | post♀ | | C
| | Isoflavones | 6 | 19 | 16 | 40 | 0 | 57 | | -0.5 | NS | | -0.5
| | Corn starch | | | | | | 53 | | +0.04 | NS
Morabito 2002 | 1 yr | Isoflavones | 54 | | | | 0 | 30 | 0.69 | +3.6 | | | +4.3 | <0.001 | post♀ | | B
| | Placebo | | | | | | 30 | 0.69 | -0.7
Supplement | RCT | No Control
Lydeking-Olsen 2004 | 2 yr | Soymilk w/Isoflavones | | | | 76 | 18 | 23 | | -0.9 | NS | NS | -- | | post♀ | | B
| | Soymilk w/o Isoflavones | | | | 1 | 18 | 22 | | +0.2 | NS | | --
| | No control
Anderson 2002 | 1 yr | ISP w/Isoflavones | >21 ^b^ | | | 36 ^c^ | | 15 | 0.93 | -3 | 0.01 | NS | -- | | pre♀ (21–25 yr) | | C
| | ISP w/o Isoflavones | | | | 0 | | 13 | 0.89 | -1 | NS | | --
| | No control

a Data reported for completers only. The noncompliant subjects or those lost to follow up had significantly higher BMD at all measured sites

b Calculated from 59%:41% isoflavones as glucosides:aglycones

Table 67 Effects of soy products on hip bone mineral density (g/cm^2^)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | % Change | | | Net % Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Supplement | RCT | Dairy
Kreijkamp-Kaspers 2004 ^a^ | 1 yr | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88 | 0.86 | -0.1 | | | +0.4 | NS | post♀ | | A
| | Milk protein | | | | | | 87 | 0.83 | -0.5
Supplement | RCT | Placebo
Chen 2004; 2003 ^b^ | 1 yr | Isoflavones | 6 | 19 | 16 | 40 | 0 | 57 | | -0.5 | NS | | +0.03 | | post♀ | | C
| | Isoflavones | 12 | 38 | 31 | 80 | 0 | 50 | | -0.2 | NS | | +0.3
| | Corn starch | | | | | | 53 | | -0.5 | NS

a Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

b Data reported for completers only. The noncompliant subjects or those lost to follow up had significantly higher BMD at all measured sites.

BMD and BMC in healthy adults are maintained if there is a balance of bone formation and bone resorption (normal bone turnover or remodeling rate). Post-menopausal women may have rapid decline of BMD due to estrogen deficiency. Research has showed the yearly BMD decline in post-menopausal women is at least 1% and up to 2.4%. ^197^

#### Study Descriptions

Since all 5 qualified studies reported BMD (in 6 publications), ^78,^ ^172,^ ^198^ – ^201^ but only 3 also reported BMC data, we focus on BMD outcomes. BMD was measured in lumbar spine (Table 65), femoral neck (Table 66), and hip (Table 67) locations. Only 1 study is in pre-menopausal women while the other 4 studies are in post-menopausal women. There is 1 high-quality study, while the quality of the remaining studies are of medium or poor quality. Five studies that otherwise would have qualified were excluded for BMD analyses due to the short duration (<1 year intervention). ^87,^ ^97,^ ^108,^ ^202,^ ^203^

Among the 3 milk-protein or placebo controlled trials, only Morabito 2002 ^172^ found that a purified soy isoflavone extract (54 mg per day of genistein) consistently increased lumbar spine (Table 65), and femoral neck (Table 66) BMD after 1-year intervention in post-menopausal women. Hip BMD was not measured in this study. The other 2 trials found small or inconsistent effects.

Two studies compared soy with isoflavones to soy without isoflavones. Neither included a non-soy control. Lydeking-Olsen 2004 ^200^ found that soy milk with isoflavones yielded a small increase in lumbar spine BMD, which was significantly different than the larger decrease in BMD with soy milk lacking isoflavones (Table 65). This effect was not seen in femoral neck BMD (Table 66) or by Anderson 2002. ^201^

Results from short-term studies (not included in Summary Tables) were similar to the long-term studies. The treatment durations were of 3 months in 1 study, ^97^ , of 6 months in 3 studies ^108,^ ^202,^ ^203^ , and of 9 months in 1 study. ^87^ Four of these short-term studies showed no significant treatment effect of soy and/or its isoflavones on lumbar spine and/or femoral neck BMD compared to the control. Only Potter 1998 found that lumbar spine BMD increased significantly in the high-dose group (soy protein with 90 mg/day of total isoflavones) compared to control. ^108^ No significant change was seen in the low-dose group (soy protein with 56 mg/day of total isoflavones.

#### Summary

Because there are few long-term RCTs and a wide variety of soy interventions used across studies, it is difficult to draw an overall conclusion about the effects of soy on bone outcomes. Overall, among the 5 studies of 1 year minimum duration, no consistent effect on BMD was seen with soy consumption. Studies of shorter duration, likewise found no effect of soy.

### 3.6.2. Bone Formation Biomarkers

(Tables 68–69)

Table 68 Effects of soy products on bone formation biomarkers: serum bone specific alkaline phosphatase (bAP)

Diet /Supplement | Design | Control | Dose | | | | | N | Base value | Unit | % Change | | | Net % Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | Animal/Usual
Katsuyama 2004 | 1 yr | 90 g Natto per wk | | | | | 16^d^ | 18 | 64 | U/L | +10 | | <0.05 | +11 | NS | pre♀ | | C
| | 30 g Natto per wk | | | | | 5^d^ | 16 | 52 | | -14 | | | -13 | NS
| | 30 g Natto per mo | | | | | 5^d^ | 21 | 54 | | +3.5 | | NS | +4.5 | NS
| | Usual diet | | | | | | 18 | 61 | | -1.0
Diet | RCT | Miscellaneous
Brooks, 2004 | 16 wk | Soy muffins | 26 | 16 | 1 | 42 | 15 | 13 | 15.9 | U/L | -0.73 | NS | | +1.49 | NS | post♀ | | B
| | Placebo muffins | | | | | | 15 | 15.6 | | +0.76 | NS
Diet | Cohort | No Control
Scheiber 2001 | 12 wk | Soy nuts and drinks | | | | | ~60 | 42 | 19 | μg/L | +5.8 | NS | | -- | | post♀ | | C
| | No control
Supplement | RCT | Dairy
Kreijkamp-Kaspers 2004 ^e^ | 1 yr | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88 | 13 | μg/L | -4.6 | | | -0.8 | NS | post♀ | | A
| | Milk protein | | | | | | 87 | 13 | | -3.8
Arjmandi 2003 | 3 mo | ISP w/Isoflavones | | | | 88 | 40 | 20^c^ | 26 | U/L | -0.1 | NS | | +0.1 | | post♀ | | C
| | Milk protein | | | | | | 22^c^ | 23 | | -0.2 | 0.05
Supplement | Xover | Placebo
Nikander 2004 15001611 | 3 mo | Isoflavones | 7 | 41 | 66 | 114 | 0 | 56 | 14.6 | μg/L | 0 | NS | | -0.5 | NS | post♀ BrCA | | A
| | Placebo | | | | | | | 14.7 | | +0.5 | 0.02
Supplement | RCT | Placebo
Jones 2003 | 6 wk | Isoflavones | | | | 50 | 0 | 69 | 46 | U/L | +10 | <0.05 | | +0.5 | NS | ♂ Teen | | B
| | Placebo | | | | | | 59 | 49 | | +8 | <0.05
Morabito 2002 | 1 yr | Isoflavones | 54 | | | | 0 | 30 | 9.7 | μg/L | +24 | | | +20 | <0.05 | post♀ | | B
| | Placebo | | | | | | 30 | 10 | | -4
Supplement | Xover | No control
Wangen, 2000 | 93 days | ISP w/Isoflavones | | | | 132 | 63 | 17 | 21 | U/L | +6.7 | <.05 | NS | -- | | post♀ | | C
| | ISP w/Isoflavones | | | | 65 | 63 | | | | +6.7 | <.05 | | --
| | ISP w/o Isoflavones | | | | 7 | 63 | | | | +17.6 | <.05 | <0.05 | --
| | No control

BrCA = breast cancer

a Median value, estimated from graph

b U/L, converted from 1:0.01667 μkat/L:U/L

c The authors report in the abstract that 22 women were on hormone therapy and 20 were not on hormone therapy.

d Soy protein was estimated from USDA database (www.nal.usda.gov/fnic/foodcomp/cgi-bin/measure.pl) for 30 gram Natto.

e Apparent discrepancies between Within-Cohort changes and Between-Cohort changes are due to rounding errors in estimated Within-Cohort changes compared to reported Between-Cohort changes.

Table 69 Effects of soy products on bone formation biomarkers: serum osteocalcin (OC, ng/mL)

Diet /Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | Animal/Usual
Chiechi 2002 12191852 | 6 mo | ISP w/Isoflavones | | | | 47 | | 53/24 | 21.9 | +5.45 | <0.05 | | +3.8 | NS | post♀ | | C
| | Control | | | | | | 58/43 | 15.5 | +1.7 | NS
Katsuyama 2004 | 1 yr | 90 g Natto per wk | | | | | 16^d^ | 18 | 1.68 | +1.18 | | NS | +1.2 | NS | pre♀ | | C
| | 30 g Natto per wk | | | | | 5.3^d^ | 16 | 1.95 | +0.22 | | | +0.2 | NS
| | 30 g Natto per mo | | | | | 5.3^d^ | 21 | 1.42 | -0.29 | | | +0.3 | NS
| | Usual diet | | | | | | 18 | 1.91 | -0.01
Diet | Cohort | No Control
Scheiber 2001 | 12 wk | Soy nuts and drinks | | | | ~60 | | 42 | 5.8 | +0.6 | <0.03 | | -- | | post♀ | | C
| | No control | | | | | | --
Supplement | RCT | Placebo
Morabito 2002 | 1 yr | Isoflavones | 54 | | | | 0 | 30 | 13 | +5 | | | +6 | <0.05 | post♀ | | B
| | Placebo | | | | | | 30 | 13 | -1
Upmalis 2000 | 12 wk | Isoflavones | | 50^c^ | | | 0 | 59 | 13 | +0.3 | NS | | -0.8 | | post♀ | | C
| | Placebo | | | | | | 63 | 14 | +1.1 | NS
Uesugi 2002 | 4 wk | ISP w/Isoflavones | | | | 62 | 16.4 | 12 | 8.5 | -1.1 | NS | | -1.0 | NS | pre♀ | | B
| | Placebo | | | | | | 11 | 7.2 | -0.1 | NS
Supplement | Xover | No control
Wangen, 2000 | 93 days | ISP w/Isoflavones | | | | 132 | 63 | 17 | 2.5 ^b^ | +0.36 | NS | NS | -- | | post♀ | | C
| | ISP w/Isoflavones | | | | 65 | 63 | | | +0.6 | NS | | --
| | ISP w/o Isoflavones | | | | 7 | 63 | | | +0.6 | NS | | --
| | No control
Supplement | RCT | No Control
Gallagher 2004 | 9 mo | ISP w/Isoflavones | 52 | 28 | | 96 | 40 | 17 | 32.8 | 0 ^f^ | NS | | -- | | post♀ | | C
| | ISP w/Isoflavones | 28 | 20 | | 52 | 40 | 19 | 25.9 | 0 ^f^ | NS | | --
| | ISP w/Isoflavones | 4 | | | <4 | 40 | 14 | 24.3 | +1.7 ^f^ | NS | | --
| | No control
Supplement | Cohort | No Control
Yamaguchi 2001 | 60 d | Nijiru powder^e^ | 0.02^e^ | 0.02^e^ | | | | 12 | 9.9^f^ | +10 ^f^ | <0.01 | | -- | | ♂♀ | | C
| | | | | | | | 6 | 10 ^f^ | +9 ^f^ | <0.01 | | -- | | ♂
| | | | | | | | 6 | 9.8 ^f^ | +11 ^f^ | <0.01 | | -- | | ♀
| | No control | | | | | | -

E_2_ = exogenous estradiol

a Median value, estimated from graph

b Unit = nmol/L

c 50 mg genistein and daidzein

d Soy protein was estimated from USDA database (www.nal.usda.gov/fnic/foodcomp/cgi-bin/measure.pl) for 30 gram Natto

e Nijiru powder is a byproduct of natto. It also contains 2.7 mg of daidzin and 2.4 mg of genistin per day

f Value was estimated from graph

Bone specific alkaline phosphatase (bAP) measurements can be used as a bone formation marker because it is thought to participate in the initiation of bone mineralization. Post-menopausal women have higher levels of bone specific alkaline phosphatase than pre-menopausal women have. Serum osteocalcin (OC), also known as bone GLA protein, is another bone formation marker. It is a bone specific non-collagenous protein and is thought to be a sensitive and specific marker of osteoblastic activity whose serum levels reflect the rate of bone formation. ^196^

#### Study Descriptions

Nine studies examined the effects of soy and/or its isoflavones on bAP (Table 68); ^78,^ ^128,^ ^138,^ ^170^ – ^172,^ ^204^– ^206^ 9 evaluated OC (Table 69). ^47,^ ^87,^ ^96,^ ^128,^ ^172,^ ^203,^ ^204,^ ^206,^ ^207^ Three additional studies reported only no significant changes in either bAP or OC with soy intervention. ^88,^ ^202,^ ^208^ Some studies reported on both biomarkers so that their results appear in both summary tables. Among these studies, there are 8 RCTs, 2 cross-over trials, and 2 non-controlled trials. The majority of these trials enrolled pre- and post-menopausal women. One study included both men and women, 1 study included peri-menopausal women and 2 studies included men or teenage boys only. There are 2 high-quality studies and the remaining studies are of quality B or C.

No statistically significant effect was reported for bone formation as measured by OC and bAP by most of the studies. Only the study by Morabito 2002, ^172^ which was the also the only study to find a significant benefit of soy on BMD and which used soy genistein 54 mg per day compared to placebo, found that genistein significantly increased bone formation as indicated by the increase in both OC and bAP biomarkers. Wangen 2000 and Gallagher 2004, 2 low-quality trials compared isolated soy protein with different doses of isoflavones and showed trends toward reduced concentrations of OC and/or bAP by the high-isoflavone group. ^87,^ ^206^

#### Summary

Overall, across studies, the evidence does not suggest any consistent or statistically significant effect of soy products on bAP or OC, 2 biomarkers of bone formation.

### 3.6.3. Bone Resorption Biomarkers

Urinary hydroxyproline, which is an amino acid in the collagen structure, has been used for a long time as a biomarker for measuring bone resorption. When collagen degradation is accelerated during bone resorption, urinary hydroxyproline increases. However, urinary hydroxyproline is not a sensitive biomarker because the majority of the hydroxyproline derived from the breakdown of collagen is reabsorbed by the renal tubules and degraded in the liver. There are now several biomarkers of bone resorption that are more sensitive. As shown in Figure 11, peptide chain of collagen has amino (N) and carboxy (C) terminals from which N-telopeptides and C-telopeptides are covalently bound to collagen by pyridinoline (Pyr) and deoxypyridinoline (D-pyr) cross-links. When collagen is degraded, pyridinoline and D-pyridinoline are released into the circulation, where 20% is free and the remaining is protein bound. The protein bound fraction binds either to N-telopeptide, as collagen type I cross-linked N-telopeptide (NTx) or to C-telopeptide (CTx). The total, free, or protein bound pyridinoline and D-pyridinoline can be measured as bone resorption markers. ^196^

Figure 11. Cross linked N- and C-telopeptides of type I collagen. Source: Dogan and Posaci. Postgrad.Med.J. 2002; 78(926):727–31

3.6.3.a. Urinary Hydroxyproline

(Table 70)

Table 70 Effects of soy products on urinary hydroxyproline (mmol/24 hours)

Diet /Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vsControl
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | Animal/Usual
Chiechi 2002 12191852 | 6 mo | ISP w/Isoflavones | | | | 47 | | 53/24 | 55.3 ^a^ | -6.12 | NS | | -1.5 | NS | post♀ | | C
| | Control | | | | | | 58/43 | 50.7 ^a^ | -4.6 | NS
Diet | RCT | Miscellaneous
Murkies 1995 | 12 wks | Soy flour | 40 g of flour per day | | | | | 23 | 186.2 | +14.6 | NS | | -40.1 | NS | post♀ | | C
| | Wheat flour | | | | | | 24 | 181.6 | +54.7 | <0.05

a Unit used was not reported clearly (“hydroxyproline/creatine”)

#### Study Descriptions

Two RCTs reported urinary hydroxyproline as a bone resorption biomarker in post-menopausal women. ^66,^ ^203^ They are both of poor quality. No significant effects were found comparing soy protein with isoflavones from diet to control diets. Notably, Murkies 1995 found that bone resorption significantly increased in the control group but not in the soy flour group. ^66^

#### Summary

Inconsistent and non-significant effects were observed in the 2 RCTs evaluating urinary hydroxyproline.

3.6.3.b. Urinary Cross-Linked N-telopeptide (NTx)

(Table 71)

Table 71 Effects of soy products on urinary cross-linked N-telopeptide (NTx, nmol BCE/mmol creatinine)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | Animal/Usual
Katsuyama 2004 | 1 yr | 90 g Natto per week | | | | | 16^b^ | 18 | 46.7 | -2.2 | | NS | +0.5 ^ c ^ | NS | pre♀ | | C
| | 30 g Natto per week | | | | | 5^b^ | 16 | 36.0 | -11.7^c^ | | | -9.0 ^ c ^ | NS
| | 30 g Natto per month | | | | | 5^b^ | 21 | 45.8 | -12.0 | | | -9.3 ^ c ^ | NS
| | Usual diet | | | | | | 18 | 35.7 | -2.7^c^
Diet | RCT | Miscellaneous
Chiechi 2002 12191852 | 6 mo | ISP w/Isoflavones | | | | 47 | | 53/24 | 29.5^g^ | +4.9 | NS | | +3.6 | | post♀ | | C
| | Control | | | | | | 58/43 | 29.9^g^ | +1.3 | NS
Alekel 2000 | 6 mo | ISP w/Isoflavones | | | | 80 | 40 | 24 | 65^a^ | | NS | NS | | NS | peri♀ | | C
| | ISP w/o Isoflavones | | | | 4 | 40 | 24 | 67^a^ | | NS | | | NS
| | Whey protein | | | | | | 21 | 55^a^ | | NS
Diet | Cohort | No Control
Scheiber 2001 | 12 wk | Soy nuts and soy drinks | | | | ~60 | | 42 | 52 | -7.3 | <0.02 | | -- | | post♀ | | C
| | No control
Supplement | Xover | Placebo
Nikander 2004 15001611 | 3 mo | Isoflavones | 7 | 41 | 66 | 114 | 0 | 56 | 71.9 | -2.4 | NS | | -5.5 | NS | post♀ BrCA | | A
| | Placebo | | | | | | | 73.7 | +3.1 | NS
Supplement | RCT | Placebo
Upmalis 2000 | 12 wk | Isoflavones | 50^d^ | | | | 0 | 59 | 52.6^g^ | +0.7 | | | +2.1 | | post♀ | | C
| | Placebo | | | | | | 63 | 54.8^g^ | -1.4
Murray 2003 | 6 mo | ISP w/Isoflavones + 0.5 mg E_2_ | 66 | 44 | 10 | 120 | 38 | 8 | 18.5^e^ | -5.1 | NS | | -1.6 | NS | post♀ | | C
| | Placebo + 0.5 mg E_2_ | | | | | | 7 | 16.8^e^ | -3.5 | 0.02
| | ISP w/Isoflavones + 1.0 mg E_2_ | 66 | 44 | 10 | 120 | 38 | 8 | 15.1^e^ | -3.9 | 0.02 | | +2.5 | NS
| | Placebo + 1.0 mg E_2_ | | | | | | 7 | 17.0^e^ | -6.4 | 0.03
Supplement | RCT | No Control
Gallagher 2004 | 9 mo | ISP w/Isoflavones | 52 | 28 | | 96 | 40 | 17 | 94.2 | -4 ^f^ | NS | <0.05 | -- | | post♀ | | C
| | ISP w/Isoflavones | 28 | 20 | | 52 | 40 | 19 | 60.8 | -0.8 ^f^ | NS | NS | --
| | ISP w/o Isoflavones | 4 | | | <4 | 40 | 14 | 60.9 | -4 ^f^ | NS | NS | --
| | No control

E_2_ = exogenous estradiol; BrCA = breast cancer

a Median value, estimated from graph

b Soy protein was estimated from USDA database (www.nal.usda.gov/fnic/foodcomp/cgi-bin/measure.pl) for 30 g Natto

c According to reported baseline and final mean values, for 90 g per week net change = -1.4; for 30 g per week change = -8.3 and net change = -7.5; for 30 g per month net change = -11.2; for usual diet change = -0.8.

d 50 mg genistein and daidizein

e Unit = nM bone collagen equivalents

f Value was estimated from graph

g Unit used was not clear

#### Study Descriptions

A total of 8 trials reported NTx as a bone resorption biomarker. ^47,^ ^87,^ ^103,^ ^128,^ ^138,^ ^202^ – ^204^ Most of these trials are of poor quality. Katsuyama 2004,in pre-menopausal women ^204^ and Alekel 2000, in peri-menopausal women ^202^ found no significant effects of diets of soy protein with or without isoflavones compared to the control diets, regardless of dose in either study.

The other 6 studies were in post-menopausal women, including 1 trial in post-menopausal women with breast cancer. These 6 studies are very heterogeneous: 1 soy diet RCT, 1 soy diet uncontrolled cohort, 2 soy isoflavones trials (1 cross-over and 1 RCT), 1 RCT of soy protein with isoflavones in combination of hormone replacement therapy, and 1 RCT compared the effects of soy protein with different amount of isoflavones. Regardless of the heterogeneity across the 6 trials of post-menopausal women, there was no significant effect of soy and/or its isoflavones when compared to the placebo treatments. Scheiber 2001, a prospective uncontrolled cohort of soy nuts and soy drinks, showed that the post-menopausal women received the soy dietary intervention had significantly reduced urinary NTx levels. ^128^

Gallagher 2004, ^87^ an RCT without a non-soy control, found no dose-response relationship of soy protein with different dose of isoflavones. While among the women who consumed soy with the highest dose of isoflavones did have a statistically significant decrease in NTx, in contrast to the women consuming lower doses of isoflavones, the magnitude of the change was the same as for those not consuming soy isoflavones and they had a substantially higher baseline NTx level.

#### Summary

There is no consistent effect of soy protein and/or its isoflavones on urinary NTx levels compared to the control treatments in pre-, peri- and post-menopausal women. However, the poor quality of these trials might contribute to the inconsistent findings.

3.6.3.c. Urinary Pyridinoline

(Table 72)

Table 72 Effects of soy products on urinary pyridinoline (nmol/umol creatinine)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | Animal/Usual
Chiechi 2002 12191852 | 6 mo | ISP w/Isoflavones | | | | 47 | | 53/24 | nd | -6.12 | NS | | -1.5 | | post♀ | | C
| | Usual diet | | | | | | 58/43 | nd | -4.60 | NS
Diet | RCT | Miscellaneous
Yamori, 2002 | 10 wk | Soybean and sesame | 6 | 21 | 11 | 37 | 6 | 20 | 3.04 | -0.95 | <0.05 | | -0.47 | NS | post♀ | | B
| | Sesame | | | | | | 20 | 2.65 | -0.48 | NS
Supplement | RCT | Dairy
Arjmandi 2003 | 3 mo | ISP w/Isoflavones | | | | 88 | 40 | 20^c^ | 9.62 | -2.43 | 0.01 | | -1.56 | NS | post♀ | | C
| | Milk protein | | | | | | 22^c^ | 7.66 | -0.87 | NS
Supplement | Xover | Placebo
Nikander 2004 15001611 | 3 mo | Isoflavones | 7 | 41 | 66 | 114 | 0 | 56 | 7.95 | -0.82 | 0.001 | | -0.82 | | post♀ BrCA | | A
| | Placebo | | | | | | | 7.48 | -0.03 | NS
Supplement | RCT | Placebo
Jones 2003 | 6 wk | Isoflavones | | | | 50 | 0 | 69 | 8.72 | +0.36 | | | -0.44 | NS | ♂ Teen | | B
| | Placebo | | | | | | 59 | 9.29 | +0.77
Morabito 2002 | 1 yr | Isoflavones | 54 | | | | 0 | 30 | 11.2 | -4.7 | <0.05 | | -4.0 | <0.05 | post♀ | | B
| | Placebo | 0 | | | | | 30 | 9.9 | -0.7 | NS
Uesugi 2002 | 4 wk | ISP w/Isoflavones | | | | 62 | 16 | 12 | 19.7 | -6.6 | <0.05 | | -8.0 | <0.05 | pre♀ | | B
| | Placebo | | | | | | 11 | 16.2 | +1.4 | NS
Supplement | RCT | Miscellaneous
Dalais, 2003 | 3 mo | ISP w/Isoflavones | | | | 118 | 40 | 37 | 7.07 | -0.38 | | | -0.30 | NS | post♀ | | C
| | Wheat protein | | | | | | 40 | 7.35 | -0.08

#### Study Descriptions

Eight trials reported urinary pyridinoline as a bone resorption biomarker. ^96,^ ^138,^ ^170,^ ^172,^ ^203,^ ^205,^ ^209,^ ^210^ One study was of good quality, 4 of moderate quality, and 3 of poor quality. Five RCTs were conducted in post-menopausal women, 1 cross-over trial was in post-menopausal women with breast cancer, 1 RCT was in teenage boys, and 1 RCT was in pre-menopausal women.

Of the 5 RCTs in post-menopausal women, all showed a net reduction in the urinary pyridinoline after the soy protein and/or its isoflavones treatments compared to the control treatments. However, only Morabito 2002 reported a significant effect. ^172^ This study, which used soy genistein 54 mg per day in comparison with placebo, was also the only study to find a significant effect on BMD and biomarkers of bone formation. It found that genistein significantly reduced bone resorption as indicated by the decrease in urinary pyridinoline. The RCT of soy protein with isoflavones in pre-menopausal women (Uesugi 2002) also found a significant net reduction in urinary pyridinoline compared to the placebo. ^96^ Non-significant net reductions in urinary pyridinoline were found in the cross-over trial of soy isoflavones among post-menopausal women with breast cancer and in the RCT of soy isoflavones among teenage boys.

#### Summary

There is some evidence to suggest that soy protein and/or its isoflavones might reduce urinary pyridinoline levels in both pre-menopausal and post-menopausal women. However, the evidence is limited given that few studies found a statistically significant effect and the large degree of heterogeneity across studies.

3.6.3.d. Urinary Deoxypyridinoline

(Table 73)

Table 73 Effects of soy products on urinary deoxypyridinoline (nmol/mmol creatinine)

Diet/Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | Miscellaneous
Yamori, 2002 | 10 wk | Soybean and sesame | 6 | 21 | 11 | 37 | 6 | 20 | 7.6 | -2.8 | NS | | -3.5 | <0.05 | post♀ | | B
| | Sesame | | | | | | 20 | 5.2 | +0.7 | NS
Brooks, 2004 | 16 wk | Soy muffins | 26 | 16 | 1 | 42 | 15 | 13 | 9.52 | -0.54 | NS | | -0.85 | NS | post♀ | | B
| | Placebo muffins | | | | | | 15 | 9.01 | +0.31 | NS
Supplement | RCT | Dairy
Supplement | Xover | Placebo
Nikander 2004 15001611 | 3 mo | Isoflavones | 7 | 41 | 66 | 114 | 0 | 56 | 19.7 | -2.0 | 0.008 | | -2.4 | <0.05 | post♀ BrCA | | A
| | Placebo | | | | | | | 18.9 | +0.4 | NS
Supplement | RCT | Placebo
Morabito 2002 | 1 yr | Isoflavones | 54 | | | | 0 | 30 | 27^a^ | -12 | <0.05 | | -11 | <0.05 | post♀ | | B
| | Placebo | 0 | | | | | 30 | 23^a^ | -1 | NS
Uesugi 2002 | 4 wk | ISP w/Isoflavones | | | | 62 | 16 | 12 | 11.7 | -1.9 | <0.05 | | -1.1 | NS | pre♀ | | B
| | Placebo | | | | | | 11 | 10.1 | -0.8 | NS
Uesugi 2003 | 3 mo | Isoflavones | 7^b^ | 31^b^ | 21^b^ | 62^b^ | 0 | 11 | 13.7 | -6.9 | <0.01 | | -6.5 | 0.01 | post♀ | | B
| | Placebo | | | | | | 10 | 12.9 | -0.4 | NS
Supplement | RCT | Miscellaneous
Dalais, 2003 | 3 mo | ISP w/Isoflavones | | | | 118 | 40 | 37 | 15.29 | -0.8 | | | +0.4 | NS | post♀ | | C
| | Wheat protein | | | | | | 40 | 14.47 | -0.3
Supplement | Xover | No Control
Wangen, 2000 | 93 days | ISP w/Isoflavones | | | | 132 | 63 | 17 | 6.84 | -0.52 | NS | NS | -- | | post♀ | | C
| | ISP w/Isoflavones | | | | 65 | 63 | | | -0.07 | NS | | --
| | ISP w/o Isoflavones | | | | 7 | 63 | | | -0.73 | NS | | --
| | No control
Supplement | RCT | No Control
Mackey 2000 | 12 wk | ISP w/Isoflavones | | | | 65 | | 25 | 8.9^d^ | -0.64 | 0.01 | NS | | | post♀ | | C ^d^
| | ISP w/o Isoflavones | | | | 4 | | 24
| | No control

a pmol/mmol creatinine

b glucosides

c The authors reported in the abstract that 22 women were on hormone replacement therapy and 20 were not

d Data were reported for both arms combined. The authors stated that the observed change was due largely to group ISP w/o isoflavones although no statistical change was found between groups. Limited data was in contrast to other outcomes reported in this article.

#### Study Descriptions

Ten trials reported on urinary deoxypyridinoline. ^88,^ ^96,^ ^97,^ ^138,^ ^171,^ ^172,^ ^206,^ ^208^ – ^210^ The majority of these trials are of moderate quality. Eight trials were conducted in post-menopausal women, 2 of which were of dietary soy, the others of soy supplements. One of these studies included women with breast cancer, 1 in pre-menopausal women, and 1 in men.

Among the 8 trials of post-menopausal women, all but Dalais 2003 ^210^ found a net reduction in urinary deoxypyridinoline with soy consumption; however, the reduction was statistically significant in only half the studies and the net effects ranged from +0.4 to -6.5 nmol/mmol creatinine. In the 2 studies by Wangen 2000 ^206^ and Mackey 2000 ^88^ that compared different doses of soy isoflavones (although did not include a non-soy control), no dose-effect was seen. No dose-effect was evident across studies either, where isoflavone doses ranged from 4 to 132 mg per day and reported soy protein doses ranged from 6 to 63 g per day (in addition to studies without soy protein).

The single study of pre-menopausal women (Uesugi 2002 ^96^ ) found asignificnat reduction in urinary deoxypyridinoline among women consuming soy protein with isoflavones, but this effect was not significantly different than the reduction in women in the control arm.

Khalil 2002 ^208^ evaluated the effect of soy protein with isoflavones on urinary deoxypyridinoline among men. Detailed results were not reported; however, no significant difference in effect was reported for all men and for subgroups based on age.

#### Summary

Among women, almost all studies reported reductions and net reductions in urinary deoxypyridinoline with soy consumption. However the range of effects was broad and only half the studies (of post-menopausal women) reported significant effects. No dose-effect for either soy isoflavones or soy protein was evident.

### 3.6.4. Summary of Osteoporosis and Osteoporosis Risk Factors Studies

Overall, 31 studies evaluated various markers of bone health, including BMD, bone formation biomarkers (bAP and OC) and bone resorption biomarkers (urinary hydroxyproline, urinary NTx, urinary pyridinoline, and urinary deoxypyridinoline).

Studies of BMD and of bone formation biomarkers generally found no effect of soy consumption when compared to control. While a number of studies reported reductions in 2 markers of bone resorption - urinary pyridinoline and deoxypyridinoline - no effects were found on the other markers of bone resorption and the effects were not consistent across studies. For these markers there is no clear evidence of a dose effect for either soy isoflavones or soy protein.

Only one study found a consistent effect on these markers. Morabito 2002 was the only study to find a significant increase in BMD or on markers of bone formation and among the few studies to find a significant reduction on markers of bone resorption. ^172^ They compared genistein 54 mg per day for 1 year to placebo in 30 post-menopausal women. Several factors might explain the more positive results from this study. First, this is the only study that excluded subjects with denser femoral neck BMD (>0.795 g/cm ^2^ , which corresponds to a T score of -1 standard deviation). Thus the subjects recruited into this study had a lower BMD at femoral neck at baseline than about 50% of general population. Second, the preparation of the purified genistein tablets used in this study is also unique and may have different properties than other preparations of soy isoflavone extracts.

## 3.7. Reproductive Health

We included 11 trials with results on menstrual cycle length. We also included 5 trials with results on testosterone level in men, 2 trials with results on FSH in men, 6 trials with results on FSH in pre-menopausal women, and 12 trials with results on E2 in pre-menopausal women. These trials are described under Endocrine Function, in sections 3.4.1–4.

## 3.8. Miscellaneous Outcomes

This section summarizes the studies that evaluated the effects of soy and/or its isoflavones on various health conditions not included in previous sections. There is very limited evidence regarding these topics. These topics include cognitive function, kidney function, and glucose metabolism.

### 3.8.1. Kidney Function

(Table 74)

Table 74 Effects of soy protein diet on glomerular filtration rate and creatinine clearance

Author Year | Duration | Intervention | Dose | | | | | N | Base value | % Change | | | Net % Change | | Population | Applicability | Quality
| | | mg/day | | | | g/day | | GFR CrCl | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Xover | Animal/Usual
Anderson, 1998 | 8 wk | Soy protein diet | | | | | 1 g/1 kg body weight | 8 | 49 | -5 | | -- | 0 | NS | ♂ | | C
| | | | | | | | | 99 | -12 | | -- | +8 | NS
| | Animal-protein diet | | | | | | | 49 | -5
| | | | | | | | | 103 | -20

GFR = Glomerular Filtration Rate; CrCl = Creatinine Clearance

Only 1 study of poor quality and limited applicability assessed the effects of soy protein on kidney function. ^211^ We did not evaluate other kidney-related outcomes, such as nephrolithiasis and its risk factors. The study reported on 8 men with insulin treated type 2 diabetes, obesity, hypertension and proteinuria (with excretion between 50 and 1000 mg/day), who were enrolled in a cross-over study involving a soy protein and an animal protein diet each for 8 weeks. The study showed that there was no significant change in glomerular filtration rate or creatinine clearance after 8 weeks of soy protein vs. animal protein diet. There is no explanation, though, why the measurements of glomerular filtration rate and creatinine clearance are so radically different.

### 3.8.2. Cognitive Function

(Tables 75–76)

Table 75 Cognitive function tests used

First author, year | Cognitive Function Tests
Duffy, 2003 | - Verbal IQ: National Adult Reading Test revised version (NART-R); - Tests of Attention: Digit symbol substitution, Digit cancellation; Paced Auditory Serial Addition test; - Tests of Memory: Short-story test a (from the Weschler Memory Scale - revised), Delayed Matching to Sample Test from the Cambridge Neuropsychological Test Automated Battery (CANTAB; CeNeS Ltd, Cambridge), Picture test; Category generation task.; - Tests of Frontal Function: Verbal fluency, Test of rule shifting and reversal
File, 2001 | - Verbal IQ: National Adult Reading Test revised version (NART-R); - Tests of Attention: Digit symbol substitution, Digit cancellation; Paced Auditory Serial Addition test; - Tests of Memory: Short-story test a (from the Weschler Memory Scale - revised), Delayed Matching to Sample Test from the Cambridge Neuropsychological Test Automated Battery (CANTAB; CeNeS Ltd, Cambridge), Picture test; Category generation task.; - Tests of Frontal Function: Verbal fluency, Test of rule shifting and reversal
Kritz-Silverstein, 2003 | - Mini-Mental State Examination; - Tests of Memory: Trails A andrails B (from the Halstead-Reitan Neuropsychological Test Battery), Category fluency; Logical memory and recall
Kreijkamp-Kaspers, 2004 | - Tests of Memory: Rey Auditory Verbal Learning Test (immediate recall, delay recall; recognition); Digit span (forward and reversed); Doors test; - Tests of Complex Attention: Trailmaking test (A1, A2; B); Digital symbol substitution; - Verbal tasks: Fluency N, Fluency A, Fluency animals; Fluency occupations; - Boston naming task; - Mini-Mental State Examination

Table 76 Effects of soy products on cognitive function

Diet /Supplement | Design | Control | Dose | | | | | N | Cognitive Function Tests | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | RCT | No Control
File, 2001 | 10 wk | High soy | | | | 100 | | ~13–14^a^ | High soy diet showed significant improvements in short-term (immediate recall of prose and 4 sec delayed matching to sample of patterns) and long-term memory (picture recall after 20 min) and in mental flexibility (rule shifting and reversal). In a letter fluency test and in a test of planning (Stockings of Cambridge), the high soy diet improved performance only in females. | ♂ Pre♀ | | C
| | Low soy | | | | 0.5 | | ~13–14^a^ | There was no effect of diet on tests of attention or in a category generation task.
| | No Control | | | | | | --
Supplement | RCT | Dairy
Kreijkamp-Kaspers, 2004 | 1 yr | ISP w/Isoflavones | 52 | 41 | 6 | | 26 | 88 | No significant differences in any of the cognitive function tests between the groups. | post♀ | | A
| | Milk protein | | | | | | 87
Supplement | RCT | Placebo
Kritz-Silverstein, 2003 | 6 mo | Isoflavones | | | | 110 | 0 | 27 | Performance in category fluency in the soy isoflavones group improved by 23% between baseline and follow-up, whereas the performance in the placebo group improved only by 3% (P=0.02) | post♀ | | B
| | Placebo | | | | | | 26 | No significant differences in any other cognitive function tests between the groups.
Duffy, 2003 | 12 wk | Isoflavones | | | | 60 | 0 | 18 | Soy isoflavones group showed significantly greater improvement in delay recall of pictures, in immediate story recall tests, and in PASAT. | post♀ | | B
| | Lactose | | | | | | 15 | Groups did not differ in any other cognitive function tests.

DMST = Delayed Matching to Sample Test; PASAT = Paced Auditory Serial Addition Test

a 27 students were randomly allocated to the 2 groups

#### Study Descriptions

Four studies examined the effects of soy products on cognitive function. ^78,^ ^147^ – ^149^ The studies include a total of 261 post-menopausal women and 27 male and female college students. None of these subjects had Alzheimer disease, dementia or mental retardation at baseline, as indicated by the average scores on the Mini-Mental State Examination (MMSE) or IQ (Intelligence quotient). All 3 studies on post-menopausal women are RCTs, of which, 2 studies of medium quality used isoflavone supplements and the other of high quality used an isolated soy protein supplement. The fourth study on male and female college students was a low quality RCT of a soy diet intervention.

Various measures of cognitive function were used across the studies (Table 75). Notably, the 2 studies reported by Duffy 2003 and File 2001 were from the same group of investigatorswho used the same protocols for testing subjects' cognitive functions. ^147,^ ^148^ The results of these 4 studies are summarized in Table 76.

Kreijkamp-Kaspers 2004, a high quality study, compared soy protein with isoflavones to milk protein and found no significant differences in any of the cognitive function tests between the groups of post-menopausal women after 1-year treatments. ^78^ This study alone contributed about 60% of the total subjects evaluated by all 4 studies. The other 2 studies in post-menopausal women found that performance in some cognitive function tests were significantly improved in the soy isoflavones group compared to the placebo group. ^147,^ ^149^ However, the test instruments used by the 3 studies were all different, limiting their comparability. The only study in young male and female college students by File 2001 showed that high soy diet resulted in significant improvements in short-term and long-term memory and in mental flexibility compared to low soy diets. The diets had no effect on tests of attention or in a category generation task.

#### Summary

The few available studies are too heterogeneous to draw an overall conclusion regarding the effects of soy protein and/or its isoflavones on cognitive function. The only long-term and high quality study showed no significant differences in any of the cognitive function tests between the groups of post-menopausal women consuming soy protein with isoflavones or milk protein.

### 3.8.3. Glucose Metabolism

(Tables 77–78)

Table 77 Effects of soy products on fasting blood glucose

Author Year | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
| Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Diet | Xover | Animal/Usual
Huff, 1984 | 6 wk | Soybean diet | | | | | 41 | 5 | ND | 76 ^c^ | | | -10 | NS | ♂ | | C
| | Mixed diet | | | | | | | ND | 86^c^
Diet | NRCT | Animal/Usual
Yamashita, 1998 | 16 wk | ISP w/Isoflavones | | | | | 130 | 17 | 82.8 | +1.8 | NS | | 0 | NS | post♀ Obese | | C
| | Red meat diet | | | | | | 19 | 84.6 | +1.8 | NS
Supplement | RCT | Dairy
Onning, 1998 | 4 wk | Soy milk | | | | | 23/30 ^a^ | 12 | 95.4 | +1.8 | NS | | 0 | | ♀♂ | | B
| | Milk | | | | | | 11 | 93.6 | +1.8 | NS
| | Soy milk | | | | | 23 | 6 | 95.4 | +5.4 | 0.05 | | +5.4 | | ♀
| | Milk | | | | | | 5 | 93.6 | 0 | NS
| | Soy milk | | | | | 30 | 6 | 95.4 | -3.6 | 0.01 | | -5.4 | | ♂
| | Milk | | | | | | 6 | 93.6 | +1.8 | NS
Supplement | Xover | Placebo
Washburn, 1999 | 6 wk | ISP w/Isoflavones once daily | | | | 34 | 14 | 51/42 ^b^ | 91.7 | +0.9 | NS | | | NS | peri♀ | | B
| | ISP w/Isoflavones twice daily | | | | 34 | 14 | | | +0.6 | NS | | | NS
| | Carbohydrates | | | | | | | | +0.1 | NS
Nikander, 2004 15240647 | 13 wk | Isoflavones | 6 | 42 | 66 | 114 | | 56 | 91.8 | +9 | NS | | +9 | NS | post♀ | | A
| | Placebo | | | | | | | 91.8 | 0 | NS
Supplement | RCT | Placebo
Han, 2002 | 13 wk | Isoflavones | 70 | 19 | 11 | 100 | 0 | 40 | 95.6 | +1.8 | NS | | +4.7 | NS | post♀ | | A
| | Placebo | | | | | | 40 | 96.8 | -2.9 | NS

a Women/Men values

b Baseline/Final values

c Final values were used due to no baseline value was reported.

Table 78 Effects of soy products on 2-hour oral glucose tolerance test

Diet /Supplement | Design | Control | Dose | | | | | N | Base value | Change | | | Net Change | | Population | Applicability | Quality
Author Year | Duration | Intervention | mg/day | | | | g/day | | | Value | P within | P btw Soy | Value | P vs Control
| | | Genistein | Daidizein | Glycitein | T. Isoflav | Soy Protein
Supplement | Xover | Placebo
Nikander, 2004 15240647 | 13 wk | Isoflavones | 6 | 42 | 66 | 114 | | 56 | 106.2 | -7.2 | NS | | -12.6 | | post♀ | | A
| | Placebo | | | | | | | 108 | +5.4 | NS

Six studies reported the effects of soy intervention on fasting blood glucose in non-diabetic populations (Table 77). ^23,^ ^34,^ ^89,^ ^91,^ ^104,^ ^212^ One additional study reported only no significant effect on fasting blood glucose. ^75^ Nikander 2004 also included the results of a 2-hour oral glucose tolerance test (Table 78). ^89^ In the study by Onning 1998, ^104^ 12 healthy men and women consumed oat milk and soy milk for 4 weeks each, and 12 healthy men and women consumed oat milk and cow's milk also for 4 weeks each. The 6 women who received the soy intervention had a net increase of blood glucose of 5.4 mg/dL (P=0.05) compared to baseline diet. The 6 men who received the soy intervention had a net decrease of blood glucose of 3.6 mg/dL (P=0.01) compared to baseline diet. The combined (men and women) result, however, did not show significant change.

All 7 studies, including the one that did not report data, found no significant changes in fasting blood glucose (or glucose tolerance test) with soy intervention.

### 3.8.4. Other Miscellaneous Outcomes

(Table 79)

Table 79 Other miscellaneous soy studies

Author, Year | Soy Interventions | Outcome Measures
Jenkins, 2003 | Soy foods | Serum Prostate Specific Antigen
Laskowski, 2003 | Soy protein supplement | Adaptation process in young judoists
Lenn, 2002 | Soy isolate | Delayed Onset Muscle Soreness
Pap, 1983 | Soy flour diet | Secretin-pancreozymin
Pap, 1984 | Soy flour & cholecystokinin-octapeptide | Pancreatic enzyme secretory capacity
Ross, 1995 | Soy diet | Platelet-derived growth factor
Saxena, 1999 | Soybean | Platelet factor 3 availability test

Included in this table, for completeness, are 7 studies that evaluated the effect of soy on a miscellaneous collection of biomarkers and outcomes that are unrelated to the health conditions examined in the previous sections. ^185,^ ^188,^ ^213^ – ^217^ No analyses were performed for this group of studies.

## 3.9. Association of Dose and Product Type with Effects

Key Question 3: What is the scientific evidence of a dose-response effect of different forms of soy and individual constituents of soy for the conditions specified in Key Question 1?

Each outcome section in Chapter 3 (3.2–3.8) discusses the evidence for any associations between outcomes and both dose of either soy protein or soy isoflavones and type of soy product. In order to provide clearer answer to the Key Questions on dose-response effect and different product effects, we summarize the evidence here.

### Dose-Response effect

To examine the question of possible dose-response effect we both looked across studies, comparing effects in different studies that evaluated soy products with different doses, and we summarized those studies that directly compared soy products with different doses. The large majority of these studies with direct comparisons compared soy products with the same amount of soy protein but differing amounts of soy isoflavones. Few studies compared soy products with different doses of soy protein.

Overall, across studies, for all examined outcomes, we either found no association between soy dose and treatment effect or the available studies were too few or too heterogeneous to make an assessment. Few of the studies that made direct comparisons found clinically significant or statistically significant difference in treatment effect based on soy protein or isoflavone dose. Below, we summarize the data for each outcome.

#### Cardiovascular

Only for lipids and blood pressure are there sufficient studies to attempt to satisfactorily answer this question using data from across studies. Among the lipid studies (total cholesterol, LDL, HDL, and triglycerides), despite a wide range of treatment effects found across studies and wide ranges of doses of both soy protein and soy isoflavones used, little evidence of a dose-response was found across studies. Meta-regression of the LDL studies did find a statistically significant association between increasing soy protein dose and increasing beneficial effect of soy, but only in the subset of studies with mean baseline LDL greater than 130 mg/dL. However, when studies with minimal soy protein (<10 g/day) were omitted the association disappeared. No association was found between soy protein dose and effect on HDL, triglycerides, or blood pressure. Also, soy isoflavone dose was not associated with effect in any analysis. The 4 studies that directly compared the effect of different doses of soy protein on lipids were inconclusive regarding the association with change in lipid levels. The 14 studies that directly compared the effect of different doses of soy isoflavones on lipids almost all found no association with change in lipid levels. Likewise, across studies of lipoprotein (a) no dose-response effect was found. The 6 studies that directly compared different isoflavone doses and the 2 that compared different soy protein doses also found no association.

Similarly for blood pressure, no difference in effect was seen across studies related to either soy protein or soy isoflavone dose. Only a single study compared different doses of isoflavones and found no difference in effect. For the remaining cardiovascular outcomes examined (CRP, homocysteine, endothelial function, systemic arterial compliance, and oxidized LDL) there were either too few studies or outcome metrics were too heterogeneous to allow for cross-study comparisons of dose. One study compared the effect of different doses of isoflavones on CRP, homocysteine, endothelial function, and oxidized LDL and found no difference for any outcome. An additional study also found no difference in effect on homocysteine with different isoflavone doses.

#### Menopausal Symptoms

Despite the large number of studies that evaluated menopausal symptoms, comparing effects across studies was hampered by the large variety of different outcome metrics used. Nevertheless, no difference in effect was evident based on soy protein or isoflavone dose. Three studies directly compared different doses of isoflavones (2 in peri-menopausal women). Two of the 3 studies reported either clinically or statistically significant differences based on whether the soy product contained isoflavones. In both, consumption of soy protein with isoflavones reduced menopausal symptoms compared to consumption of soy protein without isoflavones. The third study, however, found no difference across a range of isoflavone doses.

#### Endocrine Function

Although only 5 studies reported the effect of soy products on TSH and no difference in effect was evident across studies based on isoflavone or soy protein dose, 2 of these studies compared different doses of isoflavones. Both studies reported larger increases in TSH when subjects consumed higher isoflavone-dose products, although neither reported whether the difference was significantly different than with the lower dose products.

Too few studies evaluated FSH levels in men or pre-menopausal women to assess a dose-effect. Across the 14 studies of FSH in post-menopausal women, though, no dose effect was evident. Two studies that compared different isoflavone-dose products both found decreases in FSH in women on lower dose products and either increases or no effect with higher dose products. Although it is unclear if this difference is meaningful.

Among both pre-menopausal and post-menopausal women, no dose effect was evident for estradiol. The 3 studies that compared different doses of isoflavones likewise found no difference in effect based on dose. There were too few studies of testosterone in men to assess a possible dose effect.

Across studies menstrual cycle length was not affected by soy product consumption, regardless of dose. The one study that compared different doses of soy isoflavones found no dose effect.

#### Osteoporosis and Osteoporosis Risk Factors

Bone mineral density was evaluated after 1 to 2 years of treatment by only 5 studies, precluding meaningful cross-study comparisons. Two of the studies directly compared different doses of isoflavones and found no difference in effect. Likewise, across studies of osteocalcin, bone specific alkaline phosphatase, urinary cross-linked N-telopeptide, urinary pyridinoline, and urinary deoxypyridinoline no dose-effects were evident across studies. One study compared different soy protein doses (of natto) for several of the outcomes and found no consistent or significant differences in effect. The small number of studies of different isoflavone doses also found no difference in effect. With only 2 studies of urinary hydroxyproline, neither of which directly compared different doses, no conclusion about a dose effect can be made.

#### Cognitive Function

The small number of studies and heterogeneity in outcome measures makes cross-study comparisons of dose effect difficult. However, 1 study did report a significantly greater improvement in verbal episodic immediate memory and non-verbal episodic long-term memory with high-isoflavone-dose soy compared to soy without isoflavones.

#### Kidney Function

Only a single study evaluated kidney function with only a single soy product.

#### Glucose Metabolism

No significant effect was seen in any of the small number of studies of glucose metabolism. No study compared different doses.

### Soy Product Effects

Similar to how we evaluated possible dose effects, to compare the effects of different soy products we both looked across studies, comparing effects in different studies that evaluated different soy products and we summarized those studies that directly compared soy products.

No study compared different types of soy products. All studies that compared different soy products compared similar types of products which varied either in amount of total product or dose of either soy protein or soy product. The most frequent comparison was between formulations of isolated soy protein with isoflavones and specifically designed similar isolated soy protein with either all or some of the isoflavones removed. There are no comparisons between different products such as comparing tofu to soy milk or soy milk to isolated soy protein beverages. Given the great heterogeneity among all the studies in terms of such factors as soy protein dosage, soy isoflavone dose, non-soy control, mode of consumption, study duration, and study design, it is not possible to parse out any possible differences across studies based on brand or type of product. Differences based on soy product type defined as soy protein with isoflavones versus soy protein without isoflavones are discussed above where there are relevant data in sections 3.2 to 3.8.

## 3.10. Adverse Events Associated with Soy Intake

(Tables 80–86)

Table 80 Randomized trials that reported adverse events associated with consumption of soy isoflavones (without soy protein)

Author Year | Soy Isoflavones | | Control | | Duration (weeks) | Menstrual Complaints | | GI Complaints | | Withdraw Due to AE | | Other Adverse Events
| N | Description | N | Description | | Soy | Ctrl | Soy | Ctrl | Soy | Ctrl
Parallel Trials
Chen 2003 | 68 | Isoflavones (80 mg/d) | 67 | placebo | 52 | 9 (both groups) | | 20 (both groups) | | | | Headache, bone or joint pain, hand itch, stomach tumor
| 68 | Isoflavones (40 mg/d)
Maskarinec 2002 | 15 | Isoflavones100 mg/d | 15 | placebo | 52 | | | 3 | 2 | 0 | 0 | Isoflavones group: 4 headache/ dizziness Control: 1 headache/ dizziness, 1 breast cancer diagnosis
Morabito 2002 | 30 | Genistein 54 mg/d | 30 | placebo | 52 | 4 | 2
Squadrito 2003 | 30 | Genistein 54 mg/d | 26 | placebo | 52 | 4 | 2
Squadrito 2002 | 30 | Genistein 54 mg/d | 26 | placebo | 24 | 2 | | | | | | Genistein:1 vertigo Control: 1 vertigo, 2 parasthesia
Petri 2004 | 25 | Soy germ 500 mg/d (Isoflavones 60 mg/d) | 25 | placebo | 26 | 2 | 1 | 7 | 2 | 0 | 0
Han 2002 | 40 | Isoflavones 100 mg/d | 40 | placebo | 16 | | | 1 (unclear which group) | | 2 (both groups)
Secreto 2004 | 65 | Isoflavones (80 mg/d) + melatonin | 133 | Placebo or melatonin | 12 | 30 (menstrual spotting) (both groups) | | frequent (both groups) | | 5 | 7 | Tachycardia, weight gain, insomnia, and drowsiness/head-ache
| 64 | Isoflavones 40 mg/d
Upmalis 2000 | 59 | Isoflavones (50 mg/d) | 63 | placebo | 12 | | | | | 1 | | Soy group: 1 urinary infection; placebo: 1 mastodynia. 30/89 reported 70 AEs; Placebo, 39/86 reported 79 AEs
Kumar 2002 | 33 | Genistein 40 mg/d | 33 | placebo | 12 | | | 4 | 4 | 4 | 2 | Control group: 3 weight gain
Cross-over Trials
Nikander 2004 15240647 | 28 | Isoflavones (114 mg/d) | | Placebo | 12 | | 1 | 2 | | 2 | 1 | Cross-over trial: 12 wks IF, 8 wks washout, 12 wks placebo. Dropouts occurred during 1st phase at 8 wks
Simons 2000 | 20 | Isoflavones (80 mg/d) | | Placebo | 8 | 1 | | | 1 chole-cystitis | | | Cross-over trial: 8 wks IF, 8 wks washout, 8 wks placebo. Isoflavones group:1 parasthesia Control:1 parasthesia, 1 head noises
TOTAL | 575 | | 514 | | | 13 | 6 | 16 | 9 | 12 | 10

Table 81 Randomized trials that reported adverse events associated with consumption of soy diets and beverages

Author Year | Soy Diets / Beverages | | Control | | Duration (weeks) | Menstrual Complaints | | GI Complaints | | Withdraw Due to AE | | Other Adverse Events
| N | Description | N | Description | | Soy | Ctrl | Soy | Ctrl | Soy | Ctrl
Parallel Trials
Maskarinec 2004 | 109 | Soy foods(Isoflavones~50 mg/d) (Isoflavones ~50 mg/d) | 111 | Control diet | 104 | ND | | ND | | ND | | Total AEs reported: 37 upper respiatory, 12 musculo-skeletal, 8 menst-rual or GI, 4 head-ache or psycho-logical. 3 women in control during the trial, and 1 on soy afterwards were diagnosed with breast cancer
Lydeking-Olsen 2004 | 23 | Soy milk 500 ml/d (Isoflavones 76 mg/d)+ progesterone | 22 | Progeste-rone | 104 | 7 (both groups) | | 10 | 0 | 6 | 0 | Additional soy AEs: 2 weight gain, 1 throat irritation.
| 22 | Soy milk 500 ml/d (Isoflavones 76 mg/d) | 22 | Placebo
Chiechi 2002 11836040 | 58 | Soy diet (Isoflavones ~40-60 mg/d) | 55 | Control diet | 24 | 2 | 1 | | | 1
Allison 2003 | 37 | ISP (5 ScanDiet shakes/d) | 37 | 1200 kcal diet | 12 | | | 4 (both groups) | | 5 (both groups) | | No serious AEs, but rates of gas or indigestion for soy shakes significant at P<0.001 at 4 & 8 weeks
Verrillo 1985 | 50 | Soy beverage Cholsoy (60 g/d) as diet or supplement | | | 16 | | | 1 | | 1
Knight 2001 | 9 | Soy beverage TakeCare 60g/d (Isoflavones 134 mg/d) | 11 | Casein beverage | 12 | | | 9 (both groups) | | 3 | 1 | Soy total 9 AEs, placebo 12
Puska 2004 | 69 | Soy Yogurt (41.4 g/d) | 74 | Placebo Yogurt | 8 | | | 14 | 3 | 14 | 3 | Reason for withdrawal was “refusal to take more” or AEs Symptoms however were mild
Parallel Trials
Shorey 1981 | 14 | Soy protein diet | 13 | Animal protein diet | 6 | | | | | | | initial increased fecal bulk and flatulence
Rossi 2000 | 10 | Soy beverage (protein 40 g/d genistein 44mg/d) | 10 | Whey | 3 | | | “few” (both groups)
Cross-over Trials
Maki 2002 | 50 | Soy beverage with calcium, vitamins C, D, K and isoflavones Optimize | | CaCO_3_ tablet | 12 | | | | | | | Total AEs: 16, mostly flu-like symptoms
Sirtori 1977 | 6 | Soybean textured protein diet | | “standard low lipid, low cholesterol diet” | 3 | | | 1 | | 1
Schweizer 1983 | 6 | Non-purified soya pulp (fiber 21 g/d) | | | 6 | | | 4
| | Purified soya fiber (fiber 21 g/d)
Sirtori 1985 | 65 | Textured soy proteins replace all animal proteins | | | 8 | | | Occasional & minor
| | Textured soy proteins replace 50% animal proteins
TOTAL | 528 | | 466 | | | 2 | 1 | 30 | 3 | 26 | 4

Table 82 Randomized parallel trials that reported adverse events associated with consumption of soy protein supplements

Author Year | Soy Supplements | | Control | | Duration (weeks) | Menstrual Complaints | | GI Complaints | | Withdraw Due to AE | | Other Adverse Events
| N | Description | N | Description | | Soy | Ctrl | Soy | Ctrl | Soy | Ctrl
Kreijkamp-Kaspers 2004 | 100 | Soy protein 26 g/d (Isoflavones 99 mg/d) | 102 | Total milk protein | 52 | 16 | 16 | 7 | 8 | 12 | 12 | Total soy AEs: 253; 68 musculoskeletal 62 respiratory 29 dermatological Total control AEs:258; 70 musculoskeletal 70 respiratory 28 dermatological
Burke 2002 | 25 | Phytoestrogen supplement 150 mg/d (Soy Isoflavones 120 mg/d) (also dong quai 100 mg, black cohosh 50 mg) | 24 | Placebo | 24 | | | 1 | 3 | 0 | 0 | Phytoestrogens: 1 pruritus
Murray 2003 | 16 | ISP 25 g/d (Isoflavones 120 mg/d) + 2 doses of estradiol | 14 | whey and casein + 2 doses of estradiol | 24 | 1 | 0 | 1 | 1 | 1 | 1 | The abnormal uterine bleeding noted is due to endometrial polyp not detected at baseline. 2 other dropouts due to cervical stenosis (group unclear)
Teede 2001 | 105 | ISP 40 g/d (Isoflavones 118 mg/d) | 108 | Casein | 12 | 1 | | 4 | 4 | 34 (both groups) | | Soy arm: 2 weight gain
Albertazzi 1998 | 51 | ISP 40 g/d | 53 | Casein | 12 | | | 32 | 36 | 7 | 7
Gardner 2001 | 64 | ISP 42 g/d (Isoflavones 0 or 80 mg/d) | 32 | control | 12 | 1 | | 2 | 1 | 2 | 1
Arjmandi 2003 | 20 | Soy supplement 40 g/d (Isoflavones 88.4 mg/d) | 22 | Milk based protein | 12 | | | 2 | 1 | 2 | 1
Vigna 2000 | 51 | ISP 60 g/d (Isoflavones 76 mg/d) | 53 | Casein | 11.8 | 1 | 3 | 7 | 7 | 8 | 10
Burke 2001 | 18 | Soy protein supplement (high protein diet, high or low fiber) (66 g/d) | 18 | Low protein diet (high or low fiber) | 8 | | | | | 3 | | Soy (high protein high fiber): 1 acute illness
Teixeira 2000 | 65 | ISP 20-50 g/d (Isoflavones 33-95 mg/d) | 16 | Casein | 6 | | | | | 8 (both groups) | | 2 of 8 dropouts in the 4 ISP groups described possible allergic reactions
TOTAL | 515 | | 442 | | | 20 | 19 | 56 | 61 | 35 | 32

Table 83 Randomized cross-over trials that reported adverse events associated with consumption of soy protein supplements

Author Year | Soy Supplements | | Control | | Duration (weeks) | Menstrual Complaints | | GI Complaints | | Withdraw Due to AE | | Other Adverse Events
| N | Description | N | Description | | Soy | Ctrl | Soy | Ctrl | Soy | Ctrl
Soy protein: Cross-overs
Jayagopal 2002 | 32 | Soy protein 30 g/d (Isoflavones 132 mg/d) | | Cellulose | 12 | | | 2 | 1 | 1 | 0 | Soy group: 1 myocardial infarction; Control: 1 mouth ulcer
Teixeira 2004 | 14 | ISP 0.5g/kg/d (Isoflavones 2 mg/d) | | Casein | 8 | | | 3 | 2
Steinberg 2003 | 28 | Soy protein 25 g/d (Isoflavones 107 mg/d) | | Total milk protein | 6 | | | 2 (unclear which group) | | 6 (unclear which group)
| | Soy protein 25 g/d (Isoflavones 2 mg/d)
Blum 2003 12659466 | 24 | Soy protein supplement 25 g/d (Isoflavones 85 mg/d) | | Total milk protein | 6 | | | 2 | 4 | 2 | 4
Hermansen 2001 | 20 | ISP 50 g/d (Isoflavones >165 mg/d) | | Casein + cellulose | 6 | | | 1 | | 1 | 1 | Soy: 1 unrecognized brain metastases, 1 liver metastases. Control group: 1 headache
Cuevas 2003 | 18 | ISP 40 g/d (Isoflavones 80 mg/d) | | Caseinate | 4 | | | 6 | 7
TOTAL | 136 | | | | | 0 | 0 | 14 | 14 | 4 | 5

Table 84 Adverse events reported in non-randomized studies (cohorts) of soy

Author Year | N | Soy Product | Duration (weeks) | Menstrual complaints | GI complaints | With-draw due to AE | Other Adverse Events
Medic Ristic 2003 | 106 | Soy powder 20 g/d (7% lecithin, 17% soy protein) | 24 | | | 5 | headache, flatulence, nausea, rash
DeVere White 2004 | 52 | Novasoy 5 g/d (Genistein 450 mg/d + other Iso 450 mg/d) | 24 | | 3
Scheiber 2001 | 42 | Whole soy food (Isoflavones 60 mg/d) | 12 | | 2
Foth 2003 | 16 | Soy protein 20 g/d (Isoflavones 20 mg/d) | 24 | | 2
Pesciatini 1985 | 13 | Soy based diet | 8 | | 1

Table 85 Adverse events reported in safety/pharmacokinetics studies of soy

Author Year | n | Soy (Type, Dose) | Duration (weeks) | Adverse Events | Withdraw due to AE | Comments
Busby 2002 | 30 | Genistein 1 dose (2, 4, 8 or 16 mg/kg body weight) | 4 | AEs include for 2 mg/kg group: 1 lipase, 1 amylase. For 4 mg/kg: loss of appetite, hypophosphatemia, pedal edema. For 8 mg/kg: loss of appetite, lipase, 3 cases hypophosphatemia, abdominal tenderness. For 16 mg/kg: leukopenia | | Safety and pharmacokinetics in healthy men. Isoflavones higher than usually administered
Bloedon 2002 | 24 | Genistein 1 dose (2, 4, 8 or 16 mg/kg body weight) | 4 | AEs include for 2 mg/kg group: 1 pedal edema; for 8 mg/kg: 1 nausea; for 16 mg/kg: 1 pedal edema, 1 breast tenderness | | Safety and pharmacokinetics in post-menopausal women: Isoflavones higher than usually administered.
Takimoto 2003 | 12 | Genistein 1 dose (2, 4, or 8 mg/kg body weight) | 6 | 1 macropapular rash on extremities and face | | Safety and pharmacokinetics in males with prostate or colon cancer. Isoflavones higher than in food.

Table 86 Randomized trials of soy that reported no adverse events

Author, Year | N | Soy (g/d) | Duration (Weeks)
Dragan 1992 | 38 | [underlined: Supro] Soy beverage | 8
Puska 2002 | 30 | Abacor (soy protein 26 g/d) (Isoflavones 4 mg/d) | 6
Crisafulli 2004 | 30 | Genistein 54 mg/d | 52
Alekel 2000 | 24 | Isoflavone-rich soy (Isoflavones 80 mg/d) | 24
Persky 2002 | 23 | Isolated soy protein (Isoflavones 90 mg/d) | 24
Sirtori 1999 | 21 | Soya drink 35 g/d | 4
Sirtori 2002 | 20 | Soya milk 35 g/d | 4
Anderson 2002 | 15 | Isolated soy protein (Isoflavones 90 mg/d) | 52
Uesugi 2002 | 12 | Soy Isoflavone extract (Isoflavones 62 mg/d) | 4
Shige 1998 | 11 | Isolated soy protein 20 g/d | 3
Total | 224

AE= Adverse Events; C=Control; ND= No data; nRCT= non randomized trial

GI includes nausea, bloating, flatulence, diarrhea, abdominal distension, constipation Menstrual includes breast disorders, spotting (menses-like bleeding), other urogenital complaints, such as urinary tract or vaginal infections, and hot flashes

Key Question 4: What are the frequency and type(s) of adverse events associated with use of soy that are reported in the scientific literature (both trials and epidemiology)?

Key Question 5: What is the scientific evidence of a dose-response effect of whole soy products and individual soy constituents on their safety?

We reviewed 272 clinical articles for potentially relevant human data on adverse events associated with soy foods, soy proteins, and other soy products, such as purified isoflavones. These articles included studies of clinical outcomes and risk factors and encompassed RCTs, cross-over studies, non-randomized comparison studies, cohorts and other observational studies among men and women. Most of these studies met eligibility criteria for evaluation of the health effects of soy. However, studies that failed to meet criteria due to such factors as short study duration or small sample size were also reviewed for reporting of adverse events. Of the 272 articles reviewed, 213 of them did not report either the presence or absence of adverse events. Of the remaining 59 articles, a variety of adverse events were reported in 46 studies and 3 safety/pharmacokinetic studies. There were 10 RCTs which explicitly stated that no adverse events occurred. We also reviewed 2,384 abstracts from TOXLINE to identify subsequent reports of adverse events of soy. One additional case control study was identified.

The 49 studies reporting adverse events included 3,518 subjects, about half of whom were exposed to purified isoflavones (Table 80, randomized trials), ^47,^ ^89^ – ^93,^ ^125,^ ^139,^ ^155,^ ^167,^ ^172,^ ^198^ soy-enriched diets or beverages (Table 81, randomized trials) ^62,^ ^63,^ ^67,^ ^79,^ ^136,^ ^165,^ ^200,^ ^218^ – ^223^ or isolated soy protein supplements with and without isoflavones (Table 82, randomized parallel trials, ^52,^ ^55,^ ^77,^ ^78,^ ^81,^ ^103,^ ^117,^ ^133,^ ^170,^ ^224^ and Table 83, cross-over trials ^70,^ ^74,^ ^76,^ ^84,^ ^102,^ ^225^ ). Five single cohort studies (Table 84) ^128,^ ^162,^ ^226^ – ^228^ and 3 safety and pharmacokinetic studies (Table 85) ^229^ – ^231^ also reported adverse events. Ten randomized trials reported only that there were no adverse events (Table 86). ^73,^ ^75,^ ^83,^ ^96,^ ^141,^ ^160,^ ^201,^ ^202,^ ^232,^ ^233^ The comparators in the studies included milk, milk protein powders, whey, casein, and other placebos. The amount of soy protein in the trials ranged from 20 to 60 g/day, and isoflavones from 40 to 134 mg/day.

We did not perform meta-analysis on any of the adverse events because of the heterogeneity and inadequate reporting across the studies. Meta-analysis would lend a level of precision that is unwarranted given the poor quality and poorly detailed and overall reporting of the data. Instead we simply provide a crude percentage of the events in the text.

Two trials reported a large number of adverse events. In one study, 202 post-menopausal women in an RCT by Kreijkamp-Kaspers 2004 ^78^ (Table 82) consumed either 25.6 g of soy protein enriched with 99 mg isoflavones or 25.6 g of milk protein for 1 year. The authors reported 511 adverse events, almost equally divided between soy and placebo groups. The adverse events were recorded every 3 months. There were a total of 48 GI complaints for soy and 33 for placebo. Each arm reported 16 urogenital complaints (urinary tract or vaginal infections). The mean number of any adverse events per participant was 2.54 in the soy group and 2.56 in the placebo group. There were no differences in types of adverse events (musculoskeletal complaints, urogenital, dermatological, respiratory, and miscellaneous) or in the rates of drop-out between the 2 groups.

The RCT by Maskarinec 2004 (Table 80) also reported a large number of adverse events, 126 in the soy group and 157 in the control. ^165^ There were 111 healthy pre-menopausal women who consumed either 2 daily servings of soy foods containing about 50 mg per day isoflavones or a regular diet for 2 years. The authors concluded that there was no evidence for adverse effects due to soy. They reported that collectively there were 96 upper respiratory infections, 31 musculoskeletal, 23 gynecologic or GI disorders, 11 headaches or psychological symptoms, the remaining being skin conditions, bladder infections, asthma, dental problems, high blood pressure, and diabetes. However, it is unclear how these events were distributed in the two groups. In addition, 3 women in the control group were diagnosed with breast cancer during the study and one woman in the intervention group developed breast cancer after the completion of the study.

The range of durations across studies that reported adverse events was 2 weeks to 2 years. The majority of studies evaluated a few dozen subjects for 4 to 24 weeks. Generally, the trials that reported the highest rates of adverse events were those that lasted from 1 to 2 years; however, several studies of considerably shorter duration had similar rates of adverse events. For example, among the isoflavone intervention studies (Table 80), Chen 2003 ^198^ reported 29 adverse events after 1 year, but Secreto 2004 ^139^ reported more than 30 after 12 weeks in a similar number of subjects. A stronger predictor of total number of adverse events than study duration appeared to be how frequently subjects were asked to record incidents.

## Gastrointestinal Disturbances

Gastrointestinal (GI) disturbances were the most frequently reported adverse events. These included diverse symptoms such as heartburn, stomach pain or disorder or discomfort or swelling, abdominal distension, bloating, flatulence, constipation, or diarrhea, which occurred in 30 of the 41 comparison studies and in 4 of the 5 cohorts. Specifically, for the 12 isoflavone trials (Table 80) there were 16 GI complaints in the soy arms out of a total of 575 (2.8%) compared to 9 out of 514 controls (1.8%); in the 13 soy diet and beverages studies (Table 81) there were 30 GI complaints out of a total of 528 subjects (5.7%) versus 3 in the control arms (0.1%); for the 16 soy protein randomized parallel trials (Table 82) there were 56 GI complaints out of 515 subjects (10.8%) versus 61 out of 442 in the usually casein-containing control arms (13.8%). In the cross-over trials of soy protein supplements (Table 83) the same numbers of subjects overall had GI complaints during both soy and control phases of the trials.

Overall, there were a larger number and higher rate of adverse events for the soy groups versus the controls, and there were slightly more withdrawals from the soy arms due to taste aversion. However, estimation of GI disturbances was hampered because categorization and reporting of adverse events varied widely among studies and no article used standardized definitions of serious adverse events. Some studies combined nausea and gastric pain, or constipation and gastric discomfort, or headache, flatulence, nausea, dizziness, and rash, while others limited reporting to “GI disturbances” or “GI side effects.”

Of note, 1 case control study by Gunn 1980 from Los Angeles reported an outbreak of 508 afebrile GI illnesses in 1976 associated with consumption of a commercially marketed soy protein extender used in tunafish salad. ^234^ Extensive laboratory testing failed to identify any biological, chemical, or toxic agent. Significantly more cases than controls had a history of allergy (P<0.02). The authors concluded that consumption of textured soy protein may cause adverse GI symptoms in a small number of individuals.

## Menstrual Complaints

Menstrual complaints included breast tenderness and other breast disorders, spotting (menses-like bleeding), other urogenital complaints, such as urinary tract or vaginal infections, and hot flashes. These complaints occurred in 15 of the 43 comparison studies, especially in the isoflavone (genistein 54 g/d) trials in post-menopausal women, but in none of the cohorts. In the 12 isoflavone trials (Table 80) there were, in total, 13 menstrual complaints in the isoflavone interventions versus 6 with controls. The control arms often included hormone therapy regimens such as estrogen/progestin therapy, but adverse events associated with these treatments are not recorded; hence the numbers for menstrual complaints in these parallel trials cannot be compared. In the 13 soy diet and beverage trials (Table 81) there were 2 menstrual complaints in the soy arms versus 1 in the control arms. In the 16 soy protein randomized parallel trials (Table 82) there were 20 menstrual complaints in the soy arms versus 19 in the controls. No subjects had menstrual complaints in the cross-over studies of soy protein supplements (Table 83).

## Other Adverse Events

No study reported death or life-threatening illness associated with soy intake.

Other adverse events that were commonly reported included headache, dizziness, musculoskeletal complaints, weight gain, and rashes. Definitions for these observed adverse events were seldom provided. In addition, adverse event rates were reported frequently as a number or sometimes as a percentage of patients with symptoms. In some studies, adverse events were reported without differentiating by treatment assignment. Other studies did not report adverse events in specific patients who withdrew from the studies.

## Other Reports

Three safety/pharmacokinetics articles on purified soy isoflavones were identified (Table 85). They generally concluded that dietary supplements administered as single doses that exceeded normal dietary intake by many-fold results in minimal clinical toxicity. These studies were performed in healthy males, males with prostate or colon cancer, and post-menopausal women.

## Drug Interactions

Five studies reported serious interactions with concurrent medications: 2 interfering with warfarin, 1 with levothyroxine, 1 with oral contraceptives, and 1 with hormone replacement therapy.

In a case report, Cambria-Kiely 2002 ^235^ observed a 70 year old man with atrial fibrillation who was stable on warfarin therapy 3 mg per day who developed subtherapeutic international normalized ratio (INR) values after ingesting soy milk. In a case series, Gaddi 1991 ^236^ observed 10 hypercholesterolemic patients who were treated with different doses of warfarin after by-pass surgery. After 4 weeks of a soy protein diet there was a marked increase in all patients of prothrombin time: a mean increase of 114% after 2 weeks and a further increase of 2.6% during the next 2 weeks.

In a case report, Bell 2001 ^237^ observed a 45 year old woman who had hyperthyroidism after a near-total thyroidectomy and radioactive iodine ablative therapy for papillary carcinoma of the thyroid. Routine “soy cocktail” protein supplements caused decreased absorption of levothyroxine.

Martini 1999 ^176^ reported that 1 oral contraceptive user withdrew from a trial because, despite reporting regular periods before entry to the study, she had highly irregular periods while on the study.

In a safety and pharmacokinetics study involving 24 healthy post-menopausal women, Bloedon 2002 ^230^ observed in the 8 women on hormone replacement therapy a mean increase of 30.4 U/L in lipase on day 3 after treatment with isoflavones, whereas lipase among the 16 subjects not on hormones had a mean decrease of 5.2 on day 3 (P=0.005). No other statistically significant dose-response effects were seen.