# Methods

## Overview

This evidence report on the health effects of soy is based on a systematic review of the literature. The Tufts-New England Medical Center Evidence-based Practice Center (Tufts-NEMC EPC) held meetings and teleconferences with a technical expert panel (TEP) to identify specific issues central to this report. The TEP was comprised of technical experts in soy research and in relevant health areas of interest. A comprehensive search of the medical literature was conducted to identify studies addressing the key questions. Evidence tables of study characteristics and results were compiled, and the methodological quality and the applicability of studies were appraised. Study results were summarized with both qualitative and quantitative reviews of the evidence, summary tables, and meta-analyses, as appropriate.

A number of individuals and groups supported the Tufts-NEMC EPC in preparing this report. The TEP served as our science partner. It included technical experts, representatives from the Agency for Healthcare Research and Quality (AHRQ) and from the National Center for Complementary and Alternative Medicine (NCCAM) and the Office of Dietary Supplements at the National Institutes of Health (NIH). The TEP worked with the EPC staff to refine key questions, identify important issues, and define parameters for the report. Additional clinical domain expertise was obtained through local experts who joined the EPC. A draft version of this report was critically appraised by a panel of peer reviewers.^*^ Revisions were made based on their comments; although all statements within the report are those of the authors only.

Appendix D (Peer Reviewers) is available electronically at www.ahrq.gov/clinic/tp/soytp.htm.

## Key Questions Addressed in this Report

1. In the clinical trial literature, what formulations of soy were used? At what dose? For what purpose(s) (e.g., trial endpoints)? (Section 3.1)
2. Does current clinical trial evidence indicate that whole soy products and individual constituents of soy have an effect on (Sections 3.2–3.8):
  a. cardiovascular events, risk factors, and measures;
  b. menopausal symptoms;
  c. endocrine function;
  d. cancer and tumor-related biomarkers;
  e. osteoporosis and osteoporosis risk factors;
  f. reproductive health;
  g. kidney function; and
  h. other outcomes, based on results of Key Question 1 above?
3. What is the scientific evidence of a dose-response effect of different forms of soy and individual constituents of soy for the conditions specified in Key Question 1? (Section 3.9)
4. What are the frequency and type(s) of adverse events associated with consumption of soy that are reported in the scientific literature (both trials and epidemiology)? (Section 3.10)
5. What is the scientific evidence of a dose-response effect of whole soy products and individual soy constituents on their safety? (Section 3.10)

## Approach to Analyzing the Literature

The key questions in this report sought to discover the breadth and depth of soy research that has been conducted in humans to assess its effect on various health outcomes. This information will be used by NCCAM and the Office of Dietary Supplements to help identify research opportunities in soy. As the focus of the report is not to elaborate the effect of soy on a specific health condition, a single causal pathway or analytic framework is not appropriate for this report. Figure 1 in Chapter 1 illustrates the diverse potential mechanisms of soy on various health conditions.

To guide the assessment and synthesis of the literature, we used an expanded version of the generally-referred-to “PICO” method (Participants, Intervention, Comparator, Outcomes) to define the parameters of interest. With input from the TEP, we asked the following questions to establish the literature review criteria:

- What are the populations of interest?
- What are the interventions of interest?
- What are the comparators of interest?
- What are the (marker/intermediate and clinical) outcomes of interest?
- What are the health conditions of interest?
- What are acceptable study designs?

### Inclusion Criteria

This report encompasses several health conditions and many outcomes of interest. Therefore, specific inclusion criteria were needed for each of the health conditions and sometimes for different outcomes of the same health condition. In this section, we first describe the common inclusion criteria for any study included in this report, regardless of the health condition evaluated. This is followed by additional specific criteria for each of the health conditions.

The common inclusion criteria for studies analyzed in this report consist of: human subjects 13 years and older; prospective studies including randomized controlled trials, cohorts (including prospective epidemiological studies), cross-over and non-randomized comparison studies; at least 5 subjects in the soy arm; any health condition; quantification of the amount of soy; and reported outcomes of interest. In general, the minimum duration for all serum marker, urine marker, and vascular outcome studies was 4 weeks (exceptions are noted below, under Specific Inclusion Criteria for Health Conditions Examined).

For assessments of adverse events, we also included prospective observation studies and case-control studies, with no limitations on study size or duration, or quantification of soy product.

#### Health Conditions of Interest

In addition to the health conditions of interest listed under Key Question 3, the TEP suggested the category of neurocognitive outcomes. NCCAM and the Office of Dietary Supplements were also interested in knowing about research that might have been done in other health conditions. Therefore, our literature search was conducted to broadly include soy studies for any health conditions. We screened all citations to identify health conditions not on the list agreed upon with the TEP.

During our review process, we created the category of endocrine outcomes, which incorporates many of the reproductive hormones and potential cancer risk factor studies.

#### Soy Products (and Controls) Considered in this Report

We accepted studies that used soy supplements and foods that quantified the amount of soy ingredients or products. We categorized various soy products and soy foods into the following groups:

- Refined soy products
  - Isolated soy protein with isoflavones
  - Isolated soy protein without isoflavones
  - Textured soy protein
  - Soy derived isoflavone
    - genistein/genistin
    - daidzein/daidzin
    - glycitein/glycitin
- Soy/soya food products (ingested amount must be quantified)
  - Whole soy beans (edamame)
  - Soy flour
  - Soy drink (soy milk)
  - Tofu (bean curd)
  - Miso
  - Other processed soy bean products (tempeh, natto, okara, etc.)

We also categorized studies based on whether the soy products were consumed in the form of a supplement or as part of the overall diet. In general, we relied on the studies' descriptions of the products and their use to make this determination. The categorization of soy milk, however, was problematic as approximately equal numbers of studies described its consumption as either a dietary replacement of other beverages or as a supplement to be added to subjects' regular diet; many studies reported insufficient details to determine how the soy milk was being used. In consultation with the TEP, we (arbitrarily) categorized all soy milk studies as supplement studies, in order to standardize our evaluation. Where necessary, sensitivity analyses were done regarding this categorization.

For the purpose of this report, all study arms with a soy product of any type were considered to be soy interventions. Only study arms with a non-soy intervention were categorized as controls. This is in contrast to many studies that considered soy protein without isoflavones to be the control. Since we were interested in the effect of both soy protein and soy isoflavones, we categorized these study arms as soy interventions.

#### Specific Inclusion Criteria for Health Conditions Examined

In addition to the above common inclusion criteria, with input from TEP members we established the following additional criteria and specific outcomes for each of the specific health conditions.

Cardiovascular outcomes

We included in our analyses cardiovascular outcomes listed in 5 in Chapter 3. We also sought studies of clinical cardiovascular outcomes (e.g., death, myocardial infarction, angina) but found none. The list of outcomes was determined in consultation with the TEP. The decisions for which outcomes to investigate were based on expert opinion of the likelihood of an effect on the outcomes, clinical importance, and estimates of the numbers of studies likely to be available.

Because of the relatively large number of available studies reporting on lipids, triglycerides, and blood pressure, it was decided with the TEP to limit inclusion of these studies to randomized controlled trials with a minimum of 10 subjects consuming a soy product. For all cardiovascular outcomes, we required a minimum duration of 4 weeks.

Menopausal Symptoms

We evaluated studies of peri-menopausal and post-menopausal women for menopausal symptoms. A minimum duration of 4 weeks was required for studies of menopausal symptoms.

Endocrine Function

We included in our analyses the following endocrine outcomes: testosterone, follicle stimulating hormone (FSH), total estradiol and thyroid stimulating hormone (TSH). Because menstrual cycle length is directly related to female reproductive hormones, this outcome is included in this section. The decisions for which outcomes to investigate were based on expert opinion of the likelihood of an effect on the outcomes, clinical importance, and estimates of the numbers of studies likely to be available. Studies that did not report numerical data on effect for these outcomes were not summarized; however, these studies were maintained in the database. For all endocrine outcomes, we required a minimum duration of 4 weeks.

Cancer and Tumor-Related Biomarkers

To evaluate whether soy may prevent cancer or reduce cancer risk factors, we included only studies that recruited subjects without a diagnosis of cancer. We did not include studies that used soy products as “treatments” for cancer. We limited our analyses to studies with tumor-related biomarkers or cancer risk factors as outcomes and to studies of clinical cancer outcomes (e.g., diagnosis of prostate cancer). The only outcome that fulfilled these criteria was testosterone. The studies that reported testosterone as an outcome in men without diagnoses of cancer were analyzed in the endocrine section. The decision to investigate only testosterone was based on expert opinion of the likelihood of an effect on the outcomes, and clinical importance. For all tumor-related biomarkers, we broadened the eligibility criteria to include a minimum duration of 1 week.

Bone outcomes

For bone resorption and/or formation biomarkers, general inclusion criteria were used, including a minimum duration of 4 weeks. Because effects on bone mineral density occur slowly over time, we used minimum study duration of 1 year; although we did briefly review studies of less than 12 months.

Miscellaneous outcomes

For all other outcomes (neurocognitive, kidney, glucose metabolism), the general inclusion criteria were used in combination with the restriction to populations without the related specific diseases or conditions. Thus, studies of cognitive function outcomes were restricted to populations without Alzheimer's disease, dementia, or mental retardation at baseline. Studies of kidney function outcomes were restricted to those populations without kidney disease at baseline. Studies of glucose metabolism were restricted to populations without diabetes.

Reproductive health

Based on the included studies in our systematic review, outcomes that could address reproductive health issues in men and women are hormones related to fertility status as well as menstrual cycle length in women, which is used in the initial assessment for female infertility. The goal of the initial infertility evaluation of the couple is to determine the likely cause of the infertility and to determine the most logical approach to treatment. The initial evaluation for male factor infertility should include a reproductive history and two properly performed semen analyses. An initial endocrine evaluation should include at least a serum testosterone and FSH. Endocrine evaluation should be performed if there is: (1) an abnormally low sperm concentration, especially if less than 10 million/mL; (2) impaired sexual function; or (3) other clinical findings suggestive of a specific endocrinopathy. The initial evaluation for female factor infertility should include a reproductive history and documentation of ovulation, which is usually done with over the counter ovulation kits. An initial endocrine evaluation includes day three FSH level and estradiol.

### Exclusion Criteria

We excluded studies that investigated soy products that were mixed with other potentially active ingredients (e.g., soy and fish oil) where the effect of the soy could not be separated from the other ingredients. Studies that compared combinations to similar products without soy (e.g., soy + estrogen vs. estrogen) were included. We also excluded soy products that are used as an ingredient of enteral feedings. In addition, we excluded the following studies:

- Review articles (no primary data)
- Non-trial observational studies
- Animal or in vitro studies
- Age less than 13 years
- Not English language
- Fewer than 5 subjects in the soy arm of the trial (unless adverse event reported)
- Ingested soy amount not quantified
- Not soy, soy protein, soy isoflavone
- Insignificant amount of total daily protein or isoflavones in the soy product (e.g., soy sauce, soy oil; case by case determination was made in collaboration with technical experts)
- Mixed soy product or nutrition/diet drink (e.g., brands such as Boost, Ensure, GeniSoy, Met-Rx, Revival Soy, Slim Fast) where other active ingredients may be present
- Studies that report serum or urine levels of isoflavones or amino acids achieved instead of amount ingested
- Study of serum or urine isoflavone levels without data on clinical outcomes or risk factors
- Studies that evaluated only soy allergies
- No outcome of interest

## Literature Search Strategy

We conducted a comprehensive literature search to address the key questions.^*^ Primary literature searches for English language publications on soy studies were conducted in EMBASE on March 25, 2004, in MEDLINE on April 20, 2004, and in CAB Abstracts on June 24, 2004. Search terms included subject headings and textwords with filters to limit the publications to English language and primary studies of the adult and adolescent human populations. Subject headings and text words were selected so that the same set could be applied to each of the different databases. A supplemental search was performed in MEDLINE on April 30, 2004 to retrieve articles using the textword “miso”. A search update was performed in MEDLINE In-Process & Other Non-Indexed Citations and MEDLINE on September 30, 2004, and CAB Abstracts on October 4, 2004. A search of the TOXLINE database was conducted in March 31, 2005 to identify additional reports for adverse events in humans. Additional studies were sought by contacting members of the TEP, and from reference lists of selected review articles and meta-analyses.

Appendix A (Search Strategy) is available electronically at www.ahrq.gov/clinic/tp/soytp.htm.

## Study Selection and Data Extraction

All citations identified through the literature search were screened according to the inclusion criteria. A low threshold for acceptance was used at this stage to maximize the retrieval of potentially useful studies. Retrieved articles were evaluated against the complete inclusion criteria.

A single reviewer extracted each eligible study.^†^ Data extraction problems were addressed during weekly meetings. Occasional sections were re-extracted to ensure that uniform definitions were applied across extracted studies. Problems and corrections were noted through spot checks of extracted data and during the creation of summary and evidence tables. A second reviewer independently verified the data in the summary tables using the original article. Items extracted included: factors related to study design (randomization method, allocation concealment method, blinding, study duration, and funding source), population characteristics (country, eligibility criteria, demographics, co-morbid conditions, concomitant medications, and baseline diet), interventions and comparison groups (description of soy product and control interventions or diets, including amount of specific protein), outcomes of interest (number enrolled and analyzed, intermediate and clinical outcomes, adverse events, reasons for withdrawals, results [including baseline value, final value, within-treatment change or between-treatment difference, and variance, as reported]), and whether each study addressed each of the key questions. In addition, each study was categorized based on applicability and study quality as described below.

Appendix B (Data Extraction Form) is available electronically at www.ahrq.gov/clinic/tp/soytp.htm.

## Grading of the Evidence

Studies accepted in evidence reports have been designed, conducted, analyzed, and reported with varying degrees of methodological rigor and completeness. Deficiencies in any of these components can lead to biased reporting and interpretation of the results. While it is desirable to grade individual studies to highlight the degree of potential bias, the grading of study quality is a challenging process. Most factors commonly used in quality assessment of randomized controlled trials do not demonstrate a consistent relationship to estimates of treatment effects. ^39^ Thus, there is still no uniform approach to grade studies. Our EPC has adopted the following approach in our previous evidence reports.

### Methodological Quality Grade

We used a 3-category grading system (A, B, C) to denote the methodological quality of each study. This grading system has been used in most of the previous evidence reports from the Tufts-NEMC EPC as well as in evidence-based clinical practice guidelines. ^40^ This system defines a generic grading system that is applicable to varying study designs including randomized controlled trials, cohort, and case-control studies:

A. Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized study; clear description of the population, setting, interventions and comparison groups; sufficient power (arbitrarily defined as minimum sample size of 30 subjects); clear description of the content of the intervention used (including both amount of soy protein and amount of soy isoflavones); appropriate comparator (with similar amount and distribution of fats); appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; double-blinding; no reporting errors; less than 20% dropout; clear reporting of dropouts; and no obvious bias.

B. Category B studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.

C. Category C studies have significant bias that may invalidate the results. These studies have serious errors in design, analysis or reporting, have large amounts of missing information, or discrepancies in reporting. Specific criteria included large (>20%) or unequal dropout rate, large discrepancy in baseline and final numbers of subjects, non-randomized or single-cohort studies, dissimilar baseline values among cohorts, unclear duration or numbers of subjects, missing baseline data, or irreconcilable apparent differences between data in figures, tables, and text.

Where different quality criteria applied to different outcomes within a study (e.g., missing baseline data for a specific outcome), quality grades may differ for different outcomes within the same study. In addition to applying these 3 grading systems, additional comments relating to potential sources of bias and other study limitations were recorded by each investigator during the data extraction process. Such comments are included in the evidence tables.

Methodological quality scoring was performed near the end of the review when we had the most experience and knowledge about the included studies. Each included study was graded by at least 2 people (with the exception of studies with major deficiencies, such as a non-comparative study design). When there were disagreements, 1 or 2 additional reviewers graded the studies and consensus was reached. Approximately half the studies had quality scoring by 3 or more reviewers.

### Applicability Grade

Applicability addresses the relevance of a given study to a population of interest. Every study applies certain eligibility criteria when selecting study subjects. Most of these criteria are explicitly stated (e.g., disease status, age, sex). Some may be implicit or due to unintentional biases, such as those related to study country, location (e.g., community vs. specialty clinic), or factors resulting in study withdrawals. The question of whether a study is applicable to a population of interest (such as Americans) is distinct from the question of the study's methodological quality. For example, due to differences in the background diets, an excellent study of Japanese men may be very applicable to people in Japan, but less applicable to Japanese American men, and even less applicable to African American men. The applicability of a study is thus dictated by the questions and populations that are of interest to those analyzing the studies.

In this report, the focus is on the US population and on specific subgroups within that population (i.e., post-menopausal women, peri-menopausal women, pre-menopausal women, men, and people with relevant medical histories, such as breast cancer). Even though a study may focus on a specific target population, limited study size, eligibility criteria, and the patient recruitment process may result in a narrow population sample that is of limited applicability, even to the target population. To address this issue, we categorized studies within a target population into 1 of 3 levels of applicability that are defined as follows:

[image] Sample is representative of the target population. It should be sufficiently large to cover both sexes (as appropriate for a given outcome), a wide age range, and other important features of the target population (e.g., background diet).

[image] Sample is representative of a relevant sub-group of the target population, but not the entire population. Limitations include such factors as narrow age range, single ethnicity, narrow range of risk for relevant diseases (e.g., hyperlipidemia).

[image] Sample is representative of a narrow subgroup of subjects only, and is of limited applicability to other subgroups. For example, a study of the oldest-old men or a study of a population on a highly controlled diet.

## Reporting Results

### Results of Comparative Studies

Most of the outcomes of interest were continuous variables such as blood pressure and lipid levels. For these outcomes, the summary tables describe 3 sets of data: the mean baseline level in the soy arm, the net change of the outcome, and the reported P values of the difference between the soy and the control arms. The net change of the outcome is the difference between the change in the soy arm and the change in the control arm:

Net change = (Soy_Final_ - Soy_Initial_) - (Control_Final_ - Control_Initial_).

While some studies reported adjusted and unadjusted within-arm and between-arm (net) differences, to maintain consistency across studies, we calculated the unadjusted net change using the above formula for all studies when the data were available. All exceptions and caveats are described in footnotes to the summary tables.

We included only reported P values for the net differences. We did not calculate any P values, but, when necessary, used provided information on the 95% confidence interval or standard error (SE) of the net difference to determine whether it was less than 0.05. We included any reported P value less than 0.10. Those above 0.10 and those reported as “non-significant” were described as “NS” (non-significant) in the tables.

For measures expressed using standard or Systeme International (SI) units (e.g. lipid levels), the original units reported in the study were included in the evidence tables. However, all such measurements were converted to standard units in the summary and results tables to facilitate comparisons.

### Meta-Analysis

Meta-analysis was performed for several cardiovascular outcomes. We used the random effects model for continuous outcomes to combine studies. Studies were included only if they reported sufficient data to estimate both mean net change (or mean within-cohort change for specific sub-analyses) and SE of the net change (or of the within-cohort change).

The random effects model assigns a weight to each study that is based both on the individual study variance and the between-study heterogeneity. Compared with the fixed effect model, the random effects model is more conservative in that it results in broader confidence intervals when between-study heterogeneity is present.

For the meta-analyses, we required data on both the mean change in outcome level and the SE of the change. However, many studies provided only the SEs for the baseline and final outcome levels. In order to include these studies in analysis we had to make several assumptions to estimate the SE of the change. To do this we used the equation:

SE_12_ = √ (SE_1_ ^2^ + SE_2_ ^2^ - 2 x ρ x SE_1_ x SE_2_)

where SE_1_, SE_2_, and SE_12_ are the SEs for baseline, final and change, respectively, and ρ is the correlation between SE_1_ and SE_2_. ^41^ We arbitrarily chose the correlation, ρ, to be 0.50, the mid-point value. In our experience, using different values for ρ generally results in similar estimates of SE.

For each soy cohort, the SE of the net change was then calculated using the standard calculation for determining the SE of 2 independent cohorts. Namely the above equation where the correlation factor ρ = 0 and thus the final term drops out. Where studies reported either within-cohort SEs or net change SEs, these numbers were used.

An important caveat in our analyses is that for studies with multiple soy cohorts but single non-soy cohorts, we assumed that the estimated net changes (and their SEs) are independent of each other despite their shared control groups. In addition, we made a number of “corrections” to the reported data where there were apparent errors (such as reporting standard deviation as SE or reporting mean values and SEs in different units [e.g., mg/dL and mmol/L]). Where within-cohort or net changes were reported graphically, we preferentially used tabulated data for baseline and final values; although we estimated values and SEs from graphs when necessary. Net changes reported as percentage changes were ignored when baseline values from the soy and non-soy cohorts were not identical.

Meta-analyses were performed for all eligible studies of low density lipoprotein (LDL), high density lipoprotein (HDL), triglycerides, and blood pressure. These outcomes were chosen for meta-analysis based on potential clinical relevance and the number of available studies.

#### Subgroup and Meta-Regression Analyses

To explore potential reasons for differences of results across studies and to evaluate possible dose-effects, we performed several meta-regressions analyses with the continuous variables soy protein dose, soy isoflavone dose, and mean baseline outcome value. We used a random-effects regression model as described by Berkey et al. ^42^ This model adjusts each study's weight in the regression by the degree of heterogeneity across all included covariates. Both multivariate and univariate analyses were performed. When appropriate, sub-analyses were performed to explain factors related to the meta-regressions.

In addition, we performed sub-group meta-analyses based on the following sub-groups, when appropriate:

- Study treatment arms with normal versus abnormal mean baseline outcome values (e.g., LDL less than and greater than 130 mg/dL)
- Study treatment arms with different types of soy products:
  - Protein with isoflavone
  - Protein with isoflavone (without soy milk)
  - Soy milk
  - Protein without isoflavone
  - Isoflavone alone
- Study treatment arms where soy was consumed as dietary replacement and as a supplement
- Study quality A or B versus quality C
- Outlier studies omitted.

In order to complement a previously published meta-analysis, ^43^ we also performed a meta-analysis of

- High versus low dose soy isoflavones treatment arms among studies that investigated multiple isoflavone doses
  - All high-dose cohorts versus lowest dose
  - Only highest-dose cohort versus lowest dose

For all outcomes, when there were sufficient studies, we examined all these same factors, in addition to study population and sex (when relevant) to determine if there was evidence of a differential effect based on these factors. We also specifically evaluated studies that either performed direct comparisons between treatments or reported sub-group analyses. In consultation with the TEP, it was decided to not evaluate equol-production status of study subjects. This decision was made based on the current lack of applicability of any findings of differences between equol producers and non-producers, since no one outside soy studies knows their equol production status.

### Evidence and Summary Tables

The evidence table offers a detailed description of the studies that addressed each of the key questions. The evidence table is available via the internet.^*^ The table provides information about the study design, patient characteristics, inclusion and exclusion criteria, interventions evaluated, and comparison groups evaluated. Each study appears once regardless of how many interventions or outcomes were reported. Studies are ordered alphabetically by the first author, then by publication date, then by MEDLINE unique identifier number.

Appendix C (Evidence Table) is available electronically at www.ahrq.gov/clinic/tp/soytp.htm.

Summary tables are included in each Results section. They succinctly report summary measures of the main outcomes evaluated. They include information regarding study duration, study size (of subjects analyzed), intervention and control, outcome measures, study population, and methodological quality, and study applicability. These tables were developed by condensing information from the evidence tables. They are designed to facilitate comparisons and synthesis across studies. Studies reporting multiple outcomes may appear several times in summary tables.

Description of the soy interventions includes quantification of the amount of aglycone isoflavones and the amount of soy protein, when available. When studies did not specify whether measured isoflavones were aglycones or glucosides, or when studies reported only glucoside amounts, this is indicated in the footnotes. Outcome units and metrics are reported in standard units and as in common metrics, regardless of how these were reported in the articles. These tables include baseline values of relevant outcomes, within-cohort changes (Final - Baseline) in these values, reported P values of the within-cohort changes, net changes compared to control (as defined above, under Results of Comparative Studies), and reported P values of the net changes. In addition, reported P values of differences in effect between different soy treatment arms are included. Within-cohort and net changes were calculated from reported data when necessary (these values are italicized). Blank cells indicate that the relevant data were not reported in the articles.

Studies are categorized and ordered as follows. Diet studies are above supplement studies; randomized cross-over studies are above randomized parallel controlled trials, which are above non-controlled or other non-randomized studies; studies that used dairy controls are above animal protein or usual diet controls, which are above miscellaneous controls, which are above studies with no non-soy control. Within each of these categories, studies are ordered from largest to smallest number of subjects consuming soy products.

### Adverse Events Reporting

We used the term adverse event as defined by the World Health Organization (WHO) International Conference on Harmonization. An adverse event is “any untoward medical occurrence in a patient or clinical investigation subject administered a pharmaceutical product and which does not necessarily have to have a causal relationship with this treatment. An adverse event can therefore be any unfavorable and unintended sign (including an abnormal laboratory finding, for example), symptom, or disease temporally associated with the use of a medicinal product, whether or not considered related to the medicinal product.” An adverse drug reaction is any “noxious and unintended response to a medicinal product related to any dose…” (www.fda.gov/cder/guidance/iche2a). For the purpose of this report, soy or soy ingredient is substituted for pharmaceutical product. We reviewed all accepted and rejected human studies in the analyses of soy effects for data on adverse events and drug interactions. These reports included randomized trials, cohorts, case-control studies, and individual case reports and series. We excluded articles that reported “bad taste”, “aftertaste”, or “lack of palatability” as adverse events as well as those that reported negative conclusions such as “there were no immunological effects” or “there was no increase in pancreatic size”. While adverse events attributable to soy in animal studies and changes in biomarkers in in-vitro studies might be indicative of potential toxicities in humans and would be useful in the overall evaluation of safety issues, the review of this body of literature is beyond the scope of this report.

We summarized adverse events in several tables. Adverse events were grouped according to the study design and the type of soy product used. In these tables we report for each study the data on the number of subjects, trial duration, interventions and controls, and the adverse events. Based on the adverse event data we compiled, we grouped them into menstrual-related and gastrointestinal-related complaints, withdrawals due to any effects, and a miscellaneous category. A separate table was created for studies that stated that no adverse events occurred.