# Introduction

This evidence report has been prepared by the Tufts-New England Medical Center (Tufts-NEMC) Evidence-based Practice Center (EPC) concerning the effect of soy consumption on various diseases and conditions, including but not restricted to cardiovascular, kidney and gastrointestinal diseases, cancer, osteoporosis, menopausal symptoms, and reproductive health. This report was requested and funded by the National Center for Complementary and Alternative Medicine (NCCAM) and the Office of Dietary Supplements of the National Institutes of Health (NIH), through the EPC program at the Agency for Healthcare Research and Quality (AHRQ).

There is increasing interest in soy and health since the U.S. Food and Drug Administration (FDA) approved a health claim in October 1999 for use on food labels stating that a daily diet containing 25 grams of soy protein, also low in saturated fat and cholesterol, may reduce the risk of heart disease. This claim was based on the beneficial results in reducing plasma low-density lipoprotein (LDL) levels from dozens of human controlled clinical trials. ^1^ The health claim, however, covers only soy protein, since research results surrounding soy isoflavones were controversial. ^2^ The aims of this report are to summarize the formulations of soy products and/or soy food used in clinical trials, and to reflect the current evidence on the health effects of soy and its isoflavones on the following: cardiovascular disease (CVD), menopausal symptoms, endocrine function, cancer, bone health, reproductive health, kidney disease, cognitive function, and glucose metabolism. In addition, safety issues and drug interactions of using soy and its isoflavones as reported in the literature are summarized.

## Metabolism and Mechanisms of Actions of Soy and Its Isoflavones

Soy is a legume commonly consumed by many Asians, although most Americans do not regularly eat it. Despite the increase in the consumption of soy products since the approval of the soy health claim in 1999, only a small number of Americans who believe that soy consumption is “healthy” consume soy products at least once a week, according to a survey by the United Soybean Board. ^2^ Soybean and soy foods, such as tofu, tempeh, soy drinks, soy flours, and meat alternatives or analogs, are rich in soy protein and soy isoflavones. The isoflavones are among the phenolic compounds produced by soy, and a class of phytoestrogens, or plant-derived estrogens. Soy sauce and soybean oil are soy-derived foods, but lack substantial amounts of either soy protein or soy isoflavones. ^3^

Soy isoflavones are one of the families of phytoestrogens that are similar in chemical structure to estrogen and thus may have similar effects (Figure 1). The most prominent isoflavones in soy are daidzein, genistein, glycitein, and their glucosides. Most isoflavones occur in plants in the bound form of their glucosides, daidzin, genistin and glycitin, and are biologically inactive. The glucoside forms of isoflavones can be converted to free forms (aglycones) after consumption by hydrolysis at the intestinal brush border membrane and by intestinal bacteria. The efficiency of this conversion affects bioavailability, and subsequent metabolism. Different food sources of soy isoflavones can also affect their bioavailibilities. One aglycone, equol, (7-hydroxy-3-(4'-hydroxyphenyl)-chroman), is an exclusive intestinal bacterial metabolite of dietary isoflavones. ^4,^ ^5^ Equol has superior antioxidant potencies against destructive compounds, known as free radicals ^1^ , than the parent isoflavones. ^6^ However, many adults do not produce equol. This phenomenon has led to the terminology of being an “equol-producer” or “non-equol producer” and may explain the differential clinical effectiveness among individuals of isoflavones from soy proteins. ^7^ There are many other factors that might influence the health effects of soy and its isoflavones, such as the relevant window of exposure (early in life, peri-menopausal or post-menopausal) or the frequency of exposure.

Free radicals are highly reactive substances that result from normal metabolism and from exposure to environmental factors like cigarette smoke and ultraviolet light. They cause cellular damage by attacking the body's cell membranes, proteins, and DNA.

Figure 1. Chemical structures of genistein, diadzein, glycitein and estradiol

The aglycone form of soy isoflavones and their metabolites can be absorbed by the gut and may exert several biological effects. There is a growing interest in the roles of these natural estrogenic or antioxidant substances in influencing disease progression or medical conditions in humans. Research suggests several mechanisms of action of soy isoflavones.

### Isoflavones as Estrogens and Anti-Estrogens

Estrogens produced in the ovaries and testes stimulate growth, blood flow, and water retention in the sexual organs and are also associated with the development of breast and endometrial cancers. ^8^ Because of the structural similarity of soy isoflavones to estrogens, it has been suggested that these isoflavones might act as either an agonist or antagonist of estrogen. For example, studies suggest that genistein can induce responses similar to estradiol in breast, ovarian, endometrial, prostate, vascular and bone tissues, and in cell lines. ^9^ – ^12^ Genistein can also act as an estrogen antagonist in some tissues. Animal studies have shown that genistein inhibits the development of chemically-induced mammary cancer. ^13,^ ^14^

### Isoflavones as Cancer-Enzyme Inhibitors

Genistein was first identified in 1987 as an inhibitor of protein-tyrosine kinase, an enzyme that promotes cancer cell growth. ^15^ Other cancer-related enzymes were also found to be inhibited by genistein, including DNA topoisomerases I and II ^16^ and ribosomal S6 kinase. ^17^ Possible mechanisms for the anti-proliferative properties of genistein include prevention of cell mutations by stabilization of cell DNA and reduction of cell oxidants, reduction in capacity of malignant cells to metastasize by inhibiting angiogenesis and subsequent tumor growth, as well as inducing cell differentiation. ^18^

### Isoflavones as Antioxidants

Isoflavones' antioxidant properties may enhance the resistance of LDL to oxidation and prevent free radical damage to DNA. ^19^ Studies show that genistein has greater antioxidant activities than other isoflavones. ^6,^ ^17^ Genistein may also increase the production of antioxidant enzymes, such as superoxide dismutase. ^20^

New concepts are still evolving about possible mechanisms of action of soy isoflavones. For example, some research suggests the potential health effects of soy isoflavones might occur via the transforming growth factor β signaling pathway. ^21^

## Possible Roles of Soy and its Isoflavones in Influencing Diseases or Conditions in Humans

Although direct evidence is lacking, it has been suggested that soy and its isoflavones affect various diseases or conditions, such as CVD, cancers, osteoporosis, menopausal symptoms, and kidney disease, through different mechanisms of action described above.

### Cardiovascular Disease and its Risk Factors

Heart disease is, in part, a hormone-dependent disease, as illustrated by the lower age-related incidence in pre-menopausal women compared with males and a rise in incidence among both natural and surgical post-menopausal women. ^18^ Although estrogen replacement therapy does not reduce long-term CVD risk in post-menopausal women, ^22^ soy isoflavones may reduce CVD risk by several mechanisms. One possible pathway for the protective effects of soy isoflavones on CVD may be manifested through blood lipid changes. ^1^ There has also been a suggestion that soy isoflavones may have regulatory effects on blood pressure (BP). ^23^

### Menopausal Symptoms

The reported incidence of hot flashes varies among menopausal women in different countries. For example, it occurs in 70 to 80 percent of menopausal women in Europe, 57 percent in Malaysia, and 18 and 14 percent in China and Singapore, respectively. The estrogenic effects of soy isoflavones may be responsible for modifying the incidence rates, given that substantial dietary differences in soy consumption exist among these populations. ^18^ Soy isoflavones may regulate menopausal symptoms by maintaining normal vascular function in both vasomotor tone and vessel wall compliance. ^24,^ ^25^ However, it is not clear which components of soy may be responsible for any putative effects.

### Cancers and Their Risk Factors

Several observational studies have evaluated the effects of isoflavones on the risk of developing hormone-dependent cancers, such as breast, colon, prostate, endometrial, and ovarian. Much of the evidence is based on the differences in the consumption of soy products in different areas of the world. ^18^ Case-control studies examining the association between soy-containing food intake and breast cancer risk suggest a marginally significant inverse relationship. ^26,^ ^27^ However, no significant association between soy-based foods and breast cancer risk was found in a large prospective cohort study in Japan or other prospective studies. ^26^

A recent meta-analysis of stomach cancer studies conducted among Asians showed that non-fermented soy foods significantly reduced the risk of stomach cancer while fermented soy foods had no effect. ^28^ But because various confounders such as dietary salt, fruit, and vegetable intake, were not adjusted for in the original studies, the role of soy could not be adequately assessed. A case-control study and the preliminary finding from an ongoing clinical trial suggest an inverse relationship between soy-based food and colon cancer risk. ^25,^ ^29^

### Bone Health - Osteoporosis and Fracture Risk

The pathophysiological mechanism for involuntary bone loss in post-menopausal women can be explained by the deficiency of estrogen due to a rapid decline in ovarian function. It involves loss of both cancellous and cortical bone and continues throughout the remainder of life. It is caused by the loss of estrogen effects on extra-skeletal calcium homeostasis, leading to decreased intestinal calcium absorption, increased renal calcium wasting, and, perhaps also effects on vitamin D metabolism and loss of a direct effect on the parathyroid gland that decreases parathyroid hormone (PTH) secretion. ^30^ These factors put post-menopausal women at an increased risk of developing osteoporosis and fracture.

Conventional therapies for treating osteoporosis in women, such as estrogen treatment alone or combination estrogen and progesterone, function as inhibitors of bone resorption. However, the effectiveness and safety of hormone replacement therapies in post-menopausal women remain controversial. The potential use of soy and its isoflavones to preserve bone tissue and delay or prevent the onset of osteoporosis has recently been addressed. ^9^ Benefits from soy protein for bone health may also be related to changes in dietary protein intake, and calcium excretion. Since the animal protein-rich diet is associated with the highest excretion of undissociated uric acid and calcium, it increases the risk of kidney stones and osteoporosis. ^31^ Substituting less hypercalciuric soy protein for animal protein may benefit calcium balance and bone health.

### Kidney Disease

Low protein diets can halt or attenuate the progression of chronic kidney disease, and modifications in the quality of dietary protein can also affect the course of kidney disease. In animal models of kidney disease, studies have shown that soy protein diets limit or reduce proteinuria and kidney lesions associated with progressive kidney failure. ^32^ However, it is not clear whether the kidney protective effects of soy protein diets are due to soy isoflavones or other soy components. The effect of soy protein intake on kidney function in humans has not been examined comprehensively. In a review of studies of people with different types of chronic kidney disease, soy protein moderated proteinuria and preserved kidney function, although most of the trials reviewed were of relatively short duration and involved small numbers of patients. ^32^ The applicability of these findings to prevent the development of chronic kidney disease in people with normal kidney function is uncertain.

### Reproductive Health

Reproductive health is defined by the World Health Organization (WHO) as a state of physical, mental, and social well-being in all matters relating to the reproductive system at all stages of life. This definition of reproductive health implies that people are able to have a satisfying and safe sex life and that they have the capability to reproduce and the freedom to decide if, when, and how often to do so (http://www.who.int/topics/reproductive_health/en). While reproductive health covers a wide range of issues including contraception safety and efficacy, fertility, infertility, and HIV/AIDS and other sexually transmitted diseases the focus of this report is on fertility. The putative estrogenic effect of soy may have a direct impact on endocrine function, which in turn may affect fertility.

### Other Diseases or Conditions

Studies have also reported on the use of soy-based foods combined with hypocaloric diet in the treatment of obesity, but no significant effect of soy was found when compared to the control treatment. ^33,^ ^34^ Soy-rich foods have also been used to prevent malnutrition in patients with Crohn's disease, a chronic inflammatory disorder of the bowel. A study reported that patients with inactive Crohn's disease had a higher treatment compliance while on a soy-rich and lactose-free diet than on a conventional enteral diet, although body weight and lean muscle mass were increased equally in both groups of patients. ^35^ A population-based cohort study in China showed an inverse relationship between intake of soy products and the risk of glycosuria in postmenopausal women, but not in pre-menopausal women. ^36^ Estrogen loss associated with menopause may contribute to the development of Alzheimer's Disease. ^37^ However, a cohort study of Japanese-American men reported that higher midlife consumption of soy in the form of tofu was associated with indicators of cognitive impairment and brain atrophy in late life. ^38^

Although soy has been evaluated for treatment or prevention of a variety of diseases, this report - which evaluates the effect of soy on generally healthy people and not on disease treatment - evaluates only a limited number of other conditions, based primarily on the availability of data. These include endocrine function, cognitive function, and glucose metabolism.