# Appendix D. Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- David Atkins, MD, MPH
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, Maryland

- D. Lee Alekel, PhD
- Department of Food Science and Human Nutrition
- Iowa State University
- Ames, Iowa

- Elizabeth Jackson, MD
- Department of Medicine
- Division of Cardiovascular Medicine
- University of Massachusetts Medical School
- Worcester, Massachusetts

- Penny Kris-Etherton, PhD, RD
- Pennsylvania State University
- University Park, Pennsylvania

- Mindy S. Kurzer, PhD
- Director of Graduate Studies, Nutrition
- Department of Food Science and Nutrition
- University of Minnesota
- St. Paul, Minnesota

- Gertraud Maskarinec, MD, PhD
- Cancer Research Center of Hawaii
- Honolulu, Hawaii

- Katherine M. Newton, PhD
- Center for Health Studies
- Group Health Cooperative
- Seattle, Washington

- Frank M. Sacks, MD
- Nutrition Department
- Harvard School of Public Health
- Boston, Massachusetts

- Anne Thurn, PhD
- Evidence-Based Review Program
- Office of Dietary Supplements
- National Institutes of Health
- Bethesda, Maryland

- Yvonne T. Van der Schouw, PhD
- Julius Center for Health Sciences and Primary Care
- University Medical Center Utrecht
- Utrecht, Netherlands

- Linda V. Van Horn, PhD
- Department of Preventive Medicine
- Feinberg Cardiovascular Research Institute
- Northwestern University
- Chicago, Illinois

- Connie M. Weaver, Ph.D.
- Foods and Nutrition
- Purdue University
- West Lafayette, Indiana