# Appendix C. Evidence Tables

EvidenceTable (Part 1)

Author, Year | Characteristics | Studydesign | Eligibility criteria of the study population | Soy Intervention | Control/Placebo | Outcomes | Adverse event, Dropout, Comments
Adams 2003 | Age (yr):65.1 | Design:RCT | Undergoing colonoscopy, 50–80 y, adenomatous colorectal polyps on current or recent (within 12 mo) colonoscopy | 1. ISP without isoflavone | No non-soy control | Insulin like growth factor (IGF-I) | AE:no
| (SD 7.9) | Randomized: Yes | Excluded:HRT. Various GI and other medical conditions. Habitual soy food intake >= 4 servings/week. (Initially regualr NSAID use, lifted after 1 y enrollment to increase numbers.) | Soy drink powder packets (DuPont Protein Technologies, St Louis). 2 packets/day = 58 g/d. | | IGFBP-3 | Drop out: 16 from Iso+: 7 health-related reasons; 7 logistical reasons; 2 unknown;11 from Iso-: 6 health-related; 3 logistical; 2 unknown.
| Male%:85 | Blinding: double | | Diet composition: 6240 kJ/d, carb 171 g/d, protein 61g/d, fat 59g/d | | IGF-I/IGFBP-3 | Comments: High proportion of women taking replacement estrogen and therefore ineligible, the majority of participants (85%) were men
| Country: US | Duration:12 | | 2. ISP with Isoflavone
| Sites:2 | mo | | Soy drink powder packets (DuPont Protein Technologies, St Louis). 2 packets/day = 58 g/d
| BMI:29.1 | | | Diet composition: : 6500 kJ/d, carb 175 g/d, protein 64.7g/d, fat 62g/d
| Soy1 N:74
| Soy2 N:76
| Control N:0
Adams 2004 | Age (yr):63.9 | Design:RCT | Subset of men from Soy Isoflavone prevention trial Undergoing colonoscopy, 50–80 y, adenomatous colorectal polyps on current or recent (within 12 mo) colonoscopy and consented to PSA | 1. Soy drink powder packets (DuPont Protein Technologies, St Louis). 2 packets/day = 58 g/d. | No non-soy control | PSA | AE:no
| (SD 7.2) | Randomized: Yes | Excluded:HRT. Various GI and other medical conditions. Habitual high soy food | ISP without isoflavone | | | Drop out: See Adams 12730416;In addition, only subset of men 34/51 in the isoflavone+ and 47/61 agreed to PSA test.
| Male%:100 | Blinding: double | | Diet composition: E 1528 kcal/d, Protein 61g/d, carb 170g/d, fat 37% | | | Comment: Part of Soy Isoflavone prevention trial
| Country: US | Duration:12 | | 2. Soy drink powder packets (DuPont Protein Technologies, St Louis). 2 packets/day = 58 g/d
| Sites:1 | mo | | ISP with Isoflavone
| BMI:29.1 | Duration:1 | | Diet composition: E 1545 kcal/d, protein 64g/d, carb 171 g/d, fat 36%E
| Soy1 N:61 | years
| Soy2 N:51
| Control N:0
Albert 2002 | Age (yr): >45 | Design:NRNCT | post-menopausal, > 45 y, at least one year amenorrhea, at least 6 moderate or severe daily hot flushes previous 15 day prior to inclusion | Soy Isoflavones without protein | No control | Menopausal symptom | AE:yes
| Male%: 0 | Randomized: No | Excluded:HRT during previous 6 wks, R\loxifen tx, and personal records of breast cancer | Phytosoya | | hot flushes | AE Report:“No severe side-effects were reported and tolerance was excellent.” Gastric disorders (1) and/or breast pain (2) precordial pain, and metrorrhagia.
| Country: Spain | CohortSing | | soy preparation rich in isoflavones, capsules containing 17.5 mg isoflavones | | sleep disorder | Drop out:LTF (19), protocol violations (11), intervention ineffective (9). 2 of which left study for AE
| Sites:13 | Blinding:No | | Diet composition:Detailed reporting of analyses of capsules | | vaginal dryness | Comment: Pilot clinical trial
| BMI: | Duration:4 | | | | loss of libido
| Soy1 N: 190 | mo | | | | psychological symptoms
| Control N: 0 | | | | | Bone pain
Albertazzi 1998 | Age (yr):53.3 | Design:RCT | Postmenopausal women, at least 6 mo since last menstrual period, or at least 6 wks since bilateral oophorectomy, at least 7 moderate or severe hot flushes, including night sweats per 24 hr during at least last 2 wks of 4-wk prestudy period, baseline FSH conc>50IU/L, sr estradiol conc<35pg/mL | soy | 60 g of casein powder | Menopausal symptom | AE: ND
| (SD 0.45) | Randomized: Yes | Excluded:HRT < 6 wks prior prestudy period, meds for climacteric symptoms (vit E, clonidine, and veralipride) | 60 g of isolated soy protein in powder form, supplied by manufacturer as identically appearing, code | Protein40 g | hot flushes | Drop out:yes
| Male%:0 | Blinding: double | | Supro | Product60 g | | Nausea (2), vomiting (1), bloating (13), constipation (52), other (11); LTF (4), 25 of 104 WD
| Country: Italy | Duration:12 | | ISP with Isoflavone | Diet composition: ND
| Sites:2 | wks | | Diet composition: ND | | | Comment: Two groups of 46 each with 12 more enrolled following reserve randomized list which had 1:1 treatment ratio
| BMI:25.9
| Soy1 N:51
| Control N:53
Albertazzi 1999 | Age (yr):53.3 | Design:RCT | Postmenopausal women, at least 6 mo since last menstrual period, or at least 6 wks since bilateral oophorectomy, 7 moderate or severe hot flushes, including night sweats per 24 hr during at least last 2 wks of 4-wk prestudy period, baseline FSH concentration > 50 IU/L & serum estradiol concentration < 35 pg/mL | soy | 60 g of casein contained 40 g of proteins but no isoflavones. | Vaginal cell maturation index | Adverse event: GI, constipation, bloating, nausea, vomiting (70)
| (SE 0.45) | Randomized: Yes | Excluded: ND | Daily supplements of 60 g soy powder | Total Protein 40 g | Equol | Drop out: 25 of 104 WD
| Male%: 0 | Blinding: double | | Supro | Total Product60 g | | Comment: Originally 46 randomized to each group with 12 additional on reserve randomization list for total 104
| Country: Italy | Duration:12 wks | | ISP with Isoflavone | Diet composition: ND | | Same cohort as #914 Albertazzi '98
| Sites:2 | | | Diet composition: ND
| BMI:25.9
| Soy1 N:51
| Control N:53
Alekel 2000 | Age (yr):50.2 | Design:RCT | Perimenopausl women with vasomotor symptoms; nonsmoking premenopausal >10 hot flashes/night sweats/wk, irregular menstrual periods. had1 or both ovaries, BMI between 20–31, willing to be randomized. FSH >30 IU/L | 1. ISP with Isoflavone Jumbo muffins containing 80.4 mg glycosides | whey protein | Serum bone specific alkaline phosphatase | AE:yes
| Male%:0 | Randomized: Yes | Excluded:Chronic disease: osteoporosis or CVD, no long-term meds, no HRT or ERT within past 12 mo, no excessive exercise | Diet composition: ~2.09 MJ (500 kcal) and 650 mg Ca/d for the muffin | Total Protein: 40 g/day | Type 1 Collagen cross-linked N-teleopeptide | AE Report:6 drop outs due to “inability to tolerate treatment”
| Country: US | Blinding: double | | 2. ISP with Isoflavone (low) | Total Product: ND | Urinary calcium | Drop out: 22 did not meet criteria of FSH, 11 unable to tolerate tx, 1 death, 1 family member death, 2 medical condition preventing continuance, 1 noncompliant
| Sites:1 | Duration:24 | | Jumbo muffins containing 4.4 mg glycosides components | Diet composition: ~2.09 MJ (500 kcal) and 650 mg Ca/d | BMD
| BMI:24.0 | wks | | Diet composition: ~2.09 MJ (500 kcal) and 650 mg Ca/d from the muffin | | BMC
| Soy1 N:24
| Soy2 N:24
| Control N:21
Anderson 1998 | Age (yr):64 | Design:Xover | Men with insulin-treated type 2 DM with fair glycemic control defined as glycohemoglobin concentrations of < 8%. They were free of significant medical illnesses or uncontrolled conditions, substantial proteinuria (>1000 mg/d) or proteinuria unrelated to DM or HTN | Soy diet | Animal-protein diet, which provided 1 g protein/kg BW and were weight maintaining. 50% of the protein in the form of ground beef and cow milk | Total Cholesterol | AE:ND
| (SD 6.5) | Randomized: Yes | Excluded:ND | Soy-protein diet, which provided 1 g protein/kg BW and were weight maintaining. | Product:ND | LDL | Drop out:no
| Male%:100 | Blinding:No | | Diet composition:Standard diabetic exchange diet to maintain body wt, carb ~55% E, fat 30%E | Diet composition: Standard diabetic exchange diet to maintain body wt, carb ~55% E, fat 30%E | HDL | Comment: Self-control study, compared Soy diet to animal protein diet.
| Country: US | Duration:8 | | | | Triglyceride
| Sites:1 | wks | | | | glycohemoglobin
| BMI:35.1 | | | | | GFR
| Soy1 N:8 | | | | | Sr creatinine
| Control N:8 | | | | | serum urea
Anderson 2002 | Age (yr):24.0 | Design:RCT | healthy women of any ethnic background 21–25 | isoflavone enriched soy protein diet | soy protein isolates lacking isoflavones | Bone mineral density | AE:No
| (SD 1.1) | Randomized: Yes | Excluded:pregnancy/lactation, use of oral contraceptive agents or steroid hormones, continuing longitudinal growth (height) | isoflavone-enriched soy protein isolate diet available in powder and as chocolate liquid. | Protein64.5 g at baseline | Bone mineral content | Drop out:10/38 subjects dropped out--4 began using disqualifying meds, 3 moved away, 3 were unspecified
| Male%:0 | Blinding: double | | ISP with Isoflavone | Product | BMC-lumbar | Comment: insufficient detail;small sample size, 26% drop out rate
| Country: US | Duration:1 | | Diet composition:ND | Diet composition:ND
| Sites:1 | years
| BMI:62.4
| Total:38
| Soy1 N:15
| Control N:13
| (soy and control completers only)
Arjmandi 2003 | Age (yr):62.4 | Design:RCT | postmenopausal women | soy protein | milk-based protein | IGF-1 | AE:yes
| (SD 2.4) | Randomized: Yes | Excluded:GI disorders, cancer, DM, hypo or hyperthyroidism, liver or kidney problems, pelvic inflammatory disease, endometrial polyps, heavy smokers | 40 g daily soy supplement provided in 2 packs, each containing 29 g powdered unflavored drink mix | Protein40 g | Serum bone specific alkaline phosphatase | AE Report:2 ISP, 1 control GI disturbances
| Male%:0 | Blinding: double | | Soy diet | Product | Urine deoxypyridinoline | Drop out: 7 ISP, 6 control-lack of palatability of protein;7 ISP, 5 control=time constraints; 2 ISP, 1 MBP=GI disturbances, 1 SP personal
| Country: US | Duration:3 | | Diet composition:protein 40g, carb 6 g, total fat 2g | Diet composition:protein 40g, carb 6 g, total fat < 1g | Urinary calcium | Comments: women taking HRT and not taking HRT are included--subgroup analysis done on these groups.
| Sites:1 | mo | | | | Urine Phosphorus | 41% attrition rate
| BMI:84.5 | | | | | Estradiol
| Total Enrol: 71
| Soy1 N:20
| Control N: 22
| (soy and control only for completers)
Ashton 2000 10694766 | Age (yr): 34–62 | Design:Xover | healthy male vounteers aged 34–62 yr, no symptoms or prior dx of CHD | Tofu diet | Meat diet | Total Cholesterol | AE:No
| Male%:100 | Randomized: Yes | Excluded: meds that affect lipids or BP, BMI>35 kg/m2, Total Cholesterol >7.5 mmol/L, Triglyceride >6.0 mmol/L. | 90–100% animal protein with 290g/tofu | Total Protein: ND | LDL | Drop out:3
| Country: Australia | Blinding:other | | Diet composition:energy 9.5 MJ; protein 16.9%E;carb 44%, total fat 32%, saturated fat 12.4%, MUFA 11.5%, PUFA 5.2% alcholo 5.4%, cholesterol 189.5 mg | Total Product: ND | HDL | Comment: To minimize the differences in MUFA, PUFA, and SAFA between the two diets 5g of butter, 5g of lard, and 8ml of olive oil were also prescribed daily on the tofu diet
| Sites:1 | Duration: 4.3 wks | | | Diet composition: subjects consumed 150g/d (raw weight) of cooked lean red meat, all visible fat removed + PUFA margarine 15g energy 9.6 MJ, protein 17.2%E, carb 43.7%, total fat 32.4%, saturated fat 12.9%, MUFA 11.9%, PUFA 4.8%, alcohol 4.9%, cholesterol 253.2 mg | Triglyceride
| BMI:26.2 | | | | | LDL:HDL ratio
| Soy1 N:45
| Control N:meat diet--45
Ashton 2000 11194529 | Age (yr):45.8 | Design:Xover | Healthy males | Tofu diet | Lean meat diet: 150 g (raw weight) of cooked lean red meat, with all visible fat removed, each day. | Total Cholesterol | AE:no
| (SD 7.8) | Randomized: Yes | Excluded:Symptoms or prior diagnosis of CHD. Use of any medication that affects lipids or BP, BMI > 35, Total Cholesterol > 7.5 mmol/L, Triglyceride > 6.0 mmol/L. | Designed to replace 90–100% of animal protein with 290 g tofu. 5 g butter, 5 g lard, 8 g olive oil | Total Protein: 32.4 | HDL | Drop out: 3: non-compliance.
| Male%:100 | Blinding:No | | Diet composition: E 9.5 MJ, 16.9%E protein, 44%E carb, 32%E fat, 12.4%E sat fat, 11.5%E MUFA, 5.2%E PUFA, 189.5%E Cholesterol | Total Product: 150 g raw meat | Triglyceride | Comment: Baseline data for outcomes ND
| Country: Australia | Duration:4.2 wks | | | Diet composition: E 9.6 MJ, 17.2%E protein, 43.7%E carb, 32.4%E fat, 12.9%E sat fat, 11.9%E MUFA, 4.8%E PUFA, 253.2%E Cholesterol | Lpa
| Sites:1 | | | | | Free or Non-Esterified Fatty Acids
| BMI:26.2 | | | | | Oxidized LDL
| Soy1 N:45 | | | | | Factor VII
| Control N:45 | | | | | Fibrinogen
Azadbakht 2003 | Age (yr):62.5 | Design:Xover | Type 2 DM patients who were free of any uncontrolled conditions or other renal disease. All subjects had proteinuria with total urine protein excretion between 300 and 1000 mg/da, serum creatinine between 1 and 2.5 mg/dl and blood urea nitrogen between 20 and 40 mg/dl | Soy protein diet | Animal protein diet, 0.8 g/kg total protein, including 70% animal and 30% vegetable protein | Total Cholesterol | AE:ND
| (SD 12.1) | Randomized: Yes | Excluded:ND | 0.8 g/kg protein containing 35% soy protein, 30% vegetable protein and 35% animal protein | Protein56 | LDL | Drop out:ND
| Male%:71% | Blinding:No | | Soy diet | Product | HDL | Comments:None
| Country: Iran | Duration:7 | | Diet composition: E 2403 kcal/d, protein 54 g/d, fat 55 g/d, fiber 16.1g/d, SFA 6.8g/d, MUFA 10.2g/d, PUFA 14.2g/d | Diet composition: E 2396 kcal/d, protein 55.6 g/d, fat 57.6 g/d, SFA 10.2 g/d, MUFA 8.8 g/d, PUFA 11.3g/d | Triglyceride
| Sites:1 | wks | | | | LDL:HDL
| BMI:70.6
| Soy1 N:14
| Control N:14
Baird 1995 | Age (yr): 45–65 | Design:RCT | postmenopausal, =< 65, => 2 yr after menses | Soy diet | Usual diet | Vaginal cell maturation index | AE:yes
| Male%:0 | Randomized: Yes | Excluded:Antibiotics or HRT in past 6 mo, meds known to affect outcomes measures | soy diet group ate daily portions of soy foods provided by the study as a substitute for approximate | Control group instructed to eat as usual during dietary intervention period | Sex Hormone Binding Globulin | AE Report:1 could not tolerate soy food
| Country: US | Blinding:No | | Diet composition:ND | Protein:ND | LH | Drop out:3 found ineligible (1 premenopausal, 1 on corticosteriods, 1meds for DM), 3 WD (personal reasons 2, aversion for soy foods 1)
| Sites:4 | Duration:4 | | | Product:ND | FSH | Comments: 3:1 randomization; 18/66 lack of compliance in the soy arm
| BMI: ND | wks | | | Diet composition:ND | Estradiol
| Total enrol:97
| Soy1 N:66
| Control N:25
| (soy and control for only completers)
Bakhit 1994 | Age (yr):43 | Design:Xover | Males, Plasma Total Cholesterol > 5.7 mmol/L, able to eat samples of the study muffins. | 1. Isolated Soy Protein + Cellulose | 1. Casein + Soy Cotyledon Fiber | Total Cholesterol | AE:ND
| (SD 12) | Randomized: Yes | Excluded:Persons taking lipid altering medications, thryoid and liver disorders. | 4 Muffins daily with (total) 25 g isolated soy protein, and 20 g cellulose | 4 muffins daily with (total) 25 g Casein and 20 g Soybean Cotyledon Fiber. | LDL | Drop out:10; 6 individuals could not comply with low fat, low cholesterol diet or could not consume required number of muffins on a daily basis(within first 4 week treatment block), 1 lost to follow-up, 3 left out of analysis
| Male%:100 | Duration:4 | | Supro | | HDL
| Country: US | wks | | Diet composition:Supro 610 Isolated Soy Protein, Protein Technologies International, St. Louis, MO | 2. 4 Muffins daily with (total) Casein 25 g + cellulose 20 g | Triglyceride
| Sites:1 | | | | cellulose | Apo A1
| BMI:27.1 | | | 2. Isolated Soy Protein + Soy Cotyledon Fiber | Protein25 g | Apo B/100
| Soy1 N:21 | | | 4 muffins daily with (total) 25 g Isolated Soy Protein and 20 g Soybean Cotyledon Fiber. | Product | VLDL
| Soy2 N:21 | | | Supro | Diet composition: 10225kJ, protein 19.2%KJ, carb 90.7%KJ, Fat 24.6 KJ
| Control1 N:21 | | | Diet composition: E:10692kJ, protein 19.7%KJ, carb 98%KJ, Fat 26.7 KJ
| Control2 N:21
Balk 2002 | Age (yr):56.8 | Design:RCT | postmenopausal, omnivorous, intact uterus | Soy diet | Placebo was wheat cereal, Grapenuts, that is low in isoflavones but similar in appearance & texture | Menopausal symptom | AE:yes
| (SD 5.9) | Randomized: Yes | Excluded:H/o of tamoxifen use, endometrial cancer, soy allergy, HRT in past yr, current supplementation of isoflavones | 100 mg per day of isoflavones via soy flour & corn cereal (Nutlettes by Dixie). Soy & Placeb | Protein:ND | hot flushes | AE Report:Flatus, breast tenderness, nausea, diarrhea with no difference between groups at baseline or final week
| Male%: | Blinding: double | | Diet composition:ND | Product:ND | vaginal dryness | Drop out:8 WD (2 from placebo because lack of effectiveness of cereal, taste of cereal (1); 6 from soy because of personal reasons (2), excess flatus (1), increase hot flush intensity (1), LTF(1))
| Country: US | Duration:6 | | | Diet composition:ND | decreased libido
| Sites:1 | mo | | | | depression
| BMI:ND | | | | | urinary discomfort
| Wt:154.5 lbs | | | | | Additional outcomes: headache, palpitations, night sweats, insomnia
| Soy1 N:13
| Control N:14
Baum 1998 | Age (yr):59.8 | Design:RCT | Completion of menopause with >= 1 yr since the last menstrual period, plasma cholesterol concentration between 6.2 and 7.8 mmol/L. | 1. ISP56 | Casein and non fat dry milk (CNFDM, containing 0 mg total glycosides isoflavones/d; New Zealand Milk Product) | Total Cholesterol | AE: ND
| (SD 9.1) | Randomized: Yes | Excluded:Hormone Replacement Therapy, Any medications known to lower lipids, h/o of DM mellitus or thyroid disease, or chronic illness, allergies to soybean protein. | ISP with Isoflavone | | HDL | Drop out:7 withdrew during wks 1–4: 1 moved, 3 withdrew because of unrelated medical problems, 3 unable to comply with study protocol.
| Male%:0 | Blinding: double | | Basal diet + 40 g of soy protein and 56 mg total glycosides isoflavones/day, Supro 675, Protein Techno | Protein40 g | Triglyceride | Comment: Well Reported.
| Country: US | Duration:24 | | Supro | Product:ND | Apo A1 | Industry Supported
| Sites:ND | wks | | | Diet composition:ND | Apo B/100
| BMI:28.2 | | | ISP90 | | Total chol:HDL
| Soy1 N:23 | | | ISP with Isoflavone | | HDL2, HDL3
| Soy2 N:21 | | | Basal diet + 40 g of soy protein and 90 mg total glycosides isoflavones/day, | | Non-HDLc
| Control N:22 | | | Diet composition:ND | | LDL receptor mRNA
Bazzoli 2002 | Age (yr):21 | Design:RCT | female students modrately active from an exercise standpoint | ISP w /isoflavones | whey protein | plasma lipid peroxides | AE:no
| (SD 1.8) | Randomized: Yes | Excluded:smoking, any soy product consumed>1 time/week, oral contraceptives | Soy Isolated Soy protein w isoflavones consumed as a mixture w/ water and an approved flavoring | Protein40 g | urinary 8- hydroxyl-2-deoxyguanosine | Drop out:No
| Male%:0 | Blinding: double | | Supro | Product:ND | Total antioxidant status | Comment: baseline dietary intakes not explicitly reported;not clear whether mean or median are given.
| Country: US | Duration:4 | | Diet composition:ND | Diet composition:ND
| Sites:1 | wks
| BMI:22.4
| Soy1 N:9
| Control N:9
Blum 2003 | Age (yr):55 | Design:Xover | Mildly hypercholesterolemic (LDL > 3.36 mmol/L), post-menopausal, women. (not aware of high cholesterol level). | soy supplement | Placebo of 25 g/day total milk protein in similar powder. | Total Cholesterol, LDL, HDL, Triglyceride | AE:no
12595862 | (SD 5) | Randomized: Yes | Excluded:HRT or vitamins A, C, or E, or lipid-lowering Tx in preceding 2 mo | Diet packets with isolated soy protein with isoflavones. Fortified with vitamins and minerals, sugar | | E-selectin | Drop out:
| Male%:0 | Blinding: double | | ISP with Isoflavone | Protein25 | ICAM-1 | 6 (4 during placebo, 2 during soy) stopped treatment because of bad taste and nausea caused by the powder):
| Country: Israel | Duration:6 | | Diet composition:Unclear what food was allowed or replaced. | Product: ND | IL 2R | Comment: Same study as Blum 2003 12659466 (Triglyceride reported both studies)
| Sites:1 | wks | | | Diet composition: ND: | P-selectin
| BMI: | | | | | VCAM-1
| Soy1 N:30
| Control N:30
Blum 2003 | Age (yr):55 | Design:Xover | Mildly hypercholesterolemic (LDL > 3.36 mmol/L), post-menopausal, women. (not aware of high cholesterol level). | soy supplement | Placebo of 25 g/day total milk protein in similar powder. | Total Cholesterol | AE:no
12659466 | (SD 5) | Randomized: Yes | Excluded:HRT or vitamins A, C, or E, or lipid-lowering Tx in preceding 2 mo. | Diet packets with isolated soy protein with isoflavones. Fortified with vitamins and minerals, sugar | | LDL | Drop out:
| Male%:0 | CohortMult | | ISP with Isoflavone | Protein:25g | HDL | 6 (4 during placebo, 2 during soy) stopped treatment because of bad taste and nausea caused by the powder)
| Country: Israel | Blinding: double | | Diet composition:Unclear what food was allowed or replaced. | Product: ND | Triglyceride | Comment: Same as 12595862
| Sites:1 | Duration:6 | | | Diet composition: ND | Peripheral endothelial function
| BMI: | wks
| Soy1 N:30
| Control N:30
Bricarello 2004 | Age (yr):56 | Design:Xover | Recruited from dyslipidemia clinics. 20–70 years, Total Cholesterol 200–350 mg/dL, Triglyceride <400 mg/dL | Soy milk | 1 L per day non-fat cow milk | Total Cholesterol | AE:no
| (SD 1) | Randomized: Yes | Excluded:Presence of CAD and other significant CVD, renal, hepatic, gastrointestinal, mental, and endocrine disorders, including DM and BMI >=30 kg/m2. Hypolipidemic drugs in previous 8 wk | 1 L per day soy milk (flavored with vanilla) | nonfat mil1 | LDL
| Male%:25 | Blinding: double | | SoyMilk | Protein:27.5 | HDL | Drop out: ND
| Country: Brazil | Duration:6 | | Diet composition: E 1580kcal, total fat 34%Unsat fat 39%, sat fat 20%, carb 45%, protein 21%, Cholesterol 113mg, fiber 16g | Product:1 L | Triglyceride
| Sites:2 | wks | | | Diet composition: E 1578kcal, total fat 25%Unsat fat 24%, sat fat 20%, carb 53%, protein 21%, Cholesterol 142mg, fiber 13g | Apo E
| BMI:24.9 | | | | | Oxidized LDL
| Soy1 N:60
| Control N:60
Brooks 2004 | Age (yr):54.1 | Design:RCT | healthy, postmenopausal, => 1yr of natural menopause | Soy diet | 1.Placebo muffin | Urine deoxypyridinoline | AE:no
| (SD 0.6) | Randomized: Yes | Excluded:active bowel disease, malabsorption syndrome, exogenous estrogens within past 3 mo, phytoestrogen supplements within past 1 month, thyroid disorder, oral or parenteral corticosteroids, antibiotic use in past 4 wks | The study muffins for all 3 treatment groups contained similar ingredients flour | 2.Flaxseed muffin | Bone specific alkaline phosphatase | Drop out:2 WD from analyses for missing lab data
| Male%:0 | Blinding: double | | Diet composition: E 7326 kJ/d, protein 67.7g/d, fat 58g/d, carb 242.9.1g/d, fiber 18.3g/d | Protein7.5 | Estradiol | Comment:99 enrolled in a separate study, 46 (selected for compliance)- formed this study subgroup
| Country: Canada | Duration:16 | | | Product:21g | Estrone
| Sites:ND | wks | | | Diet composition: E 6933 kJ/d, protein 81.0g/d, fat 52.8g/d, carb 240.2g/d, fiber 18.3g/d | Estrone Sulfate
| BMI:27.1 | | | | | Urinary 2OHE
| Soy1 N:15 | | | | | Urinary 16aOHE
| Control N1:15
| Control N2:16
Brown 2002 | Age (yr):27.6 | Design:Xover | Healthy premenopausal women with standard blood cell counts, and clinical chemistry determinations | Soy | 2 control diet | Cortisol | AE:no
| (SD 0.12) | Randomized: Yes | Excluded:Oral contraceptives < 6 mo, antibiotics < 3 mo, > 2 alcoholic drinks per day, irregular menstrual cycles, diets of high fiber(>25 g/day), high soy (>2 servings/wk), high fat (>35% kcal), or low fat (<25% kcal), vegetarianism, | Supro | 1. PUFA diet | Menstrual cycle length | Drop out: 47%(Pregnancy (1), antibiotics (1), relocation (2), difficult study schedule/noncompliance (8)
| Male%:0 | Blinding: single | | ISP with Isoflavone | 2.control diet | Sex Hormone Binding Globulin | Comments: ND for baseline data for outcomes; but data reported for follicular and luteal phase
| Country: US | Duration:11 | | Diet composition: Standard diet from 2,000–2,800 kcal/day. 37% kcal fat, 48% carb, 15%protein | protein | LH
| Sites:1 | mo | | | Protein: 15%E | FSH
| BMI: | | | | Product:ND | Estradiol
| Soy1 N:26 | | | | Diet composition: Standard diet from 2,000–2,800 kcal/day. 37% kcal fat, 48% carb, 15%protein | Estrone
| Control N:26 | | | | | Estrone Sulfate
| | | | | | Progesterone
| | | | | | Prolactin
| | | | | | Testosterone
| | | | | | Androstenedione
| | | | | | DHEA/DHEAS
| | | | | | Urinary 2OHE
| | | | | | Urinary 16aOHE
Bruce 2003 | Age (yr):68.9 | Design:RCT | Postmenopausal, > 60 y | Isoflavones supplement | Maltodextrin | T3 | AE:no
| (SD 1.03) | Randomized: Yes | Excluded:HRT, breast cancer h/o, BMI > 35 | Soy Isoflavones without protein | Protein | T4 | Drop out:Personal reasons (3), LTF (1)
| Male%: | Blinding: double | | Diet composition:ND | Product3 | TSH | Comments: vitamin/mineral supplementatioin incl 150 mg of iodine
| Country: US | Duration:6 | | | Diet composition:ND | | isoflavones supplied by funder
| Sites:1 | mo
| BMI:20.5
| Total enroll:42
| Soy1 N:22
| Control N:16
| (soy and control for completers)
Burke 2001 | Age (yr):59.3 | Design:RCT | Nonsmoking, men or women, at least 20 years old, currently on antihypertensive therapy for at least 6 mo with <=2 medications, SBP between 130 and 160 mm Hg, and alcohol intake <= 210 g alcohol/wk. | 1. HighSoyProteinHighFi | 1.LowProteinHighFiber | SBP | AE:yes
| Male%:55.6 | Randomized: Yes | Excluded:DM, renal disease (creatinine > 130 mmol/L), symptomatic heart disease, regular use of NSAIDs, psychiatric illness, BMI > 33 kg/m2 for men and 37 kg/m2 for women | 66 g soy protein/d, 12 g soluble Fiber in the form of Psyllium husks | 15 g psyllium/day, 66 g maltodextrin powder/day. | DBP | AE Report:3 withdrawals related to dietary intolerance.
| Country: Australia | Blinding:No | | Diet composition:E 8.1mJ/d, 23.7% E protein/day, 26.1%E fat,47.7%E carb. | Diet composition: E 9.3mJ/d, 12.2% E protein/day, 25.1%E fat,59.4%E carb. | heart rate | Drop out: 3 withdrawals due to dietary intolerance, 1 due to a change in hypertensive medications.
| Sites:1? | Duration:8 | | 2. HighSoyProteinLowFib | 2.Low, Protein, Low Fiber arm. | | Comment: Data presented clearly.
| BMI:76.2 | wks | | 66 g soy Protein/day | 66 g maltodextrin/day.
| Soy1 N:10 | | | Diet composition: E 10.0mJ/d, 22.8% E protein/day, 26.5%E fat,49.9%E carb. | Total Protein: 11.5% of energy
| Soy2 N:13 | | | | Total Product: 66 g maltodextrin
| Control1 N:9 | | | | Diet composition: E 9.0mJ/d, 11.5% E protein/day, 22.8%E fat,62.2%E carb.
| Control2 N:9
Burke 2003 | Age (yr):50.8 | Design:RCT | Perimenopausal women, 45 - 55 y, at least 1 vasomotor symptom @ day; surgical menopause subjects okay if all other inclusion/exclusion met | 1. High isoflavoneflavone | soy protein without isoflavones | Menopausal symptom | AE:yes
| (SD 0.1) | Randomized: Yes | Excluded:HRT < 3 mo, MI or stroke < 6 mo, h/o breast or endometrial cancer, invasive cancer < 5 y, active thromboembolic disease, hormonal meds for osteoporosis-related fractures, low basln bone density, prev exposure to diethylstibestrol, dyslipidemia, or endometrial biopsy with hyperplasia | 25 g ready-to-drink soy protein beverage | 25 g ready-to-drink beverage | vasomotor symptoms | AE Report:? Soy protein supplementation was quite palatable, and extremely well-tolerated.
| Male%:0 | Blinding: double | | ISP with Isoflavone | Protein25 g | | Drop out:13% drop out from 241enrolled, 3 -no symptom diaries, 14 - no baseline symptom diaries, 11 - no fwup symptom diaries, 2 had baseline diary but no hot flashes; therefore 211 included for analyses of symptom diaries
| Country: US | Duration:2 | | Diet composition:ND | Product:ND | | Comment: Breakdown of isoflavones not given
| Sites:1 | years | | 2. Med isoflavone | Diet composition:ND
| BMI:27.1 | | | 25 g ready-to-drink soy protein beverage | alcohol washed to remove isoflavones (<= 4 mg/day)
| Soy1 N:70 | | | ISP with Isoflavone
| Soy2 N:65 | | | Diet composition:ND
| Control N:76
Carroll 1978 | Age (yr):21 | Design: Xover | Healthy young women studying either food science or nutrition. Well nourished. Normal glucose, Triglyceride, Total Cholesterol, alkaline phosphatase, thyroxine, creatinine, calcium, sodium, potassium, chloride, bicarbonate, hematological and urine analyses, and chest X-ray. | Soy diet | Mixed protein diet All meals provided on a 5 day rotation. Regular foods to maintain weight and adequate amounts of essential nutrients | Total Cholesterol | AE:no
| Male%:0 | Randomized: Unclear | Excluded:Obese, metabolic or other disease, received any medication known to affect serum lipids or ingested > 30 g/day ethanol in previous 4 mo. | All meals provided on a 5 day rotation. Meats were replaced by soy protein meat analogues (textured | Protein:70 | Triglycerides | No dropouts
| Country: Canada | Blinding:No | | Soy diet | Product:
| Sites:1 | Duration:37 or 41 (each arm different) | | Diet composition: E 1880kcal, protein 75g, carb 242g, fat 68g | Diet composition: E 1853 kcal, protein 70g, carb 238g, fat 69g
| BMI:54.4 | days
| Soy1 N:10
| Control N:10
Cassidy 1994 | Age (yr):24 | Design:NRNCT | Healthy, nonvegetarian women, normal menstrual cycle, no meds => 6 mo prior to record menses data | soy diet | First complete menstrual cycle served as control period, each | Total Cholesterol, but N<10 | AE:no
| Male%:0 | Randomized: No | Excluded:ND | During 2nd month, starting on 1st day of menses, appropriate modificatioins were made to the basal d | Protein97.2 | Menstrual cycle length | Drop out:None
| Country: UK | CohortSing | | ISP with Isoflavone | Product | Follicular | Comment: All subjects under 30;4 month prior study and several mo after, basal body temp monitored to determine menstrual cycle;1 month control diet followed by 1–4 month separation period before soy diet;Small sample size
| Sites:1 | Blinding:No | | Diet composition:Energy 8.5 with- 0.3 MJ, Total fat 60.0 with- 1.7g, Carb 260.3 with- 1.0g, Nonstarch polysaccharide 16.3 with- 0.7g, Starch 106.7 with- 2.7g, Nitrogen 2.10 with- 0.06 ug/g | Diet composition:Energy 8.5 with- 0.1 MJ, Total fat 61.4 with- 0.7g, Carb 258.2 with- 1.9g, Nonstarch polysaccharide 16.0 with- 0.6g, Starch 108.3 with- 2.2g, Nitrogen 2.09 with- 0.03ug/g, Daidzein 0.76 with- 0.03 mg, Genistein 0.49 with- 0.03 mg | Sex Hormone Binding Globulin | Same study as Cassidy 1995 Study 1
| BMI:61.59 | Duration:1 | | | | FSH
| Soy1 N:6 | month | | | | Estradiol
| Control N:0 | | | | | Progesterone
| | | | | | Testosterone
Cassidy 1995 | Age (yr):20–29 | Design:NRCT | non-vegetarian female students, regular menstrual cycles and no medication for 6 mo before the study. | 45 mg conjugated isoflavones | No control | Follicular phase length | AE:no
7577895 study 1 | Male%:0 | Randomized: No | Excluded:ND | ISP with Isoflavone | | Luteal phase length | Drop out:no
| Country: US | CohortSing | | Diet composition:ND. | | Total menstrual cycle length | Comments: no baseline data
| Sites:1 | Blinding:No | | | | Total Cholesterol | Same study as Cassidy 1994
| BMI:61.6 | Duration:1 | | | | LDL
| Soy1 N:6 | mo | | | | HDL
| Control N:0 | | | | | Triglyceride
| | | | | | Sex Hormone Binding Globulin
| | | | | | LH
| | | | | | FSH
| | | | | | Progesterone
| | | | | | Oestradiol
| | | | | | Urinary LH
Cassidy 1995 | Age (yr): | Design:Xover | non-vegetarian female students, regular menstrual cycles and no medication for 6 mo before the study. | isoflavones-free soyabean product | Control diet | Follicular phase length | AE:no
7577895 study3 | Male%:0 | Randomized: Yes | Excluded: | ISP without isoflavone | | Luteal phase length | Drop out:no
| Country: US | Blinding:ND | | Diet composition:8MJ/d | | Total menstrual cycle length | Comment: blinding is unclear and small numbers
| Sites:1 | Duration:1 | | | | Total Cholesterol
| BMI: | mo | | | | LDL
| Soy1 N:5 | | | | | HDL
| Control N:5 | | | | | Triglyceride
| | | | | | Sex Hormone Binding Globulin
| | | | | | LH
| | | | | | FSH
| | | | | | Progesterone
| | | | | | Oestradiol
| | | | | | Urinary LH
Cassidy 1995 | Age (yr): | Design:NRCT | non-vegetarian female students, regular menstrual cycles and no medication for 6 mo before the study. | half-dose conjugated isoflavones | No control | Follicular phase length | AE:ND
7577895 Study 4 | Male%:0 | Randomized: No | Excluded: | 23 mg conjugated isoflavones | | Luteal phase length | Drop out:no
| Country: US | CohortSing | | ISP with Isoflavone | | Total menstrual cycle length | Comments: no baseline data
| Sites:1 | Blinding:No | | Diet composition:ND | | Total Cholesterol
| BMI:57.0 | Duration:1 | | | | LDL
| Soy1 N:6 | mo | | | | HDL
| Control N:6 | | | | | Triglyceride
| | | | | | Sex Hormone Binding Globulin
| | | | | | LH
| | | | | | FSH
| | | | | | Progesterone
| | | | | | Oestradiol
| | | | | | Urinary LH
Chen 2003 | Age (yr):54.4 | Design:RCT | age 48–62, postmenopausal women within 10 y of menopause | 1. high-dose soy isoflavones | corn starch + calcium 500 mg + Vitamin D 125 IU | Bone mineral density | AE: ND
| (SD 3.1) | Randomized: Yes | Excluded:any meds known to affect bone or calcium metabolism, current use of or h/o of exogenous estrogens, corticosteroids, thiazine; soy allergic, any systemic endocrine disease; any surgery known to affect bone health (Ovariectomy, thryoid gland or intestin | 80 mg soy isoflavones, calcium 500 mg, Vitamin D 125 IU | Protein:0 | Bone mineral content | Drop out:Isoflavone groups=14 cases abdominal distention, 6 constipation, 6 breast disorders, 3 menses-like bleeding, 12 misc.
| Male%:0 | Blinding: double | | Soy Isoflavones without protein | Product:0.5g | | Comment: same trial as Chen 2004 RefID #5256--same design, characteristics, population etc etc etc. Differences are adverse events published in this paper
| Country: HongKong | Duration:1 | | Diet composition:E 5.49MJ/d, protein 68.2g/d | Diet composition: E 5.44MJ/d, protein 74.6g/d
| Sites:1 | years | | 2. mid-dose soy isoflavones
| BMI:57.9 | | | 40 mg soy isoflavones, 12.5 mmol calcium, 125 IU Vitamin D
| Soy1 N:68 | | | Soy Isoflavones without protein
| Soy2 N:68 | | | Diet composition: E 5.38MJ/d, protein 71.3g/d
| Control N:67
Chen 2004 | Age (yr):54.4 | Design:RCT | age 48–62, postmenopausal women within 10 y of menopause | 1. high-dose soy isoflavones | corn starch + calcium 500 mg + Vitamin D 125 IU | Bone mineral density | AE:yes
| (SD 3.1) | Randomized: Yes | Excluded:any meds known to affect bone or calcium metabolism, current use of or h/o of exogenous estrogens, corticosteroids, thiazine; soy allergic, any systemic endocrine disease; any surgery known to affect bone health (Ovariectomy, thryoid gland or intestin | 80 mg soy isoflavones, calcium 500 mg, Vitamin D 125 IU | Protein:0 | Bone mineral content | AE Report:14 cases: abdominal distension; 6 constipation; 6 breast disorders; 3 menses-like bleeding; 12 misc.“We did not observe a statistically higher incidence of any adverse effect in treatment groups compared to placebo arm.”
| Male%:0 | Blinding: double | | Soy Isoflavones without protein | Product:0.5g | | Drop out: 28/203 lost to follow up
| Country: HongKong | Duration:1 | | Diet composition: Diet composition:E 5.49MJ/d, protein 68.2g/d | Diet composition: Diet composition:E 5.49MJ/d, protein 68.2g/d | | Comment: same trial as Chen 2004
| Sites:1 | years
| BMI:57.9 | | | 2. mid-dose soy isoflavones
| Soy1 N:68 | | | 40 mg soy isoflavones, 12.5 mmol calcium, 125 IU Vitamin D
| Soy2 N:68 | | | Soy Isoflavones without protein
| Control N:67 | | | Diet composition: Diet composition: E 5.38MJ/d, protein 71.3g/d
Chiechi 2002 11836040 | Age (yr):54.2 | Design:RCT | All women in menopause as defined by 1) spontaneous menopause since at least 6 mo and with FSH >30 IU/L and E2 <20 pg/ml. 2) Bilateral ovariectomy. | Soy diet | Usual diet | Total Cholesterol | AE:no
| (SD 4.04) | Randomized: Yes | Excluded:age >60; drinking more than 14 standard alcoholic drinks weekly; hormonal replacement therapy or cholesterol lowering drugs in the previous 6 mo; h/o cancer; adherence to a vegetarian or macrobiotic diet or to any other medically prescribed diet; treatment for diabetes, presence of menopausal symptoms requiring therapy | Diet intervention arm | ProteinND | LDL | Drop out: 58
| Male%:0 | Blinding:No | | Women in the dietary intervention group were asked to add a soy food serving every day (e.g. soy milk, Soy bean,Tofu, SoyMilk) | ProductND | HDL | Diet group: Dislike of soy; lack of time/too difficult, side effects; family reasons; little conviction; menstruation; foods difficult to find; high cost of the foods; and other reasons
| Country: Italy | Duration:6 | | Diet composition:ND | Diet composition:No data available on the control arm | Triglyceride | Comment: Huge drop out and race, baseline CVD not reported.
| Sites:1 | mo | | | | Apo A1
| BMI:68.5 | | | | | Apo B/100
| Soy1 N:58 | | | | | SBP
| Soy2 N:53 | | | | | DBP
| Control N:55 | | | | | Total chol:HDL
| | | | | | ApoA1:B
| | | | | | Endometrial thickness
| | | | | | Uterine artery resistance index
Chiechi 2002 | Age (yr):54.2 | Design:RCT | spontaneous menopause since 6 mo, FSH > 30 IU/I, E2 < 20 pg/ml, bilateral ovariectomy | soy diet | Usual diet | Bone mineral density | AE:yes
12191852 | (SD 4.04) | Randomized: Yes | Excluded:age >60, drinking > 14 alcoholic drinks wkly, HRT or cholesterol lowering drugs within 6 mo, h/o of cancer or other chronic diseases, adherence to veg or macrobiotic diet, treatment for DM, presence of menopausal symptoms requeiring therapy | women were invited to continue usual diet, only adding soy food serving every day (soymilk, miso soup, tempeh, or soy beans) | Protein:ND | Bone mineral content | AE Report:1 (no reason stated)
| Male%:0 | Blinding:No | | Diet composition:daily consumption of soy: 22.25 g soybeans, 33.3 g tofu, 299.06 soymilk, 8.6 g tempeh, 2.4 g miso | Product:ND | Serum Osteocalcin | Drop out: diet group= 11 disliked soy, 7 too difficult, 1 side effect etc;HRT= 7 side effects; control= var reasons listed, seem unimportant to mention
| Country: Italy | Duration:6 | | | Diet composition:“usual diet” | Type 1 Collagen cross-linked N-teleopeptide | Comment: 3 arms: diet containing soy vs HRT vs control
| Sites:1 | mo | | | | FSH
| BMI:68.5 | | | | | Estradiol
| Soy1 N:58 | | | | | Hydroxyproline/creatinine
| Soy2 N:53
| Control N:55
Chiechi 2003 | Age (yr):54.2 | Design:RCT | Asymptomatic postmenopausal women, 39–60 y, incl spontaneous menopause => 6 mo, FSH > 30 IU/1 and E2 < 20 pg/ml or with bilateral ovariectomy | soy diet | Habitual diet of Southern Italy | FSH | AE:no
| (SD 4.04) | Randomized: Yes | Excluded:>60 y, > 14 standard alcoholic drinks weekly, HRT, lipid-lowering, antiosteoporotic or other interfering drugs < 6 mo, DM, H/o cancer, vegetarian or macrobiotic diet, menopausal symptoms requiring tx | Continue usual diet & add soy food serving every day, to exchange 2 meals tice a week with meals | ProteinND | Estradiol: | Drop out:no
| Male%:0 | Blinding: double | | Soy diet | ProductND | Karyopycnotic index | Comment: See Chiechi 2002, analyses on 166 of 187. PI spectulation for high dropout due to soy foods not common part of diet
| Country: Italy | Duration:6 | | Diet intervention arm | Diet composition:No data available on the control arm | Maturation value
| Sites:1 | mo | | Women in the dietary intervention group were asked to add a soy food serving every day (e.g. soy milk, Soy bean,Tofu, SoyMilk)
| BMI:27.06 | | | Diet composition:ND
| Soy1 N:53
| Control N:58
Crisafulli 2004 | Age (yr):52 | Design:RCT | Healthy, ambulatory women, 47–57 yr, FSH > 50 IU/L, serum E2 <= 100 pmol/L, > 5 hot flushes @ day | Genistein | Placebo pills identical in appearance to intervention. | Endometrial thickness | AE:yes
| (SD 0.5) | Randomized: Yes | Excluded:Sugical menopause, menstrual period in preceding year, clinical or lab abnormalities suggesting CVD, hepatic, or renal disorders, coagulopathy, oral or transdermal estrogen, progestin, androgen or other steroids in preceding year, >10 cigarettes/day | Phytoestrogen genistein, 54 mg/day, or HRT, or placebo. All pills identical in appearance | ProteinND | Menopausal symptom | AE Report:Genistein generally well tolerated and ingested with high degree of compliance. No observed side effects after 1 year of genistein.
| Male%: | Blinding: double | | Soy Isoflavones without protein | ProductND | Hot flushes | Drop out: 7 WD from treatment but completed study
| Country: Italy | Duration:1 | | Diet composition:ND | Diet composition:ND | estradiol | Comment:Intention to treat analysis
| Sites:1 | years
| BMI:24
| Soy1 N:30
| Control N:30
Crouse 1999 | Age (yr):52 Male%:60 | Design:RCT | Mild cholesteremic (LDL 140–200 mg/dl) men and women after 1 month instruction in an NCEP Step 1 diet. Eligible individuals have to be 80% compliant with 25 g casein beverage run in 1 month period. | 1) Isolated soy protein beverage | 25 gram of casein | Total Cholesterol | Adverse event: ND
| Country: US | Randomized: Yes | Excluded:current use of lipid lowering medications, H/o CVD, current H/o DM or blood glucose levels higher than 6.94 mmol/L (125 mg/dl), uncorrected secondary causes of hypercholesterolemia, excessive alcohol consumption, triglyceride conc >4.52 mmol/L (>400 mg/dL), LDL cholesterol >5.17 mmol/L (>200 mg/dL), use of oral contraceptives or estrogen replacement, and usual consumption of high soy protein diet. | ISP with Isoflavone (62 mg) | Protein25 gram | LDL | Drop out :12: 3 in the casein group, 4 in the 3mg isoflavone group and 5 in the 27 mg isoflavone group. 8/12 were lost to follow up. Among 4/12, 2 dropped out casein group- urticaria and exacerbation of asthma, 1 from the 3mg group- indigestion, 1 from the 27 mg group-chestpain and an abnormal exercise tolerance test.
| Sites:1 | Blinding:other | | 2) Isolated soy protein | Product ND | HDL | Comment: Baseline characteristics reported according to the gender and menopausal status;Divided at the median level for LDL into low group
| BMI:26 | Duration:9 wks | | ISP without isoflavone | Diet composition: ND | Triglyceride | There is a discrepancy in the data between text and the table
| Soy1 N:31 | | | 3) Isolated soy protein beverage | | Lpa
| Soy2 N:31 | | | ISP with Isoflavone (27 mg) | | SBP
| Soy3 N:31 | | | 4) Isolated soy protein beverage | | DBP
| Soy4 N:31 | | | ISP with Isoflavone (37 mg)
| Control N:31 | | | Diet composition: ND
Cuevas 2003 | Age (yr):59 | Design:Xover | Healthy, non-smoking, post menopausal women hypercholesterolemia (LDL 4.14 and 6.21 mmol/l and triacylglycerol <3.39 mmol/l). normal liver, kidney and thyroid functions and normal fasting glucose concentrations. No patients received vit, antioxidants, antilipemic agents, arginine, anti-HTN, soy foods | Soy | Caseinate powder | Total Cholesterol | AE:yes
| Male%:0 | Randomized: Yes | Excluded:ND | 40 gram of isolated soy protein powder containing 80 mg isoflavones (60% genistein, 30% daidzein, 10 | Protein40 gram | LDL | AE Report:Constipation, heart burn
| Country: Chile | Blinding: double | | ISP with Isoflavone | Product:ND | HDL | Drop out:ND
| Sites:1 | Duration:8 | | Diet composition: NCEP step 1 diet; <30%E fat, <10%E sat fat, <300mg/day cholesterol | Diet composition: NCEP step 1 diet; <30%E fat, <10%E sat fat, <300mg/day cholesterol | Triglyceride | Comment: Small sample and drop out ND
| BMI:29.3 (0.81) | wks | | | | SBP
| Soy1 N:18 | | | | | DBP
| Control N:18 | | | | | Peripheral endothelial function
| | | | | | other test:1
| | | | | | Nitroglyce
| | | | | | FSH
Dalais 1998 | Age (yr):54 | Design:Xover | 45–65 yr; FSH>40 IU/ml, hot flush > 14 per wk; amenorrhea for 12 mos; | Soy diet | 45 grams/day of wheat kibble | Menopausal symptom | AE: ND
| Male%:0 | Randomized: Yes | no abx or HRT for preceding 3 mos., non-smoker, non-vegetarian | 45 grams per day of soy grits was achieved by using 3 different types of bread with the same backgro | Protein without fat | hot flushes | Drop out:52 enrolled, 44 completed the study, 7 drop-outs due to personal reason, 1 due to lack of compliance to study demands
| Country: Australia | Blinding: double | Excluded:ND | soy bread | Protein:ND | Vaginal cell maturation index | Comment: There is also a linseed and wheat arm reported in the paper.
| Sites:0 | Duration:12 | | Diet composition:ND | Product:45g/d
| BMI:26 | wks | | | Diet composition:ND
| Soy1 N:52
| Control N:52
Dalais 2003 | Age (yr):60 | Design:RCT | Postmenopausal women between 50 and 75 years, nonsmokers, nonvegetarians, not on HRT for the previous 12 mo, not consuming isoflavones or soy-based products and not on any antibiotics for the previous 3 mo. None of the study participants were cons | Soy protein | Placebo | Urine deoxypyridinoline | AE:yes
| (SD 1) | Randomized: Yes | Excluded:None | Soy protein, powder form (St Louis, MO, USA) | Protein40 | Urine pyridinoline | AE Report:Low incidence of mild GI side-effects
| Male%:0 | Blinding: double | | ISP with Isoflavone | ProductND | | Drop out:13 withdrew from the soy group and 15 from the placebo group, primarily due to difficulty consuming the bulk of product provided each day.
| Country: Australia | Duration:3 | | Diet composition: E 2228 kcal; protein 109g | Diet composition: E 2211kcal; protein 112 g | | Comment: This study was part of a larger trial in men and women examining the role of soy protein on cardiovascular end points Teede, 2001
| Sites:1 | mo
| BMI:24.9
| Soy1 N:51
| Control N:55
D'Amico 1992 | Age (yr):41 | Design:NRNCT | Patients with biopsy-proven glomerular disease. Consistent proteinuria of > 1.5 g/24 h for a mean of 25 mo (range 3–95]; serum creatinine < 220 umol/l; hyperlipidaemia (fasting serum cholesterol > 5.95 mmol/l); no treatment with steroids or c | Vegtarian soy diet | No control | Total Cholesterol | AE:no
| (SD 18) | Randomized: No | Excluded:ND | Vegtarian soy diet, low in fat, moderately low in protein, and rich in PUFA and MUFA and fiver | | LDL | Drop out:no dropout
| Male%:65% | CohortSing | | Soy diet | | HDL | Comment: Lipid and kidney outcomes excluded from the report (NRCT)
| Country: Italy | Blinding:No | | Diet composition: 11% E protein, 28% E fat, carb 46% | | Triglyceride
| Sites:1 | Duration:8 | | | | Apo A1
| BMI:22.7 | wks | | | | Apo B/100
| Soy1 N:20 | | | | | SBP
| Control N:0 | | | | | DBP
| | | | | | GFR
Davis 2001 | Age (yr):25–40 | Design:NRNCT | Healthy male employees of Barbara Ann Karmanos Cancer Institute | Soy isoflavone mixture | No control | 5-OHmdU | AE:ND
| Male%:100 | Randomized: No | No H/o of health problems, no medications, vitamins or hebal supplements taken | the tablets contain genistein, daidzein, and glycetin (1.3:1:0.3), which is estimated to contain 24% | | NF-kB | Drop out:no
| Country: US | CohortSing | Excluded:none reported | Diet composition:ND | | | Comment:No baseline data
| Sites:1 | Duration:3
| BMI:ND | wks
| Soy1 N:6
| Control N:0
Dent 2001 | Age (yr):50.2 | Design:RCT | Perimenopausal women experiencing >=10 hot flashes and/or night sweats per week, had irregular menses or cessation of menses for <1 yr, had one or both ovaries remaining, had a BMI between 19–31kg/m2 and were willing to be randomized | 1. Isoflavone poor soy protein isolate | Whey protein | Total Cholesterol | AE:no
| (SD 3.6) | Randomized: Yes | Excluded:women with chronic disease (ie heart disease or osteoporosis), on medications chronically, sex hormone treatment during the past 12 mo, h/o of an eating disorder or menstrual disorder and/or were excessive exercisers | isoflavone poor soy protein isolate with 4.4 mg/d glycosides component | Total Protein: 40 gram/day | LDL | Drop out: inability to tolerate treatment (n=6), medical conditions preventing continuance (n=2), death (n=1), death in the family (n=1)
| Male%:0 | Blinding: double | | ISP without isoflavone | Total Product: ND | HDL | Comment: Soy protein source not clear; outcomes assessed from figures
| Country: US | Duration:24 | | Diet composition:ND. | Diet composition: ND | Triglyceride
| Sites:1 | wks | | 2. Isoflavone +ve soy protein | | Lpa
| BMI:24.1 | | | SPI+ (80.4 mg/d glycosides components) | | Factor VII
| Soy1 N:24 | | | Name | | Fibrinogen
| Soy2 N:24 | | | ISP with Isoflavone | | Plasminogen activator inhibitor
| Control N:21 | | | Diet composition: ND
Dewell 2002 | Age (yr):69 | Design:RCT | Healthy, moderately hypercholesterolemic postmenopausal women not receiving HRT. | 150 mg soy-derived isoflavones. Tablet. Sermipurified extract. Exclude soy-containing foods from die | 150 mg maltodextrin with 10% caramel color. Tablet. Exclude soy-containing foods from diet. | Non-HDL cholesterol measured (=Total Cholesterol-HDL) | AE:no
| (SD 1) | Randomized: Yes | Excluded:Clinical or biochemical evidence of DM or renal, hepatic, or CV disease | Soy Isoflavones without protein | Other control: | Total Cholesterol | No dropouts
| Male%:0 | Blinding: double | | Diet composition: E 6958 kJ, protein 17%, fat 34%, SFA 11% carb 48% | Maltodextr | HDL | Comment: Distinction between eligibility criteria and sample description unclear."Subjects were recruited initially as part of a larger randomized trial.
| US:1 | Duration:2 mo (HDL, non-HDL), and 6 mo (Total Cholesterol, Triglyceride) | | | Protein0 | Triglyceride
| Country: US | | | | Product150 mg
| Sites:1 | | | | Diet composition: E 6460 kJ, protein 15%, fat 34%, SFA 10% carb 50%
| BMI:25 (18–32)
| Soy1 N:20
| Control N:16
Djuric 2001 | Age (yr):32 | Design:NRNCT2 | healthy male and female volunteers from Karmanos Cancer Institute staff | Soy extract pills | No control | 5-OHmdU | AE:ND
| (SD 12) | Randomized: No | Excluded:none reported | supplements contain equal amounts of genistein and daidzein and lesser amounts of glycitein (1:1:0.2 | | | Drop out: no
| Male%:50 | CohortMult | | Soy Isoflavones without protein | | | Comment: not explicitly stated that all women were pre-menopausal;sample size was too small for each cohort;non controlled trial
| Country: US | Duration:3 | | Diet composition:
| Sites:1 | wks
| BMI:~80
| Soy1 N:6
| Soy2 N:6
| Control N:0
Duffy 2003 | Age (yr):58.8 | Design:RCT | Postmenopausal women aged 50–65. All subjects were healthy and nonsmokers. | Soy Isoflavones without protein | lactose placebo | Tests of frontal lobe function | AE:
| (SD 1.1) | Randomized: Yes | Excluded:Use of HRT in the previous 12 mo, use of antibiotics in the previous 3 mo, current illness or use of psychoactive medication. | Solgen | Protein0 | Episodic memory | AE Report:
| Male%:0 | Blinding:other | | Soya isoflavone supplement | Product:2 capsules per day | Sustained attention | Drop out: 3 excluded because treatment with amitryptiline and one because HRT. All excluded subjects came from the placebo group.
| UK:1 | Duration:12 | | Diet composition: E 7.8MJ, Fat 34.3%E, MUFA 10.4%E, PUFA 5.2%E, SFA 12.7%E, Protein 15%E, carb 47.4%E | Diet composition: E 7.0MJ, Fat 31.9%E, MUFA 10.3%E, PUFA 6.1%E, SFA 11.1%E, Protein 15%E, carb 45.3%E | Menopausal symptoms | Comment: Subjects were recruited by circular email at King's College London or from a database of those who had previously participated in a study on bone mieral density at Guy's Hospital. In the Soy group, 78% of subjects were naturally menopausal and 22% were surgically menopausal
| Country: | wks | | | | Sleepiness
| Sites:1 | | | | | Mood ratings
| BMI:
| Soy1 N:18
| Control N:18
Duncan 1999 10522983 | Age (yr):56.9 | Design:Xover | Healthy postmenopausal women | 1. Soy protein powders | Soy protein powders with very low isoflavones | T3 | AE:ND
| (SD) 5.8 | Randomized: Yes | Excluded:strict vegetarian, high fiber, high soy, or low fat diets; regular vitamin and mineral supplementation >Recommended Dietary Allowances; athleticism; cigarette smoking; antibiotic or hormone use within six mo; bleeding within 12 mo; hysterectomy or oopherectomy; FSH concentration of less than 25 IU/L; history of chronic disorders, endocrine or gynecological diseases; benign breast disease; regular use of medication known to interfere with study endpoints (including aspirin); less than 90% or more than 120% ideal body weight; weight change >10 lb within the previous year, and inability to abstain from alcololic beverages duing the study. | ISP with Isoflavone (high) | Total Protein: ND | T4 | Drop out=4 due to inability to comply with the study protocol, and one for not postmenopausal.
| Male%:0 | Blinding: single | | Diet composition: E 1783kcal, protein 114g, carb 233g, fat 48g, fiber 13g | Total Product: ND | TBG | Comment:none
| Country: US | Duration: 13wks | | | Diet composition: E 1799kcal, protein 111g, carb 242g, fat 46g, fiber 13g | TSH
| Sites:mutiple | | | 2. Soy protein powders with | | Cortisol
| BMI:25.2 | | | ISP with Isoflavone (low) | | Sex Hormone Binding Globulin
| Soy1 N:23 | | | Diet composition: E 1755kcal, protein 114g, carb 232g, fat 45g, fiber 13g | | LH
| Soy2 N:23 | | | | | FSH
| Control N:23 | | | | | Estradiol
| | | | | | Estrone
| | | | | | Estrone Sulfate
| | | | | | Prolactin
| | | | | | Testosterone
| | | | | | Androstenedione
| | | | | | DHEA/DHEAS
| | | | | | Insulin
Duncan 1999 9920082 | Age (yr):26.5 | Design:Xover | Premenopausal women | 1. Soy protein powders | Soy protein powders with very low isoflavones | T3 | AE:no
| (SD 4.7) | Randomized: Yes | Excluded:vegetarian, high fiber, high soy, or low fat diets; regular consumption of vitamin and mineral supplementation greater than the recommended dietary allowances; athleticism; cigarette smoking; antibiotic or hormone use within 6 mo; h/o of chronic dis, endocrine or gynecological diseases; benign breast disease; regular use of medication known to interfere with study endpoints (including aspirin); less than 90% or more than 120% ideal body weight; weight change >10 lb within the previous year, and inability to abstain from alcololic beverages duing the study. | ISP with Isoflavone (high) | Total Protein: ND | T4 | Drop out:no
| Male%:0 | Duration:3 | | Diet composition: E 2221kcal, protein 116g, carb 293g, fat 67g, fiber 8.2g | Total Product: ND | TBG | Comment: All samples taken from days 2–5 of menstrual cycles 3 and 4.
| Country: US | mo | | | Diet composition: E 2294kcal, protein 115g, carb 297g, fat 76g, fiber 8.7g | TSH | Data came from early follicular days 2 and 4.
| Sites:1 | | | 2. Soy protein powders with | | Insulin
| BMI:23 | | | ISP with Isoflavone (low) | | PRL
| Soy1 N:14 | | | Diet composition: E 2272kcal, protein 113g, carb 296g, fat 74g, fiber 8.8g | | Sex Hormone Binding Globulin
| Soy2 N:14 | | | | | LH
| Control N:14 | | | | | FSH
| | | | | | Estradiol
| | | | | | Estrone
| | | | | | Estrone Sulfate
| | | | | | Progesterone
| | | | | | Testosterone
| | | | | | Androstenedione
| | | | | | DHEA/DHEAS
| | | | | | cortisol
Faure 2002 | Age (yr):53.0 | Design:RCT | Postmenopausal -natural or surgical, >= 6 mo since last period, 7 or more moderate to severe hot flashes including nightsweats per 24 hr during 2 week prestudy, FSH > 40 IU/L, E2 < 35 pg/mL | isoflavones | Placebo capsule was formulated with similar appearance and state...capsule contained cellulose micro | Menopausal symptom | AE:yes
| (SD 5.6) | Randomized: Yes | Excluded:HRT < 6 wk, vitamin E, clonidine | Phytosoya is standarized isoflavone supplement prepared from soy extract in 325 mg capsule Phytosoya | cellulose | hot flashes | AE Report:WD due to adverse drug reactions, 2 in placebo group
| Male%:0 | Blinding: double | | Soy Isoflavones without protein | Protein:ND | hot flashes | Drop out:Inefficacy (15), adverse drug reaction (2), LFU (2), other (1)
| Country: France | Duration:14 | | Diet composition: | Product:ND | night sweats | Comment: Not explicit on duration of intervention, first 2 wks assessments preceding randomization, unclear intervention between 14–16 weeks
| Sites:multiple | wks | | | Diet composition:ND | SBP
| BMI:24.9 | | | | | DBP
| Soy1 N:39
| Control N:36
File 2001 | Age (yr):27.1 | Design:RCT | Student volunteers were reruited by circular email at King's College London. All subjects were healthy and medication free throughout the trial, and all were non-smokers. | 1. high soya diet (100 mg total isoflavones/day) | No soy control | tests of memory | AE:ND
| (SD 3.2) | Randomized: Yes | Excluded:ND | Soy diet | | tests of frontal lobe function | Drop out:no
| Male%:56 (based on the total sample) | Blinding:No | | 2. low soya diet (0.5 mg total isoflavones/day) | | mood ratinings | Comment: Number of subjects in each group was not reported
| Country: UK | Duration:10 | | Total Protein: 16% of total energy
| Sites:1 | wks | | TotalProduct: ND
| BMI:ND
| Total:27 | | | Diet composition: The high soya and low soy diets provided approximately equivalent amounts of energy (~1550 kcal/day) and equivalent proportions of energy as fat (~37%), carb (~47%) and protein (~16%)
| Soy1 N:~13–14
| Soy2 N:~13–14
Foth 2003 | Age (yr):56.21 | Design:NRNCT | Postmenopausal, FSH serum level > 40 mIU/ml or last period > 12 mo | Soy | No control | LH | AE:yes
| (SD 5.01) | Randomized: No | Excluded:HRT < 3 mo or prolactin metabolism meds, strict vegetarian, high-fiber, high-soy, low-fat diet, withphenylketonuria, BMI>25, tx for climateric disorders | ISP with Isoflavone | | FSH | AE Report:Flatulence, and heartburn (2)
| Male%: 0 | CohortSing | | Soy supplementation was provided as tasteless soluble powder in daily dosage packets ingested once | | Estradiol | Drop out:none
| Country: Germany | Blinding:No | | Diet composition:ND | | Prolactin | Comment: selection enrollment unclear
| Sites:1 | Duration:24 | | | | Testosterone
| BMI:>25 | wks | | | | DHEA/DHEAS
| Soy1 N:16
| Control N:0
Gallagher 2004 | Age (yr):54.6 | Design:RCT | Postmenopausal women between the ages of 40 and 62 years, with femoral neck density within the normal range (+- 2 SD) for their age and Urine N-telopeptidelopeptide excretion in the upper half of the normal, premenopausal range. | 1. SPI 96 | No control | Total Cholesterol | AE:ND
| (SD 0.9) | Randomized: Yes | Excluded:Severe chronic illness, primary hyperparathyroidism or active renal stone disease, or on certain medications, such as bisphosphonates, anticonvulsants, estrogen, fluoride, or thiazide diuretics in the past 6 mo. | 40 g soy protein isolate with isoflavones isolate with 96 mg/day isoflavones | | LDL | Drop outs:15; 4 stopped becasue they had to begin hormone therapy for atrophic vaginitis or for hot flashes. 4 stopped because of noncompliance. 4 because of severe constipation or stmach irritation. 1 because of chest pain. 1 because of hypertension and 1 stopped because of breast cancer
| Male%:0 | Blinding: double | | ISP with isoflavone | | HDL | Comment: Values were estimated from Figures
| Country: US | Duration:9 | | Diet composition: | | Triglyceride
| Sites:1 | mo | | 2. SPI 52 | | Apo A1
| BMI:70.2 | | | 40 g soy protein isolate with 52 mg/day isoflavones | | Apo B/100
| Soy1 N:~22 | | | ISP with Isoflavone | | Bone mineral density
| Soy2 N:~24 | | | Diet composition: ND | | Serum Osteocalcin
| Soy3 N or Control N::~19 | | | 3. SPI 4 | | Urine N-telopeptide
| | | | 40 g soy protein isolate without isoflavones
| | | | ISP without isoflavone
| | | | Diet composition
Gardner 2001 | Age (yr):58.4 | Design:RCT | Post-menopausal women, age < 80 years, BMI 20–31 kg/m2. LDL 130–190 mg/dL and Triglyceride <250 mg/dL. | 1. Soy+Isoflavone | Milk protein supplement. | Total Cholesterol | AE:yes
| (SD 7.2) | Randomized: Yes | Excluded:Smokers, taking HRT or lipid-lowering medication during previous 3 mo, h/o CVD, DM, breast CA, endometrial CA, ovarian CA in previous 10 years. | Same as control except that protein = an isolated soy protein containg 80 mg glycosides isoflavones. | Mixure of protein, carb, and calcium in a powder form. 42 g protein | LDL | AE Report:One from the Soy+Isoflavone group due to increased number of hot flashes.
| Male%:0 | Blinding: double | | ISP with Isoflavone | Protein42 g | HDL | Drop out:1 each arm (3): bloating/constipation; 1 soy+iso: lost to follow-up; soy+iso: increased number of hot flashes; 1 milk: too much stress in her life
| Country: US | Duration:12 | | Diet composition:287 Kcal (1200 kJ) | Product2 packets | Triglyceride | Comment: Low calorie and low protein trial
| Sites:1 | wks | | 2. Soy-Isoflavone | Diet composition: 287 Kcal (1200 kJ), 40 g protein | FSH
| BMI:25.4 | | | Same as control, except protein = ethanol-extracted isolated soy protein with trace amounts of isofl | | Estradiol
| Soy1 N:34 | | | ISP without isoflavone | | Estrone
| Soy2 N:33 | | | Diet composition:287 Kcal (1200 kJ), 40 g protein | | Androstenedione
| Control N:32
GardnerThorpe 2003 | Age (yr):35.6 | Design:Xover | volunteers, omnivorous, healthy, non-smokers. | Soy diet | wheat flour | Total Cholesterol | AE:ND
| (SD 11.2) | Randomized: Yes | Excluded:obese (body mass index (BMI) > 30kg/m2) or had taken any antibiotics or vitamin supplements within the previous month. | soy flour | Protein | LDL | Drop out:personal reasons
| Male%:100 | Blinding: double | | soya scones the additional daily intake of isoflavones. | Product3 wheat scones | HDL | Comment: Most volunteers ate their scones in a semi-supervisedd manner; not clear about the race
| Country: UK | Duration:6 | | Diet composition: E9238 kj, carb 223g, protein 71, total fat 74g, sat fat 24g, MUFA 26g, PUFA 10.8g | Diet composition: E9600 kj, carb 250g, protein 85, total fat 86g, sat fat 31g, MUFA 30g, PUFA 16.2g | Triglyceride
| Sites:1 | wks | | | | Oxidized LDL
| BMI:25.6 | | | | | markers of oxidative stress
| Soy1 N:20 | | | | | Sex Hormone Binding Globulin
| Control N:20 | | | | | Testosterone
| | | | | | oestradial
Gentile 1993 | Age (yr):45.4 | Design:NRNCT | Patients with biopsy-proven glomerular disease. Proteinuria of > 2.5 g/24 h for a mean of 24 mo (range 3–90]; hyperlipidemia (fasting serum cholesterol >250 mg/dl); no treatment with steroids or cytotoxic, non-steroidal anti-inflammatory, or lip | Veg soy diet | No control for the soy arm | Total Cholesterol | AE:no
| (SD 4.5) | Randomized: No | Excluded:ND | Vegtarian soy diet, low in fat, moderately low in protein, and rich in PUFA and MUFA and fiver | | LDL | Drop out:no
| Male%:45% | CohortSing | | Soy diet | | HDL | Comment: Lipid and kidney outcomes excluded from the report as no control for soy arm.
| Country: Italy | Blinding:No | | Diet composition: 11% E protein, 28% E fat, carb 46% | | Triglyceride
| Sites:1 | Duration:2 | | | | Apo A1
| BMI:22.1 | mo | | | | Apo B/100
| Soy1 N:20 | | | | | SBP
| Control N:0 | | | | | DBP
| | | | | | GFR
| | | | | | Urinary Protein
Goldberg 1982 | Age (yr):44 | Design:Xover | Patients with primary hypercholesterolemia. Total Cholesterol and LDL > 95 %ile after being on NIH-type IIA diet for 6 wks. | Soy_Diet | 75% of protein Kcal (15% of total Kcal) was derived from animal Diet composition:s and 25% from a variety of ve | Total Cholesterol | AE:no
| Male%:58 | Randomized: Yes | Excluded:Hypertriglyceridemia, secondary cause for hyperlipidemia such as DM, thyroid disease, liver or renal dysfunction. Abnormal hematological or urine parameters. Pregancy. Estrogen containing medication. | 75% of protein Kcal (15% of total Kcal) was derived from soy protein.25% from a variety of vegetable | OP fat1 | LDL | No dropouts
| Country: US | CohortMult | | SoyMilk | Animal pro | HDL | Comments:subjects with type II a hypercholesterolemia
| Sites:1 | Blinding: single | | Unclear1 | Protein20.4% of Kcal | Triglyceride
| BMI:103% IBW | Duration:6 | | Diet composition: Calculated to keep subjects' weights stable. E 2458 Kcal; Protein 19.8%; carb 32.0%; Fat 43 | Product | Apo A1
| Soy1 N:12 | wks | | | Diet composition:Calculated to keep subjects' weights stable. 20% protein, 40% fat, 40% carb. | Apo B/100
| Control N:12 | | | | 2460 Kcal; Protein 20.4%; carb 32.2%; Fat 43.2%; Sat fat 29.3 g; PUFA 49.2 g; PUFA:SFA 1.71; Cholesterol 215 mg; Alcohol 4.1% Kcal | Apo E
| | | | | | VLDL, LDL:HDLtio, Apo A-II, LDL/Apo B ratio.
Habito 2000 | Age (yr):45.7 | Design:Xover | Healthy males, 35–62 y | soy diet | Lean meat diet | Sex Hormone Binding Globulin | AE:no
| (SD 7.6) | Randomized: Yes | Excluded:Symptoms or previous diagnosis of prostate disease or other illness, alcohol intake >10% of total daily energy, long-term meds affecting sex hormone concentrations, training athletes, obesity withBMI >35 kg/m2 | tofu diet contained 290 g tofu/d (raw wt), containing about 3 g soybean protein, | Total Protein: ND | Estradiol | Drop out: 3 didn't complete prescribed diets
| Male%:100 | Blinding:No | | Diet composition: E 9.5 MJ, Protein 16.9%E, Fat 31.9%E, SF 12.4%E, MF 11.5%E, PF 5.1%E | Total Product: 150g | Testosterone | Comments: Randomized to two 4 week diets with 2 week wash-out consisting of individual's usual diet
| Country: Australia | Duration:4 | | | Diet composition: E 9.6 MJ, Protein 17.2%E, Fat 32.4%E, SF 12.9%E, MF 11.8%E, PF 4.8%E | Dihydrotestosterone
| Sites:1 | wks | | | | Androstenediol
| BMI:26.2 | | | | | Free androgen index
| Soy1 N:42 | | | | | Estradiol
| Control N:42 | | | | | Testosterone:estradiol
Ham 1993 | Age (yr):61 | Design:Xover | hypercholesterolemic men admitted to VA, 2 or more risk factors for CHD. Willingness to reside and consume all meals at VA. | 1. soy flour | 2. nonfat dry milk | T3 | AE:yes
| (SD 6.7) | Randomized: Yes | Excluded:Those taking meds that altered lipid metabolism, those who suffered from secondary hypertriglyceridemia, renal or hepatic disease. | partially defatted extruded soy flour 6.5% fat | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E | T4 | AE Report:“baked products were well tolerated..with the exception of fruit bars.”
| Male%:100 | Blinding:other | | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E | | TSH | Drop out:No dropouts
| Country: US | Duration:4 | | 2. soy protein isolate | | Total Cholesterol | Comment:None
| Sites:1 | wks | | 50 g daily Supro 610 | | LDL
| BMI:28 | | | ISP without isoflavone | | HDL
| Soy1 N:17 | | | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E | | Triglyceride
| Soy2 N:17 | | | 3. ISP with cellulose
| Control 1 N:17 | | | 20 g dietary fiber (cellulose)
| Control 2 N:17N: | | | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E
Han 2002 | Age (yr):48 | Design:RCT | women in menopause at least 12 mo, not on any type of hormonal tx during previous 12 mo, not using lipid lowering drugs, antidiabetic meds, soybean derived products, or herbal supplements. Intact utreus, FSH > 25 U/L, estradiol < 20 pg/ml, hot flashes. | 1. isoflavones (insignificant amount of soy protein) | 2. insignificant amount of soy | Total Cholesterol | AE:yes
| (SD 1.1) | Randomized: Yes | Excluded:h/o of uncontrolled HTN, stroke or TIA, dx of cancer within 5 y, MI | 100 mg soy isoflavone capsules TID | without any kind of isoflavones (and glucose) TID | LDL | AE Report:1 nausea (tx arm not specified)
| Male%:0 | Blinding: double | | ISP with Isoflavone | ISP without isoflavone | HDL | Drop out:1 for poor response, 1 for nausea
| Country: Brazil | Duration:4 | | Diet composition:ND | Diet composition: ND No control | VLDL | Comment: The control is Placebo due to an insignificant amount of soy in the capsules (50 mg).
| Sites:1 | mo | | | Protein | Triglyceride
| BMI:25.6 | | | | Product | SBP
| Soy1 N:40 | | | | Diet composition: NA | DBP
| Control N:40 | | | | | Glucose
| | | | | | Endometrial thickness
| | | | | | LH
| | | | | | FSH
| | | | | | Estradiol
| | | | | | FBS
| | | | | | Menopausal Kupperman index (hot flash score)
Hargreaves 2005 | Age (yr):32 | Design:RCT | Patients attending symptomatic breast clinics at University hospital and due to undergo breast biopsy or definitive surgery for breast cancer | 60g soy in the form of ground textured vegetable protein | Normal unsupplemented diet | NA ApoD/pS2 | AE:none
| (SD 8) | Randomized: Yes | Excluded: Menopausal, on chemotherapy, steroid or OCD therapy, non compliant for soy treatment | ISP with isoflavone 45mg | | TLI | Drop out: 6 from the soy group and 4 from the control group
| Male%:0 | Blinding: None | | Diet composition:ND | | Ki67 | Comment: The control data also included 33 patients with tissue from local institute
| Country: UK | Duration:14 days | | | | ER labeling index
| Sites:1 | | | | | PR labeling index
| BMI:ND | | | | | Apoptotic index
| Soy1 N:28 | | | | | Mitotic index
| Control N:23 | | | | | Bcl-2 MOD
| Control N2:33
Hermansen 2001 | Age (yr):63.6 | Design:Xover | Healthy Type 2 diabetics with normal liver and renal function | soy | 50 g casein + 20 g cellulose | Total Cholesterol | AE:yes
| (SD 7.5) | Randomized: Yes | Excluded:Insulin, hypolipidemic agents, BBs, aspirin | ISP 50 g/d + 20 g soy cotyledon fiber (Supro) | Total Protein: ND | LDL | AE Report:control: 1 headache and vertigo, 1 did not tolerate phlebotomia; soy: 1 diarrhea, 1 previously undetected brain metastases, 1 liver metastases
| Male%:70% | Blinding: double | | ISP with Isoflavone | Total Product: ND | HDL | Drop out: 5/25 did not complete the study
| Country: Norway | Duration:6 | | Diet composition:total energy 2040 kcal/d, carb 47E, fat 30% enregy, protein 19%, alcohol 4%, fiber 26%, cholesterol 290 mg/d | Diet composition: total energy 2021 kcal/d, carb 48E, fat 30% enregy, protein 19%, alcohol 4%, fiber 27%, cholesterol 327 mg/d | Triglyceride | Comment:none
| Sites:1 | wks | | | | Lpa
| BMI:30 | | | | | Apo B/100
| Soy1 N:20 | | | | | SBP
| Control N:20 | | | | | DBP
| | | | | | Homocysteine
| | | | | | Factor VII
| | | | | | Fibrinogen
| | | | | | von Willebrand Factor, Factor VIII:Ag
| | | | | | PAI-1
| | | | | | HgbA1c
| | | | | | FBS
Hill 2004 | Age (yr):21.8 | Design:RCT | “recreationally trained young adult men”;active life style incorporating resistance training for 6 mo | ISP | antioxidant poor whey protein | Oxidized LDL | AE:no
| (SD 2.0) | Randomized: Yes | Excluded:smoking, soy consumption > 1/wk, competitive lifters and athletes | Supro | Protein39 g | IL-8 | Drop out:no
| Male%:100 | Blinding: double | | ISP with Isoflavone | Product:ND | | Comment: Data derived from Figure 1 and illegible Figure 1
| Country: US | Duration:4 | | Diet composition:soy protein daily service contained 88 mg naturally occurring isoflavones(glycosides weight)/53 mg genistein, OR | Diet composition:ND
| Sites:1 | wks | | 151 mg total isoflavones (conjugated weight)/90 mg genistien
| BMI:25.3
| Soy1 N:9
| Control N:9
Hsu 2001 | Age (yr):51.4 | Design:NRNCT | healthy postmenopausal women | isoflavone | No control | Total Cholesterol | AE:no
| (SD 4.3) | Randomized: No | Excluded:no meds for 6 mo before study | isoflavone supplements | | LDL | Drop out:no
| Male%:0 | CohortSing | | Soy Isoflavones without protein | | HDL | Comment:None
| Country: Taiwan | Blinding:No | | Diet composition: | | HDL/LDL
| Sites:1 | Duration:6 | | | | Triglyceride
| BMI:ND | mo | | | | Bone mineral density
| Weight:53.0 | | | | | Estradiol
| Soy1 N:37
| Control N:0
Huff 1984 | Age (yr):49 | Design:Xover | 5 male outpatients withfasting cholesterol exceeding normal, LDL >190 mg/dl, fasting Triglyceride <200 | soybean diet | high polyunsaturated fat, low cholesterol diet containing mixed protein from meat, dairy, plant sour | VLDL | AE:
| (SD 5) | Randomized: Yes | Excluded: ND | whole soybean protein diet, all-plant protein in which meat and dairy protein was replaced by soybea | Other control: | IDL | AE Report:
| Male%:100 | Blinding: double | | Soy bean | various | LDL | Drop out:0
| Country: Canada | Duration:6 | | Diet composition:protein 81 g/d, carb 291g/d, fat 99 g/d, cholesterol 173 mg/day | Protein41 g | HDL | Comment: Too selective a group of 5 individuals
| Sites:1 | wks | | | Product | Total Cholesterol
| BMI:82 | | | | Diet composition:protein 82 g/d, carb 287g/d, fat 95 g/d, cholesterol 133 mg/day | Triglyceride
| Soy1 N:5 | | | | | FBS
| Control N:5
Jayagopal 2002 | Age (yr):62.5 | Design:Xover | Postmenopausal women with type 2 DM | Soy | Placebo | Total Cholesterol | AE Report:Side effects were similar during both treatment phases and were predominantly gastrointestinal. Hearburn developed in 3 subject during the study 2 in the soy phase and 1 while on placebo. 6 subjects complained of feeling bloated on both soy and placebo.
| (SD 6.77) | Randomized: Yes | Excluded:Any secondary cause of hyperglycemia, current or previous (in the preceding 6 mo) use of estrogen therapy, treatment with insulin or oral hypoglycemic agents, untreated hypothyroidism, h/o of drug or alcohol abuse, and h/o of breast or uterine cancer | isolated soy protein with isoflavones (Essential Nutrition, Brough, U.K.). The product was completel | Protein:ND | LDL | Drop out:1 subject was withdrawn after MI, 1 for statin Rx, 3 for BP analysis
| Male%:0 | Blinding: double | | ISP with Isoflavone | Product:ND | HDL | Comment: 1 for statin Rx from lipid analysis, 3 for BP analysis
| Country: UK | Duration:12 | | Diet composition: ND | Diet composition:No significant calorific content | Triglyceride
| Sites:1 | wks | | | | SBP
| BMI:32.2 | | | | | DBP
| Soy1 N:33 | | | | | HgbA1c
| Control N:33 | | | | | FBS
| | | | | | Insulin sensitivity measure
| | | | | | Sr creatinine
| | | | | | T3
| | | | | | T4
| | | | | | TSH
| | | | | | Sex Hormone Binding Globulin
| | | | | | LH
| | | | | | FSH
| | | | | | Testosterone
| | | | | | Androstenedione
| | | | | | DHEA/DHEAS
| | | | | | catradiol
Jenkins 1999 | Age (yr):56.5 | Design: Xover | 19 hyperlipidemic men, 12 postmenopausal women--all with LDL >4.1 mmol/L, Triglyceride <4.0. | Soy-containing diet | lacto-ovo vegetarian diet | Total Cholesterol | Report:“compliance was good”
| (SD 9.0) | Randomized: Yes | Excluded: withclinical or biochem evidence of DM or liver or renal disease, on hypolipidemic agents | 93% animal protein replaced with vegetable protein from soy | Total Protein: ND | LDL | Drop out:no
| Male%:61 | Blinding:other | | Diet composition:energy 2341 kcal/d;total protein 118 g/d 20.2%; 110 g/d vegetable protein 18.8%; carb 318 g/d 54.3%;total fat 66 25.5%;SFA 16 g/d 6%;MUFA 22 g/d 8.4%; PUFA 25 g/d 9.6%; dietary chol 77 mg/d 33%, alcohol 0 | Total Product: ND | HDL | Comment: Same paper as Jenkins 2000 Ref ID #666
| Country: Canada | Duration: 4.2 wks | | | Diet composition: Energy 2519 kcal/d; total protein 121 g/d 19.2%;27 g 4.3%;carb 343 54/6%;total fat 71 25.5%; SFA 18 g/d 6.5%, MUFA 24 8.4%, PUFA 24 g/d 8.7% cholesterol 76 30.2% alcohol 0 | Triglyceride | Isoflavones: no data
| Sites:1 | | | | | Lpa
| BMI:24.6 | | | | | Apo A1
| Soy1 N:31 | | | | | Apo B/100
| Control N:31 | | | | | SBP
| | | | | | DBP
| | | | | | Oxidized LDL
| | | | | | Thiobarbituric reactive substances
| | | | | | Total:HDL cholesterol
| | | | | | LDL:HDL cholesterol
| | | | | | Apo B:A-1
Jenkins 2000 10647066 | Age (yr):56 | Design:Xover | Hyperlipidemia (LDL > 4.1 mmol/L, Triglyceride < 4.0 mmol/L), Inclusion in prior study. | Vegetable protein foods derived from soy, legumes, cereal foods, | Low-fat, low-cholesterol milk and egg products, soups, and low-fat, low soluble fiber dishes (Lean Cuisine and Weight Watchers). | Total Cholesterol | AE:no
| (SD 2) | Randomized: Yes | Excluded:Clinical or biochemical evidence of DM or liver or kidney disease. | Diet composition:1795 Kcal; Protein 83 g/day, 18.5%; carb 254 g/d, 57.3%; Fiber, total 38 g/d; Fiber, soluble 11 g/d (sig higher); Fat 49 g/d, 23.6%; SFA 11 g/d, 5.5%; MUFA 18 g/d, 8.7%; PUFA 16 g/d, 7.7%; Cholesterol 74 mg/d (NS); EtOH 2 g/d, 0.7% | Total Protein: 89 | LDL | No dropouts
| Male%:75 | Blinding:No | | | Total Product: ND | HDL | Comments: Unclear what exact sources of protein Same subjects, different study, as Jenkins 10381159 (RefID 747) and 10778882 (666)
| Country: Canada | Duration:8 wks | | | Diet composition: 1 g/day of soy protein | Triglyceride
| Sites:1 | | | | 1901Kcal; Protein 89 g/day, 18.7%; carb 270 g/d, 57.2%; Fiber, total 30 g/d; Fiber, soluble 7 g/d (sig lower); Fat 49 g/d, 23.1%; SFA 14 g/d, 6.9%; MUFA 17 g/d, 8.1%; PUFA 13 g/d, 6.0%; Cholesterol 104 mg/d (NS); EtOH 2 g/d, 0.7% | Apo A1
| BMI:24.2 | | | | | Apo B/100
| Soy1 N:20 | | | | | Oxidized LDL
| Control N:20 | | | | | Total:HDL
| | | | | | LDL:HDL
| | | | | | Apo B:Apo A-1
Jenkins 2000 10778882 | Age (yr):56.5 | Design: Xover | 19 hyperlipidemic men, 12 postmenopausal women--all with LDL >4.1 mmol/L, Triglyceride <4.0. | Soy-containing diet | lacto-ovo vegetarian diet | Oxidized LDL | Report:“compliance was good”
| (SD 9.0) | Randomized: Yes | Excluded: withclinical or biochem evidence of DM or liver or renal disease, on hypolipidemic agents | 93% animal protein replaced with vegetable protein from soy | Total Protein: ND | | Drop out:no
| Male%:61 | Blinding:other | | | Total Product: ND | | Comment: Same paper as Jenkins 2000 10381159
| Country: Canada | Duration: 4.2 wks | | Diet composition:energy 2341 kcal/d;total protein 118 g/d 20.2%; 110 g/d vegetable protein 18.8%; carb 318 g/d 54.3%;total fat 66 25.5%;SFA 16 g/d 6%;MUFA 22 g/d 8.4%; PUFA 25 g/d 9.6%; dietary chol 77 mg/d 33%, alcohol 0
| Sites:1 | | | Isoflavones: no data: | Diet composition: Energy 2519 kcal/d; total protein 121 g/d 19.2%;27 g 4.3%;carb 343 54/6%;total fat 71 25.5%; SFA 18 g/d 6.5%, MUFA 24 8.4%, PUFA 24 g/d 8.7% cholesterol 76 30.2% alcohol 0
| BMI:24.6
| Soy1 N:31
| Control N:31
Jenkins 2002 12077742 | Age (yr):62 | Design:Xover | Healthy hyperlipidemic men, postmenopausal women | 1.High isoflavone group | Low fat dairy food replaced protein in NCEP step 2 diet | C-reactive protein | AE:no
| (SD 2) | Randomized: Yes | Excluded:ND | 2. Low isoflavone group | Protein:88g | IL 6 | Drop out:18 WD before diet phase, 14 WD after 1–2 phases, 1 WD - didn't like dairy foods, soy arm: 1 dislike, 1 tired of eating soy, 1 bladder irritation, 1 constipation
| Male%:56 | Blinding:No | | Self-selected National Cholesterol Education Program step 2 diets | Product:ND | serum amyloid | Comments: Demographic data for 41 who completed study. Same study as Jenkins 2002; 12145008
| Country: Canada | Duration:1 | | Soy diet:Tofu, low fat soyMilk, soy hot dogs,breakfast links, soy burgers, cold cuts and tofu nuggets | Diet composition: 2000kcal diet; 88%E protein, 60%E carb, 16%E fat, SFA 7%E, MUFA 12%E, PUFA 5.9%E | Tumor necrosis factor-α
| Sites:1 | mo | | Diet composition: 2000kcal diet; 92%E protein, 59%E carb, 18%E fat, SFA 4%E, MUFA 13–15%E, PUFA 6.4–6.9%E
| BMI:25.3
| Soy1 N:55
| Soy2 N:55
| Control N:55
Jenkins 2002 12145008 | Age (yr):62 | Design:Xover | Hyperlipidemic men, postmenopausal women | 1.High isoflavone group | Low fat dairy food replaced protein in NCEP step 2 diet Protein:88g | Total Cholesterol | AE:no
| (SD 2) | Randomized: Yes | Excluded:ND | 2. Low isoflavone group | Product:ND | LDL | Drop out:18 WD before diet phase, 14 WD after 1–2 phases, 1 WD - didn't like dairy foods, soy arm: 1 dislike, 1 tired of eating soy, 1 bladder irritation, 1 constipation
| Male%:56 | Blinding:No | | Self-selected National Cholesterol Education Program step 2 diets | Diet composition: 2000kcal diet; 88%E protein, 60%E carb, 16%E fat, SFA 7%E, MUFA 12%E, PUFA 5.9%E | HDL | Comments: Demographic data for 41 who completed study. Same study as Jenkins 2002; 12077742
| Country: Canada | Duration:1 | | Soy diet:Tofu, low fat soyMilk, soy hot dogs,breakfast links, soy burgers, cold cuts and tofu nuggets | | Triglyceride
| Sites:1 | month | | Diet composition: 2000kcal diet; 92%E protein, 59%E carb, 18%E fat, SFA 4%E, MUFA 13–15%E, PUFA 6.4–6.9%E | | Lpa
| BMI:25.3 | | | | | Apo A1
| Soy1 N:55 | | | | | Apo B/100
| Soy2 N:55 | | | | | SBP
| Control N:55 | | | | | DBP
| | | | | | Homocysteine
| | | | | | IL 6
| | | | | | Total:HDL cholesterol
| | | | | | LDL:HDL cholesterol
| | | | | | Apo B:A-1
| | | | | | Oxidized LDL
| | | | | | Coronary artery disease risk 10yr
Jenkins 2003 EMB2003048927 | Age (yr):57 (SD 2) | Design:Xover | Men participated in 1 or more of 4 studies designed to assess the effect of soy protein on blood lipids. They were selected either by news paper ads or from patients already attending the Clin Nutr and RF Modific Clinics (increased LDL>4.1 mmol/L). None had clinical or biochemical evidence of DM, liver or renal disease | 1. ISP w/isoflavone (116mg) | Study 1: low fat diary foods, egg substitutes, additional soluble fiber; Study 2:starch based cereal | PSA | AE:no
| Male%:100 | Randomized: Yes | Excluded:ND | 2. ISP w/isoflavone (166mg) | low fat diet | | Drop out:ND
| Country: Canada | Blinding:ND | | 3. ISP w/isoflavone (82 mg) | Protein106
| Sites:1 | Duration:3–12 | | Diet composition: E 2208, protein 111g/d, carb 300g/d,total fat 57g/d, cholesterol 113mg/d | Product:ND
| BMI:25.3 | wks | | | Diet composition: E 2276, protein 106g/d, carb 315g/d,total fat 58g/d, cholesterol 108mg/d
| Soy1 N:46
| Control N:46
Jones 2003 | Age (yr):16.7 | Design:RCT | Male students aged 16–18 years old | Isoflavones | Placebo tablet | Serum bone specific alkaline phosphatase | AE:no
| (SD 0.78) | Randomized: Yes | Excluded:ND | Novasoy | Protein:ND | Urine pyridinoline | Drop out:4 subjects withdraw; Outside age limits
| Male%:100 | Blinding: double | | Diet composition:ND | Product:ND | Pyridinoline creatinine ratio | Comment: Adloscent boys
| Country: Australia | Duration:6 | | | Diet composition:ND
| Sites:1 | wks
| BMI:73.4
| Soy1 N:69
| Control N:59
Kanazawa 1995 | Age (yr):54.2 | Design:NRCT | outpatients who did not use hypolipemic agents--healthy patients and those with CVD identified by clinical sumptoms, carotid angiography, CT. | soycreme | no soycreme | Oxidized LDL | AE:no
| (SD 13) | Randomized: No | Excluded:as above | extract of soybeans containing 62% water, 10.6% protein, 8.2% lipid, 16.8% carb | ProteinND | | Drop out:no
| Male%:53 | CohortMult | | Diet composition:ND | Product0 | | Comment: Results are given after 6 h, 24 h, 48 h, 72 h.
| Country: Japan | Blinding:No | | | Diet composition:ND
| Sites:1 | Duration:6
| BMI:ND | mo
| Soy1 N:15
| Control1N:10
| Control2 N:11
Katsuyama 2004 | Age (yr):30.4 | Design:RCT | Healthy female hospital workers. | Natto: soybeans fermented by Bacillus natto, a traditional Japanese food. | Regular diet. | Serum bone specific alkaline phosphatase | AE:no
| (SD 9.8) | Randomized: Yes | Excluded:Dropping out, menopause, pregnancy, CVD, oopherectomy, anticoagulant use, protocol neglect. | 30 g natto at lunchtime I | No natto intake | Serum Osteocalcin | Drop out:no
| Male%:0 | Blinding:No | | 1. One/mo | Protein | Type 1 Collagen cross-linked N-teleopeptide | Comment: Poor description of methods
| Country: Japan | Duration:12 | | Diet composition:E 1787 kcal/d, protein 63.2g/d | Product | Urinary calcium
| Sites:1 | mo | | 2. Served 1/week at lunch | Diet composition: Diet composition:E 1736 kcal/d, protein 62.7g/d | Stiffness
| BMI:22.1 | | | Diet composition:E 1740 kcal/d, protein 59.3g/d
| Soy1 N:21 | | | 3. 3/wk
| Soy2 N:16 | | | Diet composition:E 1799 kcal/d, protein 69.4g/d
| Soy3 N:18
| Control N:18
Khalil 2002 | Age (yr):58.8 | Design:RCT | Men with no known h/o of osteoporosis, cancer, insulin-dependent DM, liver and kidney diseases, thyroid and parathyroid disorders, chronic GI disorders or allergy to milk or soy protein | Soy protein isolate | Milk-based protein (MP) | IGF-1 | AE:no
| (SD 2.5) | Randomized: Yes | Excluded:Current use of any prescription medications known to alter bone and calcium metabolism | ISP with Isoflavone | Protein40 | Serum bone specific alkaline phosphatase | Drop out:Milk-based protein group: 2 GI disturbances, 4 lack of palatabilaty; 4 lack of adherence.
| Male%:100 | CohortMult | | Diet composition:ND | Product58 | U-pyr | SPI group: 2 lack of palatabilaty; 4 lack of adherence.
| Country: US | Blinding: double | | | Diet composition:ND
| Sites:1 | Duration:3
| BMI:ND | mo
| Soy1 N:32
| Control N:32
Knight 2001 | Age (yr):52.3 | Design:RCT | Postmenopausal, symptomatic with > 3 flushes @ day | Soy Isoflavones without protein | The placebo was an isocaloric casein-based beverage used daily | Green menopause score: | AE:yes
| (SD 3.7) | Randomized: Yes | Excluded:HRT < 6 wks, h/o active bowel, liver, gall-bladder disease; tx for DM, malignancy, vegetarians, regular soy-product users | The isoflavone powder, TakeCare, was packaged in sachets to be used daily. | ProteinND | Menopausal symptom | AE Report:Adversion to taste (6), bloating (4), nausea (3), wt gain (2), change in bowel function (2)
| Male%: 0 | Blinding: double | | Diet composition: | Product 60g | Flushing | Drop out: Dislike soy taste (3), LTF (1)
| Country: Australia | Duration:12 | | | Diet composition:ND | Vaginal maturation index | Comment: Possible with industry funding
| Sites:2 | wks | | | | Sex Hormone Binding Globulin
| BMI:69.9 | | | | | FSH
| Soy1 N:12 | | | | | TBG
| Control N:12 | | | | | Alkaline phosphatase
| | | | | | Pyridinium cross links
| | | | | | Gamma linoleic acid
Kotsopoulos 2000 | Age (yr):59 | Design:RCT | Postmenopausal, 50–75 yr | soy | Identically presented placebo (casein) supplied in powder form in sachets | Menopausal symptom | AE:yes
| (SD 1) | Randomized: Yes | Excluded:Smoker, vegetarian, HRT past 12 mo, ingesting phytoestrogens or soy-based products, antibiotics past 3 mo | Soy dietary supplement supplied in powder form in sachets, ingested twice daily ISP with Isoflavone | ProteinND | flushes | AE Report:Dislike taste (13), constipation (2), allergies (1), wt gain (1), menopausal symptoms (1), unrelated (1)
| Male%:0 | Blinding: double | | Diet composition:ND | Producttwice daily | vaginal dryness | Drop out:Dislike taste (13), constipation (2), allergies (1), wt gain (1), menopausal symptoms (1), unrelated (1)
| Country: Australia | Duration:3 | | | Diet composition:ND | Various psychological outcomes | Comment: Limited data on quantity of protein, breakdown on isoflavones
| Sites: | mo | | | | hair, skin outcomes
| BMI:25 | | | | | Musculoskeletal outcomes - joint, muscle pain, backache; genitourinary outcomes - libido, dyspareunia
| Soy1 N:44
| Control N:50
KreijkampKaspers 2004 | Age (yr):66.5 | Design:RCT | Women aged 60 to 75 years identified via the database of a breast cancer screening program | SP | Milk protein powder | Total Cholesterol | AE:yes
| 4.7 | Randomized: Yes | Excluded:Active liver disease, impaired renal function, h/o of breast cancer or other malignancy, h/o of thromboembolism or deep venous thrombosis, endometrial thickness of more than 4 mm, estrogen users within past 6 mo, and known allergy or hypersensensitivity to cow or soy milk | isoflavone-ruch Soy protein | Protein25.6 | LDL | AE Report:GI complaints (eg, obstipation and gastric complaints), musculoskeletal complaints, lower and upper airway complaints (including ear, nose, and throat), urogenital complaints (eg, urinary tract infectionsor vaginal infections), skin complaints
| Male%:0 | Blinding: double | | ISP with Isoflavone | Product36.5 | HDL | Drop out:24% participants withdrew from the study; no difference in dropout rate between the 2 groups (24 placebo, 25 soy)
| Country: Netherland | Duration:12 | | Diet composition: E 1887kcal, 82.5g protein, 69.5 g fat, 28.8 g sat fat, 25.1 g MUFA, 15.5 g PUFA, 213g carb | Diet composition: E 1862kcal, 81.3g protein, 71.91 g fat, 31.8 g sat fat, 26.2 g MUFA, 13.5 g PUFA, 206 g carb | Triglyceride | Comment: None
| Sites:1 | mo | | | | Lpa
| BMI:26.4 | | | | | Bone mineral density
| Soy1 N:100 | | | | | Serum bone specific alkaline phosphatase
| Control N:102 | | | | | Plasma cal
| | | | | | Cognitive: Short and long-term verbal and visual memory, tests
KreijkampKaspers 2005 | Age (yr):66.5 | Design:RCT | Women aged 60 to 75 years identified via the database of a breast cancer screening program | SP | Milk protein powder | SBP | AE:yes
| 4.7 | Randomized: Yes | Excluded:Active liver disease, impaired renal function, h/o of breast cancer or other malignancy, h/o of thromboembolism or deep venous thrombosis, endometrial thickness of more than 4 mm, estrogen users within past 6 mo, and known allergy or hypersensensitivity to cow or soy milk | isoflavone-ruch Soy protein | Protein25.6 | DBP | AE Report:GI complaints (eg, obstipation and gastric complaints), musculoskeletal complaints, lower and upper airway complaints (including ear, nose, and throat), urogenital complaints (eg, urinary tract infectionsor vaginal infections), skin complaints
| Male%:0 | Blinding: double | | ISP with Isoflavone | Product36.5 | Endothelial function | Drop out:24% participants withdrew from the study; no difference in dropout rate between the 2 groups (24 placebo, 25 soy)
| Country: Netherland | Duration:12 | | Diet composition: E 1887kcal, 82.5g protein, 69.5 g fat, 28.8 g sat fat, 25.1 g MUFA, 15.5 g PUFA, 213g carb | Diet composition: E 1862kcal, 81.3g protein, 71.91 g fat, 31.8 g sat fat, 26.2 g MUFA, 13.5 g PUFA, 206 g carb | | Comment: None
| Sites:1 | mo
| BMI:26.4
| Soy1 N:100
| Control N:102
KritzSilverstein 2003 | Age (yr):61 | Design:RCT | Women who were in good health, postmenopausal for at least 2 years, and were not using ERT | Soy isoflavones | Placebo pills | Cognitve function | AE:ND
| (SD 5) | Randomized: Yes | Excluded:ND | Soy-extracted isoflavone (Healthy Woman: Soy Menopause Supplement, Personal Products Company, McNeil | identical-appearing pills that contained inert ingredients (<1mg isoflavones per day) | | Drop out: 2 placebo and 1 in soy
| Male%:0 | Blinding: double | | Soy Isoflavones without protein | ProteinND | | Comment: SOPHIA study 11 and 12 women in placebo and soy group respectively were past estrogen users
| US:1 | Duration:6 | | Diet composition:ND | Product2 pills
| Country: | mo | | | Diet composition:ND
| Sites:1
| BMI:ND
| Soy1 N:28
| Control N:28
Kumar 2002 | Age (yr):41.3 | Design:RCT | healthy, pre-menopausal, omnivorous (including nonvegan vegeterians) of all races and ethnicities, between the ages 25–55 y at first screening, admitted consecutively | Soy protein supplement | isocaloric placebo supplement of identical appearance w/ Tx using milk protein | Menstrual cycle length | AE:yes
| (SD 1.03) | Randomized: Yes | Excluded:H/o of any type of cancer, prgnancy or breast feeding within 12 mo preceding the study; current use of hormones including birth control pills or HRT; perimenopausal status; irregular menstrual cycles; body mass index>38; antibiotic use within a 3 mo period and vegans | Soy protein supplement containing 40 mg of genistein (20 mg per dose) | ProteinND | follicular | AE Report:bloating, nausea, feeling sick, constipation
| Male%:0 | Blinding: double | | Diet composition:E 1967kcal, protein 110gm, fat 63.8 gm, carb 228.9gm, chol 221mg | ProductND | Sex Hormone Binding Globulin | Drop out:31; unable to comply; intolerance to product; constipation; taste intolerance; pregnancy or birth control pill after starting the study; weight gain; no reason
| Country: US | Duration:12 | | | Diet composition:E 1810kcal, protein 97.2gm, fat 56.1 gm, carb 220gm, chol 188mg | Estradiol | Comments: randomization and allocation concealment; how much soy protein was in tb unclear
| Sites:1 | wks | | | | Estrone
| BMI:24.2 | | | | | anthropometric measurements (height, weight, skin fold, circumference)
| Total:97
| Soy1 N:33
| Control N:33
| (Soy and control completers)
Kurowska 1997 | Age (yr):55 | Design:Xover | healthy volunteers with hypercholesterolemia= total cholesterol 5.8–5.9 mmol/L, LDL 3.5–5.4 mmol/L. Initial Triglyceride 0.8–3.7 mmol/L, habitual milk drinkers (>2 glasses/d) | 1. soybean diet | 3 cups 2% cows' milk/d (each containing 3.6% protein) | Total Cholesterol | AE:no
| (SD 11) | Randomized: Yes | Excluded:thyroid disroders, kidney diseases, DM, alcohol intake >2 drinks/d, cholesterol lowering meds | 3 cups soybean milk/d, 1/2 cup soybean dessert/d | + 1/2 cup low-fat milk dessert/d (containing nonfat milk | LDL | AE Report:
| Male%:50 | Blinding:other | | Soy diet | Protein31 g | HDL | Drop out:no
| Country: UK | Duration:3 X 4 | | 16 g soybe | Product | Triglyceride | Comment: Soy arm 2-. milk/soy oil; so arm1 and control compared for the report
| Sites:3 | wks | | Diet composition:1996 kcal energy; protein 19% total energy, 96 g protein, carb 51% total energy, fat 29% total energy, 17.8 g SFA, 16.7 g PUFA, 22.4 g MUFA | Diet composition:2014 kcal energy; protein 19% total energy, 98 g protein, carb 51% total energy, fat 29% total energy, 24.7 g SFA (p<0.0001), 9.2 g PUFA, 23.6 g MUFA | Apo A1
| BMI:80 | | | | | Apo B/100
| Soy1 N:34 | | | | | SBP
| Soy2 N:34 | | | | | DBP
| Control N:34 | | | | | Oxidized LDL
Laskowski 2003*** | Age (yr):16.24 | Design:NRCT | Young healthy judo athletes who won medals in National Championships. | soy protein supplement | no soy protein supplement | Max Oxygen uptake VO _2 max_ | AE:ND
| Male%:ND | Randomized: Unclear | Excluded: ND | 0.5 g/Kg/day of soy protein supplement | Protein:0 | Total Work | Drop out:ND
| Country: Poland | Blinding:No | | Diet composition: E 4000 kcal/day, protein 100g/d, fat 170g/d, carb 510g/d | Product:same amount as soy supplement as liquid orange juice | Peak Power and Total Work Output measured by the Wingate test. | Comment: only graphical depiction of results.Graph values do not match the text reports.Unclear study design
| Sites:1 | Duration:4 | | | Diet composition: same as soy arm
| BMI:64.9 | wks
| Soy1 N:6
| Control N:6
Lenn 2002 | Age (yr):23.4 | Design:RCT | men and women from University of Kentucky | ISP with Isoflavone | received comparable amounts of Western fat blend and/or wheat flour | Relaxed arm angle; | AE:ND
| Male%:59 | Randomized: Yes | Excluded:h/o of significant pain/fx in arms or shoulders within past 3 years; strength training within 60 days before study; applicances in arms or shoulders; pacemaker; pregnancy; acute trauma or inflammation; bleeding disorders;infection, severe ischemia, poor | isoflavone+Western fat blend | Protein:ND | Arm circumference; | Drop out:3men and 3 women did not complete
| Country: US | Blinding:ND | | 120 mg of soy isolate(1.3:1 genistein:daidzein)/day and Western fat blend (fish oil control) | Product:ND | Strength parameters; | Comment: incomplete data; values estimated from graph
| Sites:1 | Duration:5 | | Diet composition:ND | Diet composition:ND | muscle soreness
| BMI:23.9 | wks | | | | Delayed Onset Muscle Soreness (DOMS)
| Soy1 N:7 | | | | | Sr total iron
| Soy2 N:8 | | | | | CK
| Control N:7 | | | | | Cortisol
| | | | | | IL-6
| | | | | | TNF-α
Lichtenstein 2002 | Age (yr):62.7 | Design:Xover | men and women > 50 y withcholesterol >3.36mmol/L; women were postmenopausal | 1. soy diet with isoflavones isolated soy protien, enriched with isoflavones | 1. animal diet with isoflavones | Total Cholesterol | AE:no
| (SD 8.8) | Randomized: Yes | Excluded:meds known to affect blood lipid levels | ISP with Isoflavone | The variable protein component was contributed by dairy and meat.Isoflavones, in the form of a powde | LDL | Drop out:1 female, and 8 males dropped:1 change in employment, 3 change in med status, 3 change in family member's med status, 2 disliked study food;subjects that dropped out were replaced
| Male%:43% | Blinding:other | | Diet composition:carb 46E, protein 16%, fat 37%, saturated fat 11.3, MUFA 14.4, PUFA 6.1, cholesterol 150 per 4.2 MJ | Diet composition:carb 48E, protein 15, fat 36, saturated fat 11.8, MUFA 14.3, PUFA 5.7, chol 168 per 4.2 MJ | HDL | Comment: Further subgroup analysis: benefit attributed to soy with respect to total cholesterol was limited to those with LDL >4.14 mmol/L
| Country: US | Duration:42 | | 2. soy diet without isoflavones | 2. animal diet without isoflavones | Triglyceride
| Sites:1 | days | | protein component was contributed by specially prepeared isolated soy protein, this specific one dep | This diet was designed to mimic a nonoptimal diet of a hypercholesterolemic subject. The variable pr | Apo A1
| BMI:26.6 | | | ISP without isoflavone | Diet composition:Bascially this is the control arm. | Apo B/100
| Soy1 N:57 | | | Diet composition:carb 45%, protein 17%, saturated fat 12.7, MUFA 14.7, PUFA 6.1, chol 151 per 4.2 MJ | carb 47E, protein 17%, fat 36%, saturated 12%, MUFA 14.2, PUFA 5.6, cholesterol 154 per 4.2 MJ | TC:HDL
| Soy2 N:57 | | | | | LDL:apoB
| Soy3 N:57 | | | | | HDL:apoA-1
| Control N:57
Lissin 2004 | Age (yr):61.7 | Design:RCT | post menopausal status as defined by absence of menses prev 12 mo, or if surgically menopausal, age >55; hypercholesterolemic: total chol >200 mg/dl or 5.2 mmol/l, and LDL >125 mg/dl or 3.2 mmol/l and not receiving lipid lowering meds | phytoestrogens | placebo | Total Cholesterol | AE:no
| 8.8 | Randomized: Yes | Excluded:current or recent use of ERT (within 2 mo); h/o of breast cancer, known atherosclerotic disease; current smoking; more than 6 servings of soy/wk | isoflavone tablets | Protein ND | LDL | Drop out:no
| Male%:0 | Blinding: double | | Soy Isoflavones without protein 2 tablets/d | Product2 tablets/d | Peripheral endothelial function | Comment: Baseline data given in percentages, no actual data
| Country: US | Duration:6 | | Diet composition:ND | Diet composition:ND
| Sites:1 | wks
| BMI:25.3
| Soy1 N:20
| Control N:20
Lu 1996 | Age (yr): | Design:NRNCT | healthy nonvegeterian women with regular menstrual cycles | Soy milk | No control | Menstrual cycle length | AE:ND
| Male%:0 | CohortSing | Excluded:ND | 3 12-oz portions of soy milk (one w/ each meal) daily for 1 mo under the supervision of dietary staf | | Progesterone | Drop out:yes
| Country: US | Duration:1 | | Diet composition: | | DHEA/DHEAS | Comment: sample size too small;baseline diet is not reported;eclusion criteria not explicitly described;% change given (not applicable in the tables)
| Sites:1 | mo | | | | 17 b estradiol
| BMI:ND
| Soy1 N:6
| Control N:0
Lu 2000 | Age (yr):32.7 | Design:NRNCT | Healthy premenopausal | 1. Soya-containing diet for one menstrual cycles on site. 2. SoyMilk | No control | Menstrual cycle length | AE:no
| (SD 6.6) | Randomized: No | Excluded:Smoker, vegetarian, intake > 2 alcohol drinks/week, significant change in wt or eating habits, antibiotics taken preceding 3 mo, irregular menstrual cycles, on contraceptives preceding 6 mo | Diet composition: E 2341, Fat 35.5%E, carb 50.1%E, protein 14.0%E | | LH | Drop out: 16/26 “Main reason for dropouts was frequency of blood drawing”
| Male%: 0 | Blinding:No | | | | FSH | Comment:Lipids not data extracted due to NRNCT
| Country: US | Duration: 4.2 wks | | | | Estradiol
| Sites:1 | | | | | Progesterone
| BMI:71.5 | | | | | Total Cholesterol
| Soy1 N:26 | | | | | LDL
| Control N:0 | | | | | HDL
| | | | | | Triglyceride
Lu 2001 | Age (yr):34.4 | Design:NRNCT | Healthy premenopausal | 1. Soya-containing diet for one menstrual cycles on site. 2. SoyMilk without isoflavones | No control | LH | AE:ND
| (SD 5.1) | Randomized: No | Excluded:Smoker, vegetarian, intake > 2 alcohol drinks/week, significant change in wt or eating habits, antibiotics taken preceding 3 mo, irregular menstrual cycles, on contraceptives preceding 6 mo | Diet composition: E 2352, Fat 35.9%E, carb 49.8%E, protein 14.0%E | | FSH | Drop out: ND
| Male%: 0 | Blinding:No | | | | Estradiol | Comment:Lipids not data extracted due to NRNCT
| Country: US | Duration: 3 wks | | | | Progesterone
| Sites:1
| BMI:25.8
| Soy1 N:9
| Control N:0
LydekingOlsen 2004 | Age (yr):57.8 | Design:RCT | At least 1 year postmenopausal, with a maximum age of 75 years, had not received any bone-active medication for at least 2 years previously and had at least 3 risk-criteria for osteoporosis: early menopause < 45 years of age, low-energy bone-fractures | 1. Soy milk rich in isoflavones | No non soy control | Bone mineral density | AE:yes
| (SD 8.4) | Randomized: Yes | Excluded:drug or alcohol addition, malignant disease, immobility, current steroid treatment, osteomalacia, DM, unstable thyroid disease, severe osteoarthritis in lumbar spine/kip, chronic inflammatory diseases, active liver and kidney disease | Soymilk rich in isoflavones | | Bone mineral content | AE Report:29% experienced milk and temporary side effects dur to soymilk, not leading to cessation: mild digestive trouble (nausea, bloating, flatulence 23%), undesired weight gain (fluid retention, 9%), milk throat irritation (4%), milk hot flushes (2%) and tempor
| Male%:0 | Blinding: | | Diet composition:ND | | serum-type | Drop out:lost to followup (n=3 in soymilk witho isoflavones group); soy intolerance (n=3 and n=2 in soymilk with and witho isoflavones groups respectively); Aversone (n=1 in soymilk witho isoflavones group)
| Country: Denmark | Duration:2 | | 2. Soymilk w/o isoflavones | | Equol | Comment: There are one transdermal progesterone (TDP) group (n=27); combine TDP and soymilk group (n=26)
| Sites:1 | years | | Soymilk produced by alsohol washed soy concentrate with only 1.0 mg isoflavones /day | | Type-I C-terminal telopeptide
| BMI:24.0 | | | Diet composition:ND | | Type-I procollagen N-terminal peptide
| Soy1 N:26
| Control N:28
Mackey 2000 11216493_study1 | Age (yr):56.40 | Design:RCT | postmenopausal women, 45–65.. Fasting cholesterol >5.5 mmol. | 1. ISP- and NHF diet | No control (compared between soy 1 and soy 2) | TSH | AE:no
| (SD 4.92) | Randomized: Yes | Excluded:H/o of allergy to soy, or taking any cholesterol lowering drug. | soy protein isolate with content of 4 mg isoflavones/d | | Total Cholesterol | Drop out: 54 women randomized, 46 completed. 3 discontinued and were not contactable, 5 dropped out
| Male%:0 | Blinding: double | | ISP without isoflavone | | LDL | Comment:For lipids no data on what n= for baseline and final
| Country: Australia | Duration:12 | | Diet composition:ND | | HDL
| Sites:1 | wks | | 2. ISP+ and NHF diet | | Triglyceride
| BMI:68.88 | | | soy protein with isoflavone content of 65 mg isoflavones/d | | Serum bone specific alkaline phosphatase
| Soy1 N:22 | | | ISP with Isoflavone | | Serum Osteocalcin
| Soy2 N:24 | | | Diet composition:ND | | Urine deoxypyridinoline
| Control N:0 | | | | | "menopause
| | | | | | Sex Hormone Binding Globulin
| | | | | | LH
| | | | | | FSH
Mackey 2000 11216493_study2 | Age (yr):51.5 | Design:NRNCT | Males over 40; fasting total cholesterol >5.5 mmol/L | 1. ISP+ | No control | TSH | AE:no
| Male%:100 | CohortSing | Excluded:H/o of allergy to soy or if taking cholesterol lowering agents | 28 g ISP with isoflavone content of 65 mg/d | | Total Cholesterol | Drop out:no
| Country: Australia | Blinding:No | | ISP with Isoflavone | | LDL | Comment: open prospective observational pilot study
| Sites:1 | Duration:12 | | Diet composition:ND | | HDL
| BMI: | wks | | 2. ISP- | | Triglyceride
| Soy1 N:27 | | | soy protein isolate with content of 4 mg isoflavones/d | | Sex Hormone Binding Globulin
| Control N:0 | | | ISP without isoflavone | | LH
| | | | Diet composition:ND | | FSH
| | | | | | Testosterone
| | | | | | Androstenedione
| | | | | | DHEA/DHEAS
Martini 1999 | Age (yr):25.5 | Design:Xover | Women 18–40 years from the University community, screened initially by phone in response to advertising in university newspapers and fliers | Soy diet | 10 fluid oz of skim milk | Menstrual cycle length | AE:ND
| Male%:0 | Randomized: Yes | Excluded: ND | Soy diet composition: Each serving provided 104 kcal, 20 g protein, 6 g carb, | Total Protein: ND | Sex Hormone Binding Globulin | Drop out: 3 OC users reported alterations in their menstrual cycle with the addition of soy (breakthrough bleeding or slightly delayed menses)highly irregular periods; soy allergy
| Country: US | Blinding: ND | | | Total Product: 10oz | Estradiol | Comment: duration= 2 menstrual cycles
| Sites:1 | Duration: 8.5 wks | | | Diet composition: ND | Estrone
| BMI:21.2 | | | | | Progesterone
| Soy1 N:40 | | | | | Prolactin
| Control N:40 | | | | | DHEA/DHEAS
| | | | | | Ratio Progesterone
| | | | | | Ratio 2-OH
Maskarinec 2002 | Age (yr):43 | Design:RCT | Premenopausal women 35–46 yr, regular dietary consumption of soy foods <7 serving/wk, normal mammogram during the last 6 mo, intact uterus and ovaries, regular menstrual periods | Soy_isoflavone_mixture as 100 mg tablets | Placebo tablet | Menstrual cycle length | AE:no
| Male%:0 | Randomized: Yes | Excluded: previous h/o cancer, oral contraceptive or any hormonal replacement, pregnancy, serious medical conditions | Diet composition: E 1795kcal/d, Fat 60.9g/d | Protein | Sex Hormone Binding Globulin | Drop out:ND
| Country: US | Blinding: double | | | Product:100 mg/d | LH | Comment: same as paper w/ REF ID 2111
| Sites:1 | Duration:12 | | | Diet composition: E 1705kcal/d, Fat 63.5g/d | FSH
| BMI:ND | mo | | | | Estradiol
| Weight:145lbs | | | | | Estrone
| Soy1 N:17 | | | | | Estrone Sulfate
| Control N:17 | | | | | Progesterone
Maskarinec 2003 | Age (yr):41.1 | Design:RCT | Women who had received a normal screening mammogram | Soy Isoflavone | placebo | Mammographic density | AE:ND
| (SD 3.1) | Randomized: Yes | Excluded:ND | daily regimen of 100 mg of Soy Isoflavone mixture equivalent to 76 mg glycosidess | Protein | | Drop out: 2 women decided not to have another mammogram at the end of the study, one follow-up mammogram not located, one woman left the study after 8 mo
| Male%:0 | Blinding: double | | Diet composition:E 1735kcal/d; fat 66g | Product | | Comment: randomization, blinding, and allocation concealment not explicitly described
| Country: US | Duration:12 | | | Diet composition: E 1736kcal/d; fat 61g
| Sites:1 | mo
| BMI:23.6
| Soy1 N:15
| Control N:15
Maskarinec 2004 | Age (yr):43.2 | Design:RCT | Women who had received a normal screening mammogram | Soy diet | Regular diet | E1 | AE:ND
| (SD 2.7) | Randomized: Yes | Excluded:Women on oral contraceptives or other sex hormones, diagnosed with cancer, no uterus, one ovary, regular menses, ≥6 wk serving of soy | Tofu, soy milk, soy nuts, soy protein bar and soy protein powder | Protein:ND | E2 | Drop out: 17 (15.6%) in the soy and 14 (12.6%)in the control
| Male%:0 | Blinding: double | | Diet composition: 641kcal from soy | Product:ND | Free E2 | Comment: randomization: blocked randomization, blinding, and allocation concealment not explicitly described
| Country: US | Duration:24 | | | Diet composition: ND | SHBG
| Sites:1 | mo | | | | Progesterone
| BMI:25.9 | | | | | Adione
| Soy1 N:109
| Control N:111
McMichaelPhillips 1998 | Age (yr):33.5 | Design:RCT | women with benign and malignant breast conditions who were attending clinics fo women with symptomatic breast problems at the University Hospital of South Manchester | Soy bread rolls | normal unsupplemented (without soy) diet | number of epithelial cells in the S phase of the cell cycle | AE:no
| (SD 8.09) | Randomized: Yes | Excluded:menstrual irregularities; medication likely to alter pituary function from baseline; consumption of lucagons or soy-rich diets | 4 bread rolls daily that contained a total of 60 g soy (in the form of ground textured vegetable pro | Protein ND | progesterone receptor expression | Drop out:no
| Male%:0 | Duration:14 | | Textured1 | Product ND
| Country: UK | days | | Diet composition: | Diet composition:
| Sites:1
| BMI:ND
| Soy1 N:19
| Control N:29
Meinertz 1988 | Age (yr):41 | Design:Xover | healthy normolipidemic men and women of normal body weight, | ISP | casein formula diet | Total Cholesterol | AE:no
| (SD 14) | Randomized: Unclear | Excluded: smoking, meds | soy protein formula diet | Protein119 = 2263/1500*315/4 | LDL | AE Report:
| Male%:50 | Blinding:No | | Supro | Product:ND | HDL | Drop out:no
| Country: Denmark | Duration:1 | | ISP with Isoflavone | Diet composition:casein 139 g, energy 1500 kcal, protein 315 g/l, fat 43 g/l, carb 198 g/l, chol 46 mg/l. Mean 2263 Kcal/day | Triglyceride | Comment: None
| Sites:1 | mo | | Diet composition:ISP 140 g, 54 g safflower oil, energy 1430 kcal, protein 287 g/l, fat 45 g/l, carb 184 g/l, chol 8 mg/l | | Apo A1
| BMI:62 | | | | | Apo B/100
| Soy1 N:10
| Control N:10
Meinertz 1989 | Age (yr):33 | Design:Xover | healthy normolipidemic men and women of normal body weight | Soy protein diet | Calcium caseinate | Total Cholesterol | AE:no
| Male%:45 | Randomized: Unclear | Excluded:ND | ISP without isoflavone | Protein121 | LDL | Drop out:no
| Country: Denmark | Blinding:No | | Soy protein diet (soy-protein isolate) (Purina 660) | ProductNd | HDL | Comment: See Meinertz 1988 RefID #4197
| Sites:1 | Duration:31 | | Supro | Diet composition:139 g casein, 54 g safflower oil | Triglyceride | Unclear what was extracted from the soy protein
| BMI:64.1 | days | | Diet composition:energy 2477 kcal, 112 g/d protein, fat 75 g/d, carb 338 g/d, chol 486 mg/d | energy 2494 kcal, 121 g/d protein, fat 69 g/d, carb 296 g/d, chol 549 mg/d
| Soy1 N:11
| Control N:11
Meinertz 2002 | Age (yr):30 | Design:Xover | normolipidemic subjects, mostly medical students. All had normal liver, kidney, thyroid function—none used meds regularly, none used HRT. | 1 extracted protein soy diet | liquid-formula casein diet | Total Cholesterol | AE:no
| (SD 13) | Randomized: Unclear | Excluded:as above | Liquid-formula diet containing ethanol-extracted soy protein. | Protein | LDL | AE Report:“excellent compliance”
| Male%:50 | Blinding:No | | Supro 670IF=8.2 mg lipid, 0.11 mg iso | Product | HDL | Drop out:no
| Country: Denmark | Duration:32 | | Supro | Diet composition:energy 2494 kcal, 121 g/d protein, fat 69 g/d, carb 296 g/d, chol 549 mg/d | Triglyceride | Comment: Unclear what was extracted;Change in extracted soy protein significantly greater than change in soy protein.
| Sites:1 | days | | ISP without isoflavone | | Lpa | Data from Meinertz 1989
| BMI:22.5 | | | Diet composition:
| Soy1 N:12 | | | 1 intact protein diet
| Soy2 N:12 | | | Liquid-formula diet containing soy protein.
| Control N:12 | | | Supro 670HG=63 mg lipid, 2.39 mg isoflavone (glycosides)/
| | | | Supro
| | | | ISP with Isoflavone
| | | | Diet composition:
MerzDemlow 2000 | Age (yr):26.3 | Design:Xover | Healthy premenopausal women 18–35 yr, normal menstrual cycles, not taking antibiotics or oral contraceptives within 6 mo, not taking regular meds, relatively sedentary, 90–120% ideal body lucag, BMI 18–25 kg/m2, not vegetarian, consumed diets low in fiber | 1 SPI as beverage powder | soy protein isolates as beverage powder 10mg isoflavone | Total Cholesterol | AE:no
| (SD 4.8) | Randomized: Yes | Excluded:h/o of food allergies, smokers, pregnant or lactating | ISP with Isoflavone (high) | Total Protein: ND | LDL | Drop out: 6/20 lack of compliance difficulties. 1/14 was hypercholesetrolemic and was excluded.
| Male%:0 | Blinding: double | | Diet composition: energy 2216 kcal, protein 117.7 g, carb 291.3 g, total fat 67.4, SFA 21.2, PUFA 11, MUFA 15.8, cholesterol 181.8 | Total Product: ND | HDL | Comment: In the article 10mg isoflavone was the control; but report no control arm for soy
| Country: US | Duration:3 menstrual cycles + 9d | | 1 SPI as beverage powder | Diet composition:0.15 with- 0.01 mg isoflavones, or 10 mg isoflavones/d | Triglyceride
| Sites:1 | | | ISP with Isoflavone (low) | energy 2277 kcal, protein 115 g, carb 294.2 g, total fat 75.8, SFA 23.7, PUFA 12.4, MUFA 20, cholesterol 194.3 | Lpa
| BMI:64 | | | Diet composition: energy 2275 kcal, protein 114 g, carb 296.9 g, total fat 73.7, SFA 23.7, PUFA 13, MUFA 17.4, cholesterol 238.5
| Soy1 N:20
| Soy2 N:20
| Control N:20
Meyer 2004 | Age (yr):54.0 | Design:Xover | Men or post-menopausal women, total plasma cholesterol > 5.5 mmol/l, mildly elevated BP > 140/90 mm Hg | soy | 4 serving/day (250 ml per serving) of low fat dairy milk or yoghurt into their normal diet | Total Cholesterol | AE:no
| (SD 1.8) | Randomized: Yes | Excluded:taking meds for either HTN or lipids, low habitual consumption of soy or n-3 foods | 4 serving/day (250 ml per serving) consisting of: | nonfat milk | LDL | AE Report:
| Male%:57 | Blinding:No | | So Natural Milk: fat 2.9g/100, carb 7.5 g/100, 3.1 g protein | ProteinND | HDL | Drop out: ND
| Country: Australia | Duration:5 | | SoyMilk | Product | Triglyceride | Comment: Self-reporting of dairy & soy consumption; significant differences in fat composition between soy and control arm
| Sites:1 | wks | | and yoghurt | Diet composition: Energy 1900 Kcal, protein 20%E, carb 43%E, fat 33%E, SFA 36%E, MUFA 36%E, PUFA 30%E | Lpa
| BMI:75.9 | | | Diet composition: Energy 2100 Kcal, protein 21%E, carb 45%E, fat 29%E, SFA 44%E, MUFA 42%E, PUFA 25%E | | SBP
| Soy1 N:26 | | | | | DBP
| Control N:26 | | | | | Systemic arterial compliance
Mitchell 2001 | Age (yr): ND | Design:NRNCT | Healthy, 18 – 35 y males, no significant reproductive medical h/o, normal semen quality, normal serum levels of oestradiol, testosterone, FSH, LH | soy_extract | No control | LH | AE:no
| Male%:100 | Randomized: No | Excluded:Vegetarian, significant reproductive medical h/o | subjects received 500 mg tablets consisting of standardized soy extract containing 40 mg, in total, | | FSH | Drop out: 1 WD midway in supplement period, 3 at final post-supplement assessment
| Country: UK | CohortSing | | Soy Isoflavones without protein | | Estradiol | Comment: limited data; assessments twice before intervention, twice during and 3 times post-intervention
| Sites:1 | Blinding:No | | Diet composition:ND | | Testosterone
| BMI:ND | Duration:2
| Soy1 N:15 | mo
| Control N:0
Morabito 2002 | Age (yr):52 | Design:RCT | Healthy, ambulatory women aged 47–57 who had not undergone surgically-induced menopause, had not had a period in the preceding year, and who had a FSH level >50 UI/L and an E2 level of <=100 pmol/L | Genistein | Placebo tablets | PTH:1 | AE:yes
| 3 | Randomized: Yes | Excluded:Cardiovascular, lucago, or renal disorders, coagulopathy, use of oral or transdermal estrogen, progestin, androgen, or other steroids in the preceding year, smoking habit of more than 2 cigarettes per day, previous treatment with any drug that could affect the skeleton; family h/o estrogen dependent cancer; BMD at femoral neck >0.795 g/cm2 | 54 mg/day. | Protein | Bone mineral density | AE Report: endometrial thickness >5 mm (3/30 genistein, 3/30 placebo); vaginal bleeding (1/30 genistein, 1/30 placebo); also reported
| Male%:0 | Blinding: double | | Soy Isoflavones without protein | Product | Serum bone specific alkaline phosphatase | Drop out:no
| Country: Italy | Duration:1 | | Genistein tablets obtained for Lab. Plants (Messina, Italy). The purity of the genistein | Diet composition: Isocaloric fat-restricted diet 30%E from fat, <10% E from sat fat, Cholesterol intake <300mg/d | Urine deoxypyridinoline | Comment: There is also a 3^rd^ arm, HRT; Do not report allocation concealment, do not address drop-outs/withdrawals
| Sites:1 | years | | Diet composition: Isocaloric fat-restricted diet 30%E from fat, <10% E from sat fat, Cholesterol intake <300mg/d | | Urine pyridinoline
| BMI:24 | | | | | Bone Gla p
| Soy1 N:30 | | | | | FSH
| Control N:30 | | | | | Estradiol
Murkies 1995 | Age (yr):53.8 | Design:RCT | postmenopausal women (from interested patients and newspaper ads) with at least 12 mo amenorrhea, an FSH >15 mIU/mL, hot flushes>14/wk; non-smokers; not on antibiotics or HRT for the previous 3 mo | Soy flour | 45 g/d wheat flour: the flour was to be taken preferably raw (eg added to a drink or mixed w/ cereal | Total Cholesterol | AE:ND
| (SD 1.07) | Randomized: Yes | Excluded:ND | 45 g/d soy flour: the flour was to be taken preferably raw (eg added to a drink or mixed w/ cereal). | Other control: | HDL | Drop out: 11 (5 soy and 6 wheat)
| Male%:0 | Blinding: double | | Soy diet | wheat flou | Triglyceride | Comment: no data on baseline diet, co-morbidities or medcation;exclusion criteria not explicitly reported;amount of protein not specified
| Country: Australia | Duration:12 | | Soy flour | Protein | Urinary calcium
| Sites:1 | wks | | Diet composition:ND | Product45 g | urine hydroxyproline
| BMI:26.5 | | | | Diet composition:ND | Vaginal cell maturation index
| Soy1 N:28 | | | | | FSH
| Control N:30 | | | | | Equol
| | | | | | Menopausal symptom score
| | | | | | flushes, score
| | | | | | urine enterolactone
Murray 2003 | Age (yr):56.3 | Design:RCT | Healthy postmenopausal women over 45 years old with an FSH level > 40 mIU/mL and an intact uterus | 1.ISP with Isoflavone | 1.placebo plus 0.5mg Estradiol | Total Cholesterol | AE:yes
| 7.4 | Randomized: Yes | Excluded:Use of HRT within 3 mo of initiating study, obesity (BMI > 30), endometrial hyperplasia or cancer, breast cancer, cerebrovascular accident, myocardial infarction, CVD, gallbladder disease, h/o of thrombosis, active liver disease, undiagnosed ge | SPI plus 0.5 mg Estradiol | Protein:ND | LDL | AE Report:GI intolerance 1 in SPI group, 1 in TMP placebo; 2 cervical stenosis; 1 unrelated surgery in SPI+1mgE group, 1 abnormal uterine bleeding in SPI+1mgE group
| Male%:0 | Blinding: double | | Protein powder plus oral micronized estradiol tablets | Product38 g | HDL | Drop out:same as AE
| Country: US | Duration:6 | | Diet composition:ND | Diet composition:ND | Triglyceride | Comment:This paper in table 5 compares 9 other isoflavone RCTs on the effect on postmenopausal endometrium
| Sites:1 | mo | | | 2.placebo plus 1.0 mg Estradiol | Type 1 Collagen cross-linked N-teleopeptide
| BMI:24.6 | | | 1 ISP with Isoflavone | Protein:ND | Endometrial thickness
| Soy1 N:8 | | | SPI plus 1.0 mg Estradiol | Product38 g
| Soy2 N:8 | | | Protein powder plus oral micronized estradiol tablets: | Diet composition:ND
| Control1 N: | | | 38 g SPI as lucagons packets containing 2
| Control2 N: | | | Diet composition:ND
Nagata 1998 | Age (yr):26.1 | Design:RCT | Female students and teachers who were premenopausal and not lucagon in a nursing school course. | Soy.milk | Continue with their usual diet. | Menstrual cycle length | AE:no
| 7.9 | Randomized: Yes | Excluded:Endocrine disease (DM or adrenal). Taking hormonal medication | Instructed to consume about 400 mL of soymilk daily. | Other control: | Sex Hormone Binding Globulin | Drop out: No
| Male%:0 | CohortMult | | Diet composition:1570 Kcal; Protein 60.0 g; Fat 54.2 g; Cholesterol 231 mg; carb 199 g; Fiber 2.7 g; EtOH 3.6 mL | Regular di | Estradiol | Comment: Subanalysis of women who had blood drawn on days 9–12 in both cycles 1 and 3. The remaining women are included in the main analysis.
| Country: Japan | Blinding:No | | 45.4 g soy products; Isoflavones from soy products 19.4with-15.0 mg | Protein51.4 g | Estrone
| Sites:1 | Duration:2 menstrual periods | | | Product
| BMI:20.6 | | | | Diet composition:Results imply that controls were told to not drink any soy milk.
| Soy1 N:31 | | | | 1486 Kcal; Protein 51.4 g; Fat 48.8 g; Cholesterol 221 mg; carb 202 g; Fiber 2.6 g; EtOH 2.7 mL
| Control N:29 | | | | 0 g soymilk. 43.9 g soy products; Isoflavones from soy products 18.4with-13.4 mg
Nagata 2001 11303585 | Age (yr):32 | Design:RCT | Teachers and students in a nurse school | soymilk | habitual diet | Sex Hormone Binding Globulin | AE:ND
| (SD 8.4) | Randomized: Yes | Excluded:Current use of hormonal medication, diagnosis of prostatic disease, DM, chronic liver disease, or any endocrine disease | The soymilk-supplemented group was required to consume 400 ml (408 g) of soymilk daily for 8 weeks. | Protein0 g from soymilk | Estradiol | Drop out:One in the soymilk-group dropped out-sick on the first day
| Male%:100 | Blinding:No | | Diet composition: E 2244Kcal, protein 73.6g/d, fat 77.3g/d, carb 287g/d | ProductND | Estrone | Comment: randomized method not clear, no blinding
| Country: Japan | Duration:8 | | | Diet composition:2030 kcal/day: 72.7 g/d protein, 63.5 g/day fat; 290 g/day carb | Testosterone
| Sites:1 | wks
| BMI:23.3
| Soy1 N:17
| Control N:17
Nestel 1997 | Age (yr):54.0 | Design:Xover | postmenopausal, perimenopausal women | soy isoflavone tablet | Placebo tablet | Total Cholesterol | AE:no
| (SD 6.0) | Randomized: Yes | Excluded:age > 69 y and HRT, other supplements such as vitamin E and primrose oil, meds that might affect lipids or CV function, smoking, >14 standard alc drinks/wk | isoflavone tablet 40g for 5 wks | Protein | LDL | Drop out: 2 drop out; reasons ND
| Male%:0 | Blinding:other | | ISP with Isoflavone | Product | HDL | Comment: Oxidation stress outcomes were carried out only in 1^st^ 15 subjects; Trial began 40 mg/d X 5 wks. When results did not lucago, dosage was raised to 80 mg and the trial was extended 5 more wks.
| Country: Australia | Duration:5 | | Diet composition: <30%E fat | Diet composition: <30%E fat | Triglyceride
| Sites:1 | wks | | | | MAP
| BMI:27.0 | | | | | Peripheral endothelial function
| Soy1 N:21 | | | | | Systemic arterial compliance
| Control N:21 | | | | | Oxidized LDL
| | | | | | FBS
Nikander 2003 12798527 | Age (yr):54 | Design:Xover | postmenopausal women who had been treated for breast CA; no residual malignant disease; incapacitating climacteric complaints; FSH>30 U/L | phyto | similar-looking placebo tablets | Menopausal symptom | AE:ND
| (SD 6) | Randomized: Yes | Excluded:use of sex steroids including tamoxifen; use of natural products with possible estrogenic activity; use of drugs possibly affecting climacteric symptoms, or metabolism or absorption of phytoestrogens (eg, abx during the previous 3 mo); h/o of any throm | 6 phytoestrogens tablets (total of 114 mg of phytoestrogens, an extract of soy isoflavones) per day | Protein:0 | Kupperman index | Drop out: 2 stomache ache, 1 recurrent breast CA, 1 personal reason, 1 vaginal bleeding, 1 lack of effect
| Male%:0 | Blinding: double | | SSP1 | Product:6 tab/d | Work ability | Comment: Same as Nikander 14602747, 15001611, 15240647
| Country: Finland | Duration:3 | | Diet composition:ND | Diet composition:ND | depression
| Sites:1 | mo | | | | Sr creatinine
| BMI:26.3 | | | | | Sex Hormone Binding Globulin
| Soy1 N:60 | | | | | LH
| Control N: 60 | | | | | FSH
| | | | | | Estradiol
| | | | | | Equol
| | | | | | Other outcomes: Anxiety and Self-confidence
| | | | | | aspartate transaminase; alanine transaminase
Nikander 2003 14602747 | Age (yr):54 | Design:Xover | Post menopausal women who were treated for breast cancer previously and devoid of metastasis at recruitment. Patients who had chemotherapy had been discontinued 5 mo to 4 yr before recruitment. All women had incapacitating hot flashes and other climacteric symptoms and menopause confirmed by FSH >30U/L | phytoestrogen tablet | Placebo tablets | C-reactive protein | AE:no
| (SD 6) | Randomized: Yes | Excluded:FSH <30U/L and taken a course of antibiotics within previous 3 mo | Three phytoestrogen tablets were to be taken every 12 hr with a glass of water (6 tablets/day). | Protein:ND | E-selectin | Drop out: 6 women discontinued the trial during the first treatment regimen: 4 in the phytoestrogen group (1-stomach ache; 1-personal reason; 1-recurrent breast cancer) and 2 in the placebo group (1-lack of effect and 1-vaginal bleeding)
| Male%:0 | Blinding: double | | Diet composition: ND | Product: 6 tab/day | Nitrous oxide | Comments: See Nikander 2003, and 2004; 15001611, 15240647
| Country: Finland | Duration:3 | | | Diet composition:ND
| Sites: | mo
| BMI:26.3
| Soy1 N:60
| Control N:60
Nikander 2004 | Age (yr):54 | Design:Xover | postmenopausal women treated for breast cancer 8 mo to 22 yr before. 1) lack of residual malignant disease 2) incapacitating climacteric complaints such as hot flashes, night sweats, sleeplessness 3) FSH >30 U/L | Isoflavonoid tablets (Bonette, Novomed, Helsinki) 19 mg of isoflavoids each. 3 tablets every 12 hour | Similar looking placebo | Serum bone specific alkaline phosphatase | AE:yes
| (SD 6) | Randomized: Yes | Excluded:1) use of sex steroids such as tamoxifen 2) use of natural products withpossible estrogenic activity 3) use of drugs affectring climacteric symptoms, metabolism, or absorption of phytoesterogens incl antibiotics within 3 mo 4) h/o of thromboembolic or hepatic | Soy Isoflavones without protein | Protein:0 | Urine deoxypyridinoline | AE Report:4 in PE group= 2 for stomach ache, 1 personal, 1 recurrence of lucag cancer, 2 in placebo group= 1 for lack of effect, 1 for vaginal bleeding
| Male%:0 | Blinding: double | | Diet composition: ND | Product: ND | Urine pyridinoline | Drop out:Same as AE
| Country: Finland | Duration:3 | | | Diet composition: ND | Type 1 Collagen cross-linked N-teleopeptide | Comment: See Nikander 12798527, 14612747, 15240647
| Sites:1 | mo | | | | PINP; PICP
| BMI:25.8
| Soy1 N:60
| Control N:60
Nikander 2004 15240647 | Age (yr):54 | Design:Xover | Post-menopausal women treated for breast cancer more than 6 mo earlier, without metastatis, Incapacitating hot flashes and other climacteric symptoms. At least 6 mo post-menopausal. FSH > 30 U/L. | Isoflavonoid tablets (Bonette, Novomed, Helsinki) 19 mg of isoflavoids each. 3 tablets every 12 hour | Similar looking placebo | Total Cholesterol | AE:yes
| (SD 6) | Randomized: Yes | Excluded:HRT, Tamoxifen, statins, natural products with presumed estrogenic activity, drugs possibly affecting lucagonsc symptoms, antibiotics and other substances affecting the metabolism or absorption of phytoestrogens. History of thromboembolic or hepatic event | Soy Isoflavones without protein | Protein:0 | LDL | AE Report:2 stopped during phytoestrogen treatment because of stomach ache.
| Male%:0 | Blinding: double | | Diet composition: ND | Product: ND | HDL | Drop out: 6 (4 isoflavonoid: 2 stomach ache, 1 personal, 1 breast ca recurrence; 2 placebo: 1 “lack of effect”, 1 vaginal bleeding)
| Country: Finland | Duration:3 | | | Diet composition: ND | Triglyceride | Comment: See Nikander 12798527, 14612747, 15001611
| Sites:1 | mo | | | | Lpa
| BMI:26.3 | | | | | Apo A1
| Soy1 N:62 | | | | | Apo B/100
| Control N:62 | | | | | SBP
| | | | | | DBP
| | | | | | FBS
| | | | | | Oral glucose tolerance test
| | | | | | Insulin
Nilausen 1999 | Age (yr): 37 (SD 16.8) | Design:Xover | active healthy normolipidemic men | 1 liquid formula soy diet | casein | Total Cholesterol | Adverse event: No
| Male%:100 | Randomized: Unclear | Excluded:ND | Supro | Total Protein: ND | LDL | Dropouts:0
| Country: Denmark | Blinding:No | | ISP with Isoflavone | Total Product: ND | HDL | Comment: None
| Sites:1 | Duration: 4.2 wks | | Diet composition: daily intake 154 g, protein constituted ~20E intake | Diet composition:carb ~55E, fat ~25E, chol 55 mg/MJ | Triglyceride
| BMI:22.9 | | | carb ~55E, fat ~25E, chol 55 mg/MJ | | Lpa
| Soy1 N:9
| Control N:9
Onning 1998 | Age (yr):31.5 | Design:Xover | healthy nonsmoking volunteers | soya milk | Oat milk | Total Cholesterol | AE:no
| Male%:50 | Randomized: Yes | Excluded:ND | Tofu-line sweetened . Women 750 mL/day; Men 1L/day SoyMilk | medium fat | LDL | Drop out: 1 dropout due to pregnancy
| Country: Sweden | Blinding:No | | Diet composition:energy 1900 kJ, 30 g protein, 20 g fat, 40 g carb, 5.6 dietary fiber | Protein:15g | HDL | Comment: insufficient data; group A received oat milk 4 w and soya milk 4 w; group B received oat milk 4 w and cow's milk 4 w.
| Sites:1 | Duration:4 | | | Product Women 750 mL/day; Men 1L/day | Triglyceride
| BMI:20–25 | wks | | | Diet composition:energy 1990 kJ, 34 g protein, 17 g fat, 49 g carb | Antioxidant status
| Soy1 N:24 | | | | | FBS
| Control N:24
Pap 1983 | Age (yr):43.9 | Design:NRNCT | chronic pancreatitis based on typical h/o, starch tolerance test or limiodol test or both;pancreatic insufficiency for 6 mo based on screening tests | soy flour | No control | Lundh Test measurement of Trypsin, Lipase and Amylase | AE:ND
| Male%:56 | Randomized: No | Excluded:ND | Natural (raw) soy flour (Rakosvolgye Co., Budapest) three times a day, 30 gm in 250 ml water 15 min | | Secretin-Pancreozymin Test of Trypsin, Lipase | Drop out:yes
| Country: Hungary | CohortSing | | Diet composition:ND | | | Comment: %change from pretreatment value (100%) and pretreatment value not reported
| Sites:1 | Blinding:No
| BMI:ND | Duration:1
| Soy1 N:34 | mo
| Control N:0
Pap 1984 | Age (yr):42.6 | Design:Xover | chronic pancreatitis | soy flour | Cholecystokinin octapeptide as intranasal drops | Lundh test result | AE:ND
| (SD 2.78) | Randomized: Yes | Excluded:ND | Natural (raw) soy flour (Rakosvolgye Co., Budapest) three times a day, 30 gm in 250 ml water 15 min | Protein:0 | Trypsin, Lipase, Amylase results | Drop out:ND
| Male%:70 | CohortMult | | Diet composition:ND | Product:2 dropsx3 times daily | | Comment:wide interval between two treatments; incomplete data; estimated from graph; lacking complete data on the actual study design
| Country: Hungary | Blinding:No | | | Diet composition:ND
| Sites:1 | Duration:1
| BMI:ND | mo
| Soy1 N:10
| Control N:10
Penotti 2003 | Age (yr):52.5 | Design:RCT | 45–60 yr women; postmenopausal for at least 6 mo; FSH, and 17-Beta E2 levels within the postmenopausal range within the authors' laboratory; LDL cholesterol <160 mg/dl; no major disease, no HTN, DM, heart disease, renal or peripheral vascular diseases | isoflavone | one gram tablet twice a day; | Menopausal symptom | AE:ND
| Male%:0 | Randomized: Yes | Excluded: | One gram tablet before lunch and before dinner. | contains 0.5 g of talc and 0.5 g of microcrystalline cellulose | hot flushes | Drop out: one patient in the isoflavone group: onset of diarrhea; the other dropouts in both groups: persistence of hot flushes.
| Country: Italy | Blinding: double | | Contains 36 mg of soy-derived isoflavones | Protein:ND | Endometrial thickness | Comment:None
| Sites:1 | Duration:6 | | Soy Isoflavones without protein | Product1g | pulsatility
| BMI:23.2 | mo | | Diet composition:ND | Diet composition:ND
| Soy1 N:28
| Control N:34
Persky 2002 | Age (yr):59.3 (ISP56) | Design:RCT | completion of menopause, >= 1 y since the last menstrual period, and a total plasma cholesterol concentration of 6.2 – 7.8 mmol/L. | 1 ISP56 | Casein+usual diet | T3 | AE:no
| Male%:0 | Randomized: Yes | Excluded: On hormone replacement therapy, other medication to lower cholesterol, h/o of lucagon mellitus or thyroid lucago, chronic illness that affect lipid measurements or limit participation in the study | Group patients continue their basal diets to which 40 g test protein/d was incorporated as ISP conta | Group patients continue their basal diets to which 40 g test protein/d was incorporated as casein | T4 | Drop out:yes
| Country: US | Blinding: double | | Supro | Protein40 | TSH | 1 moved to another state, 3 withdrew:medical problems unrelated to soy-product consumption, and 3 withdrew :Lack of compliance with the study protocol. One woman who was taking levothyroxine was excluded from the analysis.
| Sites:multiple | Duration:24 | | ISP with Isoflavone | Product:ND | Cortisol | Comment: patients and laboratory personnels blinded
| BMI:28.0 | wks | | Diet composition: | Diet composition:ND | Other ENDO:1
| Soy1 N:24 | | | 1 ISP90 | | free thyro
| Soy2 N:23 | | | Group patients continue their basal diets to which 40 g test protein/d was incorporated as ISP conta | | Sex Hormone Binding Globulin
| Control N:25 | | | Supro | | FSH
| | | | ISP with Isoflavone | | Estradiol
| | | | Diet composition:ND | | Estrone
| | | | | | Estrone Sulfate
| | | | | | DHEA/DHEAS
| | | | | | Sex Hormone Binding Globulin-bound
| | | | | | Urinary 2OHE
| | | | | | Urinary 16aOHE
| | | | | | Equol
| | | | | | Insulin:lucagons
| | | | | | Insulin
| | | | | | Glucagon
Petrakis 1995 | Age (yr): 29–58 | Design:NRCT | Pre and postmenopausal women volunteered to a prior study on nipple aspirate fluid. Also included were nonpregnant women who had yielded breast fluid by nipple aspiration | Soy supplement as beverage | Daily diet | Nipple fluid aspirate | AE:No
| Male%:0 | Randomized: No | Excluded:ND | Two pkts of ISP | Historical control | Volume | Drop out:37% for 12 mos
| Country: US | Blinding: No | | 37.4 g of protein | Protein:ND | Color | Comment: Included were 24 women from an original cohort of 37
| Sites:1 | Duration: | | 37.4 g of genistein | Product: ND | Cytology
| BMI:ND | Intervention:6 mo | | Diet composition: ND | Diet composition: ND | GCDFP15
| Soy1 N:24 | Follow-up:12 mo | | | | Estradiol
| Control N:24 | | | | | Progesterone
| | | | | | SHBG
| | | | | | Prolactin
| | | | | | Composite menstrual cycle
| | | | | | Total Cholesterol
| | | | | | HDL
| | | | | | Triglyceride
Petri 2004 | Age (yr):53.7 | Design:RCT | last menses 12 mo before study, FSH > 40 mIU/L, symptoms of estrogenic privation (hot flushes) and contraindications or intolerance to conventional HRT | soy supplement | lactose caps | Total Cholesterol | AE:yes
| (SD 5.45) | Randomized: Yes | Excluded:veg or macrobiotic diets, Asians, smokers, alcoholics, h/o of chronic GI diseases, use of HRT, tamoxifen or antibiotics within 6 mo, thyroid dysfunctions | 4 cap X 500 mg soy germ/d | milk1 | LDL | AE Report:2 isoflavones, 1 placebo=discreet vaginal bleeding (2 atrophic endometrium, 1 polyp), 3 isoflavones reported constipation, 2 flatulence, 2 nausea. 2 placebos reported constipation, and flatulence.
| Male%:0 | Blinding: double | | ***These capsules contained soy germ in a glycosilated natural form | lactose | HDL | Drop out: no dropouts
| Country: Brazil | Duration:6 | | isoflavone soy capsule | Protein:ND | Triglyceride | Comment: pts randomized at baseline exhibited elevated baseline values of cholesterol and LDL compared to placebo group (P< 0.05); from graph
| Sites:1 | mo | | Diet composition:ND | Product:4cap/day | LH
| BMI:27.97 | | | | Diet composition: ND | FSH
| Soy1 N:25 | | | | | Estradiol
| Control N:25 | | | | | Kupperman menopausal index
Potter 1993 | Age (yr):61 | Design:Xover | Male outpatients at VAMC, Danville Illinois. | 1. soy flour | 2. nonfat dry milk | Total Cholesterol | AE:yes
| Male%:100 | Randomized: Yes | Excluded:chol <5.17 mmol/L, hyperlipidemia secondary to renal disease, med use known to alter lipoid metabolism, BB use for HTN, documented abnormality of thyroid | partially defatted extruded soy flour 6.5% fat | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E | LDL | AE Report:dropouts not related to soy consumption
| Country: US | Blinding:other | | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E | | HDL | Drop out: 6 dropouts in 1st wk, 6 dropouts who did not complete the project, 1 who required ophthalmol surgery
| Sites:1 | Duration:4 | | 2. soy protein isolate | | Triglyceride | Comment: 2 subjects were eliminated because TG were >5.65 mmol/L; same study as Ham 1993
| BMI:93.3 | wks | | 50 g daily Supro 610 | | Apo A1
| Soy1 N:25 | | | ISP without isoflavone | | Apo B/100
| Soy2 N:25 | | | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E
| Soy3 N:25 | | | 3.ISP with cellulose
| Control N:25 | | | 20 g dietary fiber (cellulose)
| | | | Diet composition: E ND, protein 20%E, carb 55%E, Fat 25%E
Potter 1998 | Age (yr):59.8 | Design:RCT | Completion of menopause with >= 1 yr since the last menstrual period, plasma cholesterol concentration between 6.2 and 7.8 mmol/L. | 1.ISP56 | Casein and non fat dry milk (CNFDM, containing 0 mg total glycosides isoflavones/d; New Zealand Milk Product) | Bone mineral density | AE:
| (SD 9.1) | Randomized: Yes | Excluded:Hormone Replacement Therapy, Any medications known to lower lipids, h/o of DM mellitus or thyroid disease, or chronic illness, allergies to soybean protein. | ISP with Isoflavone | Protein40 g | Bone mineral content | Drop out:
| Male%:0 | Blinding: double | | Basal diet + 40 g of soy protein and 56 mg total glycosides isoflavones/day, Supro 675, Protein Techno | Product:ND | LDL receptor mRNA | Comment: same as Baum 1998
| Country: US | Duration:24 | | 2. ISP90 | Diet composition:ND | Total cholesterol
| Sites:ND | wks | | ISP with Isoflavone | | HDL
| BMI:28.2 | | | Basal diet + 40 g of soy protein and 90 mg total glycosides isoflavones/day, | | Non-HDL
| Soy1 N:23 | | | Diet composition:ND | | Total:HDL
| Soy2 N:21
| Control N:22
Puska 2002 | Age (yr):52 | Design:RCT | chol 6.9–9.9 mmol/L, Triglyceride <4.5 mmol/L, age 17–75 for men, 45–70 for postmenopausal women (at elast 6 mo witho vaginal bleeding). | soya | Milk powder, calcium caseiate, and cellulose | Total Cholesterol | AE:yes
| Male%:75 | Randomized: Yes | Excluded:any signs of CV, renal, hepatic, endocrine, GI disease; familial hypercholesterolemia, type 1 or 2 DM treated withinsulin, any past or concomitant use of statins, n-3 or other lipid-lowering drugs (incl foods) during past 8 wk. HRT within past 6 mo, no drug or alcohol dependency, no eating disorder and no plan for loss of weight | ISP supplement | Protein | LDL | AE Report:“no seriius adverse effects”--slight increase in serum uric acid values.
| Country: Finland | Blinding: double | | Abacor | Product | HDL | Drop out:6/30 from Abacor tx, and 2/30 placebo dropped out because of GI symptoms
| Sites:1 | Duration:6 | | ISP with Isoflavone | Diet composition:ND | Triglyceride | Comment: The difference between the study groups for drop outs was sig from the soy
| BMI:84 | wks | | Diet composition:ND | | Lpa
| Soy1 N:24 | | | | | Apo B/100
| Control N:28 | | | | | Homocysteine
Puska 2004 | Age (yr):58 | Design:RCT | chol 6.9–9.9 mmol/L, Triglyceride <4.5 mmol/L, age 17–75 for men, 45–70 for postmenopausal women (at elast 6 mo witho vaginal bleeding). | Soy yogurt | placebo yoghurt | Total Cholesterol | AE:yes
| Male%:48 | Randomized: Yes | Excluded:any signs of CV, renal, hepatic, endocrine, GI disease; familial hypercholesterolemia, type 1 or 2 DM treated withinsulin, any past or concomitant use of statins, n-3 or other lipid-lowering drugs (incl foods) during past 8 wk. HRT within past 6 mo, no drug or alcohol dependency, no eating disorder and no plan for loss of weight | 1 cup bid soya protein | Protein:12.2 | LDL | AE Report:intolerability of product: nausea, vomiting, stomach pain, feeling of stomach swelling--symptoms all mild and transient
| Country: Finland | Blinding: double | | Diet composition: ND | Product:ND | HDL | Drop out: 14 from the soy arm and 3 from the placebo group. Statistically sig drop out from the soy arm compared to control
| Sites:ND | Duration:8 | | | Diet composition: ND | Triglyceride | Comments: None
| BMI:82.2 | wks | | | | SBP
| Soy1 N:69 | | | | | DBP
| Control N:74 | | | | | Homocysteine
Quella 2000 | Age (yr): 34, 66 | Design:Xover | women >18 yr, h/o of breast CA; currently no residual malignant disease;hot flashes (requiring interventions) ≥14 times/week for at least 1 month;life expectancy ≥6 mo AND Eastern Coop Onc Group score of 0 or 1; tamoxifen or raloxifene Rx is allowed if the pt had started such drug at least 4 weeks before registration and was planning to continue throughtout the term of the trial | soy tablet | identical appearing placebo tablet | hot flash score | AE:no
| Male%:0 | Randomized: Yes | Excluded:current or planned Rx with antineoplastic chemo, androgens, estrogens, progestational agents or steroids; agents for hot flashes, like megestrol acetate, clonidine, vit E, belladonna, phenobarb, ergotamine tartrate or other SOY products | 600 mg tablet one tablet three times a day for 4 weeks | Total Protein: ND | hot flash as mild, moderate, severe or or very severe | AE Report:no difference between the two study arms with regard to diarrhea, vomiting, nausea or bloating/gas
| Country: US | Blinding: double | | Diet composition: ND | Total Product: ND | | Drop out: 12%stopped medication early;did not complete diary forms appropriately
| Sites:1 | Duration: 8 wks | | | Diet composition: ND | | Comment: May be some biases because some patients are on tamoxifen and/or raloxifene
| BMI:
| Soy1 N:175
| Control N:175
Rivas 2002 | Age (yr):47.5 | Design:RCT | Both Men and women with essential HTN as diagnosed after no cause of HTN was detected after a complete investigation were included in the study. Patients had HTN of degree 1 or 2 according to the JNC on Detection, Evaluation, and Treatment of High Blood P | Soy milk | Cow's milk | SBP | AE:no
| (SD 10.4) | Randomized: Yes | Excluded:Urinary genistein >100 mu mol/L | Diet composition:Supplied by Calcimel, Santivery s.a., Barcelona, Spain | Protein15.5 grams | DBP | Drop out:ND
| Male%:14/20 | Blinding:ND | | Isoflavanoid concentration and chemical characteristics in soy milk: Genistein 80 (SD 8); Daidzein 63 (SD 9); Equol ND; protein 18 g/L; carb 13.5 g/L; Lipids 10.5 g/L; Calcium 600 mg/L; Energy 2 | Product1 Liter | Mean blood pressure | Comment: Men aged 18–70 yr and women aged 50–70 yr were included. NO definite description of pre or post menopause Method of randomization, blinding, allocation concealment not stated
| Country: Spain | Duration:3 | | | Diet composition:Leche Pasual desnatada (Spain) | Equol
| Sites:1 | mo | | | Isoflavanoid concentration and chemical characteristics in cows milk: Genistein ND; Daidzein ND; Equol ND; protein 15.5 g/L; carb 25 g/L; Lipids 1.5 g/L; Calcium 600 mg/L; Energy 175 kJ/L
| BMI:ND
| Soy1 N:20
| Control N:20
Ross 1995 | Age (yr):ND | Design:Xover | healthy adults consuming a typical american diet (low in fruit and vegetables) | Soy diet | commonly consumed foods and no fruits and vegetables and was essntially phytochemical free | Platelet derived growth factor | AE:ND
| Male%:47 | Randomized: Yes | Excluded:medical H/o of gastrointestinal symptoms; food allergies; weight loss and gain >4.5kg within the past year; major changes in eating habits within the last year or significant short-term dietary changes (such as seen with high intensity exercise regimens, alcohol intake >2 drinks/d, OCD by women, smoking and unwillingness to consume all foods provided | Tofu | Protein:ND | PDGF-AA; PDGF-BB | Drop out:4;unexpected prgnancy; logistical problems; non-compliance
| Country: US | Blinding:ND | | control diet plus daily servings of firmed tofu and 45g FriChick, a textured vegetable protein product | Product:ND | mitogenic activity | Comment:no specific baseline characteristics are given;quantity of tofu not reported
| Sites:1 | Duration:9 | | Diet composition:ND | Diet composition:ND
| BMI:ND | days
| Soy1 N:23
| Control N:23
Russo 2003 | Age (yr):53.3 | Design:Xover | Recent menopause, 48 - 54 y, Caucasian, Neg PAP test, normal pelvic US, symptoms of Climacteric syndrome | isoflavones | Comercially available preparation based on phyto-oestrogens against a placebo | Menopausal symptom | AE:No
| (SD 3.3) | Randomized: Yes | Excluded:Surgical h/o for genital or mammary neoplasia, HRT within 6 mo, arterial hypertension and/or cardiovascular pathologies, endocrinological pathologies, nicotinism, obesity, alcohol or narcotic abuse | Comercially available preparation based on phyto-oestrogens against a placebo | Protein:ND | hot flushes | Drop out:Non-hormone-dependent neoplastic pathology (1), intense vegetative syndrome (1), spotting after 15 days (1)
| Male%:0 | Blinding: double | | Soy oil, 5 mcg vitamin D, | Product:ND | | Comment:None
| Country: Italy | Duration:3 | | Diet composition:ND | Diet composition:ND
| Sites:1 | mo
| BMI:26.3
| Soy1 N:50
| Control N:50
Sagara 2004 | Age (yr):52.2 | Design:RCT | Systolic blood pressure 130 mmHg or higher and/or Total Cholesterol 220 mg/dL or higher. | Soy powder | placebo group | Total Cholesterol | AE:ND
| (SD 3.9) | Randomized: Yes | Excluded:Presence of DM mellitus and any other chronic illnesses that could affect BP or blood lipid concentration or limit individual's ability to participate in the study, and use of anti-hypertensive drugs, cholesterol lowering drugs and any medication kn | Soy powder mixed in cereals, biscuits and bread rolls were consumed in addition to the usual diet. | Other control: | HDL | Drop out:8 (13%) subjects withdrew during the 5 wk intervention; 2 because of missing the blood sampling; One excluded prior to data analysis for noncompliance with the diet
| Male%:100 | Blinding: double | | Diet composition:ND | cereals, b | SBP | Comment: There is a difference in soy protein and isoflavones between the text and the table. Entered below are from the text.
| Country: UK | Duration:5 | | | Protein26.7 g | DBP
| Sites:12 | wks | | | Product | non HDL-C
| BMI:27.6 | | | | Diet composition:ND | non HDL-C/HDL-C ratio
| Total enroll:61
| Soy1 N:25
| Control N:25
Saxena 1999 | Age (yr): | Design:NRNCT | Patient with platelet functional defect and with lab test available for PCI, PF3 availability and platelet aggregation studies | Soya Bean, consumed in the form of boiled beans, soya flour or soya milk. | No control | Miscellaneous outcomes; | AE:
| Male%: | Randomized: No | Excluded:ND | Soy bean | | Bleeding | AE Report:
| Country: India | CohortSing | | SoyMilk | | Platelet studies | Drop out:
| Sites:1 | Duration:3mo | | Soy diet | | | Reason:
| BMI:ND | | | soya flour
| Soy1 N:45 | | | Diet composition:ND
| Control N:0
Scambia 2000 | Age (yr):54 | Design:RCT | Postmenopausal women: spontaneous amenorrhea at least 12 mo, surgical or early menopause; and Ecarb endomerial thickness <4.5 mm; negative X-ray mammograpphy; metabolic and biochemical index within normal range | 1. Soy tablet | Placebo tb contained lactose, cellulose microcrystalline, sillica colloidal, and sodium Mg stearic | PTH | AE:No side effects
| (SD 7.1) | Randomized: Yes | Excluded: involved in any clinical trial 6 mo before entering this study | 12% isoflavones and 35% saponins. | Total Protein: ND | Total Cholesterol | Drop out: refusal of patients to undertake certain tests
| Male%:0 | Blinding: double | | 200 mg SOYSELECT, lactose, cellulose microcrystalline, sillica colloidal, and sodium Mg stearic | Total Product: ND | LDL | Comment: diet and medication not reported; not explicitly reported whether women on HRT were excluded; power calculations not reported; race not reported; No follow up values or differences were reported
| Country: Italy | Duration:10 wks | | Soy Isoflavones without protein | Diet composition: ND | HDL
| Sites:1 | | | Diet composition: ND | | Triglyceride
| BMI:26.2 | | | | | Endothelin -1
| Soy1 N: 20 | | | | | Serum Osteocalcin
| Control N:19 | | | | | Vaginal cell maturation index
| | | | | | Menopausal symptom
| | | | | | vasomotor symptoms and the Greene climacteric scale
| | | | | | Endometrial thickness
| | | | | | Pulsatility index of uterine artery
| | | | | | LH
| | | | | | FSH
| | | | | | Prolactin
Scheiber 2001 | Age (yr):55.5 | Design:NRNCT | Menopausal (either natural or surgical) women with amenorrhea for > 6 mo and an FSH level > 23 IU/L at enrollment. | Soy Nuts | No control | Total Cholesterol | AE:yes
| (SD 5.2) | Randomized: No | Excluded:Women on estrogens, progestins, androgens, corticosteroids, or antioxidant drugs within the 4 mo before enrollmen, or on a full course of antiobiotics within 3 mo of enrollment, or h/o of estrogen-dependent | Whole soy nuts (10 gm/serving) or commercially available soy milk drinks (SoGood, 250 mL/serving). | | LDL | AE Report:2 subjects dropped out due to intestinal bloating
| Male%:0 | Blinding:No | | SoyMilk | | HDL | Drop out:no
| US:1 | Duration:12 | | SSP1 | | Triglyceride | Comment: Did not define “post-menopausal;Do not report total grams of soy protein in intervention, or bread down the different levesl of isoflavones.
| Country: US | wks | | Diet composition: | | Oxidized LDL
| Sites:1 | | | | | Serum bone specific alkaline phosphatase
| BMI:27.1 | | | | | Serum Osteocalcin
| Soy1 N:42 | | | | | Type 1 Collagen cross-linked N-teleopeptide
| Control N:0 | | | | | FSH
| | | | | | Estradiol
Secreto 2004 | Age (yr):53 | Design:Factorial | Postmenopausal women aged >= 35 years; last menstrual flow > 6 mo before recruitment; any condition for which classic HRT is not recommended | 1. Soy isoflavones | Placebo | Greene Climacteric Scale | AE:yes
| Male%:0 | Randomized: Yes | Excluded:Breast cancer therapy or HRT during the previous 3 mo; overt endocrinopathy (DM, hyperthyroidism etc.); intolerance to soy | Each soy capsule contained 300 mg of soy extract, equivalent to 40 mg of isoflavones. | sorbitol | Psychological subscale | AE Report:Gastric intolerance, tachycardia, increased body weight, insomnia, excessive drowsiness, headache and constipation.
| Country: Italy | Blinding: double | | Soy extract | Protein0 | Somatic subscale | Drop out: 9%; lost to follow-up, did not received allocated treatment, discontinued treatment for adverse events or other causes.
| Sites:3 | Duration:3 | | Diet composition:ND | Product2 identical capsules per day | Vasomotor subscale | Comment: NOTE: Some subjects also received melatonin only; AE breakdown incomplete report
| BMI:Median 23.8 | mo | | 2. Isoflavone+melatonin | Diet composition:ND
| Soy1 N:65 | | | Each soy capsule contained 300 mg of soy extract, equivalent to 40 mg of isoflavones.
| Soy2 N:64 | | | Soy extract
| Control N:67 | | | Diet composition:ND
Shorey 1981 | Age (yr):26 | Design:RCT? | Mildly hypercholesterolemic males from the student and Faculty population at the University of Texas at Austin and those who gave informed consent for the study | Soy protein diet | Animal protein diet | Total Cholesterol | AE:yes
| (SD 4) | Randomized: Unclear | Excluded:ND | Soy analogs and soy milk | Other control: | HDL | AE Report:Increased fecal bulk and flatulence unclear if reported by soy arm or both arms
| Male%:100 | Blinding:ND | | Soy diet | Restructur | Triglyceride | Drop out:One withdrew for job related reasons, one was in a car accident, and one exhibited wide fluctuations in triglyceride from lipid analysis.
| Country: US | Duration:6 | | SoyMilk | Protein58.5 g | HDL-C/Total cholesterol | Comment: None
| Sites:1 | wks | | Diet composition: Energy 2469 with-137 kcal; Protein 87with-7g; carb 333with-26g; Fiber 7with-2 g; Fat 93with-7 g; Sat fat 33g cholesterol 183 | Product
| BMI:79.1 | | | | Diet composition: 2400 kcal with 13 to 15% of energy from protein, 30 to 35% from fat and remainder from carb.
| Soy1 N:14
| Control N:13
Simons 2000 | Age (yr):59 | Design:Xover | Healthy postmenopausal volunteers 50–70 yr (LMP >12 mo), significant endothelial dysfunction, nonsmoking, cholesterol <8.0 mmol/L and Triglyceride <3.0 | Phytoestrogen (PE) tablets bid | placebo | Total Cholesterol | AE:yes
| Male%:0 | Randomized: Yes | Excluded: Cardiac renal, hepatic disease or DM. Vitamins, and minerals supplementation, lipid-regulating drugs, warfarin, antihypertensive medications, sex hormones | Soy bean | Total Protein: ND | LDL | AE Report:on placebo, 1 parasthesiae in arm and leg, 1 head noises, 1 laparocholecystectomy.On PE, 1 parasthesiae and 1 brief menstrual period 5 wk into tx.
| Country: Australia | Blinding: double | | Diet composition: isocaloric fat restricted diet, 30%E fat, <10% E sat fat, cholesterol <300 | Total Product: ND | HDL | Drop out: 3 dropout--one PE- vaginal spotting and bleeding; One on placebo severe menopausal symptoms and 1 moved out
| Sites:1 | Duration:8 wks | | | Diet composition: isocaloric fat restricted diet, 30%E fat, <10% E sat fat, cholesterol <300 | Triglyceride | Comment:None
| BMI:26.8 | | | | | Lpa
| Soy1 N:23 | | | | | BP
| Control N:23 | | | | | Peripheral endothelial function
| | | | | | Glyceryl trinitrate induced dilation
| | | | | | Flow mediated dilation
Sirtori 1999 | Age (yr):51.9 (SD 13.5) | Design:Xover | Severe hypercholesterolemia (13 genetic, 8 sporadic) with cholesterol >7.8 mmol/L and LDL >5.8 mmol/L in absence of drug tx, Triglyceride <2 mmol/L | Soya milk supplemented diet | Cows' milk supplemented diet | Total Cholesterol | AE:no
| Male%:38 | Randomized: Yes | Excluded:type I or II DM, alcoholism or alcohol liver disease, severe ailments: cancer, degenerative mental disease, heart or kidney failure | | Total Protein: 70g/d | LDL | no dropouts--side effects vague (side effects occurred during cows' milk period probably as result of lactose intolerance"
| Country: Italy | Blinding: double | | Diet composition:500 ml fluid milk to achieve 7% protein content energy 1124 kJ/d, protein 70 g/l, fat 22 g/l | Total Product: 500ml | HDL | Comment: Data below derives from later study: Sirtori 2002 RefID#354;Control baseline and final values from graph
| Sites:1 | Duration:4 wks | | 2 dietary schedules 1400 kcal and 2000kcal | Diet composition: 2 dietary schedules 1400 kcal (carb 56.7, fat 25.1, protein 18.2) and 2000kcal (carb 59.9, fat 24.3, protein 15.8) | Triglyceride
| BMI:24.4 | | | | | SBP
| Soy1 N:21 | | | | | DBP
| Control N:21 | | | | | FBS
Sirtori 2002 | Age (yr):59.5 | Design:Xover | type II hypercholesterolemics withcholesterol >7 mmol/L, LDL >5.5. | Soya milk supplemented diet | Cow' milk supplemented diet | Total Cholesterol | AE:no
| 8.35 | Randomized: Yes | Excluded:alc intake >4 standard drinks/d or >40 g alcohol/d, diabetics on meds or insulin, SBP >160 mm Hg or DBP >95. Meds for dyslipidemia or agents that affect lipids, vegetarians or those consuming >1 soy-containing milk serving/d | | Total Protein: 70g/d | LDL | no dropouts--side effects vague (side effects occurred during cow' milk period probably as result of lactose intolerance”
| Male%:20 | Blinding: double | | Diet composition:500 ml fluid milk to achieve 7% protein content energy 1124 kJ/d, protein 70 g/l, fat 22 g/l | Total Product: 500ml | | Comment: same as Sirtori 1999 RefID#783
| Country: Italy | Duration:4 | | 2 dietary schedules 1400 kcal and 2000kcal | Diet composition: 2 dietary schedules 1400 kcal (carb 56.7, fat 25.1, protein 18.2) and 2000kcal (carb 59.9, fat 24.3, protein 15.8)
| Sites:1 | wks
| BMI:24.2
| Soy1 N:20
| Control N:20
Soroka 1998 | Age (yr): 30–85 | Design:Xover | CRF patients, CrCl between 15 and 50 ml/min/1.73 m2 and the 24-hour urinary protein excretion < 3 g/day/1.73 m2 (i.e. no patient had nephrotic syndrome) | Vegetable protein diet (VPD): (1) soya-based schnitzels, hamburger, and sausage (2) Soy drink | Animal-protein diet (APD) 50% protein from eggs, chicken, meat, turkey, fish, and milk; 50% protein from bread. | Total Cholesterol | AE:ND
| Male%:56 | Randomized: Yes | Excluded:DM or other systemic diseases | Diet composition: E 2,049kcal/d, protein 48.9g/d, carb 54.5%E, fat 35.8%E, proteins 9.45%E | Protein:0.75 g/kg/day | LDL | Drop out:6
| Country: Israel | Blinding:ND | | | Product:ND | HDL | 2 cerebrovascular accidents, 1 refusal to have GFR test performed a second time, 1 rapid worsening of the renal function after receiving an ACE inhibitor, and 2 non-compliant
| Sites:1 | Duration:6 | | | Diet composition: E 1,838 kcal/d, protein 52.5 g/d, carb 55.5%E, fat 33.3%E, proteins 11.13%E | Triglyceride | Comment: VPD had a highercaloric intake, a lower proteinintake, and a lower protein intake per kilogram body. Small sample size and high dropout rate (40%)
| BMI:ND | mo | | | | GFR
| Soy1 N:15 | | | | | Sr creatinine
| Control N:15 | | | | | BUN
| | | | | | serum albumin
| | | | | | Urinary calcium
Squadrito 2002 | Age (yr):54 | Design:RCT | healthy ambulatory women aged 52–60 who had not undergone surgical menopause, had no menstrual cycle in preceding yr, FSH > 50 IU/L, estradiol <100 pmol/L. | genistein | placebo | Total Cholesterol | AE:yes
| (SD 7) | Randomized: Yes | Excluded:any clinical or lab abnormailities that suggested cardiovasc, hepatic, or renal disorders; coagulopathy; used oral or transdermal estrogen, progestin, androgen or other steroids in preceding yr; smoked >10 cigs/d; had taken cholesterol-lowering or CV meds | genistein 54 mg/d | Protein:ND | LDL | AE Report:In genistein, 2 women had brief menstrual period after 5 wk tx, 1 woman had vertigo. In placebo, 2 pts had paresthesiae and 1 had vertigo.
| Male%:0 | Blinding: double | | Diet composition:isocaloric fat restricted diet 30%E fat, 10%E from sat fat, chol <300 mg/d | Product:ND | HDL | Drop out: genistein, 2 brief menstrual period after 5 wk tx, 1 vertigo. In placebo, 2 paresthesiae and 1 vertigo.
| Country: Italy | Duration:6 | | | Diet composition:isocaloric fat restricted diet 30%E fat, 10%E from sat fat, chol <300 mg/d | Triglyceride | Comment:Similar cohor as Squadrito 2003
| Sites:1 | mo | | | | SBP
| BMI: ND | | | | | DBP
| Soy1 N:30 | | | | | Endothelin -1
| Control N:30 | | | | | Peripheral endothelial function
| | | | | | Estradiol
Squadrito 2003 | Age (yr):56 | Design:RCT | healthy ambulatory women aged 52–60 who had not undergone surgical menopause, had no menstrual cycle in preceding yr, FSH > 50 IU/L, estradiol <100 pmol/L. | genistein | placebo | Peripheral endothelial function | AE:yes
| (SD 7) | Randomized: Yes | Excluded:clinical or lab abnormailities that suggested cardiovasc, hepatic, or renal disorders; coagulopathy; used oral or transdermal estrogen, progestin, androgen or other steroids in preceding yr; smoked >10 cigs/d; had taken cholesterol-lowering or CV meds. | genistein 54 mg/d | ProteinND | Endothelin -1 | AE Report:Breast tenderness in 3 on genistein, 5 on HRT, 1 on placebo. Vaginal bleeding in 1 on genistein, 5 on HRT, 1 on placebo. Hot flushes on 5 in genistein, 1 on HRT, 11 during placebo
| Male%:0 | | | Soy diet | Product ND | vascular resistance | Drop out:Same as AE and Endometrial thickness >5 mm occurred to 3
| Country: Italy | Blinding: double | | genistein | Diet composition:ND | Estradiol | Comment: a 3rd arm is EPT: 17B-estradiol 1 mg/d withnorethisterone acetate n=26. Similar cohort as Squadrito 2003
| Sites:1 | Duration:12 | | Diet composition:ND
| BMI: | mo
| Soy1 N:27
| Control N:26
St Germain 2001 | Age (yr):50 | Design:RCT | nonsmoking perimenopausal women, experiencing at least nd hot flushes and/or night sweats/week, within 12 minths of their last menstrual cycle, free from chronic disease or chronic medication use, not taking HRT or ERT during the time of the study or 12 m | 1. SPI+ | Whey protein control | Menopausal symptom | AE:no
| Male%:0 | Randomized: Yes | Excluded:FSH < 30 IU/mL | Soy protein isolate with isoflavones (Supro) | Total Protein: 40 | hot flush | Drop outs:Inability to tolerate treatment (n=6), death (n=1), death of a fmily member (n=1), medical conditions preventing their continual (n=2), or noncompliance (n=1)
| Country: US | Blinding: double | | Diet composition: | Total Product: ND | Other symp | Comment: No breakdown demographic data for each group.
| Sites:1 | Duration:12 | | 2. SPI- | Diet composition: ND | Menopausal Index (to measure hot flush and night sweat frequency, duration and severity)
| BMI: ND | wks | | Soy protein isolate without isoflavones (Supro)
| Soy1 N:24 | | | Diet composition:ND
| Soy2 N:24
| Control N:21
Steinberg 2003 | Age (yr):54.9 | Design:Xover | healthy postmenopausal women; | ISP w/ isoflavones | total milk protein | Total Cholesterol | AE:yes
| (SD 1.0) | Randomized: Yes | Excluded:HRT use within 6 mo, hyperlipidemia (chol >5.17 mmol/L or 200 mg/dL), meds to treat high BP or hypercholesterolemia, GI abnormalities affecting dietary intake, prev heart attack or dx heart disease, hepatic or renal disease, DM, h/o of thrombosis or blood | ISP w/ naturally occurring isoflavones | Protein25 g | LDL | AE Report:no withdrawals due to adverse events once the trial began
| Male%:0 | Blinding: double | | ISP with Isoflavone | Product | HDL | Drop out: 42 enrolled/28 completed. Of 14 dropouts, 3 could not tolerate the tx, 2 GI disturbances, 1 because of taste intolerance.
| Country: US | Duration:6 | | Diet composition:25 g protein, 1g fat | Diet composition:energy 8.0 MJ, carb 263.7 g/d, protein 91.1 g/d, total fat 55.3 g/d, saturated fat 17.1 g/d, chol 178.1 mg/d, fiber 21.2 mg/d | Triglyceride | Comment: no baseline values
| Sites: | wks | | energy 7.6 MJ, carb 247.9 g/d, protein 89.6 g/d, total fat 52.4 g/d, saturated fat 15.5 g/d, chol 164.4 mg/d, fiber 21.6 mg/d | | Peripheral endothelial function
| BMI:24.6 | | | ISP w/o isoflavones | | Oxidized LDL
| Total enroll:42 | | | ethanol-washed ISP w/ trace amounts of isoflavones | | E-selectin
| Soy1 N:28 | | | ISP without isoflavone | | Endothelin -1
| Soy2 N:28 | | | Diet composition:24 g protein, 1 g fat | | Nitrous oxide
| Control N:28 | | | energy 7.2 MJ, carb 225.7 g/d, protein 84.3 g/d, total fat 52.1 g/d, saturated fat 16.3 g/d, chol 175.9 mg/d, fiber 19.4 mg/d | | VCAM-1
| | | | | | ICAM
Stroescu 2001 | Age (yr):14.9 | Design:RCT | Elite female gymnasts, members of the Romanian Olympic Team with primary amenorrhea (13/14 gymnasts) | ISP | placebo beverage: 10 g sugar, 3 g cocoa, 250 ml water. The total protein ratio per day and kg was 2. | Total Cholesterol | AE: ND
| (SD 1.3) | Randomized: Yes | Excluded: ND | Daily supplementation of 1 g of soy protein per kg body weight in the form of cocoa-flavoured bevera | Protein without fat | T3 | Drop out: ND
| Male%:0 | Blinding: double | | Supro | none repor | T4 | Comment: Small sample size; withdrawals are not reported; no statistical comparison between Tx and conrols at baseline is reported
| Country: Romania | Duration:4 | | Isolated Soy Protein, unclear re: Isoflavones | Total Protein: 2.8/Kg BW | serum: proteins, total fat, FFA, SGOT, SGPT, total Ca, Mg, IgA, IgM, IgG; urine mucoproteins
| Sites:1 | mo | | Diet composition: ND | Total Product: ND | Sr creatinine
| BMI:33.1 | | | | Diet composition: protein amount is higher in controls than in Tx subjects; type of protein in controls not specified | BUN
| Soy1 N:7 | | | | | Estradiol
| Control N:7 | | | | | Progesterone
| | | | | | Prolactin
| | | | | | Testosterone
| | | | | | 17-ketosteroids metabolites of androgenic steroids
Swain 2002 | Age (yr):50.2 | Design:RCT | perimenopausal women throughout Iowa and bordering states; >/= 10 flushes/wk; irregular menses or menstrual period cessation; FSH./=30 IU/L; BMI=20–31; no chronic disease; no excessively exercising; one or both ovaries remaining; able and willing to participate | 1. Isoflavone poor SPI | whey protein: 40g/day w/ 50% of this protein incorporated into a muffin and the 50% as a powde | Total Cholesterol | AE:no
| (SD 3.6) | Randomized: Yes | Excluded:chronic disease; routine use of medications; smoking; alcohol abuse; estrogen or HRT during the prior 12 mo; H/o of eating disorders | 40g/day w/ 50% of this protein incorporated into a muffin and the 50% as a powder that subject | Protein40 g | LDL | Drop out:ND
| Male%:0 | Blinding: double | | 2. ISP without isoflavone | ProductND | HDL | Comment: seperate description for each arm is not shown; isoflavone amount not specified
| Country: US | Duration:24 | | Isoflavone rich SPI | Diet composition:ND | Lpa
| Sites:1 | wks | | 40g/day w/ 50% of this protein incorporated into a muffin and the 50% as a powder that subject | | FSH
| BMI:24.1 | | | ISP without isoflavone | | Estrone
| Soy1 N:24 | | | Diet composition:ND | | 17b-estradiol
| Soy2 N:24 | | | | | serum ferritin, serum iron, transferrin saturation
| Control N:21 | | | | | Hb concentration
| | | | | | anthropometric measurements
Takatsuka 2000 | Age (yr):26.1 | Design:RCT | all premenopausal female students and teachers at Gifu Nursing SChool. | soy supplements | usual diet | Total Cholesterol | AE:No
| (SD 7.6) | Randomized: Yes | Excluded:h/o of endocrine diseases and HRT, chronic hepatitis or CVD. Total Chol >220 mg/dl or Triglyceride >160. | 400 ml (408 g) commercial regular soymilk/d. | Total Protein: ND | LDL | Drop out: 8 excluded after randomization
| Male%:100 | Blinding: double | | Diet composition: E 1569 kcal/d, protein 59.9g, fat 54.5g, carb 197.5g | Total Product: ND | HDL | Comment:None
| Country: Japan | Duration:2 | | | Diet composition: E 1491 kcal/d, protein 50.7g, fat 50.2g, carb 200g | Triglyceride
| Sites:1 | mo
| BMI:20.4
| Total enroll:60
| Soy1 N:27
| Control N:25
Teede 2001 | Age (yr):61 | Design:RCT | Healthy participants men and women 50–75 yr | soy | casein | Total Cholesterol | AE:yes
| (SD 1) | Randomized: Yes | Excluded:no antibiotics or soy products or suppls for 3 mo, no estrogen therapy for 3 mo;moderate to severe menopausal symptoms, smoking over past 10 yr, alcohol consumption >30 g/d, hypertension, abnormal uterine bleeding, cervical cytology, or mammogram and coexistent major illness | ISP w/isoflavones, 2 sachets/d | Total Protein: ND | LDL | AE Report:34/213 withdrew soy: 3 GI including constipation, placebo: 2; soy: 1 diarrhea, placebo 2; soy: 1 hot flashes; soy: 2 exclusions due to high FSH
| Male%:53.6 | Blinding: double | | 28 g powdered ISP | Total Product: ND | HDL | Drop out: 34/213 withdrew
| Country: Australia | Duration:3 | | ISP with Isoflavone | Diet composition: ND | Triglyceride | Comment: None
| Sites:1 | mo | | Diet composition: ND | | Lpa
| BMI:25 | | | | | SBP
| Soy1 N:105 | | | | | DBP
| Control N:108 | | | | | Peripheral endothelial function
| | | | | | Systemic arterial compliance
| | | | | | pulse wave
| | | | | | LH
| | | | | | FSH
| | | | | | Testosterone
Teede 2004 | Age (yr):61 | Design:RCT | postmenopausal women 50–75 yr with 12 mo amenorrhea and FSH >20IU/L | soy | Casein placebo | TBG | AE:No
| (SD 1) | Randomized: Yes | Excluded:no antibiotics or soy products or suppls for 3 mo, no estrogen therapy for 3 mo; moderate to severe menopausal symptoms, smoking over past 10 yr, alcohol consumption >30 g/d, HTN, abnormal uterine bleeding, cervical cytology, or mammogram result and coexistent major illness. | ISP with Isoflavone | Protein:ND | C-reactive protein | Drop out:no
| Male%:0 | Blinding: double | | Diet composition: ND | Product:ND | Sex Hormone Binding Globulin | Comments: nested trial from a larger study of 210 healthy participants (Teede 2001 11443167)
| Country: Australia | Duration:3 | | | Diet composition:ND | LH
| Sites:1 | mo | | | | FSH
| BMI:26 | | | | | DHEA/DHEAS
| Soy1 N:30
| Control N:20
Teixeira 2000 | Age (yr):43.3 | Design:RCT | Free living men age >23, Total Cholesterol 5.69–7.76 mmol/L, BMI 20–33 | 1. 20 g Supro Plus 675HG plus 30 g casein | 50 g casein | Total Cholesterol | AE:yes
| (SD 11.4) | Randomized: Yes | Excluded:DM, thyroid disease, chronic disease that affect lipids, any medication that affect lipds. Weight variation >3 kg during the study. | ISP with Isoflavone | Total Protein: 50 g | LDL | AE Report:2 possible allergic reactions such as skin rash and itching
| Male%:100 | Blinding: double | | 2. 30 g Supro 675HG plus 20 g casein | Total Product: ND | HDL | Drop out: 8 dropouts due to AE
| Country: US | Duration:6 wks | | ISP with Isoflavone | Diet composition:NCEPstepI diet 30%E fat, <10%E sat fat, <300mg cholesterol/d | Triglyceride | Comment:None
| Sites:1 | | | 3. 40 g Supro 675HG plus 10 g casein | | Lpa
| BMI:27.1 | | | ISP with Isoflavone50 g ISP | | Apo A1
| Soy1 N:15 | | | 4. 50 g Supro 675HG | | Apo B/100
| Soy2 N:18 | | | Supro
| Soy3 N:17 | | | ISP with Isoflavone
| Soy4 N:15 | | | Diet composition:NCEPstepI diet 30%E fat, <10%E sat fat, <300mg cholesterol/d
| Control N:16
Tonstad 2002 | Age (yr):51.4 | Design:RCT | Men aged 30–70 yr and post menopausal women aged 45–70 yr with total cholesterol 5.8–7.9 mmol/L and triacylglycerol conc <4.5 mmol/L were eligible | 1. ISP 30g | Casein 30g and 50g | Total Cholesterol | AE:no
| (SD 9.8) | Randomized: Yes | Excluded:Significant CVD, renal, GI, endocrine disease, including DM type 1 and 2 treated with drugs; familial hypercholesterolemia; obesity (BMI >=30) and uncontrolled HTN (BP >160/100 mmHg), plan to lose weight during the study, alcohol consumption 28units/wk, intake of statins, n-3 supplements, other lipid lowering drugs and women on HRT within 6 mo of study | Isolated soy protein 30 gram available as ready to mix beverage | Protein30g and 50g | LDL | Drop out:Total 29: 19 withdrawals: 2 were lost to follow-up; 9 withdrew consent or were unable to comply with the study protocol; 1 developed angina pectoris; 1 complained dizziness; 6 complained GI problems. An additional 10 subjects were excluded from the statistical analysis
| Male%:83 | Blinding: double | | ISP with Isoflavone | Product | HDL | Comment: Quantity of ISP and soy protein clearly stated
| Country: Norway | Duration:16 | | Diet composition: | Diet composition:<30% E fat, <10%E sat fat, <300 mg cholesterol/d | Triglyceride
| Sites:2 | wks | | 2. ISP 50g | | Lpa
| BMI:24–25 | | | Isolated soy protein 50g available as ready to mix beverage | | Apo B/100
| Total enrol: 159 | | | ISP with Isoflavone | | SBP
| Soy1 N:34 | | | Diet composition:<30% E fat, <10%E sat fat, <300 mg cholesterol/d | | DBP
| Soy2 N:31 | | | | | Homocysteine
| Control N1:29 | | | | | Fibrinogen
| Control N2:36 | | | | | Alpha Tocopheral in mu mol/L, vit B12, folate
Uesugi 2002 | Age (yr):51.8 | Design:RCT | healthy perimenopausal employees of a food processing factory age 40–62 | soybean isoflavone extract | placebo capsules | Total Cholesterol | AE:No
| (SD 1.9) | Randomized: Yes | Excluded:ND | Isoflavone only | Protein:ND | LDL | AE Report:“no side effects were detected”
| Male%:0 | Blinding: double | | Diet composition:ND | Product:ND | HDL | Drop out:no
| Country: Japan | Duration:4 | | | Diet composition:ND | Triglyceride | Comment:None
| Sites:1 | wks | | | | Serum Osteocalcin
| BMI:22.9 | | | | | Urine deoxypyridinoline
| Soy1 N:12 | | | | | Urine pyridinoline
| Control N:11 | | | | | Bone stiffness
| | | | | | HgbA1c
Uesugi 2003 | Age (yr):53.7 | Design:RCT | age 45–65, 5–10 yr after natural menopause, weight 35–70 kg, no evidence of disease associated with osteoporosis or other med problems, no h/o of drug use, including estrogen, known to affect bone metabolism | isoflavone extract | dextrin | Total Cholesterol | AE:
| (SD 6.9) | Randomized: Yes | Excluded:as above | Soy Isoflavones without protein | Protein:ND | HDL | AE Report:
| Male%:0 | Blinding: double | | Diet composition:ND | Product:2 times daily | Triglyceride | Drop out:no
| Country: Japan | Duration:3 | | | Diet composition: | Urine pyridinoline | Comment:None
| Sites:1 | mo | | | | Urinary calcium
| BMI:52.0 | | | | | vaginal parabasal cytology
| Soy1 N:11 | | | | | FSH
| Control N:10
Unfer 2004 | Age (yr):49 | Design:RCT | intact uterus, absense of menses for 12 mo, FSH >30 IU/L, body weight range within 20% normal weight | phytoestrogens | Placebo tablets | Endometrial thickness | AE:no
| (SD 4.3) | Randomized: Yes | Excluded:any meds containing estrogens, progestins, androgens within 8 wks of trial, presence of endometrial hyperplasia | 3 tablets/d soy=150 mg isoflavones | ProteinND | | Drop out: 25 in the soy and 32 in the control
| Male%:0 | Blinding: double | | Soy Isoflavones without protein | Product:3/day | | Comment:Limited data
| Country: Italy | Duration:5 | | Diet composition:ND | Diet composition:ND
| Sites:1 | years
| BMI:67
| Soy1 N:179
| Control N:197
Upmalis 2000 | Age (yr):54.8 | Design:RCT | Healthy postmenopausal women age 50 years or older and in good overall health, with a BW within =-35% range for BMI, FSH levels of 40 mIU/mL or more, E2 levels of 25 pg/mL or less, and an average of 3 or more vasomotor symptoms per day. Subjects have discontinued | Soy isoflavone extract tablet (with little protein) | Placebo | Total Cholesterol | AE:yes
| (SD 4.9) | Randomized: Yes | Excluded:H/o of breast cancer, hyperplasia, endometrial carcinoma, or cervical neoplasia; a positive pregnancy test' undiagnosed abnormal vaginal bleeding, a bilateral oophorectomy or hysterectomy; thromboembolic disorders; h/o of CVDs; liver disease; h/o chronic alcoholism, medication hypersensitivity, or allergy to dietary supplement, uncontrolled addiction or severe depression, acute systemic infection or abnormal lab values | Diet composition: ND | Total Protein: ND | LDL | AE Report:30 (33.7%) of 89 subjects in the soy group reported a total of 70 adverse experiences, and 39 (45.3%) in the placebo group reported a total of 79 adverse experiences. Adverse experiences including respirotory, GI, and genital/reproductive systems. 1 subject due to UTI
| Male%:0 | Blinding: double | | | Total Product: ND | HDL | Drop out:16 Medication and diet noncompliance, discontinued the study before week 12, discontinued because of a urinary infection, baseline transvaginal ultrsound was not performed within 10 days of the first dose of study medication; 5 invalidity of endometrial and lab analysis
| Country: US | Duration:12 | | | Diet composition: ND | Triglyceride
| Sites:15 | wks | | | | Serum Osteocalcin
| BMI:152.2 | | | | | Type 1 Collagen cross-linked N-teleopeptide
| Soy1 N:89 | | | | | Endometrial thickness
| Control N:86 | | | | | FSH
| | | | | | Hot flushes
| | | | | | Night sweats
Van Horn L 2001 | Age (yr):66.6 | Design:RCT | Age > 50 yr and/or confirmed post menopausal status, Total Cholesterol concentrations above 5.17mmol/L on average with two screenings, and BMI <35. | 1. Oats/soy | 1. Oats and milk arm | Total Cholesterol | AE:No
| Male%:0 | Randomized: Yes | Additional eligibility criteria: not being on a weight loss diet; not taking fiber, soy or other dietary suppleme | 2. Wheat/soy | Protein without fat | LDL | Drop out:1/127 was unable to provide a final blood sample or food record
| Country: US: | Duration:6 | Excluded:Subjects allergic to soy, milk, or oats were excluded. | Soy protein powder | Total Protein: ND | HDL | Comment: Non fat milk protein powder served as the control product for soy. Cream of wheat or a non oat ready to cereal served as the control for oats. Well described study characteristics
| Sites:1 | wks | | ISP without isoflavone | Total Product: 29 gram
| BMI:26.6 | | | Diet composition: E ~1400, total fat 24%E, protein 18–19%E | Diet composition:The oat group incorporated 2 servings (56 g dry weight) of cooked oatmeal or (2oz) ready to eat oat bran cereal per day. Non fat milk protein powder served as the control product for soy
| Soy1 N:32 | | | | 2. Wheat+milk
| Control N:32 | | | | Cream of wheat or a non-oat ready to eat cereal and non fat milk protein powder
| | | | | Total Protein: ND
| | | | | Total Product: ND
| | | | | Diet composition: Diet composition: E ~1400, total fat 23%E, protein 18–19%E
Van Patten CL 2002 | Age (yr):55.5 | Design:RCT | Breast cancer pts > 4 mo since cancer tx, menopausal, moderate hot flashes (score => 10 wk) | soy milk | Rice beverage as placebo, 250 mL of study beverage twice a day, vanilla flavored with similar calori | | AE:yes
| (SD 8.9) | Randomized: Yes | Excluded:Amenorrhea < 12 mo, HRT preceding 4 mo, smokers, antibiotic use, IBD, liver impairment, recurrent breast cancer. allergies, consumed soy foods | Soybean beverage, 250 mL twice per day, was vanilla flavored, with similar calorie & fat content | milk1 | | AE Report:Bloating 15, flatulence 6, constipation 4, gastritis 3, diarrhea 9, nausea 2, vomiting 1, heartburn 2, wt gain 9, vaginal spotting 5, other 5
| Male%: | CohortMult | | SoyMilk | rice milk | Menopausal symptom | Drop out:Of 157 randomized, 9 became ineligible after randomization, 25 WD for time commitment (9), intolerance to soy (10: soy 7, placebo 3), other reasons (6)
| Country: Canada | Blinding: double | | Diet composition:Donated by Soya World Inc in BC, Canada | ProteinND | hot flashes | Comment: 3 subjects didn't complete last 4 weeks, their previous 4 week data was carried forward
| Sites:Multiple | Duration: | | | Product250 mL 2 @ day
| BMI:26.8 | | | | Diet composition:
| Total:157
| Soy1 N:59
| Control N:64
Verrillo 1985 | Age (yr):Male 48;Female 54 | Design:RCT | Stable hypercholesterolemia.Total Cholesterol > 7.8 mmol/L and LDL > 4. | 1.Soy.Addition | No non soy control | Total Cholesterol | AE:yes
| Male%:44% | Randomized: Yes | Excluded:Clinical or biochemical evidence of cardiac, renal, hepatic or endocrine disease. | Cholsoy granules (60 g/day) as a supplement to the low fat diet. | | LDL | AE Report:1/66 did not finish because of gastric discomfort
| Country: Italy | CohortMult | | Diet composition:Actual: 2353 Kcal, Protein 19.7% (animal 8.5%, soy 5.3%), Fat 31.0%, Sat fat 6.5%, MUFA 11.5%, PUFA 13.0%, carb 49.3%, Cholesterol 205 mg | | HDL | Drop out: 3 soy substitution (1 died of MI, 1 did not return after 1 month, 1 non-compliance),6 soy addition (1 gastric discomfort, 2 dental prosthesis, 3 non-compliance)
| Sites:1 | Blinding:No | | 2.Soy.Substitution | | Triglyceride | Comment: No non-soy control (except baseline diet)
| BMI:28.0 | Duration:16 | | Animal proteins replaced with Cholsoy (Gipharmex, Milan), a soybean preparation (26.5% carb, 5% sucro
| Soy1 N:44 | wks | | Diet composition:Actual: 2150 Kcal, Protein 15% (animal 2.3%, Soy 5.8%), Fat 33.5%, Sat fat 7.4%, MUFA 11.4%, PUFA 14.7%, carb 51.5%, Cholesterol 188 mg
| Soy2 N:22
| Control N:0 (66 on 8 wk low fat diet)
Vigna 2000 | Age (yr):53.8 | Design:RCT | Post menopausal women with hot flushes. Amenorrhea for at least 6 mo or bilateral oopherectomy at least 6 wks earlier. Severe hot flushes (>7/24 hr); baseline FSH > 50 IU/L, Serum estradiol < 130 pmol/L; TSH and thyroxine normal. | Soy.powder | Replace breakfast with beverage containing 60 g caseinate powder and to increase liquid intake. | LDL:HDL | AE:yes
| (SD 3.1) | Randomized: Yes | Excluded:ND | Replace breakfast with beverage containing 60 g soy powder (ISP, Supro brand) and to increase liquid intake | TotalProtein: 40 g | Total Cholesterol | AE Report:See dropouts.
| Male%:0 | Duration:12 | | Supro | TotalProduct: 60 g | LDL | Drop out: Constipation: 3 soy, 4 control; Nausea/vomiting: 4 soy, 3 control;Lack of compliance: 1 soy, 1 control; switch to HRT because of climacteric symptoms: 1 soy, 3 control;excluded from lipid analysis because of Triglyceride > 11.3 mmol/L
| Country: Italy | wks | | ISP with Isoflavone | Diet composition: ND. | HDL | Comment: Dropouts because of symptoms. Exclusions because of Tg. After initial randomization, 12 additional women enrolled to make up for drop outs. Note smaller N's in final than baseline. Same study as Albertazzi 1998 9464712 (JL)
| Sites:2 | | | Diet composition:ND | | Triglyceride
| BMI:25.9 | | | | | Lpa
| Soy1 N:51(46+5 post initial randomization) | | | | | Apo A1
| Control N:53 (46+7 post initial randomization) | | | | | Apo B/100
| | | | | | SBP
| | | | | | DBP
Wangen 2000 2 parallel studies (1 post- and 1 pre- menopausal women) | Age (yr):14 pts (peri) 26.5;17 pts (post) 57.1 | Design:Xover | premenopausal or postmenopausal women | 1. Isolated soy protein powder | ISP powder containing 10 + 1.1 isoflavones/d (14 premenopausal) | Bone specific alkaline phosphatase | AE:ND
| Male%:0 | Randomized: Yes | Excluded:strict vegetarian, high fiber, high soy, or low fat diets; regular vitamin and mineral supplementation >Recommended Dietary Allowances; athleticism; cigarette smoking; antibiotic or hormone use within six mo; bleeding within 12 mo; hysterectomy or oopherectomy; FSH concentration of less than 25 IU/L; history of chronic disorders, endocrine or gynecological diseases; benign breast disease; regular use of medication known to interfere with study endpoints (including aspirin); less than 90% or more than 120% ideal body weight; weight change >10 lb within the previous year, and inability to abstain from alcololic beverages duing the study. | ISP with Isoflavone (high) | ISP powder containing 7 + 1.1 isoflavones/d (17 postmenopausal subjects) | Osteocalcin | Drop out: 10/31 had compliance issues; 1 postmenopausal woman was not postmenopausal; 1 postmenopausal used alendronate sodium.
| Country: US | Blinding: double | | Diet composition: energy 1.21 MJ or 290 kcal, protein 53g, carb 15 g, fat 1.9 g in premenopausal study; energy 1.46 MJ or 349 kcal, protein 63g, carb 21 g, fat 1.9 g in postmenopausal study. | Total Protein: ND | Deoxypyridinoline cross-links | Comment: No baseline data given. Same patients as in Duncan 1999 10522983
| Sites:1 | Duration:3 | | 2. Isolated soy protein powder | Total Product: ND | IGF-I
| BMI:14 pts (peri) 63.4; 17 pts (post) 65.5 | mo | | ISP with Isoflavone (low) | Diet composition: E 1799kcal, protein 111g, carb 242g, fat 46g, fiber 13g | IGFBP3
| Soy1 N: 14 (peri); 17 (post) | | | Diet composition: E 1755kcal, protein 114g, carb 232g, fat 45g, fiber 13g: | | Carboxy terminal telopeptide I collagen
| Soy2 N: 15 (peri); 17 (post)
| Control N: 14 (peri); 17 (post)
Wangen 2001 | Age (yr):56.9 | Design:Xover | Postmenopausal women | 1. Soy protein powders | Soy protein powders with very low isoflavones | Total Cholesterol:HDL | AE:ND
| (SD) 5.8 | Randomized: Yes | Excluded:strict vegetarian, high fiber, high soy, or low fat diets; regular vitamin and mineral supplementation >RDA; athleticism; cigarette smoking; antibiotic or hormone use within six mo; bleeding within 12 mo; hysterectomy or oopherectomy; FSH concentration of less than 25 IU/L; history of chronic disorders including endocrine or gynecological diseases; benign breast disease; regular use of medication known to interfere with study endpoints (including aspirin); less than 90% or more than 120% ideal body weight; weight change of more than 10 lb within the previous year, and inability to abstain from alcololic beverages duing the study. | ISP with Isoflavone (high) | Total Protein: ND | LDL:HDL | Drop out:4 subjects due to inability to comply with the study protocol, and one for not postmenopausal.
| Male%:0 | Blinding: single | | Diet composition: E:1783Kcal; Protein 114g, carb 233g, total fat 47.7g, SFA 15.1g, PUFA 8.1 g, MUFA 13.9g, Cholesterol 149mg | Total Product: ND | Total Cholesterol | Comment: Secondary analysis of Duncan 1999 (9920082, Adam).
| Country: US | Duration: 13wks | | | Diet composition: E:1799Kcal; Protein 112g, carb 243g, total fat 45.9g, SFA 14.3g, PUFA 8.1 g, MUFA 13.2g, Cholesterol 154mg | LDL
| Sites:mutiple | | | 2. Soy protein powders with | | HDL
| BMI:25.2 | | | ISP with Isoflavone (low) | | Triglyceride
| Soy1 N:23 | | | Diet composition: E:1755Kcal; Protein 114g, carb 232g, total fat 45.3g, SFA 14.4g, PUFA 7.7 g, MUFA 13.3g, Cholesterol 155mg | | Lpa
| Soy2 N:23 | | | | | Apo A1
| Control N:23 | | | | | Apo B/100
| | | | | | T3
| | | | | | T4
| | | | | | TBG
| | | | | | TSH
| | | | | | Cortisol
| | | | | | Sex Hormone Binding Globulin
| | | | | | LH
| | | | | | FSH
| | | | | | Estradiol
| | | | | | Estrone
| | | | | | Estrone Sulfate
| | | | | | Prolactin
| | | | | | Testosterone
| | | | | | Androstenedione
| | | | | | DHEA/DHEAS
| | | | | | Insulin
Washburn 1999 | Age (yr):51 | Design:Xover | Perimenopausal women aged 45–55 yr. Menopausal symptoms (at least one hot flush or night sweat daily), not on HRT (or in the past 6 mo) and currently perimenopausal (missing at least 3 menstrual periods in the last 12 mo and having last menstrual period not > 12 mo prior). | 1. Soy.Supplement Daily | 20 g complex carb supplement | Total Cholesterol | Adverse event: 1 dropout for acne rosacea.
| (SD 4.8) | Randomized: Yes | Excluded: ND | ISP with Isoflavone | no phytoestrogens. | LDL | 9 drop out (5 personal reasons, 1 unrelated illness, 1 concern about aspartame, 1 remembered allergic to soy, 1 recurrence of acne rosacea)
| Male%:0 | Blinding: double | | 2. Soy.SupplementTwice.Daily | Total Protein: <0.02 g | HDL | Comment:unclear N possibly equal 51 (? if includes dropouts)
| Country: US | Duration:6 wks | | ISP with Isoflavone | Total Product: 20g | Triglyceride
| Sites:1 | | | Diet composition:68% Protein, 17% carb, 3% Fat, 0% Sat Fat, 108.3 Kcal.Niacin 0 mg, Folate 59.0 mcg.Calcium 708 mg, Potassium 203.6 mg, Sodium 203.6 mg | Diet composition:94% carb, <1.0 % Protein, <1.0% Fat, 0% Sat Fat, 83.6 Kcal. | SBP
| BMI: 74.3 | | | | Vitamin supplement | DBP
| Soy1 N:51 | | | | | BUN
| Soy2 N:51 | | | | | FBS
| Control N:51 | | | | | Menopausal symptoms:
| | | | | | Hot flash frequency, score
| | | | | | Night sweat frequency, score
| | | | | | Estrogenic symptom score
Watanabe 2000 | Age (yr): | Design:Unclear Xover | Female students in the nutritional course (pre-menopausal) who provided data for at least 2 menstruation cycles before the experiment | Soy Isoflavones (without protein) 40mg from Soya hypocotyl tea | No non isoflavone control arm | Total Cholesterol | AE:no
| Male%:0 | Randomized: Unclear | Excluded:ND | Diet composition: ND. | | LDL | Drop out:yes
| Country: Japan | Blinding:ND | | Soy Isoflavones (without protein) 20mg from Soya hypocotyl tea | | HDL | Comment: exclusion criteria not explicitly described;no data on soy protein per day;cross-over design not explicitly described;not explicit description of the design (randomization cannot be excluded). Unclear control arm
| Sites:1 | Duration:1 | | Diet composition: ND. | | Triglyceride
| BMI: | mo | | | | BP (not specified if SBP or DBP), leucine aminopeptidase, total bilirubin
| Soy1 N:20 | | | | | Menstrual cycle length
| Soy2 N:20 | | | | | 17-b estradiol
| Control N:0(?20) | | | | | Progesterone
Wong 1998 9848504_Hyper | Age (yr):41.4 | Design:Xover | Hypercholesterolemic (Total Cholesterol>6.21, Triglyceride<5.65, LDL>4.53) men. HDL>0.91 mmol/L. Age 20–50 y | Soy protein diet | Animal protein diet | Total Cholesterol | AE:no
| (SD 7.8) | Randomized: Yes | Excluded:Hypertensive or cholesterol-lowering medication, on special diet, chromic condition including GI problems and DM. | NCEP Step I. Supro isolated soy protein (Protein Technologies International, St Louis). Usual energy | Protein≥75% of each diet | LDL | Drop out: No dropouts
| Male%:100 | Blinding:No | | Supro | Product:ND | HDL | Comment: HDL normal
| Country: US | Duration:5wks | | Diet composition:20% protein, 30% fat, 50% carb | Diet composition: 20% protein, 30% fat, 50% carb | Triglyceride | Two parallel studies of normo and hyper cholesterolemics. Hyper here; did not quantify isoflavone
| Sites:1 | | | | | Apo A1
| BMI:87.1 | | | | | Apo B/100
| Soy1 N:13 | | | | | LDL:HDL
| Control N:13
Wong 1998 9848504_Normo | Age (yr):35.5 | Design:Xover | Normocholesterolemic (Total Cholesterol 3.10–4.91 mmol/L, Triglyceride <1.69, LDL<3.49). HDL>0.91 mmol/L. Age 20–50 y | Soy protein diet | Animal protein diet | Total Cholesterol | AE:no
| (SD 7.2) | Randomized: Yes | Excluded:Hypertensive or cholesterol-lowering medication, on special diet, chromic condition including GI problems and DM. | NCEP Step I. Supro isolated soy protein (Protein Technologies International, St Louis). Usual energy | Protein≥75% of each diet | LDL | Drop out:No dropouts
| Male%:100 | Blinding:No | | Supro | Product:ND | HDL | Comment: 20–50 y. Normal HDL;High fiber in both treatment and control;Two parallel studies of normo and hyper cholesterolemics. Normo here; did not quantify isoflavone
| Country: US | Duration:5 | | Diet composition:20% protein, 30% fat, 50% carb | Diet composition: 20% protein, 30% fat, 50% carb | Triglyceride
| Sites:1 | wks | | | | Apo A1
| BMI:87.6 | | | | | Apo B/100
| Soy1 N:13 | | | | | LDL:HDL
| Control N:13
Wu 2000 | Age (yr):34.1 | Design:NRNCT2 | Premenopausal | Soy diet | No control arm | Menstrual cycle length | AE:no
| (SD 7.4) | Randomized: No | Excluded:Current or recent pregnancy or lactation, irregular menstrual cycles, oral or hormonal contraceptives or hormones, h/o chronic illness or cancer, smoker, special diets | Tofu | | Sex Hormone Binding Globulin | Drop out:No
| Male%:0 | CohortMult | | SoyMilk | | Estradiol | Comment: 3 different soy sources & no data on consumption levels of 3 soy sources. Ten Asians & ten non-Asians in soy intervention study
| Country: US | Blinding:No | | soybean peas | | Progesterone
| Sites:1 | Duration:3 | | 3 cycle intervention of usual diets supplemented with 3 traditional Asian soy foods (tofu, soymilk,
| BMI:23.1 | mo | | Diet composition: 16.7% protein, 33.0% fat, 51% carb, 236 mg cholesterol
| Soy1 N:20
| Control N:0
Xu 2000 | Age (yr):56.9 | Design:Xover | Postmenopausal women | 1. Habitual diets supplemented with soy protein powders | Habitual diets supplemented with soy protein powders | Urinary 2OHE | AE:no
| (SD 5.8) | Randomized: Yes | Excluded:Athleticism, strict vegetarian, high fiber or high soy or low fat diet, cigarette smoking, regular vitamin/mineral supplementation > RDA, meds incl aspirin, hormones or antibiotics preceding 6 mo, menses preceding 12 mo, hysterectomy, and oophorectomy | ISP with Isoflavone (high) | ISP with Isoflavone (Lowest) | Urinary 16aOHE | Drop out: 4 WD in 1st diet period for noncompliance, one subject excluded from analyses - not postmenopausal
| Male%:0 | Blinding: single | | 2. Habitual diets supplemented with soy protein powders | Diet composition: | Equol | Comment: Data referrred to Duncan 1999; 3 diet periods of 93-days, each separated by 26-day washout periods; subjects blinded to intervention
| Country: US | Duration:93 | | ISP with Isoflavone (Low) | Total Protein: 63g
| Sites:1 | days | | Diet composition: 1779kcal, 113g protein, 236 g carb, 46 g fat, 13g dietary fiber | Total Product:ND
| BMI:25.2 | | | | Diet composition: 1779kcal, 113g protein, 236 g carb, 46 g fat, 13g dietary fiber
| Total enrol:23
| Soy1 N:18
| Soy2 N:18
| Control N:18
Yamaguchi 2001 | Age (yr):17–58 yr | Design:NRNCT | adult volunteers with no abnormal liver or kidney function | nijiru | No control | Total Cholesterol | AE:no
| Male%:50 | Randomized: No | Excluded:intake of foods abundant in Vitamin K | nijiru powder (byproduct of natto which is fermented soybeans) | | HDL | Drop out:no
| Country: Japan | CohortSing | | Diet composition:ND | | Triglyceride | Comment:None
| Sites:1 | Blinding:No | | | | Serum Osteocalcin
| BMI:ND | Duration:60 | | | | Urinary calcium
| Soy1 N:12 | days | | | | BUN
| Control N:0 | | | | | Albumin
Yamashita 1998 | Age (yr):40 | Design:NRNCT | premenopausal obese women; BMI >25 kg/m2, age 30–61, absence of DM ane endocrine, hepatic, or renal disease or pharmacotherapy that might affect arterial function or glucose metabolism. | plant diet | lean red meat diet (5d/wk, 2 d fish or non-soy legumes) | Total Cholesterol | AE:yes
| (SD 9) | Randomized: No | Excluded:ND | plant-white meat diet--soybean was substituted for lean meat with 130g dried soybean. Soybeans offer | red meat | LDL | AE:. 1 subject has lengthy infection,
| Male%:0 | Blinding:No | | Soy bean | Protein | HDL | Drop out: 6 were unwilling to keep appts and were excluded.
| Country: Australia | Duration:16 | | Diet composition:energy 1500 kcal, protein 25E, soy protein 31% total protein, fat 22% total energy, SFA 19% fat, carb 51% total energy, 54 mg cholesterol | Product: 150 g | Triglyceride | Comment:Basically this is a weight-reduction trial designed to find whether SAC improves with weight loss.
| Sites:1 | wks | | | Diet composition:energy 1500 kcal, protein 25E, fat 23% total energy, SFA 28% fat, carb 50% total energy, 79 mg cholesterol | Lpa
| BMI:32.4 | | | | | MAP
| Soy1 N:17 | | | | | Systemic arterial compliance
| Control N:19 | | | | | FBS
Yamori 2002 | Age (yr):52.7 | Design:RCT | healthy postmenopausal Japanese immigrants from Okinawa living in Brazil, aged 45–59 | isoflavone diet | roasted sesame mixture | Urine deoxypyridinoline | AE:no
| 3.3 | Randomized: Yes | Excluded:none mentioned | mixture of roasted soybean and sesame | Protein:ND | Urine pyridinoline | Drop out:no
| Male%:0 | Blinding: double | | Soy bean | Product:ND | Bone stiffness | Comment: Limited data available on the control
| Country: Brazil | Duration:10 | | Diet composition:total protein 1800 mg, lipids 2400 mg, carb 1600 mg | Diet composition:ND
| Sites:1 | wks
| BMI:59.7
| Soy1 N:20
| Control N:20
Yildirir 2001 | Age (yr):50.1 | Design:NRNCT | Hypercholesterolemic, non-smoking men with normal BMI. | Soy.Protein.Diet | Compared to before diet | Lpa | AE:no
| 11.8 | Randomized: No | Total Cholesterol > 230 mg/dL, LDL > 160 despite the use of NCEP/AHA Step 1 diet for at least 6 mo. | 60% of animal Diet composition: proteins of the diet were replaced by soy protein | Protein68.2with-12.2 | Apo A1 | Drop out: No dropouts
| Male%:100 | CohortSing | Excluded:Taking cholesterol-lowering medications. Consuming EtOH or special diets. Chronic illnesses including GI problems or DM. | Soy flour, bean, bean sprouts | Product | Apo B/100 | Comment: Not controlled
| Country: Turkey | Blinding:No | | Diet composition:1846 Kcal; Protein 68.5 g; Animal protein 16.4 g, Plant excluding soy protein 32.2 g, Fat 52.3 g, Sat fat 11.5 g, MUFA 21.7 g, PUFA 19.4 g, carb 280 g, Cholesterol 95 mg, Fiber 5.8 g. | Diet composition:1844 Kcal, Protein 68.2 g, Animal protein 30.2 g, Plant protein excluding soy 36.4 g, Fat 51.6 g, Sat fat 20.8 g, MUFA 21.3 g, PUFA 9.4 g, carb 278 g, Cholesterol 160 mg, Fiber 5.6 g | Peripheral endothelial function
| Sites:1 | Duration:6 | | | | Also Total Cholesterol, HDL, LDL, Triglyceride, Total Cholesterol:HDL, but no control arm
| BMI:25.3 | wks
| Soy1 N:20
| Control N:0

Evidence Table (Part 2)

Study | Outcome | Primary / Secondary | Cohort | N (final) | Base | | | Follow?up / Change | | P W/in | P Diff | P net ▵
Adams 2003 | Insulin like growth factor (IGF-I) IGFBP-3 | 1° | ISP with Isoflavone | 74 | Outcomes tabulated
| IGF-I/IGFBP-3 | | ISP without isoflavone | 76
Adams 2004 | PSA | 1° | ISP with Isoflavone | 61 | Outcomes tabulated
| | | ISP without isoflavone | 51
Albert A 2002 | Vasomotor Symptoms: Score | 1° | Isoflavone | 146 | 82.73±17.14 | Other | SD | f/up | 36.33±27.71
Albertazzi 1998 | Vasomotor Symptoms: Score and Frequency | 1° | Soy | 40* | Kupperman Index: 11.4 (Range: 10.7 – 12.7) | | | ▵▵ | -1.59
| | | Control/Pl | 39* | Kupperman Index: 10.9 (Range: 10.2 – 11.8)
| | | | | Significantly improved weekly hot flash frequency in both groups (44% reduction with soy, 31% with placebo) at 12 weeks, p<0.01
Albertazzi 1999 (Same as Albertazzi 1998) | Vaginal cell maturation index Equol | 1° | ISP with Isoflavone | 51 | Outcomes tabulated
| | | casein | 53
Alekel 2000 | bAP | 1° | ISP w/ Isofl | 24 | Data expressed in a scatterplot. Baseline values for bAP were significantly different (p=0.036) among the groups; ISP+ had higher values than control. Treatment per se had no significant effect on bAP (p=0.32).
| | | ISP w/o Isofl | 24
| | | Casein | 21
| NTx | 1° | ISP w/ Isofl | 24 | Data expressed in a scatterplot. Treatment per se had no significant effect on N-Tx (p=0.12).
| | | ISP w/o Isofl | 24
| | | Casein | 21
Anderson 1998 | GFR | 1° | Soy diet | 8 | 49±7 | | SE | ▵▵ | 0 | | | NS
| | | Control/Pl | 8 | 49±6
Anderson 2002 | BMC: Lumbar | 1° | Isoflavone | 15 | 58.32±9.17 | g | SD | f/up | 59.23±9.38 | 0.11 | | 0.61
| | | Control/Pl | 13 | 57.73±10.68 | | | | 58.41±10.83 | 0.19
| BMD: FemoralNeck Neck | 1° | Isoflavone | 15 | 0.93±0.10 | g/cm2 | SD | f/up | 0.90±0.11 | 0.01 | 0.39
| | | Control/Pl | 13 | 0.89±0.14 | | | | 0.88±0.15 | 0.4
Arjmandi 2003 | bAP | 1° | Soy protein | 20 | 0.438±0.032 | | SE | f/up | 0.412±0.032 | 0.1394 | | 0.7601
| | | milk-based | 22 | 0.381±0.031 | | | | 0.348±0.031 | 0.0493
| E2 | 1° | Soy protein | 20 | 51.5±22.4 | | SE | f/up | 66.6±23.1 | 0.3428 | 0.8292
| | | milk based | 22 | 84.8±21.5 | | | | 95.0±22.2 | 0.5135
| E2 (HRT) | 1° | Soy protein | 20 | 93.4±16.8 | | SE | f/up | 116.9±28.1 | 0.3335 | | 0.399
| | | milk based | 22 | 122.84±28.7 | | | | 158.3±48.38 | 0.6299
| E2 (no HRT) | 1° | Soy protein | 20 | 35.6±6.4 | | SE | f/up | 61.7±16.9 | 0.7793 | | 0.961
| | | milk based | 22 | 45.9±13.9 | | | | 93.2±44.4 | 0.6596
Ashton E 2000 | HDL | 1° | Tofu | 42 | 1.25±0.35 | mmol/L | SD | ▵F | -0.08 (95% CI: -0.14, -0.02) | | 0.01
| | | Control/Pl | 42 | x-over
| LDL | 1° | Tofu | 42 | 3.68±0.86 | mmol/L | SD | ▵F | 0.09 (95% CI: -0.10, 0.27) | <0.05 | <0.05
| | | Control/Pl | 42 | 3.68±0.86
| LDL oxidation | 1° | Tofu | 42 | nd | | SD | ▵F | +6.77 (95% CI: +2.39, +11.15) | | 0.01
| | | Control/Pl | 42 | nd
| Lp(a) | 1° | Tofu | 42 | nd | mg/L | SD | ▵F | -7.78 (95% CI: -35.59, +20.04) | | 0.3
| | | Control/Pl | 42 | nd
| TC | 1° | Tofu | 42 | 5.79±0.97 | mmol/L | SD | ▵F | -0.23 (95% CI: -0.43, -0.02) | | 0.03
| | | Control/Pl | 42 | x-over
| Tg | 1° | Tofu | 42 | 1.96±1.33 | mmol/L | SD | ▵F | -0.15 (95% CI: -0.31, +0.02) | | 0.02
| | | Control/Pl | 42 | x-over
Azadbakht 2003 | HDL | 1° | Soy protein | 14 | 46.5±12.8 | mg/dL | SD | ▵▵ | 2±8.5 | | | NS
| | | Control/Pl | 14 | 45.8±12.2
| LDL | 1° | Soy protein | 14 | 145±6.3 | mg/dL | SD | ▵ | --6.3±9.3
| | | Control/Pl | 14 | 144.2±6.7 | | | | 2.07±5.8
| TC | 1° | Soy protein | 14 | 201.4±45.2 | mg/dL | SD | ▵▵ | -16.2±20.1 | | | <0.01
| | | Control/Pl | 14 | 197.0±47.2
| Tg | 1° | Soy protein | 14 | 242.5±60.0 | mg/dL | SD | ▵▵ | -13.1±12.9 | | | <0.002
| | | Control/Pl | 14 | 240.5±61.6
Baird DD 1995 | FSH | 1° | Soy | 66 | 61.1±22.1 | Other | SD | f/up | 58.4±21.2
| | | Control/Pl | 25 | 63.4±24.5 | | | | 61.6±25.8
Bakhit R 1994 | HDL | 1° | Soy Protein | 21 | 1.33±0.19 | mmol/L | SD | f/up | 1.30±0.11 | NS | | NS
| | | Soy Protein | 21 | | | | | 1.30±0.18 | NS
| | | Casein + S | 21 | | | | | 1.28±0.16 | NS
| | | Control/Pl | 21 | | | | | 1.31±0.20 | NS
| HDL: TC > 220 mg/dL | | ISP + cell | 11 | 1.38±0.26 | mmol/L | SD | f/up | 1.30±0.13 | NS | | NS
| | | ISP + SCF | 11 | | | | | 1.30±0.22 | NS
| | | Casein + S | 11 | | | | | 1.31±0.20 | NS
| | | Control/Pl | 11 | | | | | 1.38±0.23 | NS
| LDL | 1° | Soy Protein | 21 | 4.08±0.62 | mmol/L | SD | f/up | 4.01±0.54 | NS | | NS
| | | Soy Protein | 21 | | | | | 4.07±0.46 | NS
| | | Casein + S | 21 | | | | | 4.03±0.55 | NS
| | | Control/Pl | 21 | | | | | 4.21±0.70 | NS
| LDL: TC > 220 mg/dL | | ISP + cell | 11 | 4.37±0.66 | mmol/L | SD | f/up | 4.14±0.63 | NS | | 0.07
| | | ISP +SCF | 11 | | | | | 4.09±0.56 | NS
| | | Casein + S | 11 | | | | | 4.11±0.64 | NS
| | | Control/Pl | 11 | | | | | 4.35±0.76 | NS
| TC | 1° | Soy Protein | 21 | 5.74±0.64 | mmol/L | SD | f/up | 5.63±0.48 | NS | | NS
| | | Soy Protein | 21 | | | | | 5.73±0.46 | NS
| | | Casein + S | 21 | | | | | 5.70±0.48 | NS
| | | Control/Pl | 21 | | | | | 5.84±0.65 | NS
| TC: TC(base) > 220 mg/dL | | ISP + cell | 11 | 6.20±0.45 | mmol/L | SD | f/up | 5.79±0.53 | <0.05 | | 0.04
| | | ISP + SCF | 11 | | | | | 5.72±0.54 | <0.05
| | | Casein + S | 11 | | | | | 5.83±0.60 | NS
| | | Control/Pl | 11 | | | | | 6.03±0.71 | NS
| Tg | 1° | Soy Protein | 21 | 1.72±0.99 | mmol/L | SD | f/up | 1.48±0.51 | NS | | NS
| | | Soy Protein | 21 | | | | | 1.68±0.76 | NS
| | | Casein + S | 21 | | | | | 1.57±0.82 | NS
| | | Control/Pl | 21 | | | | | 1.57±0.66 | NS
| Tg: TC >220 mg/dL | | ISP + cell | 11 | 1.98±1.27 | mmol/L | SD | f/up | 1.43±0.51 | <0.05 | | NS
| | | ISP + SCF | 11 | | | | | 1.80±0.93 | NS
| | | Casein + S | 11 | | | | | 1.74±0.89 | NS
| | | Control/Pl | 11 | | | | | 1.65±0.74 | NS
Balk JL 2002 | Vasomotor Symptoms: per wk | 1° | Soy | 7 | 1.31 | | | f/up | 0.857 | 0.059
| | | Control/Pl | 12 | 1.28 | | | | 0.5 | 0.014
Baum JA; 1998 | HDL | 1° | ISP56 | 23 | 1.34±0.27 | mmol/L | SD | ▵▵ | 0.12 | | | 0.01
| | | ISP90 | 21 | 1.38±0.32 | | | | 0.1 | | | 0.03
| | | Control/Pl | 22 | 1.38±0.31
| TC | 1° | ISP56 | 23 | 6.57±0.85 | mmol/L | SD | f/up | 6.18±0.91 | | | NS
| | | ISP90 | 21 | 6.47±0.88 | | | | 6.13±0.91 | | | NS
| | | Control/Pl | 22 | 6.26±0.67 | | | | 6.08±0.72
| Tg | 1° | ISP56 | 23 | 1.89±1.02 | mmol/L | SD | f/up | 1.73±0.99 | | | NS
| | | ISP90 | 21 | 1.74±0.75 | | | | 1.74±0.96 | | | -
| | | Control/Pl | 22 | 1.75±1.11 | | | | 1.76±1.28
Bazzoli 2002 | plasma lipid peroxides | 1° | ISP w/ Isofl | 9 | 3.9±0.6 | μM | SD | f/up | 2.9 ±0.3 | | | <0.05
| | | Whey | 9 | 3.0±0.4 | μM | SD | f/up | 2.8±0.3
| urinary 8- hydroxyl-2-deoxyguanosine and total antioxidant status | 1° | ISP w/ Isofl | 9 | Outcome tabulated
| | | Whey | 9
Blum A 2003 | BA.endo.fxn_Flow.hyp | 1° | ISP w/ Isofl | 24 | | | SD | f/up | 76±40 | | 0.65
| | | Control/Pl | 24 | | | | | 81±44
| HDL | 2° | ISP w/ Isofl | 24 | 1.56±0.46 | mmol/L | SD | f/up | 1.53±0.33 | 0.53 | NS
| | | Control/Pl | 24 | x-over | | | | 1.60±0.39
| LDL | 2° | ISP w/ Isofl | 24 | 4.62±0.74 | mmol/L | SD | f/up | 3.70±0.77 | 0.0001 | 0.72
| | | Control/Pl | 24 | x-over | | | | 3.57±0.74
| TC | 2° | ISP w/ Isofl | 24 | 7.00±0.82 | mmol/L | SD | f/up | 6.23±0.93 | 0.0001 | 0.97
| | | Control/Pl | 24 | x-over | | | | 6.18±0.85
| Tg | 2° | ISP w/ Isofl | 24 | 1.50±0.56 | mmol/L | SD | f/up | 2.18±0.86 | 0.04 | P=0.70
| | | Control/Pl | 24 | x-over | | | | 2.20±1.34
Bricarello 2004 | HDL | 1° | Soy Milk | 60 | 58±2 | mg/dL | SE | f/up | 62 | <0.05 | | <0.05
| | | Control/Pl | 60 | x-over | | | | 57
| LDL | 1° | Soy Milk | 60 | 157±4 | mg/dL | SE | f/up | 148 | <0.05 | | <0.05
| | | Control/Pl | 60 | x-over | | | | 158
| TBARs | 2° | Soy Milk | 60 | 1.82±0.12 | - | SE | f/up | 1.49±0.09 | | | <0.05
| | | Control/Pl | 60 | x-over | | | | 1.91±0.11
| TC | 1° | Soy Milk | 60 | 241±5 | mg/dL | SE | f/up | 237 | NS | | NS
| | | Control/Pl | 60 | x-over | | | | 241
| Tg | 1° | Soy Milk | 60 | 136±9 | mg/dL | SE | f/up | 133 | NS | | NS
| | | Control/Pl | 60 | x-over | | | | 135
Brooks J 2004 | E2 | 1° | Soy | 13 | 10.60±1.00 | Other | SE | f/up | 20.27±9.92
| | | Control/Pl | 15 | 20.11±3.55 | | | | 15.14±2.11
Brown BD 2002 | Menstrual Cycle Length | 1° | Soy diet | 13 | | Other | | f/up | 31±0.7
| | | Control/Pl | 14 | | | | | 29.2±0.7
Bruce B; 2003 | TSH | 1° | Soy | 21 | 3.00±0.44 | Other | SE | f/up | 3.49±0.52
Burke GL 2003 | Vasomotor Symptoms: per wk | 1° | Med Isofla | 76 | 2.6±0.31 | Other | SE | f/up | 1.5±0.29 | <0.0001
| | | High Isofl | 65 | 3.2±0.38 | | | | 1.3±0.28 | <0.0001
| | | Control/Pl | 70 | 3.5±0.38 | | | | 0.8±0.20 | <0.0001
Burke V; 2001 | DBP | 1° | High (Soy) | 9 | 74.1 (95% CI: 66.7, 81.4) | mm Hg | | ▵▵ | -2.6 (95% CI: (-4.2, -1.0)) | | | 0.006
| | | High (Soy) | 9 | 76.8 (95% CI: 69.3, 84.3)
| | | Low protein | 9 | 78.1 (95% CI: 69.4, 86.9)
| | | Control/Pl | 9 | 74.6 (95% CI: 67.8, 81.5)
| SBP | 1° | High (Soy) | 9 | 135.0 (95% CI: 120.0, 150.0) | mm Hg | | ▵▵ | -5.9 (95% CI: (-8.0, -3.8)) | | | 0.001
| | | High (Soy) | 9 | 133.7 (95% CI: 123.7, 143.4)
| | | Low protein | 9 | 131.6 (95% CI: 121.0, 142.2)
| | | Control/Pl | 9 | 131.8 (95% CI: 122.6, 141.0)
Carroll 1978 | TC | 1° | Cross 1 | 5 | 161(graph) | mg/dL | SE | f/up | 161±4 | | <0.05
| | | Cross 2 | 5 | 164 (graph) | | | | 161±3
| | | Calculated | 10 | 163 (mean of 1 and 2) | | | | 161 (mean of 1&2)
| | | Control/Pl | (5, | | | | | (175, 166) 170±(5, 3)
Cassidy 1994 | E2 | 1° | Soy diet | 6 | | | SD | f/up | 362.5±82.0
| | | Control/Pl | 6* | 246.2±38.4
| FSH | 1° | Soy diet | 6 | | Other | SD | f/up | 7.8±4.6
| | | Control/Pl | 6* | 14.6±5.6
Cassidy 1995 | FSH | 1° | 45 mg conj | 6 | | | | | 7.2±0.9 | not significant | not significant
| | | Isoflavone | 5 | | | | | 4.6±0.6 | | not significant
| | | 23 mg conj | 6 | | | | | 4.2±0.1 | | not significant
| | | Control/Pl | 6 | | | | | 8.7±0.8 | ns
| | | Control/Pl | 5 | | | | | 4.6±0.2
Cassidy 1995 | E2 | 1° | Isoflavone | 6 | 81.7 | | | | -11 | not significant
| | | Isoflavone | 5 | 114.4 | | | | -30 | not significant
Chen YM; 2003, 2004 | BMD: Femoral Neck | 1° | 40 mg Isof | 57 | | g/cm2 | SD | ▵ | -0.47±2.14
| | | 80mg Isofl | 50 | | | | | 0.14±2.19
| | | Control/Pl | 53 | | | | | 0.04±2.86
| BMD: Hip | 1° | 40 mg Isof | 57 | | g/cm2 | SD | ▵ | -0.48±1.81
| | | 80mg Isofl | 50 | | | | | -0.21±1.62
| | | Control/Pl | 53 | | | | | -0.51±1.82
| BMD: Lumbar | 1° | 40 mg Isof | 57 | | g/cm2 | SD | ▵ | -0.47±2.60
| | | 80mg Isofl | 50 | | | | | -0.89±1.88
| | | Control/Pl | 53 | | | | | -0.63±2.56
Chiechi 2002 | DBP | | Diet group | 24 | 81.3±8.7 | mm Hg | SD | ▵ | 0.2 (95% CI: -5.3/5.76) | ns
| | | HRT | 41 | 80.2±8.2 | | | | -1.07 (95% CI: -4.45/2.3) | ns
| | | Control/Pl | 43 | 81.4±9.0 | | | | 2.8 (95% CI: -1.51/7.23) | ns
| HDL | | Diet group | 24 | 52.01±11.6 | mg/dL | SD | ▵ | -1.8 (95% CI: -4.69/0.94)
| | | HRT group | 41 | 51.9±11.3 | | | | -5.5 (95% CI: -7.59/-3.45) | <0.05
| | | Control/Pl | 43 | 54.7±11.7 | | | | -3.6 (95% CI: -5.51/-1.83)
| LDL | | Diet group | 24 | 159.3±34.5 | mg/dL | SD | ▵ | -6.1 (95% CI: -17.11/4.76) | ns
| | | HRT group | 41 | 156.8±31.7 | | | | -12.0 (95% CI: -21.67/-2.37) | <0.05
| | | Control/Pl | 43 | 145.02±26.9 | | | | 0.3 (95% CI: -5.39/6.1) | ns
| NTx | 1° | Soy diet | 24 | 29.5±31.3 | | SD | ▵ | 4.92 (95% CI: -20.1, 29.9)
| | | HRT | 41 | 40.6±64.4 | | | | -10.1 (95% CI: -23, 2.7)
| | | Control/Pl | 43 | 29.9±40.7 | | | | 1.34 (95% CI: -17.6, 20.3)
| SBP | | Diet group | 24 | 131.8±14.3 | mm Hg | SD | ▵ | -3.4 (95% CI: -11.9/5.11) | NS
| | | HRT group | 41 | 130±13.5 | | | | -9.7 (95% CI: -14.8/-4.71) | <0.05
| | | Control/Pl | 43 | 129.5±14.8 | | | | -3.1 (95% CI: -10.06/3.7) | NS
| Serum Osteocalcin | 1° | Soy diet | 24 | 21.9±44.3 | | SD | ▵ | 5.45 | <0.05 | | 0.13
| | | HRT | 41 | 14.5±11.3 | | | | -1.10 | NS
| | | Control/Pl | 43 | 15.5±10.5 | | | | 1.7 | NS
| TC | | diet group | 24 | 235.5±38.7 | mg/dL | SD | ▵ | -8.6 (95% CI: -20.98/3.65) | ns
| | | HRT group | 41 | 233.8±36.5 | | | | -15.1 (95% CI: -23.37/-6.94) | <0.05
| | | Control/Pl | 43 | 220.08±31.5 | | | | -2.6 (95% CI: -8.65/3.35) | ns
| Tg | | Diet group | 24 | 119.7±65.4 | mg/dL | SD | ▵ | -3.3 (95% CI: -22.7/15.4) | ns
| | | HRT group | 41 | 124.6±56.1 | | | | -7.02 (95% CI: -20.64/6.59) | ns
| | | Control/Pl | 43 | 99.5±49.8 | | | | 3.6 (95% CI: -3.31/10.6) | ns
Chiechi 2002 12191852
Chiechi 2003 | E2 | 1° | Soy diet | 22 | 10.1±18.8 | Other | SD | f/up | 6.2±18.8
| | | Control/Pl | 41 | 13.6±16.3 | | | | 15.7±22.6
| FSH | 1° | Soy diet | 22 | 60.9±21.6 | Other | SD | f/up | 61.8±18.8
| | | Control/Pl | 41 | 59.1±27.6 | | | | 58.4±26.1
Crisafulli 2004 | Vasomotor Symptoms: Score | 1° | Genistein | 30* | 4.6±0.58 | no unit | SE | error
| | | Control/Pl | 30* | 4.7±0.58
Crouse J 1999 | HDL: LDL 140–166 mg/dL | 1° | 3mg Isofla | 16 | 1.24±0.31 | mmol/L | SD | f/up | 1.24±0.31 | NS
| | | 27mg Isofl | 12 | 1.14±0.34 | | | | 1.14±0.28 | NS
| | | 37mg Isofl | 18 | 1.09±0.18 | | | | 1.19±0.18 | NS
| | | 62mg Isofl | 15 | 1.22±0.26 | | | | 1.27±0.28 | <0.04 FOR TRE
| | | Control/Pl | 15 | 1.06±0.21 | | | | 1.06±0.21
| HDL: LDL 140–200 mg/dL | 1° | 3 mg Isofl | 28 | 1.19±0.28 | mmol/L | SD | f/up | 1.19±0.28 | NS
| | | 27 mg Isof | 27 | 1.16±0.26 | | | | 1.16±0.23 | NS
| | | 37 mg Isof | 30 | 1.16±0.23 | | | | 1.19±0.21 | NS
| | | 62 mg Isof | 30 | 1.19±0.23 | | | | 1.22±0.28 | NS
| | | Control/Pl | 31 | 1.16±0.23 | | | | 1.14±0.23
| HDL: LDL 166–200 mg/dL | 1° | 3mg Isofla | 12 | 1.16±0.23 | mmol/L | SD | f/up | 1.11±0.18 | NS
| | | 27mg Isofl | 15 | 1.16±0.18 | | | | 1.22±0.21 | NS
| | | 37mg Isofl | 12 | 1.24±0.18 | | | | 1.19±0.28 | NS
| | | 62mg Isofl | 15 | 1.19±0.21 | | | | 1.16±0.26 | NS
| | | Control/Pl | 16 | 1.24±0.23 | | | | 1.19±0.23
| LDL: : LDL 140–166 mg/dL | 1° | 3mg Isofla | 16 | 3.83±0.23 | mmol/L | SD | f/up | 3.85±0.52 | NS
| | | 27mg Isofl | 12 | 3.88±0.23 | | | | 3.98±0.57 | NS
| | | 37mg Isofl | 18 | 3.77±0.23 | | | | 3.88±0.36 | NS
| | | 62mg Isofl | 15 | 3.80±0.23 | | | | 3.83±0.31 | NS
| | | Control/Pl | 15 | 3.77±0.21 | | | | 3.85±0.41
| LDL: LDL 140–200 mg/dL | | 3 mg Isofl | 28 | 4.24±0.59 | mmol/L | SD | f/up | 4.14±0.57 | NS
| | | 27 mg Isof | 27 | 4.40±0.62 | | | | 4.27±0.65 | NS
| | | 37 mg Isof | 30 | 4.16±0.59 | | | | 4.03±0.49 | NS
| | | 62 mg Isof | 30 | 4.29±0.65 | | | | 4.03±0.44 | <0.05 VS CASEIN
| | | Control/Pl | 31 | 4.27±0.54 | | | | 4.27±0.59
| LDL: LDL 166–200 mg/dL | 1° | 3 mg Isofl | 12 | 4.78±0.47 | mmol/L | SD | f/up | 4.53±0.44 | NS
| | | 27 mg Isof | 15 | 4.81±0.52 | | | | 4.50±0.62 | NS
| | | 37 mg Isof | 12 | 4.71±0.49 | | | | 4.27±0.57 | <0.03 VS CONTROL
| | | 62 mg Isof | 15 | 4.78±0.54 | | | | 4.22±0.47 | <0.03 VS CONTROL
| | | Control/Pl | 16 | 4.71±0.31 | | | | 4.65±0.47
| TC: LDL 140–166 mg/dL | 1° | 3mg Isofla | 16 | 5.77±0.44 | mmol/L | SD | f/up | 5.79±0.52 | | | NS
| | | 27mg Isofl | 12 | 5.92±0.49 | | | | 5.87±0.67 | | | NS
| | | 37mg Isofl | 18 | 5.66±0.49 | | | | 5.82±0.44 | | | NS
| | | 62mg Isofl | 15 | 5.84±0.39 | | | | 5.95±0.47 | | | NS
| | | Control/Pl | 15 | 5.72±0.31 | | | | 5.74±0.52
| TC: LDL 140–200 mg/dL | 1° | 3 mg Isofl | 28 | 6.18±0.70 | mmol/L | SD | f/up | 6.10±0.65 | | | NS
| | | 27 mg Isof | 27 | 6.41±0.75 | | | | 6.21±0.78 | | | NS
| | | 37 mg Isof | 30 | 6.08±0.70 | | | | 5.97±0.57 | | | NS
| | | 62 mg Isof | 30 | 6.28±0.67 | | | | 6.03±0.52 | | | <0.05 vs con
| | | Control/Pl | 31 | 6.21±0.62 | | | | 6.23±0.70
| TC: LDL 166–200 mg/dL | 1° | 3 mg Isofl | 12 | 6.75±0.57 | mmol/L | SD | f/up | 6.52±0.54 | | | NS
| | | 27mg Isofl | 15 | 6.83±0.70 | | | | 6.47±0.80 | | | NS
| | | 37 mg Isof | 12 | 6.72±0.41 | | | | 6.21±0.65 | | | <0.03 VS CON
| | | 62 mg Isof | 15 | 6.75±0.59 | | | | 6.13±0.54 | | | <0.03 VS CON
| | | Control/Pl | 16 | 6.67±0.41 | | | | 6.67±0.54
| Tg: LDL 140–166 mg/dL | 1° | 3mg Isofla | 16 | 1.54±0.72 | g/L = mg/mL | SD | f/up | 1.56±0.64 | NS
| | | 27mg Isofl | 12 | 1.93±0.56 | | | | 1.85±0.80 | NS
| | | 37mg Isofl | 18 | 1.70±0.68 | | | | 1.63±0.63 | NS
| | | 62mg Isofl | 15 | 1.82±0.59 | | | | 1.87±0.81 | NS
| | | Control/Pl | 16 | 1.87±0.78 | | | | 1.84±0.76
| Tg: LDL 140–200 mg/dL | 1° | 3 mg Isofl | 28 | 1.63±0.68 | g/L = mg/mL | SD | f/up | 1.72±0.65 | NS
| | | 27 mg Isof | 27 | 1.87±0.71 | | | | 1.74±0.79 | NS
| | | 37 mg Isof | 30 | 1.69±0.62 | | | | 1.64±0.63 | NS
| | | 62 mg Isof | 30 | 1.73±0.67 | | | | 1.72±0.75 | NS
| | | Control/Pl | 31 | 1.73±0.70 | | | | 1.89±0.84
| Tg: LDL 166–200 mg/dL | 1° | 3 mg Isofl | 12 | 1.76±0.63 | g/L = mg/mL | SD | f/up | 1.93±0.64 | NS
| | | 27 mg Isof | 15 | 1.83±0.81 | | | | 1.65±0.80 | <0.03 VS CONTROL
| | | 37mg Isofl | 12 | 1.66±0.54 | | | | 1.64±0.67 | NS
| | | 62mg Isofl | 15 | 1.65±0.75 | | | | 1.57±0.65 | <0.03 VS CONTROL
| | | Control/Pl | 16 | 1.59±0.60 | | | | 1.93±0.91
Cuevas A 2003 | DBP | | Soy protein | ND | 73±2 | mm Hg | SE | f/up | 70±3 | NS | NS
| | | Control/Pl | ND | 73±2 | | | | 69±3 | NS
| FMD (RH) | | Soy protein | 18 | 5.3±1.2 | % | SE | f/up | 9.4±1.8 | <0.03 | <0.05
| | | Control/Pl | 18 | 5.3±1.2 | | | | 4.9±1.5 | NS
| FSH | | Soy protein | 18 | 56.5±5.8 | Other | SE | f/up | 58.6±6.6 | NS | NS
| | | Control/Pl | 18 | 56.5±5.8 | | | | 60.4±6.3 | NS
| HDL | | Soy protein | ND | 53.8±2.5 | mg/dL | SE | f/up | 53±1.9 | NS | NS
| | | Control/Pl | ND | 53.8±2.5 | | | | 50.8±1.9 | <0.05
| LDL | 1° | Soy protein | ND | 194.8±6.0 | mg/dL | SE | f/up | 160±6.8 | <0.05 | NS
| | | Control/Pl | ND | 194.8±6.0 | | | | 160.8±8.0 | <0.05
| SBP | | Soy protein | ND | 132±4 | mm Hg | SE | f/up | 127±5 | NS | NS
| | | Control/Pl | ND | 132±4 | | | | 127±5 | NS
| TC | | Soy protein | 18 | 285.9±6.8 | mg/dL | SE | f/up | 240.5±7.5 | <0.05 | NS
| | | Control/Pl | 18 | 285.9±6.8 | | | | 243.7±9.6 | <0.05
| Tg | | Soy protein | ND | 190.3±18.7 | mg/dL | SE | ▵ | -54.7 | <0.05 | NS
| | | Control/Pl | ND | 190.3±18.7 | | | | -30.1 | NS
D'Amico 1992 | DBP | 2° | Soy diet | 20 | 87±8 | mm Hg | SD | f/up | 87±10 | NS
| SBP | 2° | Soy diet | 20 | 143±20 | mm Hg | SD | f/up | 141±21 | NS
Dalais 1998 | Vasomotor symptoms | 1° | Soy bread | 44 | No statistically significant decrease in hot flush rate was detected during soy ingestion.
| | | Wheat bread | | Women consuming soy showed a statistically significant increase of 103% in vaginal cytology maturation index pattern compared to baseline (p=0.03)
Dalais 2003 | D-pyr | 1° | ISP w/ Isofla | 37 | 15.29 | nmol/umol creatinine | | ▵ | -0.8 | | NS
| | | Wheat protein | 40 | 14.47 | | | | -0.3
| Pyr | 1° | ISP w/ Isofla | 37 | 7.07 | nmol/umol creatinine | | ▵ | -0.38 | | NS
| | | Wheat protein | 40 | 7.35 | | | | -0.08
Davis 2001 | NF-kB 5-OhmdU | 1° | Soy isoflavone | Outcomes tabulated
| | | No control
Dent SB 2001 | HDL | | SPI+ | 24 | 1.51 | mmol/L | | f/up | 1.39
| | | SPI- | 24 | 1.45 | | | | 1.42
| | | Control/Pl | 21 | 1.48 | | | | 1.42
| LDL | | SPI+ | 24 | 3.28 | mmol/L | SE | f/up | 3.43
| | | SPI- | 24 | 3.49 | | | | 3.51
| | | Control/Pl | 21 | 3.47 | | | | 3.51
| Lp(a) | | SPI+ | 24 | 18.75 | nmol/L | | f/up | 18.75
| | | SPI- | 24 | 18.75 | | | | 18.75
| | | Control/Pl | 21 | 26.25 | | | | 48.75
| TC | | SPI+ | 24 | 5.42 | mmol/L | SE | f/up | 5.42
| | | SPI- | 24 | 5.63 | | | | 5.48
| | | Control/Pl | 21 | 5.49 | | | | 5.48
| Tg | | SPI+ | 24 | 1.062 | mmol/L | Unclear SD/SE | f/up | 1.186
| | | SPI- | 24 | 1.124 | | | | 1.062
| | | Control/Pl | 21 | 0.812 | | | | 1.31
Dewell A 2002 | HDL | 1° | Isoflavone | 20 | 1.2±0.1 | mmol/L | SE | f/up | 1.0±0.1 | | | NS
| | | Control/Pl | 16 | 1.2±0.1 | | | | 1.0±0.1
| TC | 1° | Isoflavone | 18 | 6.8±0.2 | mmol/L | SE | f/up | 6.4±0.2 | | | NS
| | | Control/Pl | 16 | 6.3±0.5 | | | | 6.0±0.2
| Tg | 1° | Isoflavone | 17 | 0.8±0.1 | mmol/L | SE | f/up | 0.9±0.1 | | | NS
| | | Control/Pl | 16 | 1.3±0.2 | | | | 1.4±0.2
Djuric 2001 | 5-OHmdU levels | 1° | SPI+ | 12 | Outcomes tabulated
Duncan A 1999 | E2 | 1° | low Isofla | 18 | 35.6±3.1 | | SE | f/up | 34.7±2.4 | ns
| | | high Isofl | 18 | 35.6±3.1 | | | | 29.7±2.3 | P=0.04
| FSH | 1° | low Isofla | 18 | 56.2±1.13 | | SE | f/up | 52.6±0.70 | 0.01 | <0.05
| | | low-Isofla | 14 | | | | | 4.24±0.8 | | not significant
| | | high Isofl | 18 | 56.2±1.13 | | | | 54.2±0.67 | ns | ns
| | | high-Isofl | 14 | | | | | 4.15±0.8 | | not significant
| | | Control/Pl | 18 | 56.2±1.13 | | | | 52.6±0.67 | ns
| Testosterone | 1° | low Isofla | 18 | 0.94±0.04 | nmol/L | SE | f/up | 0.90±0.02 | ns
| | | high-Isofl | 18 | 0.94±0.04 | | | | 0.83±0.02 | ns
| TSH | 1° | low Isofla | 18 | 3.48±0.15 | | SE | f/up | 3.33±0.14 | ns | ns
| | | low Isofla | 14 | | | | | 1.52±0.3 | | not significant
| | | high Isofl | 18 | 3.48±0.15 | | | | 3.49±0.13 | ns | ns
| | | high Isofl | 14 | | | | | 1.41±0.3 | | not significant
| | | Control/Pl | 18 | 3.48±0.15 | | | | 3.25±0.13 | ns
| | | Control/Pl | 14 | | | | | 1.44±0.3
Duffy 2003 | Cognitive function tests | 1° | Isoflavones | 18 | Soy isoflavones group showed significantly greater improvement in delay recall of pictures, in immediate story recall test, and in PASAT.
| | | Lactose | 15 | Groups did not differ in any other cognitive function tests.
Faure ED 2002 | Vasomotor Symptoms: per wk | 1° | Isoflavone | 38 | 10.1±6.4 | | SE | ▵ | -6.4±1.0
| | | Control/Pl | 35 | 9.4±3.4 | | | | -2.2±1.2
File 2001 | Memory Tests | 1° | High soya | 27 | High soy diet showed significant improvements in short-term (immediate recall of prose and 4 sec delayed matching to sample of patterns) and long-term memory (picture recall after 20 min) and in mental flexibility (rule shifting and reversal). In a letter fluency test and in a test of planning (Stockings of Cambridge), the high soy diet improved performance only in females.
| | | Low soya | | There was no effect of diet on tests of attention or in a category generation task.
Foth D;N 2003 | E2 | 1° | Soy | 16 | 32.30±11.69 | Other | SD | f/up | 27.40±13.23
| FSH | 1° | Soy | 16 | 70.94±39.23 | Other | SD | f/up | 72.47±30.38
Gallagher 2004 | HDL | 2° | SPI 96 | 17 | 55.0±3.1 | mg/L | SE | f/up | 52.9±3.5 | <0.05
| | | SPI 52 | 19 | 56.9±3.0 | | | | 51.7±2.6 | <0.05
| | | SPI 4 | 14 | 55.8±2.8 | | | | 51.9±2.2 | <0.05
| LDL | 2° | SPI 96 | 17 | 137.9±7.6 | mg/dL | SE | f/up | 140.9±7.1 | NS
| | | SPI 52 | 19 | 135.5±7.4 | | | | 138.2±6.7 | NS
| | | SPI 4 | 14 | 134.5±13.5 | | | | 133.8±13.8 | NS
| TC | 2° | SPI 96 | 17 | 220.6±8.3 | mg/dL | SE | f/up | 223.3±7.5 | NS
| | | SPI 52 | 19 | 219.5±7.7 (per author by email) | | | | 218.3±6.9 | NS
| | | SPI 4 | 14 | 212.5±13.6 | | | | 212.4±14.5 | NS
| Tg | 2° | SPI 96 | 17 | 137.7±19.5 | mg/dL | SE | f/up | 147.3±14.7 | NS
| | | SPI 52 | 19 | 135.3±16.4 | | | | 141.7±14.6 | NS
| | | SPI 4 | 14 | 109.9±11 | | | | 133.4±15.6 | NS
Gardner 2001 | HDL | 1° | Soy-Isofla | 33 | 1.4±0.3 | mmol/L | SD | f/up | 1.5±0.2 | | | NS
| | | Soy+Isofla | 31 | 1.5±0.3 | | | | 1.6±0.3 | | | NS
| | | Control/Pl | 30 | 1.5±0.4 | | | | 1.5±0.4
| LDL | 1° | Soy-Isofla | 33 | 3.9±0.6 | mmol/L | SD | ▵ | -0.09 | | | NS
| | | Soy+Isofla | 31 | 3.9±0.6 | | | | -0.38 | | | NS
| | | Control/Pl | 30 | 4.0±0.5 | | | | ND
| TC | 1° | Soy-Isofla | 33 | 5.9±0.7 | mmol/L | SD | ▵ | -0.02 | | | NS
| | | Soy+Isofla | 31 | 5.9±0.6 | | | | -0.27 | | | NS
| | | Control/Pl | 30 | 6.1±0.6 | | | | ND
| Tg | 1° | Soy-Isofla | 33 | 1.3±0.5 | mmol/L | SD | f/up | 1.3±0.6 | | | NS
| | | Soy+Isofla | 31 | 1.3±0.8 | | | | 1.3±0.7 | | | NS
| | | Control/Pl | 30 | 1.3±0.7 | | | | 1.4±1.0
Gardner-Thorpe 2003 | E2 | 1° | Soya flour | 19 | 102.80 (95% CI:93.07–113.55) | | SD | ▵F | 0.05 (95% CI: -1.07, 1.16) | | 0.47
| HDL | 1° | Soya flour | 19 | 1.00 (IQR: 0.90–1.18) | mmol/L | SD | ▵F | 0.00 (IQR: -0.10,0.00) | | 0.25
| | | Control/Pl | ND*
| LDL | 1° | Soya flour | 19 | 3.60 (IQR: 3.30–4.70) | mmol/L | SD | ▵F | 0.15 (IQR: -0.15,0.40) | | 0.39
| | | Control/Pl | ND*
| TC | 1° | Soya flour | 19 | 5.5 (IQR: 4.70–6.83) | mmol/L | SD | ▵F | 0.00 (IQR: -0.15,0.35) | | 0.37
| | | Control/Pl | ND
| Testosterone | 1° | Soya flour | 19 | 19.30 (95% CI:16.98–21.93) | nmol/L | SD | ▵F | 1.06 (95% CI: 1.01, 1.12) | | 0.03
| Tg | 1° | Soya flour | 19 | 1.20 (IQR: 1.00–2.90) | mmol/L | SD | ▵F | 0.00 (IQR: -0.30,0.45) | | 0.82
| | | Control/Pl | ND*
| Hydroperoxides | 1° | Soya flour | 19 | 2.69 | ¨mol /L | | ▵F% | -13% | | | 0.009
| | | Control/Pl | ND* | | | | | -4%
| Lag time | 1° | Soya flour | 19 | 59 | min | | ▵F% | +2% | | | NS
| | | Control/Pl | ND* | | | | | +2%
Gentile 1993 | DBP | 2° | Soy diet | 20 | 89.2±1.9 | mm Hg | SE | f/up | 87.4±2.2 | NS
| SBP | 2° | Soy diet | 20 | 141.1±4.8 | mm Hg | SE | f/up | 142.4±4.6 | NS
Goldberg 1982 | HDL | 1° | Soy diet | 12 | 45±10 | mg/dL | SD | f/up | 44±11 | NS | NS
| | | Control/Pl | 12 | same | | | | 45±10 | NS
| LDL | 1° | Soy diet | 12 | 191±19 | mg/dL | SD | f/up | 158±27 | <0.0001 | <0.05
| | | Control/Pl | 12 | same | | | | 168±21 | <0.001
| TC | 1° | Soy diet | 12 | 260±23 | mg/dL | SD | f/up | 220±21 | <0.0001 | <0.05
| | | Control/Pl | 12 | same | | | | 228±21 | <0.0001
| Tg | 1° | Soy diet | 12 | 116±45 | mg/dL | SD | f/up | 104±34 | NS | NS
| | | Control/Pl | 12 | same | | | | 103±39 | <0.025
Habito 2000 | Estradiol | 1° | Soy diet | 42 | | | | ▵F | 0.1 (-0.6, 0.8) | | | NS
| | | Lean meat diet | 42
| Testosterone | 1° | Soy diet | 42 | | | | ▵F | 4.6 (-3.0,12.2) | | | NS
| | | Lean meat diet | 42
Ham 1993 | TSH | 1° | Soy flour | 17 | 1.8 | mIU/L | | f/up | -0.6 | NS | | nd
| | | ISP w/Isoflavones + cotyledon | | 1.8 | mIU/L | | f/up | -0.6 | NS | | nd
| | | ISP w/Isoflavones + cellulose | | 1.8 | mIU/L | | f/up | -0.7 | NS | | nd
| | | Casein+cellulose | | 1.8 | mIU/L | | f/up | -0.3 | NS
Han KK 2002 | DBP | 1° | Isoflavone | 40 | 84±1 | | SE | f/up | 85±1 | NS | | NS
| | | Placebo | 40 | 84±2 | | | | 84±1 | NS
| E2 | 1° | Isoflavone | 40 | 9±12 | | SE | f/up | 19±2.2 | <0.001 | | <0.001
| | | Placebo | 40 | 9.6±0.5 | | | | 10.9±0.6 | NS
| Fasting Blood Glucose | 1° | Isoflavone | 40 | 95.6±1.5 | | SE | f/up | 97.4±1.4 | NS | | NS
| | | Placebo | 40 | 96.8±1.7 | | | | 93.9±1.4 | NS
| FSH | 1° | Isoflavone | 40 | 90.3±3.3 | | SE | f/up | 67±3.2 | <0.01 | | NS
| | | Placebo | 40 | 84.3±0.5 | | | | 65.4±3.7 | <0.01
| HDL | 1° | Isoflavone | 40 | 40.2±1.4 | mg/dL | SE | f/up | 44.3±1.6 | <0.005 | | NS
| | | Placebo | 40 | 40±1.3 | | | | 43.9±1.6 | <0.005
| LDL | 1° | Isoflavone | 40 | 133.6±5.3 | mg/dL | SE | f/up | 120.3±4.3 | <0.001 | | <0.001
| | | Placebo | 40 | 133.5±6.4 | | | | 139±5.2 | NS
| SBP | 1° | Isoflavone | 40 | 131±2 | | | f/up | 131±1 | NS | | NS
| | | Placebo | 40 | 133±3 | | | | 133±2 | NS
| TC | 1° | Isoflavone | 40 | 225.6±6.2 | mg/dL | SE | f/up | 199±5 | <0.001 | | <0.001
| | | Placebo | 40 | 226.6±7.7 | | | | 226.8±8.1 | NS
| Tg | 1° | Isoflavone | 40 | 204.3±23.3 | mg/dL | SE | f/up | 210.8±15.8 | <0.05 | | NS
| | | Placebo | 40 | 175.8±23.3 | | | | 186.1±6.2 | <0.05
Hargreaves 2005 | Breast cell epithelial proliferation | 1° | ISP w/Isoflav | 28 | Outcomes tabluted
| | | Control | 56
Hermansen 2001 | DBP | 1° | Soy | 20 | 78±5 | mm Hg | SD | f/up | 77±7 | | | NS
| | | Control/Pl | 20 | 78±6 | | | | 77±6
| HDL | 1° | Soy | 20 | 1.31±0.22 | mmol/L | SD | ▵▵ | 0% | | p=0.20 | NS
| | | Control/Pl | 20 | 1.28±0.29
| Homocysteine | 1° | Soy | 20 | 11.2±3.9 | mmol/L | SD | ▵▵ | -14% | | 0.004 | 0.006
| | | Control/Pl | 20 | 10.6±2.6
| LDL | 1° | Soy | 20 | 3.63±0.78 | mmol/L | SD | ▵▵ | -10% | | 0.0044 | 0.048
| | | Control/Pl | 20 | 3.64±0.80
| Lp(a) | 1° | Soy | 20 | 29.5±29.9 | | SD | ▵▵ | +8% | | NS | NS
| | | Control/Pl | 20 | 32.3±37.5
| SBP | 1° | Soy | 20 | 130±9 | | SD | f/up | 130±10 | NS | | NS
| | | Control/Pl | 20 | 130±9 | | | | 129±10 | NS
| TC | 1° | Soy | 20 | 5.68±0.84 | mmol/L | SD | f/up | 5.11±0.78 | | p=0.0041
| | | Control/Pl | 20 | 5.59±0.81 | | | | 5.45±0.88
| Tg | 1° | Soy | 20 | 1.70±1.17 | mmol/L | SD | ▵▵ | -22% | | NS | 0.04
| | | Control/Pl | 20 | 1.70±1.49
Hill S 2004 | Lipid Peroxides | 1° | ISP | 9* | ~5.2 | | SE | error
| | | Control/Pl | 9* | ~4.8
Hsu CS;S 2001 | E2 | 1° | Isoflavone | 37 | 9.6±7.7 | | SD | f/up | 21.4±22.6 | sig
Huff MW; 1984 | Fasting Blood Glucose | 2° | Soy | 5* | ND | mg/dL | SE | f/up | 76±8 | | NS
| | | Control/Pl | 5* | ND | | | f/up | 86±10
Jayagopal 2002 | DBP | 1° | Soy | 29 | 81.5±8.78 | mm Hg | SD | ▵ | -0.41%±10.4% | | 0.991
| | | Control/Pl | 29 | 82.6±7.8 | | | | -0.23%±8.83%
| FSH | 2° | Soy | 32 | 48.7±18.7 | | SD | ▵ | -5.23%±16.8% | | 0.443
| | | Control/Pl | 32 | 49.2±18.6 | | | | -2.29%±13.1%
| HDL | 1° | Soy | 31 | 1.32±0.33 | mmol/L | SD | ▵ | +0.69%±10.1% | | 0.787
| | | Control/Pl | 31 | 1.30±0.30 | | | | +1.29%±8.78%
| LDL | 1° | Soy | 31 | 3.63±0.91 | mmol/L | SD | ▵ | -7.09%±12.7% | | 0.001
| | | Control/Pl | 31 | 3.47±1.06 | | | | +5.35%±15.2%
| SBP | 1° | Soy | 29 | 146.9±18.8 | | SD | ▵ | -0.76%±9.63% | | 0.325
| | | Control/Pl | 29 | 147.2±15.2 | | | | +1.65%±7.46%
| TC | 1° | Soy | 31 | 5.78±1.02 | mmol/L | SD | ▵ | -4.07%±8.13% | | 0.004
| | | Control/Pl | 31 | 5.62±1.05 | | | | +2.82%±8.70%
| TSH | 2° | Soy | 32 | 2.15±1.08 | | SD | ▵ | +9.23%±36.4% | | 0.739
| | | Control/Pl | 32 | 2.18±1.08 | | | | +9.48%±46.1%
Jenkins 1999 | DBP | 1° | Soy | 31 | 79±2 | mm Hg | SE | ▵▵ | 2.1%±1.9% | | | 0.277
| | | Control/Pl | 31 | 80±2
| HDL | 1° | Soy | 31 | 1.26±0.06 | mmol/L | SE | ▵▵ | -0.2%±1.6% | | | 0.915
| | | Control/Pl | 31 | 1.24±0.06
| LDL | 1° | Soy | 31 | 4.40±0.15 | mmol/L | SE | ▵▵ | -6.7%±1.7% | | | <0.001
| | | Control/Pl | 31 | 4.37±0.15
| Lp(a) | 1° | Soy | 31 | 31.8±4.7 | mg/L | SE | ▵▵ | 7.2%±5.2% | | | 0.179
| | | Control/Pl | 31 | 28.8±4.2
| SBP | 1° | Soy | 31 | 120±3 | mm Hg | SE | ▵▵ | 1.3%±2.2% | | | 0.548
| | | Control/Pl | 31 | 120±3
| TBARS | 1° | Soy | 31 | 6.08±0.21 | ? | SE | ▵▵ | -2.6%±3.3% | | | 0.442
| | | Control/Pl | 31 | 6.35±0.17
| TC | 1° | Soy | 31 | 6.48±0.16 | mmol/L | SE | ▵▵ | -6.2%±1.2% | | | <0.001
| | | Control/Pl | 31 | 6.42±0.17
| Tg | 1° | Soy | 31 | 1.79±0.13 | mmol/L | SE | ▵▵ | -8.3%±4.4% | | | 0.068
| | | Control/Pl | 31 | 1.78±0.14
Jenkins 1999 Jenkins 2000 (2 publications that include patients from Jenkins 1999 paper) | Conjugated dienes | 1° | Soy | 31 | 67 | pmol/L | | ▵▵% | -16% | | | <0.001
| | | Control/Pl | 31 | 62 | | | | +2%
| Conjugated dienes:LDL | 1° | Soy | 31 | 15.7 | μmol/mmol | | ▵▵% | -4% | | | 0.03
| | | Control/Pl | 31 | 14.6 | | | | +8%
| Conjugated dienes:LDL | 1° | Soy | 20 | | μmol/mmol | | ▵▵% | 12.9 | | | 0.02
| | | Control/Pl | 20 | | | | | 14
Jenkins 2002 | DBP | 1° | low Isoflav | 41 | 78±1 | mm Hg | SE | f/up | 76±1
| | | high Isoflav | 41 | 78±2 | | | | 77±1
| | | Control/Pl | 41 | 78±2 | | | | 78±1
| HDL | 1° | low Isoflav | 41 | 1.32±0.05 | mmol/L | SE | f/up | 1.27±0.05
| | | high Isoflav | 41 | 1.32±0.06 | | | | 1.25±0.05
| | | Control/Pl | 41 | 1.33±0.05 | | | | 1.23±0.05
| Homocysteine | 1° | low Isoflav | 41 | 8.2±0.3 | mcmol/L | SE | f/up | 7.4±0.3
| | | high Isoflav | 41 | 8.2±0.4 | | | | 7.6±0.4
| | | Control/Pl | 41 | 7.6±0.3 | | | | 8.0±0.4
| LDL | 1° | low Isoflav | 41 | 4.52±0.12 | mmol/L | SE | f/up | 4.18±0.11
| | | high Isoflav | 41 | 4.55±0.11 | | | | 4.14±0.11
| | | Control/Pl | 41 | 4.62±0.10 | | | | 4.47±0.11
| Lp(a) | 1° | low Isoflav | 41 | 20.2±3.1 | mg/dL | SE | f/up | 21.7±3.4
| | | high Isoflav | 41 | 19.2±2.5 | | | | 20.1±3.2
| | | Control/Pl | 41 | 19.6±3.1 | | | | 21.6±3.4
| SBP | 1° | low Isoflav | 41 | 124±3 | mm Hg | SE | f/up | 120±2
| | | high Isoflav | 41 | 123±3 | | | | 122±2
| | | Control/Pl | 41 | 125±3 | | | | 123±3
| TC | 1° | low Isoflav | 41 | 6.68±0.13 | mmol/L | SE | f/up | 6.22±0.12
| | | high Isoflav | 41 | 6.76±0.12 | | | | 6.32±0.12
| | | Control/Pl | 41 | 6.84±0.10 | | | | 6.64±0.12
| Tg | 1° | low Isoflav | 41 | 1.84±0.18 | mmol/L | SE | f/up | 1.70±0.17
| | | high Isoflav | 41 | 1.96±0.17 | | | | 2.04±0.23
| | | Control/Pl | 41 | 1.96±0.17 | | | | 2.07±0.22
Jenkins 2002 | Conjugated dienes | 1° | low Isoflav | 37 | | pmol/L | | f/up | -16% | | NS | NS
| | | high Isoflav | 37 | | | | | -16% | | | <0.05
| | | Control/Pl | 37 | | | | | +1%
Jenkins 2003 | PSA | 1° | Soy based diet Control/Pl | 46 | outcomes tabulated
Jones G, 2003 | bAP | 1° | Isoflavone | 69 | 46.3±21.2 | no unit | SD | ▵ | 9.69±9.04 | <0.05 | NS
| | | Control/Pl | 59 | 49.0±24.9 | | | | 8.37±10.1 | <0.05
Kanazawa 1995 | oxidized LDL | 1° | Soycreme | 15 | outcomes tabulated
| | | Control/Pl | 10
Katsuyama 2004 | bAP | 1° | 1/mo | 21 | 54.3±16.6 | | Unclear SD/SE | ▵ | +1.9±24.4 | | | NS
| | | 1/wk | 16 | 51.9±19.0 | | | | -7.1±17.5 | | | NS
| | | 3/wk | 18 | 63.8±19.8 | | | | +6.7±20.8 | | | NS
| | | Control/Pl | 18 | 60.8±21.5 | | | | -0.6±20.9
| NTx | 1° | 1/mo | 21 | 45.8±23.2 | | Unclear SD/SE | ▵ | -12.0±16.7 | | | NS
| | | 1/wk | 16 | 36.0±15.3 | | | | -11.7±19.1 | | | NS
| | | 3/wk | 18 | 46.7±13.8 | | | | -2.2±30.4 | | | NS
| | | Control/Pl | 18 | 35.7±14.0 | | | | -2.7±24.4
| Serum osteocalcin | 1° | 1/mo | 21 | 1.42±0.99 | | Unclear SD/SE | ▵ | -0.29±0.73 | | | NS
| | | 1/wk | 16 | 1.95±1.55 | | | | +0.22±1.68 | | | NS
| | | 3/wk | 18 | 1.68±1.46 | | | | +1.18±2.88 | | | NS
| | | Control/Pl | 18 | 1.91±1.03 | | | | -0.01±1.43
Khalil 2002 | Bone biomarkers | 1° | ISP w/ Isofl | 24 | outcomes tabulated
| | | Casein | 22
Knight D 2001 | FSH | 1° | Isoflavone | 9 | 74.7±30.9 | other | SD | f/up | 67.4±40.7
| | | Control/Pl | 11 | 74.3±24.3 | | | | 63.9±26.7
| Vasomotor Symptoms: per wk | 1° | Isoflavone | 9 | 50.2±13.6 | | SD | f/up | 29.1±42.5
| | | Control/Pl | 11 | 56.2±26.5 | | | | 45.5±31.3
Kotsopoulos 2000 | Vasomotor Symptoms: Score | 1° | Soy | 34 | 0.82±0.17 | | SE | f/up | 0.77±0.17
| | | Control/Pl | 41 | 0.85±0.12 | | | | 0.83±0.12
Kreijkamp-Kaspers 2004 | BMD: Hip | 2° | Soy | 88 | 0.861±0.112 | g/cm2 | SE | ▵▵ | 0.005 (95% CI: -0.004, 0.013) | | | 0.27
| | | Control/Pl | 87 | 0.831±0.119
| BMD: Lumbar | 1° | Soy | 88 | 0.917±0.15 | g/cm2 | SE | ▵▵ | -0.001 (95% CI: -0.010, 0.008) | | | 0.79
| | | Control/Pl | 87 | 0.895±0.166
| bAP | 2° | Soy | 88 | 12.7±3.9 | | SE | ▵▵ | -0.229 (95% CI: -0.983, 0.525) | | | 0.55
| | | Control/Pl | 87 | 12.9±4.0
| HDL | 2° | Soy | 88 | 59.08±15.8 | mg/dL | SE | ▵▵ | +1.93 (95% CI: -0.39, 3.86) | | | 0.09
| | | Control/Pl | 87 | 59.0±13.14
| LDL | 2° | Soy | 88 | 161±38.2 | mg/dL | SE | ▵▵ | +5.40 (95% CI: -1.54, 12.74) | | | 0.12
| | | Control/Pl | 87 | 159.4±33.9
| Lp(a) | 2° | Soy | 88 | 0.27±0.37 | g/L = mg/mL | SE | ▵▵ | 0.03 (95% CI: -0.01, 0.06) | | | 0.14
| | | Control/Pl | 87 | 0.24±0.27
| TC | 1° | Soy | 88 | 240.15±45.1 | mg/dL | SD | ▵▵ | +5.79 (95% CI: -2.3, 13.9) | | | 0.15
| | | Control/Pl | 87 | 236.2±36.6
| Tg | 1° | Soy | 88 | 120.3±63.7 | mg/dL | SE | ▵▵ | -7.96 (95% CI: -19.5, 2.65) | | | 0.14
| | | Control/Pl | 87 | 110.6±52.2
KreijkampKaspers 2005 | FMD (RH) | 1° | Soy | 75 | 4.8 | % | | f/up | +0.3 | | | NS
| | | Control/Pl | 78 | 4.4 | | | | 0
| SBP | 1° | ISP w/isoflav | 88 | 138.4±16.7 | mm Hg | SD | ▵▵ | 139.2±18.2 | | | NS
| | | Milk protein | 87 | 143.4±18.2 | mm Hg | | | 139.9±18.1
| DBP | 1° | ISP w/isoflav | 88 | 74.1±10.7 | mm Hg | | ▵▵ | 74.4±14.1
| | | Milk protein | 87 | 76.2±12.9 | mm Hg | | | 74.5±12.4
Kritz-Silverstein, 2003 | Cognitive function | 1° | Isoflavones | 27 | Performance in category fluency in the soy isoflavones group improved by 23% between baseline and follow-up, whereas the performance in the placebo group improved only by 3% (P=0.02)
| | | | | No significant differences in any other cognitive function tests between the groups.
| | | Placebo | 26
Kumar NB 2002 | E2 | 1° | Soy protein | 33 | 1.31±0.21 | | SE | f/up | 1.28±0.19 | 0.19 | | 0.48
| | | Control/Pl | 33 | 1.54±0.18 | | | | 1.59±0.25 | 0.19
Kurowska 1997 | DBP | 1° | milk | 34 | 77±10 | mm Hg | SD | f/up | 73±10 | p=0.02
| | | Soybean | 34 | 77±10 | | | | 77±8 | p=0.02
| HDL | 1° | milk | 34 | 1.31±0.32 | mmol/L | SD | f/up | 1.30±0.41 | p=0.04
| | | milk/Soy o | 34 | 1.31±0.32 | | | | 1.37±0.38
| | | Soybean | 34 | 1.31±0.32 | | | | 1.40±0.28 | p=0.04
| LDL | 1° | milk | 34 | 4.45±0.95 | mmol/L | SD | f/up | 4.36±1.07
| | | milk/Soy o | 34 | 4.45±0.95 | | | | 4.29±1.15
| | | Soybean | 34 | 4.45±0.95 | | | | 4.26±1.04
| SBP | 1° | milk | 34 | 131±17 | mm Hg | SD | f/up | 123±15 | p=0.04
| | | Soybean | 34 | 131±17 | | | | 128±15 | p=0.04
| TBARs | 1° | milk | 34 | 1.35±0.43 | ? | SD | f/up | 1.26±0.43 | 0.01
| | | Soybean | 34 | 1.35±0.43 | | | | 1.41±0.55 | 0.01
| TC | 1° | milk | 34 | 6.86±0.99 | mmol/L | SD | ▵F | -1%
| | | milk/Soy | 34 | 6.86±0.99 | | | | 4%
| | | Soybean | 34 | 6.86±0.99 | | | | 9%
| Tg | 1° | milk | 34 | 1.75±0.64 | mmol/L | SD | f/up | 1.85±0.72
| | | milk/Soybean | 34 | 1.75±0.64 | | | | 1.90±0.85
| | | Soybean | 34 | 1.75±0.64 | | | | 1.94±0.83
Laskowski 2003 | Adaptation process | 1° | soy protein supplement | 6 | outcomes tabulated
| | | no soy protein supplement | 6
Lenn 2002 | Cortisol | 1° | ISP+ | 8 | outcomes tabulated
| | | Control/Pl | 7
Lichtenstein 2002 | HDL | | Soy w/o Isoflav | 42 | 1.32±0.28 | mmol/L | SD | f/up | 1.36±0.34
| | | Soy w/ Isoflav | 42 | 1.32±0.28 | | | | 1.36±0.33
| | | animal die | 42 | 1.32±0.28 | | | | 1.33±0.32
| | | animal die | 42 | 1.32±0.28 | | | | 1.31±0.34
| LDL | 1° | Soy w/o Isoflav | 42 | 4.14±0.65 | mmol/L | SD | f/up | 4.34±0.92
| | | Soy w/ Isoflav | 42 | 4.14±0.65 | | | | 4.29±0.96
| | | animal wit | 42 | 4.14±0.65 | | | | 4.42±0.97
| | | animal WIT | 42 | 4.14±0.65 | | | | 4.44±1.01
| TC | 1° | Soy w/o Isoflav | 42 | 6.17±0.78 | mmol/L | SD | f/up | 6.37±1.12
| | | Soy w/ Isoflav | 42 | 6.17±0.78 | | | | 6.24±1.11
| | | animal wit | 42 | 6.17±0.78 | | | | 6.47±1.17
| | | animal WIT | 42 | 6.17±0.78 | | | | 6.42±1.17
| Tg | 1° | Soy w/o Isoflav | 42 | 1.54±0.66 | mmol/L | SD | f/up | 1.27±0.50
| | | Soy w/ Isoflav | 42 | 1.54±0.66 | | | | 1.27±0.46
| | | animal die | 42 | 1.54±0.66 | | | | 1.44±0.57
| | | animal die | 42 | 1.54±0.66 | | | | 1.46±0.52
Lissin L 2004 | LDL | 1° | Isoflavones | 20* | 163±29 | mg/dL | SE | ▵ | -0.56%±2.5% | | | 0.16
| | | Control/Pl | 20* | 165±22 | | | | -5.6%±2.5%
| TC | 1° | Isoflavones | 20* | 243±26 | mg/dL | SE | ▵ | -2.2%±1.7% | | | 0.27
| | | Control/Pl | 20* | 236±22 | | | | -5.2%±2.0%
| FMD (RH) | 1° | Isoflavones | 20* | 1.3 | % | | ▵ | +3.4 | NS | | NS
| | | Control/Pl | 20* | 3.8 | | | | -0.6 | NS
Lu 1996 | Menstrual Cycle Length | 1° | Soy milk | 6 | 28.3 | days | | ▵ | +3.5 | NS
Lu LJ;An 2000 | Menstrual Cycle Length | 1° | Soy milk | 10 | 26.6±1.6 | days | SD | f/up | 26.0±2.0 | NS
Lu LJ 2001 | FSH | 1° | Soymilk w/ | 9 | 2.7 | IU/L | | ▵ | -0.2 | NS
| | | Soymilk w/
| estradiol | 1° | Soymilk w/ | 9 | 107 | pg/mL | | ▵ | 0 | NS
| | | Soymilk w/
Luz LJW; 2000 | Menstrual Cycle Length | 2° | Soymilk w/ | 8 | | other | SD | f/up | 26.6±2.9
| | | Soymilk no | 8 | | | | | 25.8±1.9
Lydeking-olsen 2004 | BMD: Femoral Neck | 1° | Soymilk w/ | 23 | ND | g/cm2 | SD | ▵ | -0.9 | NS | | NS
| | | Soymilk w/ | 22 | ND | | | | +0.2 | NS
| BMD: Lumbar | 1° | Soymilk w/ | 23 | 0.925±0.260 | g/cm2 | SD | ▵ | +1.1% | NS | | 0.009
| | | Soymilk w/ | 22 | 0.865±0.190 | | | | -4.2% | 0.006
Mackey R 2000 | HDL | 1° | ISP+ | 25 | 1.52±0.39 | mmol/L | SD | f/up | 1.52±0.31
| | | ISP- | 24 | 1.66±0.45 | | | | 1.70±0.45
| | | ? | tot | 1.59±0.42 | | | | 1.60±0.39
| LDL | 1° | ISP+ | 25 | 5.07±0.73 | mmol/L | SD | f/up | 4.71±0.73
| | | ISP- | 24 | 5.11±1.02 | | | | 4.78±0.96
| | | ? | tot | 5.09±0.88 | | | | 4.74±0.84
| SHBG_outcomes | 1° | ISP+ | 22 | 43.73±22.89 | | SD | f/up | 38.85±20.19
| | | ISP- | 24 | 45.03±17.79 | | | | 43.07±19.18
| | | ? | tot | 44.41±20.17 | | | | 41.05±19.57
| TC | 1° | ISP+ | 25 | 7.29±0.90 | mmol/L | SD | f/up | 6.94±0.84
| | | ISP- | 24 | 7.47±1.04 | | | | 7.15±1.02
| | | ? | Tot | 7.38±0.96 | | | | 7.04±0.93 | 0.0003
| Tg | 1° | ISP+ | 25 | 1.53±0.82 | mmol/L | SD | f/up | 1.54±0.74
| | | ISP- | 24 | 1.54±0.72 | | | | 1.46±0.82
| | | ? | tot | 1.53±0.77 | | | | 1.50±0.77
Mackey 2000 11216493_study2 | Testosterone | 1° | ISP+ | 27 | outcomes tabulated
| FSH
| TSH
Martini 1999 | E2 | 1° | ISP+ | 36 | outcomes tabulated
Maskarinec 2002 | E2 | 1° | Soy Isofla | 13 | 3.7±1 | other | SD | ▵▵ | -0.51 (95% CI: -1.62, +0.61) | | 0.36
| | | Control/Pl | 13 | 3.2±1.4
| FSH | 1° | Soy Isofla | 12 | 3.2±1.2 | | SD | ▵▵ | -0.82 (95% CI: -2.53, +0.897) | | 0.34
| | | Control/Pl | 16 | 4.1±1.8
Maskarinec 2004 | E2 | 1° | ISP+ | 91 | 150 | pg/mL | | ▵ | +2 | | NS | NS
| | | | 96 | 136 | pg/mL | | ▵ | -14 | NS
Maskarinec 2003 | Mammographic density | 1° | Soy Isofla | 15 | outcomes tabulated
| | | Control/Pl
Mc Michael Philips 1998 | epithelial cells in the S phase progesterone receptor expression | 1° | Soy bread | 19 | outcomes tabulated
| | | normal unsupplemented (without soy) diet | 29
Meinertz 1988 | HDL | 1° | ISP | 10 | 47±13 | mg/dL | SD | f/up | 47±11 | | NS
| | | casein | 10 | 47±13 | | | | 46±10
| LDL | 1° | ISP | 10 | 110±25 | mg/dL | SD | f/up | 68±21 | | NS
| | | casein | 10 | 110±25 | | | | 67±19
| TC | 1° | ISP | 10 | 171±32 | mg/dL | SD | f/up | 127±24 | | NS
| | | casein | 10 | 171±32 | | | | 125±24
| Tg | 1° | ISP | 10 | 68±32 | mg/dL | SD | f/up | 63±25 | | NS
| | | casein | 10 | 68±32 | | | | 56±14
Meinertz 1989 | HDL | 1° | ISP | 11 | 1.49±0.32 | mmol/L | SD | ▵F | +16% | | <0.01
| | | casein | 11 | same
| LDL | 1° | ISP | 11 | 2.64±0.97 | mmol/L | SD | ▵F | -16% | | <0.02
| | | casein | 11
| TC | 1° | ISP | 11 | 4.43±0.98 | mmol/L | SD | ▵F | -4% | | NS
| | | casein | 11 | same
| Tg | 1° | ISP | 11 | 0.65±0.23 | mmol/L | SD | ▵F | +2% | | NS
| | | casein | 11 | same
Meinertz 2002 | HDL | 1° | casein | 12 | | mmol/L | SD | f/up | 1.27±0.23 | <0.05 | | --
| | | extracted | 12 | | | | | 1.34±0.22 | NS | | NS
| | | intact Soy | 12 | | | | | 1.40±0.19 | NS | | <0.05
| LDL | 1° | casein | 12 | 2.05±0.60 | mmol/L | SD | f/up | 1.65±0.35 | <0.01 | | --
| | | extracted | 12 | 2.17±0.52 | | | | 1.71±0.41 | <0.01 | | NS
| | | intact Soy | 12 | 2.16±0.50 | | | | 1.61±0.36 | <0.001 | | NS
| TC | 1° | casein | 12 | 4.02±0.87 | mmol/L | SD | f/up | 3.15±0.43 | <0.001 | | --
| | | extracted | 12 | 4.16±0.64 | | | | 3.25±0.37 | <0.001 | | NS
| | | intact Soy | 12 | 4.15±0.86 | | | | 3.39±0.34 | <0.001 | | NS
| Tg | 1° | casein | 12 | 0.87±0.30 | mmol/L | SD | f/up | 0.74±0.20 | NS | | --
| | | extracted | 12 | 0.92±0.34 | | | | 0.66±0.14 | <0.01 | | NS
| | | intact Soy | 12 | 1.00±0.43 | | | | 0.83±0.22 | NS | | NS
Merz- Demlow 2000 | HDL | 1° | high Isofl | 13 | 47.8±0.5 | mg/dL | SE | f/up | 48.8±1.1
| | | low Isofla | 13 | | | | | 48.6±1.1
| | | no Isoflav | 13 | | | | | 47.3±1.0
| LDL | 1° | high Isofl | 13 | 84.4±1.0 | mg/dL | SE | f/up | 79.8±2.0
| | | low Isofla | 13 | | | | | 86.8±2.0
| | | no Isoflav | 13 | | | | | 88.7±1.9
| TC | 1° | high Isofl | 13 | 143.8±1.1 | mg/dL | SE | f/up | 139.1±2.9
| | | low Isofla | 13 | | | | | 146.3±2.9
| | | no Isoflav | 13 | | | | | 148.7±2.7
| Tg | 1° | high Isofl | 13 | 56.3±1.6 | mg/dL | SE | f/up | 52.4±3.8
| | | low Isofla | 13 | | | | | 54.3±3.8
| | | no Isoflav | 13 | | | | | 62.9±3.5
| Lp(a) | 1° | high Isofl | 13 | nd | mg/dL | SE | | 14.59±0.63 | NS
| | | low Isofla | 13 | | | | | 15.16±0.63
| | | no Isoflav | 13 | | | | | 14.64±0.58
Meyer BJ 2004 | DBP | 1° | Soy | 23 | 77±1.9 | | SE | ▵F | -2.00±1.7 | | NS
| | | dairy | 23 | 77±1.9
| HDL | 1° | Soy | 23 | 1.28±0.09 | mmol/L | SE | ▵F | 0.06±0.03 | | NS
| | | dairy | 23 | 1.28±0.09
| LDL | 1° | Soy | 23 | 4.13±0.24 | mmol/L | SE | ▵F | -0.05±0.10 | | NS
| | | dairy | 23 | 4.13±0.24
| Lp(a) | 1° | Soy | 23 | 15.4±26.0 | mg/dL | SE | ▵F | -0.30±-0.87 | | NS
| | | dairy | 23 | 15.4±26.0
| SAC (Large Arteries) | 1° | Soy | 23 | 13.0±0.07 | mL/mmHg | SE | ▵F | -0.03±0.04 | | ns
| | | dairy | 23 | 13.0±0.07
| SAC (Small Arteries) | 1° | Soy | 23 | 5.8±0.6 | mL/mmHg | SE | ▵F | -0.05±0.36 | | NS
| | | dairy | 23 | 5.8±0.6
| SBP | 1° | Soy | 23 | 132±2.9 | | SE | ▵F | -0.60±1.7 | | NS
| | | diary | 23 | 132±2.9
| TC | 1° | Soy | 23 | 6.00±0.25 | mmol/L | SE | ▵F | 0.00±0.13 | | NS
| | | control | 23 | 6.00±0.25
| Tg | 1° | Soy | 23 | 1.30±0.14 | mmol/L | | ▵F | -0.02±0.10 | | NS
| | | dairy | 23 | 1.30±0.14
Mitchell 2001 | E2 | 1° | Soy | 14 | 4.44 | Other | SE | f/up | 4.40
| FSH | 1° | Soy | 14 | 35.21 | Other | SE | f/up | 33.38
Morabito 2002 | BMD: Femoral Neck | 1° | Placebo | 30* | 0.689±0.06 | Other | SE | ▵ | -0.65±0.1
| | | Genistein | 30* | 0.687±0.05 | | | | 3.6±3
| BMD: Lumbar | 1° | Placebo | 30* | 0.934±0.07 | g/cm2 | SE | ▵ | -1.6%±0.3
| | | Genistein | 30* | 0.915±0.07 | | | | 3%±2 | <0.04
| bAP | 1° | Placebo | 30 | 10±4 | | SD | f/up | 9.6±3
| | | Genistein | 30 | 9.7±1.2 | | | | 12±4
| E2 | 1° | Placebo | 30 | 77±14 | Other | SD | f/up | 73±7.3
| | | Genistein | 30 | 73±2.9 | | | | 77±2.9
Murkies 1995 | FSH | 1° | Soy Flour | 23 | 84.52±4.63 | Other | SE | f/up | 83.17±4.62 | <0.05 | | 0.32
| | | Control/Pl | 24 | 82.93±3.85 | | | | 74.84±4.64
| HDL | 1° | Soy flour | 23 | 1.73±0.09 | mmol/L | SE | f/up | 1.68±0.10 | NS | | 0.35
| | | Control/Pl | 24 | 1.64±0.06 | | | | 1.60±0.06
| TC | 1° | Soy flour | 23 | 6.09±0.21 | mmol/L | SE | f/up | 5.82±0.20 | NS | | 0.38
| | | Control/Pl | 24 | 5.93±0.17 | | | | 5.69±0.21 | NS
| Tg | 1° | Soy flour | 23 | 1.07±0.13 | mmol/L | SE | f/up | 1.05±0.15 | NS | | 0.62
| | | Control/Pl | 24 | 1.08±0.10 | | | | 1.12±0.15
| Vasomotor Symptoms: Flush Score | 1° | Soy flour | 28 | 6±0.5 | no unit | SE | f/up | 3.5±0.6 | <0.001 | | 0.82
| | | Control/Pl | 30 | 5.3±0.5 | | | | 4±0.6
Murray M 2003 | HDL | 2° | placebo+0 | 7 | 67±9 | mg/dL | SD | f/up | 71±10 | 0.21 | | 0.43
| | | placebo+1m | 7 | 62±21 | | | | 60±19 | 0.87
| | | SPI+0.5mgE | 8 | 64±15 | | | | 68±15 | 0.40
| | | SPI+1mgE | 8 | 69±16 | | | | 64±17 | 0.24
| LDL | 2° | placebo+0 | 7 | 125±17 | mg/dL | SD | f/up | 118±15 | 0.35 | | 0.45
| | | placebo+1m | 7 | 164±43 | | | | 168±105 | 0.35
| | | SPI+0.5mgE | 8 | 120±28 | | | | 120±24 | 0.74
| | | SPI+1mgE | 8 | 129±35 | | | | 107±37 | 0.12
| TC | 2° | placebo+0 | 7 | 211±12 | mg/dL | SD | f/up | 209±18 | 0.60 | | p=0.46
| | | placebo+1m | 7 | 261±15 | | | | 244±19 | 0.13*
| | | SPI+0.5mgE | 8 | 212±29 | | | | 213±22 | 0.73
| | | SPI+1mgE | 8 | 216±25 | | | | 203±44 | 0.26
| Tg | 2° | placebo+0 | 7 | 99±55 | mg/dL | SD | f/up | 87±24 | 0.69 | | 0.04
| | | placebo+1m | 7 | 191±89 | | | | 256*±150 | 0.46
| | | SPI+0.5mgE | 8 | 116±60 | | | | 119±58 | 0.78
| | | SPI+1mgE | 8 | 97±38 | | | | 150±58 | 0.02
Nagata C 1998 | E2 | 1° | Soymilk | 21 | 98.0±85.0 | | SD | f/up | 65.4±51.7 | 0.10 | 0.13
| | | Control/Pl | 23 | 84.8±74.8 | | | | 93.6±90.1 | 0.60
Nagata 2001 | testosterone | 1° | Soymilk | 17 | 16.3 | | | f/up | -2.2 | NS | | NS
| | | Control/Pl | 17 | 15.6 | | | | -0.4 | NS
Nestel P 1997 | Diene Oxidation Rate | 1° | Isoflavone | 15 | ND | | SD | f/up | 14.1±1.9 | | NS
| | | placebo | 15 | ND | | | | 14.4±2.3
| HDL | 1° | Isoflavone | 21 | 1.30±0.43 | mmol/L | SD | f/up | 1.23±0.31
| | | placebo | 21 | 1.30±0.43 | | | | 1.30±0.39
| Lagtime: Copper | 1° | Isoflavone | 15 | ND | min | SD | f/up | 53.2±5.2 | | NS
| | | placebo | 15 | ND | | | | 53.5±5.7
| LDL | 1° | Isoflavone | 21 | 3.57±0.84 | mmol/L | SD | f/up | 3.43±0.85
| | | placebo | 21 | 3.57±0.84 | | | | 3.35±0.14
| MAP | 1° | Isoflavone | 21 | 86±10 | | SD | f/up | 80±10 | <0.05 | | NS
| | | placebo | 21 | 86±10 | | | | 80±12 | <0.05
| Max. Diene Concentration | 1° | Isoflavone | 15 | nd | nmol/mg | SD | f/up | 406.0±41 | | NS
| | | placebo | 15 | nd | | | | 409.0±45
| SAC | 1° | Isoflavone | 21 | 0.67±0.33 | | SD | f/up | 0.99±0.54 | <0.05 | 0.011
| | | placebo | 21 | 0.67±0.33 | | | | 0.81±0.4 | <0.05
| TBARS (after oxidation) | 1° | Isoflavone | 15 | nd | | SD | f/up | 72.0±14 | | NS
| | | placebo | 15 | nd | | | | 70.0±16
| TC | 1° | Isoflavone | 21 | 5.54±0.94 | mmol/L | SD | f/up | 5.37±0.93
| | | placebo | 21 | 5.54±0.94 | | | | 5.25±1.28
| Tg | 1° | Isoflavone | 21 | 1.45±0.71 | mmol/L | SD | f/up | 1.53±0.99
| | | placebo | 21 | 1.45±0.71 | | | | 1.30±0.67
Nikander 2003 | CRP | | Isoflavones 1^st^ | 56 | 1.16±1.03 | mg/L | SD | f/up | 1.10±0.91 | 0.779
| | | Placebo 1^st^ | 56 | 1.10±0.79 | | | | 1.10±0.84 | 0.322
| E2 | 2° | Isoflavones 1^st^ | 28 | 0.140±0.085 | Other | SD | f/up | 0.138±0.144 | 0.579
| | | Placebo 1^st^ | 28 | 0.127±0.085 | | | | 0.141±0.156 | 0.542
| FSH | 2° | Isoflavones 1^st^ | 28 | 79.9±34.5 | Other | SD | f/up | 79.5±32 | 0.851
| | | Placebo 1^st^ | 28 | 78.8±31.3 | | | | 77.8±30.7 | 0.552
| Vasomotor Symptoms: Score | 1° | Isoflavones 1^st^ | 28 | 2±0.9 | no unit | SD | f/up | 1.8±1.0 | 0.235
| | | Placebo 1^st^ | 28 | 2.1±0.8 | | | | 1.8±0.9 | 0.006
Nikander 2004 | 2-hr OGTT | 2° | Isoflavones 1^st^ | 56 | 5.9±2.0 | mmol/L | SD | f/up | 5.5±1.4 | | | NS
| | | Control/Pl | 56 | 6.0±1.8 | | | | 6.3±2.2
| bAP | 1° | Isoflavones 1^st^ | 28 | 14.6±5.8 | mg/L | SD | ▵ | 0.00±2.5 | 0.896
| | | placebo | 28 | 14.7±6.2 | | | | 0.5±2.3 | 0.024
| Fasting Blood Glucose | 2° | Isoflavones 1^st^ | 56 | 5.1±1.1 | mmol/L | SD | f/up | 5.6±2.2 | | | NS
| | | Control/Pl | 56 | 5.1±0.9 | | | | 5.1±0.9
| HDL | 2° | Isoflavones 1^st^ | 56 | 1.78±0.45 | mmol/L | SD | ▵ | -0.028±0.26 | NS
| | | Control/Pl | 56 | 1.76±0.38 | | | | -0.008±0.27 | NS
| LDL | 2° | Isoflavones 1^st^ | 56 | 3.87±0.93 | mmol/L | SD | ▵ | +0.28±0.63 | NS
| | | Control/Pl | 56 | 3.80±1.17 | | | | -0.06±0.68 | NS
| LDL: Baseline > 162 mg/dL | 2° | Isoflavones 1^st^ | 26 | nd | mmol/L | SD | ▵ | +0.65±0.60 | | | 0.009
| | | Control/Pl | 26 | nd | | | | -0.45±0.67
| Lp(a) | 2° | Isoflavones 1^st^ | 56 | 171.2±204.8 | mg/L | SD | ▵ | +8.7±66.9 | NS
| | | Control/Pl | 56 | 175.8±221.7 | | | | -8.6±79.1 | NS
| NTx | 1° | Isoflavones 1^st^ | 28 | 71.9±48.1 | | SD | ▵ | -2.4±22.7 | 0.388
| | | Control/Pl | 28 | 73.7±49.1 | | | | +3.1±37.8 | 0.185
| TC | 2° | Isoflavones 1^st^ | 56 | 5.88±0.97 | mmol/L | SD | ▵ | +0.14±0.95 | NS
| | | Control/Pl | 56 | 5.83±1.04 | | | | +0.06±0.67 | NS
| Tg | 2° | Isoflavones 1^st^ | 56 | 1.22±0.57 | mmol/L | SD | ▵ | +0.015±0.48 | NS
| | | Control/Pl | 56 | 1.25±0.53 | | | | +0.005±0.39 | NS
Nilausen 1999 | Lp(a) | 1° | Soy diet liquid | 9 | 12.7 | mg/L | SEM | ▵ | -2.7 | NS | | <0.002
| | | Casein, liquid | 9 | 12 | mg/L | | | -7.2 | <0.0002
Onning G 1998 | Fasting Blood Glucose | 1° | Soya milk | 12* | 5.3±0.1 | mmol/L | SE | ▵ | +0.1±0.1 | NS
| | | oat milk
| HDL | 1° | Soya milk | 12* | 1.1±0.1 | mmol/L | SE | ▵ | 0.0±0.0 | NS
| | | oat milk
| LDL | 1° | Soya milk | 12* | 2.9±0.3 | mmol/L | SE | ▵ | -0.2±0.1 | <0.05
| | | oat milk
| TC | 1° | Soya milk | 12* | 4.4±0.3 | mmol/L | SE | ▵ | -0.1±0.1 | NS
| | | oat milk
| Tg | 1° | Soya milk | 12* | 0.9±0.1 | mmol/L | SE | ▵ | +0.1±0.1 | NS
| | | oat milk
Pap A 1983 | Secretin-pancreozymin | 1° | Soy flour | 34 | Outcomes tabulated
Pap A 1984 | Pancreatic enzyme secretory capacity | 1° | Soy flour | 10 | Outcomes tabulated
| | | cholecystokinin-octapeptide | 10
Penotti 2003 | Vasomotor Symptoms: per wk | 1° | Isoflavone | 22 | 9.9±4.5 | no unit | SD | f/up | 4.6±3.8
| | | Control/Pl | 27 | 8.6±2.9 | | | | 4.0±3.9 | not significant diff
Persky V 2002 | E2 | 1° | ISP56 | 24 | 17.5 (95% CI: 8.1–37.9) | | | f/up | 24.5 (95% CI: 11.7–51.5) | ns | | ns
| | | ISP90 | 23 | 9.7 (95% CI: 3.0–31.4) | | | | 10.8 (95% CI: 3.9–30.1) | ns | | ns
| FSH | 1° | ISP56 | 24 | 39.7 (95% CI: 34.6–44.8) | | | f/up | 36.8 (95% CI: 30.7–42.9) | ns | | ns
| | | ISP90 | 23 | 43.7 (95% CI: 34.9–52.4) | | | | 44.0 (95% CI: 37.0–51.0) | ns | | ns
| TSH | 1° | ISP56 | 24 | 2.22 (95% CI: 1.94–2.54) | | | f/up | 2.05 (95% CI: 1.83–2.29) | ns | | ns
| | | ISP90 | 22 | 2.04 (95% CI: 1.68–2.49) | | | | 2.22 (95% CI: 1.79–2.75) | ns | | 0.01
| | | Control/Pl | 24 | 2.25 (95% CI: 1.82–2.79) | | | | 2.00 (95% CI: 1.65–2.43) | ns
Petrakis 1996 | E2 pre | 1° | ISP+ | 14 | 81.2 | pg/mL | | ▵ | +8.6 | NS
| E2 post | 1° | ISP+ | 10 | 53.3 | pg/mL | | ▵ | -0.5 | NS
Petri NE 2004 | E2 | 1° | Soy | 25 | 15.8±7.3 | | SD | f/up | 17.7±6.7 | < 0.05
| | | Control/Pl | 25 | 14.6±6.0 | | | | 12.3±3.8
| FSH | 1° | Soy | 25 | 76.8±13.4 | | SD | f/up | 77.7±19.6
| | | Control/Pl | 25 | 75.2±28.7 | | | | 82.5±30.7
| HDL | 1° | Soy | 25 | 43.95±11.31 | mg/dL | SD | f/up | 57 | <0.05
| | | Control/Pl | 25 | 48.10±12.96 | | | | 48 | NS
| LDL | 1° | Soy | 25 | 151.50±39.22 | mg/dL | SD | f/up | 132 | <0.05
| | | Control/Pl | 25 | 130.50±23.57 | | | | 143 | NS
| TC | 1° | Soy | 25 | 229.65±31.58 | mg/dL | SD | f/up | 217 | NS
| | | Control/Pl | 25 | 203.75±25.08 | | | | 204 | NS
| Tg | 1° | Soy | 25 | 150.35±94.38 | mg/dL | SD | f/up | 150 | NS
| | | Control/Pl | 25 | 139.00±68.93 | | | | 143 | NS
Potter S 1993 | HDL | 1° | Soy flour | 24 | 0.96±0.18 | mmol/L | SD | f/up | 0.95±0.16
| | | ISP w/fiber | 24 | 0.96±0.18 | | | | 0.91±0.15
| | | ISP w/fiber | 24 | 0.96±0.18 | | | | 0.91±0.15
| | | control | 24 | 0.96±0.18 | | | | 0.92±0.14
| LDL | 1° | Soy flour | 24 | 4.53±0.61 | mmol/L | SD | f/up | 4.30±0.78
| | | ISP w/fiber | 24 | 4.53±0.61 | | | | 4.15±0.75 | <0.01
| | | ISP w/cell | 24 | 4.53±0.61 | | | | 4.17±0.65 | <0.01
| | | control | 24 | 4.53±0.61 | | | | 4.64±0.87
| TC | 1° | Soy flour | 25 | 5.90±0.70 | mmol/L | SD | f/up | 5.61±0.88 | | <0.05
| | | ISP w/fiber | 25 | 5.90±0.70 | | | | 5.45±0.81 | <0.05 | <0.01
| | | ISP w/cell | 25 | 5.90±0.70 | | | | 5.44±0.69 | <0.05 | <0.01
| | | control | 25 | 5.90±0.70 | | | | 6.10±1.04
| Tg | 1° | Soy flour | 23 | 1.95±0.82 | mmol/L | SD | f/up | 2.12±0.86
| | | ISP w/fiber | 23 | 1.95±0.82 | | | | 2.00±0.70
| | | ISP w/cell | 23 | 1.95±0.82 | | | | 2.00±0.75
| | | control | 23 | 1.95±0.82 | | | | 2.29±0.96
Potter 1998 | BMD | 1° | ISP56 | 23 | Lumbar spine BMD increased significantly in the high-dose group (soy protein with 90 mg/day of total isoflavones) compared to control.
| | | ISP90 | 21
| | | Nonfat milk | 22
Puska P; 2002 | HDL | 1° | Soya | 24* | 1.58±0.44 | mmol/L | SD | ▵▵ | +0.01 (95% CI: +0.10, -0.09) | | | 0.904
| | | placebo | 28* | 1.56±0.43
| Homocysteine | 1° | Soya | 24* | 10.52±3.68 | mmol/L | SD | ▵▵ | -1.74 (95% CI: -0.87, -2.60) | | | <0.001
| | | placebo | 28* | 9.65±2.27
| LDL | 1° | Soya | 24* | 5.13±0.48 | mmol/L | SD | ▵▵ | -0.27 (95% CI: -0.06, -0.49) | | | 0.014
| | | placebo | 28* | 5.15±0.74
| Lp(a) | 1° | Soya | 24 | 272±341 | g/L = mg/mL | SD | ▵▵ | +43.6 (95% CI: +111.0, -23.9) | | | 0.212
| | | placebo | 24 | 341±495
| TC | 1° | Soya | 24* | 7.50±0.57 | mmol/L | SD | ▵▵ | -0.25 (95% CI: -0.01, -0.50) | | | 0.049
| | | placebo | 28* | 7.68±0.54
| Tg | 1° | Soya | 24* | 1.76±0.78 | mmol/L | SD | ▵▵ | +0.06 (95% CI: +0.35, -0.22) | | | 0.663
| | | placebo | 28* | 1.81±1.30
Puska P; 2004 | DBP | 1° | Soya | 69 | 80.5±8.7 | mm Hg | SD | f/up | 80.6±8.2
| | | placebo | 74 | 81.1±9.4 | | | | 81.3±9.7
| HDL | 1° | Soya | 69* | 1.67±0.53 | mmol/L | SD | ▵▵ | +0.01 (: -0.05, 0.03) | | | 0.60
| | | placebo | 74* | 1.72±0.45
| Homocysteine | 1° | Soya | 69* | 10.41±2.74 | mmol/L | SD | ▵▵ | +0.58 (95% CI: -1.48, 0.32) | | | 0.20
| | | placebo | 74* | 11.16±5.50
| LDL | 1° | Soya | 69* | 5.11±0.69 | mmol/L | SD | ▵▵ | -0.40 (95% CI: 0.25, 0.55) | | | <0.001
| | | placebo | 74* | 5.13±0.75
| SBP | 1° | Soya | 69 | 130.0±15.8 | mm Hg | SD | f/up | 129.6±15.8
| | | placebo | 74 | 132.4±17.1 | | | | 131.3±15.7
| TC | 1° | Soya | 69* | 7.53±0.79 | mmol/L | SD | ▵▵ | -0.40 (95% CI: -0.26, -0.55) | | | <0.001
| | | placebo | 74* | 7.59±0.77
| Tg | 1° | Soya | 69* | 1.68±0.80 | mmol/L | SD | ▵▵ | 0 (95% CI: -0.15, 0.15) | | | 1.00
| | | placebo | 74* | 1.67±0.58
Quella 2000 | Hot flash score | 1° | Isoflavones | 177 /149 | 12 | 1 score unit | | ▵▵ | -30% | | | NS
| | | Placebo | | 13 | | | | -32%
Ross 1995 | PDGF | 1° | tofu | 23 | Outcomes tabulated
Rivas M; 2002 | DBP | | Soy milk | 20* | 100.3±8.8 | mm Hg | SD | ▵ | -15.9±9.8 | <0.0001
| | | Control/Pl | 20* | 99.2±5.4 | | | | -3.7±5.0
| SBP | | Soy milk | 20* | 155±12.5 | mm Hg | SD | ▵ | -18.4±10.7 | <0.0001
| | | Control/Pl | 20* | 151.7±13.8 | | | | -1.4±7.2
Russo 2003 | Menopausal symptoms | 1° | Isoflavones Placebo | 47 | Although a crossover trial, the data were analyzed descriptively in the study. The percent change for both treatment arms was calculated as follows: (# subjects reported no improvement after soy treatment - # reporting no improvement after placebo treatment) / (# reported no improvement after soy treatment). Dropouts excluded from analyses. This analysis does not consider time effect (i.e.. the order of getting treatments).
| | | | | No significant difference in the overall improvement rate of menopausal symptoms between the groups.
Sagara M 2004 | DBP | | Soy | 25 | 87.1±1.8 | mm Hg | SE | ▵ | -5.1 | <0.01 | | 0.138
| | | Control/Pl | 25 | 80.8±10.2 | | | | -1.7 | ns
| HDL | | Soy | 25 | 53.7±2.0 | mg/dL | SE | ▵ | 3.7 | <0.01 | | 0.057
| | | Control/Pl | 25 | 55.0±2.5 | | | | 4.7 | <0.01
| SBP | | Soy | 25 | 142.0±3.0 | mm Hg | SE | ▵ | -10.8 | <0.01 | | 0.05
| | | Control/Pl | 25 | 134.0±3.2 | | | | | ns
| TC | | Soy | 25 | 239.5±7.9 | mg/dL | SE | ▵ | -14.8 | <0.05 | | 0.357
| | | Control/Pl | 25 | 231.5±7.2 | | | | -5.0 | ns
Saxena 1999 | Misc. outcomes | | Soy diet | 45 | Outcome tabulated
Scambia 2000 | Vasomotor Symptoms: per wk | 1° | Soy extract | 20* | 27±5.2 | | SD | error | | <0.01
| | | Control/Pl | 19* | 33±5.1
Scheiber 2001 | bAP | 1° | Soy | 42 | 19.4±9.3 | | SD | f/up | 20.5±12.5
| E2 | 2° | Soy | 42 | 17.4±7.0 | | SD | f/up | 18.9±12.4
| FSH | 2° | Soy | 42 | 54.1±23.4 | | SD | f/up | 52.5±20.8
| LDL oxidation lag time | 1° | Soy | 42 | 34.9±6.8 | | SD | f/up | 38.2±7.6 | <0.05
| NTx | 1° | Soy | 42 | 52.4±26.3 | | SD | f/up | 45.1±21.1 | <0.02
| Serum Osteocalcin | 1° | Soy | 42 | 5.8±2.1 | | SD | f/up | 6.4±2.1 | <0.03
Secreto 2004 | Vasomotor Symptoms: Score | 1° | Isoflavone | 61 | Median=24 (IQR: 20–30) | | SD | ▵ | 9.8±11.4
| | | Isoflavone | 59 | Median=25 (IQR: 19–30) | | | | 8.9±8.4
| | | Melatonin | 54 | Median=25.5 (IQR: 16–31) | | | | 7.3±8.1
| | | Control/Pl | 58 | Median=23 (IQR: 17–32) | | | | 9.2±9.9
Shorey R 1981 | HDL | | Soy protein | 13 | 52±14 | mg/dL | SD | ▵ | -8±6 | 0.001
| | | Control/Pl | 11 | 46±12 | | | | -4±8 | NS
| TC | | Soy protein | 13 | 241±38 | mg/dL | SD | ▵ | -16±22 | 0.027
| | | Control/Pl | 11 | 221±21 | | | | -22±18 | 0.002
| Tg | | Soy protein | 13 | 97±48 | mg/dL | SD | ▵ | +40±66 | 0.046
| | | Control/Pl | 11 | 130±56 | | | | +12±50 | ns
Simons L 2000 | BP | 1° | Soy | 20 | 135/82±4/2 | mm Hg | SE | f/up | 125/80±4/1 | | NS
| | | placebo | 20 | 135/82±4/2 | | | | 126/80±4/2
| HDL | 1° | Soy | 20 | 1.42±0.07 | mmol/L | SE | f/up | 1.33±0.06 | | NS
| | | placebo | 20 | 1.42±0.07 | | | | 1.34±0.06
| LDL | 1° | Soy | 20 | 3.94±0.26 | mmol/L | SE | f/up | 3.61±0.25 | | NS
| | | placebo | 20 | 3.94±0.26 | | | | 3.69±0.22
| Lp(a) | 1° | Soy | 20 | nd | mg/L | SE | f/up | 166 (IQR: 53–855) | | NS
| | | placebo | 20 | nd | | | | 179 (IQR: 43–720)
| TC | 1° | Soy | 20 | 5.86±0.29 | mmol/L | SE | f/up | 5.45±0.29 | | NS
| | | placebo | 20 | 5.86±0.29 | | | | 5.52±0.27
| Tg | 1° | Soy | 20 | 1.12±0.13 | mmol/L | SE | f/up | 1.12±0.15 | | NS
| | | placebo | 20 | 1.12±0.13 | | | | 1.07±0.09
| FMD (RH) | 1° | Soy | 20 | 2.1 | % | | f/up | +2 | NS | | NS
| | | placebo | 20 | | | | | +1.2 | NS
Sirtori 1999 | LDL | 1° | Soya | 21 | 6.39±0.95 | mmol/L | SD | ▵ | -7.8% | <0.05
| | | Control/Pl | 21 | 6.41 | | | | | NS
| TC | 1° | Soya | 21* | 8.74±0.74 | mmol/L | SD | ▵ | -6.2%
| | | Control/Pl | 21* | Same | | | | -3.9% | NS
Sirtori 2002 | LDL | 1° | Soya | 20 | 226 | mmol/L | | f/up | 233 | NS | | NS
| | | Control/Pl | 20 | 225 | | | | 235 | NS
| TC | 1° | Soya milk | 20 | 314 | mmol/L | SD | f/up | 308 | NS | | NS
| | | Control/Pl | 20 | 318 | | | | 321 | NS
Squadrito 2002 | DBP | 1° | genistein | 30 | 80±7 | mm Hg | SD | f/up | 79±12 | NS | | NS
| | | Control/Pl | 30 | 77±10 | | | | 78±7 | NS
| HDL | 1° | genistein | 30 | 1.2±0.5 | mmol/L | SD | f/up | 1.2±0.6 | NS | | NS
| | | Control/Pl | 30 | 1.2±0.3 | | | | 1.3±0.4 | NS
| LDL | 1° | genistein | 30 | 3.6±0.4 | mmol/L | SD | f/up | 3.6±0.4 | NS | | NS
| | | Control/Pl | 30 | 3.8±0.9 | | | | 3.7±0.2 | NS
| SBP | 1° | genistein | 30 | 113±11 | mm Hg | SD | f/up | 110±13 | NS | | NS
| | | Control/Pl | 30 | 112±13 | | | | 113±15 | NS
| TC | 1° | genistein | 30 | 5.3±1.1 | mmol/L | SD | f/up | 5.5±0.9 | NS | | NS
| | | Control/Pl | 30 | 5.4±0.8 | | | | 5.5±0.7 | NS
| Tg | 1° | genistein | 30 | 1.5±1.8 | mmol/L | SD | f/up | 1.8±1.5 | NS | | NS
| | | Control/Pl | 30 | 1.7±1.5 | | | | 1.6±1.2 | NS
Squadrito 2003 | DBA FMD (RH) | 1° | genistein | 27 | 24±4 | mL/dL/min | | f/up | 35±9 | | | <0.001
| | | Control/Pl | 26 | 24±6 | | | | 25±8
| DBA FMD (RH) (size) | 1° | genistein | 27 | 3.5±0.7 | Diam mm | | f/up | 4.0±0.5 | | | p=0.02
| | | Control/Pl | 26 | 3.5±0.9 | | | | 3.5±0.9
| E2 | 1° | genistein | 27 | 19.6 | pg/mL | | f/up | +0.6 | | | NS
| | | Control/Pl | 26 | 19.1 | | | | +0.2
Steinberg 2003 | Brachial Artery Reactivity | 1° | ISP w/Isof | 24 | | % | | f/up (graph) | +13 | 0.03 | NS
| | | ISP w/o is | 24 | | % | | | +15 | NS
| | | Control/Pl | 24 | | % | | | +20
| HDL | 1° | ISP w/Isof | 24 | 1.55±0.1 | mmol/L | SE | f/up | 1.49±0.1
| | | ISP w/o is | 24 | 1.55±0.1 | | | | 1.55±0.1
| | | Control/Pl | 24 | 1.55±0.1 | | | | 1.61±0.1
| LDL | 1° | ISP w/Isof | 24 | 2.89±0.1 | mmol/L | SE | f/up | 2.86±0.1
| | | ISP w/o is | 24 | 2.89±0.1 | | | | 2.87±0.1
| | | Control/Pl | 24 | 2.89±0.1 | | | | 2.94±0.1
| TC | 1° | ISP w/Isof | 24 | 4.91±0.1 | mmol/L | SE | f/up | 4.82±0.1
| | | ISP w/o is | 24 | 4.91±0.1 | | | | 4.92±0.2
| | | Control/Pl | 24 | 4.91±0.1 | | | | 5.00±0.1
| Tg | 1° | ISP w/Isof | 24 | 1.03±0.1 | mmol/L | SE | f/up | 1.04±0.1
| | | ISP w/o is | 24 | 1.03±0.1 | | | | 1.08±0.1
| | | Control/Pl | 24 | 1.03±0.1 | | | | 0.98±0.1
St Germain 2001 | Hot flash | 1° | ISP w/Isof | 24 | 36 | Weekly | | ▵ | -50% | | | NS
| | | ISP w/Isof | 24 | 36.5 | frequency | | | 0 | | | NS
| | | Wheat protein | 21 | 32 | | | | -47%
Stroescu 2001 | estradiol | 1° | ISP | 7 | nd | pg/mL | | f/up | -18.3 | <0.01 | | NS
| | | Control/Pl | 7 | nd | | | | -17.4 | <0.01
Swain 2002 | FSH | 1° | ISP w/Iso | 24 | Outcomes tabulated
| | | ISP w/o Iso | 24
| | | Control/Pl | 21
| estradiol | 1° | ISP w/Iso | 24 | Outcomes tabulated
| | | ISP w/o Iso | 24
| | | Control/Pl | 21
Takatsuka 2000 | HDL | 1° | Soy | 27 | 65.7±12,5 | mg/dL | SD | f/up | 63.4±10.2 | 0.276 | | 0.184
| | | Control/Pl | 25 | 63.3±8.9 | | | | 65.0±9.8 | 0.431
| LDL | 1° | Soy | 27 | 91.3±22.9 | mg/dL | SD | f/up | 86.0±32.0 | 0.109 | | 0.142
| | | Control/Pl | 25 | 94.2±20.2 | | | | 96.7±19.4 | 0.428
| TC | 1° | Soy | 27 | 176.6±24.2 | mg/dL | SD | ▵ | -10.9 | 0.004 | | 0.022
| | | Control/Pl | 25 | 176.7±23.8 | | | | | 0.931
| Tg | 1° | Soy | 27 | 98.2±51.4 | mg/dL | SD | f/up | 81.6±32.0 | 0.154 | | 0.962
| | | Control/Pl | 25 | 95.9±45.6 | | | | 80.0±29.6 | 0.152
Teede HJ 2001 | DBP | 1° | Soy | 105 | 76±1 | mm Hg | SE | ▵ | -4.3±0.8 | | | <0.05
| | | Control/Pl | 108 | 76±2 | | | | -1.9±0.7
| FSH: Men | 1° | Soy | 55 | 11.1±1.4 | mmol/L | SE | ▵ | 2.7±1.5
| | | Control/Pl | 53 | 9.2±0.8 | | | | 4.7±2.7
| FSH: women | 1° | Soy | 50 | 97.4±6 | mmol/L | SE | ▵ | 1.1±3.4
| | | Control/Pl | 55 | 112.7±6 | | | | -2.6±3.2
| HDL | 1° | Soy | 105 | 1.44±0.1 | mmol/L | SE | ▵ | -0.04±0.03
| | | Control/Pl | 108 | 1.51±0.1 | | | | -0.11±0.04
| LDL | 1° | Soy | 105 | 3.9±0.1 | mmol/L | SE | ▵ | -0.42±0.07
| | | Control/Pl | 108 | 3.8±0.1 | | | | -0.28±0.07
| Lp(a) | 1° | Soy | 105 | 286 (95% CI: 207–365) | mg/L | SE | ▵ | 42 (95% CI: 17–67) | | | <0.05
| | | Control/Pl | 108 | 341 (95% CI: 251–433) | | | | 4 (95% CI: -22 -30)
| SAC: combined | 1° | Soy | 105 | 0.53 (95% CI: 0.49–0.58) | | SE | ▵ | 0.04 (95% CI: -0.003–0.08)
| | | Control/Pl | 108 | 0.56 (95% CI: 0.49–0.63) | | | | 0.01 (95% CI: -0.06-0.08)
| SAC: men | 1° | Soy | 55 | 0.54 (95% CI: 0.47–0.61) | | SE | f/up | 0.60 (95% CI: 0.53–0.68)
| | | Control/Pl | 53 | 0.62 (95% CI: 0.51–0.73) | | | | 0.62 (95% CI: 0.55–0.68)
| SAC: women | 1° | Soy | 50 | 0.52 (95% CI: 0.46–0.58) | | SE | f/up | 0.54 (95% CI: 0.47–0.61)
| | | Control/Pl | 55 | 0.50 (95% CI: 0.43–0.56) | | | | 0.52 (95% CI: 0.49–0.63)
| SBP | 1° | Soy | 105 | 130±2 | mm Hg | SE | ▵ | -7.5±1.2 | | | <0.05
| | | Control/Pl | 108 | 128±2 | | | | -3.6±1.1
| TC | 1° | Soy | 105 | 5.9±0.1 | mmol/L | SE | ▵ | -0.55±0.09
| | | Control/Pl | 108 | 5.9±0.1 | | | | -0.4±0.09
| Testosterone | 1° | Soy | 55 | 16.8±0.9 | nmol/L | SE | ▵ | -1.5±0.9
| | | Control/Pl | 53 | 15.8±0.8 | | | | -1.0±0.6
| Tg | 1° | Soy | 105 | 1.2±0.1 | mmol/L | SE | ▵ | -0.19±0.05 | | | <0.05
| | | Control/Pl | 108 | 1.2±0.1 | | | | -0.01±0.05
| FMD (RH) in ♂ | 1° | Soy | 96 | | % | | ▵ | -3.5 | | | 0.02
| | | Control/Pl | | | | | | 0
| FMD (RH) in post ♀ | 1° | Soy | 83 | | % | | ▵ | +0.5 | | | NS
| | | Control/Pl | | | | | | -1.0
Teede HJ 2004 | CRP | 1° | Soy | 30 | 1.91±0.33 | | SE | ▵ | 0.42±0.2 | <0.05
| | | Control/Pl | 22 | 1.39±0.22 | | | | 0.48±0.2 | <0.05
Teixeira 2000 | HDL | 1° | 20 g ISP | 15 | 1.07±0.06 | mmol/L | SE | ▵ | -0.039 | NS
| | | 30 g ISP | 18 | 1.13±0.09 | | | | 0 | NS
| | | 40 g ISP | 17 | 1.11±0.08 | | | | 0 | NS
| | | 50 g ISP | 15 | 1.13±0.05 | | | | 0.039 | NS
| | | Control/Pl | 16 | 1.10±0.08 | | | | -0.026 | NS
| Lp(a) | 1° | 20 g ISP | 15 | 55.3 (95% CI: 7.6–266.4) | | SE | f/up | 52.3 (95% CI: 6.5–326.2)
| | | 30 g ISP | 18 | 64.2 (95% CI: 3.1–310.7) | | | | 75.7 (95% CI: 4.2–272.6)
| | | 40 g ISP | 17 | 61.3 (95% CI: 8.4–672.7) | | | | 59.0 (95% CI: 7.3–578.7)
| | | 50 g ISP | 15 | 74.1 (95% CI: 3.3–469.2) | | | | 68.0 (95% CI: 2.3–514.7)
| | | Control/Pl | 16 | 42.8 (95% CI: 1.0–340.4) | | | | 43.9 (95% CI: 0.0–410.1)
| TC | 1° | 20 g ISP | 15 | 5.98±0.22 | mmol/L | SE | ▵ | -0.126 | 0.04
| | | 30 g ISP | 18 | 6.01±0.18 | | | | -0.115 | 0.04
| | | 40 g ISP | 17 | 5.96±0.20 | | | | -0.053 | NS
| | | 50 g ISP | 15 | 6.28±0.18 | | | | -0.167 | 0.02
| | | Control/Pl | 16 | 6.08±0.22 | | | | 0.222 | NS
| Tg | 1° | 20 g ISP | 15 | 1.77±0.12 | mmol/L | SE | ▵ | 0.632 | NS
| | | 30 g ISP | 18 | 2.52±0.31 | | | | 0.782 | NS
| | | 40 g ISP | 17 | 2.05±0.22 | | | | 0.443 | NS
| | | 50 g ISP | 15 | 2.18±0.28 | | | | 0.872 | NS
| | | Control/Pl | 16 | 2.14±0.28 | | | | 0.664 | NS
Tonstad 2002 | HDL | | 30 g ISP | 34 | 1.48±0.42 | mmol/L | SD | ▵▵ | 0.04 (95% CI: -0.02, 0.10) | | | ns
| | | 50 g ISP | 31 | 1.35±0.33
| | | Control 30 g | 36 | 1.26±0.39
| | | Control/Pl | 29 | 1.33±0.37
| Homocysteine | | 30 g ISP | 34 | 10.0±2.2 | Other | SD | ▵▵ | -0.8 (95% CI: -1.4, -0.2) | | | 0.005
| | | 50 g ISP | 31 | 10.6±2.9
| | | Control 30 g | 36 | 10.1±2.2
| | | Control/Pl | 29 | 10.6±2.5
| LDL | | 30 g ISP | 34 | 4.81±0.54 | mmol/L | SD | ▵▵ | -0.26 (95% CI: -0.43, -0.09) | | | 0.01
| | | 50 g ISP | 31 | 4.58±0.50
| | | Control 30 g | 36 | 4.88±0.66
| | | Control/Pl | 29 | 4.96±0.50
| Lp(a) | | 30 g ISP | 34 | 437±410 | mg/L | SD | ▵▵ | 25 (95% CI: -4, 54) | | | ns
| | | 50 g ISP | 31 | 417±498
| | | Control 30 g | 36 | 405±314
| | | Control/Pl | 29 | 367±409
| TC | | 30 g ISP | 34 | 6.86±0.67 | mmol/L | SD | f/up | 6.00±0.55
| | | 50 g ISP | 31 | 6.52±0.63 | | | | 5.61±0.71
| | | Control 30 g | 36 | 6.84±0.72 | | | | 6.29±0.54
| | | Control/Pl | 29 | 6.90±0.54 | | | | 6.13±0.53
| Tg | | 30 g ISP | 34 | 1.28±0.38 | mmol/L | SD | ▵▵ | -0.04 (95% CI: -0.22, 0.14) | | | ns
| | | 50 g ISP | 31 | 1.33±0.70
| | | Control 30 g | 36 | 1.57±0.76
| | | Control/Pl | 29 | 1.46±0.67
Uesugi T 2002 | HDL | 1° | Isoflavone | 12 | 66.2±15.8 | | SE | f/up | 65.1±16.8 | | | NS
| | | Control/Pl | 11 | 64.9±15.2 | | | | 68.1±14.2
| LDL | 1° | Isoflavone | 12 | 148.1±34.7 | | SE | f/up | 138.4±36.1 | <0.05 | | NS
| | | Control/Pl | 11 | 162.3±24.5 | | | | 163.9±21.6 | NS
| Serum Osteocalcin | 1° | Isoflavone | 12 | 8.5±1.2 | | SE | f/up | 7.4±1.1 | NS
| | | Control/Pl | 11 | 7.2±0.7 | | | | 7.1±0.6 | NS
| TC | 1° | Isoflavone | 12 | 226.3±39.7 | | SE | f/up | 215.4±44.4 | <0.05 | | NS
| | | Control/Pl | 11 | 237.6±31.2 | | | | 240.9±25.4 | NS
| Tg | 1° | Isoflavone | 12 | 94.8±43.9 | | SE | f/up | 106.1±51.0 | NS | | NS
| | | Control/Pl | 11 | 105.2±40.0 | | | | 97.5±27.5 | NS
Uesugi T 2003 | FSH | 1° | Isoflavone | 11 | 56.5±13.2 | | SD | f/up | 55.8±10.8 | | | 0.89
| | | Control/Pl | 10 | 73.5±12.4 | | | | 60.9±13.3
| HDL | 1° | Isoflavone | 11 | 65.2±4.0 | mg/dL | SD | f/up | 64.0±4.1 | | | 0.28
| | | Control/Pl | 10 | 70.6±67.1 | | | | 67.1±5.5
| TC | 1° | Isoflavone | 11 | 223.7±14.7 | mg/dL | SD | f/up | 218.7±11.5 | | | 0.69
| | | Control/Pl | 10 | 221.1±6.3 | | | | 219.9±7.0
| Tg | 1° | Isoflavone | 11 | 126.5±17.4 | mg/dL | SD | f/up | 112.3±16.0 | | | 0.22
| | | Control/Pl | 10 | 117.7±15.4 | | | | 135.2±9.9
Upmalis 2000 | FSH | 2° | Soy Isofla | 59 | 76.2 | | | f/up | 85.3 | NS
| | | Control/Pl | 63 | 79.3 | | | | 86.3 | NS
| NTx | 2° | Soy Isofla | 59 | 52.6 | | | f/up | 53.3
| | | Control/Pl | 63 | 54.8 | | | | 53.4
| Serum Osteocalcin | 2° | Soy Isofla | 59 | 13.43 | | | f/up | 13.75
| | | Control/Pl | 63 | 13.75 | | | | 14.89
| Vasomotor: Night Sweats/day | 1° | Soy Isofla | 59 | 1.52 | | | ▵ | -62% | | | NS
| | | Control/Pl | 63 | 1.89 | | | | -34%
Van Horn 2001 | HDL | | Oats/Soy | 32* | 1.59 | mmol/L | | ▵ | -0.01 | NS
| | | Wheat/Soy | 31* | 1.66 | | | | -0.01 | NS
| | | Oats/Milk | 32* | 1.74 | | | | -0.03 | NS
| | | Control/Pl | 32* | 1.64 | | | | -0.02 | NS
| LDL | | Oats/Soy | 32* | 3.89 | mmol/L | | ▵ | -0.27 | <0.02
| | | Wheat/Soy | 31* | 3.80 | | | | 0.01 | NS
| | | Oats/milk | 32* | 4.01 | | | | -0.23 | <0.02
| | | Control/Pl | 32* | 3.91 | | | | -0.03 | NS
| TC | | Oats/Soy | 32* | 6.17 | mmol/L | | ▵ | -0.21 | <0.02
| | | Wheat/Soy | 31* | 6.06 | | | | 0.01 | NS
| | | Oats/milk | 32* | 6.33 | | | | -0.24 | <0.02
| | | Control/Pl | 32* | 6.21 | | | | 0.00 | NS
Van Patten 2002 | Hot flash | 1° | Soy beverage | 59 | 4.7 | Weekly | | ▵ | -26% | <0.05 | | NS
| | | Rice beverage | 64 | 5.2 | frequency | | | -35% | <0.05
Verrillo 1985 | HDL | 1° | Substitution | 19 | 1.3±0.1 | mmol/L | SD | ▵ | +7.7% | NS
| | | Addition | 38 | 1.4±0.1 | | | | -7.1% | NS
| | | Control/Pl | 0*
| LDL | 1° | Substitution | 19 | 6.7±0.5 | mmol/L | SD | ▵ | -38.8% | <0.01
| | | Addition | 38 | 6.3±0.2 | | | | -36.5% | <0.01
| | | Control/Pl | 0
| TC | 1° | Substitution | 19 | 8.8±0.4 | mmol/L | SD | ▵ | -29.5% | <0.01
| | | Addition | 38 | 8.7±0.2 | | | | -29.9% | <0.01
| | | Control/Pl | 0
| Tg | 1° | Substitution | 19 | 1.7±0.2 | mmol/L | SD | ▵ | -11.8%
| | | Addition | 38 | 2.2±0.6 | | | | -18.2%
| | | Control/Pl | 0
Vigna GB 2000 | DBP | 2° | ISP w/ Isofl. | 40 | 81.9±8.1 | | SD | ▵ | -0.1±10.2 | NS
| | | Control/Pl | 37 | 82.5±10.4 | | | | -3.1±13.1 | NS
| HDL | 2° | ISP w/ Isofl. | 40 | 1.57±0.36 | mmol/L | SD | f/up | 1.58±0.35 | NS
| | | Control/Pl | 37 | 1.61±0.38 | | | | 1.58±0.37 | NS
| LDL | 2° | ISP w/ Isofl. | 40 | 4.13±0.87 | mmol/L | SD | f/up | 3.78±0.77 | <0.01
| | | Control/Pl | 37 | 4.33±0.87 | | | | 4.01±0.73 | <0.01
| Lp(a) | 2° | ISP w/ Isofl. | 40 | 160 (Range: 30–1140) | mg/L | | f/up | 170 (Range: 20–1030) | NS
| | | Control/Pl | 37 | 170 (Range: 50–1010) | | | | 200 (Range: 40–1190) | NS
| SBP | 2° | ISP w/ Isofl. | 40 | 127.2±15.8 | mm Hg | SD | ▵ | -3.2±16.1 | NS
| | | Control/Pl | 37 | 129.9±15.1 | | | | -8.6±20.9 | NS
| TC | 2° | ISP w/ Isofl. | 40 | 6.37±1.01 | mmol/L | SD | f/up | 5.96±0.95 | <0.01
| | | Control/Pl | 37 | 6.55±0.93 | | | | 6.14±0.82 | <0.01
| Tg | 2° | ISP w/ Isofl. | 40 | 1.47±0.90 | mmol/L | SD | f/up | 1.31±0.60 | NS
| | | Control/Pl | 37 | 1.32±0.77 | | | | 1.19±0.57 | NS
Wangen 2000 (post-menopausal women only) | bAP | 1° | ISP w/ Isofl. | 17 | 20.9±0.7 | U/L | SE | f/up | 22.3±0.5 | <0.05 | NS
| | | ISP w/ Isofl. | | | | | | 22.3±0.6 | <0.05 | NS
| | | ISP w/o Isofl. | | | | | | 24.6±0.6 | <0.05 | <0.05
| OC | 1° | ISP w/ Isofl. | 17 | 2.5 | | | | +0.36 | NS | NS
| | | ISP w/ Isofl. | | | nmol/L | | ▵ | +0.6 | NS | NS
| | | ISP w/o Isofl. | | | | | | +0.6 | NS | NS
| D-pyr | 1° | ISP w/ Isofl. | 17 | 6.84 | nmol/mmol creatinine | | | -0.52 | NS | NS
| | | ISP w/ Isofl. | | | | | ▵ | -0.07 | NS | NS
| | | ISP w/o Isofl. | | | | | | -0.73 | NS | NS
Wangen K 2001 | HDL | 2° | Low Isofla | 17 | 52±17 SD | mg/dL | Unclear SD/SE | f/up | 53.3±0.9 SE | NS
| | | High Isofl | 18 | same | | | | 52.7±0.9 SE | NS
| | | No Isoflav | 18 | same | | | | 52.0±0.9 SE | NS
| | | Control/Pl | 0
| LDL | 2° | Low Isofla | 17 | 136±31 SD | mg/dL | Unclear SD/SE | ▵F | ND | 0.0006 | 0.07
| | | High Isofl | 18 | Same | | | | -6.5% | 0.0003 | 0.02
| | | No Isoflav | 18 | Same | | | | | 0.02
| | | Control/Pl | 0
| Lp(a) | 2° | Low Isofla | 17 | 25±1 SE | mg/dL | SE | f/up | 27.2±0.9 SE | NS
| | | High Isofl | 18 | Same | | | | 27.4±0.8 SE | NS
| | | No Isoflav | 18 | Same | | | | 26.8±0.8 SE | NS
| | | Control/Pl | 0
| TC | 2° | Low Isofla | 17 | 215±26 SD | mg/dL | Unclear SD/SE | f/up | 193±3 SE | 0.0004
| | | High Isofl | 18 | same | | | | 191±2 SE | 0.0004 | 0.17
| | | No Isoflav | 18 | same | | | | 197±2 SE | 0.0006
| | | Control/Pl | 0
| Tg | 2° | Low Isofla | 17 | 130±114 SD | mg/dL | Unclear SD/SE | f/up | 108±7 SE | NS
| | | High Isofl | 18 | Same | | | | 108±7 SE | NS
| | | No Isoflav | 18 | Same | | | | 103±7 SE | NS
| | | Control/Pl | 0
Washburn 1999 | DBP | 1° | Soy qD | 42 | 82.2±11.4 SD | | Unclear SD/SE | f/up | 76.3±1.4 SE | | NS
| | | Soy BID | 42 | Same | | | | 73.7±1.4 | | <0.01
| | | Control/Pl | 42 | Same | | | | 78.6±1.4
| Fasting Blood Glucose | 2° | Soy qD | 42 | 91.7±20.6 SD | mg/dL | Unclear SD/SE | f/up | 92.6±1.4 SE | | NS
| | | Soy BID | 42 | Same | | | | 92.3±1.5 | | NS
| | | Control/Pl | 42 | Same | | | | 91.8±1.4
| HDL | 1° | Soy qD | 42 | 54.9±15.6 SD | mg/dL | Unclear SD/SE | f/up | 52.2±0.9 SE | | NS
| | | Soy BID | 42 | Same | | | | 52.2±0.9 | | NS
| | | Control/Pl | 42 | Same | | | | 53.3±0.9
| LDL | 1° | Soy qD | 42 | 126.9±38.5 SD | mg/dL | Unclear SD/SE | ▵F | -7.5% | | <0.05
| | | Soy BID | 42 | Same | | | | -7.5% | | <0.01
| | | Control/Pl | 42 | Same
| SBP | 1° | Soy qD | 42 | 132.0±19.6 SD | | Unclear SD/SE | f/up | 124.2±1.6 SE | | NS
| | | Soy BID | 42 | Same | | | | 125.3±1.6 | | NS
| | | Control/Pl | 42 | Same | | | | 126.6±1.7
| TC | 1° | Soy qD | 42 | 208.0±40.5 SD | mg/dL | Unclear SD/SE | ▵F | -6% | | <0.01
| | | Soy BID | 42 | Same | | | | -6% | | <0.01
| | | Control/Pl | 42 | Same
| Tg | 1° | Soy qD | 42 | 131.1±67.1 SD | mg/dL | Unclear SD/SE | ▵F | -28 | | NS
| | | Soy BID | 42 | Same | | | | -15 | | NS
| | | Control/Pl | 42 | Same
| Vasomotor Symptoms: per wk | 1° | Soy qD | 42 | | | SE | f/up | 23.1±4.9 | | NS
| | | Soy BID | 42 | | | | | 22.3±2.7 | | NS
| | | Control/Pl | 42 | | | | | 21.3±3.0
Watatnabe 2000 | E2 | 1° | Soy | 19 | | pg/mL | | f/up | ~20 | NS
| | | Control/Pl | | | | | | ~25 | NS
Wong WW 1998 | HDL: Baseline < 50/40 mg/DL (m/w) | 1° | Soy Protein | 13 | 1.01±0.29 | mmol/L | SD | f/up | 0.96±0.26 | | | NS
| | | Control/Pl | 13 | 1.06±0.36 | | | | 0.93±0.29
| HDL: Baseline > 50/40 mg/DL (m/w) | 1° | Soy Protein | 13 | 1.06±0.26 | mmol/L | SD | f/up | 0.98±0.31 | | | NS
| | | Control/Pl | 13 | 1.06±0.31 | | | | 0.98±0.28
| LDL: Baseline < 130 mg/dL | 1° | Soy Protein | 13 | 2.87±0.49 | mmol/L | SD | f/up | 2.53±0.65 | | | 0.03
| | | Control/Pl | 13 | 2.82±0.62 | | | | 2.69±0.54
| LDL: Baseline > 130 mg/dL | 1° | Soy Protein | 13 | 4.68±0.65 | mmol/L | SD | f/up | 4.09±1.09 | | | 0.03
| | | Control/Pl | 13 | 4.71±0.67 | | | | 4.34±0.96
| TC: Baseline < 200 mg/dL | 1° | Soy Protein | 13 | 4.40±0.60 | mmol/L | SD | f/up | 4.01±0.96 | | | NS
| | | Control/Pl | 13 | 4.37±0.75 | | | | 4.14±0.72
| TC: Baseline > 200 mg/dL | 1° | Soy Protein | 13 | 6.78±0.70 | mmol/L | SD | f/up | 6.39±0.98 | | | NS
| | | Control/Pl | 13 | 6.85±0.72 | | | | 6.57±0.93
| Tg: LDL <130 mg/dL | 1° | Soy Protein | 13 | 1.01±0.36 | mmol/L | SD | f/up | 1.11±0.47 | | | NS
| | | Control/Pl | 13 | 1.04±0.55 | | | | 0.96±0.31
| Tg: LDL >130 mg/dL | 1° | Soy Protein | 13 | 2.37±1.34 | mmol/L | SD | f/up | 3.00±2.28 | | | NS
| | | Control/Pl | 13 | 2.94±2.64 | | | | 2.83±1.83
Wu 2000 | E2 | 1° | Soy diet | 20 | Outcomes tabulated
Xu X 2000 | Urinary 2OHE;Urinary 16aOHE | 1° | ISP+ | 18 | Outcomes tabulated
| | | Control/Pl
Yamaguchi 2001 | Serum Osteocalcin | 1° | nijiru | 12 | graphically represented | | SE | f/up | graphically represented | <0.01
| | | - | 6 m | | | | | | <0.01
| | | - | 6 w | | | | | | <0.01
Yamashita 1998 | Fasting Blood Glucose | 1° | Soy | 17 | 4.6±0.4 | mmol/L | SD | f/up | 4.7±0.4
| | | Control/Pl | 19 | 4.7±0.5 | | | | 4.8±0.3
Yamori 2002 | Urinary Pyr | 1° | Soybean and sesame | 20 | 3.04 | nmol/umol creatinine | | ▵ | -0.95 | <0.05 | | NS
| | | Sesame | 20 | 2.65 | | | | --0.48 | NS
| Urinary D-Pyr | 1° | Soybean and sesame | 20 | 7.6 | nmol/umol creatinine | | ▵ | -2.8 | NS | | <0.05
| | | Sesame | 20 | 5.2 | | | | +0.7 | NS
Yildirir 2001 | FMD (RH) | 1° | Soy Diet | 20 | 8.2±0.6 | % | SD | f/up | 12.6±0.6 | 0.002
| | | Control/Pl | 0*
| Lp(a) | 1° | Soy Diet | 20 | 23.4±28.6 | mg/dL | SD | f/up | 22.2±28.0 | 0.49
| | | Control/Pl | 0*