# Appendix A. Search Strategies

Ovid: Search Form EMBASE

<1980 to 2004 Week 12>

# | Search History | Results
1 | exp soybean protein/ | 1247
2 | exp soybean/ | 4388
3 | exp isoflavone/ | 815
4 | exp casein/ | 3830
5 | exp genistein/ | 4989
6 | soy$.mp. | 13750
7 | tofu.mp. | 133
8 | tempeh.mp. | 27
9 | casein$.mp. | 11015
10 | isoflavone$.mp. | 1962
11 | genistein$.mp. | 5759
12 | daidzein$.mp. or exp DAIDZEIN/ | 1272
13 | exp GLYCITEIN/ or glycitein$.mp. | 102
14 | aglycone$.mp. | 1811
15 | or/1–14 | 31218
16 | limit 15 to human | 10162
17 | limit 16 to english language | 9578
18 | limit 17 to (adult <18 to 64 years> or aged <65+ years>) | 1420
19 | 17 not 18 | 8158
20 | limit 19 to (infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to
| 17 years>) | 839
21 | 17 not 20 | 8739
22 | exp controlled study/ | 1724288
23 | exp clinical study/ | 2696150
24 | double blind procedure/ | 51005
25 | single blind procedure/ | 4636
26 | Crossover Procedure/ | 14692
27 | or/22–26 | 3787687
28 | 21 and 27 | 4532
29 | exp in vivo study/ | 3875902
30 | 28 not 29 | 2182
31 | exp in vitro study/ | 2038097
32 | 30 and 31 | 1893
33 | 28 not 32 | 2639

Ovid: Search Form Ovid MEDLINE(R)

<1966 to March Week 5 2004>

# | Search History | Results
1 | exp soybean proteins/ | 2636
2 | exp soybeans/ | 10386
3 | exp isoflavones/ | 6991
4 | exp caseins/ | 9648
5 | exp genistein/ | 3130
6 | soy.mp. | 5149
7 | soya.mp | 1635
8 | tofu.mp. | 152
9 | tempeh.mp. | 32
10 | casein$.tw. | 14637
11 | soybean$.mp. | 17685
12 | soyabean$.mp. | 313
13 | isoflavone$.mp. | 3814
14 | genistein$.mp. | 5387
15 | daidzein$.mp. | 918
16 | glycitein$.mp. | 70
17 | aglycone$.mp. | 1890
18 | or/1–17 | 48150
19 | limit 18 to human | 13705
20 | limit 19 to english language | 12541
21 | limit 20 to all adult <19 plus years> | 2516
22 | 20 not 21 | 10025
23 | limit 22 to all child <0 to 18 years> | 1262
24 | 20 not 23 | 11279
25 | limit 24 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index) | 400
26 | 24 not 25 | 10879
27 | follow-up studies/ | 280686
28 | (follow-up or followup).tw. | 297836
29 | exp Case-Control Studies/ | 250582
30 | (case adj20 control).tw. | 38163
31 | exp Longitudinal Studies/ | 456180
32 | longitudinal.tw. | 54945
33 | exp Cohort Studies/ | 487498
34 | cohort.tw. | 58541
35 | (random$ or rct).tw. | 280359
36 | exp Randomized Controlled Trials/ | 31513
37 | exp random allocation/ | 50295
38 | exp Double-Blind Method/ | 77373
39 | exp Single-Blind Method/ | 7937
40 | randomized controlled trial.pt. | 186803
41 | clinical trial.pt. | 378381
42 | (clin$ adj trial$).tw. | 76518
43 | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. | 74006
44 | exp PLACEBOS/ | 22848
45 | placebo$.tw. | 83019
46 | exp Research Design/ | 177697
47 | exp Evaluation Studies/ | 480708
48 | exp Prospective Studies/ | 170854
49 | exp Comparative Study/ | 1106306
50 | or/27–49 | 2492656
51 | 26 and 50 | 2650

Ovid: Search Form Ovid MEDLINE(R)

<1966 to March Week 5 2004>

# | Search History | Results
1 | exp soybean proteins/ | 2644
2 | exp soybeans/ | 10410
3 | exp isoflavones/ | 7023
4 | exp caseins/ | 9657
5 | exp genistein/ | 3139
6 | soy.mp. | 5166
7 | soya.mp | 1637
8 | tofu.mp. | 152
9 | tempeh.mp. | 32
10 | casein$.tw. | 14662
11 | soybean$.mp. | 17720
12 | soyabean$.mp. | 315
13 | isoflavone$.mp. | 3839
14 | genistein$.mp. | 5402
15 | daidzein$.mp. | 923
16 | glycitein$.mp. | 70
17 | aglycone$.mp. | 1896
18 | or/1–17 | 48260
19 | limit 18 to human | 13744
20 | limit 19 to english language | 12576
21 | limit 20 to all adult <19 plus years> | 2524
22 | 20 not 21 | 10052
23 | limit 22 to all child <0 to 18 years> | 1264
24 | 20 not 23 | 11312
25 | limit 24 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index) | 401
26 | 24 not 25 | 10911
27 | follow-up studies/ | 281231
28 | (follow-up or followup).tw. | 298732
29 | exp Case-Control Studies/ | 251543
30 | (case adj20 control).tw. | 38324
31 | exp Longitudinal Studies/ | 457323
32 | longitudinal.tw. | 55119
33 | exp Cohort Studies/ | 488857
34 | cohort.tw. | 58921
35 | (random$ or rct).tw. | 281428
36 | exp Randomized Controlled Trials/ | 31687
37 | exp random allocation/ | 50387
38 | exp Double-Blind Method/ | 77581
39 | exp Single-Blind Method/ | 7981
40 | randomized controlled trial.pt. | 187367
41 | clinical trial.pt. | 379438
42 | (clin$ adj trial$).tw. | 76848
43 | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. | 74193
44 | exp PLACEBOS/ | 22885
45 | placebo$.tw. | 83266
46 | exp Research Design/ | 178254
47 | exp Evaluation Studies/ | 482188
48 | exp Prospective Studies/ | 178254
49 | exp Comparative Study/ | 1109381
50 | or/27–49 | 2499998
51 | 26 and 50 | 2663
52 | miso.tw. | 417
53 | 53 not 18 | 354
54 | limit 53 to human | 97
55 | limit 54 to english language | 84
56 | limit 55 to (all adult <19 plus years> or adolescent <13 to 18 years>) | 35
57 | 55 not 56 | 49
58 | limit 57 to (all infant <birth to 23 months> or preschool child <2 to 5
| years> or child <6 to 12 years>) | 0
59 | limit 58 to (addresses or bibliography or biography or case reports or
| congresses or consensus development conference or consensus
| development conference, nih or dictionary or directory or editorial or
| festschrift or government publications or interview or lectures or legal
| cases or legislation or letter or news or newspaper article or patient
| education handout or periodical index) | 1
60 | 55 not 61 | 83
61 | 60 and 50 | 47
62 | misonidazole.tw | 1196
63 | 61 not 62 | 10