# Appendixes

Appendix A. Search Strategies

Appendix B. Data Abstraction Form

Appendix C. Evidence Tables

Appendix D. Peer Reviewers