# Flow Diagrams

- Flow Diagram 1. Analytic framework
- Flow Diagram 2. Study retrieval and selection

## Flow Diagram 1. Analytic framework

[image]

## Flow Diagram 2. Study retrieval and selection

[image]