# Acknowledgments

We are grateful to members of the technical expert panel for providing input on the direction of the review. The members of the panel include J. Todd Arnedt, Ph.D., Richard Bootzin, Ph.D., Irvin Mayers, M.D., Parameswaran Nair, M.D., Ph.D., Larry Pawluk, M.D., and Arthur Spielman, Ph.D.

We thank the NIH Office of Medical Applications of Research for their support of this work. We are grateful to the Agency for Healthcare Research and Quality for granting the contract for this work and the Task Order Officer, CAPT Tina Murray, for facilitating the process. We also thank Alan I. Leshner, Ph.D., for his input on the direction of the review and for chairing the pre-conference panel meeting for the State-of-the-Science Conference on the “Manifestations and Management of Chronic Insomnia in Adults.”