# Discussion

Our inclusion criteria for age allowed for the inclusion of studies in the review for which participants between the ages of 15 and 18 years were eligible. This decision was in agreement with our aim to conduct a comprehensive review of the literature, since we would have otherwise excluded predominantly adult studies based on the possibility that their populations included a sub-population of adolescents. Only 10 out of 79 studies relevant to the manifestations of chronic insomnia explicitly stated that individuals under the age of 18 years were eligible for the study, and only two out of 116 studies relevant to the management of chronic insomnia explicitly stated that individuals under the age of 18 years were eligible for the study. Given the low number of included studies for which adolescents were eligible for inclusion, it is reasonable to assume that the findings of the review apply to adults.

We reviewed only English-language reports. The inclusion of non-English language reports in systematic reviews has been shown to increase treatment estimates in reviews of complementary and alternative medicine (CAM). ^66^ This effect is thought to occur due to the presence of publication bias in CAM literature, such that studies with negative CAM findings are more likely to be published in English-language journals, and studies with positive CAM findings are more likely to be published in non-English language journals. ^66^ However, we found no evidence of publication bias by three out of four tests conducted for studies on melatonin. There were not enough studies on L-tryptophan and valerian to conduct meaningful tests of publication bias for these interventions. Only seven non-English language reports were identified that were potentially relevant to this category of intervention, and given that the inclusion rate for the question on management of chronic insomnia was approximately 15 percent, only one study would likely have been relevant to the review. Given the relatively small sample sizes of the studies identified for this category of intervention, it is unlikely that the addition of one study to this category would have considerably affected treatment estimates.

## Prevalence, Natural History, Incidence and Factors Associated with Chronic Insomnia

The range of prevalence of chronic insomnia in the three categories of populations analyzed was wide. This variability may be due to the cumulative effect of variation in a number of factors across studies such as the sampling frame and method of sampling, the response rate, whether the method of data collection was validated, the criteria for chronic insomnia, the age distribution of the population, and the presence of psychological or psychiatric problems in the population. Indeed, the criteria for the duration of insomnia varied across studies from one month to one year and the severity of chronic insomnia varied across these populations as well. The interquartile range of prevalence varied from 8.5–24.3 percent across high quality studies of general populations, to 19.8–53.7 percent across moderate quality studies of outpatient populations, to 27.8–43.0 percent across moderate quality studies of clinical populations. Therefore, the prevalence estimates for chronic insomnia in outpatient and clinical populations appear to be significantly higher than for the general population, a finding that is consistent with evidence of an association between chronic insomnia and medical conditions, poor general health and increased healthcare utilization. Although we identified a number of high quality studies examining a general population, we did not identify any high quality studies examining outpatients of general practice and only one examining clinical populations, suggesting that high quality studies investigating the prevalence of chronic insomnia in outpatients of general practice and clinical populations are needed.

Only one study provided data on the natural history of chronic insomnia; the remission rate was 13.1 percent after a four-month follow-up. More research is necessary to determine the course of chronic insomnia in various populations. We did not identify any studies that provided evidence regarding the incidence of chronic insomnia; more research is needed in this area as well.

The majority of studies identified did not have designs that would support the categorization of associated factors of chronic insomnia as risk factors or consequences of the disorder. That is, most identified studies had designs in which both chronic insomnia and a factor of interest were assessed in a population at the same point in time. It is necessary that longitudinal cohort studies be conducted to elucidate the relationship between chronic insomnia and its associated factors. We found evidence to suggest that chronic insomnia is associated with older age, female gender, present or past psychiatric illness and psychological problems, medical conditions and poor general health, increased healthcare utilization, lower quality of life and social relationships, socioeconomic status (marital separation, unemployment, poorer working conditions and lower social status), and decrements in memory, mood and cognitive function. Some of the factors that are thought to contribute to insomnia in the elderly include multiple medical problems, polypharmacy and environmental factors, such as absence of zeitgebers (time/schedule cues). ^50^ ; ^67^ Similarly, factors such as stress, pregnancy, menopause, medical conditions and complex home life may explain the higher prevalence of insomnia in females. ^68^ It is noteworthy that there were studies that did not find evidence of an association between these factors and chronic insomnia. One of the reasons for this finding may be the different methods of data analysis employed in these studies; some studies performed multivariate analyses, while others performed univariate analyses. Other factors that may explain this finding are the age and gender distribution of the population, the response rate, and the duration of insomnia. Similarly, studies showing a lack of association between variables may have been underpowered. The relationship between chronic insomnia and race/ethnicity, shift-work, and absenteeism and work performance is not clear; there were too few studies examining these relationships to arrive at any conclusions. We did not identify any studies that examined the relationship between chronic insomnia and accidents or falls in the elderly. There was also no evidence regarding the direct and indirect costs of the disorder. Research in these areas is required.

## Efficacy and Safety of Treatments for Chronic Insomnia

The interventions for chronic insomnia that were investigated in included studies may be categorized as either benzodiazepines, non-benzodiazepines, antidepressants, complementary and alternative care (L-tryptophan, melatonin and valerian), relaxation therapy, cognitive/behavioral therapy, barbiturates, hormone therapy, alcohol, low energy emission therapy and combination therapy. The majority of studies were classified under the first six categories of the preceding list. The discussion of results relevant to the management of chronic insomnia is focused on the results as they pertain to the primary and secondary outcomes of this review, sleep onset latency (SOL) and wakefulness after sleep onset (WASO); however, any major discrepancies between the estimates for these outcomes and other outcomes will be discussed.

The benzodiazepines, non-benzodiazepines, antidepressants and melatonin significantly decreased SOL. L-tryptophan, valerian, relaxation therapy and cognitive/behavioral therapy reduced SOL, but the results were not statistically significant. Although the overall SOL estimate for relaxation therapy was not significantly different from placebo, when only short-term studies were analyzed, the effect became statistically significant in favour of relaxation therapy. The benzodiazepines, non-benzodiazepines and antidepressants significantly reduced WASO. Melatonin decreased WASO, but the result was not statistically significant. Melatonin had a non-significant effect on sleep efficiency, total sleep time and sleep quality. The studies on L-tryptophan did not report on any other outcomes besides SOL, and only one study on valerian provided data on WASO; valerian significantly reduced WASO in this study. Valerian did not have a significant effect on sleep efficiency, total sleep time or sleep quality. Relaxation therapy reduced WASO, but the result was not significant; however, this intervention significantly increased total sleep time (no significant effect on sleep efficiency or sleep quality). Cognitive/behavioral therapy significantly reduced WASO, and significantly increased sleep efficiency and sleep quality (no significant effect on total sleep time). The review provides evidence that benzodiazepines and non-benzodiazepines are effective treatments for chronic insomnia. The review provides some evidence that antidepressants are effective treatments for chronic insomnia, although more research is required in this area. There is some evidence that melatonin is an effective treatment for subsets of the chronic insomnia population, although more research is required in this area as well. The review provides evidence that relaxation therapy and cognitive/behavioral therapy are effective treatments in subsets of the chronic insomnia population. There were too few studies of L-tryptophan and valerian to draw conclusions regarding the efficacy of these treatments in the management of chronic insomnia: additional large-scale, randomized trials are needed. Additional large-scale, randomized trials are also needed in the area of relaxation therapy and cognitive/behavioral therapy in the management of chronic insomnia, in order to determine the efficacy of these interventions across subsets of the chronic insomnia population. The reduction in sleep onset latency by benzodiazepines and non-benzodiazepines was significantly greater than for antidepressants and melatonin, based on indirect comparisons. However, it should be noted that there were significantly fewer studies of antidepressants and melatonin compared to benzodiazepines and non-benzodiazepines, and additional large-scale, randomized trials of the former interventions are needed before firm conclusions can be drawn regarding the relative efficacy of these interventions.

The benzodiazepines, non-benzodiazepines and antidepressants had a significantly greater risk of harm than placebo, while melatonin did not. There were too few studies of L-tryptophan to draw conclusions regarding the safety of this intervention. Although there was no evidence that valerian poses a risk of harm, this result was based on only three studies of relatively small sample size. Therefore, more studies are needed before firm conclusions can be drawn regarding the safety of valerian. The risk for benzodiazepines was significantly greater than for non-benzodiazepines, based on indirect comparisons. Indeed, benzodiazepine use has been shown to increase the risk of injury in the elderly, ^69^ and there is pharmacologic evidence that the non-benzodiazepines have a better side-effect profile than the benzodiazepines. ^70^ – ^71^ Studies of relaxation therapy and cognitive/behavioral therapy did not provide adverse event data.

We did not aim to conduct a head-to-head comparison between pharmacological and non-pharmacological treatments for chronic insomnia, in which case we would have required randomized, controlled trials, which directly compare these interventions, in order to control for systematic differences between control and experimental groups. An indirect comparison between these categories of interventions is not presented here for the following reasons: (1) although our inclusion criteria required blinding for drug and CAM treatments, this criteria was omitted for psychological treatments; (2) the placebo intervention was considered to have no effect for drug and CAM treatments, while it may have had minimal effect for psychological treatments; (3) the pool of participants for psychological interventions was much smaller than for either the benzodiazepines, non-benzodiazepines or antidepressants. Thus, only indirect comparisons between non-psychological intervention categories and between psychological interventions were made.

There was substantial heterogeneity in the pooled estimate for SOL for benzodiazepines, non-benzodiazepines, L-tryptophan, valerian and relaxation therapy. Similarly, there was substantial heterogeneity in the pooled estimate for WASO for benzodiazepines, non-benzodiazepines, melatonin and cognitive/behavioral therapy. The heterogeneity was often due to differences in the magnitude of the point estimate and confidence interval across studies, rather than differences in the directionality of the effect. The exceptions are for estimates of the efficacy of relaxation therapy with respect to SOL and the efficacy of melatonin with respect to WASO. The heterogeneity in the pooled estimates for SOL was explored in sensitivity and sub-group analyses. The results indicate that heterogeneity in the pooled estimate for SOL for relaxation therapy is at least partially due to type of relaxation therapy, length of treatment, age and gender distribution of the study population, and study quality.

There was strong evidence of publication bias in the pooled estimates for SOL for the benzodiazepine and non-benzodiazepine categories of intervention. This finding suggests that the true estimate of efficacy is lower than the estimate calculated in the current analysis.

The results of sub-group analyses of SOL were varied. The efficacy of non-benzodiazepines was greater in participants without a psychiatric illness relative to those with such a disorder. This finding may reflect the strong, poorly understood, complex relationship between psychological or psychiatric disorders and insomnia, ^4^ which necessitates individualized treatment of insomnia for people suffering from these psychological or psychiatric disorders. The efficacy of relaxation therapy was greater with short-term treatment compared to long-term treatment. There were no salient differences in the design, population, intervention or method of measurement of sleep outcomes between short- and long-term studies that could explain the differences in effect of relaxation therapy with length of treatment. The possibility exists that the subgroup for long-term treatment did not have sufficient power to detect a statistically significant difference between relaxation therapy and placebo. There were too few long-term studies of cognitive/behavioral therapy to arrive at a conclusion regarding the difference in efficacy of this intervention with short- and long-term treatment. There was no evidence to suggest that treatment efficacy is affected by age or gender distribution of the population. It is noteworthy that many of the sub-group analyses were conducted with very few studies in sub-groupings, and some analyses could not be performed at all due to lack of data. Thus, the results of these analyses should be interpreted with caution. It is important that future research examine the role of factors such as psychiatric illness, length of treatment, age and gender in treatment efficacy in chronic insomnia.

We made an a priori decision to combine summary estimates of outcomes even if they were measured by different methods i.e. (polysomnography, actigraphy and sleep diary). We assumed that any differences between methods would be cancelled out when absolute differences in the effect of treatment and placebo were obtained. This assumption is correct as long as the differences in measurement between methods were not correlated with the value of the measurement, which is a reasonable assumption in our view. The sub-group analyses based on method of measurement produced variable results. Of the six comparisons made between polysomnography and sleep diary data, the methods most commonly used in the studies included in this review, only two analyses revealed a significant difference between pooled estimates (benzodiazepines and valerian); in both cases sleep diary overestimated effects relative to polysomnography. However, while four comparisons showed sleep diary to overestimate effects relative to polysomnography (benzodiazepines, non-benzodiazepines, antidepressants, and valerian), two other comparisons showed polysomnography to overestimate effects relative to sleep diary (L-tryptophan and melatonin). These results appear to be inconsistent in terms of the direction of a potential bias and cause us to doubt whether any true relationship between measurement method and effect estimates exists. It is noteworthy that the direction and significance of the estimates were not different between overall and sub-group estimates for the benzodiazepine, non-benzodiazepine and antidepressant categories of interventions. Although some differences were observed in the directionality and significance of overall and sub-group estimates for L-tryptophan, melatonin and valerian, the results may simply reflect the lower power of these sub-group analyses: sub-groups contained only one to three studies of small sample size.

There was no evidence of an effect of barbiturates, hormone therapy, alcohol and low energy emission therapy on sleep onset latency of chronic insomniacs. The lack of evidence may reflect the low number of studies and/or participants encompassed by these categories. It would be worthwhile to explore these interventions in future research on chronic insomnia.

We identified a small sample of studies examining the efficacy of combination treatments in the management of chronic insomnia; some of these studies compared a combination of treatments with placebo, while others compared them with single treatment. Many comparisons did not have data for our primary outcome, sleep onset latency, and the majority of results were non-significant. The latter finding may reflect the low power of these analyses. None of the studies provided data on adverse events. We identified only one study that compared the efficacy of a combined pharmacological and psychological treatment with these treatments administered sequentially. The research agenda for the management of chronic insomnia should include an evaluation of the efficacy and safety of combination treatments and sequential treatments.

Our results regarding the efficacy of benzodiazepines and non-benzodiazepines in the management of chronic insomnia are consistent with those of other meta-analyses. ^72^ – ^74^ Our results regarding the efficacy of melatonin in subsets of the chronic insomnia population are similar to another review. ^75^ Our results regarding the efficacy of relaxation therapy and cognitive/behavioral therapy in subsets of the chronic insomnia population are similar to a recent meta-analysis reviewing the efficacy of cognitive/behavioral therapy in the management of sleep problems in older adults. ^76^ Similar to our meta-analysis, the authors restricted the review to randomized, controlled trials. Our results relating to relaxation therapy and cognitive/behavioral therapy are somewhat at odds with three meta-analyses reviewing the efficacy of psychological treatments in the management of chronic insomnia. ^74^ ; ^77^ – ^78^ The difference in the findings may relate to key differences in the conduct of the reviews. First, we restricted our meta-analysis to a review of placebo-controlled, randomized trials and accounted for placebo effects in our estimations of efficacy. Other meta-analyses have included non-controlled studies, and for these studies, have not accounted for placebo/control effects in their estimation of efficacy. Second, we used clearly defined criteria for chronic insomnia; however, for some studies the criteria for insomnia was not clear. Third, we separated predominantly cognitive/behavioral approaches from predominantly relaxation approaches in management of insomnia, resulting in distinct meta-analyses for each category of intervention. These interventions have been grouped under the broader heading of psychological/non-pharmacological treatments in other reviews.

## Limitations of the Review and Future Research

Additional high quality studies investigating the prevalence of chronic insomnia in outpatients of general practice and clinical populations are needed. Similarly, we found a paucity of data on the natural history and incidence of chronic insomnia, which necessitates further research in these areas. We did not identify any cohort studies that examined the causal relationship between various factors and chronic insomnia; future research should be directed at conducting such studies in order to determine the nature of the relationship between chronic insomnia and its associated factors. Additional studies are needed to examine the relationship between chronic insomnia and race/ethnicity, shift-work, and absenteeism and work performance, since few studies in this area exist. Future research should also examine the relationship between chronic insomnia and accidents and falls in the elderly, and the direct and indirect costs of this disorder, since we did not identify any studies that addressed these issues.

The pooled estimates of efficacy for antidepressants, CAM therapies, relaxation therapy and cognitive/behavioral therapy were based on a small sample size relative to benzodiazepines and non-benzodiazepines. It is necessary that additional large-scale, randomized trials be conducted before firm conclusions can be drawn regarding their efficacy and safety and how they compare to other treatments for chronic insomnia. We found a relatively small number of studies examining the long-term efficacy and safety of various interventions for chronic insomnia: more long-term studies are needed in order to differentiate the short and long-term efficacy and safety of these interventions. It is necessary that an agreed upon criteria be developed to determine what constitutes short- and long- term treatment of chronic insomnia. In addition, research should be conducted to establish a threshold for a clinically significant treatment effect in the management of chronic insomnia, such that statistically significant findings can be put into some clinical context. Future research should report on outcomes in addition to SOL, such as WASO, in order to determine the efficacy of treatments across subsets of the chronic insomnia population; our analysis revealed that studies tend to report SOL much more often than WASO. Quality of life outcomes should also be given more attention. It is necessary that future research be directed at establishing an agreed upon placebo treatment for psychological treatment that is standardized across studies, such that meaningful comparisons can be made across studies of this type. Finally, additional studies are necessary to determine the efficacy and safety of combined pharmacological and psychological treatments, as well as sequential treatments in the management of chronic insomnia.

Many of the sub-group analyses conducted in this review were based on a small number of studies within sub-groupings, and some analyses could not be conducted at all due to lack of data. The paucity of data may reflect a need for future research to determine the efficacy and safety of treatments for chronic insomnia within specific sub-populations stratified by age, gender, and presence or absence of psychiatric illness. There was no evidence of an effect of barbiturates, hormone therapy, alcohol and low energy emission therapy on sleep onset latency of chronic insomniacs, however, there was a small amount of data in these areas, which prevents one from drawing firm conclusions before additional research is conducted.

A number of the six major categories of interventions for chronic insomnia had substantial heterogeneity, suggesting that the studies within these categories were significantly different. In some cases, sub-categorization by type of intervention significantly reduced heterogeneity within some of these categories. The categorization of interventions into classes is reasonable when the goal is to determine the efficacy and safety of a given class of intervention; however, it should be noted that although the interventions of a given class may be similar in some respects, they are in fact unique. For many interventions within these categories, there were few studies that addressed their safety and efficacy, and additional research is required into the efficacy and safety of these various interventions of chronic insomnia.

There was strong evidence of publication bias for the benzodiazepine and non-benzodiazepine categories, which suggests that the pooled estimates of treatment efficacy may be overestimates.

It is noteworthy that research in the area of bright light therapy and physical exercise in the management of insomnia is ongoing; however, we did not identify any studies of these interventions that fulfilled our inclusion criteria.

We restricted our analysis of efficacy and safety to evidence derived from randomized-controlled trials in order to provide the least biased estimate of these parameters. However, it should be noted that the short follow-up period that generally characterizes these types of studies is a limitation when assessing the long-term safety of pharmacological treatments.

## Conclusions

- There is evidence that the prevalence of chronic insomnia in outpatient and clinical populations is larger than in the general population.
- There is evidence that chronic insomnia is associated with older age, female gender, present or past psychiatric illness and psychological problems, medical conditions and poor general health, increased healthcare utilization, lower quality of life and social relationships, socioeconomic status (marital separation, unemployment, poorer working conditions and lower social status), and decrements in memory, mood and cognitive function.
- Additional studies are needed to determine the incidence and natural history of chronic insomnia in adults. Similarly, additional studies are needed to explore the relationship between chronic insomnia and race/ethnicity, shift-work, absenteeism and work performance, accidents, falls in the elderly, and the direct and indirect costs of the disorder. It is necessary that longitudinal studies be undertaken to explore the risk factors and consequences of chronic insomnia.
- There is evidence that benzodiazepines and non-benzodiazepines are effective in the management of chronic insomnia. There is some evidence that antidepressants are effective in the management of chronic insomnia: more research is required in this area. There is evidence that benzodiazepines, non-benzodiazepines and antidepressants pose a risk of harm.
- There is some evidence that melatonin is effective in the management of chronic insomnia in subsets of the chronic insomnia population, and there is no evidence that melatonin poses a risk of harm. However, more research is required in this area, given that the results are based on a small number of studies. Similarly, additional large-scale, randomized trials are needed to determine the efficacy of melatonin across subsets of the chronic insomnia population. There is insufficient evidence to conclude on the efficacy and safety of L-tryptophan and valerian in the management of chronic insomnia. Additional large-scale, randomized trials are needed in these areas.
- There is evidence that relaxation therapy and cognitive/behavioral therapy are effective in the management of chronic insomnia in subsets of the chronic insomnia population. Additional large-scale, randomized trials are needed in order to determine their efficacy across subsets of the chronic insomnia population.
- There is evidence that benzodiazepines have a greater risk of harm than non-benzodiazepines.
- There is insufficient evidence to conclude if there are differences between the short-term and long-term efficacy and safety of the various categories of interventions in the management of chronic insomnia; additional long-term studies are needed.
- There is insufficient evidence regarding the efficacy and safety of combined treatments of pharmacological and psychological interventions, and sequential treatments, in the management of chronic insomnia; additional studies are needed in these areas.