# Introduction

## Prevalence of Insomnia

Insomnia, or inability to sleep, is the most commonly reported sleep problem in the industrialized world. ^1^ Estimates suggest that between 40–70 million Americans are affected by either intermittent or chronic sleep problems, representing approximately 20 percent of the population. ^2^ The Sleep in America Poll, conducted by the National Sleep Foundation, revealed that almost 50 percent of people surveyed had complaints of frequent insomnia, but only 6 percent were formally diagnosed. ^3^ Moreover, approximately, 30–35 percent of respondents complained of nightly insomnia. ^3^ The most prevalent symptoms of insomnia, experienced at least a few nights a week by people with insomnia, include waking up feeling un-refreshed (34 percent) and being awake often during the night (32 percent). ^3^ The symptoms of difficulty falling asleep and waking up too early are less common, but still experienced at least a few nights a week by about one-fourth of adults with insomnia (23–24 percent). ^3^ The reported prevalence rates of insomnia vary in epidemiological studies based on the definitions and methods used to define insomnia. Earlier studies report prevalences of 5–35 percent. ^1^ The prevalence rate decreases to 10–15 percent for severe insomnia, when more stringent criteria are used. ^1^ The duration of insomnia is often classified as being transient, short-term or chronic. Chronic insomnia implies that insomnia is either persistent or recurrent. Definitions of chronic insomnia vary, ranging from greater than one month to greater than 6 months. Unfortunately, there is no standard definition of chronic insomnia used in studies.

There is emerging evidence that short-term sleep deprivation, under strict experimental conditions, is associated with a variety of adverse physiological and cognitive effects. Decrements in memory, concentration and executive function have been reported. There is also an increased risk of injury and accidents. Physiological effects resulting from sleep deprivation include hypertension, activation of the sympathetic nervous system, altered glucose metabolism and increased inflammatory markers. Sleep deprivation is associated with excessive sleepiness. Acute insomnia, however, may not equate to sleep deprivation. There is no evidence to suggest that patients with insomnia experience similar changes. Furthermore, it is not yet clear from the evidence what the physiological consequences of chronic insomnia are or if there is a process of adaptation that occurs in individuals with chronic insomnia. Thus, further research is needed in the area of chronic insomnia to determine what impact chronic insomnia has on health.

## Risk Factors for Insomnia

Although some risk factors and etiologies of insomnia have been identified, the nature of the relationships has not been fully elucidated. Some risk factors for insomnia that have emerged from data related to insomnia include female gender ^3^ and old age. ^4^ Additional risks factors include less education, unemployment, separation or divorce and medical illness. ^1^ Insomnia may be primary or secondary to other sleep problems, and may be associated with a number of co-morbidities. An association has been found between insomnia and psychiatric (depression and anxiety) and psychological disorders. ^4^ There is increasing evidence that chronic insomnia may predispose individuals to the development of psychiatric disorders. ^5^ – ^6^ Persistent insomnia increases the risk of depression, substance abuse and anxiety disorders. Environmental factors such as irregular sleep schedules, use of caffeine or other stimulants, co-morbid medical conditions and/or shift-work may also predispose vulnerable individuals to insomnia. We speculate that genetic predisposition to insomnia and environmental factors are likely involved in the development and maintenance of insomnia, and differences in the relative exposure to these influences may explain differences in the manifestation of this disorder among affected individuals.

## Consequences of Insomnia

Insomnia has significant direct and indirect effects on the health and wellness of affected individuals. Insomnia has been correlated with frequent use of medical services, ^7^ – ^8^ chronic health problems, ^9^ – ^10^ increased drug use, ^7^ – ^8^ perceived poor health, ^11^ and associated with medical problems including heart disease, ^12^ hypertension ^13^ and musculoskeletal problems. ^12^ One study reported associations between insomnia and medical problems, and found that individuals with insomnia were more likely to have hypertension (59 percent), night time heartburn (62 percent) and depression (74 percent). ^3^ The daytime consequences of chronic insomnia often include increased healthcare utilization, increased risk of depression, ^14^ poor memory, reduced concentration, poor work performance and perceived or real risk of failure at work. ^15^ The economic implications of insomnia and associated morbidity have been described. ^3^ ; ^7^ The direct costs of insomnia (insomnia treatments, healthcare services, hospital and nursing home care) are estimated to be nearly $14 billion. ^16^ – ^17^ The indirect costs of insomnia, such as time lost from work and loss of productivity, are estimated to be nearly $28 billion. A National Sleep Foundation survey found that lost productivity from insomnia, alone, was over $18 billion. Another estimate of total costs of insomnia has reported amounts totaling almost $100 billion. ^18^ This estimate is based on a high prevalence of insomnia, in the range of 33 percent, and the costs are related to sleepiness rather than insomnia. The data related to costs of chronic insomnia cannot be fully understood because of the impact insomnia has on many aspects of life. Nevertheless, insomnia, in its various forms, does result in substantial burden for affected individuals.

## Management of Insomnia

Management of acute insomnia has traditionally involved pharmacotherapy. The use of such agents is common practice for both acute and chronic insomnia, despite the fact that the Food and Drug Administration (FDA) has approved none of them for chronic insomnia. Another medication, eszopiclone (Lunesta), was recently approved by the FDA for treatment of insomnia, but the duration of use is not explicitly stated. An estimated 0.5 percent of the population takes sedative medications for insomnia for more than one year. ^3^ More than one in ten people (11 percent) report using prescription (6 percent) and/or over-the-counter (OTC) medications (6 percent), at least a few nights a month, to help them sleep, according to a Sleep in America Poll. ^3^ Individuals reporting symptoms of medical conditions are more likely to take sleep aids, both prescription and OTC medications. For example, 14 percent of people with symptoms of depression report using prescription medication, and 12 percent of people with symptoms of depression report using OTC sleep aids. ^3^ Medications commonly used to treat insomnia include sedating antidepressants, ^19^ antihistamines, anticholinergics, benzodiazepines and non-benzodiazepine hypnotics. A side effect of all hypnotics is to reduce slow wave sleep. Other side effects of concern are possible daytime residual effects related to sedation, rebound insomnia and tolerance, along with minor side effects specific to each drug class. Many questions and challenges related to pharmacological therapy for chronic insomnia remains, such as the appropriate treatment for different types of primary and secondary insomnia, and the long-term side effects and daytime consequences of pharmacotherapy. The evidence for management of chronic insomnia with pharmacotherapy has not been systematically evaluated.

Cognitive/behavioral therapy has been recognised as a valid and successful treatment approach for insomnia. Cognitive/behavioral therapy can include any combination of sleep restriction, sleep hygiene, stimulus control, paradoxical intention and cognitive restructuring. Brief descriptions of these techniques are provided here.

Sleep restriction therapy involves limiting the amount of time in bed. The affected individual spends only the amount of time in bed that he/she sleeps, thus sleep may be restricted to 6 hours for an insomniac that spends 8 hours in bed. The purpose of the exercise is to improve the sleep efficiency progressively until the desired sleep duration is achieved, without prolonged sleep latency or maintenance insomnia.

Sleep hygiene instructions or education involves addressing environmental factors and health practices that may be counterproductive to sleep. It involves education about sleep patterns and the impact of health habits related to sleep. For example, alcohol consumed in the evening may help sleep onset, but promotes sleep maintenance insomnia during the night as the alcohol level declines.

Stimulus control therapy involves instructions aimed at curtailing sleep maladaptive behaviors and altering sleep-wake schedules. The instructions include: 1) going to bed when sleepy; 2) no other activities, besides sleep and sex, should be undertaken in the bed and bedroom; 3) get out of bed when unable to sleep for 15–20 minutes and return only if sleepy; 4) the daily wake-up time should be the same irrespective of how much sleep was obtained the previous night; 5) no naps allowed during the day.

Paradoxical intention is a technique that involves having the patient with insomnia stay awake, which is the most feared activity. The premise is that performance anxiety related to sleep would be alleviated if the patient stops trying to sleep and instead genuinely attempts to stay awake.

Cognitive restructuring can involve cognitive behavioral therapy targeted at an individual's unique perpetuating factors for insomnia.

Sleep non-suppression involves allowing oneself to think about whatever comes to mind, without any restrictions, as one gets to bed. The mind is allowed to go free, without the individual attempting to control his/her thoughts. This approach is thought to counteract the negative effects of thought suppression that often accompanies insomnia.

Relaxation therapy may or may not be a part of cognitive behavioral therapy. Different forms of relaxation therapy are designed to reduce somatic tension or cognitive arousals. Relaxation therapy may focus on somatic tension such as autogenic training, progressive muscle relaxation, or biofeedback, or may focus on the cognitive component such as intrusive thoughts that prevent sleep.

Many of these commonly used clinical tools have not undergone rigorous testing to determine their efficacy and long-term safety. The efficacy of these treatments has been evaluated in some studies, ^4^ ; ^20^ but differences in the definition of insomnia and outcome measures make it difficult to compare study results.

In summary, insomnia is a common complaint with significant consequences. Significant advancements have been made in sleep research over the past three decades, yet many questions related to the treatment of chronic insomnia remain. Our goal was to review the evidence and state of research in the area of chronic insomnia.

## Objectives

To conduct a systematic review of (1) the prevalence, natural history, incidence, risk factors and consequences of chronic insomnia in adults and (2) the efficacy and safety of treatments used in the management of chronic insomnia in adults. A population was considered to suffer from chronic insomnia if the sleep disturbance persisted for at least 4 weeks, regardless of severity of symptoms.

## Analytic Approach

The analytic framework outlining the approach to the review is depicted in Flow Diagram 1. The specific questions addressed in the review appear below.

### Etiology and Population at Risk

The following questions pertain to the clinical definition and etiology of chronic insomnia in adults, as well as the population at risk of the disorder.

1. How is chronic insomnia defined, diagnosed and classified, and what is known about its etiology?
2. What are the prevalence, natural history, incidence, and risk factors for chronic insomnia? Specific risk factors of interest include:
  - Age
  - Gender
  - Race/ethnicity
  - Psychiatric illness and psychological problems
  - Medical disease
  - Socioeconomic status
  - Shift-work

### Consequences, Morbidities, Co-morbidities, and Public Health Burden

The following question pertains to the clinical, social and economic consequences of chronic insomnia in adults.

1. What are the consequences, morbidities, co-morbidities, and public health burden associated with chronic insomnia? Specific outcomes of interest include:
  - Healthcare utilization
  - Risk of developing psychiatric disease
  - Absenteeism, work performance
  - Accidents
  - Falls in the elderly
  - Quality of life, social relationships
  - Memory, cognitive function, mood
  - Direct and indirect costs

### Treatment

The following question pertains to the benefits and harms of treatments used in the management of chronic insomnia in adults.

1. What treatments are used in the management of chronic insomnia and what is the evidence regarding their safety, efficacy, and effectiveness? Specific treatments of interest include:
  - Prescription medication
  - Over the counter medication
  - Alcohol
  - Behavioral therapy
  - Combination of therapies
  - Complementary and alternative care

### Future Direction

The answer to the following question is based on the evidence for the preceding questions.

1. What are important future directions for insomnia-related research?