# Appendix E: Excluded Studies

Four hundred and forty-nine studies were excluded for the questions on manifestations of chronic insomnia. The reasons for exclusion of studies potentially relevant to these questions are as follows: (1) the study was reported in a language other than English (n=9), (2) the report was a review (n=38), (3) the study was not relevant to the review topic (n=71), (4) the study was a case report (n=9), (5) the study did not have a control group (n=47), (6) the study did not examine an adult population (n=8), (7) the study population did not have chronic insomnia as defined in this report (208), (8) the study did not report on any of the outcomes of this review (n=58) and (9) data relevant to the study outcomes were not adequately reported (n=1).

### Excluded - Non-English

The following studies were excluded because they were reported in a language other than English.

1 Blais FC, Morin CM, Boisclair A, et al. Insomnia - Prevalence and Treatment in the General Practice. Can Fam Phys. 2001;47:759-67.
2 De Almeida CAV, Lins OG, Lins SG, et al. Sleep Disorders in Temporal Lobe Epilepsy. Arq NeuroPsiquiatr. 2003;61(4):979-87. [pmid: 14762602].
3 Horiguchi J, Inami Y, Nishimatsu O, et al. Sleep-wake complaints in Parkinson's disease. Clin Neurol. 1990;30(2):214-6.
4 Jakoubkova M, Sonka K, Roth J, et al. Sleep in Parkinson's Disease - a Questionnaire Study. Cesk Neurol Neurochir. 2001;64(5):268-72.
5 Kamenski G, Pichler I, Zohrer B, et al. Insomnia and sleeping disorders in the elderly in general practice (Germ). Wien Med Wochenschr. 2004;154(12):27-31. [pmid: 15002687].
6 Leger D, Stal V, Guilleminault C, et al. Daily Consequences of Insomnia: Impact on Quality of Life. Rev Neurol. 2001;157(10):1270-8. [pmid: 11885520].
7 Ohayon MM, Lemoine P. [Daytime consequences of insomnia complaints in the French general population]. Encephale. 2004;30(3):222-7. [pmid: 15235519].
8 Ohayon MM, Lemoine P. [Sleep and insomnia markers in the general population]. Encephale. 2004;30(2):135-40. [pmid: 15107715].
9 Wittchen HU, Krause P, Hofler M, et al. The Nationwide Insomnia Screening and Awareness Study (Nisas) 2000. Nervenheilkunde. 2001;20(1):4-16.

### Excluded - Review

The following studies were excluded because they were reviews.

1 Nighttime pain: a major problem for one out of three adults J Pract Nurs 1996; 46(2):27–9.
2 Aguzzi A, Weissmann C, Tateishi J. Sleepless in Bologna: Transmission of fatal familial insomnia. Trends Microbiol. 1996;4(4):129-32. [pmid: 8728604].
3 Akerstedt T. Sleepiness as a consequence of shift work. Sleep. 1988;11(1):17-34. [pmid: 3283910].
4 Alley PM. Helping individuals with sleep disturbances: Some behavior therapy techniques. Pers Guid J. 1983;61(10):606-8.
5 Ancoli-Israel S. Epidemiology of sleep disorders. Clin Geriatr Med. 1989;5(2):347-62. [pmid: 2665916].
6 Anonymous. Insomnia may lead to depression later in life . J Psychosoc Nurs Ment Health Serv 1998; 36(2):13.
7 Anonymous. Management of anxiety and insomnia. Int Pharm J 1996; 10(2):58–60.
8 Asplund R. Sleep disorders in the elderly. Drugs Aging. 1999;14(2):91-103. [pmid: 10084363].
9 Avidan AY. Insomnia in the geriatric patient. Clin Cornerstone. 2003;5(3):51-8. [pmid: 14626541].
10 Ball J, Koloian B. Sleep patterns among ADHD children. Clin Psychol Rev. 1995;15(7):681-91.
11 Bannerman C. Sleep disorders in the later years. Postgrad Med 1988; 84(1):265–6, 271–2, 274.
12 Baratte-Beebe KR, Lee K. Sources of midsleep awakenings in childbearing women. Clin Nurs Res. 1999;8(4):386-97. [pmid: 10855105].
13 Barthlen GM, Stacy C. Dyssomnias, parasomnias, and sleep disorders associated with medical and psychiatric diseases. Mt Sinai J Med. 1994;61(2):139-59. [pmid: 8022426].
14 Chilcott LA, Shapiro CM. The socioeconomic impact of insomnia: An overview. Pharmacoeconomics. 1996;10(Suppl 1):1-14. [pmid: 10163422].
15 Chung KF. Relationships between insomnia and sleep-disordered breathing. Chest. 2003;123(1):310-3. [pmid: 12527644].
16 Crowe C. Evaluation of severe insomnia in the general population--implications for the management of insomnia: focus on results from Ireland. J Psychopharmacol. 1999;13(4 Suppl 1):S29. [pmid: 10667454].
17 Culebras A, Magana R. Neurologic disorders and sleep disturbances. Seminars Neurol. 1987;7(3):277-85.
18 Daly MP. Insomnia in the elderly. Am Fam Phys. 1992;45(2):445-6.
19 Finucane TE. Insomnia and cognitive decline. J Am Geriatr Soc. 2002;50(9):1604-5. [pmid: 12383169].
20 Ford DE, Cooper-Patrick L. Sleep disturbances and mood disorders: An epidemiologic perspective. Depress Anxiety. 2001;14(1):3-6. [pmid: 11568977].
21 Gaillard J-M, Merica H, Blois R. Clinical presentation and psychopathology in chronic insomnia. I. Int J Short-Term Psychother. 1996;11(1):41-54.
22 Gambetti P, Parchi P. Insomnia in prion diseases: sporadic and familial. N Engl J Med. 1999;340(21):1675-7. [pmid: 10341282].
23 Giesecke ME. The symptom of insomnia in university students. J Am Coll Health. 1987;35(5):215-21. [pmid: 3584702].
24 Gillin JC, Spinweber CL, Johnson LC. Rebound insomnia: A critical review. J Clin Psychopharmacol. 1989;9(3):161-72. [pmid: 2567741].
25 Holm KJ, Goa KL. Zolpidem: an update of its pharmacology, therapeutic efficacy and tolerability in the treatment of insomnia. Drugs. 2000;59(4):865-89. [pmid: 10804040].
26 Howard GF. Evaluation of insomnia. Hosp Pract (Office Ed) 1986; 21(1A):16, 21–2, 24.
27 Hudson JI, Pope HG, Sullivan LE, et al. Good sleep, bad sleep: a meta-analysis of polysomnographic measures in insomnia, depression, and narcolepsy. Biol Psychiatry. 1992;32(11):958-75. [pmid: 1467388].
28 Idzikowski C. Impact of insomnia on health-related quality of life. Pharmacoecon. 1996;10(Suppl 1):15-24.
29 Kales A, Soldatos CR, Bixler EO, et al. Rebound insomnia and rebound anxiety: a review. Pharmacol. 1983;26(3):121-37.
30 Kales A, Vgontzas AN. Predisposition to and development and persistence of chronic insomnia: importance of psychobehavioral factors. Arch Int Med. 1992;152(8):1570-2. [pmid: 1497389].
31 Kales JD, Kales A. Nocturnal psychophysiological correlates of somatic conditions and sleep disorders. Int J Psychiatry Med. 1975;6(12):43-62. [pmid: 773862].
32 Locsin RC. Sleeplessness among the elderly. Rehab Nurs. 1988;13(6):340-1.
33 McDowell Anderson W, Falestiny M. Women and sleep. Prim Care Update Obstet Gynecol. 2000;7(4):131-7.
34 Roth T. Social and economic consequences of sleep disorders. Sleep. 1996;19(8 Suppl):S46-7.
35 Stoller MK. Economic effects of insomnia. Clin Ther 1994; 16(5):873–97; 854.
36 Verster JC, Veldhuijzen DS, Volkerts ER. Residual effects of sleep medication on driving ability. Sleep Med Rev. 2004;8(4):309-25. [pmid: 15233958].
37 Walsh J, Ustun TB. Prevalence and health consequences of insomnia. Sleep. 1999;22(Suppl 3):S427-36.
38 Walsh JK. Clinical and socioeconomic correlates of insomnia. J Clin Psychiatry. 2004;65 Suppl 8:13-9. [pmid: 15153063].

### Excluded - Topic

The following studies were excluded because they were not relevant to the review topic.

1 Adam K, Oswald I. Can a rapidly-eliminated hypnotic cause daytime anxiety?. Pharmacopsychiatry. 1989;22(3):115-9. [pmid: 2748714].
2 Ancolio C, Tardieu S, Soubrouillard C, et al. A Randomized Clinical Trial Comparing Doses and Efficacy of Lormetazepam Tablets or Oral Solution for Insomnia in a General Practice Setting. Hum Psychopharmacol Clin Exper. 2004;19(2):129-34.
3 Arnulf I, Konofal E, Gauthier C, et al. Severe restless legs syndrome presenting as intractable insomnia. Neurol. 2004;62(8):E19.
4 Backhaus J, Hohagen F, Voderholzer U, et al. Long-term effectiveness of a short-term cognitive-behavioral group treatment for primary insomnia. Eur Arch Psychiatry Clin Neurosci. 2001;251(1):35-41. [pmid: 11315517].
5 Baskett JJ, Broad JB, Wood PC, et al. Does melatonin improve sleep in older people? A randomised crossover trial. Age Ageing. 2003;32(2):164-70. [pmid: 12615559].
6 Bastien CH, Vallieres A, Morin CM. Validation of the insomnia severity index as an outcome measure for insomnia research. Sleep Med. 2001;2(4):297-307. [pmid: 11438246].
7 Belcher TL. Environmental changes affect sleep patterns: a case study. Percept Mot Skills. 1995;80(3 Pt 2):1089-90. [pmid: 7478862].
8 Bonnet MH, Arand DL. Situational insomnia: Consistency, predictors, and outcomes. Sleep. 2003;26(8):1029-36. [pmid: 14746386].
9 Braun WA. High blood pressure and insomnia: not a good combination. Med Update. 1999;23(1):2.
10 Broman JE, Hetta J. Electrodermal activity in patients with persistent insomnia. J Sleep Res. 1994;3(3):165-70. [pmid: 10607122].
11 Bucci L. Migraine, insomnia, reactive depression due to brain serotonin deficiency. Br J Psychiatry. 1988;152:867-8. [pmid: 3167494].
12 Buysse DJ, Reynolds CF III, Kupfer DJ, et al. Clinical diagnoses in 216 insomnia patients using the International Classification of Sleep Disorders (ICSD), DSM-IV and ICD-10 categories: A report from the APA/NIMH DSM-IV field trial. Sleep. 1994;17(7):630-7. [pmid: 7846462].
13 Carr-Kaffashan L, Woolfolk RL. Active and placebo effects in treatment of moderate and severe insomnia. J Consult Clin Psychol. 1979;47(6):1072-80. [pmid: 41856].
14 Chung KF, Lee CK. Over-the-counter sleeping pills: a survey of use in Hong Kong and a review of their constituents. Gen Hosp Psychiatry. 2002;24(6):430-5. [pmid: 12490346].
15 Clapin-French E. Sleep patterns of aged persons in long-term care facilities. J Adv Nurs. 1986;11(1):57-66. [pmid: 3632986].
16 Cluydts R, Heyde K, De Volder I. Polysomnographic findings during non-continuous administration of zolpidem. Sleep Med Rev. 2002;6(Suppl 1):S13-9. [pmid: 12607572].
17 Coates TJ, Thoresen CE. Assessing daytime thoughts and behavior associated with good and poor sleep: Two exploratory case studies. Behav Assess. 1984;6(2):153-67.
18 Cohen M, Oksenberg A, Snir D, et al. Temporally related changes of sleep complaints in traumatic brain injured patients. J Neurol Neurosurg Psychiatry. 1992;55(4):313-5. [pmid: 1583518]. [pmcid: 489047].
19 Coren S, Searleman A. Left sidedness and sleep difficulty: the alinormal syndrome. Brain Cogn. 1987;6(2):184-92. [pmid: 3593558].
20 Davies R, Lacks P, Storandt M, et al. Countercontrol treatment of sleep-maintenance insomnia in relation to age. Psychol Aging. 1986;1(3):233-8. [pmid: 3267403].
21 de Jonghe F, Ameling EH, Jonkers F, et al. Flurazepam and temazepam in the treatment of insomnia in a general hospital population. Pharmacopsychiatry. 1984;17(4):133-5. [pmid: 6147866].
22 deVries MW, Peeters FP. Melatonin as a therapeutic agent in the treatment of sleep disturbance in depression. J Nerv Ment Dis. 1997;185(3):201-2. [pmid: 9091602].
23 Doi Y, Minowa M, Okawa M, et al. Prevalence of sleep disturbance and hypnotic medication use in relation to sociodemographic factors in the general Japanese adult population. J Epidemiol. 2000;10(2):79-86. [pmid: 10778031].
24 Drake CL, Roehrs TA, Mangano RM, et al. Dose-response effects of zaleplon as compared with triazolam (0.25 mg) and placebo in chronic primary insomnia. Hum Psychopharmacol. 2000;15(8):595-604. [pmid: 12404612].
25 Edinger JD, Hoelscher TJ, Marsh GR, et al. A cognitive-behavioral therapy for sleep-maintenance insomnia in older adults. Psychol Aging. 1992;7(2):282-9. [pmid: 1610517].
26 Edinger JD, Wohlgemuth WK, Radtke RA, et al. Cognitive behavioral therapy for treatment of chronic primary insomnia: a randomized controlled trial. J Am Med Assoc. 2001;285(14):1856-64.
27 Ellison ZR, Asplund R. Sleep and cardiac diseases amongst elderly people. J Int Med. 1995;237(2):215-6.
28 Espie CA, Inglis SJ, Harvey L. Predicting clinically significant response to cognitive behavior therapy for chronic insomnia in general medical practice: analysis of outcome data at 12 months posttreatment. J Consult Clin Psychol. 2001;69(1):58-66. [pmid: 11302278].
29 Franklin J. The measurement of sleep onset latency in insomnia. Behav Res Ther. 1981;19(6):547-9. [pmid: 7316932].
30 Franklin LM. Sleep and hypnotics in a psychiatric admission ward. N Z Med J. 1969;69(445):353-6. [pmid: 5257554].
31 Fulda S, Schulz H. Cognitive dysfunction in sleep disorders. Sleep Med Rev. 2001;5(6):423-45. [pmid: 12531152].
32 Gallassi R, Morreale A, Montagna P, et al. Fatal familial insomnia: behavioral and cognitive features. Neurol. 1996;46(4):935-9.
33 Garfinkel D, Laudon M, Zisapel N. Improvement of sleep quality by controlled-release melatonin in benzodiazepine-treated elderly insomniacs. Arch Gerontol Geriatr. 1997;24(2):223-31. [pmid: 15374128].
34 Goldenberg F, Hindmarch I, Joyce CRB, et al. Zopiclone, sleep and health-related quality of life. Hum Psychopharmacol. 1994;9(4):245-51.
35 Guilleminault C, Clerk A, Black J, et al. Nondrug treatment trials in psychophysiologic insomnia. Arch Int Med. 1995;155(8):838-44. [pmid: 7717792].
36 Hajak G, Bandelow B. Safety and tolerance of zolpidem in the treatment of disturbed sleep: A post-marketing surveillance of 16,944 cases. Int Clin Psychopharmacol. 1998;13(4):157-67. [pmid: 9727726].
37 Hajak G, Bandelow B, Zulley J, et al. “As needed” pharmacotherapy combined with stimulus control treatment in chronic insomnia--assessment of a novel intervention strategy in a primary care setting. Ann Clin Psychiatry. 2002;14(1):1-7. [pmid: 12046635].
38 Hajak G, Clarenbach P, Fischer W, et al. Effects of hypnotics on sleep quality and daytime well-being. Data from a comparative multicentre study in outpatients with insomnia. Eur Psychiatry J Assoc Eur Psychiatrists. 1995;10(Suppl 3):173S-9.
39 Hajak G, Clarenbach P, Fischer W, et al. Zopiclone improves sleep quality and daytime well-being in insomniac patients: Comparison with triazolam, flunitrazepam and placebo. Int Clin Psychopharmacol. 1994;9(4):251-61. [pmid: 7868847].
40 Hajak G, Cluydts R, Declerck A, et al. Continuous versus non-nightly use of zolpidem in chronic insomnia: results of a large-scale, double-blind, randomized, outpatient study.[erratum appears in Int Clin Psychopharmacol 2002 Jul;17(4):206]. Int Clin Psychopharmacol. 2002;17(1):9-17. [pmid: 11800507].
41 Hartz AJ, Bentler S, Noyes R, et al. Randomized controlled trial of Siberian ginseng for chronic fatigue. Psychol Med. 2004;34(1):51-61. [pmid: 14971626].
42 Harvey AG. The attempted suppression of presleep cognitive activity in insomnia. Cognitive Therapy & Research. 2003;27(6):593-602.
43 Harvey AG. Pre-sleep cognitive activity: A comparison of sleep-onset insomniacs and good sleepers. Br J Clin Psychol. 2000;39(3):275-86. [pmid: 11033749].
44 Hedner J, Yaeche R, Emilien G, et al. Zaleplon shortens subjective sleep latency and improves subjective sleep quality in elderly patients with insomnia. The Zaleplon Clinical Investigator Study Group. Int J Geriatr Psychiatry. 2000;15(8):704-12. [pmid: 10960882].
45 Hulisz DT. OTC sleep aids and the elderly. U.S. Pharm. 1995;20(1):24-31.
46 Hynes SN, Fitzgerald SG, Shute GE, et al. The utility and validity of daytime naps in the assessment of sleep-onset insomnia. J Behav Med. 1985;8(3):237-47. [pmid: 4087289].
47 Johnson LC, Chernik DA, Hauri P. A multicenter 14-day study of flurazepam and midazolam in chronic insomniacs: general discussion and conclusions. J Clin Psychopharmacol. 1990;10(4 Suppl):76S-90S. [pmid: 2229466].
48 Jones HM. In vivo serotonin 5-HT2A receptor occupancy and quetiapine. Am J Psychiatry. 2000;157(1):148. [pmid: 10618043].
49 Karacan I, Williams R, Salis P, et al. New approaches to the evaluation and treatment of insomnia. Psychosom J Consult Liaison Psychiatry. 1971;12(2):81-8.
50 Lamphere JK, Roehrs TA, Zorick FJ, et al. The dose effects of zopiclone. Hum Psychopharmacol. 1989;4(1):41-6.
51 Leppik IE, Roth-Schechter GB, Gray GW, et al. Double-blind, placebo-controlled comparison of zolpidem, triazolam, and temazepam in elderly patients with insomnia. Drug Devel Res. 1997;40(3):230-8.
52 Levin Y. “Brain music” in the treatment of patients with insomnia. Neurosci Behav Physiol. 1998;28(3):330-5. [pmid: 9682240].
53 Li Pi Shan RS, Ashworth NL. Comparison of lorazepam and zopiclone for insomnia in patients with stroke and brain injury: a randomized, crossover, double-blinded trial. Am JPhys Med Rehab. 2004;83(6):421-7.
54 Lichstein KL, Riedel BW, Lester KW, et al. Occult sleep apnea in a recruited sample of older adults with insomnia. J Consult Clin Psychol. 1999;67(3):405-10. [pmid: 10369061].
55 Mahendran R. Characteristics of patients referred to an insomnia clinic. Singapore Med J. 2001;42(2):064-7.
56 Margolis N. Prevalence, costs, and consequences of insomnia. Reference bibliography: 1993-1998 Sleep. 1999;22(Suppl 2):S409-12.
57 Mashiko H, Niwa S, Kumashiro H, et al. Effect of trazodone in a single dose before bedtime for sleep disorders accompanied by a depressive state: dose-finding study with no concomitant use of hypnotic agent. Psychiatry Clin Neurosci. 1999;53(2):193-4. [pmid: 10459686].
58 Morawetz D. Behavioral self-help treatment for insomnia: A controlled evaluation. Behav Ther. 1989;20(3):365-79.
59 Nelson J, Harvey AG. An exploration of pre-sleep cognitive activity in insomnia: Imagery and verbal thought. Br J Clin Psychol. 2003;42(3):271-88. [pmid: 14565893].
60 Reynolds CF, Kupfer DJ, Thase ME, et al. Sleep, gender, and depression: an analysis of gender effects on the electroencephalographic sleep of 302 depressed outpatients. Biol Psychiatry. 1990;28(8):673-84. [pmid: 2242388].
61 Riemann D, Klein T, Rodenbeck A, et al. Nocturnal cortisol and melatonin secretion in primary insomnia. Psychiatry Res. 2002;113(12):17-27. [pmid: 12467942].
62 Saletu B, Prause W, Loffler-Stastka H, et al. Quality of life in nonorganic and organic sleep disorders: I. Comparison with normative data. Wien Klin Wochenschr. 2003;115(78):246-54. [pmid: 12778777].
63 Savard J, Laroche L, Simard S, et al. Chronic insomnia and immune functioning. Psychosom Med. 2003;65(2):211-21. [pmid: 12651988].
64 Smith MT, Perils ML, Chengazi VU, et al. Neuroimaging of NREM sleep in primary insomnia: A Tc-99-HMPAO single photon emission computed tomography study. Sleep. 2002;25(3):325-35. [pmid: 12003163].
65 Stepanski E, Zorick F, Roehrs T, et al. Effects of sleep deprivation on daytime sleepiness in primary insomnia. Sleep. 2000;23(2):215-9. [pmid: 10737338].
66 Stoller MK. The socio-economics of insomnia: The materials and the methods. Eur Psychiatry. 1997;12(Suppl 1):41S-8.
67 Tachibana H, Izumi T, Honda S, et al. The prevalence and pattern of insomnia in Japanese industrial workers: relationship between psychosocial stress and type of insomnia. Psychiatry Clin Neurosci. 1998;52(4):397-402. [pmid: 9766687].
68 Van Egeren L, Haynes SN, Franzen M, et al. Presleep cognitions and attributions in sleep-onset insomnia. J Behav Med. 1983;6(2):217-32. [pmid: 6620374].
69 Vgontzas AN, Bixler EO, Kales A, et al. Validity and clinical utility of sleep laboratory criteria for insomnia. Int J Neurosci. 1994;77(12):11-21. [pmid: 7989156].
70 Waters WF, Adams SG Jr, Binks P, et al. Attention, stress and negative emotion in persistent sleep-onset and sleep-maintenance insomnia. Sleep. 1993;16(2):128-36. [pmid: 8446832].
71 Wittig RM, Zorick FJ, Blumer D, et al. Disturbed sleep in patients complaining of chronic pain. J Nerv Ment Dis. 1982;170(7):429-31. [pmid: 7086403].

### Excluded - Design (Case Report)

The following studies were excluded because they were case reports.

1 Aguglia U, Gambardella A, Quattrone A. Sleep-induced masticatory myoclonus: A rare parasomnia associated with insomnia. Sleep. 1991;14(1):80-2. [pmid: 1811324].
2 Allan Hobson J. Sleep and dream suppression following a lateral medullary infarct: a first-person account. Conscious Cogn. 2002;11(3):377-90. [pmid: 12435373].
3 Bricolo A. Insomnia after bilateral stereotactic thalamotomy in man. J Neurol Neurosurg Psychiatry. 1967;30(2):154-8. [pmid: 6034107]. [pmcid: 496154].
4 Cordeiro QJ, de Araujo Medrado Faria M, Fraguas RJ. Depression, insomnia, and memory loss in a patient with chronic intoxication by inorganic mercury. J Neuropsychiatry Clin Neurosci. 2003;15(4):457-8. [pmid: 14627777].
5 Hayter J. Insomnia in an older person. Clin Gerontol. 1983;1(3):96-7.
6 Jones ME, Withey S, Harrison DH. ‘Clicking-brain syndrome’: A curious cause of insomnia. Br J Plast Surg. 2001;54(8):714-6. [pmid: 11728117].
7 Kayukawa Y, Okada T, Hayakawa T, et al. Rapid eye movement-localized apnea in a female patient with chronic insomnia. Psychiatry Clin Neurosci. 2002;56(3):321-2. [pmid: 12047615].
8 Mendelson WB, Garnett D, Gillin JC. Flurazepam-induced sleep apnea syndrome in a patient with insomnia and mild sleep-related respiratory changes. J Nerv Ment Dis. 1981;169(4):261-4. [pmid: 7217935].
9 Taratuto AL, Piccardo P, Reich EG, et al. Insomnia associated with thalamic involvement in E200K Creutzfeldt-Jakob disease. Neurol. 2002;58(3):362-7.

### Excluded - Design (No Control Group)

The following studies were excluded because they did not have a control group.

1 Agargun MY, Kara H. Recurrent sleep panic, insomnia, and suicidal behavior in patients with panic disorder. Compr Psychiatry. 1998;39(3):149-51. [pmid: 9606581].
2 Aikens JE, Vanable PA, Tadimeti L, et al. Differential rates of psychopathology symptoms in periodic limb movement disorder, obstructive sleep apnea, psychophysiological insomnia, and insomnia with psychiatric disorder. Sleep. 1999;22(6):775-80. [pmid: 10505823].
3 Allaert FA, Urbinelli R. Sociodemographic profile of insomniac patients across national surveys. CNS Drugs. 2004;18(Suppl 1):3-7. [pmid: 15291008].
4 Bastien CH, Vallieres A, Morin CM. Precipitating factors of insomnia. Behav Sleep Med. 2004;2(1):50-62. [pmid: 15600224].
5 Bliwise N, Bliwise DL, Dement WC. Age and psychopathology in insomnia. Clin Gerontol. 1985;4(2):3-9.
6 Bonnet MH, Kramer M. The interaction of age, performance and hypnotics in the sleep of insomniacs. J Am Geriatr Soc. 1981;29(11):508-12. [pmid: 7299009].
7 Broughton R, Tolentino MA, Krelina M. Excessive fragmentary myoclonus in NREM sleep: a report of 38 cases. Electroencephalogr Clin Neurophysiol. 1985;61(2):123-33. [pmid: 2410221].
8 Buda FB. Sleep disorders in HIV-positive patients. Curable causes of daytime fatigue and sleepiness. Int Conf AIDS. 1996;11(1):107. (abstr Mo.B.1301).
9 Chapman J, Arlazoroff A, Goldfarb LG, et al. Fatal insomnia in a case of familial Creutzfeldt-Jakob disease with the codon 200(Lys) mutation. Neurol. 1996;46(3):758-61.
10 Chemerinski E, Ho B, Flaum M, et al. Insomnia as a predictor for symptom worsening following antipsychotic withdrawal in schizophrenia. Compr Psychiatry. 2002;43(5):393-6. [pmid: 12216015].
11 de Carvalho LB, Lopes EA, Silva L, et al. Personality features in a sample of psychophysiological insomnia patients. Arq NeuroPsiquiatr Sep. 61(3A):588-90.
12 Edinger JD, Stout AL, Hoelscher TJ. Cluster analysis of insomniacs' MMPI profiles: relation of subtypes to sleep history and treatment outcome. Psychosom Med. 1988;50(1):77-87. [pmid: 3344306].
13 Guilleminault C, Lin CM, Goncalves MA, et al. A prospective study of nocturia and the quality of life of elderly patients with obstructive sleep apnea or sleep onset insomnia. J Psychosom Res. 2004;56(5):511-15. [pmid: 15172207].
14 Guilleminault C, Palombini L, Poyares D, et al. Chronic insomnia, postmenopausal women, and sleep disordered breathing: part 1 Frequency of sleep disordered breathing in a cohort. J Psychosom Res. 2002;53(1):611-5. [pmid: 12127179].
15 Hall M, Buysse DJ, Nowell PD, et al. Symptoms of stress and depression as correlates of sleep in primary insomnia. Psychosom Med. 2000;62(2):227-30. [pmid: 10772402].
16 Hart RP, Morin CM, Best AM. Neuropsychological performance in elderly insomnia patients. Aging Cogn. 1995;2(4):268-78.
17 Hattori T. Clinical study of insomnia, a common disorder in primary care: from a viewpoint of consultation-liaison psychiatry. Jpn J Psychiatry Neurol. 1991;45(4):775-8. [pmid: 1813673].
18 Kales A, Caldwell AB, Preston TA, et al. Personality patterns in insomnia. Theoretical implications. Arch Gen Psychiatry. 1976;33(9):1128-24. [pmid: 962495].
19 Kalimo R, Tenkanen L, Harma M, et al. Job stress and sleep disorders: Findings from the Helsinki Heart Study. Stress Med. 2000;16(2):65-75.
20 Kalogjera-Sackellares D, Cartwright RD. Comparison of MMPI profiles in medically and psychologically based insomnias. Psychiatry Res. 1997;70(1):49-56. [pmid: 9172276].
21 Morin CM, Rodrigue S, Ivers H. Role of stress, arousal, and coping skills in primary insomnia. Psychosom Med. 2003;65(2):259-67. [pmid: 12651993].
22 Ohayon MM, Caulet M, Lemoine P. Comorbidity of mental and insomnia disorders in the general population. Compr Psychiatry. 1998;39(4):185-97. [pmid: 9675502].
23 Philip P, Guilleminault C. Adult psychophysiologic insomnia and positive history of childhood insomnia. Sleep. 1996;19(3 Suppl):S16-22. [pmid: 8723371].
24 Prause W, Saletu B, Anderer P, et al. Quality of life in nonorganic and organic sleep disorders: II. Correlation with objective and subjective quality of sleep and awakening. Wien Klin Wochenschr. 2003;115(10):326-33. [pmid: 12800446].
25 Radecki SE, Brunton SA. Management of insomnia in office-based practice. National prevalence and therapeutic patterns. Arch Fam Med. 1993;2(11):1129-34. [pmid: 8124487].
26 Riedel BW, Winfield CF, Lichstein KL. First night effect and reverse first night effect in older adults with primary insomnia: Does anxiety play a role?. Sleep Med. 2001;2(2):125-33. [pmid: 11226861].
27 Roehrs T, Conway W, Wittig R, et al. Sleep-wake complaints in patients with sleep-related respiratory disturbances. Am Rev Resp Dis. 1985;132(3):520-3. [pmid: 4037527].
28 Roehrs T, Zorick F, Sicklesteel J, et al. Age-related sleep-wake disorders at a sleep disorder center. J Am Geriatr Soc. 1983;31(6):364-70. [pmid: 6853947].
29 Rosenthal L, Roehrs T, Sicklesteel J, et al. Periodic movements during sleep, sleep fragmentation, and sleep-wake complaints. Sleep. 1984;7(4):326-30. [pmid: 6515247].
30 Rossini SRG, Reimao R, Lefevre BH. Chronic insomnia in senior citizens: A psychological assessment. Rev Bras Neurol Psiquiatr. 1999;3(2):49-52.
31 Rotenberg V, Tsetlin M. Clinicophysiological analysis of sleep disorders in patients with borderline states. Sov Neurol Psychiatry. 1985;18(1):24-35.
32 Schneider-Helmert D, Kumar A. Sleep, its subjective perception, and daytime performance in insomniacs with a pattern of alpha sleep. Biol Psychiatry. 1995;37(2):99-105. [pmid: 7718685].
33 Schramm E, Hohagen F, Kappler C, et al. Mental comorbidity of chronic insomnia in general practice attenders using DSM-III-R. Acta Psychiatr Scand. 1995;91(1):10-7. [pmid: 7754780].
34 Skaer TL, Robison LM, Sclar DA, et al. Psychiatric comorbidity and pharmacological treatment patterns among patients presenting with insomnia. An assessment of office-based encounters in the USA in 1995 and 1996. Clin Drug Invest. 1999;18(2):161-7.
35 Smith MT, Perlis ML, Haythornthwaite JA. Suicidal ideation in outpatients with chronic musculoskeletal pain: an exploratory study of the role of sleep onset insomnia and pain intensity. Clin J Pain. 2004;20(2):111-8. [pmid: 14770051].
36 Specchio LM, Prudenzano MP, De Tommaso M, et al. Insomnia, quality of life and psychopathological features. Brain Res Bull. 2004;63(5):385-91. [pmid: 15245765].
37 Stephanski E, Koshorek G, Zorick F, et al. Characteristics of individuals who do or do not seek treatment for chronic insomnia. Psychosom. 1989;30(4):421-7.
38 Stone J, Morin CM, Hart RP, et al. Neuropsychological functioning in older insomniacs with or without obstructive sleep apnea. Psychol Aging. 1994;9(2):231-6. [pmid: 8054171].
39 Tabloski PA, Church OM. Insomnia, alcohol and drug use in community-residing elderly persons. J Subst Use. 1999;4(3):147-54.
40 Tan T, et al. Biopsychobehavioral correlates of insomnia: IV. Diagnosis based on DSM-III. Am J Psychiatry. 1984;141(3):357-62. [pmid: 6703098].
41 Vandeputte M, de Weerd A. Sleep disorders and depressive feelings: A global survey with the Beck depression scale. Sleep Med. 2003;4(4):343-5. [pmid: 14592308].
42 Vincent N, Walker J. Anxiety sensitivity: predictor of sleep-related impairment and medication use in chronic insomnia. Depress Anxiety. 2001;14(4):238-43. [pmid: 11754132].
43 Vlasov N, Yadgarov I. The structure of nocturnal sleep in sleep disorders in middle-aged and elderly people. Sov Neurol Psychiatry. 1986;19(3):71-9.
44 Vollrath M, Wicki W, Angst J. The Zurich study. VIII. Insomnia: association with depression, anxiety, somatic syndromes, and course of insomnia. Eur Arch Psychiatry Neurol Sci. 1989;239(2):113-24. [pmid: 2806334].
45 Wilson KG, Eriksson MY, D'Eon JL, et al. Major depression and insomnia in chronic pain. Clin J Pain. 2002;18(2):77-83. [pmid: 11882770].
46 Wilson KG, Watson ST, Currie SR. Daily dairy and ambulatory activity monitoring of sleep in patients with insomnia associated with chronic musculoskeletal pain. Pain. 1998;75(1):75-84. [pmid: 9539676].
47 Zucconi M, Ferini-Strambi L, Gambini O, et al. Structured psychiatric interview and ambulatory sleep monitoring in young psychophysiological insomniacs. J Clin Psychiatry. 1996;57(8):364-70. [pmid: 8752020].

### Excluded - Population (Non-Adult)

The following studies were excluded because they did not examine an adult population.

1 Abdel-Khalek AM. Epidemiologic study of sleep disorders in Kuwaiti adolescents. Percept Mot Skills. 2001;93(3):901-10. [pmid: 11806616].
2 Abdel-Khalek AM. Prevalence of reported insomnia and its consequences in a survey of 5,044 adolescents in Kuwait. Sleep. 2004;27(4):726-31. [pmid: 15283008].
3 Ando K, Hayakawa T, Ohta T, et al. Long-term follow-up study of 10 adolescent patients with sleep-wake schedule disorders. Jpn J Psychiatry Neurol. 1994;48(1):37-41. [pmid: 7933714].
4 Bertelson AD, Monroe LJ. Personality patterns of adolescent poor and good sleepers. J Abnorm Child Psychol. 1979;7(2):191-7. [pmid: 469112].
5 Bruni O, Ferri R, D'Agostino G, et al. Sleep disturbances in Angelman syndrome: a questionnaire study. Brain Devel. 2004;26(4):233-40. [pmid: 15130689].
6 Dollinger SJ, Horn JL, Boarini D. Disturbed sleep and worries among learning disabled adolescents. Am J Orthopsychiatry. 1988;58(3):428-34. [pmid: 3407733].
7 Leger D, Guilleminault C, Bader G, et al. Medical and socio-professional impact of insomnia. Sleep. 2002;25(6):625-9. [pmid: 12224841].
8 Okuji Y, Matsuura M, Kawasaki N, et al. Prevalence of insomnia in various psychiatric diagnostic categories. Psychiatry Clin Neurosci. 2002;56(3):239-40. [pmid: 12047575].

### Excluded - Population (Not Chronic Insomnia)

The following studies were excluded because the participants did not suffer from chronic insomnia as defined in this report.

1 Abe K, Suzuki T. Age trends of early awakening and feeling worse in the morning than in the evening in apparently normal people. J Nerv Ment Dis. 1985;173(8):495-8. [pmid: 4020367].
2 Agarguen MY, Kara H, Solmaz M. Sleep disturbances and suicidal behavior in patients with major depression. J Clin Psychiatry. 1997;58(6):249-51. [pmid: 9228889].
3 Alapin I, Fichten CS, Libman E, et al. How is good and poor sleep in older adults and college students related to daytime sleepiness, fatigue, and ability to concentrate?. J Psychosom Res. 2000;49(5):381-90. [pmid: 11164064].
4 Aldrich MS, Foster NL, White RF, et al. Sleep abnormalities in progressive supranuclear palsy. Ann Neurol. 1989;25(6):577-81. [pmid: 2742360].
5 Aldrich MS, Shipley JE. Alcohol use and periodic limb movements of sleep. Alcohol Clin Exp Res. 1993;17(1):192-6. [pmid: 8452202].
6 Allen RP. Article reviewed: Mortality associated with sleep duration and insomia. Sleep Med. 2002;3(4):373-5. [pmid: 14592204].
7 Allgulander C, Borg S, Vikander B. A 4–6 year follow-up of 50 patients with primary dependence on sedative and hypnotic drugs. Am J Psychiatry. 1984;141(12):1580-2. [pmid: 6507663].
8 Almeida OP, Tamai S, Garrido R. Sleep complaints among the elderly: results from a survey in a psychogeriatric outpatient clinic in Brazil. Int Psychogeriatr. 1999;11(1):47-56. [pmid: 10189598].
9 Almer G, Hainfellner JA, Brucke T, et al. Fatal familial insomnia: a new Austrian family. Brain. 1999;122(Pt 1):5-16. [pmid: 10050890].
10 Alster J, Shemesh Z, Ornan M, et al. Sleep disturbance associated with chronic tinnitus. Biol Psychiatry. 1993;34(12):84-90. [pmid: 8373941].
11 Althuis MD, Fredman L, Langenberg PW, et al. The relationship between insomnia and mortality among community-dwelling older women. J Am Geriatr Soc. 1998;46(10):1270-3. [pmid: 9777910].
12 Amagai Y, Ishikawa S, Gotoh T, et al. Sleep Duration and Mortality in Japan: the Jichi Medical School Cohort Study. J Epidemiol. 2004;14(4):124-8. [pmid: 15369129].
13 Andrews HB, Davis N. Sleeping disorders among West Australian tertiary students. Community Health Stud. 1988;12(2):208-11. [pmid: 3262037].
14 Angle HV. Sleep problems and sleep medication involvement of psychiatric patients. J Nerv Ment Dis. 1979;167(12):752-7. [pmid: 41883].
15 Angst J, Vollrath M, Koch R, et al. The Zurich Study: VII. Insomnia: Symptoms, classification and prevalence. Eur Arch Psychiatry Neurol Sci. 1989;238(56):285-93. [pmid: 2767086].
16 Arriaga F, Paiva T, Matos-Pires A, et al. The sleep of non-depressed patients with panic disorder: A comparison with normal controls. Acta Psychiatr Scand. 1996;93(3):191-4. [pmid: 8739665].
17 Asplund R. Sleep and cardiac diseases amongst elderly people. J Int Med. 1994;236(1):65-71.
18 Asplund R. Sleepiness and sleep in elderly persons with tinnitus. Arch Gerontol Geriatri. 2003;37(2):139-45.
19 Astrom C, Lunde I, Ortmann J, et al. Sleep disturbances in torture survivors. Acta Neurol Scand. 1989;79(2):150-4. [pmid: 2711821].
20 Atkinson JH, Ancoli-Israel S, Slater MA, et al. Subjective sleep disturbance in chronic back pain. Clin J Pain. 1988;4(4):225-32.
21 Aversa Lopes E, Coin De Carvalho LB, Bernal Da Costa Seguro P, et al. Sleep disorders in pregnancy. Arq NeuroPsiquiatr. 2004;62(2 A):217-21. [pmid: 15235720].
22 Avoni P, Cortelli P, Montagna P, et al. Circadian hormonal rhythms in two new cases of fatal familial insomnia. Acta Neurol. 1991;13(6):574-6.
23 Baker FC, Driver HS. Self-reported sleep across the menstrual cycle in young, healthy women. J Psychosom Res. 2004;56(2):239-43. [pmid: 15016584].
24 Baldwin CM, Bell IR, Guerra S, et al. Associations between chemical odor intolerance and sleep disturbances in community-living adults. Sleep Med. 2004;5(1):53-9. [pmid: 14725827].
25 Baldwin CM, Griffith KA, Nieto FJ, et al. The association of sleep-disordered breathing and sleep symptoms with quality of life in the Sleep Heart Health Study. Sleep. 2001;24(1):96-105. [pmid: 11204058].
26 Ban DJ, Lee TJ. Sleep Duration, Subjective Sleep Disturbances and Associated Factors Among University Students in Korea. J Korean Med Sci. 2001;16(4):475-80. [pmid: 11511794].
27 Barak Y, Achiron A, Kimh R, et al. Health risks among shift workers: a survey of female nurses. Health Care Women Int. 1996;17(6):527-33. [pmid: 9119772].
28 Barbe F, Quera-Salva MA, McCann C, et al. Sleep-related respiratory disturbances in patients with Duchenne muscular dystrophy. Eur Resp J. 1994;7(8):1403-8.
29 Barthlen GM, Lange DJ. Unexpectedly severe sleep and respiratory pathology in patients with amyotrophic lateral sclerosis. Eur J Neurol. 2000;7(3):299-302. [pmid: 10886313].
30 Bassetti CL, Mauerhofer D, Gugger M, et al. Restless legs syndrome: a clinical study of 55 patients. Eur Neurol. 2001;45(2):67-74. [pmid: 11244268].
31 Beetar JT, Guilmette TJ, Sparadeo FR. Sleep and pain complaints in symptomatic traumatic brain injury and neurologic populations. Arch Phys Med Rehab. 1996;77(12):1298-302.
32 Bell IR, Bootzin RR, Ritenbaugh C, et al. A polysomnographic study of sleep disturbance in community elderly with self-reported environmental chemical odor intolerance. Biol Psychiatry. 1996;40(2):123-33. [pmid: 8793044].
33 Bellia V, Catalano F, Scichilone N, et al. Sleep disorders in the elderly with and without chronic airflow obstruction: the SARA study. Sleep. 2003;26(3):318-23. [pmid: 12749552].
34 Bellows JG. One genetic mutation, two diseases: fatal familial insomnia and Creutzfeldt-Jakob disease. Compr Ther. 1993;19(1):3. [pmid: 8334858].
35 Beshwari MMM, Bener A, Ameen A, et al. Pesticide-related health problems and diseases among farmers in the United Arab Emirates. Int J Environ Health Res. 1999;9(3):213-21.
36 Bliwise DL. Historical change in the report of daytime fatigue. Sleep. 1996;19(6):462-4. [pmid: 8865502].
37 Bonati MT, Ferini-Strambi L, Aridon P, et al. Autosomal dominant restless legs syndrome maps on chromosome 14q. Brain. 2003;126(Pt 6):1485-92. [pmid: 12764067].
38 Brabbins CJ, Dewey ME, Copeland JRM, et al. Insomnia in the elderly: Prevalence, gender differences and relationships with morbidity and mortality. Int J Geriatr Psychiatry. 1993;8(6):473-80.
39 Brassington GS, King AC, Bliwise DL. Sleep problems as a risk factor for falls in a sample of community-dwelling adults aged 64–99 years. J Am Geriatr Soc. 2000;48(10):1234-40. [pmid: 11037010].
40 Brower KJ, Aldrich MS, Robinson EA, et al. Insomnia, self-medication, and relapse to alcoholism. Am J Psychiatry. 2001;158(3):399-404. [pmid: 11229980].
41 Brown S, Atkinson H, Gutierrez R et al. Subjective sleep disturbance in HIV illness. Int Conf AIDS 1990; 6(2):397 (abstr 2173).
42 Buboltz WCJ, Brown F, Soper B. Sleep habits and patterns of college students: a preliminary study. J Am Coll Health. 2001;50(3):131-5. [pmid: 11765249].
43 Budka H. Fatal familial insomnia around the world. Brain Pathol. 1998;8(3):553-70. [pmid: 9669707].
44 Buzzi G, Mostacci B, Sancisi E, et al. Sleep complaints in periodic paralyses: A web survey. Funct Neurol. 2001;16(3):245-52. [pmid: 11769870].
45 Byles JE, Mishra GD, Harris MA, et al. The problems of sleep for older women: changes in health outcomes. Age Ageing. 2003;32(2):154-63. [pmid: 12615558].
46 Caap-Ahlgren M, Dehlin O. Insomnia and depressive symptoms in patients with Parkinson's disease: Relationship to health-related quality of life. An interview study of patients living at home. Arch Gerontol Geriatr. 2001;32(1):23-33. [pmid: 11251236].
47 Call-Schmidt TA, Richardson SJ. Prevalence of sleep disturbance and its relationship to pain in adults with chronic pain. Pain Manag Nurs. 2003;4(3):124-33. [pmid: 14566710].
48 Carney RM, Freedland KE, Jaffe AS. Insomnia and depression prior to myocardial infarction. Psychosom Med. 1990;52(6):603-9. [pmid: 2287700].
49 Carpenter BD, Strauss ME, Patterson MB. Sleep disturbances in community-dwelling patients with Alzheimer's disease. Clin Gerontol. 1995;16(2):35-49.
50 Cartwright RD, Wood E. Adjustment disorders of sleep: The sleep effects of a major stressful event and its resolution. Psychiatry Res. 1991;39(3):199-209. [pmid: 1798820].
51 Cernovsky ZZ. Life stress measures and reported frequency of sleep disorders. Percept Mot Skills. 1984;58(1):39-49. [pmid: 6718201].
52 Chang PP, Ford DE, Mead LA, et al. Insomnia in young men and subsequent depression. The Johns Hopkins Precursors Study. Am J Epidemiol. 1997;146(2):105-14. [pmid: 9230772].
53 Charon F, Dramaix M, Mendlewicz J. Epidemiological survey of insomniac subjects in a sample of 1,761 outpatients. Neuropsychobiol. 1989;21(3):109-10.
54 Chen CC, Yeh TL, Yang YK, et al. Psychiatric morbidity and post-traumatic symptoms among survivors in the early stage following the 1999 earthquake in Taiwan. Psychiatry Res. 2001;105(12):13-22. [pmid: 11740971].
55 Chiu HF, Leung T, Lam LC, et al. Sleep problems in Chinese elderly in Hong Kong. Sleep. 1999;22(6):717-26. [pmid: 10505817].
56 Cirignotta F, Mondini S, Zucconi M, et al. Insomnia: an epidemiological survey. Clin Neuropharmacol. 1985;8(Suppl 1):S49-54. [pmid: 3837686].
57 Cohen D, Eisdorfer C, Prinz P, et al. Sleep disturbances in the institutionalized aged. J Am Geriatr Soc. 1983;31(2):79-82. [pmid: 6822712].
58 Coren S. The prevalence of self-reported sleep disturbances in young adults. Int J Neurosci. 1994;79(12):67-73. [pmid: 7744552].
59 Cortelli P, Gambetti P, Montagna P, et al. Fatal familial insomnia: clinical features and molecular genetics. J Sleep Res. 1999;8(Suppl 1):23-9. [pmid: 10389103].
60 Cortelli P, Parchi P, Contin M, et al. Cardiovascular dysautonomia in fatal familial insomnia. Clin Auton Res. 1991;1(1):15-21. [pmid: 1821660].
61 Cricco M, Simonsick EM, Foley DJ. The impact of insomnia on cognitive functioning in older adults. J Am Geriatr Soc. 2001;49(9):1185-9. [pmid: 11559377].
62 Crum RM, Storr CL, Chan YF, et al. Sleep Disturbance and Risk for Alcohol-Related Problems. Am J Psychiatry. 2004;161(7):1197-203. [pmid: 15229051].
63 Curless R, French JM, James OF, et al. Is caffeine a factor in subjective insomnia of elderly people?. Age Ageing. 1993;22(1):41-5. [pmid: 8438665].
64 Dahlitz M, Parkes JD. Sleep paralysis. Lancet. 1993;341(8842):406-7. [pmid: 8094172].
65 Daly RJ, Hassall C. Reported sleep on maintenance haemodialysis. British Medical Journal. May 30. 1970;2(708):508-9. [pmid: 5428714]. [pmcid: 1700353].
66 Davidson JR, MacLean AW, Brundage MD, et al. Sleep disturbance in cancer patients. Soc Sci Med. 2002;54(9):1309-21. [pmid: 12058848].
67 Davidson LM, Fleming R, Baum A. Chronic stress, catecholamines, and sleep disturbance at Three Mile Island. J Hum Stress. 1987;13(2):75-83.
68 De Souza J. Quality of life and insomnia in university psychology students. Hum Psychopharmacol. 1996;11(3):169-84.
69 De Vecchi A, Finazzi S, Padalino R, et al. Sleep disorders in peritoneal and haemodialysis patients as assessed by a self-administered questionnaire. Int J Artif Organs. 2000;23(4):237-42. [pmid: 10832657].
70 DeViva JC, Zayfert C, Mellman TA. Factors associated with insomnia among civilians seeking treatment for PTSD: An exploratory study. Behav Sleep Med. 2004;2(3):162-76. [pmid: 15600231].
71 Dodge R, Cline MG, Quan SF. The natural history of insomnia and its relationship to respiratory symptoms. Arch Int Med. 1995;155(16):1797-800. [pmid: 7654114].
72 Doi Y, Minowa M. Gender differences in excessive daytime sleepiness among Japanese workers. Soc Sci Med. 2003;56(4):883-94. [pmid: 12560020].
73 Domenighetti G, D'Avanzo B, Bisig B. Health effects of job insecurity among employees in the Swiss general population. Int J Health Serv. 2000;30(3):477-90. [pmid: 11109177].
74 Dorandeu A, Wingertsmann L, Chretien F, et al. Neuronal apoptosis in fatal familial insomnia. Brain Pathol. 1998;8(3):531-7. [pmid: 9669704].
75 Douchez J, Droz JP, Desclaux B, et al. Quality of life in long-term survivors of nonseminomatous germ cell testicular tumors. J Urol. 1993;149(3):498-501. [pmid: 8382321].
76 Drake C, Richardson G, Roehrs T, et al. Vulnerability to stress-related sleep disturbance and hyperarousal. Sleep. 2004;27(2):285-91. [pmid: 15124724].
77 Drummond SP, Gillin JC, Smith TL, et al. The sleep of abstinent pure primary alcoholic patients: natural course and relationship to relapse. Alcohol Clin Exp Res. 1998;22(8):1796-802. [pmid: 9835298].
78 Dryman A, Eaton WW. Affective symptoms associated with the onset of major depression in the community: Findings from the US National Institute of Mental Health Epidemiologic Catchment Area Program. Acta Psychiatr Scand. 1991;84(1):1-5. [pmid: 1927557].
79 Dumont M, Montplaisir J, Infante-Rivard C. Sleep quality of former night-shift workers... XIIth International Symposium on Night and Shiftwork. Foxwoods symposium series, June 1995. Int J Occupat Environ Health. 1997;3(3:Suppl):S10-4.
80 Elger BS. Prevalence, Types and Possible Causes of Insomnia in a Swiss Remand Prison. Eur J Epidemiol. 2004;19(7):665-77. [pmid: 15461198].
81 Elsenbruch S, Thompson JJ, Hamish MJ, et al. Behavioral and physiological sleep characteristics in women with irritable bowel syndrome. Am J Gastroenterol. 2002;97(9):2306-14. [pmid: 12358249].
82 Eriksen W, Natvig B, Bruusgaard D. Sleep Problems: a Predictor of Long-Term Work Disability? A Four-Year Prospective Study. Scand J Public Health. 2001;29(1):23-31. [pmid: 11355713].
83 Factor SA, McAlarney T, Sanchez-Ramos JR, et al. Sleep disorders and sleep effect in Parkinson's disease. Mov Disord. 1990;5(4):280-5. [pmid: 2259351].
84 Fetveit A, Bjorvatn B. Sleep disturbances among nursing home residents. Int J Geriatr Psychiatry. 2002;17(7):604-9. [pmid: 12112156].
85 Fichten CS, Libman E, Creti L, et al. Role of thoughts during nocturnal awake times in the insomnia experience of older adults. Cogn Ther Res. 2001;25(6):665-92.
86 Fichtenberg NL, Millis SR, Mann NR, et al. Factors associated with insomnia among post-acute traumatic brain injury survivors. Brain Inj. 2000;14(7):659-67. [pmid: 10914647].
87 Fischler B, Le Bon O, Hoffmann G, et al. Sleep anomalies in the chronic fatigue syndrome. A comorbidity study. Neuropsychobiol. 1997;35(3):115-22.
88 Foley D, Ancoli-Israel S, Britz P, et al. Sleep disturbances and chronic disease in older adults: Results of the 2003 National Sleep Foundation Sleep in America Survey. J Psychosom Res. 2004;56(5):497-502. [pmid: 15172205].
89 Foley DJ, Monjan AA, Brown SL, et al. Sleep complaints among elderly persons: an epidemiologic study of three communities. Sleep. 1995;18(6):425-32. [pmid: 7481413].
90 Foley DJ, Monjan AA, Izmirlian G, et al. Incidence and remission of insomnia among elderly adults in a biracial cohort. Sleep. 1999;22(Suppl 2):S373-8. [pmid: 10394610].
91 Folmer RL, Griest SE. Tinnitus and insomnia. Am J Otolaryngol Head Neck Med Surg. 2000;21(5):287-93.
92 Frisoni GB, de Leo D, Rozzini R, et al. Psychic correlates of sleep symptoms in the elderly. Int J Geriatr Psychiatry. 1992;7(12):891-8.
93 Fukunishi I, Kawamura N, Ishikawa T, et al. Sleep characteristics of Japanese working men who score alexithymic on the Toronto Alexithymia Scale. Percept Mot Skills. 1997;84(3, Pt 1):859-65. [pmid: 9172194].
94 Gallassi R, Morreale A, Montagna P, et al. “Fatal familial insomnia”: neuropsychological study of a disease with thalamic degeneration. Cortex. 1992;28(2):175-87. [pmid: 1499304].
95 Ganguli M, Reynolds CF, Gilby JE. Prevalence and persistence of sleep complaints in a rural older community sample: the MoVIES project. J Am Geriatr Soc. 1996;44(7):778-84. [pmid: 8675924].
96 Garbarino S, De Carli F, Mascialino B, et al. Sleepiness in a population of Italian shiftwork policemen. J Hum Ergol. 2001;30(12):211-6.
97 Garbarino S, De Carli F, Nobili L, et al. Sleepiness and sleep disorders in shift workers: a study on a group of Italian police officers. Sleep. 2002;25(6):648-53. [pmid: 12224843].
98 Garbarino S, Nobili L, Beelke M, et al. Sleep disorders and daytime sleepiness in state police shiftworkers. Arch Environ Health. 2002;57(2):167-73. [pmid: 12194162].
99 Gering RC, Mahrer AR. Difficulty falling asleep. Psychol Rep. 1972;30(2):523-8. [pmid: 5024931].
100 Gigli GL, Moroni M, Visani L, et al. A pharmacoepidemiologic Italian multicenter study on the treatment of unselected insomniac patients with brotizolam. Curr Ther Res Clin Exp. 1991;50(5):652-66.
101 Gislason T, Almqvist M. Somatic diseases and sleep complaints. An epidemiological study of 3,201 Swedish men. Acta Med Scand. 1987;221(5):475-81. [pmid: 3496735].
102 Gislason T, Reynisdottir H, Kristbjarnarson H, et al. Sleep habits and sleep disturbances among the elderly--an epidemiological survey. J Int Med. 1993;234(1):31-9.
103 Goldfarb LG, Petersen RB, Tabaton M, et al. Fatal familial insomnia and familial Creutzfeldt-Jakob disease: disease phenotype determined by a DNA polymorphism. Science. 1992;258(5083):806-8. [pmid: 1439789].
104 Haermae M, Tenkanen L, Sjoeblom T, et al. Combined effects of shift work and life-style on the prevalence of insomnia, sleep deprivation and daytime sleepiness. Scand J Work Environ Health. 1998;24(4):300-7. [pmid: 9754862].
105 Haider I. Patterns of insomnia in depressive illness: a subjective evaluation. Br J Psychiatry. 1968;114(514):1127-32. [pmid: 5684661].
106 Hansotia P, Wall R, Berendes J. Sleep disturbances and severity of Huntington's disease. Neurol. 1985;35(11):1672-4.
107 Hatoum HT, Kania CM, Kong SX, et al. Prevalence of insomnia: a survey of the enrollees at five managed care organizations. Am J Manage Care. 1998;4(1):79-86.
108 Hatoum HT, Kong SX, Kania CM, et al. Insomnia, health-related quality of life and healthcare resource consumption. A study of managed-care organisation enrollees. Pharmacoecon. 1998;14(6):629-37.
109 Hauri P, Chernik D, Hawkins D, et al. Sleep of depressed patients in remission. Arch Gen Psychiatry. 1974;31(3):386-91. [pmid: 4370375].
110 Hayer CA, Hicks RA. Type A-B scores and insomnia among college students: A replication and extension of earlier studies. Percept Mot Skills. 1993;77(3, Pt 2):1265-6. [pmid: 8170776].
111 Heath AC, Eaves LJ, Kirk KM, et al. Effects of lifestyle, personality, symptoms of anxiety and depression, and genetic predisposition on subjective sleep disturbance and sleep pattern. Twin Res. 1998;1(4):176-88. [pmid: 10100809].
112 Heath AC, Kendler KS, Eaves LJ, et al. Evidence for genetic influences on sleep disturbance and sleep pattern in twins. Sleep. 1990;13(4):318-35. [pmid: 2267475].
113 Henderson S, Jorm AF, Scott LR, et al. Insomnia in the elderly: its prevalence and correlates in the general population. Med J Aust. 1995;162(1):22-4. [pmid: 7845293].
114 Hoffmann G. Evaluation of severe insomnia in the general population--implications for the management of insomnia: focus on results from Belgium. J Psychopharmacol. 1999;13(4 Suppl 1):S31-2. [pmid: 10667456].
115 Hugel H, Ellershaw JE, Cook L, et al. The prevalence, key causes and management of insomnia in palliative care patients. J Pain Symptom Manage. 2004;27(4):316-21. [pmid: 15050659].
116 Hui DS, Wong TY, Ko FW, et al. Prevalence of sleep disturbances in chinese patients with end-stage renal failure on continuous ambulatory peritoneal dialysis. Am J Kidney Dis. 2000;36(4):783-8. [pmid: 11007681].
117 Hyyppa MT, Kronholm E. Sleep movements and poor sleep in patients with non-specific somatic complaints--II. Affective disorders and sleep quality. J Psychosom Res. 1987;31(5):631-7. [pmid: 3430426].
118 Infante-Rivard C, Dumont M, Montplaisir J. Sleep disorder symptoms among nurses and nursing aides. Int Arch Occupat Environ Health. 1989;61(5):353-8.
119 Janson C, Gislason T, De Backer W, et al. Prevalence of sleep disturbances among young adults in three European countries. Sleep. 1995;18(7):589-97. [pmid: 8552930].
120 Janson C, Lindberg E, Gislason T, et al. Insomnia in men - A 10-year prospective population based study. Sleep. 2001;24(4):425-30. [pmid: 11403527].
121 Jensen E, Dehlin O, Hagberg B, et al. Insomnia in an 80-year-old population: relationship to medical, psychological and social factors. J Sleep Res. 1998;7(3):183-9. [pmid: 9785273].
122 Johns MW. Factor analysis of subjectively reported sleep habits, and the nature of insomnia. Psychol Med. 1975;5(1):83-8. [pmid: 1118533].
123 Johnson JE. Insomnia, alcohol, and over-the-counter drag use in old-old urban women. J Commun Health Nurs. 1997;14(3):181-8.
124 Johnston SK, Landis CA, Lentz MJ, et al. Self-reported nap behavior and polysomnography at home in midlife women with and without insomnia. Sleep. 2001;24(8):913-9. [pmid: 11766161].
125 Kapur VK, Redline S, Nieto FJ, et al. The relationship between chronically disrupted sleep and healthcare use. Sleep. 2002;25(3):289-96. [pmid: 12003159].
126 Katz DA, McHorney CA. Clinical correlates of insomnia in patients with chronic illness. Arch Int Med. 1998;158(10):1099-1107. [pmid: 9605781].
127 Kawada T, Kiryu Y, Sasazawa Y, et al. Prevalence of insomnia and its relationship to the health habits or status of women living along a city road part 1. Epidemiologic study. Environ Health Prevent Med. 1997;1(4):211-15.
128 Kiejna A, Wojtyniak B, Rymaszewska J, et al. Prevalence of insomnia in Poland - Results of the National Health Interview Survey. Acta Neuropsychiatri. 2003;15(2):68-73.
129 Kim K, Uchiyama M, Liu X, et al. Somatic and psychological complaints and their correlates with insomnia in the Japanese general population. Psychosom Med. 2001;63(3):441-6. [pmid: 11382271].
130 Kim K, Uchiyama M, Okawa M, et al. An epidemiological study of insomnia among the Japanese general population. Sleep. 2000;23(1):41-7. [pmid: 10678464].
131 Klink ME, Quan SF, Kaltenborn WT, et al. Risk factors associated with complaints of insomnia in a general adult population. Influence of previous complaints of insomnia. Arch Int Med. 1992;152(8):1634-7. [pmid: 1497397].
132 Krakow B, Haynes PL, Warner TD, et al. Nightmares, insomnia, and sleep-disordered breathing in fire evacuees seeking treatment for posttraumatic sleep disturbance. J Traumatic Stress. 2004;17(3):257-68.
133 Krakow B, Melendrez D, Ferreira E, et al. Prevalence of insomnia symptoms in patients with sleep-disordered breathing. Chest. 2001;120(6):1923-9. [pmid: 11742923].
134 Krakow B, Melendrez D, Pedersen B, et al. Complex insomnia: insomnia and sleep-disordered breathing in a consecutive series of crime victims with nightmares and PTSD. Biol Psychiatry. 2001;49(11):948-53. [pmid: 11377413].
135 Kripke DF, Garfinkel L, Wingard DL, et al. Mortality associated with sleep duration and insomnia. Arch Gen Psychiatry. 2002;59(2):131-6. [pmid: 11825133].
136 Kupfer D, Harrow M, Detre T. Sleep patterns and psychopathology. Acta Psychiatr Scand. 1969;45(1):75-89. [pmid: 5345567].
137 Leger D, Levy E, Paillard M. The direct costs of insomnia in France. Sleep. 1999;22(Suppl 2):S394-401. [pmid: 10394613].
138 Li RH, Wing YK, Ho SC, et al. Gender differences in insomnia--a study in the Hong Kong Chinese population. J Psychosom Res. 2002;53(1):601-9. [pmid: 12127178].
139 Liljenberg B, Almqvist M, Hetta J, et al. Age and the prevalence of insomnia in adulthood. European Journal of Psychiatry. 1989;3(1):5-12.
140 Liljenberg B, Almwvist M, Hetta J, et al. Affective disturbance and insomnia: A population study. Eur J Psychiatry. 1989;3(2):91-8.
141 Livingston G, Blizard B, Mann A. Does sleep disturbance predict depression in elderly people? A study in inner London. Br J Gen Pract. 1993;43(376):445-8. [pmid: 8292414]. [pmcid: 1372481].
142 Loayza H MP, Ponte TS, Carvalho CG, et al. Association between mental health screening by self-report questionnaire and insomnia in medical students. Arq NeuroPsiquiatr. 2001;59(2-A):180-5. [pmid: 11400021].
143 Lobbezoo F, Visscher CM, Naeije M. Impaired health status, sleep disorders, and pain in the craniomandibular and cervical spinal regions. Eur J Pain. 2004;8(1):23-30. [pmid: 14690671].
144 Maggi S, Langlois JA, Minicuci N, et al. Sleep complaints in community-dwelling older persons: prevalence, associated factors, and reported causes. J Am Geriatr Soc. 1998;46(2):161-8. [pmid: 9475443].
145 Manabe K, Matsui T, Yamaya M, et al. Sleep patterns and mortality among elderly patients in a geriatric hospital. Gerontol. 2000;46(6):318-22.
146 Mant A, Eyland EA. Sleep patterns and problems in elderly general practice attenders: an Australian survey. Community Health Stud. 1988;12(2):192-9. [pmid: 3262035].
147 McCall WV, Reboussin BA, Cohen W. Subjective measurement of insomnia and quality of life in depressed inpatients. J Sleep Res. 2000;9(1):43-8. [pmid: 10733688].
148 McCarren M, Goldberg J, Ramakrishnan V, et al. Insomnia in Vietnam era veteran twins: influence of genes and combat experience. Sleep. 1994;17(5):456-61. [pmid: 7991958].
149 Medori R, Montagna P, Tritschler HJ, et al. Fatal familial insomnia: a second kindred with mutation of prion protein gene at codon 178. Neurol. 1992;42(3 Pt 1):669-70.
150 Mellinger GD, Balter MB, Uhlenhuth EH. Insomnia and its treatment. Prevalence and correlates. Arch Gen Psychiatry. 1985;42(3):225-32. [pmid: 2858188].
151 Morgan K. Daytime activity and risk factors for late-life insomnia. J Sleep Res. 2003;12(3):231-8. [pmid: 12941062].
152 Morgan K, Clarke D. Longitudinal trends in late-life insomnia: Implications for prescribing. Age Ageing. 1997;26(3):179-84. [pmid: 9223712].
153 Morgan K, Clarke D. Risk factors for late-life insomnia in a representative general practice sample. Br J Gen Pract. 1997;47(416):166-9. [pmid: 9167321]. [pmcid: 1312924].
154 Morgan K, Dallosso H, Ebrahim S, et al. Characteristics of subjective insomnia in the elderly living at home. Age Ageing. 1988;17(1):1-7. [pmid: 3364306].
155 Morgan K, Healey DW, Healey PJ. Factors influencing persistent subjective insomnia in old age: a follow-up study of good and poor sleepers aged 65 to 74. Age Ageing. 1989;18(2):117-22. [pmid: 2729006].
156 Morin CM, Gramling SE. Sleep patterns and aging: Comparison of older adults with and without insomnia complaints. Psychol Aging. 1989;4(3):290-4. [pmid: 2803622].
157 Moul DE, Nofzinger EA, Pilkonis PA, et al. Symptom reports in severe chronic insomnia. Sleep. 2002;25(5):553-63. [pmid: 12150322].
158 Nakata A, Haratani T, Kawakami N, et al. Sleep problems in white-collar male workers in an electric equipment manufacturing company in Japan. Ind Health. 2000;38(1):62-8. [pmid: 10680312].
159 Nakata A, Haratani T, Takahashi M, et al. Job stress, social support, and prevalence of insomnia in a population of Japanese daytime workers. Soc Sci Med. 2004;59(8):1719-30. [pmid: 15279928].
160 Newman AB, Enright PL, Manolio TA, et al. Sleep disturbance, psychosocial correlates, and cardiovascular disease in 5201 older adults: the Cardiovascular Health Study... abstract presented at the November 1993 meeting of American Geriatrics Society. J Am Geriatr Soc. 1997;45(1):1-7. [pmid: 8994480].
161 Neylan TC, Marmar CR, Metzler TJ, et al. Sleep disturbances in the Vietnam generation: findings from a nationally representative sample of male Vietnam veterans. Am J Psychiatry. 1998;155(7):929-33. [pmid: 9659859].
162 Novak M, Mucsi I, Shapiro CM, et al. Increased utilization of health services by insomniacs - An epidemiological perspective. J Psychosom Res. 2004;56(5):527-36. [pmid: 15172209].
163 Ogunremi O. The subjective sleep patterns and dreams of Nigerians. Afr J Psychiatry. 1978;4(3 Suppl 4):113-9.
164 Ohayon M. Epidemiological study on insomnia in the general population. Sleep. 1996;19(3 Suppl):S7-15. [pmid: 8723370].
165 Ohayon MM, Caulet M, Guilleminault C. How a general population perceives its sleep and how this relates to the complaint of insomnia. Sleep. 1997;20(9):715-23. [pmid: 9406323].
166 Ohayon MM, Caulet M, Philip P, et al. How sleep and mental disorders are related to complaints of daytime sleepiness. Arch Int Med. 1997;157(22):2645-52. [pmid: 9531234].
167 Ohayon MM, Caulet M, Priest RG, et al. DSM-IV and ICSD-90 insomnia symptoms and sleep dissatisfaction. Br J Psychiatry. 1997;171:382-8. [pmid: 9373431].
168 Ohida T, Kamal AMM, Uchiyama M, et al. The Influence of Lifestyle and Health Status Factors on Sleep Loss Among the Japanese General Population. Sleep. 2001;24(3):333-8. [pmid: 11322717].
169 Olson LG. A community survey of insomnia in Newcastle. Aust N Z J Pub Health. 1996;20(6):655-7. [pmid: 9117975].
170 Owens JF, Matthews KA. Sleep disturbance in healthy middle-aged women. Maturitas. 1998;30(1):41-50. [pmid: 9819782].
171 Pallesen S, Nordhus IH, Nielsen GH, et al. Prevalence of insomnia in the adult Norwegian population. Sleep. 2001;24(7):771-9. [pmid: 11683480].
172 Partinen M, Eskelinen L, Tuomi K. Complaints of insomnia in different occupations. Scand J Work Environ Health. 1984;10(6):467-9. [pmid: 6535249].
173 Piani A, Brotini S, Dolso P, et al. Sleep disturbances in elderly: A subjective evaluation over 65. Arch Gerontol Geriatr. 2004;38(Suppl):325-31.
174 Piccione P, Tallarigo R, Zorick F, et al. Personality differences between insomniac and non-insomniac psychiatry outpatients. J Clin Psychiatry. 1981;42(7):261-3. [pmid: 7240111].
175 Pollak CP, Perlick D, Linsner JP, et al. Sleep problems in the community elderly as predictors of death and nursing home placement. J Community Health. 1990;15(2):123-35. [pmid: 2355110].
176 Quera-Salva MA, Orluc A, Goldenberg F, et al. Insomnia and use of hypnotics: Study of a French population. Sleep. 1991;14(5):386-391. [pmid: 1759090].
177 Redeker NS, Lev EL, Ruggiero J. Insomnia, fatigue, anxiety, depression, and quality of life of cancer patients undergoing chemotherapy. Sch Inq Nurs Pract 2000; 14(4):275–90; 291–8.
178 Reimao R, Souza JC, Gaudioso CE, et al. Nocturnal sleep pattern in Native Brazilian Terena adults. Arq NeuroPsiquiatr. 2000;58(2A):233-8. [pmid: 10849620].
179 Reynolds CTL, Sewitch DE, Restifo K, et al. Persistent psychophysiologic insomnia: Preliminary research diagnostic criteria and EEG sleep data. Am J Psychiatry. 1984;141(6):804-5. [pmid: 6731625].
180 Roberts RE, Shema SJ, Kaplan GA. Prospective data on sleep complaints and associated risk factors in an older cohort. Psychosom Med. 1999;61(2):188-96. [pmid: 10204972].
181 Roberts RE, Shema SJ, Kaplan GA, et al. Sleep complaints and depression in an aging cohort: A prospective perspective. Am J Psychiatry. 2000;157(1):81-8. [pmid: 10618017].
182 Robinson E, Richardson-Robinson F. Effects of Loss of Sleep (2). J Exp Psychol. 1922;5:93-100.
183 Roehrs T, Lineback W, Zorick F, et al. Relationship of psychopathology to insomnia in the elderly. J Am Geriatr Soc. 1982;30(5):312-5. [pmid: 7077007].
184 Rubinstein ML, Selwyn PA. High prevalence of insomnia in an outpatient population with HIV infection. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;19(3):260-5. [pmid: 9803968].
185 Rumble R, Morgan K. Hypnotics, sleep, and mortality in elderly people. J Am Geriatr Soc. 1992;40(8):787-91. [pmid: 1634722].
186 Sadler M. Lamotrigine associated with insomnia. Epilepsia. 1999;40(3):322-5. [pmid: 10080513].
187 Schubert CR, Cruickshanks KJ, Dalton DS, et al. Prevalence of sleep problems and quality of life in an older population. Sleep. 2002;25(8):889-93. [pmid: 12489896].
188 Seppala M, Hyyppa MT, Impivaara O, et al. Subjective quality of sleep and use of hypnotics in an elderly urban population. Aging Clin Exp Res. 1997;9(5):327-34.
189 Shute GE, Fitzgerald SG. Cognitive developmental level and sleep-onset insomnia. Percept Mot Skills. 1988;67(2):470. [pmid: 3217194].
190 Simon GE, VonKorff M. Prevalence, burden, and treatment of insomnia in primary care. Am J Psychiatry. 1997;154(10):1417-23. [pmid: 9326825].
191 Sukying C, Bhokakul V, Udomsubpayakul U. An epidemiological study on insomnia in an elderly Thai population. J Med Assoc Thai. 2003;86(4):316-24. [pmid: 12757075].
192 Sutton DA, Moldofsky H, Badley EM. Insomnia and health problems in Canadians. Sleep. 2001;24(6):665-70. [pmid: 11560179].
193 Sweetwood HL, et al. Sleep disorder over time: Psychiatric correlates among males. Br J Psychiatry. 1980;136:456-62. [pmid: 7388250].
194 Tabernero C, Polo JM, Sevillano MD, et al. Fatal familial insomnia: clinical, neuropathological, and genetic description of a Spanish family. J Neurol Neurosurg Psychiatry. 2000;68(6):774-7. [pmid: 10811705]. [pmcid: 1736952].
195 Tachibana H, Izumi T, Honda S, et al. A study of the impact of occupational and domestic factors on insomnia among industrial workers of a manufacturing company in Japan. Occup Med (Oxford). 1996;46(3):221-7.
196 Tandberg E, Larsen JP, Karlsen K. A community-based study of sleep disorders in patients with Parkinson's disease. Mov Disord. 1998;13(6):895-9. [pmid: 9827612].
197 Tani P, Lindberg N, Nieminen-von Wendt T, et al. Insomnia is a frequent finding in adults with Asperger syndrome. BMC Psychiatry. 2003;3(1):12. [pmid: 14563215]. [pmcid: 270035].
198 Unger ER, Nisenbaum R, Moldofsky H, et al. Sleep assessment in a population-based study of chronic fatigue syndrome. BMC Neurol. 2004;4(1):6. [pmid: 15096280]. [pmcid: 419502].
199 Walker S, Fine A, Kryger MH. Sleep complaints are common in a dialysis unit. Am J Kidney Dis. 1995;26(5):751-6. [pmid: 7485127].
200 Walsh JK, Engelhardt CL. The direct economic costs of insomnia in the United States for 1995. Sleep. 1999;22(Suppl 2):S386-93. [pmid: 10394612].
201 Watts FN, Coyle K, East MP. The contribution of worry to insomnia. Br J Clin Psychol. 1994;33(2):211-20. [pmid: 8038740].
202 Weissman MM, Greenwald S, Nino-Murcia G, et al. The morbidity of insomnia uncomplicated by psychiatric disorders. Gen Hosp Psychiatry. 1997;19(4):245-20. [pmid: 9327253].
203 Weyerer S, Dilling H. Prevalence and treatment of insomnia in the community: results from the Upper Bavarian Field Study. Sleep. 1991;14(5):392-8. [pmid: 1759091].
204 Wiegand M, Moller AA, Lauer CJ, et al. Nocturnal sleep in Huntington's disease. J Neurol. 1991;238(4):203-8. [pmid: 1832711].
205 Wilson C, Lack L. Sleeping habits of people living in the Adelaide metropolitan area: A telephone survey. Aust Psychol. 1983;18(3):369-76.
206 Yasuma F, Okada T. Sleep disturbances complicated with surgical stress. A questionnaire survey in 50 patients. Jpn J Anesthesiol. 1989;38(1):66-70.
207 Yee B, Campbell A, Beasley R, et al. Sleep disorders: A potential role in New Zealand motor vehicle accidents. Int Med J. 2002;32(7):297-304.
208 Young T, Rabago D, Zgierska A, et al. Objective and subjective sleep quality in premenopausal, perimenopausal, and postmenopausal women in the Wisconsin Sleep Cohort Study. Sleep. 2003;26(6):667-72. [pmid: 14572118].

### Excluded - Outcomes (Irrelevant)

The following studies were excluded because they did not report on any of the outcomes of this review.

1 Agnew H, Webb WB. Sleep latencies in human subjects: Age, prior wakefulness, and reliability. Psychon Sci. 1971;24(6):253-4.
2 Alapin I, Libman E, Bailes S, et al. Role of nocturnal cognitive arousal in the complaint of insomnia among older adults. Behav Sleep Med. 2003;1(3):155-70. [pmid: 15600219].
3 Asplund R, Aberg H. Sleep complaints in women of ages 40–64 years in relation to sleep in their parents. Sleep Med. 2001;2(3):233-7. [pmid: 11311686].
4 Azad N, Byszewski A, Sarazin FF-A, et al. Hospitalized patients' preference in the treatment of insomnia: Pharmacological versus non-pharmacological. Can J Clin Pharmacol. 2003;10(2):89-92. [pmid: 12879147].
5 Backhaus J, Junghanns K, Hohagen F. Sleep disturbances are correlated with decreased morning awakening salivary cortisol. Psychoneuroendocrinol. 2004;29(9):1184-91.
6 Barnas C, Whitworth AB, Fleischhacker WW. Are patterns of benzodiazepine use predictable? A follow-up study of benzodiazepine users. Psychopharmacol. 1993;111(3):301-5.
7 Bastien CH, LeBlanc M, Carrier J, et al. Sleep EEG power spectra, insomnia, and chronic use of benzodiazepines. Sleep. 2003;26(3):313-7. [pmid: 12749551].
8 Bastien CH, Morin CM. Familial incidence of insomnia. J Sleep Res. 2000;9(1):49-54. [pmid: 10733689].
9 Bonato RA. Electroencephalographic correlates of sleep onset in chronic psychophysiological insomniacs and normal sleepers. Ottawa (ON): Carleton University; 1998.
10 Brassington GS. Insomnia and styles of parental authority in college students. Psychol Rep. 1994;74(3, Pt 1):712-14. [pmid: 8058850].
11 Buhr A, Bianchi MT, Baur R, et al. Functional characterization of the new human GABA(A) receptor mutation beta3(R192H). Hum Genet. 2002;111(2):154-60. [pmid: 12189488].
12 Cheek RE, Shaver JK, Lentz MJ. Lifestyle practices and sleep in women with and without insomnia... 35th Annual Communicating Nursing Research Conference/16th Annual WIN Assembly, “Health Disparities: Meeting the Challenge,” held April 18–20, 2002, Palm Springs, California. Commun Nurs Res. 2002;35(10):393.
13 Cheek RE, Shaver JL, Lentz MJ. Variations in sleep hygiene practices of women with and without insomnia. Res Nurs Health. 2004;27(4):225-36. [pmid: 15264262].
14 Chevalier H, Los F, Boichut D, et al. Evaluation of severe insomnia in the general population: results of a European multinational survey. J Psychopharmacol. 1999;13(4 Suppl 1):S21-4. [pmid: 10667452].
15 Cortelli P, Perani D, Parchi P, et al. Cerebral metabolism in fatal familial insomnia: relation to duration, neuropathology, and distribution of protease-resistant prion protein. Neurol. 1997;49(1):126-33.
16 Cortelli P, Polinsky R, Montagna P, et al. Alteration of the serotoninergic system in fatal familial insomnia [1]. Ann Neurol. 2001;50(3):421-2. [pmid: 11558802].
17 Coursey RD, Frankel BL. Novelty-seeking, fantasy, and sensitization in chronic insomniacs. Percept Mot Skills. 1977;44(3 Pt 1):795-8. [pmid: 876789].
18 Currie SR, Clark S, Rimac S, et al. Comprehensive Assessment of Insomnia in Recovering Alcoholics Using Daaily Sleep Diaries and Ambulatory Monitoring. Alcohol -Clin Exp Res. 2003;27(8):1262-9. [pmid: 12966320].
19 Ellis J, Hampson SE, Cropley M. Sleep hygiene or compensatory sleep practices: An examination of behaviours affecting sleep in older adults. Psychol Health Med. 2002;7(2):157-62.
20 Fast A, Hertz G. Nocturnal low back pain in pregnancy: Polysomnographic correlates. Am J Reprod Immunol. 1992;28(34):251-3. [pmid: 1285894].
21 Gaillard JM. Chronic primary insomnia: possible physiopathological involvement of slow wave sleep deficiency. Sleep. 1978;1(2):133-47. [pmid: 227028].
22 Gaillard JM. Is insomnia a disease of slow-wave sleep?. Eur Neurol. 1976;14(6):473-84. [pmid: 186267].
23 Goder R, Friege L, Fritzer G, et al. Morning headaches in patients with sleep disorders: A systematic polysomnographic study. Sleep Med. 2003;4(5):385-91. [pmid: 14592279].
24 Harvey AG. Beliefs about the utility of presleep worry: An investigation of individuals with insomnia and good sleepers. Cogn Ther Res. 2003;27(4):403-14.
25 Harvey AG. Sleep hygiene and sleep-onset insomnia. J Nerv Ment Dis. 2000;188(1):53-5. [pmid: 10665463].
26 Harvey L, Inglis SJ, Espie CA. Insomniacs' reported use of CBT components and relationship to long-term clinical outcome. Behav Res Ther. 2002;40(1):75-83. [pmid: 11762429].
27 Hauri PJ. A cluster analysis of insomnia. Sleep. 1983;6(4):326-38. [pmid: 6665395].
28 Irwin M, Clark C, Kennedy B, et al. Nocturnal catecholamines and immune function in insomniacs, depressed patients, and control subjects. Brain Behav Immun. 2003;17(5):365-72. [pmid: 12946658].
29 Kales A, Bixler EO, Tan TL, et al. Chronic hypnotic-drug use. Ineffectiveness, drug-withdrawal insomnia, and dependence. J Am MedAssoc. 1974;227(5):513-7.
30 Kales A, Bixler EO, Vela-Bueno A, et al. Biopsychobehavioral correlates of insomnia, III: Polygraphic findings of sleep difficulty and their relationship to psychopathology. Int J Neurosci. 1984;23(1):43-55. [pmid: 6724816].
31 Kales A, Scharf MB, Kales JD. Rebound insomnia: a new clinical syndrome. Science. 1978;201(4360):1039-41. [pmid: 684426].
32 Karadeniz D, Ondze B, Besset A, et al. Are periodic leg movements during sleep (PLMS) responsible for sleep disruption in insomnia patients?. Eur J Neurol. 2000;7(3):331-6. [pmid: 10886318].
33 Mariotti P, Della Marca G, Iuvone L, et al. Sleep disorders in Sanfilippo syndrome: a polygraphic study. Clin Electroencephal. 2003;34(1):18-22.
34 Medori R, Tritschler HJ, LeBlanc A, et al. Fatal familial insomnia, a prion disease with a mutation at codon 178 of the prion protein gene. N Engl J Med. 1992;326(7):444-9. [pmid: 1346338].
35 Mendelson WB. Long-term follow-up of chronic insomnia. Sleep. 1995;18(8):698-701. [pmid: 8560137].
36 Mendelson WB. Are periodic leg movements associated with clinical sleep disturbance?. Sleep. 1996;19(3):219-23. [pmid: 8723379].
37 Mendelson WB, Garnett D, Linnoila M. Do insomniacs have impaired daytime functioning?. Biol Psychiatry. 1984;19(8):1261-4. [pmid: 6498247].
38 Morin CM, Stone J, Trinkle D, et al. Dysfunctional beliefs and attitudes about sleep among older adults with and without insomnia complaints. Psychol Aging. 1993;8(3):463-7. [pmid: 8216967].
39 Morris M, Lack L, Dawson D. Sleep-onset insomniacs have delayed temperature rhythms. Sleep. 1990;13(1):1-14. [pmid: 2305166].
40 Nowell PD, Buysse DJ, Reynolds CF 3rd, et al. Clinical factors contributing to the differential diagnosis of primary insomnia and insomnia related to mental disorders. Am J Psychiatry. 1997;154(10):1412-6. [pmid: 9326824].
41 Ohayon MM, Zulley J. Correlates of global sleep dissatisfaction in the German population. Sleep. 2001;24(7):780-7. [pmid: 11683481].
42 Perlis ML, Kehr EL, Smith MT, et al. Temporal and stagewise distribution of high frequency EEG activity in patients with primary and secondary insomnia and in good sleeper controls. J Sleep Res. 2001;10(2):93-104. [pmid: 11422723].
43 Perlis ML, Smith MT, Andrews PJ, et al. Beta/Gamma EEG activity in patients with primary and secondary insomnia and good sleeper controls. Sleep. 2001;24(1):110-7. [pmid: 11204046].
44 Pollak CP, Perlick D, Linsner JP. Daily sleep reports and circadian rest-activity cycles of elderly community residents with insomnia. Biol Psychiatry. 1992;32(11):1019-27. [pmid: 1467382].
45 Riedel BW, Lichstein KL. Objective sleep measures and subjective sleep satisfaction: how do older adults with insomnia define a good night's sleep?. Psychol Aging. 1998;13(1):159-63. [pmid: 9533198].
46 Saletu-Zyhlarz GM, Anderer P, Berger P, et al. Nonorganic insomnia in panic disorder: Comparative sleep laboratory studies with normal controls and placebo-controlled trials with alprazolam. Hum Psychopharmacol. 2000;15(4):241-54. [pmid: 12404319].
47 Schneider-Helmert D, Whitehouse I, Kumar A, et al. Insomnia and alpha sleep in chronic non-organic pain as compared to primary insomnia. Neuropsychobiol. 2001;43(1):54-8.
48 Souza JC, Magna LA, Reimao R. Insomnia and hypnotic use in Campo Grande general population, Brazil. Arq Neuropsiquiatr. 2002;60(3-B):702-7. [pmid: 12364933].
49 Staner L, Cornette F, Maurice D, et al. Sleep microstructure around sleep onset differentiates major depressive insomnia from primary insomnia. J Sleep Res. 2003;12(4):319-30. [pmid: 14633244].
50 Stepanski E, Zorick F, Roehrs T, et al. Daytime alertness in patients with chronic insomnia compared with asymptomatic control subjects. Sleep. 1988;11(1):54-60. [pmid: 3363270].
51 Takekawa H, Kubo J, Miyamoto T, et al. Amyotrophic lateral sclerosis associated with insomnia and the aggravation of sleep-disordered breathing. Psychiatry Clin Neurosci. 2001;55(3):263-4. [pmid: 11422868].
52 Terashima K, Mikami A, Tachibana N, et al. Sleep characteristics of menopausal insomnia: a polysomnographic study. Psychiatry Clin Neurosci. 2004;58(2):179-85. [pmid: 15009824].
53 Vallieres A, Morin CM. Actigraphy in the assessment of insomnia. Sleep. 2003;26(7):902-6. [pmid: 14655927].
54 Vanable PA, Aikens JE, Tadimeti L, et al. Sleep latency and duration estimates among sleep disorder patients: variability as a function of sleep disorder diagnosis, sleep history, and psychological characteristics. Sleep. 2000;23(1):71-9. [pmid: 10678467].
55 Vgontzas AN, Tsigos C, Bixler EO, et al. Chronic insomnia and activity of the stress system: a preliminary study. J Psychosom Res. 1998;45(1 Spec No):21-31. [pmid: 9720852].
56 Voderholzer U, Al-Shajlawi A, Weske G, et al. Are there gender differences in objective and subjective sleep measures? A study of insomniacs and healthy controls. Depress Anxiety. 2003;17(3):162-72. [pmid: 12768650].
57 Walsh JK, Schweitzer PK. Ten-year trends in the pharmacological treatment of insomnia. Sleep. 1999;22(3):371-5. [pmid: 10341388].
58 Zorick FJ, Roth T, Hartze KM, et al. Evaluation and diagnosis of persistent insomnia. Am J Psychiatry. 1981;138(6):769-73. [pmid: 7246806].

### Excluded - Outcomes (Inadequate Reporting)

The following study was excluded because data relevant to the outcomes of interest were inadequately reported.

1 Winett CA. The mediating role of insomnia in the relation between life events and depression and mania. Miami (FL): University of Miami; 2001.

### References

Five hundred and fifty six studies were excluded for the question on management of chronic insomnia. The reasons for exclusion of studies were as follows: (1) the study was reported in a language other than English (n=27), (2) the report was a review/commentary/practice parameter (n=32), (3) the study report was a duplicate publication (n=3) (4) the study did not examine an adult population (n=17), (5) the study population did not suffer from chronic insomnia as defined in this report (n=221), (6) the study was not a randomized controlled trial (n=160), (7) the study did not have a placebo arm (n=48), (8) the study was not double-blind (n=15), (9) the study did not report on any of the outcomes of this review (n=18) and (10) the study outcomes were not adequately reported (n=15).

### Excluded - Non-English

The following studies were excluded because they were reported in a language other than English.

1 Altamura AC, Colacurcio F, Mauri MC, et al. Controlled clinical study on the effect of quazepam versus triazolam in patients with sleep disorders [Ital]. Minerva Psichiatr. 1989;30(3):159-64. [pmid: 2691808].
2 Bourin M, Andre-David F. Triazolam 0.25 mg versus loprazolam 1 mg in common insomnia treated by general practitioners (double blind cross-over randomized study). [Fr]. Therapie. 1989;44(2):107-14. [pmid: 2569239].
3 Buscaino GA, Steardo L. [Efficacy of the oral treatment with L-tryptophan in subjects with insomnia. Preliminary results]. [Italian]. Acta Neurologica. Jul-Aug. 1975;30(4):411-5. [pmid: 779409].
4 Carlini EA, Braz S, Troncone LR, et al. [Hypnotic effect of homeopathic medication and placebo. Evaluation by double-blind and crossing technics]. [Portuguese]. Amb; Revista Da Associacao Medica Brasileira. May-Jun. 1987;33(56):83-8. [pmid: 3329355].
5 Castellani A, Lescovelli M, Perbellini D. Clinical and EEG changes in sleep patterns after administration of N-demethyldiazepam to 25 psychiatric patients affected by insomnia. [Italian]. Lav Neuropsichiatr. 1975;56(1, Suppl 3):155-83.
6 de Anna M, Zucconi M, Baruzzi A, et al. Double blind trial of lormetazepam and flurazepam in the treatment of insomniacs. Farmaco Ed Prat. 1982;37:275-81.
7 Duriez R, Barthelemy C, Rives H, et al. Clinical trial of zopiclone in insomnia. Therapie London Paris. 1979;34(3):317-26.
8 Estivill-Sancho E, Jaraba G. The treatment of chronic insomnia: A program of creative relaxation and body consciousness as adjuvant of pharmacotherapy. [Spanish]. Psiquis: Revista de Psiquiatria, Psicologia y Psicosomatica. Vol 12(9) 1991, 52–57 Alpe Editores SA Spain 12 (9), 52–57 1991.
9 Ferrero F, Zahnd J. [Tryptophan in the treatment of insomnia in hospitalized psychiatric patients]. [French]. Encephale. Jan-Feb. 1987;13(1):35-7. [pmid: 3556145].
10 Friede M, Liske E, Woelk H, et al. Herbal agent for the treatment of insomnia. [German]. Tw Neurologie Psychiatrie. 1997;11(10):697-700.
11 Herberg KW, Laux G, Fischer W. Analysis of the effects of a 14 days treatment with zopiclone 7.5mg/d on performance capability, actual well-being, and quality of sleep of patients with primary insomnia. [Germ]. Psychopharmakother. 2002;9(1):25-34.
12 Huang GG, Chen Q, Li L. Comparison between the effect of behavioral and drug therapy on the treatment of insomnia in patients with schizophrenia in rehabilitation period. [Chin]. Zhongguo Linchuang Kangfu. 2004;8(9):1628-9.
13 Ito E, Matsui T, Okada T, et al. A double-blind controlled trial of s-1530 in patients with insomnia. Rinsyoyakuri. 1973;4(2):61-75.
14 Ito H, Yagi G, Tateyama M, et al. Clinical evaluation of flunitrazepam on insomnia in neuropsychiatric field: a comparative double-blind cross-over study with nitrazepam. Rinsho Hyoka (Clin Eval). 1981;9(3):733-67.
15 Kobayashi R, Ito K, Hirabayashi Y, et al. Effectiveness of zopiclone (27 267 r so:p.) In insomnia: multi-center double-blind study in comparison with flurazepam (the second report). Rinsho Hyoka (Clin Eval). 1986;14:77-108.
16 Kurihara M, Jinbo M, Hirose T, et al. A study of the clinical efficacy of triazolam on insomnia -Double-blind cross-over study among the smaller and larger doses of triazolam, and flurazepam. Rinsho Hyoka (Clin Eval). 1980;8(1):79-110.
17 Lan S, Deng M, Zhu X, et al. Relaxation training and sleep related behavior modification in patients with insomnia. [Chin]. Chin Ment Health J. 2002;16(9):625-7.
18 Levin I. “Music of the Brain” in the treatment of insomnia patients. [Rus]. Zh Nevropatol Psikhiatr Im S S Korsakova. 1997;97(4):39-43.
19 Li LH, Chen JD, Zhao JP, et al. Zaleplon vs zolpidem in treatment of insomnia: a multicenter, randomized, double-blind controlled clinical trial. Zhongguo Xinyao Yu Linchuang Zazhi. 2003;22(11):667-70.
20 Massot JE, Toblli JE. Double-blind study by comparing the effect of triazolam and nitrazepam on the sleep of usual insomniac patients. Prensa Med Argent. 1983;70(8):340-5.
21 Montakab H. [Acupuncture and insomnia]. [German]. Forschende Komplementarmedizin. 6 Suppl 1:29–31, 1999 Feb 1(6), 29–31.
22 Rocha FL, Paprocki J, Bustamante LS, et al. Double-blind, randomized, comparative study between zopiclone (Imovane) and flunitrazepam (Rohypnol) in chronic insomniac patients. [Portuguese]. J Brasil Psiquiatr. 1991;40(4):199-215.
23 Ruther E, Clarenbach P, Hajak G, et al. Zopiclone in patients with disturbed sleep. Impact on sleep quality and day-time wellbeing in comparison of flunitrazepam, triazolam and placebo. [German]. Munch Med Wochenschr. 1992;134(46):59-65.
24 Schadeck B, Chelly M, Amsellem D, et al. Comparative efficacy of doxylamine (15 mg) and zolpidem (10 mg) for the treatment of common insomnia. A placebo-controlled study. [Fr]. Semaine Hopitaux. 1996;72(1314):428-39.
25 Yamamura Y, Kokubu T, Ueda E, et al. Clinical effects of lorazepam on insomnia in the field of internal medicine -evaluated by double blind study using nitrazepam and placebo as control drugs. Rinsho Hyoka (Clin Eval). 1978;6(2):201-21.
26 Zhang H, Shen Y, Liu N, et al. Effect and reliability of zaleplon on treatment of insomnia: A randomized, double-blind, control study. [Chin]. Zhongguo Linchuang Kangfu. 2004;8(18):3488-90.
27 Zhou CL, Xie HJ, Wang LQ. Paroxetine in treatment of primary insomnia. Zhongguo Xinyao Yu Linchuang Zazhi. 2002;21(8):481-4.

### Excluded - Review/Commentary/Practice Parameter

The following studies were excluded because they were reviews/commentaries/practice parameters.

1 Agargun MY, Kara H, Ozbek H, et al. Restless legs syndrome induced by mirtazapine. J Clin Psychiatry. 2002;63(12):1179. [pmid: 12530413].
2 Allain H, Milon D, van den Driessche J. Clinical pharmacology of hypnotics. Therapie - London Paris. 1984;39(1):13-6.
3 Barker MJ, Jackson M, Greenwood KM, et al. Cognitive effects of benzodiazepine use: A review. Aust Psychol. 2003;38(3):202-13.
4 Belleville G, Morin CM. Cognitive-behavioral treatment of insomnia secondary to chronic pain. [Fr]. Doul Analg. 2003;16(2):111-16.
5 Berger M, Van Calker D, Riemann D. Sleep and manipulations of the sleep-wake rhythm in depression. Acta Psychiatr Scand. 2003;108(418, Suppl):83-91. [pmid: 12823164].
6 Bootzin RR, Perlis ML. Nonpharmacologic treatments of insomnia. J Clin Psychiatry. 1992;53(6 Suppl):37-41. [pmid: 1613018].
7 Campbell SS, Terman M, Lewy A, et al. Light treatment for sleep disorders: Consensus report. V. Age-related disturbances. J Biol Rhythms. 1995;10(2):151-4. [pmid: 7632988].
8 Chesson ALJ, Littner M, Davila D, et al. Practice parameters for the use of light therapy in the treatment of sleep disorders. Sleep. 1999;22(5):641-60. [pmid: 10450599].
9 Dall JV. Promoting sleep with therapeutic touch. Addict Nurs Network. 1993;5(1):23-4.
10 Doan RJ. Risperidone for insomnia in PDDs. Can J Psychiatry. 1998;43(10):1050-1. [pmid: 9868572].
11 Dundar Y, Dodd S, Strobl J, et al. Comparative efficacy of newer hypnotic drugs for the short-term management of insomnia: a systematic review and meta-analysis. Hum Psychopharmacol. 2004;19(5):305-22. [pmid: 15252823].
12 Garfinkel D. For insomniacs: A way to break tranquilizer addiction. Health Facts. 1999;24(12):3.
13 Gillin JC, Mendelson WB, Dement WC, et al. Flurazepam and insomnia. Science. 1979;205(4410):954-5. [pmid: 38503].
14 Grad RM. Benzodiazepines for insomnia in community-dwelling elderly: a review of benefit and risk. J Fam Pract. 1995;41(5):473-81. [pmid: 7595266].
15 Hajak G, Cluydts R, Allain H, et al. The challenge of chronic insomnia: Is non-nightly hypnotic treatment a feasible alternative?. Eur Psychiatry. 2003;18(5):201-8. [pmid: 12927320].
16 Hirst A, Sloan R. Benzodiazepines and related drugs for insomnia in palliative care. The Cochrane Database of Systematic Reviews 2001 2001; 4(CD003346. DOI: 10.1002/14651853. CD003346).
17 Israel AG, Kramer JA. Safety of zaleplon in the treatment of insomnia. Ann Pharmacother. 2002;36:852-9. [pmid: 11978165].
18 James SP, Mendelson WB. The use of trazodone as a hypnotic: a critical review. J Clin Psychiatry. 2004;65(6):752-5. [pmid: 15291651].
19 Jonas JM, Coleman BS, Sheridan AQ, et al. Comparative clinical profiles of triazolam versus other shorter-acting hypnotics. J Clin Psychiatry. 1992;53(Suppl):19-31. [pmid: 1336776].
20 Jones CR, Czajkowski L. Evaluation and management of insomnia in menopause. Clin Obstet Gynecol. 2000;43(1):184-97. [pmid: 10694999].
21 Kales A, Bixler EO, Scharf M, et al. Sleep laboratory studies of flurazepam: a model for evaluating hypnotic drugs. Clin Pharmacol Ther. 1976;19(5 Pt 1):576-83. [pmid: 6180].
22 Kales A, Soldatos CR, Bixler EO, et al. Rebound insomnia and rebound anxiety: a review. Pharmacol. 1983;26(3):121-37.
23 Kales JD, Kales A, Soldatos CR. Quazepam: sleep laboratory studies of effectiveness and withdrawal. Clin Neuropharmacol. 1985;8(Suppl 1):S55-62. [pmid: 3837687].
24 Krystal AD, Walsh JK, Laska E, et al. The sustained 6-month efficacy of eszopiclone in the treatment of chronic insomnia. Sleep. 2004;27(2):346-7.
25 Larzelere MM, Wiseman P. Anxiety, depression, and insomnia. Prim Care. 2002;29(2):339-60. [pmid: 12391715].
26 Lee YJ. Overview of the therapeutic management of insomnia with zolpidem. CNS Drugs 2004; 18(41, Suppl 1):17–23; 43–5.
27 McCall WV, D'agostino R, Dunn A. A Meta-Analysis of Sleep Changes Associated With Placebo in Hypnotic Clinical Trials. Sleep Med. 2003;4(1):57-62. [pmid: 14592361].
28 Nicholson AN. Brotizolam: studies of effects on sleep and on performance in young adulthood and in middle age. Br J Clin Pharmacol. 1983;16(Suppl 2):S365-9.
29 Nishino S, Mignot E. Drug treatment of patients with insomnia and excessive daytime sleepiness: pharmacokinetic considerations.[erratum appears in Clin Pharmacokinet 2000 Jan;38(1):40]. Clin Pharmacokinet. 1999;37(4):305-30. [pmid: 10554047].
30 Pierce MW, Shu VS, Groves LJ. Safety of estazolam. The United States clinical experience. Am J Med. 1990;88(3A):12S-7S. [pmid: 1968713].
31 Stahl SM, Mendels J, Schwartz GE. Effects of reboxetine on anxiety, agitation, and insomnia: results of a pooled evaluation of randomized clinical trials. J Clin Psychopharmacol. 2002;22(4):388-92. [pmid: 12172338].
32 Trevena L. Sleepless in Sydney--is valerian an effective alternative to benzodiazepines in the treatment of insomnia?. ACP J Club. 2004;141(1):A14-6. [pmid: 15230562].

### Excluded - Duplicate Publication

The following studies were excluded because the report was a duplicate publication.

1 Demisch K, Bauer J, Georgi K, et al. Treatment of severe chronic insomnia with L-tryptophan: Results of a double-blind cross-over study. Pharmacopsychiatry. 1987;20(6):242-4. [pmid: 3432357].
2 Dominguez RA, Goldstein BJ, Jacobson AF, et al. Estazolam in the treatment of insomnia. Psychopharmacol Bull. 1986;22(1):278-80. [pmid: 2873616].
3 Dorn M. [Efficacy and tolerability of Baldrian versus oxazepam in non-organic and non-psychiatric insomniacs: a randomised, double-blind, clinical, comparative study]. [German]. Forschende Komplementarmedizin und Klassische Naturheilkunde. 2000;7(2):79-84. [pmid: 10899744].

### Excluded - Population (Non-Adult)

The following studies were excluded because they did not examine an adult population.

1 Cartwright RD, Weiss MF. The effects of electrosleep on insomnia revisited. J Nerv Ment Dise. 1975;161(2):134-7.
2 Cloos F, Creteur R, Defesche C, et al. Randomized double blind cross over patient preference studies comparing triazolam versus nitrazepam in insomnia. Acta Ther. 1977;3(1):73-89.
3 Cluydts R, Heyde K, De Volder I. Polysomnographic findings during non-continuous administration of zolpidem. Sleep Med Rev. 2002;6(Suppl 1):S13-9. [pmid: 12607572].
4 Gifford SD. A comparison of drug treatment for insomnia and the effect of causal attribution. Dallas (TX): North Texas State University. 1979.
5 Heffron WA, Roth P. Double-blind evaluation of the safety and hypnotic efficacy of temazepam in insomniac outpatients. Br J Clin Pharmacol. 1979;8(1):S69-72.
6 Jasovic G M, Nikolic B G., Kuzmanovic V et al. The effects of benzodiazepines uhypnotics on performance and recent memory during the therapy of insomnia in schizophrenic patients. Proceedings of the 9th ECNP (European-College-of-Neuropsychopharmacology) Congress; 1996 Sep 23; Amsterdam, The Netherlands. Oxford University Press, New York 1996:S1–213–4.
7 Kales A, Kales JD, Bixler EO, et al. Hypnotic efficacy of triazolam: sleep laboratory evaluation of intermediate-term effectiveness. J Clin Pharmacol. 1976;16(89):399-406. [pmid: 184118].
8 Kales A, Scharf MB, Kales JD. Rebound insomnia: a new clinical syndrome. Science. 1978;201(4360):1039-41. [pmid: 684426].
9 Kudo Y, Kurihara M. Clinical evaluation of diphenhydramine hydrochloride for the treatment of insomnia in psychiatric patients: double blind study. J Clin Pharmacol. 1990;30:1041-8. [pmid: 2243152].
10 Levin Y. “Brain music” in the treatment of patients with insomnia. Neurosci Behav Physiol. 1998;28(3):330-5. [pmid: 9682240].
11 Minzi A, Celeste M, Ciampini M. Lormetazepam as a hypnoinducing drug: A multicenter national survey. Curr Ther Res. 1985;38(2):183-95.
12 Scharf MB. Feasibility of an every-other-night regimen in insomniac patients: subjective hypnotic effectiveness of quazepam, triazolam, and placebo. J Clin Psychiatry. 1993;54(1):33-8. [pmid: 8428895].
13 Schoicket S. Meditation training and stimulus control as treatments for sleep-maintenance insomnia. St. Louis (MO) Washington University. 1987.
14 Seigenberg R. Combined treatment approach to sleep onset insomnia: Objective measurement by subject monitoring of recorded sounds. Salt Lake City (UT) Brigham Young University. 1985.
15 Uhthoff H, Brunet J, Aggerwal A, et al. A clinical study of Quazepam in hospitalized patients with insomnia. J Int Med Res. 1981;9(4):288-91. [pmid: 6114885].
16 Weiss MF. The treatment of insomnia through the use of electrosleep: an EEG study. J Nerv Ment Dis. 1973;157(2):108-20. [pmid: 4146811].
17 Willis CS. Effects of problem-solving and relaxation treatments for insomnia on sleep-onset latency and cognitive arousal prior to sleep. Panama City (FL): Florida State University. 1991.

### Excluded - Population (Not Chronic Insomnia)

The following studies were excluded because the participants did not suffer from chronic insomnia as defined in this report.

1 Adam K, Oswald I. Can a rapidly-eliminated hypnotic cause daytime anxiety?. Pharmacopsychiatry. 1989;22(3):115-9. [pmid: 2748714].
2 Aivazian G. Clinical evaluation of diazepam. Dis Nerv Syst. 1964;25:491-6. [pmid: 14199198].
3 Akpinar S. Restless legs syndrome treatment with dopaminergic drugs. Clin Neuropharmacol. 1987;10(1):69-79. [pmid: 3545461].
4 Alberts MS, Anderson RH, Greaves DW, et al. Affective-state changes during short-term treatment of insomnia with triazolam. Curr Ther Res. 1987;41:746-50.
5 Alexander N, Baldwin RJJ, Cranfield R, et al. Comparison of triazolam (Halcion) and flurazepam (Dalmane) for the treatment of insomnia in general practice. A United Kingdom multicentre study. Clin Trials J. 1984;21(6):371-7.
6 Allain H, Bentue-Ferrer D, Le Breton S, et al. Preference of Insomniac Patients Between a Single Dose of Zolpidem 10 Mg Versus Zaleplon 10 Mg. Hum Psychopharmacol - Clin Exp. 2003;18(5):369-74.
7 Allain H, Bentue-Ferrer D, Tarral A, et al. Effects on postural oscillation and memory functions of a single dose of zolpidem 5 mg, zopiclone 3.75 mg and lormetazepam 1 mg in elderly healthy subjects. A randomized, cross-over, double-blind study versus placebo. Eur J Clin Pharmacol. 2003;59(3):179-88. [pmid: 12756510].
8 Alperson J, Biglan A. Self administered treatment of sleep onset insomnia and the importance of age. Behav Ther. 1979;10(3):347-56.
9 Ananth JV, Bronheim LA, Klingner A, et al. Diazepam in the treatment of insomnia in psychiatric patients. Curr Ther Res. 1973;15:217-22. [pmid: 4633283].
10 Ancolio C, Tardieu S, Soubrouillard C, et al. A Randomized Clinical Trial Comparing Doses and Efficacy of Lormetazepam Tablets or Oral Solution for Insomnia in a General Practice Setting. Hum Psychopharmacol Clin Exper. 2004;19(2):129-34.
11 Andersen T, Lingjaerde O. Nitrazepam (Mogadon) as a sleep-inducing agent. An analysis based on a double-blind comparison with phenobarbitone. Br J Psychiatry. 1969;115(529):1393-7. [pmid: 4902186].
12 Anderson AA. Zopiclone and nitrazepam: a multicenter placebo controlled comparative study of efficacy and tolerance in insomniac patients in general practice. Sleep. 1987;10(Suppl 1):54-62. [pmid: 3326116].
13 Andrade CS. Melatonin in medically ill patients with insomnia: a double-blind, placebo-controlled study. J Clin Psychiatry. 2001;62(1):41-5. [pmid: 11235927].
14 Anonymous. Clinical evaluation of flurazepam. J Clin Pharmacol New Drugs 1972; 12:217–20.
15 Anonymous. A randomized controlled trial of amantadine in fatigue associated with multiple sclerosis. The Canadian MS Research Group. Can J Neurol Sci Aug; 14(3): 273–8.
16 Ansfield ME, Wegner DM, Bowser R. Ironic effects of sleep urgency. Behav Res Ther. 1996;34(7):523-31. [pmid: 8826759].
17 Ansoms S, Lebon O, Pelc I et al. Zopiclone or lormetazepam in the treatment of insomnia and the effect on behavior and mood in patients during the postalcoholism withdrawal period. Curr Ther Res 1991; 49(154–64).
18 Ansseau M, Diricq S. Lormetazepam and amobarbital sodium in the outpatient treatment of insomnia: a controlled trial. Clin Ther. 1983;5(4):365-76. [pmid: 6135507].
19 Armitage R, Yonkers K, Cole D, et al. A multicenter, double-blind comparison of the effects of nefazodone and fluoxetine on sleep architecture and quality of sleep in depressed outpatients. J Clin Psychopharmacol. 1997;17(3):161-8. [pmid: 9169959].
20 Armitage R, Yonkers K, Rush A et al. No pub Comparison of the effects of nefazodone and fluoxetine on sleep architecture and sleep efficiency in depressed patients. Conf Abstr. Proceedings of the 8th Eur Coll Neuropsychopharmacol Congress. 1995 Sep 30 – Oct 4; Venice, Italy. 1995; 5(3):??
21 Arriaga F, Cavaglia F, Pires A, et al. Effects of trazodone on insomnia and anxiety in depressed patients: A clinical and sleep EEG study. Int J Psychiatry Clin Prac. 1997;1(4):281-86.
22 Ascher L, Michael E, Jay S. Use of paradoxical intention in a behavioral program for sleep onset insomnia. J Consult Clin Psychol. 1978;46(3):547-50. [pmid: 670496].
23 Baiotti G. Comparative trial of a new hypnotic (Finorgal) with nitrazepam and triclofos sodium. J Int Med Res. 1979;7(5):383-6. [pmid: 387491].
24 Bamford CR, Sandyk R. Failure of clonidine to ameliorate the symptoms of restless legs syndrome. Sleep. 1987;10(4):398-99. [pmid: 3659738].
25 Barabasz AF. Treatment of insomnia in depressed patients by hypnosis and cerebral electrotherapy. Am J Clin Hypnosis. 1976;19(2):120-22.
26 Baskett JJ, Broad JB, Wood PC, et al. Does melatonin improve sleep in older people? A randomised crossover trial. Age Ageing. 2003;32(2):164-70. [pmid: 12615559].
27 Bersani G, Garavini A. Melatonin add-on in manic patients with treatment resistant insomnia. Prog NeuroPsychopharmacol Biol Psychiatry. 2000;24(2):185-91. [pmid: 10800742].
28 Biondi F, Casadei GL. Results of a multicenter trial with the hypnotic zolpidem in 1152 insomniac patients. Curr Ther Res. 1994;55(3):262-74.
29 Bixler EO, Kales A, Tan TL, et al. The effects of hypnotic drugs on performance. Curr Ther Res Clin Exper. 1973;15(1):13-24. [pmid: 4631377].
30 Bongenaar TCT, Danhof G, Doesborgh HLW, et al. Results of a multicentre, double-blind study under general practice conditions with the new hypnotic, lormetazepam. Curr Ther Res Clin Exper. 1985;38(2):204-14.
31 Bonnet MH, Arand DL. Situational insomnia: Consistency, predictors, and outcomes. Sleep. 2003;26(8):1029-36. [pmid: 14746386].
32 Bonnet MH, Kramer M. The interaction of age, performance and hypnotics in the sleep of insomniacs. J Am Geriatr Soc. 1981;29(11):508-12. [pmid: 7299009].
33 Borkovec TD, Fowles DC. Controlled investigation of the effects of progressive and hypnotic relaxation on insomnia. J Abnorm Psychol. 1973;82(1):153-8. [pmid: 4730647].
34 Borkovec TD, Grayson JB, O'Brien GT, et al. Relaxation treatment of pseudoinsomnia and idiopathic insomnia: an electroencephalographic evaluation. J Appl Behav Anal. 1979;12(1):37-54. [pmid: 381276]. [pmcid: 1311348].
35 Borkovec T, Steinmark SW, Nau SD. Relaxation training and single-item desensitization in the group treatment of insomnia. J Behav Ther Exper Psychiatry. 1973;4(4):401-3.
36 Boyd DH, Ankier SI. A clinical trial of a new hypnotic--loprazolam. Br J Clin Pract. 1983;37(4):143-8. [pmid: 6136294].
37 Brusca D. Clinical study of cycloheptenylethylbarbiturate (medomin) for insomnia. J Nerv Ment Dis. 1955;121:67-71. [pmid: 14368316].
38 Buguet AG, Roussel BH, Watson WJ, et al. Cold-induced diminution of paradoxical sleep in man. Electroencephal Clin Neurophysiol. 1979;46(1):29-32.
39 Buysse DJ, Reynolds CF 3rd, Houck PR, et al. Does lorazepam impair the antidepressant response to nortriptyline and psychotherapy?. J Clin Psychiatry. 1997;58(10):426-32. [pmid: 9375592].
40 Carrera RN, Elenewski JJ. Implosive therapy as a treatment for insomnia. J Clin Psychol. 1980;36(3):729-34. [pmid: 7410572].
41 Carskadon MA, Dement WC. Effects of total sleep loss on sleep tendency. Percept Mot Skills. 1979;48(2):495-506. [pmid: 461051].
42 D'Cruz IA, Ramamoorthy K, Shanbhag SK, et al. Comparison of two non-barbiturate hypnotics--methaqualone hydrochloride and meprobamate; a double-blind controlled clinical trial. J Assoc Phys India. 1966;14(12):727-30.
43 Davies C, Levine S. A controlled comparison of nitrazepam (‘mogadon’) with sodium amylobarbitone as a sleep-inducing agent. Br J Psychiatry. 1967;113(502):1005-8. [pmid: 4862703].
44 Davison GC, Tsujimoto RN, Glaros AG. Attribution and the maintenance of behavior change in falling asleep. J Abnorm Psychol. 1973;82(1):124-33. [pmid: 4730643].
45 Day BH, Davis H, Parsons DW. An assessment of two hypnotics in the elderly. Clin Trials J. 1981;18(4):273-9.
46 de Jonghe F, Ameling EH, Jonkers F, et al. Flurazepam and temazepam in the treatment of insomnia in a general hospital population. Pharmacopsychiatry. 1984;17(4):133-5. [pmid: 6147866].
47 Declerck AC, Ruwe F, O'Hanlon JF, et al. Effects of zolpidem and flunitrazepam on nocturnal sleep of women subjectively complaining of insomnia [published erratum appears in ogy (Berl)1992;109(1–2):254]. Psychopharmacol. 1992;106(4):497-501.
48 Dehlin O, Bjornson G. Triazolam as a hypnotic for geriatric patients. A double-blind cross-over comparison of nitrazepam and triazolam regarding effects on sleep and psychomotor performance. Acta Psychiatr Scand. 1983;67(5):290-6. [pmid: 6135296].
49 deVries MW, Peeters FP. Melatonin as a therapeutic agent in the treatment of sleep disturbance in depression. J Nerv Ment Dis. 1997;185(3):201-2. [pmid: 9091602].
50 Disayavanish C, Srisurapanont M, Disayavanish P. Zopiclone in the treatment of insomnia: An open clinical trial. J Med Assoc Thai. 1998;81(6):393-6. [pmid: 9676070].
51 Dockhorn RJ, Dockhorn DW. Zolpidem in the treatment of short-term insomnia: a randomized, double-blind, placebo-controlled clinical trial. Clin Neuropharmacol. 1996;19(4):333-40. [pmid: 8828996].
52 Dominguez RA, Jacobson AF, Goldstein BJ, et al. Comparison of triazolam and placebo in the treatment of insomnia in depressed patients. Curr Ther Res. 1984;36:856-65.
53 Dorsey CM, Lukas SE, Teicher MH, et al. Effects of passive body heating on the sleep of older female insomniacs. J Geriatr Psychiatry Neurol. 1996;9(2):83-90. [pmid: 8736588].
54 Elie R, Caille G, Levasseur FA, et al. Comparative hypnotic activity of single doses of loprazolam, flurazepam, and placebo. J Clin Pharmacol. 1983;23:32-6. [pmid: 6132929].
55 Engle-Friedman M, Bootzin RR, Hazlewood L, et al. An evaluation of behavioral treatments for insomnia in the older adult. J Clin Psychol. 1992;48(1):77-90. [pmid: 1556221].
56 Erman MK, Loewy D, Scharf MB. Comparison of temazepam 7.5 mg with temazepam 15 mg for the treatment of transient insomnia. Curr Med Res Opin. 2004;20(4):441-9. [pmid: 15119980].
57 Evans JI, Lewis SA, Gibb IA, et al. Sleep and birbiturates: some experiments and observations. Br Med J. 1968;4(626):291-3. [pmid: 4301261]. [pmcid: 1912258].
58 Fabre LF, Metzler CM. Comparison of 0.25 mg of triazolam with 30 mg of flurazepam in the treatment of insomnia. Clin Ther. 1978;1(5):339-47.
59 Fabre LFJ, Gainey A, Kemple S, et al. Pilot open-label study of triazolam in the treatment of insomnia following alcohol withdrawal. J Stud Alcohol. 1977;38(11):2188-92. [pmid: 22780].
60 Fabre LJ, McLendon D, Harris R. Preference studies of triazolam with standard hypnotics in out patients with insomnia. J Int Med Res. 1976;4(4):247-54. [pmid: 16801].
61 Fabre LF Jr, Smith WT. Multi-clinic cross-over comparison of triazolam (Halcion) and placebo in the treatment of co-existing insomnia and anxiety in anxious out-patients. Dis Nerv Syst. 1977;38(6):487-91. [pmid: 16735].
62 Fabre LF, et al. Multi-clinic double-blind comparison of triazolam (Halcion(R)) and placebo administered for 14 consecutive nights in outpatients with insomnia. J Clin Psychiatry. 1978;39(8):679-82. [pmid: 28313].
63 Fischbach R. Efficacy and safety of midazolam and vesparax in treatment of sleep disorders. Br J Clin Pharmacol. 1983;16(Suppl 1):S167-171.
64 Fisher S, Gal P. Flurazepam versus amobarbital as a sedative-hypnotic for geriatric patients: double-blind study. J Am Geriatr Soc. 1969;17(4):397-9. [pmid: 4886875].
65 Fontaine R, Beaudry P, Le Morvan P, et al. Zopiclone and triazolam in insomnia associated with generalized anxiety disorder: a placebo-controlled evaluation of efficacy and daytime anxiety. Int Clin Psychopharmacol. 1990;5(3):173-83. [pmid: 2230061].
66 Frost JD, DeLucchi MR. Insomnia in the elderly: treatment with flurazepam hydrochloride. J Am Geriatr Soc. 1979;27:541-6. [pmid: 229146].
67 Gallais H, Casanova P, Fabregat H. Midazolam and oxazepam in the treatment of insomnia in hospitalized patients. Br J Clin Pharmacol. 1983;16(Suppl 1):S145-149.
68 Garcia HF, Figueroa E, De La Canal A, et al. Evaluation of a single daily dose of theophylline in asthmatic volunteers. [Sp]. Prensa Med Argent. 1993;80(8):610-15.
69 Garfinkel D, Zisapel Na, Wainstein J, et al. Facilitation of benzodiazepine discontinuation by melatonin: A new clinical approach. Arch Int Med. 1999;159(20):2456-60. [pmid: 10665894].
70 Gelinas B, Thorsteinson L, Lapierre YD. Placebo controlled assessment of quazepam as a hypnotic. Curr Ther Res. 1982;31(Sec 1):992-8.
71 Ghosh AK. Four-week tolerance study of chlormezanone for the treatment of insomnia in the elderly. J Int Med Res. 1982;10(6):431-6. [pmid: 7152083].
72 Gigli GL, Maschio MCE, Diomedi M, et al. Brotizolam and cognitive performance: A double-blind, crossover study versus placebo in a population of shift workers. Curr Ther Res. 1993;53(2):129-36.
73 Gigli GL, Moroni M, Visani L, et al. A pharmacoepidemiologic Italian multicenter study on the treatment of unselected insomniac patients with brotizolam. Curr Ther Res Clin Exp. 1991;50(5):652-66.
74 Gillin JC, Rapaport M, Erman MK, et al. A comparison of nefazodone and fluoxetine on mood and on objective, subjective, and clinician-rated measures of sleep in depressed patients: a double-blind, 8-week clinical trial.[erratum appears in J Clin Psychiatry 1997 Jun;58(6)275]. J Clin Psychiatry. 1997;58(5):185-92. [pmid: 9184611].
75 Globus G, Phoebus E, Humphries J, et al. The effect of lorazepam on anxious insomniacs' sleep as recorded in the home environment. J Clin Pharmacol. 1974;14(4):192-201. [pmid: 4362996].
76 Gnirss F, Schneider HD, Schenker J. L-tryptophan + oxprenolol: A new approach to the treatment of insomnia. Pharmakopsychiatr Neuropsychopharmakol. 1978;11(4):180-5. [pmid: 353833].
77 Gossop M, Bradley B. Insomnia among addicts during supervised withdrawal from opiates: a comparison of oral methadone and electrostimulation. Drug Alcohol Dep. 1984;13(2):191-8.
78 Gotestam KG, Oppoyen F, Berntzen D. Treatment of insomnia with two benzodiazepines: a double-blind crossover study. Eur J Clin Pharmacol. 1991;41(2):137-40. [pmid: 1743245].
79 Graham KR, Wright GW, Toman WJ, et al. Relaxation and hypnosis in the treatment of insomnia. Am J Clin Hypnosis. 1975;18(1):39-42.
80 Greenblatt DJ, Harmatz JS, Zinny MA, et al. Effect of gradual withdrawal on the rebound sleep disorder after discontinuation of triazolam. New Engl J Med. 1987;317:722-8. [pmid: 3306380].
81 Hardy M, Kirk-Smith MD, Stretch DD. Replacement of drug treatment for insomnia by ambient odour. Lancet. 1995;346(8976):701. [pmid: 7658836].
82 Hartmann E, Chung R, Chien C. L-tryptophan and sleep. Psychopharmacol. 1971;19(2):114-27.
83 Hartmann E, Elion R. The insomnia of ‘sleeping in a strange place’: effects of l-tryptophan. Psychopharmacol. 1977;53(2):131-3.
84 Hartmann E, Spinweber CL. Sleep induced by L-tryptophan: effect of dosages within the normal dietary intake. J Nerv Ment Dis. 1979;167:497-9. [pmid: 469515].
85 Hartz AJ, Bentler S, Noyes R, et al. Randomized controlled trial of Siberian ginseng for chronic fatigue. Psychol Med. 2004;34(1):51-61. [pmid: 14971626].
86 Hartz AJ, Bentler SE, Brake KA, et al. The effectiveness of citalopram for idiopathic chronic fatigue. J Clin Psychiatry. 2003;64(8):927-35. [pmid: 12927008].
87 Harvey AG, Farrell C. The efficacy of a Pennebaker-Like writing intervention for poor sleepers. Behav Sleep Med. 2003;1(2):115-24. [pmid: 15600133].
88 Hauri P, Wisbey J. Wrist actigraphy in insomnia. Sleep. 1992;15(4):293-301. [pmid: 1519002].
89 Haynes SN, Price M, Simons JP. Stimulus control treatment of insomnia. J Behav Ther Exp Psychiatry. 1975;6(4):279-82.
90 Hayoun G, Bagot C. Comparative efficacy and safety of triazolam and zopiclone in insomniacs seen in general practice. Curr Ther Res. 1989;46:1236-44.
91 Hearst ED, Cloninger CR, Crews EL, et al. Electrosleep therapy: a double-blind trial. Arch Gen Psychiatry. 1974;30(4):463-6. [pmid: 4592898].
92 Heffler D, Lisman S. Attribution and insomnia A replication failure. Psychol Rec. 1978;28(1):123-8.
93 Hegelbach F, Tschopp J, Christeller S, et al. Comparison of the short-acting benzodiazepines Midazolam and Triazolam with placebo. Arzneimittel Forschung. 1988;38(3):387-92. [pmid: 3289550].
94 Helcl I, Lupolover R, Buch JP, et al. Evaluation of the efficacy and tolerance of orally administered midazolam as a hypnotic agent compared with oxazepam in the treatment of insomnia of mild to moderate severity. Arzneimittel Forschung. 1981;31(12a):2284-7. [pmid: 6120705].
95 Hemmeter U, Seifritz E, Hatzinger M, et al. Serial partial sleep deprivation as adjuvant treatment of depressive insomnia. Prog NeuroPsychopharmacol Biol Psychiatry. 1995;19(4):593-602. [pmid: 8588058].
96 Hindmarch I. Effects of hypnotic and sleep-inducing drugs on objective assessments of human psychomotor performance and subjective appraisals of sleep and early morning behaviour. Br J Clin Pharmacol. 1979;8(1):S43-6.
97 Hindmarch I. Psychopharmacological aspects of idiopathic and transient insomnia. Acta Psychiatr Scand. 1986;332(Suppl):47-54.
98 Hinton J, Marley E. The effects of meprobamate and pentobarbitone sodium on sleep and motility during sleep: A controlled trial with psychiatric patients. J Neurol Neurosurg Psychiatry 1959;(137–40).
99 Hohenthal TT. Comparative clinical studies of a new somnifacient combination of methaqualone and etodroxizine versus glutethimide and placebo. Cross-over double-blind control test with sequential analysis. Arzneimittel Forschung. 1969;19(9):1527-9. [pmid: 4899292].
100 Holborn SW, Hiebert DE, Bell CL. Computer-interfaced operant measurement in treating insomnia. J Behavior Ther Exp Psychiatry. 1987;18(4):365-72.
101 Hughes RJ, Sack RL, Lewy AJ. The role of melatonin and circadian phase in age-related sleep- maintenance insomnia: Assessment in a clinical trial of melatonin replacement. Sleep. 1998;21(1):52-68. [pmid: 9485533].
102 Hunter GM. Two-dose comparison of chlormezanone in sleep disturbance due to anxiety. Curr Med Res Opin. 1982;8(1):22-7. [pmid: 7049583].
103 Itil TM, Bozak M, Polvan N, et al. Effects of supidimide (CG-3033) on objective and subjective sleep parameters (a sleep laboratory study). Curr Ther Res Clin Exp. 1980;27:442-57.
104 Jean-Louis G, von Gizycki H, Zizi F. Melatonin effects on sleep, mood, and cognition in elderly with mild cognitive impairment. J Pineal Res. 1998;25(3):177-83. [pmid: 9745987].
105 Jobert M, Poiseau E, Jahnig P, et al. ECG activity in the sleep of insomniac patients under the influence of lormetazepam and zopiclone. Neuropsychobiol. 1995;31(4):204-9.
106 Johnson LC, Church MW, Seales DM, et al. Auditory arousal thresholds of good sleepers and poor sleepers with and without flurazepam. Sleep. 1979;1(3):259-70. [pmid: 228373].
107 Kales A, Allen C, Scharf MB, et al. Hypnotic drugs and their effectiveness. All-night EEG studies of insomniac subjects. Arch Gen Psychiatry. 1970;23(3):226-32. [pmid: 4318151].
108 Kales A, Kales JD, Scharf MB, et al. Hypnotics and altered sleep-dream patterns. II. All-night EEG studies of chloral hydrate, flurazepam, and methaqualone. Arch Gen Psychiatry. 1970;23(3):219-25. [pmid: 4318150].
109 Kales A, Manfredi RL, Vgontzas AN, et al. Rebound insomnia after only brief and intermittent use of rapidly eliminated benzodiazepines. Clin Pharmacol Ther. 1991;49(4):468-76. [pmid: 2015735].
110 Kales J, Kales A, Bixler E, et al. Effects of placebo and flurazepam on sleep patterns in insomniac subjects. Clin Pharmacol Ther. 1971;12(4):691-7. [pmid: 4327923].
111 Kales J, Tjiauw-Ling T, Swearingen C, et al. Are over-the-counter sleep medications effective? All-night EEG studies. Curr Ther Res. 1971;13:143-51. [pmid: 4397942].
112 Kanba S, Miyaoka H, Terada H, et al. Triazolam accumulation in the elderly after prolonged use. Am J Psychiatry. 1991;148(9):1264-5. [pmid: 1652900].
113 Kangas L, Kanto J, Lehtinen V, et al. Long-term nitrazepam treatment in psychiatric out-patients with insomnia. Psychopharmacol. 1979;63(1):63-6.
114 Karacan I, Thornby JI, Anch M, et al. Dose-related sleep disturbances induced by coffee and caffeine. Clin Pharmacol Ther. 1976;20(6):682-9. [pmid: 186223].
115 Katsunuma H, Shimizu T, Ogawa K, et al. Treatment of insomnia by concomitant therapy with zopiclone and aniracetam in patients with cerebral infarction, cerebroatrophy, Alzheimer's disease and Parkinson's disease. Psychiatry Clin Neurosci. 1998;52(2):198-200. [pmid: 9628149].
116 Kaynak H, Kaynak D, Gozukirmizi E, et al. The effects of trazodone on sleep in patients treated with stimulant antidepressants. Sleep Med. 2004;5(1):15-20. [pmid: 14725822].
117 Kesson CM, Gray JM, Lawson DH, et al. Long-term efficacy and tolerability of a new hypnotic-loprazolam. Br J Clin Pract. 1984;38(9):306-12. [pmid: 6148097].
118 King A, Oman R, Brassington G, et al. Moderate-intensity exercise and self-rated quality of sleep in older adults. A randomized controlled trial. J Am Med Assoc. 1997;277(1):32-7.
119 Kolber M, Spooner GR, Szafran O. Adverse events with Zyban (buproprion) [2]. Can Med Assoc J. 2003;169(2):103-4. [pmid: 12874152].
120 Koves P. Placebo-controlled clinical trial of dormicum 15-mg tablet. Ther Hungarica. 1993;41(3):89-99.
121 Kramer M, Bonnet M, Schoen LS, et al. Efficacy and safety of midazolam 75 mg. in geriatric insomniacs. Curr Ther Res Clin Exp. 1985;38(3):414-22.
122 Kramer M, Schoen LS, Scharf M. Effects of alprazolam on sleep and performance in geriatric insomniacs. Curr Ther Res. 1984;36:67-76.
123 Kudo Y. Hypnotic effects of a benzodiazepine derivative: a clinical observation. Int Pharmacopsychiatry. 1982;17(1):49-64. [pmid: 6123490].
124 Kullander NE. A double-blind clinical trial of a new sleep-inducing combination of methaqualone and etodroxizine compared with nitrazepam and placebo. Arzneimittel Forschung. 1969;19(9):1530-2. [pmid: 4899293].
125 Leathwood P, Chauffard F. Aqueous extract of valerian reduces latency to fall asleep in man. Planta Med. 1985;(2):144-8. [pmid: 4034730].
126 Leigh TJ, Bird HA, Hindmarch I, et al. The evaluation of a nonsteroidal anti-inflammatory drug (Tenoxicam) in the treatment of sleep disturbance in osteoarthritic patients. Clin Rheumatol. 1989;8(4):489-93. [pmid: 2692948].
127 Li Pi Shan RS, Ashworth NL. Comparison of lorazepam and zopiclone for insomnia in patients with stroke and brain injury: a randomized, crossover, double-blinded trial. Am JPhys Med Rehab. 2004;83(6):421-7.
128 Lingjaerde O, Berglund J, Bratland SZ, et al. Alimemazine (trimeprazine; Vallegran) as a hypnotic in general practice patients: controlled comparison with nitrazepam. Curr Ther Res Clin Exp. 1978;24(4):388-96.
129 Lingjaerde O, Bratlid T. Triazolam (Halcion) versus flunitrazepam (Rohypnol) against midwinter insomnia in Northern Norway. Acta Psychiatr Scand. 1981;64(3):260-9. [pmid: 6119872].
130 Lingjaerde O, Bratlid T, Westby OC, et al. Effect of midazolam, flunitrazepam, and placebo against midwinter insomnia in northern Norway. Acta Psychiatr Scand. 1983;67(2):118-29. [pmid: 6133412].
131 Linnoila M, Erwin CW, Brendle A. Efficacy and side effects of flunitrazepam and pentobarbital in severely insomniac patients. J Clin Pharmacol. 1982;22(1):14-9. [pmid: 6120958].
132 Linnoila M, Erwin C, Logue P. Efficacy and side effects of flurazepam and a combination of amo barbital and seco barbital in insomniac patients. J Clin Pharmacol. 1980;20(23):117-23. [pmid: 6991532].
133 Lipani JA. Preference study of the hypnotic efficacy of triazolam 0.125 mg compared to placebo in geriatric patients with insomnia. Curr Ther Res Clin Exp. 1978;24:397-402.
134 Loew F, Pawlak C, Benaroyo L, et al. Comparison of midazolam and oxazepam as hypnotics in elderly hospitalized patients. A double-blind clinical trial. Arzneimittel Forschung. 1988;38(4):563-7. [pmid: 3041972].
135 Lohmann H, von Delbruck O, Findeisen P. Comparative studies on the efficacy of brotizolam and nitrazepam: a multi-centre study. Br J Clin Pharmacol. 1983;16(Suppl 2):S403-6.
136 Lorizio A, Salsa F. Effectiveness of oral midazolam as a hypnotic compared with lorazepam. Pharmather. 1986;4(7):463-71.
137 Lupolover R, Ballmer U, Helcl J, et al. Efficacy and safety of midazolam and oxazepam in insomniacs. Br J Clin Pharmacol. 1983;16(Suppl 1):139S-43S. [pmid: 6138067]. [pmcid: 1428086].
138 Lupolover R, Buch JP. Evaluation of efficacy and safety of midazolam administered orally in sleep disorders. A dose-finding study. Arzneimittel Forschung. 1981;31(12a):2281-3. [pmid: 6120704].
139 MacPhail I, Ogilvie WA, Purvis CR. Comparison of diazepam and flurazepam in the treatment of insomnia in general practice. J Int Med Res. 1979;7(5):401-3. [pmid: 387494].
140 Maggini C, Murri M, Sacchetti G. Evaluation of the effectiveness of temazepam on the insomnia of patients with neurosis and endogenous depression. Arzneimittel Forschung. 1969;19(10):1647-52. [pmid: 4311716].
141 Maiman DJ. Effect of short term quazepam treatment on outpatients with insomnia. Current Therapeutic Research 30[Dec], 1005–1013 1981.
142 Mamelak M, Csima A, Price V. The effects of a single night's dosing with triazolam on sleep the following night. J Clin Pharmacol. 1990;30(6):549-555. [pmid: 2355105].
143 Manber R, Rush A, Thase M, et al. The effects of psychotherapy, nefazodone, and their combination on subjective assessment of disturbed sleep in chronic depression. Sleep. 2003;26(2):130-6. [pmid: 12683470].
144 Marino A. Treating chronic insomnia: A cognitive-behavioural group therapy approach. Toronto (ON): University of Toronto. 2002.
145 Martinez HT, Serna CT. Short term treatment with quazepam for insomnia in geriatric patients. Clin Ther. 1982;5(2):174-8. [pmid: 6130842].
146 Mashiko H, Niwa S, Kumashiro H, et al. Effect of trazodone in a single dose before bedtime for sleep disorders accompanied by a depressive state: dose-finding study with no concomitant use of hypnotic agent. Psychiatry Clin Neurosci. 1999;53(2):193-4. [pmid: 10459686].
147 Mendels J. Evaluation of the safety and efficacy of quazepam for the treatment of insomnia in psychiatric outpatients. J Clin Psychiatry. 1994;55(2):60-5. [pmid: 7915708].
148 Meyer JA, Kurland KZ. Controlled evaluation of flurazepam hydrochloride, a new nonbarbiturate hypnotic. Mil Med. 1973;138(8):471-4. [pmid: 4200136].
149 Mitchell JL. The efficacy of short-term group cognitive-behavioral therapy in the treatment of insomnia in the severely and persistently mentally ill. New York (NY): City University of New York. 2002.
150 Mitler MM, Browman CP, Menn SJ, et al. Nocturnal myoclonus: Treatment efficacy of clonazepam and temazepam. Sleep. 1986;9(3):385-92. [pmid: 2876485].
151 Moja EA, Scamonatti L, Maxia D, et al. Double-blind evaluation of the safety and hypnotic efficacy of lormetazepam in general practice. Clin Ther. 1983;5(6):580-4. [pmid: 6138152].
152 Montgomery I, Oswald I, Morgan K, et al. Trazodone enhances sleep in subjective quality but not in objective duration. Br J Clin Pharmacol. 1983;16(2):139-44. [pmid: 6615688]. [pmcid: 1427983].
153 Monti JM, Alterwain P, Debellis J, et al. Short-term sleep laboratory evaluation of midazolam in chronic insomniacs: preliminary results. Arzneimittel Forschung. 1987;37(1):54-7. [pmid: 3551970].
154 Monti JM, Boussard M, Olivera S, et al. The effect of midazolam on transient insomnia. Eur J Clin Pharmacol. 1993;44(6):525-7. [pmid: 8405006].
155 Monti J, Debellis J, Gratadoux E, et al. Sleep laboratory study of the effects of Midazolam in insomniac patients. Eur J Clin Pharmacol. 1982;21(6):479-84. [pmid: 7075654].
156 Morgan K, Thompson J, Dixon S, et al. Predicting longer-term outcomes following psychological treatment for hypnotic-dependent chronic insomnia. J Psychosom Res. 2003;54(1):21-9. [pmid: 12505552].
157 Morgan VC. Effects of progressive muscle relaxation and stimulus control procedures in the treatment of insomnia. Louisiana (MS): Mississippi State University. 1981.
158 Nair N, Schwartz G. Triazolam in insomnia: A standard-controlled trial. Curr Ther Res. 1978;23(3, Pt 2):388-92.
159 Ngen CC, Hassan R. A double-blind placebo-controlled trial of zopiclone 75 mg and temazepam 20 mg in insomnia. Int Clin Psychopharmacol. 1990;5(3):165-71. [pmid: 2230060].
160 Nierenberg AA, Adler LA, Peselow E, et al. Trazodone for antidepressant-associated insomnia. Am J Psychiatry. 1994;151:1069-72. [pmid: 8010365].
161 Norman T, Fulton A, Burrows GD, et al. An open evaluation of midazolam as a hypnotic. Curr Ther Res. 1984;36(3):461-7.
162 O'Hair DE, Winsauer HJ. Evaluation of short-term treatment with 30 mg of quazepam in insomniac outpatients. Clin Ther. 1981;4(4):291-301. [pmid: 7037183].
163 Okawa KK. Comparison of triazolam 0.25 mg and flurazepam 15 mg in treating geriatric insomniacs. Curr Ther Res Clin Exp. 1978;23(Sec 2):381-7.
164 Pagot R, Cramer P, L' HC, et al. Comparison of the efficacy and tolerability of zolpidem 20 mg and triazolam 0.5 mg in anxious or depressed insomniac patients. Curr Ther Res. 1993;53(1):88-97.
165 Palomaki H, Berg A, Meririnne E, et al. Complaints of poststroke insomnia and its treatment with mianserin. Cerebrovasc Dis. 2003;15(12):56-62. [pmid: 12499712].
166 Pegram V, Hyde P, Linton P. Chronic use of triazolam: the effects on the sleep patterns of insomniacs. J Int Med Res. 1980;8(3):224-31. [pmid: 6104615].
167 Pelka RB, Jaenicke C, Gruenwald J. Impulse magnetic-field therapy for insomnia: A double-blind, placebo-controlled study. Adv Ther. 2001;18(4):174-80. [pmid: 11697020].
168 Philipp E, Kapp W. Comparative study of midazolam and vesparax in moderate or severe insomnia in female surgical patients. Br J Clin Pharmacol. 1983;16(Suppl 1):S161-6.
169 Piccione P, Zorick F, Lutz T, et al. The efficacy of triazolam and chloral hydrate in geriatric insomniacs. J Int Med Res. 1980;8(5):361-7. [pmid: 6106611].
170 Pines A, Rooney JF, Arenillas L. Flurazepam (‘Dalmane’) in the treatment of insomnia in patients with respiratory disorders. Practitioner. 1976;217(1298):281-4. [pmid: 9636].
171 Polacek J. Confirmation of safety and effect of zolpidem on sleep disturbances and well-being score in insomniac patients. Homeost Health Dis. 1997;38(1):14-5.
172 Polo-Kantola P, Erkkola R, Helenius H, et al. When does estrogen replacement therapy improve sleep quality?. Am J Obstet Gynecol. 1998;178(5):1002-9. [pmid: 9609575].
173 Ponciano E, Freitas F, Camara J, et al. A comparison of the efficacy, tolerance and residual effects of zopiclone, flurazepam and placebo in insomniac outpatients. Int Clin Psychopharmacol. 1990;5(Suppl 2):69-77. [pmid: 2201731].
174 Post G, Patrick R, Crowder J, et al. Estazolam treatment of insomnia in generalized anxiety disorder A placebo-controlled study. J Clin Psychopharmacol. 1991;11(4):249-53. [pmid: 1918423].
175 Roehrs T, Zorick F, Lord N, et al. Dose-related effects of estazolam on sleep of patients with insomnia. J Clin Psychopharmacol. 1983;3(3):152-6. [pmid: 6135720].
176 Roehrs T, Zorick F, Wittig R, et al. Efficacy of a reduced triazolam dose in elderly insomniacs. Neurobiol Aging. 1985;6(4):293-6. [pmid: 4088425].
177 Roger M, Attali P, Coquelin JP. Multicenter, double-blind, controlled comparison of zolpidem and triazolam in elderly patients with insomnia. Clin Ther. 1993;15(1):127-36. [pmid: 8458042].
178 Rosenberg J, Ahlstrom F. Randomized, double blind trial of zolpidem 10 mg versus triazolam 025 mg for treatment of insomnia in general practice. Scand J Prim Health Care. 1994;12(2):88-92. [pmid: 7973199].
179 Roslund K, Olsen I. Clinical trial of propiomazine and placebo in the treatment of insomnia in the elderly. Curr Ther Res. 1987;41:6-12.
180 Roth T, Roehrs T, Vogel G. Zolpidem in the treatment of transient insomnia: a double-blind, randomized comparison with placebo. Sleep. 1995;18(4):246-51. [pmid: 7618022].
181 Rush JA, Gillin C, Armitage R, et al. Comparative Effects of Nefazodone and Fluoxetine on Sleep in Outpatients with Major Depressive Disorders. Proceedings of the 149th Annual Meeting of the American Psychiatric Association; 1996 May 4–9; New York, NY. Bio Psychiatry. 1998;44:3-14. [pmid: 9646878].
182 Sakamoto T, Uchimura N, Mukai M, et al. Efficacy of L-846 in patients with insomnia: evaluation by polysomnography. Psychiatry Clin Neurosc. 1998;52(2):156-7.
183 Salkind MR, Silverstone T. The clinical and psychometric evaluation of a new hypnotic drug, loprazolam, in general practice. Curr Med Res Opin. 1983;8(5):368-74. [pmid: 6340977].
184 Sapienza PL. A double-blind comparison of methaqualone, pentobarbital and placebo in the management of insomnia. Curr Ther Res Clin Exp. 1966;8(11):523-7. [pmid: 4962778].
185 Scharf M, Hirschowitz J, Zemlan F, et al. Comparative effects of Limbitrol and Amitriptyline on sleep efficiency and architecture. J Clin Psychiatry. 1986;47(12):587-91. [pmid: 3536890].
186 Schlich D, L'Heritier C, Coquelin JP, et al. Long-term treatment of insomnia with zolpidem: A multicentre general practitioner study of 107 patients. J Int Med Res. 1991;19(3):271-9. [pmid: 1670039].
187 Seno H, Morita Y, Ikehata K, et al. Effects of a weak diffuse-brain-stimulation on insomniacs with vibration syndrome. Acta Neurobiol Exp. 1989;49(5):289-94.
188 Shamsi Z, Stanley N, Yoon J, et al. Effects of three doses of 3-indole pyruvic acid on subjective and objective measures of sleep and early morning performance. Hum Psychopharmacol. 1996;11(3):235-9.
189 Silvestri R, Ferrillo F, Murri L, et al. Rebound insomnia after abrupt discontinuation of hypnotic treatment: Double-blind randomized comparison of zolpidem versus triazolam. Hum Psychopharmacol. 1996;11(3):225-33.
190 Simon GE, Heiligenstein JH, Grothaus L, et al. Should anxiety and insomnia influence antidepressant selection: a randomized comparison of fluoxetine and imipramine. J Clin Psychiatry. 1998;59(2):49-55. [pmid: 9501885].
191 Singer C, Tractenberg RE, Kaye J, et al. A multicenter, placebo-controlled trial of melatonin for sleep disturbance in Alzheimer's disease. Sleep. 2003;26(7):893-901. [pmid: 14655926].
192 Smith JA, Renshaw DC. Clinical study of insomnia. Am Fam Phys. 1975;11:140-1.
193 Stevinson C. Study of combined herbal treatment for insomnia. Focus AACN. 1999;4(2):73.
194 Sundaresan P, Wardell W, Weintraub M, et al. Methodology for demonstrating sustained efficacy of hypnotics A comparative study of triazaolam and flurazepam. Clin Pharmacol Ther. 1979;25(4):391-8. [pmid: 34496].
195 Sunshine A. Comparison of the hypnotic activity of triazolam, flurazepam hydrochloride, and placebo. Clin Pharmacol Ther. 1975;17(5):573-7. [pmid: 236108].
196 Swanson DA. Double-blind evaluation of a new hypnotic--flurazepam hydrochloride. S Afr Med J. 1973;47:1339-41. [pmid: 4578725].
197 Tang NK, Harvey AG. Correcting distorted perception of sleep in insomnia: a novel behavioural experiment?. Behav Res Ther. 2004;42(1):27-39. [pmid: 14744521].
198 Thase ME R, ush AJ, Manber R, et al. Differential effects of nefazodone and cognitive behavioral analysis system of psychotherapy on insomnia associated with chronic forms of major depression. J Clin Psychiatry. 2002;63(6):493-500. [pmid: 12088160].
199 Thomson J, Oswald I. Effect of oestrogen on the sleep, mood, and anxiety of menopausal women. Br Med J. 1977;2(6098):1317-9. [pmid: 338104]. [pmcid: 1632495].
200 Tosi GC, Tosi EC, Hattab JR. Use of N-demethyldiazepam in outpatients suffering from insomnia. Curr Ther Res. 1973;15:460-4. [pmid: 4198307].
201 Usui A, Ishizuka Y, Matsushita Y, et al. Bright light treatment for night-time insomnia and daytime sleepiness in elderly people: comparison with a short-acting hypnotic. Psychiatry Clin Neurosci. 2000;54(3):374-6. [pmid: 11186120].
202 Van Moffaert M, Pilate C. Zopiclone in the treatment of insomnia in depressed patients. Eur/ Psychiatry J Assoc Eur Psychiatrists. 1995;10(Suppl 3):S167-72.
203 Van Moffaert M, Wilmotte J, Mesters P, et al. Comparison of Zopiclone and Flunitrazepam in the treatment of insomnia in depressed patients. Curr Ther Res. 1990;48(1):140-53.
204 Van Steenis D. A comparison of chlormezanone and temazepam in sleep disturbance. Curr Med Res Opin. 1982;8(1):28-32. [pmid: 6125345].
205 Velasco M, Velasco F, Cepeda C, et al. Effect of a new thienodiazepine WE 941 on sleep patterns of normal and insomniac subjects. Neuropharmacol. 1981;20(5):461-8.
206 Velden M, Wolk C. Baroreceptor activity and the induction of sleep. Percept Mot Skills. 1996;82(1):178. [pmid: 8668472].
207 Verbeek I, Declerck G, Neven AK, et al. Sleep information by telephone: Callers indicate positive effects on sleep problems. Sleep Hypnosis. 2002;4(2):47-51.
208 Viukari M, Vartio T, Verho E. Low doses of brotizolam and nitrazepam as hypnotics in the elderly. Neuropsychobiol. 1984;12(23):130-3.
209 Vogel GW, Barker K, Gibbons P, et al. A comparison of the effects of flurazepam 30 mg and triazolam 0.5 mg on the sleep of insomniacs. Psychopharmacol. 1976;47(1):81-6.
210 Walsh JK, Pollak CP, Scharf MB, et al. Lack of residual sedation following middle-of-the-night zaleplon administration in sleep maintenance insomnia. Clin Neuropharmacol. 2000;23(1):17-21. [pmid: 10682226].
211 Walsh JK, Schweitzer PK, Sugerman JL, et al. Transient insomnia associated with a 3-hour phase advance of sleep time and treatment with zolpidem. J ClinPsychopharmacol. 1990;10(3):184-9.
212 Wang RI, Stockdale SL, Hieb E. Hypnotic efficacy of lorazepam and flurazepam. Clin Pharmacol Ther. 1976;19(2):191-5. [pmid: 4255].
213 Ware JC, Brown FW, Moorad PJ Jr, et al. Effects on sleep: a double-blind study comparing trimipramine to imipramine in depressed insomniac patients. Sleep. 1989;12(6):537-49. [pmid: 2688037].
214 Warner M. Stimulus control procedures and a paradoxical intention instruction in the treatment of sleep onset insomnia. Reno (NV): University of Nevada. 1977.
215 Wheatley D. Zopiclone: a non-benzodiazepine hypnotic. Controlled comparison to temazepam in insomnia. Br J Psychiatry. 1985;146:312-4. [pmid: 2859069].
216 Wickstrom E, Godtlibsen OB, Bredesen JE, et al. Performance and mood following partial sleep deprivation: A randomized, double-blind crossover study of zopiclone, triazolam, flunitrazepam, ethanol and placebo. Hum Psychopharmacol. 1988;3(1):3-11.
217 Winokur A, Demartinis NA, Mcnally DP, et al. Comparative effects of mirtazapine and fluoxetine on sleep physiology measures in patients with major depression and insomnia. J Clin Psychiatry. 2003;64(10):1224-9. [pmid: 14658972].
218 Wittig R, Zorick F, Roehrs T, et al. Effects of temazepam soft gelatin capsules on the sleep of subjects with insomnia. Curr Ther Res. 1985;38:15-22.
219 Wojtulewski JA, Walter J. Treatment of sleep disturbance in arthritis with chlormezanone. Curr Med Res Opin. 1983;8(7):456-60. [pmid: 6354600].
220 Zwart CA, Lisman SA. Analysis of stimulus control treatment of sleep-onset insomnia. J Consult Clin Psychol. 1979;47(1):113-8. [pmid: 429643].
221 Zyhlarz G, Saletu B, Brandst_tter N, et al. Sleep studies in insomnia based on generalized anxiety disorder with diphenhydramine/lorazepam (SomniumR) Conf Abstr. Proceedings of the XXth Collegium Internationale Neuro-psychopharmacologicum; 1996 Jun 23–27; Melbourne, Australia. Eur Neuropsychopharmacol. 1996;6(Supp 3):1-247.

### Excluded - Design (Not Randomized Controlled Trial)

The following studies were excluded because they were not randomized-controlled trials.

1 Autret E, Maillard F, Autret A. Comparison of the clinical hypnotic effects of zopiclone and triazolam. Eur J Clin Pharmacol. 1987;31(5):621-23. [pmid: 3549323].
2 Backhaus J, Hohagen F, Voderholzer U, et al. Long-term effectiveness of a short-term cognitive-behavioral group treatment for primary insomnia. Eur Arch Psychiatry Clin Neurosci. 2001;251(1):35-41. [pmid: 11315517].
3 Bastien CH, Morin CM, Ouellet MC, et al. Cognitive-behavioral therapy for insomnia: Comparison of individual therapy, group therapy, and telephone consultations. J Consult Clin Psychol. 2004;72(4):653-9. [pmid: 15301650].
4 Beaumont G, Holland RL. A multi-centre open study in general practice to evaluate the efficacy and acceptability of zopiclone 7.5 mg nocte in patients requiring the prescription of an hypnotic. Int Clin Psychopharmacol. 1990;5(Suppl 2):11-20. [pmid: 2201723].
5 Bes F, Hofman W, Schuur J, et al. Effects of delta sleep-inducing peptide on sleep of chronic insomniac patients. A double-blind study. Neuropsychobiol. 1992;26(4):193-7.
6 Bixler EO, Kales A, Soldatos CR, et al. Effectiveness of temazepam with short-intermediate-, and long-term use: sleep laboratory evaluation. J Clin Pharmacol. 1978;18(12):110-8. [pmid: 342551].
7 Bliwise DL, Seidel W, Schanfald D, et al. Short-term trial of estrazolam in geriatric insomniacs. Curr Ther Res. 1983;34(6):1009-13.
8 Bonnet MH. Effect of 64 hours of sleep deprivation upon sleep in geriatric normals and insomniacs. Neurobiol Aging. 1986;7(2):89-96. [pmid: 3960268].
9 Bonnet MH, Rosa R. Sleep and performance in young adults and older normals and insomniacs during acute sleep loss and recovery. Biol Psychol. 1987;25(2):153-72. [pmid: 3502753].
10 Broomfield NM, Espie CA. Initial insomnia and paradoxical intention: An experimental investigation of putative mechanisms using subjective and actigraphic measurement of sleep. Behav Cognit Psychother. 2003;31(3):313-24.
11 Carskadon M, Dement WC, Mitler MM, et al. Self-reports versus sleep laboratory findings in 122 drug-free subjects with complaints of chronic insomnia. Am J Psychiatry. 1976;133(12):1382-8. [pmid: 185919].
12 Cesco G, Giannico S, Fabbruci I, et al. Single-blind evaluation of hypnotic activity of chlordesmethyldiazepam in No-placebo-reactor medical patients. Arzneimittel forschung. 1977;27(1):146-8. [pmid: 322671].
13 Childs-Clarke A. Stimulus control techniques for sleep onset insomnia. Nurs Times. 1990;86(35):52-3. [pmid: 2395713].
14 Choliz Montanes M. Development of a technique of breathing for insomnia treatment: Theoretical basis and experimental results. [Sp]. Anal Modific Conduct. 1993;19(65):421-32.
15 Cluydts RJ, De Roeck J M, Jolie AM. A three week multicentre general practitioner study of zolpidem in 651 patients with insomnia. Acta Ther. 1993;19(1):73-91.
16 Cuanang JR, Limos L. Treatment of insomnia with temazepam: double blind placebo controlled evaluation. Clin Ther. 1982;4(5):402-12. [pmid: 6121626].
17 Currie SR, Wilson KG, Curran D. Clinical significance and predictors of treatment response to cognitive-behavior therapy for insomnia secondary to chronic pain. J Behav Med. 2002;25(2):135-53. [pmid: 11977435].
18 Currie SR, Wilson KG, Pontefract AJ, et al. Cognitive-behavioral treatment of insomnia secondary to chronic pain. J Consult Clin Psychol. 2000;68(3):407-16. [pmid: 10883557].
19 Dahl LE, Dencker SJ, Lundin L, et al. Comparison of nitrazepam with triazolam in insomniac outpatients. Acta Psychiatr Scand. 1982;65(2):86-92. [pmid: 6138924].
20 Dahlitz M, Wells P, James R, et al. Treatment of insomnia with ritanserin. Lancet. 1990;336:379. [pmid: 1975361].
21 Danjou P, Puech A, Warot D, et al. Lack of sleep-inducing properties of propranolol (80 mg) in chronic insomniacs previously treated by common hypnotic medications. Int Clin Psychopharmacol. 1987;2(2):135-40. [pmid: 3298418].
22 Dashevsky BA, Kramer M. Behavioral treatment of chronic insomnia in psychiatrically ill patients. J Clin Psychiatry. 1998;59(12):693-9. [pmid: 9921709].
23 Davies D. A multiple treatment approach to the group treatment of insomnia: a follow-up study. Behav Psychother. 1989;17(4):323-31.
24 Dominguez RA, Jacobson AF, Goldstein BJ et al. Crossover comparison of brotizolam and temazepam in the treatment of insomnia. Current Therapeutic Research 33[Mar], 371–279 1983
25 Dopke CA, Lehner RK, Wells AM. Cognitive-behavioral group therapy for insomnia in individuals with serious mental illnesses: a preliminary evaluation. Psychiatr Rehab J. 2004;27(3):235-42.
26 Edinger JD, Hoelscher TJ, Marsh GR, et al. A cognitive-behavioral therapy for sleep-maintenance insomnia in older adults. Psychol Aging. 1992;7(2):282-9. [pmid: 1610517].
27 Ellinwood E, Linnoila M, Marsh G. Plasma concentrations of flurazepam and midazolam in chronic insomniacs during 14-day use and their relationship to therapeutic effects and next-day performance and mood. J Clin Psychopharmacol. 1990;10(4 Suppl):S68-7.5.
28 Espie CA, Inglis SJ, Tessier S, et al. The clinical effectiveness of cognitive behaviour therapy for chronic insomnia: implementation and evaluation of a sleep clinic in general medical practice. Behav Res Ther. 2001;39(1):45-60. [pmid: 11125723].
29 Espie C, Brooks D, Lindsay W. An evaluation of tailored psychological treatment of insomnia. J Behav Ther Exp Psychiatry. 1989;20(2):143-54. [pmid: 2685045].
30 Evans DR, Bond IK. Reciprocal inhibition therapy and classical conditioning in the treatment of insomnia. Behav Res Ther. 1969;7(3):323-5. [pmid: 5344975].
31 Goldstein L, Graedon J, Willard D, et al. A comparative study of the effects of methaqualone and glutethimide on sleep in male chronic insomniacs. J Clin Pharmacol J New Drugs. 1970;10(4):258-68. [pmid: 4393286].
32 Goldstein L, Stoltzfus NW, Smith RR. An analysis of the effects of methaqualone and glutethimide on sleep in insomniac subjects. Res Commun Chem Pathol Pharmacol. 1971;2(6):927-33. [pmid: 4949642].
33 Guilleminault C, Clerk A, Black J, et al. Nondrug treatment trials in psychophysiologic insomnia. Arch Int Med. 1995;155(8):838-44. [pmid: 7717792].
34 Hagenbucher J, Kleh J. Treatment of insomnia in geriatric patients: double-blind study with methyprylon and pentobarbital. J Am Geriatr Soc. 1962;10:1038-40. [pmid: 13951889].
35 Hajak G, Bandelow B. Safety and tolerance of zolpidem in the treatment of disturbed sleep: A post-marketing surveillance of 16,944 cases. Int Clin Psychopharmacol. 1998;13(4):157-67. [pmid: 9727726].
36 Hajak G, Bandelow B, Zulley J, et al. “As needed” pharmacotherapy combined with stimulus control treatment in chronic insomnia--assessment of a novel intervention strategy in a primary care setting. Ann Clin Psychiatry. 2002;14(1):1-7. [pmid: 12046635].
37 Harvey L, Inglis SJ, Espie CA. Insomniacs' reported use of CBT components and relationship to long-term clinical outcome. Behav Res Ther. 2002;40(1):75-83. [pmid: 11762429].
38 Hauri P. Treating psychophysiologic insomnia with biofeedback. Arch Gen Psychiatry. 1981;38(7):752-8. [pmid: 7247638].
39 Hauri P, Roth T, Sateia M, et al. Sleep laboratory and performance evaluation of midazolam in insomniacs. Br J Clin Pharmacol. 1983;16(Suppl 1):109S-14S. [pmid: 6138061]. [pmcid: 1428082].
40 Hauri PJ, Olmstead EM. Reverse first night effect in insomnia. Sleep. 1989;12(2):97-105. [pmid: 2711096].
41 Hauri PJ, Silberfarb PM. Effects of aspirin on the sleep of insomniacs. Curr Ther Res Clin Exper. 1980;28:867-74.
42 Haynes SN, Adams AE, West S, et al. The stimulus control paradigm in sleep-onset insomnia: a multimethod assessment. J Psychosom Res. 1982;26(3):333-9. [pmid: 7120159].
43 Hinkle JE, Lutker ER. Insomnia: A new approach. Psychother Theory Res Pract. 1972;9(3):236-7.
44 Hryshko-Mullen AS. Behavioral treatment of insomnia: the Wilford Hall Insomnia Program. Mil Med. 2000;165(3):200-7. [pmid: 10741083].
45 Jacobs GD, Rosenberg PA, Friedman R, et al. Multifactor behavioral treatment of chronic sleep-onset insomnia using stimulus control and the relaxation response. A preliminary study. Behav Modif. 1993;17(4):498-509. [pmid: 8216184].
46 Jason L. Rapid improvement in insomnia following self-monitoring. J Behav Ther Exp Psychiatry. 1975;6(4):349-50.
47 Johnson LC, Spinweber CL, Seidel WF, et al. Sleep spindle and delta changes during chronic use of a short-acting and a long-acting benzodiazepine hypnotic. Electroencephal Clin Neurophysiol. 1983;55(6):662-7.
48 Kahn M, Baker BL, Weiss JM. Treatment of insomnia by relaxation training. J Abnorm Psychol. 1968;73(6):556-8. [pmid: 5717357].
49 Kales A, Bixler EO, Kales JD, et al. Comparative effectiveness of nine hypnotic drugs: Sleep laboratory studies. J Clin Pharmacol. 1977;17(4):207-13. [pmid: 321488].
50 Kales A, Bixler EO, Soldatos CR, et al. Quazepam and flurazepam: long-term use and extended withdrawal. Clin Pharmacol Ther. 1982;32(6):781-8. [pmid: 7140142].
51 Kales A, Bixler EO, Soldatos CR, et al. Quazepam and temazepam: effects of short- and intermediate-term use and withdrawal. Clin Pharmacol Ther. 1986;39(3):345-52. [pmid: 2868823].
52 Kales A, Bixler EO, Vela-Bueno A, et al. Alprazolam: effects on sleep and withdrawal phenomena. J Clin Pharmacol. 1987;27(7):508-15. [pmid: 3655003].
53 Kales A, Bixler EO, Soldatos CR, et al. Dose-response studies of lormetazepam: efficacy, side effects, and rebound insomnia. J Clin Pharmacol. 1982;22(1122):520-30. [pmid: 6131080].
54 Kales A, Hauri P, Bixler EO, et al. Effectiveness of intermediate-term use of secobarbital. Clin Pharmacol Ther. 1976;20(5):541-5. [pmid: 185000].
55 Kales A, Masfredi R, Vgontzas A, et al. Clonazepam sleep laboratory study of efficacy and withdrawal. J Clin Psychopharmacol. 1991;11(3):189-93. [pmid: 2066457].
56 Kales A, Scharf MB, Bixler EO, et al. Dose-response studies of quazepam. Clin Pharmacol Ther. 1981;30(2):194-200. [pmid: 6113910].
57 Kales A, Scharf M, Soldatos C, et al. Quazepam A new benzodiazepine hyponotic intermediate term sleep laboratory evaluation. J Clin Pharmacol. 1980;20(4 Part 1):184-92. [pmid: 6103903].
58 Kales A, Soldatos CR, Bixler EO, et al. Early morning insomnia with rapidly eliminated benzodiazepines. Science. 1983;220(4592):95-7. [pmid: 6131538].
59 Kales A, Soldatos C, Bixler E, et al. Diazepam Effects on sleep and withdrawal phenomena. J Clin Psychopharmacol. 1988;8(5):340-6. [pmid: 3183072].
60 Karam-Hage M, Brower KJ. Open pilot study of gabapentin versus trazodone to treat insomnia in alcoholic outpatients. Psychiatry Clinl Neurosci. 2003;57(5):542-544.
61 Kirisoglu C, Guilleminault C. Twenty minutes versus forty-five minutes morning bright light treatment on sleep onset insomnia in elderly subjects. J Psychosom Res. 2004;56(5):537-42. [pmid: 15172210].
62 Krahn LE, Hanson CA, Pileggi TS, et al. Electroconvulsive therapy and cardiovascular complications in patients taking trazodone for insomnia. J Clin Psychiatry. 2001;62(2):108-10. [pmid: 11247094].
63 Kummer J, Guendel L, Linden J, et al. Long-term polysomnographic study of the efficacy and safety of zolpidem in elderly psychiatric in-patients with insomnia. J Int Med Res. 1993;21(4):171-84. [pmid: 8112475].
64 Lamphere J, Roehrs T, Vogel G, et al. The chronic efficacy of midazolam. Int Clin Psychopharmacol. 1990;5(1):31-9. [pmid: 2332606].
65 Lamphere J, Roehrs T, Zorick F, et al. Chronic hypnotic efficacy of estazolam. Drugs Exp Clin Res. 1986;12(8):687-91. [pmid: 2875857].
66 Leger D, Laudon M, Zisapel N. Nocturnal 6-sulfatoxymelatonin excretion in insomnia and its relation to the response to melatonin replacement therapy. Am J Med. 2004;116(2):91-5. [pmid: 14715322].
67 Leger D, Stal V, Guilleminault C, et al. Daily consequences of insomnia: Impact on quality of life. Rev Neurol. 2001;157(10):1270-8. [pmid: 11885520].
68 Lichstein KL, Wilson NM, Johnson CT. Psychological treatment of secondary insomnia. Psychol Aging. 2000;15(2):232-40. [pmid: 10879578].
69 Lick JR, Heffler D. Relaxation training and attention placebo in the treatment of severe insomnia. J Consult Clin Psychol. 1977;45(2):153-61. [pmid: 321491].
70 Lingjaerde O, Bratlid T, Hansen T. Insomnia during the “dark period” in northern Norway. An explorative, controlled trial with light treatment. Acta Psychiatr Scand. 1985;71(5):506-12. [pmid: 4013808].
71 Liu CY, Yang YY, Yeh EK. Efficacy and side effects of zopiclone and triazolamin in the treatment of Chinese patients with insomnia - A double blind cross-over study. Int Med J. 1997;4(1):45-48.
72 MacFarlane J, Cleghorn J, Brown G, et al. The effects of exogenous melatonin on the total sleep time and daytime alertness of chronic insomniacs A preliminary study. Biol Psychiatry. 1991;30(4):371-6. [pmid: 1912128].
73 Maeda K, Okamoto N, Nishimoto M, et al. A multicenter study of the effects of vitamin B12 on sleep-waking rhythm disorders: In Shizuoka Prefecture. Jpn J Psychiatry Neurol. 1992;46(1):229-30. [pmid: 1635320].
74 Mamelak M, Csima A, Price V. Effects of brotizolam on the sleep of chronic insomniacs. Br JClin Pharmacol. 1983;16(Suppl 2):S377-82.
75 Mamelak M, Scima A, Price V. Effects of zopiclone on the sleep of chronic insomniacs. Int Pharmacopsychiatry. 1982;17(Suppl 2):156-64. [pmid: 7188373].
76 Manfredi RL, Kales A, Vgontzas AN, et al. Buspirone: Sedative or stimulant effect?. Am J Psychiatry. 1991;148(9):1213-7. [pmid: 1883000].
77 McClusky HY, Milby JB, Switzer PK, Williams V, Wooten V. Efficacy of behavioral versus triazolam treatment in persistent sleep-onset insomnia. Am J Psychiatry. 1991;148(1):121-6. [pmid: 1888345].
78 Mendelson WB. Subjective vs objective tolerance during long term administration of triazolam. Clin Drug Invest. 1995;10(5):276-9.
79 Mendelson WB, Garnett D, Gillin JC. Flurazepam-induced sleep apnea syndrome in a patient with insomnia and mild sleep-related respiratory changes. J Nerv Ment Dis. 1981;169(4):261-4. [pmid: 7217935].
80 Mendelson WB, Martin JV, Stephens H, et al. Effects of flurazepam on sleep, arousal threshold, and the perception of being asleep. Psychopharmacol. 1988;95(2):258-62.
81 Mendelson WB, Weingartner H, Greenblatt DJ, et al. A clinical study of flurazepam. Sleep. 1982;5(4):350-60. [pmid: 6761826].
82 Mimeault V, Morin CM. Self-help treatment for insomnia: bibliotherapy with and without professional guidance. J Consult Clin Psychol. 1999;67(4):511-9. [pmid: 10450621].
83 Monaco V, Bonfante A. Long-term use of doxefazepam, a new hypnotic benzodiazepine. Curr Ther Res. 1985;37(4):626-47.
84 Monti JM. Effect of zolpidem on sleep in insomniac patients. Eur J Clin Pharmacol. 1989;36(5):461-6. [pmid: 2666141].
85 Monti JM, Debellis J, Alterwain P, et al. Study of delta sleep-inducing peptide efficacy in improving sleep on short-term administration to chronic insomniacs. Int J Clin Pharmacol Res. 1987;7(2):105-10. [pmid: 3583493].
86 Morawetz D. Behavioral self-help treatment for insomnia: A controlled evaluation. Behav Ther. 1989;20(3):365-79.
87 Morgan K, Dixon S, Mathers N, et al. Psychological treatment for insomnia in the management of long-term hypnotic drug use: a pragmatic randomised controlled trial. Br J Gen Pract. 2003;53(497):923-8. [pmid: 14960215]. [pmcid: 1314744].
88 Morin CM, Gaulier B, Bary T, et al. Patients' acceptance of psychological and pharmacological therapies for insomnia. Sleep. 1992;15(4):302-5. [pmid: 1519003].
89 Morin CM, Kowatch RA, Wade JB. Behavioral management of sleep disturbances secondary to chronic pain. J Behav Ther Exp Psychiatry. 1989;20(4):295-302. [pmid: 2534597].
90 Morin CM, Stone J, McDonald K, et al. Psychological management of insomnia: A clinical replication series with 100 patients. Behav Ther. 1994;25(2):291-309.
91 Morin CM, Colecchi CA, Ling WD, et al. Cognitive behavior therapy to facilitate benzodiazepine discontinuation among hypnotic-dependent patients with insomnia. Behav Ther. 1995;26(4):733-45.
92 Morin CM, Kowatch RA, Barry T, et al. Cognitive-behavior therapy for late-life insomnia. J Consult Clin Psychol. 1993;61(1):137-46. [pmid: 8450099].
93 Morishita S, Sonohara M, Murakami H, et al. Long-term treatment of brotizolam and zopiclone in elderly insomniacs. Kawasaki Med J. 2000;26(1):9-11.
94 Moskowitz H, Linnoila M, Roehrs T. Psychomotor performance in chronic insomniacs during 14-day use of flurazepam and midazolam. J Clin Psychopharmacol. 1990;10(Suppl 4):S44-55.
95 Murphy PJ, Campbell SS. Enhanced performance in elderly subjects following bright light treatment of sleep maintenance insomnia. J Sleep Res. 1996;5(3):165-72. [pmid: 8956206].
96 Nowell PD, Reynolds CF 3rd, Buysse DJ, et al. Paroxetine in the treatment of primary insomnia: preliminary clinical and electroencephalogram sleep data. J Clin Psychiatry. 1999;60(2):89-95. [pmid: 10084634].
97 Parrino L, Spaggiari M, Boselli M, et al. Clinical and polysomnographic effects of trazodone CR in chronic insomnia associated with dysthymia. Psychopharmacol. 1994;116(4):389-95.
98 Pat-Horenczyk R. Changes in attitudes toward insomnia following cognitive intervention as part of a withdrawal treatment from hypnotics. Behav Cognit Psychother. 1998;26(4):345-57.
99 Pecknold J, Wilson R, le Morvan P. Long term efficacy and withdrawal of zopiclone: a sleep laboratory study. Int Clin Psychopharmacol. 1990;5(Suppl 2):57-67. [pmid: 2117623].
100 Peeters K, Boucau M, De Bouyalsky I, et al. Efficacy and safety of a one-month treatment with zolpidem in middle-aged and elderly insomniacs. Acta Ther. 1997;23(12):5-19.
101 Pillitteri JL, Kozlowski LT, Person DC, et al. Over-the-counter sleep aids: widely used but rarely studied. J Subst Abuse. 1994;6(3):315-23. [pmid: 7703708].
102 Poirrier R, Franck G, Scheldewaert R, et al. The effects of long-term zolpidem treatment on nocturnal polysomnography and daytime vigilance in patients with psychophysiological insomnia. Acta Ther. 1994;20(12):77-86.
103 Puder R, Lacks P, Bertelson AD, et al. Short-term stimulus control treatment of insomnia in older adults. Behav Ther. 1983;14(3):424-9.
104 Quadens OP, Hoffman G, Buytaert G. Effects of zopiclone as compared to flurazepam on sleep in women over 40 years of age. Pharmacol. 1983;27(Suppl 2):146-55.
105 Quesnel C, Savard J, Simard S, et al. Efficacy of cognitive-behavioral therapy for insomnia in women treated for nonmetastatic breast cancer. J Consult Clin Psychol. 2003;71(1):189-200. [pmid: 12602439].
106 Rani PU, Naidu MUR. Subjective and polysomnographic evaluation of a herbal preparation in insomnia. Phytomed. 1998;5(4):253-7.
107 Relinger H. Treatment of sleep onset insomnia by paradoxical instruction Missoula (MT): University of Montana. 1978
108 Relinger H, Bronstein PH. Treatment of sleep onset insomnia by paradoxical instruction: A multiple baseline design. Behav Modif. 1979;3(2):203-22.
109 Rickels K, Gingrich RL, Morris RJ, et al. Triazolam in insomniac family practice patients. Clin Pharmacol Ther. 1975;18:315-24. [pmid: 1100300].
110 Riedel BW, Lichstein KL. Strategies for evaluating adherence to sleep restriction treatment for insomnia. Behav Res Ther. 2001;39(2):201-12. [pmid: 11153973].
111 Riemann D, Feige B, Hornyak M, et al. The tryptophan depletion test: Impact on sleep in primary insomnia--a pilot study. Psychiatry Res. 2002;109(2):129-35. [pmid: 11927137].
112 Roehrs T, Hollebeek E, Drake C, et al. Substance use for insomnia in metropolitan Detroit. J Psychosom Res. 2002;53(1):571-6. [pmid: 12127173].
113 Roehrs T, Merlotti L, Zorick F, et al. Rebound insomnia and hypnotic self administration. Psychopharmacol. 1992;107(4):480-4.
114 Roehrs T, Pedrosi B, Rosenthal L, et al. Hypnotic self administration and dose escalation. Psychopharmacol. 1996;127(2):150-4.
115 Romano SJ, Tepner RG, Basson BR. Changes in insomnia during the treatment of depression: An analysis of double-blind, placebo-controlled trials of fluoxetine hydrochloride. Psychiatr Ann. 1999;29(10):562-7.
116 Roth T, Roehrs T, Linnoila M, et al. Characteristics of chronic insomniacs examined in a multicenter 14-day study of flurazepam and midazolam. J Clin Psychopharmacol. 1990;10(4 Suppl):S24-7.
117 Rybarczyk B, Lopez M, Benson R, et al. Efficacy of two behavioral treatment programs for comorbid geriatric insomnia. Psychol Aging. 2002;17(2):288-98. [pmid: 12061413].
118 Saletu B, Anderer P, Brandstatter N, et al. Insomnia in generalized anxiety disorder: polysomnographic, psychometric and clinical investigations before, during and after therapy with a long- versus a short-half-life benzodiazepine (quazepam versus triazolam). Neuropsychobiol. 1994;29(2):69-90.
119 Saletu B, Salegu-Zyhlarz G. Sleep laboratory studies with trazodone in insomnia related to depression and dysthymia. Ceska Slov Psychiatr. 2002;98(7):369-76.
120 Saletu Z, Abu B, Anderer P, et al. Insomnia in depression: Differences in objective and subjective sleep and awakening quality to normal controls and acute effects of trazodone. Prog NeuroPsychopharmacol Biol Psychiatry. 2002;26(2):249-60. [pmid: 11817501].
121 Saletu Z, Abu B, Anderer P, et al. Insomnia related to dysthymia: Polysomnographic and psychometric comparison with normal controls and acute therapeutic trials with trazodone. Neuropsychobiol. 2001;44(3):139-49.
122 Scharf MB, Kales A, Bixler EO, et al. Lorazepam-efficacy, side effects, and rebound phenomena. Clin Pharmacol Ther. 1982;31(2):175-9. [pmid: 6120058].
123 Scharf MBa, Mendels J, Thorpy M, et al. Safety of long-term zolpidem treatment in patients with insomnia. Curr Ther Res. 1994;55(9):1100-11.
124 Schneider H. Interval therapy with L tryptophan in severe chronic insomniacs A predictive laboratory study. Int Pharmacopsychiatry. 1981;16(3):162-73. [pmid: 7033160].
125 Schoicket SL, Bertelson AD, Lacks P. Is sleep hygiene a sufficient treatment for sleep-maintenance insomnia?. Behav Ther. 1988;19(2):183-90.
126 Scholz OB, Ott R. Effect and course of tape-based hypnotherapy in subjects suffering from insomnia. Aust J Clin Hypnoth Hypnosis. 2000;21(2):96-114.
127 Schramm E, Hohagen F, Backhaus J, et al. Effectiveness of a multicomponent group treatment for insomnia. Behav Cognit Psychother. 1995;23(2):109-27.
128 Shealy R, Lowe J, Ritzler B. Sleep onset insomnia: Personality characteristics and treatment outcomes. J Consult Clin Psychol. 1980;48(5):659-61. [pmid: 7410669].
129 Simeit R, Deck R, Conta-Marx B. Sleep management training for cancer patients with insomia. Support Care Cancer. 2004;12(3):176-83. [pmid: 14760542].
130 Smirne S, et al. Intermediate-term hypnotic efficacy of doxefazepam: A sleep laboratory study in insomniacs. Curr Ther Res. 1985;37(4):648-57.
131 Spence DW, Kayumov L, Chen A, et al. Acupuncture increases nocturnal melatonin secretion and reduces insomnia and anxiety: a preliminary report. J Neuropsychiatry Clin Neurosci. 2004;16(1):19-28. [pmid: 14990755].
132 Spielman AJ, Saskin P, Thorpy MJ. Treatment of chronic insomnia by restriction of time in bed. Sleep. 1987;10(1):45-56. [pmid: 3563247].
133 Spinweber CL. L-tryptophan administered to chronic sleep-onset insomniacs: late-appearing reduction of sleep latency. Psychopharmacol. 1986;90(2):151-5.
134 Stepanski E, Zorick F, Roehrs T, et al. Effects of sleep deprivation on daytime sleepiness in primary insomnia. Sleep. 2000;23(2):215-9. [pmid: 10737338].
135 Strom L, Pettersson R, Andersson G. Internet-based treatment for insomnia: A controlled evaluation. J Consult Clin Psychol. 2004;72(1):113-20. [pmid: 14756620].
136 Suen LKP, Wong TKS, Leung AWN. Effectiveness of auricular therapy on sleep promotion in the elderly. Am J Chin Med. 2002;30(4):429-49. [pmid: 12568272].
137 Suen LKP, Wong TKS, Leung AWN, et al. The Long-Term Effects of Auricular Therapy Using Magnetic Pearls on Elderly With Insomnia. Complement Ther Med. 2003;11(2):85-92. [pmid: 12801493].
138 Suhner AG, Murphy PJ, Campbell SS. Failure of timed bright light exposure to alleviate age-related sleep maintenance insomnia. J Am Geriatr Soc. 2002;50(4):617-23. [pmid: 11982660].
139 Tan T, Kales J, Kales A, et al. Inpatient multidimensional management of treatment-resistant insomnia. Psychosom J Consult Liaison Psychiatry. 1987;28(5):266-72.
140 Thoresen CE, Coates TJ, Kirmil-Gray K, et al. Behavioral self-management in treating sleep-maintenance insomnia. J Behav Med. 1981;4(1):41-52. [pmid: 7026793].
141 Tilleard-Cole RR. A placebo-controlled, dose-ranging study comparing 0.5 mg, 1 mg and 2 mg flunitrazepam in out-patients. Curr Med Res Opin. 1983;8(8):543-6. [pmid: 6653132].
142 Timotijevic I, Tasic A, Vezmar M, et al. Brotizolame (Lendormin) in treatment of insomnia and anxious-depressive disorders. Psihijatr Danas. 1997;29(12):61-77.
143 Turner RM, Ascher LM. A within-subject analysis of stimulus control therapy with severe sleep-onset insomnia. Behav Res Ther. 1979;17(2):107-12. [pmid: 426741].
144 Turner RM, Ascher LM. Therapist factor in the treatment of insomnia. Behav Res Ther. 1982;20(1):33-40. [pmid: 7066001].
145 Verbeek I, Schreuder K, Declerck G. Evaluation of short-term nonpharmacological treatment of insomnia in a clinical setting. J Psychosom Res. 1999;47(4):369-83. [pmid: 10616231].
146 Vermeeren A, O'Hanlon JF, Declerck AC, et al. Acute effects of zolpidem and flunitrazepam on sleep, memory and driving performance, compared to those of partial sleep deprivation and placebo. Acta Ther. 1995;21(1):47-64.
147 Vgontzas AN, Kales Aa, Bixler EO, et al. Temazepam 7.5 mg: Effects on sleep in elderly insomniacs. Eur J Clin Pharmacol. 1994;46(3):209-13. [pmid: 8070501].
148 Viens M, De Koninck J, Mercier P, et al. Trait anxiety and sleep-onset insomnia: evaluation of treatment using anxiety management training. J Psychosom Res. 2003;54(1):31-7. [pmid: 12505553].
149 Vincent N, Lionberg C. Treatment preference and patient satisfaction in chronic insomnia. Sleep. 2001;24(4):411-17. [pmid: 11403525].
150 Vogel GW. Sleep laboratory study of lormetazepam in older insomniacs. Psychopharmacol 1984;(Suppl 1):69–78.
151 Vogel GW, Morris D. The effects of estazolam on sleep, performance, and memory: a long-term sleep laboratory study of elderly insomniacs. J Clin Pharmacol. 1992;32(7):647-51. [pmid: 1640005].
152 Walsh JK, Schweitzer PK. Ten-year trends in the pharmacological treatment of insomnia. Sleep. 1999;22(3):371-5. [pmid: 10341388].
153 Walsh J, Schweitzer P, Parwatikar S. Effects of lorazepam and its withdrawal on sleep performance and subjective state. Clin Pharmacol Ther. 1983;34(4):496-500. [pmid: 6617072].
154 Webb M, Kirker JG. Severe post-traumatic insomnia treated with L-5-hydroxytryptophan. Lancet. 1981;1(8234):1365-6. [pmid: 6113331].
155 Wheatley D. Kava and valerian in the treatment of stress-induced insomnia. Phytother Res. 2001;15(6):549-51. [pmid: 11536390].
156 Wheatley D. Stress-induced insomnia treated with kava and valerian: Singly and in combination. Hum Psychopharmacol. 2001;16(4):353-6. [pmid: 12404572].
157 Wolsko PM, Eisenberg DM, Davis RB, et al. Use of mind-body medical therapies. J Gen Int Med. 2004;19(1):43-50.
158 Woolfolk RL, McNulty TF. Relaxation treatment for insomnia: a component analysis. J Consult Clin Psychol. 1983;51(4):495-503. [pmid: 6352753].
159 Wu R, Zhang C, Deng J, et al. Comparison between cognitive-behavior therapy and medication on chronic insomnia. [Chinese]. [References]. Chin Ment Health J. 2002;16(10):677-80.
160 Zung WW, Wilson WP. The treatment of insomnia with antidepressant drugs. Psychophysiol. 1968;5(2):234-5.

### Excluded - Design (No Placebo Arm)

The following studies were excluded because they did not have a placebo arm.

1 Agnoli A, Manna V, Martucci N. Double blind study on the hypnotic and anti-anxiety effects of zopiclone compared with nitrazepam in the treatment of insomnia. Int J Clin Pharmacol Res. 1989;9(4):277-81. [pmid: 2674029].
2 Allen R, Mendels J, Nevins D, et al. Efficacy without tolerance or rebound insomnia for midazolam and temazepam after use for one to three months. J Clin Pharmacol. 1987;27(10):768-75. [pmid: 2892863].
3 Bliwise D, Seidel W, Karacan I, et al. Daytime sleepiness as a criterion in hypnotic medication trials: Comparison of triazolam and flurazepam. Sleep. 1983;6(2):156-63. [pmid: 6136085].
4 Blumenthal M, Byring R, Koivula K. Comparison of nitrazepam 5 mg with triazolam 0.5 mg in young psychiatric insomniac inpatients: Double-blind single night cross-over study. Acta Psychiatr Scand. 1980;62(5):519-24. [pmid: 6111178].
5 Chaudoir PJ, Bodkin NL, O'Donnell J, et al. A comparative study of zopiclone and triazolam in patients with insomnia. Int Clin Psychopharmacol. 1990;5(Suppl 2):21-7. [pmid: 2201727].
6 Cluydts R, Peeters K, De Bouyalsky I, et al. Comparison of continuous versus intermittent administration of zolpidem in chronic insomniacs: A double-blind, randomized pilot study. J Int Med Res. 1998;26(1324).
7 Cluydts R, Peeters K, De Bouyalsky I et al. A pilot, randomized, double-blind study of zolpidem 10 mg comparing intermittent versus continuous administration. Proceedings of the Sixth World Congress of Biological Psychiatry; 1997 Jun 22–27; Nice, France. Biol Psychiatry 1997; 42 (1 Suppl): S1–316.
8 Currie SR, Clark S, Hodgins DC, et al. Randomized controlled trial of brief cognitive-behavioural interventions for insomnia in recovering alcoholics. Addiction. 2004;99(9):1121-32. [pmid: 15317632].
9 Dehlin O, Bengtsson C, Rubin B. Comparison of zopiclone and propiomazine as hypnotics in outpatients: multicenter, double blind, randomized, parallel group comparison of zopiclone and propiomazine in insomniacs. Curr Med Res Opin. 1997;13(10):565-72. [pmid: 9327191].
10 Dehlin O, Rubin B, Rundgren A. Double-blind comparison of zopiclone and flunitrazepam in elderly insomniacs with special focus on residual effects. Curr Med Res Opin. 1995;13(6):317-24. [pmid: 8829890].
11 Dehlin O, Rundgren A, Borjesson L, et al. Zopiclone to geriatric patients. A parallel double-blind dose-response clinical trial of zopiclone as a hypnotic to geriatric patients - a study in a geriatric hospital. Pharmacol. 1983;27(Suppl 2):173-8.
12 Dordain G, Puech AJ, Simon P. Triazolam compared with nitrazepam and with oxazepam in insomnia: two double-blind, crossover studies analyzed sequentially. Br J Clin Pharmacol. 1981;11(Suppl 1):S43-9.
13 Dorn M. Wirksamkeit und Vertraglichkeit von Baldrian versus Oxazepam bei Nichtorganischen und nichtpsychiatrischen Insomnien: Eine randomisierte, doppelblinde, klinische Vergleichsstudie (Germ). Forsch Komplementarmed Klass Naturheilkd. 2000;7(2):79-84. [pmid: 10899744].
14 Fabre LF jr, Gross L, Pasigajen V, et al. Multiclinic double-blind comparison of triazolam and flurazepam for seven nights in outpatients with insomnia. J Clin Pharmacol. 1977;17(7):402-9. [pmid: 18492].
15 Feighner JP, Brown SL, Olivier JE. Electrosleep therapy. A controlled double blind study. J Nerv Ment Dis. 1973;157(2):121-8. [pmid: 4724809].
16 Fleming JA, McClure DJ, Mayes C, et al. A comparison of the efficacy, safety and withdrawal effects of zopiclone and triazolam in the treatment of insomnia. Int Clin Psychopharmacol. 1990;5(Suppl 2):29-37. [pmid: 2201728].
17 Frattola L, Maggioni M, Cesana B, et al. Double blind comparison of zolpidem 20 mg versus flunitrazepam 2 mg in insomniac inpatients. Drugs Exp Clin Res. 1990;16(7):371-6. [pmid: 2092963].
18 Fritz OA, Arias OJL, Dorantes JF, et al. Brotizolam and chronic insomnia: A multi-centre study. Br J Clin Pharmacol. 1983;16(Suppl 2):S413-414.
19 Hajak G, Cluydts R, Declerck A et al. Continuous versus non-nightly use of zolpidem in chronic insomnia: results of a large-scale, double-blind, randomized, outpatient study.[erratum appears in Int Clin Psychopharmacol 2002 Jul;17(4)206]. Int Clin Psychopharmacol 2002; 17(1):9–17
20 Herrera-Arellano A, Luna-Villegas G, Cuevas-Uriostegui M, et al. Polysomnographic evaluation of the hypnotic effect of Valeriana edulis standardized extract in patients suffering from insomnia. Planta Med. 2001;67(8):695-9. [pmid: 11731907].
21 Jovanovic UJ, Dreyfus JF. Polygraphical sleep recordings in insomniac patients under zopiclone or nitrazepam. Pharmacol. 1983;27(Suppl 2):136-45.
22 Kales A, Bixler EO, Vela-Bueno A, et al. Comparison of short and long half-life benzodiazepine hypnotics: triazolam and quazepam. Clin Pharmacol Ther. 1986;40(4):378-86. [pmid: 3530586].
23 Kales A, Soldatos C, Bixler E, et al. Midazolam dose response studies of effectiveness and rebound insomnia. Pharmacol Basel. 1983;26(3):138-49.
24 Kellner R, Silverberg L, Bennett J, et al. First night effects of triazolam in insomnia. Curr Ther Res. 1985;37:619-25.
25 Klimm HD, Dreyfus JF, Delmotte M. Zopiclone versus nitrazepam: a double-blind comparative study of efficacy and tolerance in elderly patients with chronic insomnia. Sleep. 1987;10(Suppl 1):73-8. [pmid: 3326118].
26 Krakow B, Melendrez D, Sisley BN, et al. A randomized controlled trial of nasal dilator strip therapy for sleep maintenance insomnia. Sleep. 2003;26:A303.
27 Leibowitz M, Sunshine A. Long term hypnotic efficacy and safety of triazolam and flurazepam. J Clin Pharmacol. 1978;18:302-9. [pmid: 25288].
28 Linet OI, Rudzik AD. Comparison of triazolam and methyprylon as a hypnotic in insomniacs. Psychopharmacol Commun. 1975;15(47380).
29 Lomen P, Linet OI. Hypnotic efficacy of triazolam and methyprylon ininsomniac in-patients. J Int Med Res. 1976;4(1):55-8. [pmid: 16792].
30 Lorizio A, Terzano MG, Parrino L, et al. Zolpidem: A double-blind comparison of the hypnotic activity and safety of a 10-mg versus 20-mg dose. Curr Ther Res Clin Exp. 1990;47(5):889-98.
31 Mamelak M, Csima A, Price V. Comparative 25 night sleep laboratory study on the effects of quazepam and triazolam on chronic insomniacs. J Clin Pharmacol. 1984;24:65-75. [pmid: 6143767].
32 Mauri MC, Gianetti S, Pugnetti L, et al. Quazepam versus triazolam in patients with sleep disorders: A double-blind study. Int J Clin Pharmacol Res. 1993;13(3):173-7. [pmid: 7901174].
33 McClure DJ, Walsh J, Chang H, et al. Comparison of lorazepam and flurazepam as hypnotic agents in chronic insomniacs. J Clin Pharmacol. 1988;28(1):52-63. [pmid: 3280615].
34 Melo de Paula AJ. Comparative study of zopiclone and pentobarbitone as hypnotics. Int Pharmacopsychiatry. 1982;17(Suppl 2):188-95. [pmid: 6765243].
35 Mouret J, Ruel D, Maillard F, et al. Zopiclone versus triazolam in insomniac geriatric patients: a specific increase in delta sleep with zopiclone. Int Clin Psychopharmacol. 1990;5(Suppl 2):47-55. [pmid: 2201730].
36 Richards HH, Valle-Jones CJ. A double-blind comparison of two lormetazepam doses in elderly insomniacs. Curr Med Res Opin. 1988;11(1):48-55. [pmid: 3289831].
37 Roehrs T, Bonahoom A, Pedrosi B, et al. Nighttime versus daytime hypnotic self-administration. Psychopharmacol. 2002;161(2):137-42.
38 Saletu B, Saletu-Zyhlarz G, Anderer P, et al. Nonorganic insomnia in generalized anxiety disorder. 2 Comparative studies on sleep, awakening, daytime vigilance and anxiety under lorazepam plus diphenhydramine (Somnium) versus lorazepam alone, utilizing clinical, polysomnographic and EEG mapping methods. Neuropsychobiol. 1997;36(3):130-52.
39 Scharf M, Sachais B, Mayleben D, et al. A polysomnographic comparison of temazepam 15 and 30 mg with triazolam 0125 and 025 mg in chronic insomnia. Curr Ther Res. 1990;48(3):555-67.
40 Singh AN, Bourgouin J. Comparison of zopiclone and flurazepam treatments in insomnia. Hum Psychopharmacol. 1990;5(3):217-23.
41 Smirne S, Cassano GB, Ferrillo F, et al. Brotizolam versus triazolam for the treatment of insomnia in anxious patients. Curr Ther Res Clin Exp. 1993;53(1):9-17.
42 Tamminen T, Hansen PP. Chronic administration of zopiclone and nitrazepam in the treatment of insomnia. Sleep. 1987;10(Suppl 1):63-72. [pmid: 3326117].
43 Tsutsui S. A double-blind comparative study of zolpidem versus zopiclone in the treatment of chronic primary insomnia. J Int Med Res. 2001;29(3):163-77. [pmid: 11471853].
44 Venter CP, Joubert PH, Stahmer SD, et al. Zopiclone compared with triazolam in insomnia in geriatric patients. Curr Ther Res. 1986;40:1062-8.
45 Vogel GW, Vogel F. Effect of midazolam on sleep of insomniacs. Br J Clin Pharmacol. 1983;16(Suppl 1):S103-108.
46 Voshaar RCO, Van Balkom A, Zitman FG. Zolpidem Is Not Superior to Temazeparn With Respect to Rebound Insomnia: a Controlled Study. Eur Neuropsychopharmacol. 2004;14(4):301-6. [pmid: 15163440].
47 Wheatley D. Brotizolam: a new short-acting hypnotic. Int Clin Psychopharmacol. 1986;1(1):36-44. [pmid: 3549870].
48 Ziegler G, Ploch M, Miettinen-Baumann A, et al. Efficacy and tolerability of valerian extract Li 156 compared with oxazepam in the treatment of non-organic insomnia - a randomized, double-blind, comparative clinical study. Eur J Med Res. 2002;7(11):480-6. [pmid: 12568976].

### Excluded - Design (Not Double-Blind)

The following studies were excluded because they were not double-blind.

1 Bliwise D, Seidel W, Greenblatt DJ, et al. Nighttime and daytime efficacy of flurazepam and oxazepam in chronic insomnia. Am J Psychiatry. 1984;141(2):191-5. [pmid: 6691478].
2 Bonnet MH, Arand DL. The use of lorazepam TID for chronic insomnia. Int Clin Psychopharmacol. 1999;14(2):81-9. [pmid: 10220122].
3 Brown WT. A comparative study of three hypnotics: methyprylon, glutethimide and chloral hydrate. Can Med Assoc J. 1970;102(5):510-1. [pmid: 4914614]. [pmcid: 1946598].
4 Chen HC, Hsieh MT. Clinical trial of suanzaorentang in the treatment of insomnia. Clin Ther. 1985;7(3):334-7. [pmid: 3888394].
5 Hedner J, Emilien G, Salinas E. Zaleplon reduces sleep latency and improves sleep quality in elderly patients with primary insomnia. No pub Proceedings of the XXIst Collegium Internationale Neuropsychopharmacologicum; 1987 Jul 12–16; Glasgow, Scotland. 1998;():S212–3.
6 Johnson LC, Chernik DA, Hauri P. A multicenter 14-day study of flurazepam and midazolam in chronic insomniacs: general discussion and conclusions. J Clin Psychopharmacol. 1990;10(4 Suppl):76S-90S. [pmid: 2229466].
7 Judd L, Ellinwood E, McAdams L. Cognitive performance and mood in patients with chronic insomnia during 14-day use of flurazepam and midazolam. J Clin Psychopharmacol. 1990;10(4 Suppl):S56-67.
8 Kales A, Kales JD, Bixler EO, et al. Effectiveness of hypnotic drugs with prolonged use: flurazepam and pentobarbital. Clin Pharmacol Ther. 1975;18(3):356-63. [pmid: 240529].
9 Kripke D, Hauri P, Ancoli I, et al. Sleep evaluation in chronic insomniacs during 14-day use of flurazepam and midazolam. J Clin Psychopharmacol. 1990;10(4 Suppl):S32-43.
10 Mitler MM, Carskadon MA, Phillips RL, et al. Hypnotic efficacy of temazepam: a long-term sleep laboratory evaluation. Br J Clin Pharmacol. 1979;8(1):S63-8.
11 Morin CM, Bastien CH, Brink D, et al. Adverse effects of temazepam in older adults with chronic insomnia. Hum Psychopharmacol Clin Exp. 2003;18(1):75-82.
12 Roehrs T, Bonahoom A, Pedrosi B, et al. Treatment regimen and hypnotic self-administration. Psychopharmacol. 2001;155(1):11-17.
13 Saletu ZGM, Anderer P, Berger P, et al. Nonorganic insomnia in panic disorder: Comparative sleep laboratory studies with normal controls and placebo-controlled trials with alprazolam. Hum Psychopharmacol. 2000;15(4):241-54. [pmid: 12404319].
14 Saletu ZG, Anderer P, Brandstatter N, et al. Placebo-controlled sleep laboratory studies on the acute effects of zolpidem on objective and subjective sleep and awakening quality in nonorganic insomnia related to neurotic and stress-related disorder. Neuropsychobiol. 2000;41(3):139-48.
15 Sateia MJ, Hauri P, Kripke D, et al. Clinical safety of flurazepam and midazolam during 14-day use in chronic insomniacs. J Clin Psychopharmacol. 1990;10(Suppl 4):S28-31.

### Excluded - Outcomes (Irrelevance)

The following studies were excluded because they did not report on any outcomes of this review.

1 Baillargeon L, Landreville P, Verreault R, et al. Discontinuation of benzodiazepines among older insomniac adults treated with cognitive-behavioural therapy combined with gradual tapering: A randomized trial. Can Med Assoc J. 2003;169(10):1015-20. [pmid: 14609970]. [pmcid: 236226].
2 Bliwise D, Seidel W, Cohen S, et al. Profile of mood states changes during and after 5 weeks of nightly triazolam administration. J Clin Psychiatry. 1988;49(9):349-55. [pmid: 3047100].
3 Bonnet MH. Recovery of performance during sleep following sleep deprivation in older normal and insomniac adult males. Percept Mot Skills. 1985;60(1):323-34. [pmid: 3982941].
4 Chernik D, Johnson L, Kanitra L. Sleep performance and plasma levels in chronic insomniacs during 14-day use of flurazepam and midazolam methodology. J Clin Psychopharmacol. 1990;10(4 Suppl):S10-19.
5 Dement W. Objective measurements of daytime sleepiness and performance comparing Quazepam with Flurazepam in two adult populations using the multiple sleep latency test. J Clin Psychiatry. 1991;52(Suppl):31-7. [pmid: 1680123].
6 Demisch K, Bauer J, Georgi K. Treatment of severe chronic insomnia with L-tryptophan and varying sleeping times. Pharmacopsychiatry. 1987;20(6):245-8. [pmid: 3432358].
7 Hajak G, Clarenbach P, Fischer W, et al. Rebound insomnia after hypnotic withdrawal in insomniac outpatients. Eur Arch Psychiatry Clin Neurosci. 1998;248(3):148-56. [pmid: 9728734].
8 Johnson LC, Chernik DA, Sateia MJ. Sleep, performance, and plasma levels in chronic insomniacs during 14-day use of flurazepam and midazolam: an introduction. J Clin Psychopharmacol. 1990;10(4 Suppl):S5-9.
9 Kales A, Scharf MB, Kales JD, et al. Rebound insomnia. A potential hazard following withdrawal of certain benzodiazepines. J Am Med Assoc. 1979;241(16):1692-5.
10 Lemoine P, Allain H, Janus C, et al. Gradual withdrawal of zopiclone (75 mg) and zolpidem (10 mg) in insomniacs treated for at least 3 months. Eur Psychiatry. 1995;10(Suppl 3):S161-5.
11 Lushington K, Pollard K, Lack L, et al. Daytime melatonin administration in elderly good and poor sleepers: effects on core body temperature and sleep latency. Sleep. 1997;20(12):1135-44. [pmid: 9493923].
12 Morin CM, Azrin NH. Stimulus control and imagery training in treating sleep-maintenance insomnia. J Consult Clin Psychol. 1987;55(2):260-2. [pmid: 3571683].
13 Morin CM, Bastien C, Guay B, et al. Randomized Clinical Trial of Supervised Tapering and Cognitive Behavior Therapy to Facilitate Benzodiazepine Discontinuation in Older Adults With Chronic Insomnia. Am J Psychiatry. 2004;161(2):332-42. [pmid: 14754783].
14 Morin CM, Blais F, Savard J. Are changes in beliefs and attitudes about sleep related to sleep improvements in the treatment of insomnia?. Behav Res Ther. 2002;40(7):741-52. [pmid: 12074370].
15 Nakra BR, Gfeller JD, Hassan R. A double-blind comparison of the effects of temazepam and triazolam on residual, daytime performance in elderly insomniacs. Int Psychogeriatr. 1992;4(1):45-53. [pmid: 1391671].
16 Nelson J, Harvey AG. The differential functions of imagery and verbal thought in insomnia. J Abnorm Psychol. 2002;111(4):665-9. [pmid: 12428780].
17 Poyares D, Guilleminault C, Ohayon MM, et al. Chronic benzodiazepine usage and withdrawal in insomnia patients. J Psychiatr Res. 2004;38(3):327-34. [pmid: 15003439].
18 Scharf MB, Fletcher K, Graham JP. Comparative amnestic effects of benzodiazepine hyponotic agents. J Clin Psychiatry. 1988;49(4):134-7. [pmid: 2895761].

### Excluded - Outcomes (Inadequate Reporting)

The following study was excluded because data relevant to the outcomes of interest were inadequately reported.

1 Chen D, Chernik DA, Ellinwood E, et al. A multicenter study of sleep, performance, and plasma levels in chronic insomniacs during 14-day use of flurazepam and midazolam: executive summary. J Clin Psychopharmacol. 1990;10(4 Suppl):S3-4.
2 Dominguez RA, Goldstein BJ, Jacobson AF, et al. Hypnotic efficacy of a modified triazolodiazepine, brotizolam. Clin Pharmacol Ther. 1985;37:674-9. [pmid: 3891191].
3 Ebrahim IO, Fisher JP, De Lacy S, et al. A Prospective, Randomized, Study Comparing Cognitive Behaviour Therapy, Pharmacologic Treatment and Combination Therapy in Non-Elderly Patients With Primary Insomnia. Sleep. 2003;26:A301-A302.
4 Elie R, Deschenes JP. Efficacy and tolerance of zopiclone in insomniac geriatric patients. Rev Geriatr. 1994;19(1):45-50.
5 Elie R, Lavoie G, Bourgouin J et al. Zopiclone versus flurazepam in insomnia: prolonged administration and withdrawal. Int Clin Psychopharmacol 1990; 54(279–86).
6 Guilleminault C, Palombini L, Poyares D, et al. Chronic insomnia, premenopausal women and sleep disordered breathing - Part 2 Comparison of nondrug treatment trials in normal breathing and UARS post menopausal women complaining of chronic insomnia. J Psychosom Res. 2002;53(1):617-23. [pmid: 12127180].
7 Hajak G, Clarenbach P, Fischer W, et al. Effects of hypnotics on sleep quality and daytime well-being data from a comparative multicentre study in outpatients with insomnia. Eur Psychiatry. 1995;10(Suppl 3):S173-9.
8 Hindmarch I. Effects of zopiclone on quality of life in insomnia. Eur Psychiatry J Assoc Eur Psychiatrists. 1995;10(Suppl 3):S91-4.
9 Johnson RK. Differential treatments for internal and external locus of control insomniac clients. Louisville, (KY): University of Louisville; 1976
10 Ladouceur R, Gros-Louis Y. Paradoxical intention vs stimulus control in the treatment of severe insomnia. J Behav Ther Exp Psychiatry. 1986;17(4):267-9. [pmid: 3805311].
11 Partinen M, Hirvonen K, Hublin C, et al. Effects of after-midnight intake of zolpidem and temazepam on driving ability in women with non-organic insomnia. Sleep Med. 2003;4(6):553-61. [pmid: 14607350].
12 Riedel B, Lichstein K, Peterson BA, et al. A comparison of the efficacy of stimulus control for medicated and nonmedicated insomniacs. Behav Modif. 1998;22(1):3-28. [pmid: 9567734].
13 Saletu B. Sleep, vigilance and cognition in postmenopausal women: placebo-controlled studies with 2 mg estradiol valerate, with and without 3 mg dienogest. Climacteric. 2003;6(Suppl 2):37-45. [pmid: 14669843].
14 Sanavio E. Pre-sleep cognitive intrusions and treatment of onset-insomnia. Behav Res Ther. 1988;26(6):451-9. [pmid: 3240227].
15 Seidel WF, Cohen SA, Bliwise NG, et al. Buspirone: an anxiolytic without sedative effect. Psychopharmacol. 1985;87(3):371-3.