# Appendix D: Technical Expert Panel

The Technical Experts for this review are outlined below. Some of their professional affiliations are briefly described. The panel was consulted for their opinion regarding the definition of chronic insomnia used in the review, the inclusion criteria for the review and data analysis. They were also asked to provide feedback on the draft report.

- J. Todd Arnedt, Ph.D.
- Clinical Assistant Professor
- Sleep and Chronophysiology Laboratory
- Departments of Psychiatry and Neurology
- University of Michigan, Ann Arbor, MI

- Richard R. Bootzin, PhD
- Professor, University of Arizona, Department of Psychology;
- Professor, University of Arizona, Department of Psychiatry,
- College of Medicine; Director, Sleep Disorders Center, Insomnia Program,
- University of Arizona, College of Medicine

- Irvin Mayers, MD
- Professor, University of Alberta, Pulmonary Medicine;
- Director, University of Alberta, Pulmonary Medicine Division.

- Parameswaran Nair, MD, PhD
- Assistant Professor of Medicine,
- McMaster University, Division of Respirology.

- Larry Pawluk, MD
- Associate Professor,
- University of Alberta, Department of Psychiatry;
- Director, Sleep Medicine Program,
- University of Alberta, Department of Psychiatry.

- Arthur J. Spielman, PhD
- Professor, The City College of CUNY, Department of Psychology;
- Associate Director, Center for Sleep Disorders Medicine and Research, New York Methodist Hospital, Brooklyn, NY;
- Associate Director, Center for Sleep Medicine, Neurology, New York Presbyterian Hospital-Cornell, NY/Weill Medical College, Cornell University.