# Appendix C: Evidence Tables

Evidence Table C-1: Prevalence, natural history, incidence and associated factors of chronic insomnia in adults

AUTHOR / YEAR | STUDY DESIGN & POPULATION CHARACTERISTICS | | CO-MORBIDITY / PREVALENCE / NATURAL HISTORY / INCIDENCE / ASSOCIATED FACTORS
QUALITY (score)
Ancoli-Israel, S / 1999 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (3/8) | Age Group: | 18->65 yrs | All: (ChI) 9% (90/1000) 95%CI: 7.23–10.77. No prevalence data by gender.
| Gender | | >65 group: 20% (37/183) 95%CI:14.20–25.80
| Female: | NR | [underlined: Associated Factors] :
| Male: | NR | Significant
| Ethnicity: | White:86%(860/1000) | Socioeconomic status: (<$50,000/yr vs >$50,000/yr): 42% vs 31%; OR (no insomnia) 0.89; 95%C: 0.55–1.43, p=0.04.
| | Black:8%(80/1000) | Non-significant
| | Hispanic:3%(30/1000) | Age: (<65 vs >65):37% vs 44%; OR (no insomnia) 1.33; 95%CI: 0.83–2.14, p=0.29. Race/ethnicity: (White vs non-Caucasian) 38% vs 35%; OR (no insomnia) 1.59; 95%CI: 0.99–2.54, p=0.66; Socioeconomic status: Education: (≤ high school vs college): 41% vs 35%; OR (no insomnia) 0.78; 95%CI: 0.54–1.13, p=0.22.
| | Other:3%(30/1000)
| Sample Size: | 1950
| Response Rate: | 51.2%(1000/1950)
Bastien, CH / 2003 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (5/9) | Age Group: | >55 yrs X=62.5±5.8 | 3 groups: drug-free insomniacs (INS) vs benzodiazepine use insomniacs (INSBZ) vs good sleepers (GS); mean scores ± SD
| Gender | | Significant
| Female: | 30 | Psychiatric illness and psychological problems: 1) Depression (BDI): INS vs GS: 9.00 ± 4.48 vs 1.75 ± 1.68, p<0.01. INSBZ vs GS: 9.40 ± 7.16 vs 1.75 ± 1.68, p<0.01; 2) Anxiety (BAI): INS vs GS: 9.10 ± 8.38, p<0.01; INSBZ vs GS: 8.60 ± 5.44 vs 1.20 ± 1.47; (p<0.01). 3) Sleep impairment index: INS vs INSBZ vs GS: 17.9 ± 4.85, 16.85 ± 4.55, 1.60 ± 1.88, p<0.01.
| Male: | 30 | Non-significant
| Ethnicity: | | INS vs INSBZ vs GS: 61.7 ± 6.43, 62.3 ± 5.89, 63.35 ± 5.15, p=NS. Socioeconomic status: Education: INS vs INSBZ vs GS: 13.6 ± 5.15, 11.65 ± 2.76, 13.35 ± 3.67, p=NS. Cognitive function: 1)FolsteinMini-mental State Exam: INS vs INSBZ vs GS: 29.1 ± 1.12, 28.75 ± 1.2, 28.85 ± 1.04, p=NS. 2) Vocabulary: INS vs INSBZ vs GS: 12.65 ± 3.84, 12.0 ± 3.09, 13.30 ± 2.36, p=NS. Information: INS vs INSBZ vs GS: 10.15 ± 3.51, 10.0 ± 3.01, 11.5 ± 3.40, p=NS.
| Sample Size: | 60
| Response Rate: | NR
Bixler, EO / 2002 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (3/8) | Age Group: | > 20 yrs | Insomnia ≥1 year: 7.5% (131/1741), 95%CI: 6.27–8.73.
| Gender | | [underlined: Associated Factors] :
| Female: | 57.4%(1000/1741) | Significant
| Male: | 42.6%(741/1741) | Age: CS vs CT: 50.4 ± 1.0 vs 46.9 ± 0.7 yrs, p=0.02. Gender: M vs F: 5.9% vs 9%; OR=1.6, 95%CI: 1.1–2.4, p<0.01. Race/ethnicity: Non-Caucasian vs Caucasian 12.9% vs 6.6%; OR: 2.1; 95%CI: 1.3–3.2, p<0.002. Psychiatric illness and psychological problems: Depression: adj OR: 5.5; 95%CI: 3.6–8.4, p<0.0001. Medical conditions: 1) Colitis: adj OR: 1.3; 95%CI: 1.0–6, p<0.02. 2) Hypertension: adj OR: 1.2; 95%CI: 1.1–1.3, p<0.0001. 3) Anemia: adj OR: 1.2; 95%CI: 1.1–1.4, p=0.004.
| Ethnicity: | NR | Non-significant
| Sample Size: | 1741 | None reported
| Response Rate: | 66.6%(1160/1741)
Bixler, EO / 1979 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (3/8) | Age Group: | > 18 yrs | Life-time prevalence: (Current or past insomnia): 42.5% (428/1006), 95%CI: 39.4–45.5. Current chronic insomnia: 32.2% (324/1006), 95%CI: 29.3–35.0. Gender: M vs F: 39% (172/443), 95%CI: 34.5–43.5 vs 61% (343/563), 95%CI: 57–65.
| Gender | | [underlined: Associated Factors] :
| Female: | 56%(563/1006) | Significant
| Male: | 44%(443/1006) | Age: >51yr (higher prevalence) 39.8%, 95%CI: 34.6–45.3, p<0.05. Psychiatric illness and psychological problems: 1) Tension: 29.2%, p<0.01. 2) Depression: 19.4%, p<0.05. 3) Loneliness: 12.9%, p<0.01. Medical conditions: 1) Presence of a persistent or recurring health problem: 50%, p<0.01. 2) Multiple health problems: 17.3%, p<0.05, 3) Hospitalizations during the past year: 15.7%, p<0.01.
| Ethnicity: | NR | Non-significant
| Sample Size: | 1006 | Gender: reported NS difference. Other factors:Marital/family problems: 17.8%, Alcohol related problems: 2.8 % & Mental Healthcare utilization: 9.2%, all p=NS.
| Response Rate: | NR
Bliwise, NG / 1992 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Low (1/9) | Age Group (years): | 68.4 ± 8.7, 49–82 (CS) | Significant
| | 67.5 ± 9.9, 52–95 (CT) | Psychiatric illness and psychological problems: (SCL-90-R Revised Symptom Checklist) CS vs CT: 1) Somatization: 0.66 ± 0.54 vs 0.26 ± 0.30, p<0.05. 2) Obsessive-compulsive: 1.06 ± 0.48 vs 0.68 ± 0.66, p<0.10. 3) Anxiety: 0.55 ± 0.68 vs 0.21 ± 0.26, p<0.10. 4) Phobic anxiety: 0.15 ± 0.25 vs 0.02 ± 0.05, p<0.05. 8) Paranoid ideation: 0.50 ± 0.49 vs 0.18 ± 0.23, p<0.05. 5) Psychoticism: 0.31 ± 0.27 vs 0.12 ± 0.23, p<0.05. 6 Geriatric Depression Scale (total score): 8.10 ± 7.64 vs 4.42 ± 0.47, p<0.10.
| Gender | | Non significant
| Female: | 38 | Psychiatric illness and psychological problems: 1) Interpersonal: 0.44 ± 0.33 vs 0.31 ± 0.38; 2) Depression: 0.75 ± 0.63 vs 0.54 ± 0.54; 3) Hostility: 0.33 ± 0.36 vs 0.16 ± 0.17. Other factors: Chronic illness, Psychosocial (widowed/divorced), Age, Socioeconomic status, Exercise, Alcohol and Caffeine intake all reported p=NS.
| Male: | 0
| Ethnicity: | NS
| Sample Size: | 38 total
| | 16 (CS)
| | 22 (CT)
| Response Rate: | NR
Bonnet, MH / 1995 | Study Design: | Cross-sectional matched case-control | [underlined: Associated Factors] :
High (7/9) | Age Group: | 18–50 yrs | Significant
| Gender | | Psychiatric illness and psychological problems: (Profile of Mood States scale): 1) Confusion: 5.4 ± 4.2 vs 3.1 ± 3.2, p<0.01. 2) Tension: 6.0 ± 5.8 vs 4.0 ± 3.8, p<0.05. 3) Depression: 9.0 ± 11.8 vs 4.1 ± 5.3, p<0.05. 4) Vigor: 16.4 ± 6.7 vs 21.5 ± 7.5, p<0.001. Memory and cognitive function: 1) Low results on short-term memory (# words): 5.7 ± 3.7 vs 7.2 ± 2.7, p=0.02. 2) Low results on MAST test (# correct): 53.2 ± 24 vs 60.5 ± 19, p<0.001.
| Female: | NR | Non Significant: (cases vs controls):
| Male: | NR | Memory and cognitive function: 1) Proofread lines: 246 ± 71 vs 258 ± 75; 2) Vigilance: 0.88 ± 0.15 vs 0.87 ± 0.16. Psychiatric illness and psychological problems: 1) Fatigue: 5.7± 5.7 vs 3.6 ± 4.3; 2) Anger: 5.6 ± 9.0 vs 3.8 ± 4.7. 2) MMPI scores: Hypochondriasis: 57 ± 13 vs 51 ± 6.6; Psychopathic deviate: 72 ± 12 vs 62 ± 14; M/F: 50 ± 7.7 vs 56 ± 12; Paranoia: 60 ± 6.5 vs 56 ± 7.4; Psychasthenia: 58 ± 10 vs 54 ± 6.4; Schizophrenia: 59 ± 12 vs 57 ± 7.1; Hypomania: 60 ± 16 vs 64 ± 12; Social introversion: 52 ± 12 vs 48 ± 9.3, all p=NS.
| Ethnicity: | NR
| Sample Size: | 40 total
| | 20 (CS)
| | 20 (CT)
| Response Rate: | 50%, 10/20 (CS)
| | 50%, 10/20 (CT)
Braga-Neto. P / 2004 | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
Low (2/8) | Age Group: | 34–86 yrs | Medically ill (Parkinson's disease).
| Gender | | [underlined: Prevalence] :
| Female: | 36% (31/86) | One-month prevalence: 53.3% (49/86) (95%CI: 42.8–63.8). No prevalence data by gender.
| Male: | 64% (55/86)
| Ethnicity: | NR
| Sample Size: | 86
| Response Rate: | NR
Broman, JE / 1996 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (6/8) | Age Group: | 20–64 yrs | Three-month prevalence: (ChI): 12% (47/396) 95%CI: 8.8–15.2.
| Gender | | [underlined: Associated Factors] :
| Female: | 53.1% (210/396) | Groups 1) M vs F; 2) Age: 20–34 (reference group), 35–49 and 50–64
| Male: | 46.9% (186/396) | Significant
| Ethnicity: | NR | (Basic Nordic Sleep Questionnaire scores) Medical conditions: 1) Personal illness (age): p<0.05. Quality of life: 1) Leisure activities (age): p<0.0001. 2) Having too little time (age): p<0.0001, 3) Watching TV (age): p<0.0001. Social relationships: 1) Relatives' illness (gender): p<0.05, 2) Children's sleeping pattern (age): p<0.0001. Cognitive function: (age) p<0.001; Somatic factor (age): p <0.05; Sleepiness (age): p<0.01;
| Sample Size: | 583 | Non-Significant
| Response Rate: | 68% (396/583) | (Basic Nordic Sleep Questionnaire scores)
| | | Quality of life: Working conditions/hours, low capacity for sleep both p=NS.
Broman, JE / 1992 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (5/9) | Age Group | | Significant
| mean ± SD: | 45.8 ± 11.5 yrs (CS) | Psychiatric illness and psychological problems: 1) Mood, anxiety and cognitive performance: (VAS for Tiredness): 61.0 vs 43.4, p<0.01. 2) State anxiety (State-Trait Anxiety Inventory): 39.9 ± 9.5 vs 32.6 ± 7.6, p<0.05.
| | 45.0 ± 10.2 yrs (CT) | Non-Significant
| Gender | | Objective performance: Reaction time dominant hand 1) Speed (ms:) 225.9 ± 42.3 vs 230.1 ± 43.3; 2) Variability: 64.1 ± 44.3 vs 54.3 ± 25.4; Word recognition 1) # correct: 19.5 ± 2.6 vs 19.8 ± 2.5; 2) Latency (s): 2.66 ± 1.01 vs 2.86 ± 0.87; Figure recognition 1) # correct: 12.9 ± 3.1 vs 12.2 ± 3.1; 2) Latency (s): 3.55 ± 1.46 vs 3.24 ± 1.07; Finger tapping dominant hand 1) # taps 61.0 ± 7.6 vs 61.7 ± 8.9; 2) Variability 3.9 ± 2.9 vs 4. ± 2.8, all p=NS. Psychiatric illness and psychological problems: VAS for Tension: 47.5 vs 38.5, Excitement 46.4 vs 41.7, Stress 40.9 vs 35.4, Concentration 53.6 vs 858.1; all p=NS. Behavior: (Jenkins Activity scale) all subscales p=NS.
| Female: | 15 (CS), 15 (CT)
| Male: | 5 (CS), 5 (CT)
| Ethnicity: | NR
| Sample Size: | 40 total
| | 20 (CS), 20 (CT)
| Response Rate: | NR
Chambers, MJ / 1993 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Low (1/9) | Age Group | | Significant
| mean ± SD: | 47.5 ± 10.9 yrs (CS) | Psychiatric illness and psychological problems: Anxiety 1) State anxiety: 39.1 ± 10.3 vs 31.7 ± 7.3, p<0.001. 2) Trait anxiety: 44.8 ± 9.8 vs 32.3 ± 7.7, p<0.001.
| | 45.9 ± 16.0 yrs (CT) | Non-Significant
| Gender | | None reported
| Female: | 64.5%, 20/31 (CS)
| | 60%, 21/35 (CT)
| Male: | 35.5%, 11/31 (CS)
| | 40%, 14/35 (CT)
| Ethnicity: | NR
| Sample Size: | 66 total
| | 31 (CS), 35 (CT)
| Response Rate: | NR
Coursey, RD / 1975 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (7/9) | Age Group | | Significant
| mean ± SD: | 44.7 ± 16.8 yrs | Psychiatric illness and psychological problems: 1) Anxious worriers (Byrne's Repression-Sensitization scale): 72.7 ± 19.2 vs 50.4 ± 20.9, p<0.01; Taylor Manifest Anxiety scale: 22.5 ± 9.5 vs 13.3 ± 11.6, p<0.01; Edward's Social Desirability scale: 25.4 ± 6.1 vs 30.1 ± 5.8, p<0.05; Eysenck's Neuroticism scale: 12.1 ± 4.5 vs 5.7 ± 4.6, p<0.001; Time competence: 28.4 ± 7.8 vs 19.8 ± 3.5, p<0.001; Zung's Depression scale: 53.0 ± 11.5 vs 35.7 ± 6.2, p<0.001; MMPI Psychastenia scale: 31.24 ± 7.06 vs 25.94 ± 3.75, p<0.01. 2) Concern with internal vs external stimuli (MMPI Hysteria scale): 20.0 ± 7.1 vs 21.5 ± 4.1, p<0.01, MMPI Hypochondriasis scale: 19.0 ± 5.3 vs 12.5 ± 3.1, p<0.001; Zuckerman Sensation-Seeking scale: 7.2 ± 3.2 vs 11.4 ± 3.7, p<0.001.
| Gender | | Memory and cognitive function: Wechsler Adult Intelligence Scale 1) Low scores: Block Completion: 9.2 ± 2.2 vs 11.5 ± 2.6, p<0.05, Object Assembly: 8.4 ± 3.4 vs 11.4 ± 3.4, p<0.05 and Performance IQ: 107.1 ± 13.5 vs 118.2 ± 12.6, p<0.05.
| Female: | 5 (CS), 5 (CT) | Non-significant
| Male: | 13 (CS), 13 (CT) | Psychiatric illness and psychological problems: 1) MMPI K: 14.24 ± 4.43 vs 16.33 ± 5.39; 2) MMPI Introversion scale: 29.24 ± 9.88 vs 24.39 ± 9.47; 3) Depression Adjective Checklist: 8.94 ± 6.78 vs 7.0 ± 6.32; 4) MMPI extroversion scale: 19.94 ± 4.71 vs 20.83 ± 4.51; 5) Eysenck's Extraversion: 11.82 ± 3.13 vs 11.56 ± 4.18; all p=NS. All Test honesty and other MMPI neurotic scales NS differences. Memory and cognitive function: Wechsler Adult Intelligence Scale NS difference in scores for: Information, Comprehension, Arithmetic, Similarities, Digit span, Vocabulary, Digit symbol, Picture arrangement, Verbal IQ, Full scale IQ.
| Ethnicity: | NR
| Sample Size: | 36 total
| | 18 (CS), 18 (CT)
| Response Rate: | NR
Crenshaw, MC / 1999 | Study Design: | Cross-sectional case-control | [underlined: Co-Morbidity] :
Moderate (3/9) | Age Group | | Stable medical conditions: 3.2 ± 2.4 vs 2.3 ± 1.7, p>0.10. CS vs CT: hypertension 43.8% (14/32) vs 34.4% (11/32); diabetes 9.4% (3/32) vs 3.1% (1/32), asthma 6.3% (2/32) vs 6.3% (2/32).
| mean ± SD: | 67.7 ± 4.8 yrs (CS) | [underlined: Associated Factors] :
| | 67.5 ± 5.7 yrs (CT) | Significant
| Gender | | None detected
| Female: | 16 (CS), 16 (CT) | Non-significant
| Male: | 16 (CS), 16 (CT) | Cognitive function: Performance measures: 1) SRT- latency (ms): 256.9 ± 77.1 vs 265.4 ± 92.7; 2) SRT - mean SD (ms): 57.6 ± 29.7 vs 67.9 ± 37.5; 3) CPT-mean latency (ms): 381.6 ± 60.0 vs 373.9 ± 60.0; 4) CPT-mean SD (ms): 60.5 ± 18.6 vs 60.9 ± 20.7; 5) SWAT - Part I: mean latency (ms): 306.9 ± 63.8 vs 293.0 ± 57.3; 6) SWAT - Part I: mean SD (ms): 64.3 ± 26.9 vs 68.3 ± 26.0; 7) SWAT - Part II: mean latency (ms): 472.8 ± 93.3 vs 478.2 ± 77.4; 8) SWAT - Part II: mean SD (ms): 99.7 ± 38.6 vs 111.8 ± 43.2. For all, p >0.10.
| Ethnicity: | NR | SRT = simple reaction time; CPT = continuous performance test; SWAT = Switching attention test.
| Sample Size: | 64 total
| | 32 (CS), 32 (CT)
| Response Rate: | NR
Dorsey, CM / 1997 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Low (2/9) | | | Non-significant
| Age Group: | 18–25 yrs | Psychiatric illness and psychological problems: Objective Insomnia vs Subjective Insomnia vs CTs: 1) Eysenck Personality Inventory Extraversion scale: 10.2 ± 3.9 vs 12.7 ± 3.9 vs 14.4 ± 3.7, p<0.058; 2) Neuroticism: 9.7± 3.4 vs 13.7 ± 4.4 vs 9.9 ± 4.3, p=0.062, 3) Sociability 5.0 ± 3.0 vs 6.8 ± 2.3 vs 7.7 ± 3.1 p >0.05.
| Gender
| Female: | 14
| Male: | 17
| Ethnicity: | NR
| Sample Size: | 31 total
| | 18 (CS), 13 (CT)
| Response Rate: | NR
Edinger, JD / 2000A | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (4/8) | Age Group: | 40–59 yrs (CS) | Significant
| | 40–59 yrs (CT) | Cognitive function: Performance measures - mean latencies (ms): 1) SWAT Part II: 406.7 ± 70.2 vs 464.5 ± 130.8, p=0.05; 2) SWAT-Part III-B-direction: 611.9 ± 110.0 vs 689.8 ± 177.9, p=0.05.
| Gender | | Non-significant
| Female: | 55.6%, 15/27 (CS) | Cognitive function: Performance measures - mean latencies (ms): 1) Simple reaction time: 222.0 ± 36.5 vs 229.5 ± 40.4, p=NS; 2) Continuous performance test: 353.8 ± 37.3 vs 362.7 ± 45.2, p=NS; 3) SWAT - Part I: 257.7 ± 38.0 vs 280.4 ± 53.0, p=NS; 4) SWAT - Part III-A-side: 459.7 ± 138.7 vs 543.2 ± 192.0, p=NS.
| | 51.6%, 16/31 (CT) | SWAT = Switching attention test
| Male: | 44.4%, 12/27 (CS)
| | 48.4%, 15/31 (CT)
| Ethnicity: | NR
| Sample Size: | 32 (CS), 32 (CT)
| Response Rate: | 84.4%, 27/32 (CS)
| | 96.9%, 31/32 (CT)
Edinger, JD / 2000B | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (8/9) | Age Group: | 40–79 yrs | Significant
| Gender | | Psychiatric illness and psychological problems: Objective Insomnia CS vs Objective normal sleepers: 1) Elevation in dysfunctional beliefs and attitudes about sleep control: 37.7 ± 11.6 vs 18.5 ± 10.9; p<0.05. Subjective Insomnia CS vs Subjective normal sleepers: 2) High scores on Trait portion of the State-Trait Anxiety Inventory (STAI-2): 37.0 ± 7.3 vs 28.9 ± 6.5; p<0.05. 3) High scores on the Beck Depression Inventory: 8.6 ± 5.2 vs 3.5 ± 3.3; p<0.05. 4) High scores on Dysfunctional beliefs and attitudes about sleep effects: 44.6 ± 18.6 vs 26.9 ± 20.4; p<0.05. 5) High scores on Dysfunctional beliefs and attitudes about sleep control: 33.6 ± 11.4 vs 18.3 ± 10.8; p<0.05. 6) High scores on Dysfunctional beliefs and attitudes about sleep needs: 46.3 ± 24.4 vs 30.6 ± 15.9; p<0.05.
| Female: | 32 (CS), 31 (CT) | Non-significant
| Male: | 32 (CS), 31 (CT) | Psychiatric illness and psychological problems: Objective Insomnia CS vs Objective normal sleepers: 1) Elevation in dysfunctional beliefs and attitudes about sleep [a] Effects: 41.5 ± 19.9 vs 33.2 ± 15.6, [b] Cause: 27.0 ± 18.5 vs 29.6 ± 18.2, [c] Needs: 38.3 ± 15.9 vs 37.2 ± 11.9, [d] Habits: 25.7 ± 13.9 vs 27.0 ± 11.1, all p>0.05. 2) High scores on Trait portion of the State-Trait Anxiety Inventory (STAI-2): 34.9 ± 6.7 vs 30.7 ± 6.1, p>0.05. 3) High scores on the Beck Depression Inventory: 6.8 ± 4.0 vs 4.6 ± 3.7, p>0.05. Subjective Insomnia CS vs Subjective normal sleepers: 1) High scores on Dysfunctional beliefs and attitudes about sleep [a] Cause: 30.6 ± 17.0 vs 23.0 ± 15.4, p>0.05; [b] Habits: 27.2 ± 13.3 vs 25.1 ± 12.7, p>0.05.
| Ethnicity: | NR
| Sample Size: | 128 total
| Response Rate: | 64 (CS), 64 (CT)
| | 100%, 64/64 (CS)
| | 95.3%, 61/64 (CT)
Fichtenberg, NL / 2002 | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
Moderate (4/8) | Age Group | | Traumatic back injury, spinal cord injury, or muskuloskeletal injury.
| mean ± SD: | 36.5 ± 14.5 yrs (TBI) | [underlined: Prevalence] :
| | 38.2 ± 13.5 yrs (SCI) | DSM-IV Criteria: 30% (15/50) 95%CI:27.3–42.7% of TBI patients. PSQI Criteria: 28% (14/50) 95%CI:15.6–40. 4) of TBI patients. 56% (14/25) 95%CI: 36.5–75.5 for SCI patients. 56% (14/25) 95%CI:36.5–75.5 for MSK patients.
| | 47.3 ± 12.2 yrs (MSK)
| Gender
| Female: | 44%, 22/50 (TBI)
| | 24%, 6/25 (SCI)
| | 80%, 20/25 (MSK)
| Male: | 56%, 28/50 (TBI)
| | 76%, 19/25 (SCI)
| | 20%, 5/25 (MSK)
| Ethnicity: | NR
| Sample Size: | 100 total
| | 50 (TBI), 25 (SCI),
| | 25 (MSK)
| Response Rate: | 100%
Hajak, G / 2001 | Study Design: | Cross-sectional case-control | [underlined: Prevalence] :
High (6/8) - cross sectional | Age Group: | Over 18 yrs | One-month prevalence: (Sleep disturbances) 45% (784/1913), 95%CI: 42.7–47.2%. (Severe insomnia): 4% (81/1913), 95%CI: 3.2–4.8%. Male: 3% (26/897), 95%CI: 1.89–4.11%. Female: 5% (51/1016), 95%CI: 3.66–6.34%.
High (7/9) - case control | Gender | Cross-sectional: | [underlined: Associated Factors] :
| Female: | 53.1% (1016/1913) | Significant
| Male: | 46.8% (897/1913) | Cross-sectional data: Gender: 1) Female: OR: 1.77; 95%CI: 1.09–2.86; p=0.04. Social relationships: 1) Separated or divorced: OR: 3.45; 95%CI: 1.84–6.47, p<0.01; 2) Living in cities > 20,000: OR: 12.88; 95%CI: 6.90–24.05, p=0.004.
| Ethnicity: | NR | Case-control: Healthcare utilization: 1) Regular medication use: OR: 1.63; 95%CI: 1.06–2.52; 2) # medical tests performed in ≤ 6 mo.: OR: 1.54; 95%CI: 1.02–2.34. Cross-sectional: Quality of life: 1) Bad/Very Bad QoL (SF-36) OR: 8.49; 95%CI: 3.28–21.97.
| Sample Size: | 1913 Cross-sectional: | Non-significant
| | 368 Case-control | Age: <65 vs > 65: OR 1.06; 95%CI: 0.60–1.89. Social Relationships: # in household, # children <15 yrs; Socioeconomic status: working status, type of employment; all p=NS. Healthcare utilization:1)Consult physician any reason: OR 1.31; 95%CI: 0.78–2.18; 2) Hospitalizations in <12 m: OR 1.38; 95% C!: 0.71–2.65. Quality of life: QoL dimensions (severe insomnia vs no sleep complaints; SF-36 scores); Vitality scale: 41.17 vs 62.7; Social functioning scale: 66.7 vs 90.23; Role emotional scale: 55.17 vs 87.57; Mental health scale: 50.35 vs 73.61; all p=NS.
| | 206 (CS), 162 (CT)
| Response Rate: | NR
Han, SY / 2002 | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
Low (2/8) | Age Group: | 27–78 yrs | Diabetes requiring hemodyalisis.
| Gender | | [underlined: Prevalence] :
| Female: | 39% (32/82) | Point prevalence: (Sleep difficulties ≥2 months): 68.2% (56/82), 95%CI: 58.2–78.2; Male: 72% (36/50), 95%CI: 59.5–84.4. Female: 62.5% (20/32), 95%CI: 45.7–79.2.
| Male: | 61% (50/82) | [underlined: Associated Factors] :
| Ethnicity: | NR | Significant
| Sample Size: | 82 | Psychiatric illness and psychological problems: 1) Depression (Center for Epidemiologic Studies of Depression scale - CES-D) score ± SD; insomnia vs non-insomnia: 25.2 ± 12.1 vs 18.9 ± 10.3; p=0.02. Medical conditions: 1) Dialysis adequacy: adj OR: 0.80; 95%CI: 0.67–0.98; p=0.028.
| Response Rate: | NR | Non-significant
| | | Age: Older vs younger: CS vs CT: 60.5 ± 9.0 vs 56.1 ± 9.6; p=0.053. Gender: M/F: OR 1.54; 95%CI: 0.06–3.92. Socioeconomic status:1)Education (>12yr vs ≤ 12yrs): OR 0.81; 95%CI: 0.25–2.63; 2) Job (yes/no) OR: 0.44; 95%CI: 0.17–1.13, p=NS. Medical conditions: Duration of diabetes, frequency of somatic symptoms, p=NS. Other factors: Smoking and Alcohol, p=NS.
Harvey, AG / 2003 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (3/9) | Age Group: | 20.4 ± 4.7 yrs (CS) | Significant
| | 22.3 ± 8.9 yrs (CT) | Psychiatric illness and psychological problems: Measures of Psychopathology 1) Sleep concern (scale: 0“Not at all” to 8“Very much”) 3.7 ± 1.8 vs 0.1 ± 0.3, p<0.001. Quality of life: Cost (scale: 0“There is no cost, sleeping badly does not effect me at all” to 10“Sleeping badly is extremely costly and significantly disrupts my life”) 5.5 ± 1.8 vs 3.9 ± 2.4, p<0.01. Psychiatric conditions: 1) Beck Anxiety Inventory 13.6 ± 9.6 vs 7.3 ± 7.2, p<0.01. 2) Penn State Worry Questionnaire 57.4 ± 15.1 vs 41.2 ± 14.9, p<0.001.
| Gender | | Non-significant
| Female: | 60%, 18/30 (CS) | Age:Insomnia vs good sleeper: (mean ± SD): 20.4 ± 4.7 vs 22.3 ± 8.9, p=NS.
| | 63.3%, 19/30 (CT) | Psychiatric illness and psychological problems: 1) Beck Depression Inventory 10.3 ± 7.3 vs 7.0 ± 6.6, p=0.07.
| Male: | 40%, 12/30 (CS)
| | 36.7%, 11/30 (CT)
| Ethnicity: | NR
| Sample Size: | 60 total
| | 30 (CS), 30 (CT)
| Response Rate: | NR
Hauri, PJ / 1997 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (7/9) | Age Group | | Significant
| mean ± SD: | 47.7 ± 11.8 yrs | Memory and cognitive function: (CS vs CT) Performance: 1) Simple reaction tasks: Sway Forward/backward (sec): 43.4 vs 41.2, p<0.02; Initiation time (msec): 486 ± 614 vs 330 ± 115, p<0.01; Total time (msec): 662 ± 683 vs 485 ± 16, p<0.02; 2) Complex reaction tasks: Initiation time (msec): 489 ± 218 vs 401 ± 98, p<0.02; Total time (msec): 740 ± 289 vs 633 ± 146, p<0.03; 3) Performance on Digit Span test (Number remembered): 21.4 vs 24.5; p<0.01), 4) Sleepiness throughout the day (Stanford Sleepiness scale mean scores: 3.67 vs 2.33; p<0.0001).
| Gender | | Non-significant
| Female: | 19 (CS), 19 (CT) | Memory and cognitive function: Performance: 1) Sway sideward (sec) 43.4 vs 49.7; 2) Simple reaction tasks: Movement time (msec) 188 ± 150 vs 156 ± 79; 3) Complex reaction tasks: Initiation time (msec) 259 ± 157 vs 230 ± 102; 3) Performance on Digit Span test: Divided Attention: Sum of squares 2711 vs 1826; Reaction time (msec) 2746 vs 2771; Digit symbol substitution: # attempted 58.9 vs 62.1, all p=NS.
| Male: | 7 (CS), 7 (CT)
| Ethnicity: | NR
| Sample Size: | 52 total
| | 26 (CS), 26 (CT)
| Response Rate: | NR
Healey, ES / 1981 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (8/9) | Age Group: | 19–63 yrs (CS) | Significant
| | 18–63 yrs (CT) | Psychiatric illness and psychological problems: Childhood variables 1) Nightmares (1–5 scale); 1 = never: 2.19 vs 1.58; p<0.05, 2) Sleeping problems (1–5 scale); 1 = never: 1.90 vs 1.48; p<0.05, 3) Sleep quality in childhood (1–5 scale); 1 = excellent: 1.90 vs 1.45; p<0.01, 4) Reporting of eating problems: 1.77 vs 1.35; p<0.05. Self concept (Adjective Checklist): 1) Affiliation: 42.3 vs 48.2; p<0.05, 2) Abasement: 54.4 vs 47.8; p<0.05, 3) Aggression: 55.9 vs 49.6; p<0.05, 4) Counseling readiness: 55.9 vs 47.4; p<0.01, 5) Low defensiveness: 43.1 vs 52.4; p<0.01, 6) Low self-control: 44.7 vs 50.3; p<0.05, 7) Low personal adjustment: 41.4 vs 50.9; p<0.01, 8) Low achievement: 46.1 vs 52.7; p<0.05, 9) Low dominance: 45.0 vs 52.6; p<0.05, 10) Low affiliation: 39.9 vs 49.7; p<0.001, 11) Poor self-perception: 59.3% vs 4.5%; p<0.01, 12)“Weak” self-perception: 65.2% vs 21.7%; p<0.01, 13) Passive traits: 60% vs 20%; p<0.05, 14) Nervousness (Health Questionnaire): 61.3% vs 31.8%; p<0.05, 15) Suicidal thoughts: Health Questionnaire: 35.5% vs 9.7%; p<0.05, 16) Incidence of emotional/mental disturbance (Health Questionnaire): 38.7% vs 6.5%; p<0.01. Medical conditions: 1) Total # illnesses (Health Questionnaire): 3.19% vs 1.84%; p<0.001, 2) Incidence of allergies (Health Questionnaire): 45.2% vs 12.9%; p<0.05. Socio-economic status: 1) Change in financial status (Social Readjustment Rating Scale): 53.23 vs 40.48 ± 69.37; p<0.05, 2) Change to different line of work: 56.13 vs 41.61; p<0.05. Healthcare utilization 1) More hospitalizations two years prior to onset of insomnia to evaluation time (Health Questionnaire): 1.55% vs 0.34%; p<0.01, 2) Major hospitalizations ≥ 3 days during same period (Health Questionnaire): 1.07% vs 0.26%; p<0.05. Quality of life: 1) Satisfaction with parent relationship (Life Satisfaction scale mean subscores; 1 = satisfied): 4.07 vs 2.85; p<0.01, 2) Satisfaction with social life (Life Satisfaction scale mean subscores; 1 = satisfied): 3.74 vs 2.94; p<0.05, 3) Satisfaction with leisure time (Life Satisfaction scale mean subscores; 1 = satisfied): 4.16 vs 3.16; p<0.05, 4) Satisfaction with living arrangements (Life Satisfaction scale mean subscores; 1 = satisfied): 3.26 vs 2.32; p<0.01, 5) Satisfaction with oneself (Life Satisfaction scale mean subscores; 1 = satisfied): 3.94 vs 2.48; p<0.01, 6) Satisfaction with health prior to sleep problem (Life Satisfaction scale mean subscores; 1 = satisfied): 2.90 vs 1.90; p<0.05, 7) Satisfaction with health in the present (Life Satisfaction scale mean subscores; 1 = satisfied): 3.84 vs 1.97; p<0.001, 8) Total number of health complaints (Health Questionnaire): 9.55 vs 5.87; p<0.001, 9) Lack of energy (Health Questionnaire): 64.5% vs 25.8%; p<0.05. Social relationships: 1) Mean # losses from social field: 1.19 ± 1.01 vs 0.52 ± 1.03; p<0.01. Memory and cognitive function: 1) Trouble concentrating (Health Questionnaire): 51.6% vs 12.9%; p<0.05. Other factors: Life events: 1) Life events year of insomnia onset (Life Change Unit scale): 157.52 ± 65.96 vs 91.90 ± 69.37; p<0.0), 2) Recent experiences during year of insomnia onset (Schedule of Recent Experience interview): 345.56 ± 148.08 vs 197.78 ± 158.64; p<0.01, 3) Mean # personal events experienced: 2.71 ± 1.97 vs 1.58 ± 1.95; p<0.05, 4) Mean # undesirable events: 2.68 ± 2.12 vs 1.03 ± 1.33; p<0.001.
| Gender | | Non-significant
| Female: | 22 (CS), 22 (CT) | Social relationships: Area of activity: 1) mean # life events: work, financial, legal, family, desirable, ambiguous, deaths; all p=NS. 2) Mean # entrances into social field 0.32 ± 0.60 vs 0.19 ± 0.48; p=NS.
| Male: | 9 (CS), 9 (CT)
| Ethnicity: | NS
| Sample Size: | 62 total
| | 31 (CS), 31 (CT)
| Response Rate: | NS
Hetta, J / 1999 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Low (0/8) | Age Group: | Over 18 yrs | One-month prevalence: 31% (155/499) (95%CI: 27–35). No prevalence data by gender.
| Gender
| Female: | NS
| Male: | NS
| Ethnicity: | NS
| Sample Size: | 1,996 total
| Response Rate: | 25%, 499/1996
Hidalgo, MP / 2002 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (5/8) | Age Group: | 18–35 yrs | One-year prevalence: (Sleep difficulties ≤ 1 mo): 26% (89/342) 95%CI: 21.3–30.6. No prevalence data by gender.
| Gender | | [underlined: Associated Factors] :
| Female: | 41.8%, 143/342 | Significant
| Male: | 58.2%, 199/342 | Psychiatric illness and psychological problems: 1) Minor psychiatric disorders and insomnia: adj OR: 2.45; 95%CI: 1.32–4.56; p<0.05.
| Ethnicity: | NS | Non-significant
| Sample Size: | 342 total | Gender: (F vs M) OR 0.87; 95%CI: 0.56–0.65; p=NS. Psychiatric illness and psychological problems: Hx psychopathologies: OR 0.99, 95%CI: 0.5 -1.96; p=NS.
| Response Rate: | NS
Hohagen, F / 1993 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (4/8) | Age Group: | 18–65 yrs | Six-month prevalence: (Severe, moderate, mild insomnia): 45.9% (1152/2512) 95%CI: 44–48. Severe: 18.7% (469/2512) 95%CI: 17.1–20.2. No prevalence data by gender.
| Gender | | [underlined: Associated Factors] :
| Female: | 55.3%, 1389/2512 | Significant
| Male: | 44.7%, 1123/2512 | Psychiatric illness and psychological problems: 1) Depression (mild chronic insomnia): n = 23, 8.0%; p<0.01; moderate ChI: n = 18, 7%; p<0.001; severe ChI: n = 85, 21.7%; p<0.001, 2) Neurosis/personality disorders (severe chronic insomnia): n = 28, 7.2%; p<0.001, 3) Acute psychological distress (moderate chronic insomnia): n = 20, 7.8%; p<0.001; severe ChI: n = 40, 10.2%; p<0.001, 4) Alcohol drug abuse (severe ChI): n = 18, 4.6%; p<0.001, 5) Psychosomatic disorders (severe ChI): n = 22, 5.6%; p<0.001.
| Ethnicity: | NS | Non-significant
| Sample Size: | 2,512 total | Psychiatric illness and psychological problems: 1) Neurosis/personality disorders - moderate Chll: n = 10, 3.9%; p=NS.
| Response Rate: | 97.9%, 2459/2512
Hohagen, F / 1994 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (4/8) | Age Group: | Over 65 yrs | Point prevalence: (All DSM-III-R insomnia): 56.3% (186/330) 95%CI: 50.9–61.6. Severe DSM-III-R insomnia: 23% (17/75) 95%: 18.4–27.5. No prevalence data by gender.
| Gender | | [underlined: Associated Factors] :
| Female: | 72%, 237/330 | Significant
| Male: | 8%, 93/330 | Gender: severe insomnia F/M 29.1 vs 7.9, p <0.001. Healthcare utilization: 1) Prescribed hypnotics - patient report: OR: 6.19; 95%CI: 3.19–12.0; p<0.001; physician report: OR: 2.09; 95%CI: 2.09–12.6; p<0.001. Psychiatric illness and psychological problems: Depression OR 2.93; 95%CI: 1.51–5.71; p <0.01. Mental disorders (Total) OR 1.71; 95%CI: 1.07–2.74 p <0.01.
| Ethnicity: | NS | Non-significant
| Sample Size: | 338 | Medical conditions (acute/chronic):reported NS.
| Response Rate: | 97.5%, 330/338
Ishigooka, J / 1999 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (5/8) | Age Group: | 15–65 yrs | Point prevalence: (Insomnia lasting ≥ 1 mo): 11.7% (735/6277), 95%CI: 10.9–12.4. Male: 11.2% (295/2632), 95%CI: 10–12.4. Female: 12% (440/3645), 95%CI: 10.9–13.
| Gender | | [underlined: Associated Factors] :
| Female: | 58.1%, 3645/6277 | Significant
| Male: | 41.9%, 2632/6277 | Age: 1) Older age group (45–54 yrs): OR 1.42; p<0.001; 55–64 yrs OR: 1.81; p<0.0001; 65+ OR: 1.64; p<0.001. Gender: Female/male: OR 1.12; p<0.05.
| Ethnicity: | All Asian (Japanese) | Healthcare utilization: 1) Neurology service: OR: 1.73; p<0.01), 2) Psychiatry service: OR: 3.85; p<0.0001. Other factors: 1) Living alone: OR: 1.18; p<0.05), 2) Dissatisfaction with sleep environment: OR: 1.58; p<0.0001.
| Sample Size: | 7112 total | Non-significant
| Response Rate: | 88.3%, 6277/7112 | Other factors: Occupation, Residential area, Season, Alcohol consumption, Smoking, Caffeine intake, Regularity of living; all p=NS. (no data)
Kageyama, T / 2001 | Study Design: | Cross-sectional study | [underlined: Prevalence] :
Moderate (5/8) | Age Group: | 24–59 yrs | Point prevalence: 29.2% (162/555) 95%CI:28.7, 29.7.
| Gender | | [underlined: Associated Factors] :
| Female: | NS | Significant
| Male: | NS | Age: (40–49 yrs reference group): <24 yrs: 34% (62/184), adj OR = 2.34; 95%CI: 1.19–4.62. Work performance: (CS vs CT, mean score ± SE): 1) Workload: 2.47 ± 0.06 vs 2.30 ± 0.004, p<0.05; 2) Mental workload: 2.41 ± 0.05 vs 2.25 ± 0.04, p<0.05; 3) Problem in personal relationships: 2.18 ± 0.06 vs 2.00 ± 0.03, p<0.05; 4) Job satisfaction: 2.51 ± 0.07 vs 2.67 ± 0.04, p<0.05; 5) Support from colleagues and superiors: 2.66 ± 0.05 vs 2.82 ± 0.03, p<0.01; 7) Severity of patients' illness: 2.79 ± 0.06 vs 2.57 ± 0.04, p<0.01. 8) # non-working days in ≤ 3mo: (≤ 6 days/mo): OR 2.62; 95%CI: 1.27–5.42; 9) # night shifts in ≤ 3mo. (≥ 9 nights/mo is reference gr): (1–3 nights/mo) OR 3.32; 95%CI: 1.0–11.16. Socioeconomic status: # working days in last 3 mo (<10 vs ≥10) p<0.05
| Ethnicity: | Japanese | Non-significant
| Sample Size: | 555 total | Age: (40–49 yrs reference group): 25–29 yrs: 26% (37/143), adj OR = 1.45; 95%CI: 0.69–30.2), 30–39 yrs: 29% (30/103), adj OR = 1.48; 95%CI: 0.71–3.11; 50–59 yrs: 33% (14/43), adj OR = 2.41; 95%CI: 0.96–6.05, all p=NS. Healthcare utilization: Undergoing medical treatment (no vs yes): 27% (119/441) vs 36% (37/104), p=NS. Work performance: (CS vs CT, mean score ± SE): 1) Job control: 2.36 ± 0.05 vs 2.45 ± 0.03, p=NS). 2) # non-working days in ≤ 3mo: 7–9 days/mo): OR 1.14; 95%CI: 0.74–1.76; 3) # night shifts in ≤ 3mo. (≥ 9 nights/mo is reference gr): (4–5 nights/mo) OR 2.75; 95%CI: 0.87–8.64; (6–8 nights/mo): OR 1.80; 95%CI: 0.54–6.02. Relationships: 1) Marital status OR 1.31; 95%CI: 0.89–1.94; 2) Difficulty in patient-nurse relationship: 1.94 ± 0.04 vs 2.10 ± 0.06. 3) # Children < 6: OR 0.95; 95%CI: 0.51–1.76, 4) # life events in ≤ 6 mo (≤ 1 vs ≥ 2): OR 0.74, 95%CI: 0.49–1.12. Medical conditions:Current OR 0.67, 95%CI: 0.43–1.05.
| Response Rate: | NS
Kageyama, T / 1997 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (6/8) | Age Group: | 20 - 80 yrs | Point prevalence: 11.2% (403/3600) 95%CI:10.2, 12.2.
| Gender | | [underlined: Associated Factors] :
| Female: | 3600 | Significant
| Male: | 0 | Age: (% ± SE, reference group 30–39 yr): 70+ years: 14.2% (46/322) ± 1.9, adj OR = 2.1; 95%CI: 1.1–3.8. Medical conditions: 1) Sleep apnea-like symptoms (absent vs present, absent is reference category): adj OR = 2.7; 95%CI: 1.6–4.8; 2) Heart Disease: OR = 2.4, p<0.01. Relationships: 1) Children ≤ 6 in home: OR 1.5; 95%CI: 1.0–2.1; 2) Major life event ≤6 mo: OR 1.4; 95%CI 1.1–1.9. Healthcare utilization: 1) Consulting a physician or other specialist (insomniacs vs non-insomniacs, % ± SE): Current: 11.4% ± 1.6 (46/403) vs 1.3% ± 0.2 (42/3197), OR = 9.68; 95%CI: 6.28–14.92; Past: 17.4% ± 1.9 (70/403) vs 4.9% ± 0.4 (157/3197), OR = 4.07; 95%CI: 3.00–5.51; Never: 71.2% ± 2.3 (287/403) vs 93.8% ± 0.4 (2999/3197), OR = 0.16; 95%CI: 0.13–0.21; 2) Undergoing medical treatment (yes vs no, no is reference category) adj OR = 2.1; 95%CI: 1.6–2.8. Work performance: (insomniacs vs non-insomniacs % ± SE): 1) Inefficiency in work: 17.2% ± 1.9 (69/403) vs 8.6% ± 0.5 (275/3197), p<0.001, OR = 2.20; 95%CI: 1.65–2.93; 2) Tardiness: 10.2% ± 1.5 (41/403) vs 4.4% ± 0.4 (141/3197), p<0.001, OR = 2.45; 95%CI: 1.71–3.53; 3) Prone to errors in work (8.9% ± 1.4 (36/403) vs 3.5% ± 0.3 (112/3197), p<0.001, OR = 2.70; 95%CI: 1.83–3.99.
| Ethnicity: | Japanese | Non-significant
| Sample Size: | 3600 total | Age: (% ± SE, reference group 30–39 yr): 20–29 yrs: 13.3% (45/337) ± 1.8, adj OR = 1.5; 95%CI: 0.9–2.5; 40–49 yrs: 9.2% (90/982) ± 0.9, adj OR = 1.1; 95%CI: 0.7–1.7, 50 - 59 yrs: 12.6% (107/852) ± 1.1, adj OR = 1.1; 95%CI: 0.8–2.0, 60–69 yrs 13.1% (66/501) ± 1.5, adj OR = 1.6; 95%CI: 0.9–2.6; all p=NS. Socio-economic status: (% with insomnia ± SE): employed: 10.5% (183/1739) ± 0.7, unemployed: 11.9% (195/1639) ± 0.8; p=NS. Social relationships: Marital Status: Married: 10.7% (291/2722) ± 0.2, Single 13.0% (94/721) ± 1.3, p=NS. Other factors: Exercise, Smoking, Alcohol, Caffeine all reported NS (no data).
| Response Rate: | Varied between district 51–59%
Kales, AK / 1983 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (4/9) | Age Group | 43.1 ± 0.9 (CS) | Significant
| mean ± SD: | 40.9 ± 1.5 (CT) | Psychiatric illness and psychological problems: (MMPI) (mean ± SE): 1) F Scale: 7.4 ± 0.2 vs 4.2 ± 0.3, p<0.01; 2) K Scale: 13.9 ± 0.3 vs 15.8 ± 0.5, p<0.01; 3) Hypochondriasis Scale: 63.2 ± 0.8 vs 50.2 ± 0.8, p<0.01); 4) Depression Scale: 71.6 ± 1.0 vs 52.8 ± 1.1, p<0.01; 5) Conversion Hysteria Scale: 66.8 ± 0.7 vs 54.8 ± 0.8, p<0.01; 6) Psychopathic Deviate Scale: 65.0 ± 0.7 vs 56.2 ± 1.1, p<0.01; 9) Paranoia Scale: 60.7 ± 0.6 vs 55.4 ± 0.9, p<0.01; 10) Psychasthenia Scale: 67.7 ± 0.8 vs 53.7 ± 0.9, p<0.01; 11) Schizophrenia Scale: 66.4 ± 0.9 vs 54.5 ± 1.0, p<0.01.
| Gender | | Non-significant
| Female: | 59%, 177/300 (CS) | Psychiatric illness and psychological problems: (MMPI) (mean ± SE): 1) L Scale: 50.1 ± 0.4 vs 49.1 ± 0.7, p=NS; 2) Masculine-Feminine Scale: Male 65.5 ± 0.9 vs 62.3 ± 1.7, p=NS. Female 45.2 ± 0.7 vs 45.5 ± 1.3, p=NS. 3) Hypomania Scale: 57.2 ± 0.7 vs 55.0 ± 1.0, p=NS.
| | 59%, 59/100 (CT) | MMPI = Minnesota Multiphasic Personality Inventory Scale
| Male: | 41%, 123/300 (CS)
| | 41%, 41/100 (CT)
| Ethnicity: | NS
| Sample Size: | 400 total
| | 300 (CS), 100 (CT)
| Response Rate: | 93%, 279/300 (CS)
| | 97%, 97/100 (CT)
Kales, AK / 1982 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Low (2/9) | Age Group: | 18–78 yrs (CS) | Significant
| | 18–74 yrs (CT) | Psychiatric illness and psychological problems: (CSs with sleep apnea vs CTs with sleep apnea; mean ± SE): 1) Elevation in MMPI Psychopathic deviate scale: 64.5 ± 2.2 vs 52.4 ± 2.7; p<0.01. 2) Elevation in MMPI Psychasthenia scale: 66.2. ± 3.1 vs 55.7 ± 2.1; p<0.01. 3) Elevation in MMPI Schizophrenia scale: 64.4. ± 2.9 vs 53.8 ± 1.8; p<0.01. 4) Elevations in at least one MMPI scale: 68.4% vs 36.4%; p<0.01. 5) Mean # elevated MMPI scales: 1.9 ± 0.5 vs 0.4 ± 0.2; p<0.05. (CSs with nocturnal myoclonic activity vs CTs with nocturnal myoclonic activity; mean ± SD): 1) Elevation in MMPI Depression scale: 68.6 ± 3.9 vs 50.5 ± 3.2; p<0.01. 2) Elevation in MMPI Conversion hysteria scale: 64.3. ± 2.8 vs 55.6 ± 2.2; p<0.05. 3) Elevation in MMPI Psychopathic deviate scale: 65.8. ± 2.6 vs 54.8 ± 2.8; p<0.01. 4) Elevation in MMPI Psychasthenia scale: 66.9. ± 3.3 vs 50.9 ± 2.4; p<0.01. 5) Elevation in MMPI Schizophrenia scale: 64.2. ± 2.6 vs 50.6 ± 2.7; p<0.01. 6) Elevation in MMPI Hypomania scale: 62.2. ± 3.1 vs 51.4 ± 2.1; p<0.01. 7) Elevations in at least one MMPI scale: 83.3% vs 36.4%; p<0.05. 5) Mean number elevated MMPI clinical scales: 2.1 ± 0.5 vs 0.4 ± 0.2; p<0.01.
| Gender | | Non-significant
| Female: | 118 (CS), 59 (CT) | Psychiatric illness and psychological problems: 1) CSs with sleep apnea vs CTs with sleep apnea; mean ± SD: No difference in frequency: 9.1 ± 1.3 vs 9.5 ± 2.2 or duration of episodes (sec): 16.2 ± 1.0 vs 13.8 ± 0.7. 2) CSs with nocturnal myoclonic activity vs CTs with nocturnal myoclonic activity; mean ± SE: Prevalence: 5% (n=10) vs 6% (n=6), p=NS; Frequency 106.5 ± 16.9 vs 171.3 ± 41.2, p=NS. 3) Elevation in MMPI Hypochndriasis scale: 60.9 ± 3.8 vs 53.4 ± 2.0; p=NS. 4) Elevation in MMPI Paranoia scale: 56.4 ± 2.3 vs 53.2 ± 2.5; p=NS.
| Male: | 82 (CS), 41(CT) | MMPI = Minnesota Multiphasic Personality Inventory Scale
| Ethnicity: | NS
| Sample Size: | 300 total
| | 200 (CS), 100 (CT)
| Response Rate: | NS
Kales, JD / 1984 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Low (1/9) | Age Group | | Significant
| mean ± SD: | 43.1± NS (CS) | Psychiatric illness and psychological problems: 1). Mental Health: a) More nervous than others 50% (107/214) vs 12% (11/94), p<0.01 (OR = 7.55, 95%CI:3.81–14.95), b) Ready to go to pieces 51% (109/214) vs 12% (11/94), p<0.01 (OR = 7.83, 95%CI:3.95–15.52), c) Feeling life is a strain 46% (99/214) vs 7% (7/94), p<0.01 (OR = 10.70, 95%CI:4.73–24.19), d) Less happy than others 52% (111/214) vs 20% (19/94), p<0.01 (OR = 4.25, 95%CI:2.40–7.53), e) Lacking self-confidence 44% (94/214) vs 20% (19/94), p<0.01 (OR = 3.09, 95%CI:1.75–5.47), f) Lonely much of the time 43% (92/214) vs 7% (7/94), p<0.01 (OR = 9.37, 95%CI:4.14–21.20), g) Brood a great deal 41% (88/214) vs 8% (8/94), p<0.01 (OR = 7.51, 95%CI:3.46–16.28), h) Feeling blue 35% (75/214) vs 2% (2/94), p<0.01 (OR = 24.82, 95%CI:5.95–103.59), i) Feeling future is hopeless 17% (36/214) vs 0, p<0.01), j)“take things hard” 65% (139/214) vs 34% (32/94), p<0.01 (OR = 3.59, 95%CI:2.15–5.98), k) Have not lived“the right kind of life” 31.8% (68/214) vs 11.7% (11/94), p<0.01 (OR = 3.51, 95%CI:1.76–7.02), l) Thought there was something“wrong with their mind” 21.5% (46/214) vs 2.1% (2/94), p<0.01 (OR = 12.60, 95%CI:2.99–53.07), m) Feeling worried 81.3% (174/214) vs 38.3% (36/94), p<0.01 (OR = 7.01, 95%CI:4.09–12.02), n) Feeling anxious 50.5% (108/214) vs 7.4% (7/94), p<0.01 (OR = 12.66, 95%CI:5.60–28.62), o) Feeling“high strung” 59.8% (128/214) vs 17.0% (16/94), p<0.01 (OR = 7.26, 95%CI:3.97–13.27), p) Not usually feeling calm 43.5% (93/214) vs 11.7% (11/94), p<0.01 (OR = 5.80, 95%CI:2.92–11.50). Medical conditions: a) Poor currently 43% (43/100) vs 3% (3/100), p<0.01 (OR = 24.39, 95%CI:7.24–82.23), b) Under a doctor's care 55% (55/100) vs 11% (11/100), p<0.01 (OR = 9.89, 95%CI:4.72–20.73), c)“Psychosomatic” illnesses 59% (126/214) vs 31% (29/94), p<0.01 (OR = 3.21, 95%CI:1.92–5.37), d) Work limited by illness 49% (49/100) vs 17% (17/100), p<0.01 (OR = 4.69, 95%CI:2.44–9.01), e) Hospitalizations (means only) 2.7 vs 1.4, p<0.01, f) Headaches 19.2% (41/214) vs 1.1% (1/94), p<0.01 (OR = 22.04, 95%CI:2.98–162.81), g) Diarrhea 28.0% (60/214) vs 9.6% (9/94), p<0.01 (OR = 2.93, 95%CI:1.40–6.15), h) Stomach discomfort 28.5% (61/214) vs 3.2% (3/94), p<0.01 (OR = 12.09, 95%CI:3.69–39.67), i) Palpitations 40.7% (87/214), 16.0% (15/94), p<0.01 (OR = 3.61, 95%CI:1.95–6.68), j) Non-specific pain 34.6% (74/214) vs 13.8% (13/94), p<0.01 (OR = 3.29, 95%CI:1.72–6.31), k) Tiredness 64.0% (137/214) vs 12.8% (12/94), p<0.01 (OR = 12.16, 95%CI:6.24–23.69), l) Weakness 26.2% (56/214) vs 3.2% (3/94), p<0.01 (OR = 10.75, 95%CI:3.27–35.33). Health care Utilization:Hospitalizations (mean #) 2.7 vs 1.4 times, p<0.01). Quality of life: a)“I believe that my home life is as pleasant as that of most people I know” 64.5% (138/214) vs 94.7% (89/94), p<0.01 (OR = 0.08, 95%CI:0.03- 0.23), b)“I seem to make friends about as quickly as others do” 69.2% (148/214) vs 91.5% (86/94), p<0.01 (OR = 0.21, 95%CI:0.10–0.46), c)“I like children” 79.9% (171/214) vs 95.7% (90/94), p<0.01 (OR = 0.18, 95%CI:0.06–0.51), d)“My sex life is satisfactory” 52.8% (113/214) vs 81.9% (77/94), p<0.01 (OR = 0.16, 95%CI:0.09–0.29). Mood: Behavioural correlates (CS vs CT): 1) Feelings before going to sleep: a)“Mind racing” 48% (48/100) vs 15% (15/100), p<0.01 (OR = 5.23, 95%CI:2.66–10.27), b) Tense/anxious 44% (44/100) vs 2% (2/100), p<0.01 (OR = 38.50, 95%CI:8.99, 164.89), c) Worried 35% (35/100) vs 6% (6/100), p<0.01 (OR = 8.44, 95%CI:3.36–21.21), d) Depressed 24% (24/100) vs 2% (2/100), p<0.01 (OR = 15.47, 95%CI:3.55–67.52), e) Desperate 10% (10/100) vs 0%, p<0.01, f) Mentally tired 56% (56/100) vs 39% (39/100), p<0.01 (OR = 1.99, 95%CI:1.13–3.50), g) Sleepy 31% (31/100) vs 71% (71/100), p<0.01 (OR = 0.18, 95%CI:0.10–0.34). 2) Thoughts before going to sleep: a) About getting enough sleep 77% (77/100) vs 12% (12/100), p<0.01 (OR = 24.55, 95%CI:11.46–52.60), b) About personal problems 49% (49/100) vs 30% (30/100), p<0.05 (OR = 2.24, 95%CI:1.25–4.00), c) About work 47% (47/100) vs 29% (29/100), p<0.05 (OR = 2.17, 95%CI:1.21–3.89), d) About health 36% (36/100) vs 16% (16/100), p<0.01 (OR = 2.95, 95%CI:1.51–5.79), e) About death 14% (14/100) vs 3% (3/100), p<0.05 (OR = 5.26, 95%CI:1.16–18.94), f)“Most nights I go to sleep without thoughts or ideas bothering me” 23.8% (51/214) vs 80.9% (76/94), p<0.01 (OR = 0.07, 95%CI:0.04–0.14), g) Being frightened in the middle of the night 25.2% (54/214) vs 5.3% (5/94), p<0.01 (OR = 6.01, 95%CI:2.32–15.57).
| | 48.2 ± 1.5 (CT) | Non-significant
| Gender | | Medical conditions: a) Poor in childhood 19% (19/100) vs 11% (11/100), OR = 1.90; 95%CI:0.85–4.23; b) Attempts at suicide: 11% vs 3%, p=NS. Smoking and Caffeine consumption reported NS.
| Female: | 58.9%, 126/214 (CS)
| | 59%, 59/100 (CT)
| Male: | 41.1%, 88/214 (CS)
| | 41%, 41/100 (CT)
| Ethnicity: | NS
| Sample Size: | 314 total
| | 214 (CS), 100 (CT)
| Response Rate: | NS (CS)
| | 94%, 94/100 (CT)
Kappler, C / 2003 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Low (2/8) | Age Group: | 18–65 yrs | Six-month prevalence: (DSM-III severe/moderate insomnia): 27.3% (258/945) (95%CI: 24.5–30.1). No prevalence data by gender.
| Gender | | [underlined: Associated Factors] :
| Female: | 50.1%, 1257/2512 | Significant
| Male: | 49.9%, 1253/2512 | Age: 1) Older (OR: 18.17; p<0.001). Psychiatric illness and psychological problems: (95%CI: not reported) 1) Psychiatric disorder (OR: 7.38; p=0.007). Socio-economic status: 1) Social status (OR: 1.64; p=0.0009). Quality of life: 1) Overload housekeeping (OR: 11.02; p=0.01). Social relationships: 1) Conflicts with relatives (OR: 16.44; p=0.0002), 2) Illness of relatives (OR: 1.7; p=0.04), 3) Overload profession (OR: 11.02; p=0.0003).
| Ethnicity: | NS | Non-significant
| Sample Size: | 2512 total | None reported
| Response Rate: | 37.6%, 945/2512
Kawada, T / 2003 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (6/8) | Age Group: | 20–80 yrs | Point prevalence: (DSM-IV criteria for at least 1 month): 8.8% (57/648) (95%CI: 6.6–10.9). No prevalence data by gender.
| Gender | | [underlined: Associated Factors] :
| Female: | 1286 | Significant
| Male: | 0 | Psychiatric illness and psychological problems: 1) Depressive state (adj OR: 1.2; 95%CI: 1.1–1.3; p<0.01). Medical condition: 1) Poor self-rated health (adj OR: 3.2; 95%CI: 1.0–10.1; p<0.05). 2) Medical treatment: OR: 2.15; 95%CI: 1.23–3.76. Other factors: 1) Experiencing a major life event (adj OR: 4.4; 95%CI: 1.7–11.4; p<0.01). 2) Child ≤ 6yrs: OR: 2.08; 95%CI: 1.13–3.84.
| Ethnicity: | All Asian (Japanese) | Non-significant
| Sample Size: | 1286 | Age:(<50 vs >50) adj OR: 2.7; 95%CI: 0.9–7.9. Social Relationships: (Married vs not married) OR: 1.01; 95%CI: 0.51–2.03. Socioeconomic status:(Employed vs other) OR: 0.97; 95%CI: 0.26–1.7. Other factors: 1) Smoking: OR: 1.24; 95%CI: 0.62–2.5; 2) Alcohol (yes vs no) OR: 1.42; 95%CI: 0.76–2.66; 3) Regular exercise: OR: 0.67; 95%CI: 0.32–1.41.
| Response Rate: | 50.4%, 648/1286
Leger, D / 2000 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (6/8) | Age Group: | Over 18 yrs | One-month prevalence: (Insomnia) 19% (2376/12,778) (95%CI: 18.3–19.6).
| Gender | | [underlined: Associated Factors] :
| Female: | 53%, 6772/12,778 | Significant
| Male: | 47%, 6006/12,778 | Gender: Male: 14% (841/6006), 95%CI: 13.1–14.80). Female: 23% (1542/6772), 95%CI: 22–24. (Severe/chronic insomnia): 9% (1192/12,778), 95%CI: 8.51–9.49. Male: 6.3% (377/6006), 95%CI: 5.4–6.6. Female: 12% (815/6772), 95%CI: 11.2–12.7.
| Ethnicity: | NS | Age: Severe insomnia increased significantly both sexes p<10^-4^.
| Sample Size: | 14,998 | Socio-economic status: 1) Retired: 18.3%; p <0.0001, 2) White-collar worker: 20.8%; p<0.03. Social Relationships: Singles less insomnia than other states 13% p<10^-4^.
| Response Rate: | 85.2%, 12778/14,997 | Non-significant
| | | Other factors: Urban vs rural p=NS
Leppavuori, A / 2002 | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
Moderate (4/8) | Age Group: | 55–85 yrs | Medically ill (stroke).
| Gender | | [underlined: Prevalence] :
| Female: | 49.1%, 136/277 | Point prevalence: (DSM-IV criteria of insomnia): 37.6% (104/277) (95%CI: 31.9–43.3). (Insomnia complaints): 56.7% (157/277) (95%CI: 50.9–62.5). (Before-stroke insomnia complaints): 38.6% (107/277) (95%CI: 32.9–44.3). (Post-stroke insomnia complaints): 18.1% (50/277) (95%CI: 13.6–22.6). (Before-stroke DSM-IV insomnia): 69.2% (74/107) (95%CI: 60.5–77.9). (Post-stroke DSM-IV insomnia): 60% (30/50) (95%CI: 46.5–73.5). No prevalence data by gender.
| Male: | 50.9%, 141/277 | [underlined: Associated Factors] :
| Ethnicity: | NS | Significant
| Sample Size: | 277 | Age: 1) Age (mean ± SD years) (71.1 ± 7.1 vs 72.6 ± 7.2 (p<0.01) vs 71.6 ± 7.8 (p<0.05) vs 69.5 ± 6.8). Gender: 1) Female (Prestroke insomniacs vs New insomniacs vs All insomniacs vs Non-insomniacs: 52.3% vs 60% vs 54.8% (p<0.05) vs 41.7%). Psychiatric illness and psychological problems: 1) History of depression (29.9% vs 16% vs 25.5% (p<0.01) vs 11.7%) and anxiety disorders (32.7% (p<0.001) vs 8.0% vs 24.8% (p<0.01) vs 11.7%), 2) Any depression (51.4% (p<0.00001) vs 52% (p<0.001) vs 51.6% (p<0.00001) vs 25%), 3) Major depression (34.6% (p<0.001) vs 34% (p<0.01) vs 34.4% (p<0.001) vs 15.0%), 4) Organic depression (3.7% vs 18% (p<0.01) vs 8.3% vs 4.2%), 5) Any anxiety disorder (31.8% (p<0.00001) vs 30.0% (p<0.001) vs 31.2% (p<0.00001) vs 9.2%), 6) Generalized anxiety (21.5% (p<0.00001) vs 6.0% vs 16.6% (p<0.01) vs 4.2%), 7) Organic anxiety (9.3% vs 22.0% (p<0.001) vs 13.4% (p<0.01) vs 4.2%), 8) Dementia (18.1% vs 38.0% (p<0.001) vs 24.2% (p<0.05) vs 13.3%), 9) High scores on Beck Depression Inventory (mean score ± SD: 11.6 ± 8.3 (p<0.00001) vs 10.2 ± 5.2 (p<0.01) vs 11.2 ± 7.6 (p<0.00001) vs 7.1 ± 5.9) 10) High scores on Montgomery-Åsberg Depression Rating Scale (MADRS): 9.9 ± 8.0 (p<0.00001) vs 10.3 ± 8.6 (p<0.00001) vs 10.1 ± 8.2 (p<0.00001) vs 4.9 ± 6.3), 11) High scores on Zung depression scale (40.7 ± 10.0 (p<0.00001) vs 41.7 ± 9.3 (p<0.00001) vs 41.0 ± 9.7 vs 35.0 ± 9.2), 12) High scores on Zung anxiety scale (30.9 ± 7.8 (p<0.00001) vs 30.5 ± 7.1 (p<0.00001) vs 30.8 ± 7.6 (p<0.00001) vs 26.2 ± 5.8), 13) Low score on Global Assessment of Functioning scale (GAF) after stroke (58.6 ± 13.1 (p<0.00001) vs 56.6 ± 17.9 (p<0.00001) vs 58.0 ± 14.8 (p<0.00001) vs 65.3 ± 11.1), 14) Low score on Global Assessment of Functioning scale (GAF) before stroke: 69.8 ± 9.5 (p<0.00001) vs 72.6 ± 8.8 vs 70.7 ± 9.3 (p<0.00001) vs 74.8 ± 7.3). Medical conditions: 1) Major dominant stroke syndrome (14.2% vs 26.0% (p<0.05) vs 17.9% vs 12.5%, 2) Stroke severity (Scandinavian Stroke Scale mean score ± SD: 54.9 ± 6.4 vs 49.9 ± 12.3 (p<0.01) vs 53.3 ± 9.0 vs 54.8 ± 8.1). 3) Migraine (17.8% vs 10.0% vs 15.3% (p<0.05) vs 5.8%). Quality of life: 1) Being dependent (34.6% vs 56.0% (p<0.001) vs 41.4% (p<0.01) vs 25.8%), 2) Activities of daily living (Barthel's Index mean score ± SD: 72.4 ± 15.4 vs 61.6 ± 23.1 (p<0.00001) vs 68.9 ± 18.9 (p<0.01) vs 74.4 ± 13.7). Memory and cognitive function: 1) Cognition (Mini Mental Status Examination mean score ± SD: 25.7 ± 4.0 vs 23.8 ± 5.4 (p<0.00001) vs 25.1 ± 4.6 (p<0.01) vs 26.6 ± 3.0). Prestroke insomniacs vs New insomniacs vs All insomniacs vs Non-insomniacs: (reference group: Non-insomnia): 1) Sleep-promoting drug use (86.9% (p<0.0001) vs 78% (p<0.0001) vs 84.1% (p<0.0001) vs 0.0%), 2) Anxiolytics (32.7% (p<0.0001) vs 22% (p<0.0001) vs 29.3% (p<0.0001) vs 1.7%), 3) Antidepressants use (28% vs 42% (p<0.0001) vs 32.5% (p<0.0001) vs 10.8%), 4) Antipsychotics use (8.4% (p<0.05) vs 14.0% (0.01) vs 10.2% (p<0.01) vs 1.7%).
| Response Rate: | NS | Non-significant
| | | Non reported
Levitt, H / 2004 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Low (2/9) - case control | Age Group: | 20–30 yrs | Significant
Low (0/9) - cohort | mean ± SD: | 24.1±3.4 (CS) | Psychiatric illness and psychological problems (CS vs CT): 1) Hamilton Rating Scale for Anxiety: 5.9 ± 1.8 vs 0.0 ± 0.0, t = -8.74, p<0.001. 2) Inventory of depressive symptomatology: 11.6 ± 3.0 vs 1.9 ± 2.2, t = -7.01, p<0.001. 3) Pittsburgh Sleep Quality Index: 8.9 ± 1.0 vs 1.4 ± 1.1, t = -6.33, p<0.001. 4) SF-36 Vitality Index: 52.9 ± 21.4 vs 78.1 ± 7.0, t = 2.97, p<0.05. Cognitive function: 1) Subjective alertness morning: 46.59 ± 5.28 vs 80.86 ± 4.27, p=0.003. 2) Energy morning: 58.05 ± 5.12 vs 84.08 ± 5.11, p=0.003; noon: 73.28 ± 5.45 vs 87.68 ± 4.10, p=0.052. 3) Concentration morning: 54.75 ± 5.43 vs 82.17 ± 5.23, p=0.003; night: 53.01 ± 4.78 vs 68.21 ± 4.93, p=0.045. Mood (CS vs CT, mean ± SE) morning: 66.22 ± 4.23 vs 87.40 ± 4.49, p=0.004.
| | 23.3±1.9 (CT) | Non-significant
| Gender | | Psychiatric illness and psychological problems (CS vs CT): 1) Perceived Stress Scale: 12.6 ± 8.8 vs 9.0 ± 3.4, t = -1.01,p= NS. 2) SF-36 General Health Perceptions Index: 84.4 ± 9.3 vs 91.0 ± 8.5, t = 1.42, p=NS. Cognitive function: 1) Subjective alertness noon: 75.88 ± 4.62 vs 88.34 ± 4.69, p=0.08; evening: 74.32 ± 3.96 vs 83.04 ± 4.29, p=0.16; night: 43.47 ± 5.35 vs 45.65 ± 3.87, p=0.74. 2) Energy evening: 72.17 ± 4.26 vs 84.08 ± 5.21; p=0.098; night: 51.40 ± 5.77 vs 55.28 ± 4.50, p=0.60. 3) Concentration noon: 69.96 ± 6.67 vs 83.17 ± 5.42, p=0.15; evening: 70.20 ± 5.53 vs 81.67 ± 5.50, p=0.16. Mood (CS vs CT, mean ± SE) noon: 77.43 ± 3.83 vs 86.99 ± 3.75, p=0.10; evening: 77.02 ± 4.30 vs 86.16 ± 3.43, p=0.12; night: 74.11 ± 4.86 vs 83.25 ± 3.95, p=0.17.
| Female: | 85.7%, 6/7 (CS)
| | 87.5%, 7/8 (CT)
| Male: | 14.3%, 1/7 (CS)
| | 12.5%, 1/8 (CT)
| Ethnicity: | NS
| Sample Size: | 15 total
| | 7 (CS), 8 (CT)
| Response Rate: | 100%
Lichstein, KL / 2001 | Study Design: | Cross-sectional case-control | [underlined: Co-Morbidity] :
Moderate (5/9) | Age Group: | Over 58 yrs | Among secondary insomnia: Depression (n = 13), Anxiety (n = 8), Chronic pain (n = 10), Prostate disease (n = 7), Neurological disorders (n = 5), Respiratory disease (n = 3).
| Gender | | [underlined: Associated Factors] :
| Female: | 58 (CS) primary | Significant
| | 23 (CS) secondary | Psychiatric illness and psychological problems: (primary insomnia vs secondary insomnia vs CT; mean ± SD): 1) Self-reported anxiety (State-Trait Anxiety Inventory -Form Y Trait Scale (STAI): 33.6 ± 7.7 (p<0.001) vs 40.9 ± 12.1 (p<0.001) vs 29.8 ± 7.1; 2) Depression (Geriatric Depression Scale (GDS): 5.4 ± 4.3 (p<0.001) vs 11.6 ± 7.9 (p<0.001) vs 3.1 ± 3.7. Quality of life: 1) Mental health (SF-36 Mental health subscale: 80.7 ± 14.0 vs 56.0 ± 21.0 (p<0.001) vs 90.1 ± 26.5; 2) Physical functioning (SF-36 Physical functioning subscale: 78.1 ± 18.5 vs 52.4 ± 24.3 (p<0.001) vs 77.7 ± 21.7.
| | 35 (CT) | Non-significant
| Male: | 24 (CS) primary | Age: 68.1 ± 7.0 vs 68.4 ± 6.4 vs 71.4 ± 6. Socioeconomic status: Education years (primary insomnia 14.7 ± 3.0 vs CTs 15.0 ± 2.2). Gender: 70%; 95%CI: 60–80 vs 57%; 95%CI: 36–64 vs 57%; 95%CI: 45–69; all reported NS.
| | 23 (CS) secondary
| | 23 (CT)
| Ethnicity: | NS
| Sample Size: | 189 total
| | 82 (CS) primary
| | 46 (CS) secondary
| | 61 (CT)
| Response Rate: | NS
Linzmayer, L / 2002 | Study Design: | Cross-sectional case-control | [underlined: Co-Morbidity] :
Low (1/9) | Age Group: | 22–63 yrs | Group A: nonorganic insomnia (psychophysiological insomnia in ICSD' primary insomnia in DSM-IV) (N = 8 CS, 32 CT). Group B: bipolar affective disorder (N = 16 CS, 32 CT). Group C: depressive episode (N = 13 CS, 26 CT). Group D: recurrent depressive disorder (N = 31 CS, 31 CT). Group E: dysthymia (N = 30 CS, 30 CT). Group F: generalized anxiety disorder (N = 41 CS, 41 CT). Group G: mixed anxiety and depressive disorder (N = 16 CS, 27 CT). Group H: adjustment disorders (N = 16 CS, 32 CT).
| Gender | | [underlined: Associated Factors] :
| Female: | 51.1%, 93/182 (CS) | Significant
| | 52.2%, 131/251 (CT) | Cognitive function: Intelligence (IQ): Group A: 100–112, Group B: 100–118, Group C: 100–118, Group D: 100–112, Group E: 100–112, Group F: 100–118, Group G: 100–107, Group H: 100–112). IQ not ascertained in controls. IQ surpassing normative values found in Groups B, C and F. Memory: 1) Visual Memory: differed significantly (>2 points) from age- and intelligence-dependent expected values only for Group F. 2) Numerical Memory (GVG): Group B (5.6 ± 1.7 vs 6.9 ± 1.6. p ≤ 0.05), Group C (4.9 ± 1.4 vs 6.4 ± 1.7, p ≤ 0.01), Group D (5.3 ± 1.5 vs 6.2 ± 1.8, p ≤ 0.05). 3) Total Verbal Memory (GVG) Group C (24.0 ± 6.3 vs 27.8 ± 6.4, p ≤ 0.05), Group D (25.3 ± 7.6 vs 28.7 ± 6.7, p ≤ 0.05). Mood: 1) Thymopsychic Variables (CS vs CT, mean ± SD): Drive: Group C (70.8 ± 22.3 vs 34.7 ± 27.0, p ≤ 0.01), Group D (51.4 ± 24.9 vs 24.4 ± 19.9, p ≤ 0.01); Group E (46.2 ± 21.5 vs 23.9 ± 20.9, p ≤ 0.01) 2) Mood (VAS): Group C (35.9 ± 18.1 vs 69.4 ± 25.1, p ≤ 0.01) Group D (47.4 ± 24.7 vs 75.0 ± 19.1, p ≤ 0.01), Group E (47.8 ± 18.0 vs 66.7 ± 22.7, p ≤ 0.01). 3) Affectivity (VAS): Group C (49.8 ± 28.4 vs 77.7 ± 19.8, p ≤ 0.01), Group D (57.9 ± 19.6 vs 83.5 ± 14.0, p ≤ 0.001), Group E (60.1 ± 14.9 vs 81.9 ± 18.8, p ≤ 0.01), Group G (69.0 ± 14.7 vs 77.8 ± 22.9, p ≤ 0.01). 4) Wakefulness (VAS): Group A (48.7 ± 21.0 vs 31.0 ± 21.9, p ≤ 0.05), Group C (73.5 ± 26.9 vs 32.3 ± 26.7, p ≤ 0.01), Group D (54.3 ± 30.0 vs 22.2 ± 19.9, p ≤ 0.01), Group E (55.9 ± 28.4 vs 28.4 ± 25.6, p ≤ 0.01), Group G (46.1 ± 30.2 vs 29.0 ± 25.8, p ≤ 0.05), Group H (43.1 ± 26.9 vs 25.2 ± 25.0, p ≤ 0.05). 5) Well-being (Bf): Group B (24.3 ± 14.5 vs 9.8 ± 8.3, p ≤ 0.01), Group C (32.5 ± 13.6 vs 12.6 ± 10.4, p ≤ 0.01), Group D (29.1 ± 11.6 vs 9.9 ± 8.1, p ≤ 0.01), Group E (24.0 ± 10.5 vs 13.6 ± 10.5, p ≤ 0.01), Group G (20.5 ± 12.0 vs 13.0 ± 12.1, p ≤ 0.01), Group H (19.1 ± 7.1 vs 14.0 ± 11.5, p ≤ 0.05). 6) State Anxiety: Group B (49.3 ± 13.9 vs 35.7 ± 7.1, p ≤ 0.01), Group C (54.3 ± 13.8 vs 37.0 ± 9.3, p ≤ 0.01), Group D (51.2 ± 12.1 vs 33.6 ± 5.8, p ≤ 0.01), Group E (45.5 ± 9.9 vs 38.9 ± 8.7, p ≤ 0.05), Group G (45.1 ± 8.4 vs 35.5 ± 8.5, p ≤ 0.01). 7) Trait Anxiety: Group B (58.5 ± 6.7 vs 34.6 ± 9.2, p ≤ 0.01), Group C (53.5 ± 11.2 vs 38.6 ± 12.3, p ≤ 0.01), Group D (55.3 ± 10.7 vs 34.7 ± 8.2, p ≤ 0.01), Group E (50.4 ± 9.0 vs 39.9 ± 12.0, p ≤ 0.01), Group G (49.6 ± 8.0 vs 37.7 ± 13.4, p ≤ 0.01).
| Male: | 48.9%, 89/182 (CS) | Non-significant
| | 47.8%, 120/251 (CT) | Cognitive function: 1) Intelligence (IQ): Daytime Nonpsychic performance (cases vs controls, mean ± SD): 2) General Verbal Memory: Group A: (8.7 ± 1.9 vs 9.9 ± 2.1, p ≤ 0.10), Group B: (8.8 ± 1.5 vs 8.8 ± 2.5, p=NS), Group C: (7.3 ± 2.8 vs 8.4 ± 2.6, p=NS), Group D: (7.9 ± 2.4 vs 8.5 ± 2.6, p=NS), Group E: 8.3 ± 2.2 vs 8.4 ± 2.6, p=NS), Group F: (9.0 ± 2.2 vs 8.5 ± 2.7, p=NS), Group G: 7.6 ± 2.7 vs 8.5 2.5, p ≤0.10), Group H: (8.1 ± 1.3 vs 8.0 ± 2.6, p=NS). 3) Associative verbal memory (Gruenberger Verbal Memory): Memory Test: Group A (14.9 ± 2.7 vs 16.2 ± 3.2, p ≤ 0.10), Group B (13.5 ± 3.2 vs 14.4 ± 4.1, p=NS), Group C (11.9 ± 3.8 vs 13.2 ± 4.3, p=NS), Group D (12.1 ± 5.1 vs 14.1 ± 4.3, p=NS), Group E (12.9 ± 3.8 vs 14.2 ± 4.0, p=NS), Group F (15.1 ± 3.6 vs 13.5 ± 4.3, p ≤ 0.10), Group G (11.9 ± 5.2 vs 14.1 ± 4.3, p ≤ 0.10), Group H (12.6 ± 5.0 vs 14.0 ± 4.3, p=NS). 4) Numerical Memory (GVG): Group A (6.1 ± 2.2 vs 6.1 ± 1.9, p=NS), Group E (6.2 ± 2.0 vs 6.2 ± 1.9, p=NS), Group F (6.0 ± 2.0 vs 6.1 ± 1.9, p=NS), Group G (6.2 ± 1.7 vs 6.4 ± 1.7, p=NS), Group H (5.8 ± 1.5 vs 6.4 ± 1.6, p=NS ),5) Total Verbal Memory (GVG): Group A (29.8 ± 5.6 vs 32.8 ± 5.1, p ≤ 0.10), Group B (27.9 ± 4.3 vs 30.0 ± 6.3, p=NS), Group E (27.4 ± 6.0 vs 28.5 ± 6.5, p=NS), Group F (30.1 ± 6.2 vs 28.3 ± 7.0, p=NS), Group G (25.7 ± 8.3 vs 28.9 ± 6.5, p ≤ 0.10), Group H (26.5 ± 6.0 vs 28.4 ± 6.9, p ≤ 0.10). Mood: 1)Thymopsychic Variables (cases vs controls, mean ± SD): 1) Drive (VAS): Group A (43.9 ± 11.9 vs 35.0 ± 24.8, p ≤ 0.10), Group B (41.1 ± 31.5 vs 26.7 ± 21.2, p=NS), Group F (23.8 ± 17.4 vs 29.1 ± 23.4, p=NS), Group G (36.0 ± 25.7 vs 31.6 ± 26.3, p=NS), Group H (30.4 ± 19.5 vs 25.6 ± 24.4, p=NS). 2) Mood (VAS): Group A (66.3 ± 17.0 vs 71.3 ± 18.5. p=NS), Group B (59.3 ± 29.3 vs 73.1 ± 21.0, p=NS), Group F (69.1 ± 17.7 vs 67.4 ± 23.3, p=NS), Group G (73.5 ± 10.8 vs 71.6 ± 24.5, p=NS), Group H (71.3 ± 20.5 vs 67.3 ± 26.2, p=NS). 3) Affectivity (VAS): Group A (61.9 ± 23.0 vs 76.1 ± 19.1, p ≤ 0.10), Group B (64.3 ± 27.2 vs 78.8 ± 18.4, p ≤ 0.10), Group F (77.8 ± 16.6 vs 77.7 ± 19.9, p=NS), Group H (77.7 ± 15.4 vs 77.1 ± 22.7, p=NS). 4) Wakefulness (VAS): Group B (46.4 ± 34.8 vs 25.0 ± 21.4, p ≤ 0.10), Group F (41.5 ± 28.5 vs 29.6 ± 25.7, p ≤ 0.10). 5) Well-being (Bf): Group A (13.7 ± 5.8 vs 11.1 ± 9.2, p ≤ 0.10), Group F (15.4 ± 10.6 vs 13.4 ± 11.2, p=NS). 6) State Anxiety: Group A (33.4 ± 7.2 vs 37.2 ± 7.1, p ≤ 0.10), Group F (40.7 ± 12.6 vs 37.5 ± 8.5, p=NS), Group H (42.0 ± 13.1 vs 36.0 ± 7.9, p ≤ 0.10). 6) Trait Anxiety: Group A (32.5 ± 5.8 vs 36.9 ± 10.4, p=NS), Group F (41.8 ± 11.2 vs 37.9 ± 10.2, p ≤ 0.10), Group H (42.9 ± 9.4 vs 39.3 ± 12.5, p ≤ 0.10).
| Ethnicity: | NS
| Sample Size: | 433 total
| | 182 (CS), 251 (CT)
| Response Rate: | NS
Lundh, LG / 1997 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (5/9) | Age Group | 20–65 yrs | Significant
| mean ± SD: | 46.5 ± 11.3 (CS) | Psychiatric illness and psychological problems: (CS vs CT; mean scores): 1) Depression (Beck Depression Inventory scores; 8.5 vs 3.7; p<0.01). Memory and cognitive function: 1) Verbal ability (WAIS-R vocabulary scores; 46.9 vs 55.8; p<0.05). 2) Cued recall (Emotional Stroop test scores: 0.37 vs 0.47; p<0.005).
| | 45.5 ± 11.1 (CT) | Non-significant
| Gender | | Psychiatric illness and psychological problems: (CS vs CT; mean scores): Spielberger Trait State Anxiety Inventory: 36.5 vs 35.4; p=NS.
| Female: | 16 (CS)
| | 16 (CT)
| Male: | 4 (CS)
| | 4 (CT)
| Ethnicity: | NS
| Sample Size: | 40 total
| | 20 (CS), 20 (CT)
| Response Rate: | NS
Martikainen, K / 2003 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (5/8) | Age Group: | 41–55 yrs | Three-month prevalence: 14% (88/626) 95%CI: 11.3–16%. Male: 9.8% (26/264) 95%CI: 6.2–13.3%. Female: 17.0% (62/362) 95%CI: 13.1–20.8%.
| Gender | | [underlined: Associated Factors] :
| Female: | 57.8%, 362/626 | Significant (CS vs CT)
| Male: | 42.2%, 264/626 | Age: (> 55 yrs): p<0.01. Psychiatric illness and psychological problems: 1) Depression: adj OR: 2.78; 95%CI: 1.22–6.33; p=0.023. 2) Nervousness and tension: adj OR: 3.05; 95%CI: 1.66–5.63; p<0.001. Medical conditions: 1) Fatigue: adj OR: 2.24; 95%CI: 1.22–4.12; p<0.001, 2) Hypertension: adj OR: 2.05; 95%CI: 1.10–3.82; p=0.026. 3) Heart conditions (arrhythmias, heart failure): 14 vs 4%, p=<0.001. 4) Allergic rhinitis: 18.6%; p=0.006. Socio-economic status: 1) Poorer job: adj OR: 6.10; 95%CI: 1.82–20.5; p<0.001; Unemployed: 83.9 vs 91.7%; p=0.019. Healthcare utilization: Hospital treatment: 42.5 vs 27.1%; p=0.003 Other factors: 1) Moving house: adj OR: 0.19; 95%CI: 0.04–0.83; p=0.003. 2) Insomniacs less often current smokers: 8 vs 17.1%; p=0.032; 3) Insomniacs less caffeine/day (mean cups coffee): 4.16 vs 4.76; p=0.014.
| Ethnicity: | NS | Non-significant
| Sample Size: | 1190 | Other factors: Marital status, BMI, Exercise, Snoring, Alcohol consumption all reported p=NS. Medical conditions: Heart conditions (Angina, myocardial or brain infarction) p=NS
| Response Rate: | 52.6%, 626/1190
Mendelson, WB / 1984 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (4/9) | Age Group: | 22–44 yrs | Significant
| Gender | | Psychiatric illness and psychological problems: (CS vs CT; mean scores ± SD): 1) Depression (MMPI Depression scale: 62.0 ± 9.3 vs 49.0 ± 6.5; p<0.009). 2) Social introversion (MMPI Social introversion scale: 56.3 ± 11.2 vs 44.7 ± 6.2; p<0.009). Memory and cognitive function: (CS vs CT; number of responses ± SD): 1) Long-term semantic/knowledge memory (per time of day) (11 am: 10.4 ± 3.3 vs 12.9 ± 3.6. 2 pm: 11.3 ± 3.9 vs 13.8 ± 2.7. 5 pm: 10.6 ± 3.6 vs 13.3 ± 3.3. 8 pm: 11.3 ± 3.3 vs 13.9 ± 3.3).
| Female: | 9 (CS), 9 (CT) | Non-significant
| Male: | 1 (CS), 1 (CT) | Psychiatric illness and psychological problems: (CS vs CT; mean scores ± SD): MMPI subscales L, HS, HY, PD, MF, PA, PT, SC, MA all p=NS. Psychomotor functioning: On 12 tasks no significant differences. Cognitive Function: Attention, Vigilance, Learning and Memory no significant difference.
| Ethnicity: | NS
| Sample Size: | 20 total
| | 10 (CS), 10 (CT)
| Response Rate: | NS
Millar, A / 2004 | Study Design: | Cross-sectional case-control | [underlined: Prevalence] :
High (6/9) | Age Group: | 26–68 yrs (CS) | Percentage of reported longstanding sleep disturbances (Sleep History Questionnaire): Cases: 100% (19/19). Controls: 21% (4/19) (95%CI: 2.7–39.3). No data by gender.
| | 27–67 yrs (CT)
| Gender
| Female: | 11 (CS), 11 (CT)
| Male: | 8 (CS), 8 (CT)
| Ethnicity: | NS
| Sample Size: | 51 total
| | 32 (CS), 19 (CT)
| Response Rate: | Follow-up rate:
| | 59.3%, 19/32 (CS)
| | NS (CT)
Niemcewicz, S / 2001 | Study Design: | Case-control | [underlined: Associated Factors] :
Low (2/9) | Age Group | 21–55 yrs | Significant
| mean ± SD: | 40.8 ± 11.3 | Psychiatric illness and psychological problems: (MMPI scale, CS vs CT, mean ± SD): 1) Hypochondria (55.93 ± 8.94 vs 49.00 ± 6.65, t = -2.489, df = 30, p = 0.019). 2) Depression (57.31 ± 10.44 vs 45.53 ± 7.79, t = -3.645, df = .0, p = 0.001). 3) Hysteria (58.62 ± 8.77 vs 50.50 ± 6.34, t = -3.001, df = 30, p = 0.005). 4) Psychasthenia (51.18 ± 9.23 vs 42.50 ± 5.86, t = -2.999, df = 30, p = 0.005). 5) Hamilton score (6.4 ± 2.4 vs 0.5 ± 1.0, U = 2.5, p<0.001). 6) Beck score (6.8 ± 4.6 vs 2.2 ± 3.6, U = 42.5, p = 0.001). 6) Hyperarousal score (65.0 ± 7.54 vs 55.12 ± 8.74, U = 49.0, p = 0.003).
| Gender | | Memory: (CS vs CT, mean ± SD: 1) (Selective Reminding Test) # of presentations needed to memorize all items (10.06 ± 4.31 vs 6.56 ± 2.25, U = 68.5, p=0.02). 2) Reaction time (514.60 ± 69.24 msec vs 577.44 ± 78.25 msec, U=65.0, p = 0.02).
| Female: | 56%, 9/16 (CS) | Non-significant
| | 56%, 9/16 (CT) | Memory: 1) False target detections (Continuous Attention Test) (2.81 ± 3.10 vs 2.16 ± 4.19, U=80.5, p=0.07).
| Male: | 44%, 7/16 (CS)
| | 44%, 7/16 (CT)
| Ethnicity: | NS
| Sample Size: | 32 total
| | 16 (CS), 16 (CT)
| Response Rate: | 100%
Ohayon, MM / 2003 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (7/8) | Age Group: | Over 15 yrs | Point prevalence: (Chl > 6 mo): 17.6% (2625/14,915), 95%CI: 16.9–18.21. Male: 13.5% (965/7144), 95%CI: 12.71–14.29. Female: 22.3% (1733/7771), 95%CI: 21.38–23.22. (Insomnia ≥ month): 18.4% (2744/14,915), 95%CI: 17.78–19.02.
| Gender | | [underlined: Associated Factors] :
| Female: | 52.1% 7771/14,915 | Significant
| Male: | 47.9% 7144/14,915 | Psychiatric illness and psychological problems: 1) Previous psychiatry hx: adj OR: 5.8; 95%CI: 2.4–14.0.
| Ethnicity: | NS | Non-significant
| Sample Size: | 18,972 | None reported
| Response Rate: | 78.6%, 14,915/18,972
Ohayon, MM / 2002A | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (8/8) | Age Group: | Over 15 yrs | One-year prevalence (Insomnia symptoms): 27.6% (1096/3970) (95%CI: 26.2–28.9). Male: 24.5% (469/1916) (95%CI: 22.5–26.4). Female: 30.5% (627/2055) (95%CI: 28.5–32.4). (Insomnia disorder diagnoses): 7% (278/3970) (95%CI: 6.2–7.7). Male: 4.2% (80/1916) (95%CI: 3.3–5.1). Female: 9.2% (189/2055) (95%CI: 8.0–10.4).
| Gender | | [underlined: Associated Factors] :
| Female: | 51.8%, 2055/3470 | Significant
| Male: | 48.2%, 1916/3470 | Gender (DSM-IV insomnia diagnoses): 1) Gender: OR: 9.2; 95%CI: 8.0–10.4; p<0.001.
| Ethnicity: | NS | Non-significant
| Sample Size: | 4442 | Healthcare utilization: (95%CI not reported) 1) Use of sleep-enhancing medication (Having one insomnia symptom: OR: 2.2; Having two insomnia symptoms: OR: 3.4; Having three or four insomnia symptoms: OR: 2.9. Other factors: (Risk factors for sleep dissatisfaction) Marital status, BMI, MSK disease, heart disease, hypertension, snoring, daily stress level all p=NS
| Response Rate: | 89.4%, 3970/4442
Ohayon, MM / 2002B | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (8/8) | Age Group: | Over 18 yrs | Point prevalence: Insomnia disorder diagnoses: 11.7% (115/982). No prevalence data by gender.
| Gender
| Female: | 51.8%, 509/982
| Male: | 48.2%, 473/982
| Ethnicity: | NS
| Sample Size: | 1256
| Response Rate: | 78.2%, 982/1256
Ohayon, MM / 2002C | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (8/8) | Age Group: | 15–90 yrs | Point prevalence: 5% (186/3719) (95%CI:4.3, 5.7).
| Gender | | [underlined: Associated Factors] :
| Female: | 50.5%, 1877/3719 | Significant
| Male: | 49.5%, 1842/3719 | Age: Elderly (>65yr) 8.2% (26/314) vs other age groups (4.2 to 5%), p<0.05.
| Ethnicity: | NS | Non-significant
| Sample Size: | 4067 | Gender: Male 4.7% (87/1842) vs Female 5.1% (96/1877), OR = 0.92 (0.68, 1.24).
| Response Rate: | 91.4%, 3719/4067
Ohayon, MM / 2001A | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
High (7/8) | Age Group: | 19–24 yrs | Psychiatric illness and psychological problems: 12.6% (182/1447) had ICDS dyssomnia or sleep disturbances associated with a mental disorder.
| Gender | | [underlined: Prevalence] :
| Female: | 50.5%, 731/1447 | Point prevalence: 8.1% (117/1447) (95%CI: 7.4, 8.8).
| Male: | 49.5%, 716/1447
| Ethnicity: | NS
| Sample Size: | 1447
| Response Rate: | NS
Ohayon, MM / 2001B | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (8/8) | Age Group: | Over 15 yrs | Point prevalence: 6.1% (1,501/24,600) (95%CI:5.8, 6.4).
| Gender
| Female: | 51%, 12665/24600
| Male: | 49%, 11936/24600
| Ethnicity: | NS
| Sample Size: | 24,600 total (France=5622, UK=4972, Germany=4115, Italy=3970, Portugal=1856)
| Response Rate: | 81.0% overall (Germany=68.1, all others over 80%)
Ohayon, MM / 2001C | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (8/8) | Age Group: | Over 15 yrs | No prevalence estimates for DSM-IV insomnia disorder overall. Data for each insomnia symptom: 1) Difficulties initiating sleep: 13.11% (1712/13,057) 95%CI: 12.6–13.6%, 2) Disrupted sleep: 21.3% (2792/13,057) 95%CI: 20.6–22%, 3) Early morning awakenings: 13.1% (1712/13,057) 95%CI: 12.6–13.6%, 4) Nonrestorative sleep: 14.4 (1890/13,057) 95%CI: 13.8–15% (data extracted from graphs). No prevalence data by gender.
| Gender | | [underlined: Associated Factors] :
| Female: | 52.1%, 6791/13,057 | Significant
| Male: | 47.9%, 6266/13,057 | For difficulties initiating sleep : Gender: 1) Female (adj OR: 1.4; 95%CI: 1.2–1.6; p<0.001). Medical conditions: 1) Physical illness (adj OR: 1.9; 95%CI: 1.7–2.2; p<0.001). Psychiatric illness and psychological problems: 1) Mental disorder (adj OR: 3.5; 95%CI: 3.1–4.1; p<0.001). Quality of life: Satisfaction with life (adj OR: 0.4; 95%CI: 0.2–0.7; p<0.01).
| Ethnicity: | NS | For disrupted sleep : Gender: 1) Female (adj OR: 1.3; 95%CI: 1.2–1.5; p<0.001). Psychiatric illness and psychological factors: 1) Mental disorder (adj OR: 3.0; 95%CI: 2.6–3.4; p<0.001). Quality of life: Satisfaction with life (adj OR: 0.4; 95%CI: 0.2–0.7; p<0.01).
| Sample Size: | 16,738 | For early morning awakening : Gender: 1) Female (adj OR: 1.3; 95%CI: 1.1–1.4; p<0.001). Medical conditions: 1) Physical illness (adj OR: 1.6; 95%CI: 1.4–1.8; p<0.001).
| Response Rate: | 78%, 13,057/16,738 | For nonrestorative sleep : Gender: 1) Female (adj OR: 1.3; 95%CI: 1.1–1.4; p<0.001). Medical conditions: 1) Physical illness (adj OR: 1.9; 95%CI: 1.6–2.2; p<0.001). Psychiatric illness and psychological factors: 1) Mental disorder (adj OR: 3.6; 95%CI: 3.2–4.2; p<0.001). Quality of life: Satisfaction with life (adj OR: 0.4; 95%CI: 0.2–0.9; p<0.01).
| | | Non-significant
| | | None reported
Ohayon, MM / 2000 | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
High (7/8) | Age Group: | 19 - 24 yrs | Psychiatric disorders: 1) adjustment disorders (20, 0.9%, 95%CI: 0.5–1.3), 2) anxiety disorders (163, 7.5%, 95%CI: 6.4–8.6): 2a) panic disorder (37, 1.7%, 95%CI: 1.2–2.2), 2b) generalized anxiety (24, 1.1%, 95%CI: 0.7–1.5), 2c) obsessive-compulsive disorder (11, 0.5%, 95%CI: 0.2–0.8), 2d) posttraumatic stress disorder (30, 1.4%, 95%CI: 0.9–1.9), 2e) social phobia (20, 0.9%, 95%CI: 0.5–1.3), 2f) specific phobia (46, 2.1%, 95%CI: 1.5–2.7), 2g) agoraphobia (9, 0.4%, 95%CI: 0.1–0.7), 3) depressive disorders (52, 2.4%, 95%CI: 1.8–3.0).
| Gender | | [underlined: Prevalence] :
| Female: | 50.8%, 1102/2169 | Point prevalence: 5.4% (117/2169), 95%CI: 4.5, 6.4.
| Male: | 49.2%, 1067/2169
| Ethnicity: | NS
| Sample Size: | 2169
| Response Rate: | NS
Ohayon, MM / 1999 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (5/8) | Age Group: | Over 15 yrs | Point prevalence: (Complaint of insomnia symptoms accompanied with sleep dissatisfaction): 16.0% (1890/11,810, 95%CI: 15.3–16.7. No prevalence data by gender.
| Gender
| Female: | 55.5%, 6555/11,810
| Male: | 44.5%, 5255/11,810
| Ethnicity: | NS
| Sample Size: | 11,810
| Response Rate: | NS
Ohayon, MM / 1997 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (8/8) | Age Group: | Over 15 yrs | Point prevalence: (Insomnia complaints lasting for at least 1 month): 15.3% (860/5622) (95%CI: 14.36–16.24).
| Gender
| Female: | 52.1%, 2929/5622
| Male: | 47.9%, 2693/5622
| Ethnicity: | NS
| Sample Size: | 6966
| Response Rate: | 80.7%, 5622/6966
Pallesen, S / 2002 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (7/9) | Age Group: | 60–84 yrs (CS) | Significant
| | 63–83 yrs (CT) - Gs | Psychiatric illness and psychological problems: (CS vs GS vs CT; mean ± SD): 1) Sleep impairment (Sleep Impairment Index scale: 23.1 ± 4.8 vs 10.1 ± 2.7 vs 14.6 ± 6.0; F(1,96) = 237.6), 2) Somatization (Symptom Checklist 90-Revised: CS vs GS: 0.78 ± 0.59 vs 0.32 ± 0.28 F(1, 97) = 20.3), 3) Obsessive-compulsive traits (Symptom Checklist 90-Revised: CS vs GS: 0.95 ± 0.80 vs 0.44 ± 0.31; F(1, 95) = 14.0), 4) Interpersonal sensitivity (Symptom Checklist 90-Revised: CS vs GS): 0.56 ± 0.58 vs 0.25 ± 0.28; F(1, 97) = 9.4), 5) Depression (Symptom Checklist 90-Revised: CS vs GS): 0.74 ± 0.56 vs 0.37 ± 0.26; F(1, 95) = 14.7), 6) Anxiety (Symptom Checklist 90-Revised: CS vs GS): 0.46 ± 0.47 vs 0.09 ± 0.12; F(1, 96) = 22.6), 7) Hostility (Symptom Checklist 90-Revised: CS vs GS): 0.32 ± 0.33 vs 0.11 ± 0.16; F(1, 96) = 12.4), 8) Phobic anxiety (Symptom Checklist 90-Revised: CS vs GS): 0.17 ± 0.27 vs 0.03 ± 0.07; F(1, 97) = 10.4). 9) Mental health global measures (GSI CS vs GS: 0.61 ± 0.39 vs 0.23 ± 0.15; F(1, 92) = 31.0; Positive Symptom Distress Index: 1.75 ± 0.49 vs 1.21 ± 0.20; F(1, 92) = 39.6; Positive Symptom Total: 31.4 ± 16.8 vs 16.6 ± 9.6; F(1, 99) = 25.8; PSWQ: 44.8 ± 10.9 vs 35.7 ± 8.0; F(1, 92) = 18.8, TAS-20: 49.8 ± 9.4 vs 42.6 ± 8.8; F(1, 91) = 14.2) 10) Difficulties identifying feelings (TAS-20 subscale CS vs GS: 15.2 ± 5.8 vs 11.4 ± 4.3; F (1, 93) = 11.7). Socioeconomic status: Education: CS vs GS (p=0.001) vs community controls (p=0.26).
| | 60–86 yrs (CT) - Com | Non-significant
| Gender | | Age: CS vs GS (p=0.48) vs CT (p=0.23). Gender: CS vs GS (p=0.65) vs community controls (p=0.09). Psychiatric illness and psychological problems: (CS vs GS vs CT; mean ± SD): 1) Paranoid ideation: 0.35 ± 0.49 vs 0.13 ± 0.18 vs .033 ± 0.41; F=NS; 2) Psychoticism: 0.21 ± 0.27 vs 0.09 ± 0.14 vs 0.19 ± 0.26; p=NS; 3) Difficulty describing feelings: 13.1 ± 3.4 vs 11.8 ± 3.7 vs 12.6 ± 3.9; p=NS; 4) Externally oriented thinking: 21.2 ± 4.1 vs 19.3 ± 4.7 vs 21.0 ± 4.3; p=NS; 5) # life events: 3.5 ± 3.36 vs 3.1 ± 1.7 vs 4.55 ± 4.21; p=NS; 6) Subjective impact Life events: 8.52 ± 9.44 vs 7.31 ± 5.32 vs 10.7 ± 10.8; p=NS.
| Female: | 49 (CS), 32 (CT) - Gs
| | 41 (CT) - Com
| Male: | 11 (CS), 9 (CT) - Gs
| | 19 (CT) - Com
| Ethnicity: | NS
| Sample Size: | 187 total
| | 60 (CS), 41 (CT) - Gs,
| | 60 (CT) - Com
| Response Rate: | NS (CS), NS (CT) - Gs, 82.6% (CT) - Com
Pavlova, M / 2001 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (4/9) | Age Group | | Significant
| mean ± SD: | 45.9 ± 14 yrs (CS) | Psychiatric illness and psychological problems: (CS vs CT; mean scores for scales/subscales ± SD): 1) Introspectiveness (Introspectiveness score from the Hyperarousal scale): 40.5 ± 0.3 vs 37.1 ±0.4; p<0.002. Memory and cognitive function: (CS vs CT) 1) Hyperarousal (Hyperarousal scale mean total score ± SD, 95%CI: 41.1 ± 10.2 (95%CI: 39.9–42.3) vs 32.6 ± 7.3 (95%CI: 31.4–33.8); p<0.0001). 2) Reaction type (Median React score from the Hyperarousal scale ± range: 4.5 (6–23) vs 2 (0–12).
| | 44.6 ± 15 yrs (CT) | Non-significant
| Gender | | None reported
| Female: | NS
| Male: | NS
| Ethnicity: | NS
| Sample Size: | 532 total
| | 256 (CS), 139 (CT)
| Response Rate: | NS
Perlis, ML / 2001 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (5/9) | Age Group | | Significant
| mean ± SD: | 30.6 ± 8.9 yrs (CS) | Memory: (CT vs CS, mean ± SD): 1) First trial: 46.2 ± 12.6 vs 75.8 ± 12.7, p=0.01.
| | 32.3 ± 11.5 yrs (CT) | Non-significant
| Gender | | Memory: (CT vs CS, mean ± SD): 1) number of words encoded (43 ± 20.0 vs 49 ± 18.3, p=0.61), 2) recognition (false-positive %) (8.9 ± 7.2 vs 20 ± 19.1, p=0.27), 3) free recall (all trials, %) (4.6 ± 3.2 vs 9.8 ± 10.7, p=0.35), 4) recognition: all trials (%) (45.2 ± 11.8 vs 68.6 ± 19.9, p=0.08), Second trial (42.0 ± 17.6 vs 58.0 ± 38.1, p=0.55), Third trial (42.5 ± 26.9 vs 59.7 ± 25.5, p=0.38), Fourth trial (51.6 ± 8.6 vs 59.3 ± 29.9, p=0.69), 5) Recognition speed (true-positive, msec) (2753 ± 820 vs 2137 ± 761, p=0.29), 6) Recognition speed (false-positive, msec) (3358 ± 510 vs 2664 ± 903, p=0.19), 7) Speed (false/true-positive) (1.259 ± 0.20 vs 1.261 ± 0.17, p = 0.99).
| Female: | 3 (CS), 2 (CT)
| Male: | 2 (CS), 2 (CT)
| Ethnicity: | NS
| Sample Size: | 9 total
| | 5 (CS), 4 (CT)
| Response Rate: | NS
Riedel, BW / 2004 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (6/8) | Age Group: | 20–98 yrs | Point prevalence: 32.1% (247/769) (95%CI: 28.8–35.3). No prevalence data by gender.
| Gender | | [underlined: Associated Factors] :
| Female: | 50.7%, 390/769 | Significant (3 groups: Nonsmokers, Light smokers (<15/day) Heavier smoker (≥15/day).
| Male: | 49.3%, 379/769 | Race/ethnicity: (non-smoker vs <15/day vs ≥15/day) p<0.01. Psychiatric illness and psychological problems: 1) Depression (Beck depression inventory OR: 2.03, 95%CI: 1.45–2.83), 2) Anxiety (Trait Anxiety Inventory OR: 8.45, 95%CI: 3.21–22.28; p<0.05). Other factors: 1) Heavy smoking among females (OR: 2.31; p<0.05), 2) Light smoking (adj OR: 2.75; 95%CI: 1.17–6.49; p<0.05). Medical conditions: 1) Physical health problems (Cancer OR: 2.45; 95%CI: 1.14–5.27; p<0.05), 2) High blood pressure (OR: 1.53, 95%CI: 1.11–2.69; p<0.05), 3) Breathing problems (OR: 3.01, 95%CI: 1.68–5.40; p<0.05), 4) Gastrointestinal problems (OR: 2.00, 95%CI: 1.22–3.28; p<0.05).
| Ethnicity: | 53.6%, 536/769 (White) | Non-significant
| | 28.6%, 220/769 (Black) | None reported
| | 0.7%, 6/769 (Asian)
| | 10.8%, 7/769 (NS)
| Sample Size: | 1769
| Response Rate: | 43.4%, 769/1769
Robbins, L / 1995 | Study Design: | Retrospective cross-sectional | [underlined: Co-Morbidity] :
Moderate (4/8) | Age Group: | 18–60 yrs | Migraines.
| Gender | | [underlined: Prevalence] :
| Female: | 79.6%, 393/494 | Sleep onset insomnia: 27% (133/494), 95%CI: 23.1–30.9. Difficulty maintaining sleep insomnia: 26% (128/494), 95%CI:22.1–29.9.
| Male: | 20.4%, 101/494
| Ethnicity: | NS
| Sample Size: | 494
| Response Rate: | 100%
Rocha, FL / 2002A | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (7/8) | Age Group: | Over 60 yrs | One-month prevalence: (Insomnia): 38.9% (590/1516), 95%CI: 34.6–41.3. Male: 28.8% (170/590), 95%CI: 25.1–32.4. Female: 45.3% (419/916), 95%CI: 42.0–48.5.
| Gender | | [underlined: Associated Factors] :
| Female: | 61.1%, 926/1516 | Significant
| Male: | 38.9%, 590/1516 | Gender: 1) Female (adj OR: 1.78; 95%CI: 1.41–2.24). Medical condition: 1) Self-rated reasonable (adj OR: 2.02; 95%CI: 1.50–2.72) and very bad health (adj OR: 3.12; 95%CI: 2.21–4.39), 2) History of previous medical diagnosis of a chronic condition (adj OR: 1.38; 95%CI: 1.10–1.73), 3) Inability to perform routine activities due to a health problems in the last 2 weeks (adj OR: 1.54; 95%CI: 1.10–2.15). Other factors: 1) Staying in bed in the last 2 weeks (adj OR: 1.61; 95%CI: 1.04–2.48), 2) Dissatisfaction with free time arrangements (adj OR: 1.88; 95%CI: 1.28–2.77). Healthcare utilization: 1) Use of sleeping pills: OR: 1.74 (95%CI: 1.38–2.21). Social Relationships: Social support Unsatisfied OR 1.88; (95%CI: 1.28–2.77).
| Ethnicity: | NS | Non-significant
| Sample Size: | 1742 | Age: 60–69yr: 60.9 vs 59.2%, OR 1; 70–79yr: 29.1 vs 30.6% OR 0.92; 95%CI: 0.73–1.16); ≥80yrs: 10.0 vs 10.1%, OR 0.96; 95%CI: 0.68–1.37. Social Relationships: 1) Married/live together vs single: OR 1.05; 95%CI: 0.73–1.53. 2) Social support Indifferent OR 0.95; 95%CI: 0.62–1.43.
| Response Rate: | 87%, 1516/1742
Rocha, FL / 2002B | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (7/8) | Age Group: | Over 18 yrs | One-month prevalence: 35.4% (377/1066), 95%CI: 32.5–38.3. Male: 20.7% (98/472), 95%CI: 17.0–24.3. Female: 46.9% (279/594), 95%CI: 42.9–50.9.
| Gender | | [underlined: Associated Factors] :
| Female: | 55.7%, 594/1066 | Significant
| Male: | 44.3%, 472/1066 | Socioeconomic status: 1) Low education: (1–3 years): males adj OR: 2.2; 95%CI: 1.1–4.1; females adj OR: 1.8; 95%CI: 1.1–3.0; no years of education: females adj OR: 2.6; 95%CI: 1.3–5.1. Age: 1) Age group over 60 years (females) adj OR: 1.8; 95%CI: 1.1–3.3. Healthcare utilization: 1) Use of sleeping pills in the previous 30 days: OR: 3.5; 95%CI: 2.4–4.9.
| Ethnicity: | 53.6%, 572/1066 (White) | Non-significant
| | 2.4%, 26/1066 (Black) | Race/Ethnicity: white vs other: p=0.751. Relationships: Religion: p=0.35
| | 43.8%, 467/1066 (Other)
| | 0.2%, 1/1066 (Unknown)
| Sample Size: | 1221
| Response Rate: | 87.3%, 1066/1221
Roth, T / 1999 | Study Design: | Cross-sectional | [underlined: Associated Factors] :
Moderate (3/8) | Age Group: | 18–65 yrs | Significant
| Gender | | Memory and cognitive function: 1) Impaired concentration (ChI vs non-insomnia);“little trouble”: 68% vs 93%; p=0.01). 2) Difficulties remembering things;“very often or sometimes”: 53% vs 29%; p=0.0).
| Female: | NS | Social relationships: 1) Ability to enjoy relationships;“good or excellent”: 64% vs 89%; p=0.01. 2) Relationships with spouse;“good or excellent”: 70% vs 81%; p=0.01. Medical condition 1) Self-perceived health;“good or excellent”: 53% vs 86%; p=0.01. Psychiatric illness and psychological problems: Ability to handle minor irritations;“good or excellent”: 57% vs 81%; p = 0.0).
| Male: | NS | Non-significant
| Ethnicity: | 86%, 860/1000 (White) | Accidents: (Had an automobile accident due to being tired; ChI vs non-insomnia): 5% vs 2% (p=NS). Quality of life: (ChI vs non-insomnia;“good or excellent”: 70% vs 96%; p = NS). Psychiatric illness and psychological problems: 1) Self-perceived mental health;“good or excellent”: 67% vs 90%; p=NS).
| | 8%, 80/1000 (Black)
| | 3%, 30/1000 (Hispanic)
| | 3%, 30/1000 (Other)
| Sample Size: | 1950
| Response Rate: | 51.2%, 1000/1950
Sabbatini, M / 2002 | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
Moderate (3/8) | Age Group | | Medically Ill (Renal disorders).
| mean ± SD: | 61.0 ± 14.4 yrs | [underlined: Prevalence] :
| Gender | | Point prevalence: 45% (311/694), 95%CI: 41.3–48.7. Male: 40.5% (156/385), 95%CI: 35.6–45.4. Female: 50.1% (155/309), 95%CI: 44.5–55.6.
| Female: | 44.5%, 309/694 | [underlined: Associated Factors] :
| Male: | 55.5%, 385/694 | Significant
| Ethnicity: | NS | Psychiatric illness and psychological problems: (insomnia vs non-insomnia): 1) Anxiety (45% vs 33.2%; p<0.04). Medical conditions: 1) Longer time on dialysis (13–48 months adj OR: 1.7; 95%CI: 1.1–2.8; p=0.03; 49–84 months adj OR: 1.8; 95%CI: 1.2–2.8; p=0.006; ≥ 85 months adj OR: 1.7; 95%CI: 1.2–2.7; p=0.01), 2) Having dialysis in the morning (adj OR: 1.6; 95%CI: 1.2–2.2; p=0.003), 3) High levels of parathyroid hormone (> 149 pg/ml) (adj OR: 1.5; 95%CI: 1.0–2.2; p=0.05). 4) Pruritus (% insomnia vs non-insomnia; 19.9% vs 13.1%; p<0.04).
| Sample Size: | 694 | Non-significant
| Response Rate: | NS | Other factors: BMI, Blood pressure, Smoking, Alcohol, Caffeine intake all p=NS
Saletu-Zyhlarz, G / 1997 | Study Design: | Cross-sectional case-control | [underlined: Co-Morbidity] :
Low (1/9) | Age Group: | 24–65 yrs | Cases: all CS have generalized anxiety disorder (GAD). Controls: normal.
| mean ± SD: | 43.2 ± 11.7 yrs (CS) | [underlined: Associated Factors] :
| | 43.0 ± 11.7 yrs (CT) | Significant
| Gender | | Psychiatric illness and psychological problems: Mood: (CS vs CT, median, mean ± SD): 1) Evening well-being score (18, 19 ± 12 vs 7, 11 ± 10, p<0.01), 2) Morning well-being score (16, 18 ± 12 vs 7, 11 ± 10, p<0.05), 3) Drive (mm) (51, 50 ± 26 vs 37, 38 ± 25, p<0.05), 4) Mood (mm) (63, 62 ± 18 vs 74, 75 ± 17, p<0.01), 5) Drowsiness (mm) (59, 58 ± 27 vs 45, 42 ± 26, p<0.01). Cognitive function: (psychometry) (cases vs controls, median, mean ± SD): 1) Fine-motor activity, right (37, 37 ± 11 vs 52, 49 ± 9, p , 0.01), 2) Fine-motor activity, left (27, 28 ± 9 vs 41, 40 ± 11, p<0.01), 3) Fine-motor activity, right + left (65, 66 ± 18 vs 91, 86 ± 17, p , 0.01), 4) Reaction time (mean score ) (534, 545 ± 108 vs 473, 478 ± 113, p , 0.01).
| Female: | 56.8%, 25/44 (CS) | Non-significant
| | 54.5%, 24/44 (CT) | Psychiatric illness and psychological problems: Mood: Affectivity (mm) (68, 63 ± 23 vs 71, 71 ± 21, p=NS). Cognitive function: (psychometry) (CS vs CT, median, mean ± SD): 1) Attention score (522, 536 ± 145 vs 520, 519 ± 145, p=NS), 2) Concentration (% errors) (3, 4 ± 3 vs 3, 5 ± 5, p=NS), 3) Attention variability score (15, 16 ± 9 vs 15, 15 ± 5, p=NS), 4) Numerical memory (6, 6 ± 2 vs 6, 6 ± 2, p=NS 5) Reaction time, variability (mean score) (109, 107 ± 30 vs 105, 97 ± 37, p=NS), 6) Reaction time, errors of omission (n) (1, 2 ± 2 vs 1, 3 ± 3, p=NS), 7) Reaction time, errors of omission (n) (0, 0 ± 1 vs 0, 0 ± 1, p=NS).
| Male: | 43.2%, 19/44 (CS)
| | 45.5%, 20/44 (CT)
| Ethnicity: | NS
| Sample Size: | 88 total
| | 44 (CS), 44 (CT)
| Response Rate: | 100%, 44/44 (CS)
| | 77.3%, 34/44 (CT)
Savard, J / 2001 | Study Design: | Cross-sectional | [underlined: Co-Morbidity] :
Moderate (4/8) | Age Group: | 28–90 yrs | Medically ill (Metastatic breast cancer).
| Gender | | [underlined: Prevalence] :
| Female: | 339 | Point prevalence: (Insomnia symptoms): 51.3% (154/300) (95%CI: 45.7–56.9); (Insomnia syndrome): 19% (56/300) (95%CI: 14.6–23.4); (Chronic Insomnia syndrome): 17.6% (53/300) (95%CI: 13.3–21.9).
| Male: | 0 | [underlined: Associated Factors] :
| Ethnicity: | All White (Caucasian) | Significant
| Sample Size: | 339 | For insomnia symptoms : Medical conditions: 1) Cancer stage at diagnosis (I-III) (OR: 0.46; 95%CI: 0.24–0.88; p<0.05), 2) Lumpectomy (OR: 5.2; 95%CI: 1.5–18.1; p<0.01), 3) Chemotherapy (OR: 4.3; 95%CI: 1.7–10.7; p<0.01). Social Relationships: 1) Widowhood (OR: 4.7; 95%CI: 1.5–15.2; p<0.01). Other factors: 1) Antecedents of insomnia symptoms (OR: 0.18; 95%CI: 0.06–0.52; p<0.01).
| Response Rate: | 88%, 300/339 | For insomnia syndrome : Socioeconomic factors: Socioeconomic status: 1) University degree (OR: 4.0; 95%CI: 1.1–15.0; p<0.05). Social Relationships: Separated/divorced (OR: 4.2; 95%CI: 1.4–13.1; p<0.05). 3) Widowhood (OR: 0.08; 95%CI: 0.01–0.64; p<0.05).
| | | Direct and indirect costs: 1) Sick leave: (OR: 14.1; 95%CI: 1.1–173.8; p<0.05), 2) Unemployment (OR: 3.8; 95%CI: 1.1–13.6; p<0.05).
| | | Non-significant
| | | None reported
Schneider-Helmert, D / 1987 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (7/9) | Age Group: | 32–61 yrs (CS) | Significant
| | 28–61 yrs (CT) | Psychiatric illness and psychological problems: (CS vs CT; mean scores ± SD): 1) Personality patterns (MMPI): Hypochondriasis: 62.3 ± 9.5 vs 48.1 ± 7.2,; p<0.00001; Depression: 64.0 ± 12.7 vs 45.9 ± 7.5, p<0.00001; Hysteria: 65.3 ± 7.6 vs 52.7 ± 9.2, 0.0001; Psychopatic deviate: 62.9 ± 9.2 vs 49.2 ± 7.4, p<0.0001; Paranoia: 61.3 ± 12.6 vs 49.3 ± 11.1, p<0.01; Psychasthenia: 47.3 ± 8.2 vs 62.0 ± 9.6, p<0.0001; Schizophrenia: 60.6 ± 11.0 vs 49.1 ± 7.1; p<0.005; Ego strength: 44.4 ± 12.5 vs 56.5 ± 5.1, p<0.001; Impulsivity: 52.8 ± 8.8 vs 45.6 ± 5.6, p<0.01; Control: 54.8 ± 9.7 ± 44.1 ± 12.3; Anxiety: 57.3 ± 11.6 vs 45.2 ± 9.9, 0.005; Internalization: 55.2 ± 10.1 vs 48.8 ± 7.6, p<0.05. Cognitive function: 1) Auditory function: 7.9 vs 10.5, p<=0.001; 2) Line judgment all sessions p =0.01; 3) Line tracing (3 errors) 20.3 vs 13.6, p=0.005.
| Gender | | Non-significant
| Female: | 9 (CS), 9 (CT) | Psychiatric illness and psychological problems: (CS vs CT; mean scores ± SD): 1) Scale L: 49.6 ± 8.1 vs50.3 ± 10.4; 2) Scale K: 50.8 ± 8.3 vs 54.6 ±8.1; 3) Masculinity-femininity: 45.5 ± 10.3 vs 48.3 ± 11.0; 4) Hypomania: 46.8 ± 13.3 vs 42.1 ± 12.3; 5) Social introversion: 56.9 ± 12.2 vs 52.3 ± 12.3. All p=NS. Cognitive function: (3 sessions @ 0945, 1245, & 1500) # correct responses: Logical reasoning, Addition, Digit symbol substitution, Word detection, Visual Search All p=NS.
| Male: | 7 (CS), 7 (CT)
| Ethnicity: | NS
| Sample Size: | 32 total
| | 16 (CS), 16 (CT)
| Response Rate: | NS
Seidel, WF / 1984 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (6/9) | Age Group | | Significant
| mean ± SD: | 29 ± 5 yrs | Laboratory measures (CS vs CT; mean min. ± SD): 1) Objective total sleep time: 402.8 ± 50.5 vs 445.8 ± 42.4, p<0.001; 2) Subjective total sleep time: 352.2 ± 94.9 vs 441.2 ± 44.7, p<0.001.
| Gender | | Non-significant
| Female: | 23 (CS), 23 (CT) | Psychiatric illness and psychological problems: 1) Profile of mood state (POMS): Fatigue: 6.6 ± 6.2 vs 3.9 ± 4.5; Depression: 2.3 ± 3.6 vs 1.2 ± 1.9; Anger/hostility: 3.2 ± 5.9 vs 1.2 ± 2.2; Tension/anxiety:1.1 ± 3.8 vs -0.7 ± 2.8; Vigor: 9.5 ± 6.5 vs 11.7 ± 7.8; Total mood disturbance: 5.2 ± 19.3 vs -5.9 ± 16.9; all p=NS. 2) MMPI scale: Scale L: 48.1 ± 7.8 vs 45.5 ± 5.7; Scale F: 56.5 ± 8.7 vs 53.8 ± 10.2; Scale K: 54.3 ± 8.1 vs 56.5 ± 8.8; Hypochondriasis: 53.3 ± 7.6 vs 47.8 ± 9.2; Depression: 56.8 ± 9.8 vs 53.0 ± 8.1; Hysteria: 59.2 ± 7.2 vs 55.5 ± 8.5; Psychopathic deviate: 61.1 ± 8.0 vs 59.7 ± 8.8; Paranoia: 61.1 ± 6.7 vs 57.7 ± 6.8; Psychasthenia: 59.9 ± 7.7 vs 55.1 ± 6.8; Schizophrenia: 57.4 ± 7.4 vs 58.1 ± 8.7; Hypomania: 65.2 ± 10.7 vs 61.6 ± 11.1. All p=NS.
| Male: | 15 (CS), 15 (CT)
| Ethnicity: | NS
| Sample Size: | 76 total
| | 38 (CS), 38 (CT)
| Response Rate: | NS
Sharpley, AL / 1997 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (5/9) | Age Group | 54.7, 40–69 yrs (CS) | Significant
| (mean, range) | 53.9, 40–68 yrs (CT) | Psychiatric illness and psychological problems: (CS vs CT): 1) Past psychiatric disorder 45% (9/20) vs 10% (2/20), P<0.01; OR = 7.36, 95%CI:1.34, 40.55, 2) Major depression 35% (7/20) vs 5% (1/20), p<0.01, 3) Past alcohol dependence 20% (4/20) vs 0, p<0.05,.
| Gender | | Non-significant
| Female: | 50% (CS), 50% (CT) | Psychiatric illness and psychological problems: (CS vs CT): 1) Panic disorder 5% (1/20) vs 0, p=NS; 2) Eating disorder 5% (1/20) vs 0, p=NS; 3) Past alcohol abuse 5% (1/20) vs 5% (1/20), p=NS; 4) Past drug dependence 5% (1/20) vs ), p=NS.
| Male: | 50% (CS), 50% (CT)
| Ethnicity: | NS
| Sample Size: | 40 total
| | 20 (CS), 20 (CT)
| Response Rate: | 100% in both groups
Shaver, JLF / 2002 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (6/9) | Age Group: | PP-type: | Significant
| mean ± SD: | 46.7±3.3 yrs (CS) | Psychiatric illness and psychological problems: Psychological Distress Scores (PP-type vs SO-type insomnia vs CT, mean ± SD): 1) Somatization: 0.65 ± 0.61 vs 0.54 ± 0.47 vs 0.27 ± 0.31, p = 0.03; 2) Global severity: 0.60 ± 0.64 vs 0.50 ± 0.38 vs 0.28 ± 0.28, p = 0.04, 3) Positive symptom distress: 1.6 ± 0.40 vs 1.4 ± 0.20 vs 1.1 ± 0.40, p = 0.01.
| | SO-type: | Non-significant
| | 46.1±4.4 yrs (CS) | Psychiatric illness and psychological problems: Stress Exposure (PP-type vs SO-type insomnia vs CT, mean ± SD): 1) Daily diary: the sum of items, how stressful: (a) felt today, (b) relationship with closest friends, (c) family life, (d) work; rated 1 = not at all to 6 = very much (2.4 ± 0.6 vs 2.4 ± 0.5 vs 2.2 ± 0.76, p=NS), 2) Daily hassles, Daily Hassles and Uplifts Scale: Number (23.9 ± 15.1 vs 19.8 ± 13.9 vs 16.7 ± 15, p=NS), Severity (29.6 ± 26.2 vs 28 ± 22.4 vs 20.3 ± 23.1, p=NS), Index of Severity (1.1 ± 0.32 vs 0.89 ± 0.47 vs 0.95 ± 0.32, p=NS). 3) Stressful life events, Stressful Life Events Questionnaire: Positive (4.8 ± 3.1 vs 4.6 ± 3.4 vs 6.2 ± 3.2, p=NS), Negative: (5.3 ± 3.9 vs 5.2 ± 4.8 vs 4.8 ± 3.9, p=NS), 4) Small life events, Inventory of Small Life Events: Positive (27.9 ± 10 vs 27.6 ± 8.9 vs 30.2 ± 7.9, p=NS), Negative: (11.8 ± 7.4 vs 10.6 ± 7.3 vs 12.1 ± 6.0, p=NS). Psychological Distress Scores 1) Obsessive compulsive (0.78 ± 0.85 vs 0.64 ± 0.57 vs 0.44 ± 0.59, p = 0.24), 2) Interpersonal sensitivity (0.67 ± 0.64 vs 0.46 ± 0.43 vs 0.42 ± 0.54, p = 0.21), 3) Depression (0.79 ± 0.83 vs 0.69 ± 0.63 vs 0.42 ± 0.37, p = 0.26), 4) Anxiety (0.47 ± 0.76 vs 0.39 ± 0.39 vs 0.16 ± 0.24, p = 0.11), 5) Hostility (0.38 ± 0.67 vs 0.32 ± 0.43 vs 0.27 ± 0.32, p = 0.98), 6) Psychoticism (0.31 ± 0.63 vs 0.25 ± 0.29 vs 0.07 ± 0.11, p = 0.10), 7) Phobic anxiety (0.21 ± 0.58 vs 0.12 ± 0.20 vs 0.06 ± 0.13, p = 0.52), 8) Paranoid ideation (0.43 ± 0.61 vs 0.37 ± 0.45 vs 0.29 ± 0.32, p = 0.85), 9) Positive symptom total (31.7 ± 20.8 vs 30.1 ± 17.7 vs 19.1 ± 16.7, p = 0.10.
| | 44.4±3.5 yrs (CT) | PP-type = psychophysiologic type insomnia; SO-type = subjective only type insomnia;
| Gender
| Female: | 131
| Male: | 0
| Ethnicity: | Cases : PP-type: White 76.2%, African American 9.5%, unknown 14.3%. Cases : SO-Type: White 72.2%, Asian/Pacific Islander 5.6%, African American 11.1%, Native American 5.6%, unknown 5.6%. Controls : White 92.9%, Asian/Pacific Islander 7.1%
| Sample Size: | 101 (CS), 30 (CT)
| Response Rate: | NS
Shochat, T / 1999 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Low (1/8) | Age Group: | 18–87 yrs | Point prevalence: 19% (54/286) (95%CI:14.5, 23.5).
| Gender | | [underlined: Associated Factors] :
| Female: | 58%, 166/286 | Significant
| Male: | 42%, 120/286 | For all factors (GS vs occasional insomniac vs ChI). Psychiatric illness and psychological problems: Mood: 1) General mood Excellent p<0.0010 (25.3% (22/88) vs 11.3% (16/141) vs 11.3% (6/54)) Good (62.1% (55/88) vs 57.4% (81/141) vs 49.1% (27/54) Fair (10.3% (9/88) vs 24.8% (35/141) vs 35.8% (19/54) Poor (1.1% (1/88) vs 6.4% (9/141) vs 3.8% (3/54). 2) Ability to handle minor irritations p = 0.0060 Excellent (15.9% (14/88) vs 9.3% (13/141) vs 11.3% (6/54)) Good (58.0% (51/88) vs 43.6% (61/141) vs 45.3% (24/54)) Fair (21.6% (19/88) vs 36.4% (51/141) vs 30.2% (16/54)) Poor (2.3% (2/88) vs 10.7% (15/141) vs 13.2% (7/54). Cognitive function: 1) Ability to concentrate p = 0.0010 Excellent (19.3% (17/88) vs 9.3% (13/141) vs 13.2% (7/54) Good (68.2% (60/88) vs 57.9% (82/141) vs 52.8% (29/54) Fair (11.4% (10/88) vs 30.0% (42/141) vs 30.2% (16/54) Poor (1.1% (1/88) vs 2.1% (3/141) vs 3.8% (2/54). Memory: 1) Having trouble remembering p = 0.0370 Very often (4.5% (4/88) vs 9.3% (13/141) vs 11.1% (6/54) Sometimes (34.1% (30/88) vs 43.6 (61/141) vs 50.0% (71/141) Not very often (45.5% (40/88) vs 37.9% (53/141) vs 20.4% (11/54) Never (13.6% (12/88) vs 7.9% (11/141) vs 16.7% (9/54). Social relationships: 1) Personal relationship with spouse p = 0.0030 Excellent (44.9% (40/88) vs 26.3% (37/141) vs 23.8% (13/54) Good (38.5% (34/88) vs 43.2% (61/141) vs 40.5% (22/54) Fair (14.1% (12/88) vs 18.6% (26/141) vs 28.6% (15/54) Poor (2.6% (2/88) vs 11.9% (17/141) vs 7.1% (4/54). 2) Ability to enjoy family/social life p = 0.0050 Excellent (29.5% (26/88) vs 16.3% (23/141) vs 17.0% (9/54)) Good 48.9% (43/88) vs 48.2% (68/141) vs 35.8% (19/54)) Fair (14.5% (13/88) vs 27.7% (39/141) vs 34.0% (18/54)) Poor (4.8% (4/88) vs 7.8% (11/141) vs 13.2% (7/54). Quality of life: 1) General quality of life p = 0.0060 Excellent (18.2% (16/88) vs 10.7% (15/141) vs 9.6% (5/54)) Good (67.0% (59/88) vs 61.4% (87/141) vs 51.9% (28/54)) fair (11.4% (10/88) vs 25.7% (36/141) vs 34.6% (19/54)) Poor (2.3% (2/88) vs 0.7% (1/141) vs 1.9% (1/54)). Work performance: 1) Ability to accomplish things during the day p<0.0010 Excellent (29.5% (26/88) vs 15.7% (22/141) vs 11.3% (6/54)) Good (59.1% (52/88) vs 53.6% (75/141) vs 56.6% (31/54)) Fair (6.8% (6/88) vs 27.1% (38/141) vs 22.6% (12/54)) Poor (3.4% (3/88) vs 3.6% (5/141) vs 7.5% (4/54)).
| Ethnicity: | White 52%, Asian 28%, African-American 2.8%, Hispanic 4.5%, Other 12.2% | Non-significant
| Sample Size: | 286 | None reported
| Response Rate: | NS
Sugerman, JL / 1985 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
High (6/9) | Age Group: | 21–55 yrs | Significant
| Gender | | Memory and cognitive function: (Objective vs Subjective insomnia vs CT): 1) Waking function (Auditory Vigilance Task number of misses: 7.73 vs 29.95 vs 6.68, p<0.05).
| Female: | 6 (CS)-objective | Non-significant
| | 6 (CS)-subjective, 6 (CT) | None reported
| | 2 (CS)-objective
| Male: | 2 (CS)-subjective, 2 (CT)
| Ethnicity: | NS
| Sample Size: | 24 total
| | 16 (CS), 8 (CT)
| Response Rate: | NS
Taylor, DJ / 2003 | Study Design: | Cross-sectional | [underlined: Prevalence] :
High (6/8) | Age Group: | 20–98 yrs | Prevalence parameters: 19.6% (151/772), 95%CI:16.8, 22.4.
| Gender | | [underlined: Associated Factors] :
| Female: | 50.6%, 391/772 | Significant
| Male: | 49.4%, 381/772 | Age: (no insomnia vs insomnia, mean ± SD): 50.41 ± 19.1 vs 61.49 ± 19.68, F = 35.73, p<0.001. Gender: (no insomnia vs insomnia, % female): 45.3 (174/384) vs 60.0 (90/150), p<0.01, OR = 0.55 (0.38, 0.81. Medical conditions: (% no insomnia vs % insomnia): 1) Heart 9.1 (35/384) vs 23.3 (35/150), F = 19.15, p<0.001, OR = 0.32 (0.20, 0.55), 2) Cancer 4.2 (16/384) vs 9.3 (14/150), F = 5.43, p<0.05, OR = 0.42 (0.20, 0.89), 3) HTN 18.2 (70/384) vs 44 (66/150), F = 37.74, p<0.001, OR = 0.28 (0.19, 0.43), 4) Neurological 1.3 (5/384), vs 7.3 (11/150), F = 13.50, p<0.001, OR = 0.17 (0.06, 0.49), 5) Respiratory 5.7 (22/384) vs 24.7 (37/150), F = 39.36, p<0.001, OR = 0.19 (0.11, 0.33), 6) Urinary 9.6 (37/384) vs 18 (27/150), ). Race/Ethnicity: (no insomnia vs insomnia, % African American): 25 (96/384) vs 28 (42/150), p=NS, OR = 0.86 (0.56, 1.31). F== 7.154, p<0.01, OR = 0.49 (0.28, 0.83), 7) Diabetes 3.6 (14/384) vs 12.7 (19/150), F = 15.14, p<0.001, OR = 0.26 (0.13, 0.54), 8) Pain 19 (73/384) vs 48 (72/150), F = 45.83, p<0.001, OR = 0.25 (0.17, 0.38), 9) Gastrointestinal 9.4 (36/384) vs 32.7 (49/150), F = 43.77, p<0.001, OR = 0.21 (0.13, 0.35). Healthcare Utilization: 1) Number of medications 1.68 ± 1.93 vs 3.44 ± 2.79, F = 68.20, p<0.001.2) Psychiatric Conditions: Beck Depression Inventory 5.72 ± 5.37 vs 13.08 ± 8.93 (means adjusted for ethnicity and gender: 6.63 ± 7.19 vs 12.42 ± 6.79, p<0.001, adjusted for neurological problems, PLMD/RLS and cigarette use, OR = 8.96 (3.97, 20.19, p<0.001, reference group people with insomnia). Psychological Conditions: 33.14 ± 9.33 vs 42.26 ± 11.70, p<0.001.
| Ethnicity: | Caucasians 69.8% (539/772), African Americans 28.9% (223/772), Asian 0.9% (7/772), Hispanic 0.1% (1/772) | Non-significant
| Sample Size: | 1769 | Race/Ethnicity: (no insomnia vs insomnia, % African American): 25 (96/384) vs 28 (42/150), p=NS, OR = 0.86 (0.56, 1.31). Other factors: Alcohol (drinks/wk): 2.74 ±5.19 vs 2.0 ± 4.93, p=NS; Caffeine drinks/day: 2.36 ± 2.46 vs 2.21 ± 2.67, p=NS. Smoking and BMI p=NS.
| Response Rate: | 49%, 859/1,769
Terzano, MG / 2004 | Study Design: | Cross-sectional | [underlined: Co-morbidity] :
Moderate (4/8) | Age Group: | > 18 yrs | Medically ill: [1) Cardiovascular (1149; 35%), 2) MSK and connective (921; 28%), 3) Digestive (624; 19%), 4) Endocrine, nutritional, metabolic, immunity (556, 16.9%), 5) Brain, nervous system and sense organs (495, 15.1%), 6) Respiratory (460, 14%), 7) Genitourinary (362, 11%), 8) Infectious and parasitic (74, 2.3%), 9) Other (1008, 30.7%)].
| Gender | | [underlined: Prevalence] :
| Female: | 60.90% | Point prevalence (Sleep difficulties ≥ one month): 63.7% (2093/3284) (95%CI: 62–65). Male: 59.6% (766/1284) (95%CI: 56.9–62.2). Female: 66.3% (1327/2000) (95%CI: 64.2–68.3).
| Male: | 39.10% | [underlined: Associated Factors] :
| Ethnicity: | NS | Significant
| Sample Size: | 3284 | Age: Older (adj OR: 1.02; 95%CI: 1.02–1.03). Gender: 1) Female (adj OR: 1.19; 95%CI: 1.01–1.40). Psychiatric illness and psychological problems: 1) Depression (adj OR: 2.70; 95%CI: 2.31–3.15). Medical condition: 1) Involvement of > 1 organ system (adj OR: 1.24; 95%CI: 1.06–1.48). Socioeconomic status: 1) < junior high (adj OR: 1.18; 95%CI: 1.00–1.40). Healthcare utilization: 1) Use of prescribed drugs (OR: 2.26; 95%CI: 1.95–2.62), 2) > 1 hospitalization (OR: 1.61; 95%CI: 1.11–2.32), 3) > 1 GP home visit (OR: 2.31; 95%CI: 1.30–4.09), 4) > 1 GP office visit (OR: 1.81; 95%CI: 1.56–2.10), 5) > 1 call to a GP (OR: 1.48; 95%CI: 1.27–1.73), 6) > 1 laboratory test (OR: 1.43; 95%CI: 1.23–1.65), 7) > 1 drug prescription (OR: 1.81; 95%CI: 1.56–2.09). Quality of life: 1) SF-36 mean scores ± SD); No insomnia vs Level I vs Level II insomnia; (data extracted from graphs): Physical functioning (90.01 vs 81.11 vs 79.34), Role limitations physical (82.3 vs 76.0 vs 63.3), Bodily pain (74.4 vs 69.8 vs 61.8), Health perception (69.8 vs 61.6 vs 55.9), Energy/fatigue (64.7 vs 62.3 vs 50.0), Social functioning (81.4 vs 78.1 vs 64.0), Role limitations emotional (83.9 vs 78.5 vs 56.7), Mental health (71.6 vs 67.7 vs 52.7)). Work Performance: Direct and indirect costs: 1) > 1 sick leave day (OR: 1.54; 95%CI: 1.17–2.01; N = 1389 employed patients).
| Response Rate: | NS | Non-significant
| | | Other factors: BMI, Smoking, and Caffeine intake p=NS.
Vgontzas, AN / 1995 | Study Design: | Cross-sectional case-control | [underlined: Co-Morbidity] :
Low (2/9) | Age Group: | 18–86 yrs (CS) | Psychiatric illness in cases recruited from the sleep clinic: 98.3% (172/175) had at least one psychiatric illness as a secondary disorder: 1) depression 58.3% (102/175): 1a) major depression 10.3% (18/175), 1b) dysthymia 36.6% (64/175), 1c) other minor depression (atypical depression) 10.9% (19/175), 1d) bipolar disorder 5.7% (1/175).
| | 16–80 yrs (CT) | [underlined: Associated Factors] :
| Gender | | Non-Significant
| Female: | 50.1%, 188/375 (CS) | Medical conditions: (CS vs CT) 1) sleep apnea 2.3% 8/375) vs 1.3% (2/150), OR = 1.61 (0.34, 7.69), 2) sleep apneic activity 13.9% (52/375) vs 14.7% (22/150), OR = 0.94 (0.55, 1.61), 3) nocturnal myoclonus/nocturnal myoclonic activity 11.5% (43/375) vs 8.5% (11/150), OR = 1.63 (0.82, 3.27).
| | 58.7%, 88/150 (CT)
| Male: | 49.9%, 187/375 (CS)
| | 41.3%, 62/150 (CT)
| Ethnicity: | NS
| Sample Size: | 525 total
| | 375 (CS), 150 (CT)
| Response Rate: | NS
Vignola, A / 2000 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (5/9) | Age Group: | Over 55 yrs | Significant
| Gender | | Psychiatric illness and psychological problems: (drug-free Chl vs insomnia using benzodiazepines vs CT; mean ± SD): 1) Depression (Beck Depression Inventory): 9.00 ± 4.48 vs 9.40 ± 7.16 vs 1.75 ± 1.6, p<0.01. 2) Anxiety (Beck Anxiety Inventory): 9.10 ± 8.38 vs 8.60 ± 5.4 vs 1.20 ± 1.47, p<0.01. 3) Global security (Brief symptom inventor): 0.57 ± 0.35 vs 0.62 ± 0.42 vs 0.13 ± 0.15, p<0.01. 4) Subjective measures related to neuropsychological performance (Visual Analogue Scale-VAS for Energy): 49.80 ± 19.35 vs 46.10 ± 23.23 vs 24.25 ± 12.23, p<0.01. VAS for Mood: 35.63 ± 16.99 vs 38.85 ± 20.94 vs 15.75 ± 9.94, p<0.01. VAS for Tiredness: 51.50 ± 20.77 vs 47.70 ± 17.14 vs 21.55 ± 11.16, p<0.01. VAS for Stress/Tension: 38.50 ± 18.70 vs 39.60 ± 17.90 vs 16.85 ± 8.77, p<0.01. VAS for Motivation: 68.60 ± 20.24 vs 80.60 ± 20.38 vs 84.80 ± 15.7, p<0.05. Memory and cognitive function: 1) Attention and concentration (Digit Span Forward (percentiles): 33.60 ± 27.23 vs 41.80 ± 28.89 vs 63.95 ± 25.64, p< 0.01; Digit Span Backward (percentiles): 42.55 ± 30.60 vs 45.80 ± 21.43 vs 65.45 ± 23.32, p<0.05. 2) Subjective measures related to neuropsychological performance (Visual Analogue Scale-VAS for alertness: 44.20 ± 22.52 (p<0.01) vs 37.55 ± 22.72 (p<0.05) vs 21.55 ± 13.01, VAS for performance expectancy: 57.85 ± 17.22 (p<0.01) vs 73.55 ± 16.98 vs 83.90 ± 12.78, VAS for Performance: 61.40 ± 13.95 (p<0.05) vs 61.75 ± 12.58 (p<0.05) vs 71.07 ± 13.56).
| Female: | 10-ChI/BNZ (CS) | Non-significant
| | 11-drug-free ChI (CS) | Memory and cognitive function: 1) Mini-mental state: 29.1 ± 1.12 vs 28.75 ± 1.25 vs 28.85 ± 1.04. 2) Vocabulary: 17.9 ± 3.84 vs 12.0 ± 3.09 vs 13.3 ± 2.36. 3) Information: 10.15 ± 3.51 vs 10.0 ± 3.01 vs 11.5 ± 3.4, all p=NS. No difference on visual and verbal memory, p>0.19; psychomotor speed, p> 0.23; and executive functions, p>0.9.
| | 9 (CT)
| Male: | 10-ChI/BNZ (CS)
| | 9-drug-free ChI (CS)
| | 11 (CT)
| Ethnicity: | NS
| Sample Size: | 60 total
| | 20 – ChI/BNZ (CS), 20 drug-free ChI (CS), 20 (CT)
| Response Rate: | NS
Vincent, NK / 2000 | Study Design: | Cross-sectional case-control | [underlined: Co-Morbidity] :
Moderate (4/9) | Age Group | | Cases: 39% (12/32) had at least one secondary co-morbidity: generalized anxiety disorder (34%), social phobia (16%), hypochondriasis (3%), obsessive-compulsive disorder (3%), and major depression (3%). Controls: normal.
| mean ± SD: | 46.91±10.04 yrs (CS) | [underlined: Associated Factors] :
| | 39.6 ±11.49 yrs (CT) | Significant
| Gender | | Psychiatric illness and psychological problems: Perfectionism variables (CS vs CT, mean score ± SD): 1) Doubts about action: 10.38 ± 3.59 vs 7.46 ± 2.47, t = 3.52, p = 0.001; 2) Parental criticism: 9.44 ± 4.49 vs 6.50 ± 2.32, t = 3.21, p = 0.002; 3) Concern over mistake: 20.97 ± 7.29 vs 16.11 ± 5.38, t = 2.83, p = 0.007; 4) Socially prescribed: 49.82 ± 10.95 vs 42.23 ± 13.92, t = 2.35, p = 0.02.
| Female: | 72%,23/32 (CS), NS(CT) | Non-significant
| Male: | 28%, 9/32 (CS), NS (CT) | 1) Personal standards: 21.94 ± 4.87 vs 20.42 ± 5.08, t = 1.16, p = 0.25; 2) Parental expectations: 12.31 ± 4.61 vs 11.46 ± 3.74, t = 0.76, p = 0.45. 3) Self-oriented; 64.24 ± 18.23 vs 58.38 ± 14.51;T = 1.34, P=0.36; 4) Other-oriented: 54.76 ± 9.52 vs 54.23 ± 13.08, t = 0.17, p = 0.86.
| Ethnicity: | 30/32 Caucasian (CS)
| Sample Size: | 58 total
| | 32 (CS), 26 (CT)
| Response Rate: | NS
Wang, W / 2001 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (4/9) | Age Group | | Significant
| mean ± SD: | 30.2 ± 7.0 yrs (CS) | Psychiatric illness and psychological problems: (CS vs CT; mean ± SD): 1) Thrill and adventure seeking behaviour (Zuckerman's sensation seeking scales): 4.0 ± 2.4 vs 6.4 ± 2.5; p<0.05; 2) Impulsivity (Zuckerman-Kuhlman's personality questionnaire): 4.0 ± 1.9 vs 2.7 ± 1.6; p<0.05; 3) Neuroticism-anxiety (Zuckerman-Kuhlman's personality questionnaire: 11.7 ± 4.6 vs 7.3 ± 2.8; p<0.05).
| | 27.2 ± 5.0 yrs (CT) | Non-significant
| Gender | | Psychiatric illness and psychological problems: Zuckerman's sensation seeking scales (CS vs CT; mean ± SD): 1) Experience seeking: 3.1 ± 1.7 vs 4.0 ± 1.9; 2) Disinhibition: 2.9 ± 2.1 vs 2.8 ± 1.8; 3) Boredom susceptibility: 2.5 ± 1.7 vs 1.5 ± 1.5. 4) Impulsive sensation seeking (Zuckerman-Kuhlman's personality questionnaire): 8.8 ± 3.2 vs 8.2 ± 3.0; 5) General sensation seeking: 4.8 ± 2.3 vs 5.5 ± 2.1; 6) Aggression-hostility: 7.8 ± 3.7 vs 6.3 ± 2.7; 7) Activity 7.6 ± 3.4 vs 8.7 ± 2.7; 8) Sociability: 7.3 ± 3.8 vs 7.3 ± 2.4. All p=NS.
| Female: | 12 (CS), 19 (CT)
| Male: | 11 (CS), 9 (CT)
| Ethnicity: | NS
| Sample Size: | 51 total
| | 23 (CS), 28 (CT)
| Response Rate: | 100%, 23/23 (CS)
| | 89.2%, 25/28 (CT)
Yeo, BKL / 1996 | Study Design: | Cross-sectional | [underlined: Prevalence] :
Moderate (3/8) | Age Group: | 15–55 yrs | One-year prevalence: 15.3% (370/2418) (95%CI: 13.8–16.73). Male: 12.9% (159/1209) (95%CI: 11.02–14.78). Female: 17.5% (211/1209) (95%CI: 15.36–19.64).
| Gender | | [underlined: Associated Factors] :
| Female: | 50%, 1209/2418 | Significant
| Male: | 50%, 1209/2418 | Gender: 1) Female (OR: 1.39; 95%CI: 1.11- 1.74; p<0.01). Race/ethnicity: 1) Malay vs Chinese (OR: 1.37; 95%CI: 1.06–1.75; p<0.05). Psychiatric illness and psychological problems: 1) Moderate to severe stress (OR: 2.01; 95%CI: 1.56–2.58; p<0.001), 2) Phobic disorder (Insomnia vs Non insomnia; 20.5% vs 13.6%; p<0.001), 3) Major depression (19.7% vs 7.0%; p<0.001), 4) Anxiety disorder (6.5% vs 13.5%; p<0.001).
| Ethnicity: | All Asian (Chinese and Malays) | Non-significant
| Sample Size: | 2418 | Age: % Insomniacs (15–29 vs 30–49 vs 50+ ) 40.8 vs 46.85 vs 12.4%, p=NS. Psychiatric illness and psychological problems: Source of stress – work and others (financial, travel etc) p=NS
| Response Rate: | NR
Zammit, GK / 1999 | Study Design: | Cross-sectional case-control | [underlined: Associated Factors] :
Moderate (4/9) | Age Group | | Significant
| mean ± SD: | 44.1±14.04 yrs (CS) | Psychiatric illness and psychological problems: 1) Depression (Zung Depression Scale: 2.22 ± 0.03 vs 1.53 ± 0.03; p<0.0001), 2) Anxiety (Zung Anxiety Scale: 1.96 ± 0.02 vs 1.4 ± 0.04; p<0.0001). Quality of life: (CS vs CT): 1) Overall quality of life (SF-36 overall: No scores provided. F-21.73; p<0.001). 2) Quality of life domains (SF-36 subscales: Body pain: 84.46 vs 62.80 (p<0.0001), General health: 84.00 vs 61.05 (p<0.0001), Mental health: 80.27 vs 55.69 (p<0.0001), Role emotional: 85.98 vs 48.82 (p<0.0001), Role physical: 94.48 vs 56.28 (p<0.0001), Social functioning: 88.65 vs 60.59 (p<0.0001), Vitality: 71.65 vs 41.13 (p<0.0001), Physical functioning: 93.31vs 77.82 (p<0.0001), 3) Number of hours watching TV (Quality of Life Inventory: 3.26 ± 0.15 vs 2.46 ± 0.24; p<0.006), 4) Hours reading per day (1.91 ± 0.11 vs 2.36 ± 0.17; p<0.03), 5) Hours of recreation per day (1.54 ± 0.11 vs 2.3 ± 0.18; p<0.0001). Memory and cognitive function: (CS vs CT; mean ± SD): 1) Cognitive functions (Medical Outcomes Study Cognitive scale sum scores; 25.34 ± 0.34 vs 31.91 ± 0.58; p<0.0001). Work variables: (CS vs CT): 1) Levels of optimism regarding career and future employment (Work and Daily Activities Questionnaire: 3.17 ± 0.11 vs 3.90 ± 0.18; p<0.0001). 2) Average # days absent from work / mo. (1.32 ± 0.15 vs 0.13 ± 0.22; p<0.001).
| | 37.1±12.7 yrs (CT) | Non-significant
| Gender | | Memory and cognitive function: (Medical Outcomes Study Cognitive scale) Report no specific area of cognitive function significantly impaired.
| Female: | 157 (CS), 63 (CT)
| Male: | 104 (CS), 38 (CT)
| Ethnicity: | NR
| Sample Size: | 362 total
| | 261 (CS), 101 (CT)
| Response Rate: | NR

[underlined: Abbreviations:] adj = adjusted; BAI = Beck Anxiety Inventory; BDI = Beck Depression Inventory; BMI = body mass index; BNZ = benzodiazepine; ChI = chronic insomnia; CI = confidence interval; Com = community; CS = case; CT = control group; DSM-IV = Diagnostic and Statistical Manual of mental Disorders, 4^th^ edition; GS = good sleepers; Hx = history; INS = drug-free insomnia; INSBZ = benzodiazepine use insomnia; mo = months; msec = mili-seconds; MSK = musculoskeletal; MMPI = Minnesota Multiphasic Personality Inventory; NA = not applicable; NR = not reported; OR = odds ratio; p=NS = not statistically significant; QoL = Quality of Life; TBI = traumatic brain injury; VAS = visual analogue scale; yrs = years

Evidence Table C-2: Efficacy and safety of treatments used in the management of chronic insomnia in adults

AUTHOR / YEAR QUALITY (score) | FUNDING SOURCE | STUDY DESIGN | POPULATION CHARACTERISTICS | | INSOMNIA CHARACTERISTICS | | INTERVENTIONS
Aden, GC | Private (funds and materials) | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam
Moderate (2/5) | | Double-blind | Mean (SD): | 47 (NS) | Co-morbidity: | NA | Dose (mg): | 30
| | Parallel | Range: | 23 – 59 | Duration (years) | | Frequency / Duration: | 1 × night / 5 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 29 / 21 | Range: | NS | Route of Delivery: | NS
Allain, H / 2001 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 45.6 (9.6) - Tr | Co-morbidity: | NA | Dose (mg): | 10
| | Parallel | | 46.7 (11.5) - Pl | Duration (years) | | Frequency / Duration: | nightly × 2 nights, 2 tablets for rest of wk, final 3 wks as few as possible / 4 wks
| | | Range: | 25 – 64 | Mean (SD): | 6.7 (8.0) – Tr | Timing: | bedtime
| | | Gender | | | 6.6 (7.3) – Pl | Route of Delivery: | oral
| | | Female / Male: | 188 / 57 | Range: | NS
Allain, H / 1998 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | triazolam, zolpidem
High (4/5) | | Double-blind | Mean (SD): | 54.3 (11.0) | Co-morbidity: | NA | Dose (mg): | 0.125; 10
| | Parallel | Range: | 32 – 84 | Duration (years) | 19.5% < 1 yr | Frequency / Duration: | 1 × night / 4 nights
| | | Gender | | | 80.5% > 1 yr | Timing: | bedtime
| | | Female / Male: | 67.9% / 32.1% | Mean (SD): | NS | Route of Delivery: | oral
| | | | | Range: | NS
Ascher, LM / 1979 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | paradoxical intention (CBT), Pl, CT
Low (1/5) | | Not reported as double-blind | Mean (SD): | 39 (NS) | Co-morbidity: | NA | Frequency / Duration: | 1 × wk / 4 wks
| | Parallel | Range: | 24 – 67 | Duration (years)
| | | Gender | | Mean (SD): | 8 (NS)
| | | Female / Male: | 15/10 | Range: | NS
Asnis, GM / 1999 | Private | RCT | Age (years) | | Type: | secondary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 41.6 (1.2) Tr | Co-morbidity: | various psychiatric conditions | Dose (mg): | 10
| | Parallel | | 41.6 (1.0) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 4 wks
| | | Range: | 18 – 66 | Mean (SD): | NS | Timing: | bedtime
| | | Gender | | Range: | NS | Route of Delivery: | NS
| | | Female / Male: | 150 / 40
Beary, MD / 1984 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | temazepam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 20
| | Crossover | Range: | 23 – 35 | Duration (years) | | Frequency / Duration: | NS / NS
| | | Gender | | Mean (SD): | NS | Timing: | 2230 hr
| | | Female / Male: | 6 / 0 | Range: | 0.3 – 2 | Route of Delivery: | oral
Botter PA / 1983 | NS | RCT | Age (years) | Part 1: | Type: | secondary | Type/Description: | loprazolam
High (4/5) | | Double-blind | Mean (SD): | 44.3 (8) Tr 1mg | Co-morbidity: | anxiety neuroses | Dose (mg): | 1, 2
| | Parallel | | 40.6 (7.7) Pl | Duration (months) | | Frequency / Duration: | NS / 7 nights
| | | | Part 2: | Mean (SD): | Part 1: | Timing: | 15 min. before bed
| | | | 46.1 (7.2) Tr 2mg | | 1.3 (0.2) Tr 1mg | Route of Delivery: | oral
| | | | 44.8 (7.1) Pl | | 1.3 (0.2) Pl
| | | Range: | NS | | Part 2:
| | | Gender | | | 1.1 (0.2) Tr 2mg
| | | Female / Male: | 25 / 15 | | 1.1 (0.1) Pl
| | | | | Range: | NS
Bowen, AJ / 1978 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | triazolam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 0.5
| | Crossover | Range: | 18 – 60 | Duration (years) | | Frequency / Duration: | NS / 2 nights
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 13/5 | Range: | NS | Route of Delivery: | NS
Brown, CC / 1979 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | l-tryptophan
High (4/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 1, 3
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 6 tablets for each 10 nights / 3 months
| | | Gender | | Mean (SD): | NS | Timing: | 20 min. before bed
| | | Female / Male: | 18 / 0 | Range: | NS | Route of Delivery: | oral
Campbell, RD / 1987 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | flurazepam; zopiclone
High (4/5) | | Double-blind | Mean (SD): | 38 (2) | Co-morbidity: | NA | Dose (mg): | 30; 7.5
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × d / 3 wks each Tr
| | | Gender | | Mean (SD): | NS | Timing: | daily
| | | Female / Male: | 25 / 31 | Range: | NS | Route of Delivery: | oral
Carr-Kaffashan, L / 1979 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | progressive relax-meditation (RT); quasi-desensitization (Pl)
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 40.1 (NS) | Co-morbidity: | NA | Frequency / Duration: | 1 × wk / 4 wks
| | Parallel | Range: | 18 – 76 | Duration (years)
| | | Gender | | Mean (SD): | 11.48 (NS)
| | | Female / Male: | 18/12 | Range: | NS
Chaudoir, PJ / 1983 | Private (pre-packed drugs) | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone
Moderate (3/5) | | Double-blind | Mean (SD): | 50 (NS) | Co-morbidity: | NA | Dose (mg): | 7.5
| | Crossover | Range: | 35 – 65 | Duration: | 6 months – Tr1 | Frequency / Duration: | 1 × night / 7 nights
| | | Gender | | | 9 months – Tr2 | Timing: | NS
| | | Female / Male: | 18/17 | Mean (SD): | NS | Route of Delivery: | oral
| | | | | Range: | NS
Choliz, M / 1995 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | breathing process training (RT); CT
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | NS | Co-morbidity: | NA | Frequency / Duration: | 6 sessions in total / NS
| | Parallel | Range: | NS | Duration (years)
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | NS / NS | Range: | NS
Cohn, JB / 1991 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | estazolam; flurazepam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 1, 2; 30
| | Parallel | Range: | 18 – 65 | Duration: | 3 months or more | Frequency / Duration: | 1 × night / 7 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | NS / NS | Range: | NS | Route of Delivery: | oral
Cohn, JB / 1984 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | triazolam; lorazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 41.4 (10.2) | Co-morbidity: | various medical and psychiatric conditions | Dose (mg): | 0.5; 2
| | Crossover | Range: | 18 – 61 | Duration: | 6 months or more (all but 1 patient) | Frequency / Duration: | NS / 4 d each Tr
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 18/12 | Range: | NS | Route of Delivery: | NS
Cohn, JB / 1983 | NS | RCT | Age (years) | | Type: | secondary | Type/Description: | triazolam
High (4/5) | | Double-blind | Mean (SD): | 41.5 (NS) | Co-morbidity: | depression | Dose (mg): | 0.25
| | Crossover | Range: | 18 – 60 | Duration: | 1 month or more (all but 1 subject) | Frequency / Duration: | 2 × night / 4 night each Tr
| | | Gender | | Mean (SD): | NS | Timing: | nightly
| | | Female / Male: | 38 / 15 | Range: | NS | Route of Delivery: | oral
Coxeter, PD / 2003 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | valerian
High (5/5) | | Double-blind | Mean (SD): | 54 (15) | Co-morbidity: | NA | Dose (mg): | 225
| | Crossover | Range: | 22 – 75 | Duration (years) | | Frequency / Duration: | 2 × night / 3 wks
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 12/10 | Range: | NS | Route of Delivery: | oral
Davies, R / 1986 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | immediate Tr (CBT); delayed Tr (Pl)
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 58.59 (10.98) | Co-morbidity: | NA | Frequency / Duration: | 1 × wk / 4 wks
| | Parallel | Range: | 35 – 78 | Duration (years)
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | 16 / 18 | Range: | NS
Dawson, D / 1998 | Private (supported research) | RCT | Age (years) | | Type: | primary | Type/Description: | melatonin
Moderate (2/5) | | Double-blind | Mean (SD): | 65.67 (1.68) | Co-morbidity: | NA | Dose (mg): | 0.5
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 4 × wk / 1 wk
| | | Gender | | Mean (SD): | NS | Timing: | 1900 hr
| | | Female / Male: | NS / NS | Range: | NS | Route of Delivery: | patch placed on gums
Declerk, A / 1999 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 54 (NS) | Co-morbidity: | NA | Dose (mg): | 10
| | Parallel | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × day / 1 wk
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 17/5 | Range: | NS | Route of Delivery: | oral
Dominguez, RA / 1986 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | estazolam; flurazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 46.6 (NS) | Co-morbidity: | NA | Dose (mg): | 2; 30
| | Parallel | Range: | 21 – 65 | Duration (years) | | Frequency / Duration: | 1 × night / 7 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 46% / 54% | Range: | NS | Route of Delivery: | oral
Dominguez, RA / 1985 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | brotizolam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 0.25 to 0.5
| | Parallel | Range: | 20 – 60 | Duration (years) | | Frequency / Duration: | 1 × night / 21 nights (option to double dose after 1 wk)
| | | Gender | | Mean (SD): | NS | Timing: | bedtime
| | | Female / Male: | NS / NS | Range: | NS | Route of Delivery: | oral
Donath, F / 2000 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | valerian (short- and long-term)
Moderate (2/5) | | Double-blind | Mean (SD): | 49 (NS) | Co-morbidity: | NA | Dose (mg): | NS
| | Crossover | Range: | 22 – 55 | Duration: | 3 months to several yrs | Frequency / Duration: | 2 × night / 15 night
| | | Gender | | Range: | NS | Timing: | 1 hr before bed
| | | Female / Male: | 12/14 | Mean (SD): | NS | Route of Delivery: | oral
Drake, CL / 2000 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zaleplon; triazolam
High (4/5) | | Double-blind | Mean (SD): | 41.6 (9.5) study 1 | Co-morbidity: | NA | Dose (mg): | 10, 40; 0.25 study 1
| | Crossover | | 38.1 (11.1) study 2 | Duration (years) | | | 20, 60; 0.25 study 2
| | | Range: | 21–60 | Mean (SD): | 5.7 (7.2) study 1 | Frequency / Duration: | 1 × night / 2 nights each Tr
| | | Gender | | | 9.9 (9.8) study 2 | Timing: | 30 min. before bed
| | | Female / Male: | 38 / 45 | Range: | NS | Route of Delivery: | oral
Dujardin, K / 1998 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem; flunitrazepam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 10; 1
| | Crossover | Range: | 40 – 62 | Duration (years) | | Frequency / Duration: | 3 Tr sequences 1 wk apart
| | | Gender | | Mean (SD): | NS | Timing: | bedtime
| | | Female / Male: | 0 / 12 | Range: | NS | Route of Delivery: | oral
Edinger, JD / 2003 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | abbreviated CBT; generic sleep hygiene (Pl)
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 51.0 (13.7) | Co-morbidity: | various medical conditions | Frequency / Duration: | 1 × every 2 wks / 4 wks
| | Parallel | Range: | NS | Duration (years)
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | 2/18 | Range: | NS
Edinger, JD / 2001 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | CBT, RT, quasi-desensitization (Pl)
High (4/5) | | Double-blind | Mean (SD): | 55.8 (12.1) CBT | Co-morbidity: | NA | Frequency / Duration: | 1 × wk / 6 wks
| | Parallel | | 54.5 (10.2) RT | Duration (years)
| | | | 55.7 (9.5) Pl | Mean (SD): | 13.6 (NS)
| | | Range: | 40–80 | Range: | NS
| | | Gender
| | | Female / Male: | 35 / 40
Elie, R / 1999 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zaleplon; zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 42.5 - 44.3 | Co-morbidity: | NA | Dose (mg): | 5, 10, 20; 10
| | Parallel | | (12.0 - 12.9) Tr | Duration (years) | | Frequency / Duration: | 1 × night / 4 wks
| | | | 42.1 (12.0) Pl | Mean (SD): | NS | Timing: | before bed
| | | Range: | 18–65 | Range: | NS | Route of Delivery: | oral
| | | Gender
| | | Female / Male: | 370 / 204
Elie, R / 1990 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone, triazolam
Moderate (3/5) | | Double-blind | Mean (SD): | 76 (1.3) | Co-morbidity: | NA | Dose (mg): | 5, 7.5; 0.125, 0.25
| | Parallel | Range: | 60 – 90 | Duration (years) | 7 >= 1 yr | Frequency / Duration: | NS / 3 wks
| | | Gender | | | 17 > 10 yrs | Timing: | 30 min. before bed
| | | Female / Male: | 33 / 11 | Mean (SD): | NS | Route of Delivery: | oral
| | | | | Range: | NS
Ellis, CM / 1996 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | melatonin
High (4/5) | | Double-blind | Mean (SD): | 46 (11) | Co-morbidity: | NA | Dose (mg): | 5
| | Crossover | Range: | 32 – 67 | Duration (years) | | Frequency / Duration: | 1 × day / 7 d
| | | Gender | | Mean (SD): | 21.7 (13) | Timing: | 20.00 hr
| | | Female / Male: | 6/9 | Range: | 1–45 | Route of Delivery: | oral
Espie, CA / 1989 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | progressive relax (RT); stimulus control (CBT); paradoxical intention (CBT); imagery relief (Pl)
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 44.9 (15.3) | Co-morbidity: | NA | Frequency / Duration: | NS / 8 wks
| | Parallel | Range: | NS | Duration (years)
| | | Gender | | Mean (SD): | 12.4 (12.2)
| | | Female / Male: | 47 / 23 | Range: | NS
Farag NH / 2003 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | herbal supplement
High (4/5) | | Double-blind | Mean (SD): | 37 (13) | Co-morbidity: | NA | Dose (mg): | NS
| | Crossover | Range: | 21 – 63 | Duration (years) | | Frequency / Duration: | 2 × night / 4 nights
| | | Gender | | Mean (SD): | NS | Timing: | 1 hr before bed
| | | Female / Male: | 20/5 | Range: | NS | Route of Delivery: | oral
Ferguson, JM / 1991 | NS | RCT | Age (years) | | Type: | secondary | Type/Description: | estazolam
High (4/5) | | Double-blind | Mean (SD): | 43.4 (10.9) | Co-morbidity: | major depression | Dose (mg): | 2
| | Parallel | Range: | 18 – 65 | Duration (years) | | Frequency / Duration: | 1 × night / 7 nights
| | | Gender | | Mean (SD): | NS | Timing: | nightly
| | | Female / Male: | 56% / 44% | Range: | NS | Route of Delivery: | NS
Fillingim, JM / 1982 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | temazepam; flurazepam
High (5/5) | | Double-blind | Mean (SD): | 81 (NS) | Co-morbidity: | NA | Dose (mg): | 30; 30
| | Parallel | Range: | NS | Duration (years) | 1 yr or more | Frequency / Duration: | 1 × night / 4 nights
| | | Gender | | Mean (SD): | NS | Timing: | bedtime
| | | Female / Male: | 89% / 11% | Range: | NS | Route of Delivery: | oral
Fleming, J / 1995 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem; flurazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 33 – 37 (NS) | Co-morbidity: | NA | Dose (mg): | 10, 20; 30
| | Parallel | Range: | 21 – 60 | Duration (years) | | Frequency / Duration: | NS / 3 nights
| | | Gender | | Mean (SD): | 7 – 10 (NS) | Timing: | NS
| | | Female / Male: | 48% / 52% | Range: | NS | Route of Delivery: | NS
Fry, J / 2000 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zaleplon; zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 40 - 43 (10 - 13) Tr | Co-morbidity: | NA | Dose (mg): | 5, 10, 20; 10
| | Parallel | | 43 (12) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 28 nights
| | | Range: | 18 – 65 | Mean (SD): | NS | Timing: | immediately before bed
| | | Gender | | Range: | NS | Route of Delivery: | oral
| | | Female / Male: | 342 / 244
Garfinkel, D / 1997 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | melatonin (controlled-release)
High (4/5) | | Double-blind | Mean (SD): | 79 (5.2) | Co-morbidity: | exhibiting various medical conditions | Dose (mg): | 2
| | Crossover | Range: | 68 – 93 | Duration (years) | | Frequency / Duration: | NS / 3 wks
| | | Gender | | Mean (SD): | NS | Timing: | 2 hr before bed
| | | Female / Male: | 8/13 | Range: | NS | Route of Delivery: | oral
Garfinkel, D / 1995 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | melatonin (controlled-release)
High (4/5) | | Double-blind | Mean (SD): | 76 (8) | Co-morbidity: | NA | Dose (mg): | 2
| | Crossover | Range: | 68 – 93 | Duration (years) | | Frequency / Duration: | 1 × night / 3 wks
| | | Gender | | Mean (SD): | NS | Timing: | 2 hr before bed
| | | Female / Male: | 5/7 | Range: | NS | Route of Delivery: | oral
Gelinas, B / 1985 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone
High (4/5) | | Double-blind | Mean (SD): | 40.9 (2.19) | Co-morbidity: | NA | Dose (mg): | 7.5
| | Crossover | Range: | 18 – 60 | Duration (years) | | Frequency / Duration: | NS / 3 wks
| | | Gender | | Mean (SD): | NS | Timing: | bedtime
| | | Female / Male: | 16/10 | Range: | NS | Route of Delivery: | NS
Goethe, JW / 1982 | Private (provided materials & funding) | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam
Moderate (2/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 15
| | Parallel | Range: | 19 – 60 | Duration: | 6 months or more (all but 3 patients) | Frequency / Duration: | 1 × night / 5 nights
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 50 / 19 | Range: | NS | Route of Delivery: | oral
Goldenberg, F / 1994 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone
High (4/5) | | Double-blind | Mean (SD): | 42.5 (8.6) Tr | Co-morbidity: | NA | Dose (mg): | 7.5
| | Parallel | | 43.3 (9.2) Pl | Duration (months) | 1.6 (0.8) Tr | Frequency / Duration: | 1 × night / 14 nights, then as needed for 4 wks
| | | Range: | 25 – 60 | Mean (SD): | 1.7 (1.1) Pl | Timing: | nightly
| | | Gender | | Range: | NS | Route of Delivery: | oral
| | | Female / Male: | 291 / 167
Haffmans, PMJ | NS | RCT | Age (years) | | Type: | secondary | Type/Description: | trazodone
High (4/5) | | Double-blind | Mean (SD): | 44 (NS) | Co-morbidity: | previous severe major depression | Dose (mg): | 150 – 250
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × night / 7 nights
| | | Gender | | Mean (SD): | NS | Timing: | 2200 hr
| | | Female / Male: | 3/4 | Range: | NS | Route of Delivery: | oral
Haimov, I / 1995 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | melatonin (sustained- and fast-release)
High (4/5) | | Double-blind | Mean (SD): | 73.1 (3.9) independent living | Co-morbidity: | NA | Dose (mg): | 2
| | Crossover | | 81.1 (8.9) | Duration (years) | | Frequency / Duration: | NS / 1 wk fast; 8 wk sustained
| | | | institutionalized | Mean (SD): | NS | Timing: | 2 hr before bed
| | | Range: | NS | Range: | NS | Route of Delivery: | oral
| | | Gender
| | | Female / Male: | 16/10
Hajak, G / 2000 | Private (grant- supported) | RCT | Age (years) | | Type: | primary | Type/Description: | doxepin
Moderate (3/5) | | Double-blind | Mean (SD): | 47.6 (11.3) Tr | Co-morbidity: | NA | Dose (mg): | 25–50
| | Parallel | | 47.4 (16.8) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 4 wks
| | | Range: | NS | Mean (SD): | 11.2 (9.7) | Timing: | 1 hr before bed
| | | Gender | | Range: | NS | Route of Delivery: | oral
| | | Female / Male: | 36 / 11
Hajak, G / 1996 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | doxepin
Moderate (3/5) | | Double-blind | Mean (SD): | 41.3 (9.5) | Co-morbidity: | NA | Dose (mg): | 25
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × first wk (IV); daily for 5 wk (oral) / 5 wks
| | | Gender | | Mean (SD): | 10.7 (7.9) | Timing: | 30 min. before bed (oral)
| | | Female / Male: | 3/7 | Range: | NS | | first hours of sleep (IV)
| | | | | | | Route of Delivery: | IV and oral
Hajak, G / 1994 | NS | RCT | Age (years) | | Type: | primary | Type/Description: Dose: | zopiclone, 7.5 mg
High (5/5) | | Double-blind | Mean (SD): | 51 (11) | Co-morbidity: | NA | | funitrazepam, 1.0 mg
| | Parallel | Range: | NS | Duration (years) | | | triazolam, 0.25 mg
| | | Gender | | Mean (SD): | NS | Frequency / Duration: | 1 × daily / 28 d
| | | Female / Male: | 939 / 566 | Range: | NS | Timing: | before bed
| | | | | | | Route of Delivery: | oral
Hartmann, E / 1983 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | l-tryptophan; secobarbital; flurazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 38 - 46 (NS) | Co-morbidity: | NA | Dose (mg): | 1000; 100; 30
| | Parallel | | 39 (NS) Pl | Duration (years) | | Frequency / Duration: | NS / 7 nights
| | | Range: | 18–71 | Mean (SD): | 13 (NS) | Timing: | 30 min. before bed and 2 hr after eating
| | | Gender | | Range: | NS | Route of Delivery: | NS
| | | Female / Male: | 48 / 48
Harvey, AG / 2003 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | suppression (CBT); non-suppression (CT)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 21.1 (3.7) CBT | Co-morbidity: | various psychiatric conditions (n=13) | Frequency / Duration: | envelop with instructions to follow each morning and evening / NS
| | Parallel | | 18.6 (5.1) CT | Duration (years)
| | | Range: | NS | Mean (SD): | 6.4 (3.9) CBT
| | | Gender | | | 6.2 (5.8) CT
| | | Female / Male: | 15/11 | Range: | NS
Haynes, SN / 1977 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | EMG feedback (RT); relax instructions (RT); control (Pl)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 29.3 (NS) | Co-morbidity: | NA | Frequency / Duration: | 2 × wk / 3 wks
| | Parallel | Range: | NS | Duration (years)
| | | Gender | | Mean (SD): | 7.1 (NS)
| | | Female / Male: | 15/9 | Range: | NS
Haynes, SN / 1974 | Academic | RCT | Age (years) | | Type: | primary | Type/Description: | relax training (RT); Pl
Low (1/5) | | Not reported as double-blind | Mean (SD): | NS | Co-morbidity: | NA | Frequency / Duration: | 2 × wk / 3 wks
| | Parallel | Range: | 18–21 | Duration (years)
| | | Gender | | Mean (SD): | 5.3 (NS)
| | | Female / Male: | 5/9 | Range: | NS
Hedner, J / 2000 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zaleplon
Moderate (3/5) | | Double-blind | Mean (SD): | 72.5 (5.9 – 6.8) Tr | Co-morbidity: | NA | Dose (mg): | 5, 10
| | Parallel | | 72.5 (6.8) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 2 wks
| | | Range: | 59 – 91 Tr | Mean (SD): | NS | Timing: | NS
| | | | 63 – 95 Pl | Range: | NS | Route of Delivery: | oral
| | | Gender
| | | Female / Male: | 285 / 137
Heidrich, H / 1981 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | loremetazepam
High (4/5) | | Double-blind | Mean (SD): | 44.6 (2) Tr | Co-morbidity: | NA | Dose (mg): | 2
| | Parallel | | 46 (2) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 2 wks
| | | Range: | 64 – 21 Tr | Mean (SD): | 2.5 (NS) | Timing: | shortly before bed
| | | | 63 – 28 Pl | Range: | NS | Route of Delivery: | oral
| | | Gender
| | | Female / Male: | 67% / 33%
Hernandez, RL / 1983 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 15
| | Parallel | Range: | 22 – 65 | Duration (years) | | Frequency / Duration: | 1 × night / 5 nights
| | | Gender | | Mean (SD): | NS | Timing: | nightly
| | | Female / Male: | 24/12 | Range: | NS | Route of Delivery: | oral
Herrmann, WM / 1993 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 10
| | Parallel | Range: | 25 – 65 | Duration (years) | | Frequency / Duration: | 1 × night / 2 wks
| | | Gender | | Mean (SD): | NS | Timing: | 15 min. before lights out
| | | Female / Male: | 9/12 | Range: | NS | Route of Delivery: | NS
Hughes, RC / 1978 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | EMG biofeedback (RT); EMG pseudo-biofeedback (Pl); relax training (RT); stimulus control instructions (Pl)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 34.2 (NS) | Co-morbidity: | NA | Frequency / Duration: | EMG: 8 sessions
| | Parallel | Range: | NS | Duration (years) | | | relax: 4 sessions
| | | Gender | | Mean (SD): | NS | | stimulus: 2 sessions
| | | Female / Male: | 24/12 | Range: | NS
Jacobson, AF / 1986 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | brotizolam
Moderate (3/5) | | Double-blind | Mean (SD): | 72 (NS) Tr | Co-morbidity: | NA | Dose (mg): | 0.125
| | Parallel | | 69 (NS) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 4 nights
| | | Range: | 60 – 82 | Mean (SD): | 16 (16.4) Tr | Timing: | 30 min. before bed
| | | Gender | slightly more than half female | | 14.5 (11.9) Pl | Route of Delivery: | oral
| | | Female / Male: | NS / NS | Range: | 1 – 65 Tr
| | | | | | 1 – 40 Pl
James, SP / 1990 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | melatonin
Moderate (2/5) | | Double-blind | Mean (SD): | 33.4 (NS) | Co-morbidity: | NA | Dose (mg): | 1, 5
| | Crossover | Range: | 20 – 57 | Duration: | > 6 months | Frequency / Duration: | NS / 2 wks – 1 for each Tr
| | | Gender | | Mean (SD): | NS | Timing: | 15 min before bed
| | | Female / Male: | 6/4 | Range: | NS | Route of Delivery: | oral
Krystal, AD / 2003 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | eszopiclone
Moderate (3/5) | | Double-blind | Mean (SD): | 44 (11) | Co-morbidity: | NA | Dose (mg): | 3
| | Parallel | Range: | 21 – 69 | Duration (years) | | Frequency / Duration: | 1 × night / 6 months
| | | Gender | | Mean (SD): | NS | Timing: | bedtime
| | | Female / Male: | 498 / 290 | Range: | NS | Route of Delivery: | NS
Lacks, P / 1983 | Private (supported research) | RCT | Age (years) | | Type: | primary | Type/Description: | progressive relax (RT); stimulus control (CBT); paradoxical intention (CBT)
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 40.6 (NS) | Co-morbidity: | NA | Frequency / Duration: | 1 × wk / 4 wks
| | Parallel | Range: | NS | Duration (years)
| | | Gender | | Mean (SD): | 13.8 (NS)
| | | Female / Male: | 48 / 16 | Range: | NS
Lacks, P / 1983 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | stimulus control (CBT); visualization (Pl)
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 43.0 (NS) | Co-morbidity: | NA | Frequency / Duration: | 1 × wk / 4 wks
| | Parallel | Range: | 31 – 59 | Duration (years)
| | | Gender | | Mean (SD): | 11.7 (NS)
| | | Female / Male: | 9/6 | Range: | NS
Lahmeyer, H / 1997 | Private (grant-supported) | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
High (4/5) | | Double-blind | Mean (SD): | 44.9 (NS) | Co-morbidity: | NA | Dose (mg): | 10, 15
| | Parallel | Range: | 19 – 61 | Duration (years) | | Frequency / Duration: | 1 × night / 31 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 81 / 64 | Range: | NS | Route of Delivery: | NS
Lamphere, JK / 1989 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone
Moderate (2/5) | | Double-blind | Mean (SD): | 36 (10) | Co-morbidity: | NA | Dose (mg): | 2.5, 5.0, 7.5, 10, 15
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 3 × wk / 6 wks
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 3/9 | Range: | NS | Route of Delivery: | NS
Leppik, IE / 1997 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem; triazomam; temazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 69 (NS) | Co-morbidity: | NA | Dose (mg): | 5; 0.125; 15
| | Parallel | Range: | 59 – 85 | Duration (years) | | Frequency / Duration: | 1 × night / 4 wks
| | | Gender | | Mean (SD): | NS | Timing: | bedtime
| | | Female / Male: | 63% / 37% | Range: | NS | Route of Delivery: | oral
Lichstein, KL / 2001 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | relax (RT); sleep compression (CBT); quasi-desensitization (Pl)
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 68.03 (7.04) | Co-morbidity: | NA | Frequency / Duration: | 1 × wk / 6 wks
| | Parallel | Range: | 59 – 92 | Duration (years)
| | | Gender | | Mean (SD): | 8.93 (11.54)
| | | Female / Male: | 53 / 21 | Range: | 0.5–51
Mamelak, M / 1989 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | brotizolam; flurazepam
Moderate (2/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | | 0.25; 15
| | Parallel | Range: | 60 – 72 | Duration (years) | | Dose (mg): | NS / 14 nights
| | | Gender | | Mean (SD): | NS | Frequency / Duration: | bedtime
| | | Female / Male: | NS / NS | Range: | NS | Timing: | NS
| | | | | | | Route of Delivery:
Mamelak, M / 1987 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | flurazepam; zopiclone
High (4/5) | | Double-blind | Mean (SD): | 50 (NS) | Co-morbidity: | NA | Dose (mg): | 30; 7.5
| | Parallel | Range: | 32 – 60 | Duration (years) | | Frequency / Duration: | 1 × d / 12 d
| | | Gender | | Mean (SD): | NS | Timing: | 2300 hr
| | | Female / Male: | 21/9 | Range: | NS | Route of Delivery: | oral
McAlpine, CJ / 1984 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | loprazolam; nitrazepam
High (4/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 1.0; 5.0
| | Parallel | Range: | 18 – 94 | Duration (years) | 72 > 1 yr | Frequency / Duration: | NS / 7 nights
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 90 / 57 | Range: | NS | Route of Delivery: | oral
Melo de Paula, A / 1984 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | lormetazepam; flurazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 28 – 31 (NS) | Co-morbidity: | NA | Dose (mg): | 1, 2; 30
| | Parallel | Range: | 19 – 55 | Duration (years) | | Frequency / Duration: | NS / 2 wks
| | | Gender | | Mean (SD): | 1.3 – 2.1 (NS) | Timing: | NS
| | | Female / Male: | 42 / 16 | Range: | 0.2–10 | Route of Delivery: | NS
Mendels, J / 1983 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 47 (NS) Tr | Co-morbidity: | NA | Dose (mg): | 15
| | Parallel | | 45 (NS) Pl | Duration (years) | 36 < 10 yrs | Frequency / Duration: | 1 × night / 5 nights
| | | Range: | 20 – 58 Tr | | 24 > 10 yrs | Timing: | NS
| | | | 22 – 60 Pl | Mean (SD): | NS | Route of Delivery: | oral
| | | Gender | | Range: | NS
| | | Female / Male: | 19 / 41
Milby, JB / 1993 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | triazolam & CBT; triazolam & sleep related info (CT)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 30.4 (5.68) women | Co-morbidity: | NA | Dose (mg): | 0.25
| | Parallel | | 35 (6.13) men | Duration (years) | | Frequency / Duration: | 1 × night / 13 nights
| | | Range: | NS | Mean (SD): | NS | | 2 × wk / 3 wks
| | | Gender | 8/7 | Range: | NS | Timing: | 30 min. before bed
| | | Female / Male: | | | | Route of Delivery: | NS
Minnekeer, RJ / 1988 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam; flunitrazepam
High (4/5) | | Double-blind | Mean (SD): | 53.2 (14.5) Tr (q) | Co-morbidity: | NA | Dose (mg): | 15; 2
| | Parallel | | 55.4 (12.5) Tr (f) | Duration (years) | 30% > 5 yrs Tr (q) | Frequency / Duration: | 1 × night / 4 wks
| | | | 54.9 (13.7) Pl | | 32% > 5 yrs Tr (f) | Timing: | nightly
| | | Range: | NS | | 34% > 5 yrs Pl | Route of Delivery: | oral
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | 130 / 74 | Range: | NS
Mitchell, KR / 1979 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | progressive muscle relax (RT); relax training & cognitive control (RT & CBT); information & environmental change (Pl)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 37.4 (NS) | Co-morbidity: | NA | Frequency / Duration: | 4 / 2 wks (RT)
| | Parallel | Range: | 28 – 51 | Duration (years) | | | 2 / 2 wks (RT & CBT)
| | | Gender | | Mean (SD): | 6.3 (NS) | | 8 / wks (Pl)
| | | Female / Male: | 9/15 | Range: | 2.1 – 8.1
Mitler, MM / 1984 | Private (grant-supported) | RCT | Age (years) | | Type: | primary or secondary | Type/Description: | flurazepam; traizolam
Moderate (3/5) | | Double-blind | Mean (SD): | 37.7 – 45.4 (NS) | Co-morbidity: | personality disorder or sleep-related myoclonus | Dose (mg): | 30; 0.5
| | Parallel | Range: | 27 – 61 | Duration (years) | | Frequency / Duration: | 1 × night / 37 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 17/4 | Range: | NS | Route of Delivery: | oral
Monchesky, TC / 1986 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone
High (4/5) | | Double-blind | Mean (SD): | 47.1 (1.7) Tr | Co-morbidity: | various medical conditions | Dose (mg): | 7.5
| | Crossover | | 46.6 (1.8) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 4 wks
| | | Range: | NS | Mean (SD): | 7.0 (1.2) Tr | Timing: | bedtime
| | | Gender | | | 6.4 (0.8) Pl | Route of Delivery: | oral
| | | Female / Male: | 65 / 26 | Range: | NS
Montes, LGA / 2003 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | melatonin
Moderate (3/5) | | Double-blind | Mean (SD): | 50 (12.7) | Co-morbidity: | NA | Dose (mg): | 0.3, 1.0
| | Crossover | Range: | 30 – 72 | Duration (years) | | Frequency / Duration: | daily / 7d
| | | Gender | | Mean (SD): | 12.8 (12.1) | Timing: | 1 hr before bed
| | | Female / Male: | 4/6 | Range: | 0.5 – 32 | Route of Delivery: | oral
Monti JM / 2000 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 53.8 (1.8) Tr | Co-morbidity: | NA | Dose (mg): | 10
| | Parallel | | 50.0 (5.3) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 15 nights
| | | Range: | 27 – 59 | Mean (SD): | 12.6 (4.9) Tr | Timing: | before turning of light
| | | Gender | | | 17.7 (6.5) Pl | Route of Delivery: | oral
| | | Female / Male: | 12 / 0 | Range: | NS
Monti, JM / 1996 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 41.2 (3.9) Tr | Co-morbidity: | NA | Dose (mg): | 10
| | Parallel | | 47.3 (5.7) Pl | Duration (years) | | Frequency / Duration: | 1 × night / 27 nights
| | | Range: | NS | Mean (SD): | 9.5 (3.5) Tr | Timing: | night
| | | Gender | | | 9.3 (4.7) Pl | Route of Delivery: | oral
| | | Female / Male: | 10/2 | Range: | NS
Morin, CM / 1999 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | temazepam; temazepam & CBT; CBT; Pl
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 65 (7) | Co-morbidity: | NA | Dose (mg): | 7.5 and increasing to 30 based on response
| | Parallel | Range: | 55 or older | Duration (years) | | Frequency / Duration: | 2–3 minimum 7 maximum × wk / - Tr
| | | Gender | | Mean (SD): | 16.8 (16.9) | | 1 × wk / 8 wks - CBT
| | | Female / Male: | 50 / 28 | Range: | NS | Timing: | 1 hr before bed
| | | | | | | Route of Delivery: | oral
Nair, NPV / 1990 | Private (grant-supported) | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone; flurazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 46.9 (1.4) | Co-morbidity: | NA | Dose (mg): | 3.75, 7.5, 11.25, 15; 30
| | Parallel | Range: | 18 – 65 | Duration (years) | | Frequency / Duration: | 1 × d / 7 d
| | | Gender | | Mean (SD): | 9.8 (1.2) | Timing: | 30 min. before bed
| | | Female / Male: | 28 / 32 | Range: | NS | Route of Delivery: | oral
Negri, L / 1997 | NS | RCT | Age (years) | | Type: | secondary | Type/Description: | pivagabine
Moderate (2/5) | | Double-blind | Mean (SD): | 42.95 (13.22) | Co-morbidity: | anxiety alone + mild depressive symptoms | Dose (mg): | 900
| | Parallel | Range: | 15 – 68 | Duration (years) | | Frequency / Duration: | 1 × d / 30 d
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 70 / 30 | Range: | NS | Route of Delivery: | NS
Nicassio, P / 1974 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | autogenic training (RT); progressive relax (RT); self-relax (Pl)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 45.1 (14.57) | Co-morbidity: | NA | Frequency / Duration: | 1 × wk with 1 post-Tr session / 4 wks
| | Parallel | Range: | 22 – 71 | Duration (years)
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | 21/9 | Range: | NS
Pasche, E / 1996 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | low energy emission therapy
Low (1/5) | | Not reported as double-blind | Mean (SD): | 39.0 (0.7) | Co-morbidity: | NA | Frequency / Duration: | 3 × wk / 4 wks
| | Parallel | Range: | 21 – 55 | Duration (years)
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | 59 / 47 | Range: | NS
Perlis, ML / 2004 | Private (primary investigator- initiated project) | RCT | Age (years) | | Type: | primary | Type/Description: | CBT; modafinil & CBT; modafinil & contact control (CT)
Moderate (3/5) | | Not reported as double-blind | Mean (SD): | 41.3 (13.4) | Co-morbidity: | NA | Dose (mg): | 100
| | Parallel | Range: | 25 – 60 | Duration (years) | | Frequency / Duration: | 1 × wk / 8 wks (CBT)
| | | Gender | | Mean (SD): | NS | | 1 × d / 4 wks (Tr)
| | | Female / Male: | 70.4% / 29.6% | Range: | NS | Timing: | every morning
| | | | | | | Route of Delivery: | oral
Poyares, DR / 2002 | Academic | RCT | Age (years) | | Type: | primary | Type/Description: | valmane
Moderate (3/5) | | Double-blind | Mean (SD): | 43.3 (10.6) | Co-morbidity: | NA | Dose (mg): | 100
| | Parallel | Range: | NS | Duration (years) | | Frequency / Duration: | 3 × daily / 15 d
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 15/4 | Range: | NS | Route of Delivery: | NS
Reeves, RL / 1977 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | triazolam; flurazepam
High (4/5) | | Double-blind | Mean (SD): | 68.6 (NS) Tr (t) | Co-morbidity: | NA | Dose (mg): | 0.25; 15
| | Parallel | Range: | 69.6 (NS) Tr (f) | Duration (years) | | Frequency / Duration: | 1 × night / 28 nights
| | | | 70.4 (NS) Pl | Mean (SD): | NS | Timing: | bedtime
| | | | NS | Range: | NS | Route of Delivery: | oral
| | | Gender
| | | Female / Male: | 27 / 14
Rickles, K / 1986 | Private (grant-supported) | RCT | Age (years) | | Type: | primary | Type/Description: | brotizolam
High (4/5) | | Double-blind | Mean (SD): | 46 (12) | Co-morbidity: | NA | Dose (mg): | 0.5
| | Parallel | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × night in wk 1 option of 2 × night in final 2 wks / 3 wks
| | | Gender | | Mean (SD): | 8.6 (9.2) | Timing: | 30 min. before bed
| | | Female / Male: | 63% / 37% | Range: | NS | Route of Delivery: | oral
Riemann, D / 2002 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | lormetazepam; trimipramine
Moderate (3/5) | | Double-blind | Mean (SD): | 45.3 (10.3) Tr (l) | Co-morbidity: | NA | Dose (mg): | 1; 25–200
| | Unclear | | 47.0 (10.8) Tr (t) | Duration (years) | | Frequency / Duration: | NS / 28 d
| | | | 48.8 (11.6) Pl | Mean (SD): | NS | Timing: | NS
| | | Range: | NS | Range: | NS | Route of Delivery: | oral
| | | Gender
| | | Female / Male: | 23 / 32
Rodenbeck, A | NS | RCT | Age (years) | | Type: | primary | Type/Description: | doxepin
Moderate (3/5) | | Double-blind | Mean (SD): | 41.3 (9.5) | Co-morbidity: | NA | Dose (mg): | 25
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × night / 1 night
| | | Gender | | Mean (SD): | 10.7 (7.9) | Timing: | 30 min. before bed
| | | Female / Male: | 3/7 | Range: | NS | Route of Delivery: | acute IV
Roehrs, T / 1999 | Unclear | RCT | Age (years) | | Type: | primary | Type/Description: | ethanol (alcohol)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 34.1 (8.8) | Co-morbidity: | NA | Dose: | 0.5 g / kg
| | Crossover | Range: | 21 – 55 | Duration (years) | | Frequency / Duration: | random 4 nights, choice other 3 nights / 1 wk
| | | Gender | | Mean (SD): | NS | Timing: | 1 hr before bed
| | | Female / Male: | 5/6 | Range: | NS | Route of Delivery: | drink
Roehrs, T / 1983 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | brotizolam
Moderate (3/5) | | Double-blind | Mean (SD): | 33.3 (8.0) | Co-morbidity: | NA | Dose (mg): | 0.25, 0.5
| | Crossover | Range: | NS | Duration: | > 6 months | Frequency / Duration: | 3 × wk / 1 wk each dose
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 8/4 | Range: | NS | Route of Delivery: | oral
Roth, TG / 1997 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam
Moderate (2/5 | | Double-blind | Mean (SD): | 65.9 (4.6) | Co-morbidity: | NA | Dose (mg): | 7.5, 15
| | Parallel | Range: | NS | Duration: | > 3 months | Frequency / Duration: | 1 × night / 7 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 15 / 15 | Range: | NS | Route of Delivery: | NS
Roth, T / 1979 | Private (provided drugs and funding) | RCT | Age (years) | | Type: | unclear | Type/Description: | quazepam
High (4/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | unclear | Dose (mg): | 25
| | Crossover | Range: | 18 – 65 | Duration (years) | | Frequency / Duration: | NS / 1 night
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 0 / 16 | Range: | NS | Route of Delivery: | oral
Saletu-Zyhlarz, G / 2003 | Private (funded pharmacological part of study) | RCT | Age (years) | | Type: | primary | Type/Description: | climodien; estradiol valerate
Moderate (2/5) | | Double-blind | Mean (SD): | 58 (5) | Co-morbidity: | related to postmenopausal syndrome | Dose (mg): | 3; 2
| | Parallel | Range: | 46 – 67 | Duration (years) | | Frequency / Duration: | NS / 2 months
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 49 / 0 | Range: | NS | Route of Delivery: | NS
Sanavio, E / 1990 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | EMG biofeedback (RT); cognitive therapy (CBT); stimulus control & relax (RT & CBT); waiting-list control (Pl)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 39.6 (NS) | Co-morbidity: | NA | Frequency / Duration: | 3 × wk / 2 wks
| | Parallel | Range: | 25 – 50 | Duration (years)
| | | Gender | | Mean (SD): | 11.8 (NS)
| | | Female / Male: | 24 / 16 | Range: | 5–25
Sastre-y-Hernandez, M / 1988 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | lormetazepam
High (4/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 1
| | Crossover | Range: | 20 – 76 | Duration: | 53% > 1 yr | Frequency / Duration: | NS / 1 wk
| | | Gender | | | 20% 3–12 months | Timing: | NS
| | | Female / Male: | 36 / 24 | | 27% < 3 months | Route of Delivery: | sublingual and oral
| | | | | Mean (SD): | NS
| | | | | Range: | NS
Scharf, MB / 1994 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 38 (NS) | Co-morbidity: | NA | Dose (mg): | 10, 15
| | Parallel | Range: | 22 – 60 | Duration (years) | | Frequency / Duration: | NS / 5 wks
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 48 / 27 | Range: | NS | Route of Delivery: | oral
Scharf, MB / 1990 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | estazolam; flurazepam
High (4/5) | | Double-blind | Mean (SD): | 40.4 (13.5) Tr (e) | Co-morbidity: | NA | Dose (mg): | 2; 30
| | Parallel | Range: | 42.8 (13.9) Tr (f) | Duration (years) | | Frequency / Duration: | 1 × night / 7 nights
| | | | 41.3 (13.0) Pl | Mean (SD): | NS | Timing: | 30 min. before bedtime
| | | | 21–65 | Range: | NS | Route of Delivery: | oral
| | | Gender
| | | Female / Male: | NS / NS
Shaw, SH / 1992 | NS | RCT | Age (years) | | Type: | secondary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 74.9 (1.0) Tr 10mg | Co-morbidity: | various psychiatric conditions | Dose (mg): | 10, 20
| | Parallel | | 72.9 (1.0) Tr 20mg | Duration (months) | | Frequency / Duration: | 1 × night / 21 days
| | | | 75.7 (0.8) Pl | Mean (SD): | 23 (4) Tr 10mg | Timing: | 30 min. before bed
| | | Range: | 65–85 | | 2.9 (4.6) Tr 20mg | Route of Delivery: | oral
| | | Gender | | | 2.6 (4.9) Pl
| | | Female / Male: | 81 / 38 | Range: | NS
Shealy, RC / 1979 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | group relax & stimulus control (RT & CBT); group relax (RT); group placebo (Pl)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 19.8 (NS) | Co-morbidity: | NA | Frequency / Duration: | 2 × wk / 3 wks
| | Parallel | Range: | 17 – 30 | Duration (years)
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | 70 / 0 | Range: | NS
Stanton, HE / 1989 | NS | RCT | Age (years) | | Type: | unclear | Type/Description: | hypnotic relax (RT); stimulus control (CBT); desensitization (Pl)
Low (1/5) | | Not reported as double-blind | Mean (SD): | NS | Co-morbidity: | NS | Frequency / Duration: | 1 × wk / 4 wks
| | Parallel (with option to crossover after Tr) | Range: | 23 – 67 | Duration (years)
| | | Gender | | Mean (SD): | NS
| | | Female / Male: | 26 / 19 | Range: | NS
Steens, RD / 1993 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem; triazolam
Moderate (3/5) | | Double-blind | Mean (SD): | 58.2 (5.5) | Co-morbidity: | mild to moderate chronic obstructive pulmonary disease | Dose (mg): | 5, 10; 0.25
| | Crossover | Range: | 35 – 69 | Duration (years) | | Frequency / Duration: | 4 Tr sequences
| | | Gender | | Mean (SD): | 7.8 (6.9) | Timing: | bedtime
| | | Female / Male: | 9/15 | Range: | 1–25 | Route of Delivery: | oral
Stip, E / 1999 | NS | RCT | Age (years) | | Type: | primary or secondary | Type/Description: | zopiclone; temazepam
High (4/5) | | Double-blind | Mean (SD): | 42.6 (1.6) | Co-morbidity: | mild non-psychotic disorders | Dose (mg): | 7.5; 30
| | Parallel | Range: | 20 – 64 | Duration (years) | | Frequency / Duration: | NS / 3 wks
| | | Gender | | Mean (SD): | 10.1 (NS) Tr (z) | Timing: | NS
| | | Female / Male: | 21 / 29 | | 9.7 (NS) Tr (t) | Route of Delivery: | oral
| | | | | | 12.4 (NS) Pl
| | | | | Range: | NS
Tietz, EI / 1981 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam
Moderate (3/5) | | Double-blind | Mean (SD): | 41.2 (16.8) | Co-morbidity: | NA | Dose (mg): | 7.5, 15, 30, 45
| | Crossover | Range: | 18 – 60 | Duration (years) | | Frequency / Duration: | 1 × night / 5 non consecutive wks
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 0 / 15 | Range: | NS | Route of Delivery: | oral
Tuk, B / 1997 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | temazepam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 20
| | Crossover | Range: | 18 – 78 | Duration (years) | | Frequency / Duration: | 2 occasions
| | | Gender | | Mean (SD): | NS | Timing: | just before usual bed
| | | Female / Male: | 15/6 | Range: | NS | Route of Delivery: | oral
Vallieres, A / 2004 | GOV | RCT | Age (years) | | Type: | primary | Type/Description: | zopiclone; CBT; zopiclone & CBT
Moderate (2/5) | | Not reported as double-blind | Mean (SD): | 47.5 (7.92) | Co-morbidity: | NA | Dose (mg): | 3.75 – 7.5
| | Parallel | Range: | 34 – 50 | Duration (years) | | Frequency / Duration: | NS / 5 wks
| | | Gender | | Mean (SD): | 15.5 (9.2) | | 1 × wk / 5 wks – CBT
| | | Female / Male: | 3/3 | Range: | NS | Timing: | 30 min. before bed
| | | | | | | Route of Delivery: | NS
Viukari, M / 1983 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | flunitrazepam; nitrazepam
High (4/5) | | Double-blind | Mean (SD): | 73.2 (2.9) group A | Co-morbidity: | various medical and psychiatric conditions | Dose (mg): | 1; 5
| | Crossover | | 75.1 (1.5) group B | Duration (years) | | Frequency / Duration: | 1 × night / 2 wks
| | | Range: | NS | Mean (SD): | NS | Timing: | 7:30 PM
| | | Gender | | Range: | NS | Route of Delivery: | oral
| | | Female / Male: | 20 / 17
Walsh, JK / 2002 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
Moderate (3/5) | | Double-blind | Mean (SD): | 43.2 (1.2) Tr | Co-morbidity: | NA | Dose (mg): | 10
| | Parallel | | 45.0 (1.3) Pl | Duration (years) | | Frequency / Duration: | as needed between 3–5 per wk / 4 wks
| | | Range: | NS | Mean (SD): | NS | Timing: | nights
| | | Gender | | Range: | NS | Route of Delivery: | oral
| | | Female / Male: | 115 / 48
Walsh, JK / 2000 | Private (data analysis) | RCT | Age (years) | | Type: | primary | Type/Description: | zaleplon
Moderate (3/5) | | Double-blind | Mean (SD): | 67.5 (NS) | Co-morbidity: | NA | Dose (mg): | 2, 5, 10
| | Crossover | Range: | 60 – 79 | Duration (years) | | Frequency / Duration: | nightly / 2 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before lights out
| | | Female / Male: | 17 / 31 | Range: | NS | Route of Delivery: | oral
Walsh, JK / 2000 | Private (research design, selection of investigators, data analysis) | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem
High (4/5) | | Double-blind | Mean (SD): | 43.2 (1.2) Tr | Co-morbidity: | NA | Dose (mg): | 10
| | Parallel | | 45.0 (1.3) Pl | Duration (years) | | Frequency / Duration: | 10 capsules for each 2 wk period / 8 wks
| | | Range: | 21 – 65 | Mean (SD): | NS | Timing: | bedtime
| | | Gender | | Range: | NS | Route of Delivery: | oral
| | | Female / Male: | 115 / 48
Walsh, JK / 1998 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zaleplon; triazolam
High (4/5) | | Double-blind | Mean (SD): | 38.9 – 39.6 | Co-morbidity: | NA | Dose (mg): | 5, 10; 0.25
| | Parallel | | (10 – 11.7) Tr | Duration (years) | | Frequency / Duration: | 1 × night / 14 nights
| | | | 43.1 (9.0) Pl | Mean (SD): | 7.4 – 11.8 | Timing: | 30 min. before bed
| | | Range: | 18 – 60 | | (6.3 – 10.2) Tr | Route of Delivery: | NS
| | | Gender | | | 7.4 (7.3) Pl
| | | Female / Male: | 77 / 55 | Range: | NS
Walsh, JK / 1998 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | zolpidem; trazodone
Moderate (3/5) | | Double-blind | Mean (SD): | 42 (NS) | Co-morbidity: | NA | Dose (mg): | 10; 50
| | Parallel | Range: | 21 – 65 | Duration (years) | | Frequency / Duration: | 1 × night / 14 nights
| | | Gender | | Mean (SD): | NS | Timing: | before bed
| | | Female / Male: | 193 / 85 | Range: | NS | Route of Delivery: | oral
Walsh, JK / 1984 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | estazolam
Moderate (3/5) | | Double-blind | Mean (SD): | 41.1 (NS) | Co-morbidity: | NA | Dose (mg): | 1, 2
| | Parallel | Range: | 19 – 65 | Duration (years) | | Frequency / Duration: | 1 × night / 7 nights
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before bed
| | | Female / Male: | 52% / 48% | Range: | NS | Route of Delivery: | oral
Wang, RIH / 1977 | NS | RCT | Age (years) | | Type: | primary | Type/Description: | penobarbitol; methyprylon; glutethimide
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 100; 300; 500
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × every second night / over 5 nights
| | | Gender | | Mean (SD): | NS | Timing: | 09:45 h
| | | Female / Male: | NS / NS | Range: | NS | Route of Delivery: | oral
Waters, WF / 2003 | Foundation | RCT | Age (years) | | Type: | primary | Type/Description: | flurazepam; sleep restriction & stimulus control (CBT); sleep hygiene (non-drug Pl); sleep restrict & stimulus control & sleep hygiene (RT & CBT); aggressive muscle relax & cognitive distraction (RT & CBT)
Low (1/5) | | Not reported as double-blind | Mean (SD): | 44.1 (NS) | Co-morbidity: | NA | Dose (mg): | 15
| | Parallel | Range: | 18 – 59 | Duration (years) | | Frequency / Duration: | NS / 2 wks
| | | Gender | | Mean (SD): | NS | Timing: | bedtime
| | | Female / Male: | 37 / 16 | Range: | NS | Route of Delivery: | NS
Winsauer, HJ / 1984 | Private | RCT | Age (years) | | Type: | primary | Type/Description: | quazepam
Moderate (3/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 15
| | Parallel | Range: | 60 – 90 | Duration (years) | | Frequency / Duration: | NS / 5 nights
| | | Gender | | Mean (SD): | NS | Timing: | NS
| | | Female / Male: | 39 / 21 | Range: | NS | Route of Delivery: | NS
Zhdanova, IV / 2001 | GOV | RCT | Age (years) | over 50 yrs | Type: | primary | Type/Description: | melatonin
Moderate (2/5) | | Double-blind | Mean (SD): | NS | Co-morbidity: | NA | Dose (mg): | 0.1, 0.3, 3.0
| | Crossover | Range: | NS | Duration (years) | | Frequency / Duration: | 1 × night / 4 wks
| | | Gender | | Mean (SD): | NS | Timing: | 30 min. before fixed bedtime
| | | Female / Male: | NS / NS | Range: | NS | Route of Delivery: | oral

[underlined: Abbreviations] : CBT = cognitive behavioural therapy; CT = control; d = day; f = flunitrazepam; GOV = government; hr = hour; min. = minute; mg = milligrams; NA = not applicable; NS = not specified; Pl = placebo; q = quazepam; RCT = randomized controlled trial; RT = relaxation therapy; SD = standard deviation; Tr = treatment (drug): wk = week: wks = weeks; yr(s) = year(s).

## Evidence Table C-1: References

1 Ancoli-Israel S, Roth T. Characteristics of insomnia in the United States: results of the 1991 National Sleep Foundation Survey. Sleep. 1999;22(Suppl 2):S347-53. [pmid: 10394606].
2 Bastien CH, Fortier-Brochu E, Rioux I, et al. Cognitive performance and sleep quality in the elderly suffering from chronic insomnia. Relationship between objective and subjective measures. [erratum appears in J Psychosom Res. 2003 Nov;55(5):475]. J Psychosom Res. 2003;54(1):39-49. [pmid: 12505554].
3 Bixler EO, Kales A, Soldatos CR, et al. Prevalence of sleep disorders in the Los Angeles metropolitan area. Am J Psychiatry. 1979;136(10):1257-62. [pmid: 314756].
4 Bixler EO, Vgontzas AN, Lin HM, et al. Insomnia in Central Pennsylvania. J Psychosom Res. 2002;53(1):589-92. [pmid: 12127176].
5 Bliwise NG. Factors related to sleep quality in healthy elderly women. Psychol Aging. 1992;7(1):83-8. [pmid: 1558709].
6 Bonnet MH, Arand DL. 24-Hour metabolic rate in insomniacs and matched normal sleepers. Sleep. 1995;18(7):581-8. [pmid: 8552929].
7 Braga-Neto P, Da Silva FP, Monte FS, et al. Snoring and excessive daytime sleepiness in Parkinson's Disease. J Neurol Sci. 2004;217(1):41-5. [pmid: 14675608].
8 Broman JE, Lundh LG, Aleman K, et al. Subjective and objective performance in patients with persistent insomnia. Scand J Behav Ther. 1992;21(3):115-26.
9 Broman JE, Lundh LG, Hetta J. Insufficient sleep in the general population. Neurophysiol Clin. 1996;26(1):30-9. [pmid: 8657096].
10 Chambers MJ, Kim JY. The role of state-trait anxiety in insomnia and daytime restedness. Behav Med. 1993;19(1):42-6. [pmid: 8219529].
11 Coursey RD, Buchsbaum M, Frankel BL. Personality measures and evoked responses in chronic insomniacs. J Abnorm Psychol. 1975;84(3):239-49. [pmid: 1133252].
12 Crenshaw MC, Edinger JD. Slow-wave sleep and waking cognitive performance among older adults with and without insomnia complaints. Physiol Behav. 1999;66(3):485-92. [pmid: 10357438].
13 Dorsey CM, Bootzin RR. Subjective and psychophysiologic insomnia: an exmaination of sleep tendency and personality. Biol Psychiatry. 1997;41(2):209-16. [pmid: 9018392].
14 Edinger JD, Glenn DM, Bastian LA, et al. Slow-wave sleep and waking cognitive performance II: findings among middle-aged adults with and without insomnia complaints. Physiol Behav. 2000;70(12):127-34. [pmid: 10978487].
15 Edinger JD, Fins AI, Glenn DM, et al. Insomnia and the eye of the beholder: are there clinical markers of objective sleep disturbances among adults with and without insomnia complaints?. J Consult Clin Psychol. 2000;68(4):586-93. [pmid: 10965634].
16 Fichtenberg NL, Zafonte RD. Putnam S et al. Insomnia in a post-acute brain injury sample. Brain Inj. 2002;16(3):197-206. [pmid: 11874613].
17 Hajak G. SINE Study Group, Study of Insomnia in Europe. Epidemiology of severe insomnia and its consequences in Germany. Eur Arch Psychiatry Clin Neurosci. 2001;251(2):49-56. [pmid: 11407438].
18 Han SY, Yoon JW, Jo SK, et al. Insomnia in diabetic hemodialysis patients: Prevalence and risk factors by a multicenter study. Nephron. 2002;92(1):127-32. [pmid: 12187095].
19 Harvey AG, Greenall E. Catastrophic worry in primary insomnia. J Behav Ther Exp Psychiatry. 2003;34(1):11-23. [pmid: 12763390].
20 Hauri PJ. Cognitive deficits in insomnia patients. Acta Neurol Belg. 1997;97(2):113-7. [pmid: 9246379].
21 Healey ES, Kales A, Monroe LJ, et al. Onset of insomnia: role of life-stress events. Psychosom Med. 1981;43(5):439-51. [pmid: 7313035].
22 Hetta J, Broman JE, Mallon L. Evaluation of severe insomnia in the general population--implications for the management of insomnia: insomnia, quality of life and healthcare consumption in Sweden. J Psychopharmacol. 1999;13(4 Suppl 1):S35-6. [pmid: 10667458].
23 Hidalgo MP, Caumo W. Sleep disturbances associated with minor psychiatric disorders in medical students. Neurol Sci. 2002;23(1):35-9. [pmid: 12111619].
24 Hohagen F, Kappler C, Schramm E, et al. Sleep onset insomnia, sleep maintaining insomnia and insomnia with early morning awakening--temporal stability of subtypes in a longitudinal study on general practice attenders. Sleep. 1994;17(6):551-4. [pmid: 7809569].
25 Hohagen F, Kappler C, Schramm E, et al. Prevalence of insomnia in elderly general practice attenders and the current treatment modalities. Acta Psychiatr Scand. 1994;90(2):102-8. [pmid: 7976454].
26 Hohagen F, Rink K, Kaeppler C, et al. Prevalence and treatment of insomnia in general practice: A longitudinal study. Eur Arch Psychiatry Clin Neurosci. 1993;242(6):329-36. [pmid: 8323982].
27 Ishigooka J, Suzuki M, Isawa S, et al. Epidemiological study on sleep habits and insomnia of new outpatients visiting general hospitals in Japan. Psychiatry Clin Neurosci. 1999;53(4):515-22. [pmid: 10498235].
28 Kageyama T, Kabuto M, Nitta H, et al. A population study on risk factors for insomnia among adult Japanese women: a possible effect of road traffic volume. Sleep. 1997;20(11):963-71. [pmid: 9456461].
29 Kageyama T, Nishikido N, Kobayashi T, et al. Cross-sectional survey on risk factors for insomnia in Japanese female hospital nurses working rapidly rotating shift systems. J Hum Ergol. 2001;30(12):149-54.
30 Kales A, Caldwell AB, Soldatos CR, et al. Biopsychobehavioral correlates of insomnia. II. Pattern specificity and consistency with the Minnesota Multiphasic Personality Inventory. Psychosom Med. 1983;45(4):341-56. [pmid: 6622623].
31 Kales A, Bixler EO, Soldatos CR. et al. Biopsychobehavioral correlates of insomnia: I. Role of sleep apnea and nocturnal myoclonus. Psychosomat J Consult Liais Psychiatry. 1982;23(6):589-600.
32 Kales JD, Kales A, Bixler EO, et al. Biopsychobehavioral correlates of insomnia, V: Clinical characteristics and behavioral correlates. Am J Psychiatry. 1984;141(11):1371-6. [pmid: 6496780].
33 Kappler C, Hohagen F. Psychosocial aspects of insomnia: Results of a study in general practice. Eur Arch Psychiatry Clin Neurosci. 2003;253(1):49-52. [pmid: 12664315].
34 Kawada T, Yosiaki S, Yasuo K, et al. Population study on the prevalence of insomnia and insomnia-related factors among Japanese women. Sleep Med. 2003;4(6):563-7. [pmid: 14607351].
35 Leger D, Guilleminault C, Dreyfus JP, et al. Prevalence of insomnia in a survey of 12,778 adults in France. J Sleep Res. 2000;9(1):35-42. [pmid: 10733687].
36 Leppavuori A, Pohjasvaara T, Vataja R, et al. Insomnia in ischemic stroke patients. Cerebrovasc Dis. 2002;14(2):90-7. [pmid: 12187012].
37 Levitt H, Wood A, Moul DE, et al. A pilot study of subjective daytime alertness and mood in primary insomnia participants using ecological momentary assessment. [References]. Behav Sleep Med. 2004;2(2):113-31. [pmid: 15600228].
38 Lichstein KL, Durrence HH, Bayen UJ, et al. Primary versus secondary insomnia in older adults: subjective sleep and daytime functioning. Psychol Aging. 2001;16(2):264-71. [pmid: 11405314].
39 Linzmayer L, Arnold O, Saletu-Zyhlarz GM, et al. Daytime noopsychic and thymopsychic dysfunctions in nonorganic insomnia related to different mental disorders. Somnologie. 2002;6(4):141-8.
40 Lopes Rocha F, Guerra HL, Lima-Costa MFF. Prevalence of insomnia and associated socio-demographic factors in a Brazilian community: The Bambui study. Sleep Med. 2002;3(2):121-6. [pmid: 14592230].
41 Lundh L-G, Froeding A, Gyllenhammar L, et al. Cognitive bias and memory performance in patients with persistent insomnia. Scand J Behav Ther. 1997;26(1):27-35.
42 Martikainen K, Partinen M, Hasan J, et al. The impact of somatic health problems on insomnia in middle age. Sleep Med. 2003;4(3):201-6. [pmid: 14592322].
43 Mendelson WB, Garnett D, Gillin JC, et al. The experience of insomnia and daytime and nighttime functioning. Psychiatry Res. 1984;12(3):235-50. [pmid: 6593755].
44 Millar A, Espie CA, Scott J. The sleep of remitted bipolar outpatients: a controlled naturalistic study using actigraphy. J Affect Disord. 2004;80(23):145-53. [pmid: 15207927].
45 Niemcewicz S, Szelenberger W. Psychophysiological correlates of primary insomnia. Arch Hellenic Med. 2001;18(1):64-8.
46 Ohayon MM. Prevalence of DSM-IV diagnostic criteria of insomnia: distinguishing insomnia related to mental disorders from sleep disorders. J Psychiatr Res. 1997;31(3):333-46. [pmid: 9306291].
47 Ohayon MM, Hong SC. Prevalence of insomnia and associated factors in South Korea. J Psychosom Res. 2002;53(1):593-600. [pmid: 12127177].
48 Ohayon MM, Partinen M. Insomnia and global sleep dissatisfaction in Finland. J Sleep Res. 2002;11(4):339-36. [pmid: 12464102].
49 Ohayon MM, Roberts RE. Comparability of sleep disorders diagnoses using DSM-IV and ICSD classifications with adolescents. Sleep. 2001;24(8):920-5. [pmid: 11766162].
50 Ohayon MM, Roberts RE, Zulley J, et al. Prevalence and patterns of problematic sleep among older adolescents. J Am Acad Child Adolesc Psychiatry. 2000;39(12):1549-56. [pmid: 11128333].
51 Ohayon MM, Roth T. Place of chronic insomnia in the course of depressive and anxiety disorders. J Psychiatric Res. 2003;37(1):9-15.
52 Ohayon MM, Roth T. What are the contributing factors for insomnia in the general population?. J Psychosom Res. 2001;51(6):745-55. [pmid: 11750297].
53 Ohayon MM, Smirne S. Prevalence and consequences of insomnia disorders in the general population of Italy. Sleep Med. 2002;3(2):115-20. [pmid: 14592229].
54 Ohayon MM, Zulley J, Guilleminault C, et al. How age and daytime activities are related to insomnia in the general population: consequences for older people. J Am Geriatr Soc. 2001;49(4):360-6. [pmid: 11347777].
55 Ohayon MM, Caulet M, Arbus L, et al. Are prescribed medications effective in the treatment of insomnia complaints?. J Psychosom Res. 1999;47(4):359-68. [pmid: 10616230].
56 Pallesen S, Nordhus IH, Kvale G, et al. Psychological characteristics of elderly insomniacs. Scand J Psychol. 2002;43(5):425-32. [pmid: 12500782].
57 Pavlova M, Berg O, Gleason R, et al. Self-reported hyperarousal traits among insomnia patients. J Psychosom Res. 2001;51(2):435-41. [pmid: 11516766].
58 Perlis ML, Smith MT, Orff HJ, et al. The mesograde amnesia of sleep may be attenuated in subjects with primary insomnia. Physiol Behav. 2001;74(12):71-6. [pmid: 11564454].
59 Riedel BW, Durrence H, Lichstein KL, et al. The relation between smoking and sleep: the influence of smoking level, health, and psychological variables. [References]. Behav Sleep Med. 2004;2(1):63-78. [pmid: 15600225].
60 Robbins L. Anxiety, depression, and insomnia in migraine: A retrospective review of 494 patients. Headache Q. 1995;6(4):303-5.
61 Rocha FL, Uchoa E, Guerra HL, et al. Prevalence of sleep complaints and associated factors in community-dwelling order people in Brazil: The Bambui health and ageing study (BHAS). Sleep Med. 2002;3(3):231-8. [pmid: 14592212].
62 Roth T, Ancoli-Israel S. Daytime consequences and correlates of insomnia in the United States: Results of the 1991 National Sleep Foundation Survey. II. Sleep. 1999;22(Suppl 2):S354-8. [pmid: 10394607].
63 Sabbatini M, Minale B, Crispo A, et al. Insomnia in maintenance haemodialysis patients. Nephrol Dial Transplant. 2002;17(5):852-6. [pmid: 11981073].
64 Saletu-Zhylarz G, Saletu B, Anderer P, et al. Nonorganic insomnia in generalized anxiety disorder. Neuropsychobiol. 1997;36(3):117-29.
65 Savard J, Simard S, Blanchet J, et al. Prevalence, clinical characteristics, and risk factors for insomnia in the context of breast cancer. Sleep. 2001;24(5):583-90. [pmid: 11480655].
66 Schneider-Helmert D. Twenty-four-hour sleep-wake function and personality patterns in chronic insomniacs and healthy controls. Sleep. 1987;10(5):452-62. [pmid: 3685753].
67 Seidel WF, Ball S, Cohen S, et al. Daytime alertness in relation to mood, performance, and nocturnal sleep in chronic insomniacs and noncomplaining sleepers. Sleep. 1984;7(3):230-8. [pmid: 6484427].
68 Sharpley AL, Attenburrow ME, Cowen PJ. Assessment and treatment of insomnia (including a case control study of patients with primary insomnia). Int J Psychiatry Clin Pract. 1997;1(2):107-17.
69 Shaver JL, Johnston SK, Lentz MJ, et al. Stress exposure, psychological distress, and physiological stress activation in midlife women with insomnia. Psychosom Med. 2002;64(5):793-802. [pmid: 12271110].
70 Shochat T, Umphress J, Israel AG, et al. Insomnia in primary care patients. Sleep. 1999;22(Suppl 2):S359-65. [pmid: 10394608].
71 Sugerman JL, Stern JA, Walsh JK. Daytime alertness in subjective and objective insomnia: some preliminary findings. Biol Psychiatry. 1985;20(7):741-50. [pmid: 4005333].
72 Taylor DJ. A cross-sectional analysis of depression, anxiety, and insomnia [dissertation]. Memphis (TN): University of Memphis; 2003.
73 Terzano MG, Parrino L, Cirignotta F, et al. Studio Morfeo: insomnia in primary care, a survey conducted on the Italian population. Sleep Med. 2004;5(1):67-75. [pmid: 14725829].
74 Vgontzas AN, Kales A, Bixler EO, et al. Usefulness of polysomnographic studies in the differential diagnosis of insomnia. Int J Neurosci. 1995;82(12):47-60. [pmid: 7591515].
75 Vignola A, Lamoureux C, Bastien CH, et al. Effects of chronic insomnia and use of benzodiazepines on daytime performance in older adults. J Gerontol Series B Psychol Sci Soc Sci. 2000;55(1):P54-62.
76 Vincent NK, Walker JR. Perfectionism and chronic insomnia. J Psychosom Res. 2000;49(5):349-54. [pmid: 11164059].
77 Wang W, Zhu SZ, Pan LC, et al. Mismatch negativity and personality traits in chronic primary insomniacs. Funct Neurol. 2001;16(1):3-10. [pmid: 11396269].
78 Yeo BK, Perera IS, Kok LP, et al. Insomnia in the community. Singapore Med J. 1996;37(3):282-4. [pmid: 8942230].
79 Zammit GK, Weiner J, Damato N, et al. Quality of life in people with insomnia. Sleep. 1999;22(Suppl 2):S379-85. [pmid: 10394611].

## Evidence Table C-2: References

1 Aden GC, Thatcher C. Quazepam in the short-term treatment of insomnia in outpatients. J Clin Psychiatry. 1983;44(12):454-6. [pmid: 6361006].
2 Allain H, Arbus L, Schuck S. Efficacy and safety of zolpidem administered as needed in primary insomnia: results of a double-blind, placebo-controlled study. Clin Drug Invest. 2001;21(6):391-400.
3 Allain H, Le Coz F, Borderies P, et al. Use of zolpidem 10 mg as a benzodiazepine substitute in 84 patients with insomnia. Hum Psychopharmacol. 1998;13(8):551-9.
4 Ascher LM, Turner RM. Paradoxical intention and insomnia: an experimental investigation. Behav Res Ther. 1979;17(4):408-11. [pmid: 486046].
5 Asnis GM, Chakraburtty A, DuBoff EA, et al. Zolpidem for persistent insomnia in SSRI-treated depressed patients. J Clin Psychiatry. 1999;60(10):668-76. [pmid: 10549683].
6 Beary MD, Lacey JH, Crutchfield MB, et al. Psycho-social stress, insomnia and temazepam: a sleep laboratory evaluation in a “general practice” sample. Psychopharmacol. 1984;83(1):17-9.
7 Botter PA. Comparative double blind study of loprazolam, 1 mg and 2 mg, versus placebo in anxiety induced insomnia. Curr Med Res Opin. 1983;8(9):626-30. [pmid: 6141896].
8 Bowen AJ. Comparative efficacy of triazolam, flurazepam and placebo in out-patient insomniacs. J Int Med Res. 1978;6(4):337-42. [pmid: 28989].
9 Brown CC, Horrom NJ, Wagman AM. Effects of l-tryptophan on sleep onset insomniacs. Waking Sleeping. 1979;3(2):101-8. [pmid: 227180].
10 Campbell RD, Grace MGA, Bourgouin J, et al. Efficacy and safety of zopiclone in the treatment of insomnia. Curr Ther Res. 1987;42(4):665-70.
11 Carr-Kaffashan L, Woolfolk RL. Active and placebo effects in treatment of moderate and severe insomnia. J Consult Clin Psychol. 1979;47(6):1072-80. [pmid: 41856].
12 Chaudoir PJ, Jarvie NC, Wilcox GJ. The acceptability of a non-benzodiazepine hypnotic (zopiclone) in general practice. J Int Med Res. 1983;11(6):333-7. [pmid: 6360747].
13 Choliz M. A breathing-retraining procedure in treatment of sleep-onset insomnia: theoretical basis and experimental findings. Percept Mot Skills. 1995;80(2):507-13. [pmid: 7675582].
14 Cohn JB, Wilcox CS, Bremner J, et al. Hypnotic efficacy of estazolam compared with flurazepam in outpatients with insomnia. J Clin Pharmacol. 1991;31:747-50. [pmid: 1880233].
15 Cohn JB. Double-blind crossover comparison of triazolam and lorazepam in the posthypnotic state. J Clin Psychiatry. 1984;45(3):104-7. [pmid: 6142034].
16 Cohn JB. Triazolam treatment of insomnia in depressed patients taking tricyclics. J Clin Psychiatry. 1983;44(11):401-6. [pmid: 6139364].
17 Coxeter PD, Schluter PJ, Eastwood HL, et al. Valerian does not appear to reduce symptoms for patients with chronic insomnia in general practice using a series of randomised N-of-I trials. Complement Ther Med. 2003;11(4):215-22. [pmid: 15022653].
18 Davies R, Lacks P, Storandt M, et al. Countercontrol treatment of sleep-maintenance insomnia in relation to age. Psychol Aging. 1986;1(3):233-8. [pmid: 3267403].
19 Dawson D, Rogers NL, van den Heuvel CJ, et al. Effect of sustained nocturnal transbuccal melatonin administration on sleep and temperature in elderly insomniacs. J Biol Rhythms. 1998;13(6):532-8. [pmid: 9850013].
20 Declerck A, Smits M. Zolpidem, a valuable alternative to benzodiazepine hypnotics for chronic insomnia?. J Int Med Res. 1999;27(6):253-63. [pmid: 10726234].
21 Dominguez RA, Goldstein BJ, Jacobson AF, et al. Brotizolam in the treatment of insomnia. Psychopharmacol Bull. 1985;21(1):97-100. [pmid: 3885295].
22 Dominguez RA, Goldstein BJ, Jacobson AF, et al. Comparative efficacy of estazolam, flurazepam, and placebo in outpatients with insomnia. J Clin Psychiatry. 1986;47(7):362-5. [pmid: 2873132].
23 Donath F, Quispe S, Diefenbach K, et al. Critical evaluation of the effect of valerian extract on sleep structure and sleep quality. Pharmacopsychiatry. 2000;33(2):47-53. [pmid: 10761819].
24 Drake CL, Roehrs TA, Mangano RM, et al. Dose-response effects of zaleplon as compared with triazolam (0.25 mg) and placebo in chronic primary insomnia. Hum Psychopharmacol. 2000;15(8):595-604. [pmid: 12404612].
25 Dujardin K, Guieu JD, Leconte-Lambert C, et al. Comparison of the effects of zolpidem and flunitrazepam on sleep structure and daytime cognitive functions. A study of untreated insomniacs. Pharmacopsychiatry. 1998;31(1):14-8. [pmid: 9524979].
26 Edinger JD, Sampson WS. A primary care “friendly” cognitive behavioral insomnia therapy. Sleep. 2003;26(2):177-182. [pmid: 12683477].
27 Edinger JD, Wohlgemuth W, Radtke R, et al. Cognitive behavioral therapy for treatment of chronic primary insomnia: A randomized controlled trial. [References]. J Am Med Assoc. 2001;285(14):1856-64.
28 Elie R, Frenay M, Le Morvan P, et al. Efficacy and safety of zopiclone and triazolam in the treatment of geriatric insomniacs. Int Clin Psychopharmacol. 1990;5(Suppl 2):39-46. [pmid: 2201729].
29 Elie R, Ruther E, Farr I, et al. Sleep latency is shortened during 4 weeks of treatment with zaleplon, a novel nonbenzodiazepine hypnotic. J Clin Psychiatry. 1999;60(8):536-44. [pmid: 10485636].
30 Ellis CM, Lemmens G, Parkes JD. Melatonin and insomnia. J Sleep Res. 1996;5(1):61-5. [pmid: 8795804].
31 Espie CA, Lindsay WR, Brooks DN, et al. A controlled comparative investigation of psychological treatments for chronic sleep-onset insomnia. Behav Res Ther. 1989;27(1):79-88. [pmid: 2914008].
32 Farag NH, Mills PJ. A randomised-controlled trial of the effects of a traditional herbal supplement on sleep onset insomnia. Complement Thera Med. 2003;11(4):223-5.
33 Ferguson JM, Bielski RJ, Houston J, et al. Comparison of estazolam and placebo in the outpatient treatment of insomnia associated with major depression. Curr Ther Res. 1991;49(5):898-907.
34 Fillingim JM. Double blind evaluation of temazepam, flurazepam, and placebo in geriatric insomniacs. Clin Ther. 1982;4(5):369-80. [pmid: 6121625].
35 Fleming J, Moldofsky H, Walsh JK, et al. Comparison of the residual effects and efficacy of short term zolpidem, flurazepam and placebo in patients with chronic insomnia. Clin Drug Invest. 1995;9:303-13.
36 Fry J, Scharf M, Mangano R, et al. Zaleplon improves sleep without producing rebound effects in outpatients with insomnia. Zaleplon Clinical Study Group. Int Clin Psychopharmacol. 2000;15(3):141-52. [pmid: 10870872].
37 Garfinkel D, Laudon M, Nof D, et al. Improvement of sleep quality in elderly people by controlled-release melatonin. Lancet. 1995;346:541-4. [pmid: 7658780].
38 Garfinkel D, Laudon M, Zisapel N. Improvement of sleep quality by controlled-release melatonin in benzodiazepine-treated elderly insomniacs. Arch Gerontol Geriatr. 1997;24(2):223-31. [pmid: 15374128].
39 Gelinas B, Thorsteinson L, Lapierre YD, et al. Zopiclone in the treatment of insomniacs of family practice. Psychiatr J Univ Ottawa. 1985;10(3):165-8.
40 Goethe JW, Kader G. Short-term clinical study of quazepam 15 mg in outpatient insomniacs. Curr Ther Res. 1982;32:150-6.
41 Goldenberg F, Hindmarch I, Joyce CRB, et al. Zopiclone, sleep and health-related quality of life. Hum Psychopharmacol. 1994;9(4):245-51.
42 Haffmans PMJ, Vos MS. The effects of trazodone on sleep disturbances induced by brofaromine. Eur Psychiatry. 1999;14(3):167-71. [pmid: 10572343].
43 Haimov I, Lavie P, Laudon M, et al. Melatonin replacement therapy of elderly insomniacs. Sleep. 1995;18(7):598-603. [pmid: 8552931].
44 Hajak G, Clarenbach P, Fischer W, et al. Zopiclone improves sleep quality and daytime well-being in insomniac patients: comparison with triazolam, flunitrazepam and placebo. Int Clin Psychopharmacol. 1994;9(5):251-61. [pmid: 7868847].
45 Hajak G, Rodenbeck A, Adler L, et al. Nocturnal melatonin secretion and sleep after doxepin administration in chronic primary insomnia. Pharmacopsychiatry. 1996;29(5):187-92. [pmid: 8895944].
46 Hajak G, Rodenbeck A, Voderholzer U et al. Doxepin in the treatment of primary insomnia - a placebo-controlled, double-blind, polysomnographic study [abstract]. In: J Eur Coll Neuropsychopharmacol. Proceedings of the 13th ECNP Congress; 2000 Sep 9–13; Munich, Germany. (Suppl 3), S248.
47 Hartmann E, Lindsley JG, Spinweber C. Chronic insomnia effects of tryptophan, flurazepam, seco bartibal and placebo. Psychopharmacol. 1983;80(2):138-42.
48 Harvey AG. The attempted suppression of presleep cognitive activity in insomnia. Cognit Ther Res. 2003;27(6):593-602.
49 Haynes SN, Sides H, Lockwood G. Relaxation instructions and frontalis electromyographic feedback intervention with sleep-onset insomnia. Behav Ther. 1977;8(4):644-52.
50 Haynes SN, Woodward S, Moran R, et al. Relaxation treatment of insomnia. Behav Ther. 1974;5(4):555-8.
51 Hedner J, Yaeche R, Emilien G, et al. Zaleplon shortens subjective sleep latency and improves subjective sleep quality in elderly patients with insomnia. The Zaleplon Clinical Investigator Study Group. Int J Geriatr Psychiatry. 2000;15(8):704-12. [pmid: 10960882].
52 Heidrich H, Ott H, Beach RC. Lormetazepam A benzodiazepine derivative without hangover effect. A double-blind study with chronic insomniacs in a general practice setting. Int J Clin Pharmacol Ther Toxicol. 1981;19(1):11-17. [pmid: 6110634].
53 Hernandez LR, Del Rosal PL, Ponce MC. Short-term study of quazepam 15 milligrams in the treatment of insomnia. J Inte Med Res. 1983;11(3):162-6.
54 Herrmann WM, Kubicki ST, Boden S, et al. Pilot controlled double-blind study of the hypnotic effects of zolpidem in patients with chronic ‘learned’ insomnia: Psychometric and polysomnographic evaluation. J Int Med Res. 1993;21(6):306-22. [pmid: 8143886].
55 Hughes RC, Hughes HH. Insomnia: effects of EMG biofeedback, relaxation training, and stimulus control. Behav Eng. 1978;5(2):67-72.
56 Jacobson AF, Dominguez RA, Goldstein BJ, et al. Efficacy of brotizolam in geriatric patients with insomnia. Curr Ther Res. 1986;39:528-36.
57 James S, Sack D, Rosenthal N, et al. Melatonin administration in insomnia. Neuropsychopharmacol. 1990;3(1):19-24.
58 Krystal AD, Walsh JK, Laska E, et al. Sustained efficacy of eszopiclone over 6 months of nightly treatment: results of a randomized, double-blind, placebo-controlled study in adults with chronic Iisomnia. Sleep. 2003;26(7):793-9. [pmid: 14655910].
59 Lacks P, Bertelson AD, Sugerman J, et al. Treatment of sleep maintenance insomnia with stimulus control techniques. Behav Res Ther. 1983;21(3):291-6. [pmid: 6615394].
60 Lacks P, Bertelson AD, Gans L, et al. The effectiveness of three behavioral treatments for different degrees of sleep onset insomnia. Behav Ther. 1983;14(5):593-605.
61 Lahmeyer H, Wilcox CS, Kann J, et al. Subjective efficacy of zolpidem in outpatients with chronic insomnia: double blind comparison with placebo. Clin Drug Invest. 1997;13:134-44.
62 Lamphere JK, Roehrs TA, Zorick FJ, et al. The dose effects of zopiclone. Hum Psychopharmacol. 1989;4(1):41-6.
63 Leppik IE, Roth-Schechter GB, Gray GW, et al. Double blind, placebo controlled comparison of zolpidem, triazolam, and temazepam in elderly patients with insomnia. Drug Dev Res. 1997;40:230-8.
64 Lichstein KL, Riedel BW, Wilson NM, et al. Relaxation and sleep compression for late-life insomnia: a placebo-controlled trial. J Consult Clin Psychol. 2001;69(2):227-39. [pmid: 11393600].
65 Mamelak M, Buck L, Csima A, et al. Effects of flurazepam and zopiclone on the performance of chronic insomniac patients: a study of ethanol-drug interaction. Sleep. 1987;10(Suppl 1):79-87. [pmid: 3438646].
66 Mamelak M, Csima A, Buck L, et al. A comparative study on the effects of brotizolam and flurazepam on sleep and performance in the elderly. J Clin Psychopharmacol. 1989;9(4):260-7. [pmid: 2671059].
67 McAlpine CJ, Ankier SI, Elliott CS. A multicentre hospital study to compare the hypnotic efficacy of loprazolam and nitrazepam. J Int Med Res. 1984;12(4):229-37. [pmid: 6147285].
68 Melo de Paula AJ. Comparative study of lormetazepam and flurazepam in the treatment of insomnia. Clin Ther. 1984;6(4):500-8. [pmid: 6380724].
69 Mendels J, Stern S. Evaluation of the short-term treatment of insomnia in out patients with 15 milligrams of quazepam. J Int Med Res. 1983;11(3):155-61. [pmid: 6347747].
70 Milby JB, Williams V, Hall JN, et al. Effectiveness of combined triazolam-behavioral therapy for primary insomnia. Am J Psychiatry. 1993;150:1259-60. [pmid: 8328575].
71 Minnekeer R, Marchal J, Van de Velde L, et al. A double-blind study comparing the efficacy and safety of quazepam with flunitrazepam and placebo in patients with chronic insomnia. Acta Ther. 1988;14(2):159-70.
72 Mitchell KR. Behavioral treatment of presleep tension and intrusive cognitions in patients with severe predormital insomnia. J Behav Med. 1979;2(1):57-69. [pmid: 555480].
73 Mitler MM, Seidel WF, van den Hoed J, et al. Comparative hypnotic effects of flurazepam, triazolam, and placebo: a long-term simultaneous nighttime and daytime study. J Clin Psychopharmacol. 1984;4(1):2-13. [pmid: 6141188].
74 Monchesky TC, Billings BJ, Phillips R. Zopiclone: a new nonbenzodiazepine hypnotic used in general practice. Clin Ther. 1986;8(3):283-91. [pmid: 3521857].
75 Montes LG, Uribe MP, Sotres JC, et al. Treatment of primary insomnia with melatonin: A double-blind, placebo-controlled, crossover study. [References]. J Psychiatry Neurosci. 2003;28(3):191-6. [pmid: 12790159]. [pmcid: 161743].
76 Monti JM, Monti D, Estevez F et al. Sleep in patients with chronic primary insomnia during long-term zolpidem administration and after its withdrawal. Int Clin Psychopharmacol 1996; 114(255–63).
77 Monti JM, Alvarino F, Monti D. Conventional and power spectrum analysis of the effects of zolpidem on sleep EEG in patients with chronic primary insomnia. Sleep. 2000;23(8):1075-84. [pmid: 11145322].
78 Morin CM, Colecchi C, Stone J, et al. Behavioral and pharmacological therapies for late-life insomnia: a randomized controlled trial.[comment]. J Am Med Assoc. 1999;281(11):991-9.
79 Nair NP, Schwartz G, Dimitri R, et al. A dose-range finding study of zopiclone in insomniac patients. Int Clin Psychopharmacol. 1990;5(Suppl 2):1-10. [pmid: 2201721].
80 Negri L. Evaluation of the efficacy of pivagabine on insomnia associated with mood disorders. Arzneimittel Forschung. 1997;47(11 Suppl a):1322-5. [pmid: 9450157].
81 Nicassio P, Bootzin R. A comparison of progressive relaxation and autogenic training as treatments for insomnia. J Abnorm Psychol. 1974;83(3):253-60. [pmid: 4844912].
82 Pasche B, Erman M, Hayduk R, et al. Effects of low energy emission therapy in chronic psychophysiological insomnia. Sleep. 1996;19(4):327-36. [pmid: 8776791].
83 Perlis ML, Smith MT, Orff H, et al. The effects of modafinil and cognitive behavior therapy on sleep continuity in patients with primary insomnia. Sleep. 2004;27(4):715-25. [pmid: 15283007].
84 Poyares DR, Guilleminault C, Ohayon MM, et al. Can valerian improve the sleep of insomniacs after benzodiazepine withdrawal?. Prog NeuroPsychopharmacol Biol Psychiatry. 2002;26(3):539-45. [pmid: 11999905].
85 Reeves RL. Comparison of triazolam, flurazepam and placebo as hypnotics in geriatric patients with insomnia. J Clin Pharmacol. 1977;17:319-23. [pmid: 16041].
86 Rickels K, Morris RJ, Mauriello R, et al. Brotizolam, a triazolothienodiazepine, in insomnia. Clin Pharmacol Ther. 1986;40:293-9. [pmid: 3527513].
87 Riemann D, Voderholzer U, Cohrs S, et al. Trimipramine in Primary Insomnia: Results of a Polysomnographic Double-Blind Controlled Study. Pharmacopsychiatry. 2002;35(5):165-74. [pmid: 12237787].
88 Rodenbeck A, Cohrs S, Jordan W, et al. The sleep-improving effects of doxepin are paralleled by a normalized plasma cortisol secretion in primary iInsomnia - a placebo-controlled, double-blind, randomized, cross-over study followed by an open treatment over 3 weeks. Psychopharmacol. 2003;170(4):423-8.
89 Roehrs T, Papineau K, Rosenthal L, et al. Ethanol as a hypnotic in insomniacs: self administration and effects on sleep and mood. Neuropsychopharmacol. 1999;20(3):279-86.
90 Roehrs T, Zorick F, Koshorek GL, et al. Effects of acute administration of brotizolam in subjects with disturbed sleep. Br J Clin Pharmacol. 1983;16(Suppl 2):S371-6.
91 Roth T, Tietz EI, Kramer M, et al. The effect of a single dose of quazepam (Sch-16134) on the sleep of chronic insomniacs. J Int Med Res. 1979;7(6):583-7. [pmid: 42593].
92 Roth TG, Roehrs TA, Koshorek GL, et al. Hypnotic effects of low doses of quazepam in older insomniacs. J Clin Psychopharmacol. 1997;17(5):401-6. [pmid: 9315991].
93 Saletu-Zyhlarz G, Anderer P, Gruber G, et al. Insomnia related to postmenopausal syndrome and hormone replacement therapy: sleep laboratory studies on baseline differences between patients and controls and double-blind, placebo-controlled investigations on the effects of a novel estrogen-progestogen combination (Climodien [R], Lafamme [R]) versus estrogen alone. J Sleep Res. 2003;12(3):239-54. [pmid: 12941063].
94 Sanavio E, Vidotto G, Bettinardi O, et al. Behaviour therapy for DIMS: Comparison of three treatment procedures with follow-up. Behav Psychother. 1990;18(3):151-67.
95 Sastre-y-Hernandez M, Visser P, Schutt B, et al. Sublingual lormetazepam in the treatment of sleep disorders in general practice patients. Hum Psychopharmacol. 1988;3(2):139-44.
96 Scharf MB, Roth PB, Dominguez RA, et al. Estazolam and flurazepam: multicenter, placebo-controlled comparative study in outpatients with insomnia. J Clin Pharmacol. 1990;30:461-7. [pmid: 1971831].
97 Scharf MB, Roth T, Vogel GW, et al. A multicenter, placebo-controlled study evaluating zolpidem in the treatment of chronic insomnia. J Clin Psychiatry. 1994;55(5):192-9. [pmid: 8071269].
98 Shaw SH, Curson H, Coquelin JP. A double-blind, comparative study of zolpidem and placebo in the treatment of insomnia in elderly psychiatric in-patients.[erratum appears in J Int Med Res 1992 Nov; 20(6):following 494]. J Int Med Res. 1992;20(2):150-61. [pmid: 1521671].
99 Shealy R. The effectiveness of various treatment techniques on different degrees and durations of sleep onset insomnia. Behav Res Ther. 1979;17(6):541-6. [pmid: 393245].
100 Stanton HE. Hypnotic relaxation and the reduction of sleep onset insomnia. Int J Psychosom. 1989;36(14):64-8. [pmid: 2689375].
101 Steens RD, Pouliot Z, Millar TW, et al. Effects of zolpidem and triazolam on sleep and respiration in mild to moderate chronic obstructive pulmonary disease. Sleep. 1993;16(4):318-26. [pmid: 8341892].
102 Stip E, Furlan M, Lussier I, et al. Double-blind, placebo-controlled study comparing effects of zopiclone and temazepam on cognitive functioning of insomniacs. Hum Psychopharmacol. 1999;14(4):253-61.
103 Tietz EI, Roth T, Zorick FJ, et al. The acute effect of quazepam on the sleep of chronic insomniacs. A dose-response study. Arzneimittel-orschung. 1981;31(11):1963-6. [pmid: 6119098].
104 Tuk B, Oberye JJ, Pieters MS, et al. Pharmacodynamics of temazepam in primary insomnia: assessment of the value of quantitative electroencephalography and saccadic eye movements in predicting improvement of sleep. Clin Pharmacol Ther. 1997;62:444-52. [pmid: 9357396].
105 Vallieres A, Morin CM, Guay B, et al. Sequential treatment for chronic insomnia: A pilot study. Behav Sleep Med. 2004;2(2):94-112. [pmid: 15600227].
106 Viukari M, Jaatinen P, Kylmamaa T. Flunitrazepam and nitrazepam as hypnotics in psychogeriatric inpatients. Clin Ther. 1983;5(6):662-70. [pmid: 6627292].
107 Walsh JK. Zolpidem “as needed” for the treatment of primary insomnia: a double-blind, placebo-controlled study. Sleep Med Rev. 2002;6:S7-11. [pmid: 12607571].
108 Walsh JK, Fry J, Erwin CW, et al. Efficacy and tolerability of 14-day administration of zaleplon 5 mg and 10 mg for the treatment of primary insomnia. Clin Drug Invest. 1998;16:347-54.
109 Walsh JK, Fry J, Richardson GS, et al. Short term efficacy of zaleplon in older patients with chronic insomnia. Clin Drug Invest. 2000;20:143-9.
110 Walsh JK, Targum SD, Pegram V, et al. Multicenter clinical investigation of estazolam: short term efficacy. Curr Ther Res. 1984;36:866-74.
111 Walsh JK, Erman M, Erwin CW, et al. Subjective hypnotic efficacy of trazodone and zolpidem in DSMIII-R primary insomnia. Hum Psychopharmacol. 1998;13(3):191-8.
112 Walsh JK, Roth T, Randazzo A, et al. Eight weeks of non-nightly use of zolpidem for primary insomnia. Sleep. 2000;23(8):1087-96. [pmid: 11145323].
113 Wang RIH, Stockdale SL. Subjective and objective method assessing the efficacy of hypnotic medications in insomniacs. J Clin Pharmacol. 1977;17:728-33. [pmid: 336652].
114 Waters WF, Hurry MJ, Binks PG, et al. Behavioral and hypnotic treatments for insomnia subtypes. Behav Sleep Med. 2003;1(2):81-101. [pmid: 15600131].
115 Winsauer HJ, O'Hair DE, Valero R. Quazepam: short term treatment of insomnia in geriatric outpatients. Curr Ther Res. 1984;35:228-34.
116 Zhdanova IV, Wurtman RJa, Regan MM, et al. Melatonin treatment for age-related insomnia. J Clin Endocrinol Metab. 2001;86(10):4727-30. [pmid: 11600532].