# Appendix A: Exact Search Strings

Table A-1. MEDLINE^®^ - Ovid Version: rel9.1.0

Table A-2. EMBASE - Ovid Version: rel9.1.0

Table A-3. CINAHL^®^ (Cumulative Index to Nursing & Allied Health Literature) - Ovid Version: rel9.1.0

Table A-4. Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations - Ovid Version: rel9.1.0

Table A-5. Ovid OLDMEDLINE^®^ - Ovid Version: rel9.1.0

Table A-6. PsycINFO^®^ - Ovid Version: rel9.1.0

Table A-7. EBM Reviews - Cochrane Central Register of Controlled Trials - Ovid Version: rel9.1.0

Table A-8. International Pharmaceutical Abstracts - Ovid Version: rel9.1.0

Table A-9. AMED (Allied and Complementary Medicine) - Ovid Version: rel9.1.0

Table A-10. HealthSTAR/Ovid Healthstar - Ovid Version: rel9.1.0

Table A-11. EBM Reviews - Cochrane Database of Systematic Reviews (2^nd^ Quarter 2004); ACP Journal Club (1991 to March/April 2004); Database of Abstracts of Reviews of Effects (2^nd^ Quarter 2004) - Ovid Version: rel9.1.0

Table A-12. Science Citation Index Expanded^™^ -1945-September 2004 - ISI Web of Knowledge

Table A-13. Biological Abstracts - WebSPIRS from SilverPlatter, Version 4.3

Table A-14. Cochrane Complementary Medicine Field Registry - Reference Web Poster 2001; ISI ResearchSoft

Table A-15. CAB Abstracts - WebSPIRS from SilverPlatter, Version 4.3

Table A-16. SIGLE - FIZ Karlsruhe - Version Interhost 3000

Table A-17. OCLC Proceedings First - OCLC FirstSearch

Table A-18. Dissertation Abstracts - ProQuest

Table A-19. Alt HealthWatch - EBSCOhost

Table A-20. NLM Gateway

Table A-21. PubMed^®^

Table A-1 MEDLINE^®^ - Ovid Version: rel9.1.0

1966 to September Week 1 2004
Searched Sept. 15, 2004
1. | insomni$.mp.
2. | exp “Sleep Initiation and Maintenance Disorders”/
3. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
4. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
| 5. dims.mp.
5. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
6. | (early adj2 awaken$).mp.
7. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
8. | or/1–8
9. | “analytic stud$”.mp.
10. | exp case-control studies/ or exp retrospective studies/
11. | exp cohort studies/ or exp longitudinal studies/ or exp follow-up studies/ or exp prospective studies/ or comparative study/ or exp Evaluation Studies/
12. | exp Cross-Sectional Studies/
13. | exp RISK FACTORS/ or exp RISK/ or exp RISK ASSESSMENT/
14. | exp Odds Ratio/
15. | exp CAUSALITY/
16. | exp Logistic Models/
17. | exp epidemiologic factors/ or exp age factors/ or exp “bias (epidemiology)”/ or exp comorbidity/ or exp “confounding factors (epidemiology)”/ or exp “effect modifiers (epidemiology)”/ or exp observer variation/ or exp reproductive history/ or exp sex factors/
18. | exp morbidity/ or exp incidence/ or exp prevalence/
19. | (cohort or observational or correlational or non-experimental or “non experimental” or nonexperimental or control$ or prospectiv$ or volunteer$ or “case series” or “case-series” or “case comparison” or “case-comparison” or “case referent” or “case-referent” or “cross sectional” or “cross-sectional” or risk or “relative risk” or causation or causal$ or “odds ratio$” or etiol$ or aetiol$ or incidence).mp.
20. | exp prognosis/ or exp medical futility/ or exp treatment outcome/
21. | exp mortality/ or exp “cause of death”/ or exp fatal outcome/ or exp survival rate/
22. | exp survival analysis/ or exp disease-free survival/
23. | exp disease susceptibility/ or exp genetic predisposition to disease/
24. | exp disease progression/ or exp “Severity of Illness Index”/
25. | exp Time Factors/
26. | exp RECURRENCE/
27. | (“natural history” or “inception cohort” or predict$ or prognos$ or outcome$ or course).mp.
28. | exp “costs and cost analysis”/ or exp “cost allocation”/ or exp cost-benefit analysis/ or exp “cost control”/ or exp “cost savings”/ or exp “cost of illness”/ or exp “cost sharing”/ or exp “deductibles and coinsurance”/ or exp health care costs/ or exp direct service costs/ or exp drug costs/ or exp employer health costs/ or exp hospital costs/ or exp health expenditures/ or exp capital expenditures/
29. | exp “Quality of Life”/ or exp “Activities of Daily Living”/
30. | exp “OUTCOME ASSESSMENT (HEALTH CARE)”/ or exp “OUTCOME AND PROCESS ASSESSMENT (HEALTH CARE)”/ or exp Health Status Indicators/ or exp Health Status/ or exp Questionnaires/
31. | (cost$ or economic or social or “quality of life” or “life quality” or hrql or well-being or wellbeing or “well being” or “outcome adj assessment$” or “health status”).mp.
32. | (et or pc or ae or ep or to or ge or ec or in or ut or mo).fs.
33. | or/10–33
34. | animal/ not human/
35. | 34 not 35
36. | 9 and 36
37. | eng.la.
38. | 37 and 38
39. | insomni$.mp.
40. | exp “Sleep Initiation and Maintenance Disorders”/
41. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
42. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
43. | dims.mp.
44. | disorder$ of initiating and maintaining sleep.mp.
45. | (early adj2 awaken$).mp.
46. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
47. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
48. | or/40–48
49. | randomized controlled trial.pt.
50. | controlled clinical trial.pt.
51. | randomized controlled trials/
52. | random allocation/
53. | double blind method/
54. | single blind method/
55. | clinical trial.pt.
56. | exp Clinical Trials/
57. | (clin$ adj25 trial$).ti,ab.
58. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
59. | placebos/
60. | placebo$.ti,ab.
61. | random$.ti,ab.
62. | research design/
63. | or/50–63
64. | 64 not 35
65. | 49 and 65
66. | 66 not 39
67. | meta-analysis.pt,sh.
68. | (meta-anal$ or metaanal$).mp.
69. | ((systematic$ adj3 review$) or (systematic$ adj3 overview$)).mp.
70. | ((quantitativ$ adj3 review$) or (quantitativ$ adj3 overview)).mp.
71. | ((methodol$ adj3 review$) or (methodol$ adj3 overview$)).mp.
72. | (integrative research review$ or research integration$).mp.
73. | (quantitativ$ adj (synthes$ or analys$)).mp.
74. | ((“evidence based” or evidence-based) adj3 (medicine or guideline$ or recommendation$)).mp.
75. | guideline.pt.
76. | “cochrane database of systematic reviews”.mp.
77. | cdsr.mp.
78. | acp journal club.mp.
79. | “health tech$ assess$”.mp.
80. | hta.mp.
81. | “evidence based nursing”.mp.
82. | “evidence based mental health”.mp.
83. | “clinical evidence”.mp.
84. | technolog$ assess$.mp.
85. | “evidence report$”.mp.
86. | or/68–86
87. | review.pt. or (review or overview$ or reviews or handsearch or “hand search” or hand-search or “manual search”).mp.
88. | (medline or medlars or pubmed or embase or “index medicus” or cochrane or scisearch or “Web of Science” or psychinfo or psycinfo or psychlit or psyclit or cinahl or cinhal or “experta medica” or “excerpta medica” or “science citation index” or “sciences citation index” or “biological abstracts” or “current contents”).mp.
89. | (((electronic or bibliographic) adj3 database$) or “periodical index$”).mp.
90. | ((pool$ or combined or combining) adj (data or trials or studies or results)).mp.
91. | (peto or “der simonian” or dersimonian or “fixed effect$” or “treatment outcome$” or “mantel haenszel”).mp.
92. | or/89–92
93. | 88 and 93
94. | 87 or 94
95. | case report.ti,sh.
96. | editorial.ti,pt.
97. | letter.pt.
98. | newspaper article.pt.
99. | comment.pt.
100. | or/96–100
101. | 95 not 101
102. | animal/ not human/
103. | 102 not 103
104. | eng.la.
105. | 104 and 105
106. | 9 and 106
107. | 107 not (39 or 67)

Table A-2 EMBASE - Ovid Version: rel9.1.0

1988 to 2004 Week 37
Searched September 15, 2004
1. | insomni$.mp. or exp insomnia/
2. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
4. | dims.mp.
5. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
6. | (early adj2 awaken$).mp.
7. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
8. | or/1–7
9. | “analytic stud$”.mp.
10. | exp case-control study/ or exp retrospective study/
11. | exp cohort analysis/ or exp longitudinal study/ or exp prospective study/ or exp Comparative Study/ or exp Evaluation/
12. | ((“follow up” or follow-up) adj stud$).mp.
13. | exp GENETIC RISK/ or exp POPULATION RISK/ or exp CORONARY RISK/ or exp HIGH RISK PATIENT/ or exp HIGH RISK PREGNANCY/ or exp RISK FACTOR/ or exp CARDIOVASCULAR RISK/ or exp RISK ASSESSMENT/ or exp RISK/ or exp HIGH RISK POPULATION/ or exp CANCER RISK/ or exp RISK MANAGEMENT/ or exp RISK REDUCTION/ or exp RISK BENEFIT ANALYSIS/ or exp INFECTION RISK/ or exp RECURRENCE RISK/
14. | causality.mp.
15. | (Logistic adj Model$).mp. or exp Statistical Model/
16. | exp COMORBIDITY/ or exp Onset Age/ or exp Observer Variation/ or exp Sex Difference/
17. | exp epidemiology/ or exp incidence/ or exp morbidity/ or exp mortality/ or prevalence/
18. | (cohort or control$ or correlational or non-experimental or “non experimental” or nonexperimental or prospectiv$ or volunteer$ or “case series” or “case-series” or “case comparison” or “case-comparison” or “case referent” or “case-referent” or “cross sectional” or “cross-sectional” or risk or “relative risk” or causation or causal$ or “odds ratio$” or etiol$ or aetiol$ or incidence).mp.
19. | exp prognosis/ or medical futility.mp. or exp treatment outcome/
20. | exp “cause of death”/ or exp fatality/ or exp survival rate/
21. | exp SURVIVAL RATE/ or exp SURVIVAL/ or exp SURVIVAL TIME/
22. | exp Disease Predisposition/ or exp Genetic Predisposition/
23. | exp Disease Course/ or “Severity of illness index”.mp.
24. | exp Recurrent Disease/ or exp Disease Severity/ or exp Chronic Disease/
25. | (“natural history” or “inception cohort” or predict$ or prognos$ or outcome$ or course).mp.
26. | exp “HOSPITAL COST”/ or exp “COST EFFECTIVENESS ANALYSIS”/ or exp “COST UTILITY ANALYSIS”/ or exp “ENERGY COST”/ or exp “COST CONTROL”/ or exp “DRUG COST”/ or exp “COST BENEFIT ANALYSIS”/ or exp “COST MINIMIZATION ANALYSIS”/ or exp “COST”/ or exp “HEALTH CARE COST”/ or exp “COST OF ILLNESS”/
27. | exp “Quality of Life”/ or exp Daily Life Activity/
28. | exp Health Status/ or exp Follow Up/ or exp Questionnaire/ or exp Outcomes Research/ or exp Health Care Quality/
29. | (cost$ or economic or social or “quality of life” or Hrql or “life quality” or well-being or wellbeing or “well being” or “outcome adj assessment$” or “health status”).mp.
30. | ((human or “daily living”) adj2 activit$).mp.
31. | (et or pc or ae or ep or to or ge or ec or in or ut or mo).fs.
32. | or/9–31
33. | limit 32 to human/
34. | Nonhuman/
35. | 33 not 34
36. | 8 and 35
37. | eng.la.
38. | 36 and 37
39. | insomni$.mp. or exp insomnia/
40. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
41. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
42. | dims.mp.
43. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
44. | (early adj2 awaken$).mp.
45. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
46. | exp Jet Lag/
47. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
48. | or/39–47
49. | Randomized Controlled Trial/
50. | exp Randomization/
51. | Double Blind Procedure/
52. | Single Blind Procedure/
53. | Clinical Trial/
54. | (clin$ adj25 trial$).mp.
55. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).mp.
56. | exp Placebo/
57. | (placebo$ or random$).mp.
58. | exp Methodology/
59. | or/49–58
60. | limit 59 to human/
61. | 60 not 34
62. | 48 and 61
63. | 62 not 38
64. | meta-analysis.sh.
65. | (meta-anal$ or metaanal$).mp.
66. | ((systematic$ adj3 review$) or (systematic$ adj3 overview$)).mp.
67. | ((quantitativ$ adj3 review$) or (quantitativ$ adj3 overview)).mp.
68. | ((methodol$ adj3 review$) or (methodol$ adj3 overview$)).mp.
69. | (integrative research review$ or research integration$).mp.
70. | (quantitativ$ adj (synthes$ or analys$)).mp.
71. | ((“evidence based” or evidence-based) adj3 (medicine or guideline$ or recommendation$)).mp.
72. | cochrane database of systematic reviews.mp.
73. | cdsr.mp.
74. | acp journal club.mp.
75. | “health tech$ assess$”.mp.
76. | hta.mp.
77. | “evidence based nursing”.mp.
78. | “evidence based mental health”.mp.
79. | “clinical evidence”.mp.
80. | technolog$ assess$.mp.
81. | “evidence report$”.mp.
82. | or/64–81
83. | review.pt. or (review or overview$ or reviews or handsearch or “hand search” or hand-search or “manual search”).mp.
84. | (medline or medlars or pubmed or embase or “index medicus” or cochrane or scisearch or “Web of Science” or psychinfo or psycinfo or psychlit or psyclit or cinahl or cinhal or “experta medica” or “excerpta medica” or “science citation index” or “sciences citation index” or “biological abstracts” or “current contents”).mp.
85. | (((electronic or bibliographic) adj3 database$) or “periodical index$”).mp.
86. | ((pool$ or combined or combining) adj (data or trials or studies or results)).mp.
87. | (peto or “der simonian” or dersimonian or “fixed effect$” or “treatment outcome$” or “mantel haenszel”).mp.
88. | or/84–87
89. | 83 and 88
90. | 82 or 89
| 91. case report.ti,sh.
91. | editorial.ti,pt.
92. | letter.pt.
93. | note.pt.
94. | or/91–94
95. | 90 not 95
96. | Nonhuman/ not human/
97. | 96 not 97
98. | eng.la.
99. | 98 and 99
100. | 8 and 100
101. | 101 not (38 or 63)

Table A-3 CINAHL^®^ (Cumulative Index to Nursing & Allied Health Literature) - Ovid Version: rel9.1.0

1982 to September Week 2 2004
Searched September 15, 2004
1. | insomni$.mp. or exp INSOMNIA/
2. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
4. | dims.mp.
5. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
6. | (early adj2 awaken$).mp.
7. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
8. | or/1–7
9. | exp Analytic Research/ or (analytic adj (stud$ or research)).mp.
10. | exp Nonexperimental Studies/ or exp Case Control Studies/ or exp Hospital-Based Case Control/ or exp Matched Case Control/ or exp Population-Based Case Control/ or exp Correlational Studies/
11. | exp Prospective Studies/ or exp concurrent prospective studies/ or exp nonconcurrent prospective studies/ or exp panel studies/ or exp retrospective panel studies/ or exp revolving panel studies/ or exp pseudolongitudinal studies/
12. | exp Cross Sectional Studies/
13. | exp RELATIVE RISK/ or exp CARDIOVASCULAR RISK FACTORS/ or exp RISK MANAGEMENT/ or exp RISK FACTORS/ or exp FALL RISK ASSESSMENT TOOL/ or exp RISK ASSESSMENT/
14. | exp Odds Ratio/ or (“relative odd$” or “rate ratio”).mp.
15. | exp Causal Attribution/
16. | exp professional practice, research-based/ or exp medical practice, research-based/ or exp nursing practice, research-based/
17. | exp epidemiological research/ or exp seroprevalence studies/18. exp Age Factors/ or exp “age of onset”/ or exp comorbidity/ or exp disease surveillance/ or exp injury pattern/ or exp Sex Factors/
18. | exp morbidity/ or exp incidence/ or exp prevalence/
19. | (cohort or comparative or “evaluation stud$” or observational or non-experimental or “non experimental” or nonexperimental or control$ or prospectiv$ or volunteer$ or “case series” or “case-series” or “case comparison” or “case-comparison” or “case referent” or “case-referent” or “cross sectional” or “cross-sectional” or risk or “relative risk” or causation or causal$ or “odds ratio$” or etiol$ or aetiol$ or incidence).mp.
20. | exp prognosis/ or exp medical futility/ or exp treatment outcomes/
21. | exp mortality/ or exp “cause of death”/ or exp survival/
22. | exp survival analysis/
23. | exp disease susceptibility/
24. | exp disease progression/ or exp “Severity of Illness Indices”/
25. | exp Time Factors/
26. | exp RECURRENCE/
27. | (“natural history” or “inception cohort” or predict$ or prognos$ or outcome$ or course).mp.
28. | exp “costs and cost analysis”/ or exp “cost benefit analysis”/ or exp “cost control”/ or exp diagnosis-related groups/ or exp health care costs/ or exp HEALTH FACILITY COSTS/
29. | exp “Quality of Life”/ or exp “Activities of Daily Living”/
30. | exp “Outcomes (Health Care)”/ or exp Outcome Assessment/ or exp Health Status/ or exp Health Status Indicators/ or exp QUESTIONNAIRES/
31. | (cost$ or economic or social or “quality of life” or “life quality” or hrql or well-being or wellbeing or “well being” or “outcome adj assessment$” or “health status”).mp.
32. | (et or pc or ae or ep or to or ge or ec or in or nu or ut or mo).fs.
33. | or/9–33
34. | 8 and 34
35. | limit 35 to English
36. | insomni$.mp. or exp INSOMNIA/
37. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
38. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
39. | dims.mp.
40. | “disorder$ of initiating and maintaining sleep”.mp.
41. | (early adj2 awaken$).mp.
42. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
43. | exp Jet Lag Syndrome/ or (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
44. | or/37–44
45. | Random Assignment/
46. | random sample/
47. | Crossover Design/
48. | exp Clinical Trials/
49. | Double-Blind Studies/
50. | Single-Blind Studies/
51. | Control Group/ or Factorial Design/ or Quasi-Experimental Studies/ or Community Trials/ or Experimental Studies/ or PRETEST-POSTTEST DESIGN/ or PRETEST-POSTTEST CONTROL GROUP DESIGN/ or SOLOMON FOUR-GROUP DESIGN/
52. | clinical trial.pt.
53. | (clin$ adj25 trial$).ti,ab.
54. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
55. | ((clin$ or intervention$ or compar$ or experiment$ or preventive or therapeutic) adj10 trial$).mp.
56. | placebos/
57. | placebo$.ti,ab.
58. | random$.ti,ab.
59. | Study Design/
60. | or/46–60
61. | 45 and 61
62. | 62 not 36
63. | meta-analysis.sh.
64. | (meta-anal$ or metaanal$).mp.
65. | ((systematic$ adj3 review$) or (systematic$ adj3 overview$)).mp.
66. | ((quantitativ$ adj3 review$) or (quantitativ$ adj3 overview)).mp.
67. | ((methodol$ adj3 review$) or (methodol$ adj3 overview$)).mp.
68. | (integrative research review$ or research integration$).mp.
69. | (quantitativ$ adj (synthes$ or analys$)).mp.
70. | ((“evidence based” or evidence-based) adj3 (medicine or guideline$ or recommendation$)).mp.
71. | guideline$.mp.
72. | cochrane database of systematic reviews.mp.
73. | cdsr.mp.
74. | acp journal club.mp.
75. | “health tech$ assess$”.mp.
76. | hta.mp.
77. | “evidence based nursing”.mp.
78. | “evidence based mental health”.mp.
79. | “clinical evidence”.mp.
80. | technolog$ assess$.mp.
81. | “evidence report$”.mp.
82. | or/64–82
83. | review.pt. or (review or overview$ or reviews or handsearch or “hand search” or hand-search or “manual search”).mp.
84. | (medline or medlars or pubmed or embase or “index medicus” or cochrane or scisearch or “Web of Science” or psychinfo or psycinfo or psychlit or psyclit or cinahl or cinhal or “experta medica” or “excerpta medica” or “science citation index” or “sciences citation index” or “biological abstracts” or “current contents”).mp.
85. | (((electronic or bibliographic) adj3 database$) or “periodical index$”).mp.
86. | ((pool$ or combined or combining) adj (data or trials or studies or results)).mp.
87. | (peto or “der simonian” or dersimonian or “fixed effect$” or “treatment outcome$” or “mantel haenszel”).mp.
88. | or/85–88
89. | 84 and 89
90. | 83 or 90
91. | “case report”.ti. or “case study”.pt.
92. | editorial.ti,pt.
93. | letter.pt.
94. | commentary.pt.
95. | or/92–95
96. | 91 not 96
97. | limit 97 to English
98. | 8 and 98
99. | 99 not (36 or 63)

Table A-4 Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations - Ovid Version: rel9.1.0

Searched September 14, 2004
1. | insomni$.mp.
2. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
4. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
5. | (early adj2 awaken$).mp.
6. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
7. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
8. | or/1–7
9. | “randomized controlled trial$”.mp.
10. | “controlled clinical trial$”.mp.
11. | “random allocation”.mp.
12. | (“double blind” adj3 method$).mp.
13. | (“single blind” adj3 method$).mp.
14. | (clin$ adj25 trial$).mp.
15. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
16. | placebo$.ti,ab.
17. | random$.ti,ab.
18. | “research design$”.mp.
19. | “clinical research”.mp.
20. | or/9–19
21. | 8 and 20

Table A-5 Ovid OLDMEDLINE® - Ovid Version: rel9.1.0

1951 to 1965
Searched September 15, 2004
1. | insomni$.mp
2. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
4. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
5. | (early adj2 awaken$).mp.
6. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
7. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
8. | or/1–7
9. | “randomized controlled trial$”.mp.
10. | “controlled clinical trial$”.mp.
11. | “random allocation”.mp.
12. | (“double blind” adj3 method$).mp.
13. | (“single blind” adj3 method$).mp.
14. | (clin$ adj25 trial$).mp.
15. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
16. | placebo$.ti,ab.
17. | random$.ti,ab.
18. | “research design$”.mp.
19. | “clinical research”.mp.
20. | or/9–19
21. | 8 and 20

Table A-6 PsycINFO^®^ - Ovid Version: rel9.1.0

1872 to September Week 1 2004
Searched September 15, 2004
1. | insomni$.mp. or exp INSOMNIA/
2. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
4. | dims.mp.
5. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
6. | (early adj2 awaken$).mp.
7. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
8. | or/1–7
9. | “analytic stud$”.mp.
10. | exp Between Groups Design/ or exp Cohort Analysis/ or exp Followup Studies/ or exp Longitudinal Studies/ or exp Repeated Measures/ or empirical methods/ or observation methods/ or exp Causal Analysis/ or exp Cohort Analysis/ or exp Content Analysis/ or exp Data Collection/ or exp Self Report/ or exp QUESTIONNAIRES/
11. | prevention/ or exp accident prevention/ or exp preventive medicine/ or exp risk management/ or exp risk perception/
12. | exp EPIDEMIOLOGY/ or exp COMORBIDITY/
13. | (cohort or observational or correlational or non-experimental or “non experimental” or nonexperimental or control$ or prospectiv$ or volunteer$ or “case series” or “case-series” or “case comparison” or “case-comparison” or “case referent” or “case-referent” or “cross sectional” or “cross-sectional” or risk or “relative risk” or causation or causal$ or “odds ratio$” or etiol$ or aetiol$ or incidence).mp.
14. | exp At Risk Populations/ or exp Coronary Prone Behavior/ or exp Age Differences/ or exp Human Sex Differences/ or exp PREDISPOSITION/ or exp DISORDERS/ or exp “SUSCEPTIBILITY (DISORDERS)”/
15. | exp ETIOLOGY/ or exp ATTRIBUTION/
16. | exp PROGNOSIS/ or exp “DEATH AND DYING”/ or exp Disease Course/ or exp Treatment Effectiveness Evaluation/ or exp Treatment Outcomes/ or exp Psychotherapeutic Outcomes/ or exp “RECOVERY (DISORDERS)”/ or exp “RELAPSE (DISORDERS)”/ or exp “remission (disorders)”/
17. | (morbidity or prevalence or mortality or “cause of death” or “survival rate” or “disease progression” or “time factor$” or “disease free survival” or cure$).mp.
18. | recurrence.mp.
19. | (“natural history” or “inception cohort” or predict$ or prognos$ or outcome$ or course).mp.
20. | “costs and cost analysis”/ or exp health care costs/ or exp Resource Allocation/
21. | exp “Quality of Life”/ or exp Psychosocial Factors/ or exp Sociocultural Factors/ or exp “Activities of Daily Living”/
22. | (cost$ or economic or social or “quality of life” or “life quality” or hrql or well-being or wellbeing or “well being” or “outcome adj assessment$” or “health status”).mp.
23. | (“empirical study” or “followup study” or “longitudinal study” or “prospective study”).fc.
24. | or/9–23
25. | exp animals/
26. | 24 not 25
27. | 8 and 26
28. | limit 27 to english language
29. | insomni$.mp. or exp INSOMNIA/
30. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
31. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
32. | dims.mp.
33. | “disorder$ of initiating and maintaining sleep”.mp.
34. | (early adj2 awaken$).mp.
35. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
36. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
37. | or/29–36
38. | (“Quantitative Study” or “experimental replication”).fc.
39. | exp experimental methods/ or exp experimental design/ or exp quantitative methods/
40. | exp Experiment Controls/
41. | treatment/ or alternative medicine/ or interdisciplinary treatment approach/ or “medical treatment (general)”/ or multimodal treatment approach/ or physical treatment methods/ or preventive medicine/ or psychotherapeutic techniques/ or psychotherapy/ or rehabilitation/ or relaxation therapy/ or sociotherapy/
42 | (therapy or treat$).mp.
43. | ((clin$ or intervention$ or compar$ or experiment$ or preventive or therap$) adj25 (trial$ or study or studies)).mp.
44. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).mp.
45. | exp placebo/
46. | (cross?over or placebo$ or control$ or factorial or sham).mp.
47. | “clinical research”.mp.
48. | random$.mp.
49. | or/38–48
50. | 49 not 25
51. | 37 and 50
52. | 51 not 28

Table A-7 EBM Reviews - Cochrane Central Register of Controlled Trials - Ovid Version: rel9.1.0

2nd Quarter 2004
Searched September 15, 2004
1. | insomni$.mp.
2. | exp “Sleep Initiation and Maintenance Disorders”/
3. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
4. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
5. | dims.mp.
6. | disorder$ of initiating and maintaining sleep.mp.
7. | (early adj2 awaken$).mp.
8. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
9. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
10. | or/1–9
11. | randomized controlled trial.pt.
12. | controlled clinical trial.pt.
13. | randomized controlled trials/
14. | random allocation/
15. | double blind method/
16. | single blind method/
17. | clinical trial.pt.
18. | exp Clinical Trials/
19. | (clin$ adj25 trial$).ti,ab.
20. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
21. | placebos/
22. | placebo$.ti,ab.
23. | random$.ti,ab.
24. | research design/
25. | or/11–24
26. | animal/
27. | 25 not 26
28. | 10 and 27

Table A-8 International Pharmaceutical Abstracts - Ovid Version: rel9.1.0

1970 to August 2004
Searched September 15, 2004
1. | insomni$.mp.
2. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.4. (disorder$ adj initiating adj2 maintaining adj sleep).mp.
4. | (early adj2 awaken$).mp.
5. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
6. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
7. | or/1–7
8. | “randomized controlled trial$”.mp.
9. | “controlled clinical trial$”.mp.
10. | “random allocation”.mp.
11. | (“double blind” adj3 method$).mp.
12. | (“single blind” adj3 method$).mp.
13. | (clin$ adj25 trial$).mp.
14. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
15. | placebo$.ti,ab.
16. | random$.ti,ab.
17. | “research design$”.mp.
18. | “clinical research”.mp.
19. | or/9–19
20. | limit 20 to human
21. | 8 and 21

Table A-9 AMED (Allied and Complementary Medicine) - Ovid Version: rel9.1.0

1985 to September 2004
Searched September 15, 2004
1. | insomni$.mp.
2. | exp insomnia/
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
4. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
5. | (early adj2 awaken$).mp.
6. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
7. | (((time-zone or “time zone”) adj2 change$) or “jet lag”).mp.
8. | or/1–7
9. | “randomized controlled trial$”.mp.
10. | “controlled clinical trial$”.mp.
11. | “random allocation”.mp.
12. | (“double blind” adj3 method$).mp.
13. | (“single blind” adj3 method$).mp.
14. | (clin$ adj25 trial$).mp.
15. | ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
16. | placebo$.ti,ab.
17. | random$.ti,ab.
18. | “research design$”.mp.
19. | “clinical research”.mp.
20. | or/9–19
21. | animal/
22. | 20 not 21
23. | 8 and 22

Table A-10 HealthSTAR/Ovid Healthstar - Ovid Version: rel9.1.0

1975 to August 2004
Searched September 15, 2004
1. | insomni$.mp.
2. | exp “Sleep Initiation and Maintenance Disorders”/
3. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
4. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
5. | dims.mp.
6. | (disorder$ adj initiating adj2 maintaining adj sleep).mp.
7. | (early adj2 awaken$).mp.
8. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
9. | or/1–8
10. | “analytic stud$”.mp.
11. | exp case-control studies/ or exp retrospective studies/
12. | exp cohort studies/ or exp longitudinal studies/ or exp follow-up studies/ or exp prospective studies/ or comparative study/ or exp Evaluation Studies/
13. | exp Cross-Sectional Studies/
14. | exp RISK FACTORS/ or exp RISK/ or exp RISK ASSESSMENT/
15. | exp Odds Ratio/
16. | exp CAUSALITY/
17. | exp Logistic Models/
18. | exp epidemiologic factors/ or exp age factors/ or exp “bias (epidemiology)”/ or exp comorbidity/ or exp “confounding factors (epidemiology)”/ or exp “effect modifiers (epidemiology)”/ or exp observer variation/ or exp reproductive history/ or exp sex factors/
| 19. exp morbidity/ or exp incidence/ or exp prevalence/.
19. | (cohort or observational or correlational or non-experimental or “non experimental” or nonexperimental or control$ or prospectiv$ or volunteer$ or “case series” or “case-series” or “case comparison” or “case-comparison” or “case referent” or “case-referent” or “cross sectional” or “cross-sectional” or risk or “relative risk” or causation or causal$ or “odds ratio$” or etiol$ or aetiol$ or incidence).mp.
20. | exp prognosis/ or exp medical futility/ or exp treatment outcome/
21. | exp mortality/ or exp “cause of death”/ or exp fatal outcome/ or exp survival rate/
22. | exp survival analysis/ or exp disease-free survival/
23. | exp disease susceptibility/ or exp genetic predisposition to disease/
24. | exp disease progression/ or exp “Severity of Illness Index”/
25. | exp Time Factors/
26. | exp RECURRENCE/
27. | (“natural history” or “inception cohort” or predict$ or prognos$ or outcome$ or course).mp.
28. | exp “costs and cost analysis”/ or exp “cost allocation”/ or exp cost-benefit analysis/ or exp “cost control”/ or exp “cost savings”/ or exp “cost of illness”/ or exp “cost sharing”/ or exp “deductibles and coinsurance”/ or exp health care costs/ or exp direct service costs/ or exp drug costs/ or exp employer health costs/ or exp hospital costs/ or exp health expenditures/ or exp capital expenditures/
29. | exp “Quality of Life”/ or exp “Activities of Daily Living”/
30. | exp “OUTCOME ASSESSMENT (HEALTH CARE)”/ or exp “OUTCOME AND PROCESS ASSESSMENT (HEALTH CARE)”/ or exp Health Status Indicators/ or exp Health Status/ or exp Questionnaires/
31. | (cost$ or economic or social or “quality of life” or “life quality” or hrql or well-being or wellbeing or “well being” or “outcome adj assessment$” or “health status”).mp.
32. | (et or pc or ae or ep or to or ge or ec or in or ut or mo).fs.
33. | or/10–33
34. | animal/ not human/
35. | 34 not 35
36. | 9 and 36
37. | eng.la.
38. | 37 and 38

Table A-11 EBM Reviews - Cochrane Database of Systematic Reviews (2^nd^ Quarter 2004); ACP Journal Club (1991 to March/April 2004); Database of Abstracts of Reviews of Effects (2^nd^ Quarter 2004) - Ovid Version: rel9.1.0

Searched September 15, 2004
1. | insomni$.ti,ab.
2. | (sleep adj initiation adj2 maintenance adj disorder$).mp.
3. | (sleep adj onset adj3 (delay$ or latenc$)).mp.
4. | (early adj2 awaken$).mp.
5. | (sleeplessness or agrypnia$ or hyposomnia$).mp.
6. | or/1–5

Table A-12 Science Citation Index Expanded™ - 1945-September 2004 - ISI Web of Knowledge

Searched September 17, 2004
□ #8 | #7 NOT #5
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004
□ #7 | #6 AND #3
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004
□ #6 | TS=Analytic Stud* OR TS=Case Control Stud* OR TS=Case-Control Stud* OR TS=Retrospective Stud* OR TS=Cohort OR TS=Longitudinal OR TS=Follow-up Stud* OR TS=Follow up Stud* OR TS=Prospective Stud* OR TS=Comparative Stud* OR TS=Evaluation Stud* OR TS=Cross Sectional Stud* OR TS=Cross-sectional Stud* OR TS=Observational Stud* OR TS=Questionnaire*
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004
□ #5 | #4 AND #3
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004
□ #4 | TS=Random* OR TS=Placebo* OR TS=Randomized Controlled Trial* OR TS=Controlled Clinical Trial* OR TS=Clinical Trial* OR TS=Double Blind Method* OR TS=Single Blind Method*
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004
□ #3 | #2 OR #1
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004
□ #2 | TS=Sleeplessness OR TS=Agrypnia* OR TS=Hyposomnia*
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004
□ #1 | TS=Insomni*
| DocType=All document types; Language=All languages; Database=SCI-EXPANDED; Timespan=1945-2004

Table A-13 Biological Abstracts - WebSPIRS from SilverPlatter, Version 4.3

Searched September 17, 2004
1. | #1 insomni* or sleeplessness or agrypnia* or hyposomnia*
2. | #2 analytic stud* or case control stud* or case-control stud* or retrospective stud* or cohort or longitudinal or follow up stud* or follow-up stud* or prospective stud* or comparative stud* or evaluation stud* or cross sectional stud* or cross-sectional stud* or observational stud* or questionnaire*
3. | #3 #1 and #2
4. | #4 random* or placebo* or randomized controlled trial* or controlled clinical trial* or clinical trial* or double blind method* or single blind method
5. | #5 #1 and #4

Table A-14 Cochrane Complementary Medicine Field Registry - Reference Web Poster 2001; ISI ResearchSoft

Searched September 20, 2004
1. | Insomni or sleeplessness or agrypnia or hyposomnia

Table A-15 CAB Abstracts - WebSPIRS from SilverPlatter, Version 4.3

Searched September 18, 2004
1. | Insomni* or agrypnia* or hypsomnia* or sleeplessness
2. | Clinical trial* or randomized controlled trial* or random* or cohort or retrospective or prospective or volunteer* or questionnaire*

Table A-16 SIGLE - FIZ Karlsruhe - Version Interhost 3000

Searched September 18, 2004
1. | Insomnia or sleeplessness

Table A-17 OCLC Proceedings First - OCLC FirstSearch

Searched September 18, 2004
1. | Insomnia or insomniacs

Table A-18 Dissertation Abstracts - ProQuest

Searched September 18, 2004
1. | Insomnia

Table A-19 Alt HealthWatch - EBSCOhost

Searched September 18, 2004
1. | Insomnia or insomnia - alternative treatment

Table A-20 NLM Gateway

Searched September 18, 2004
1. | Searched for insomnia under Meeting Abstracts

Table A-21 PubMed^®^

Searched September 20, 2004
1. | A search was conducted for the period of Jan. 01, 2004, to Sept. 20, 2004 for “Sleep Initiation and Maintenance Disorders” [MeSH]