# List of Excluded Studies

Aitken M, Taylor JA. Prevalence of clinical sinusitis in young children followed up by primary care pediatricians. Arch Pediatr Adolesc Med. Mar. 1998;152(3):244-8. Observational cohort study. [pmid: 9529461].
Casillas JL, Rico G, Rodriguez Parga D, et al. Multicenter evaluation of the efficacy and safety of gatifloxacin in Mexican adult outpatients with respiratory tract infections. Adv Ther. Nov-Dec. 2000;17(6):263-71. Non-comparative study. [pmid: 11317829].
Dowzicky M, Nadler H, Dorr MB, et al. Comparison of the in vitro activity of and pathogen responses to sparfloxacin with those of other agents in the treatment of respiratory tract, urinary tract, and skin and skin-structure infections. Clin Ther. May. 1999;21(5):790-805. ; discussion 789.Non-comparative study. [pmid: 10397375].
Ficnar B, Huzjak N, Oreskovic K, et al. Azithromycin: 3-day versus 5-day course in the treatment of respiratory tract infections in children. Croatian Azithromycin Study Group. J Chemother. Feb. 1997;9(1):38-43. Mixed population. [pmid: 9106016].
Fogarty CM, Kohno S, Buchanan P, et al. Community-acquired respiratory tract infections caused by resistant pneumococci: clinical and bacteriological efficacy of the ketolide telithromycin. J Antimicrob Chemother. Apr. 2003;51(4):947-55. Mixed population. [pmid: 12654763].
Kaiser L, Morabia A, Stalder H, et al. Role of nasopharyngeal culture in antibiotic prescription for patients with common cold or acute sinusitis. Eur J Clin Microbiol Infect Dis. 1920;(7):445-51. Mixed population.
Kakish KS, Mahafza T, Batieha A, et al. Clinical sinusitis in children attending primary care centers. Pediatric Infectious Disease Journal. 2000;19(11):1071-4. Observational cohort study. [pmid: 11099088].
Kroslak M. Efficacy and acceptability of fusafungine, a local treatment for both nose and throat infections, in adult patients with upper respiratory tract infections. Curr Med Res Opin. 2002;18(4):194-200. Mixed population. [pmid: 12201619].
Lauvau DV, Verbist L. An open, multicentre, comparative study of the efficacy and safety of azithromycin and co-amoxiclav in the treatment of upper and lower respiratory tract infections in children. The Paediatric Azithromycin Study Group. J Int Med Res. Sep-Oct. 1997;25(5):285-95. Not sinusitis. [pmid: 9364291].
Lindbaek M, Hjortdahl P. Predictors of duration of acute sinusitis episodes treated with antibiotics. Scand J Prim Health Care. Mar. 1998;16(1):24-9. Cohort study. [pmid: 9612875].
Ludwig E. Cefixime in the treatment of respiratory and urinary tract infections. Chemotherapy. Sep. 1998;44 Suppl 1:31-4. Mixed population, non-comparative study. [pmid: 9797422].
Medeiros EA. Treatment of adults with community-acquired respiratory tract infections: results of a multicentric clinical trial with gatifloxacin. Braz J Infect Dis. Aug. 2002;6(4):149-56. Non-comparative study. [pmid: 12204181].
Mira E, Benazzo M. A multicenter study on the clinical efficacy and safety of roxithromycin in the treatment of ear-nose-throat infections: comparison with amoxicillin/clavulanic acid. J Chemother. Dec. 2001;13(6):621-7. Mixed population. [pmid: 11806623].
Mosges R, Spaeth J, Berger K, et al. Topical treatment of rhinosinusitis with fusafungine nasal spray. A double-blind, placebo-controlled, parallel-group study in 20 patients. Arzneimittel-Forschung. 2002;52(12):877-83. Not sinusitis. [pmid: 12572527].
Ng DK, Chow PY, Leung L, et al. A randomized controlled trial of azithromycin and amoxicillin/clavulanate in the management of subacute childhood rhinosinusitis. J Paediatr Child Health. Aug. 2000;36(4):378-81. Chronic sinusitis. [pmid: 10940175].
Nicholson SC, High KP, Gothelf S, et al. Gatifloxacin in community-based treatment of acute respiratory tract infections in the elderly. Diagn Microbiol Infect Dis. Sep. 2002;44(1):109-16. Non-comparative study. [pmid: 12376040].